# Introduction

## Background

The use of psychotropic medications, including antipsychotics, in children, adolescents, and young adults has risen over the past 20 years,^1–5^ and use of antipsychotics in children with public health insurance^2^ and living in foster homes^4^ is greater than in those with private health insurance in the United States. During 2010, the percentages of young people filling prescriptions for antipsychotics in the United States was 0.11 percent (younger children), 0.8 percent (older children) 1.19 percent (adolescents), and 0.84 percent (young adults).^5^ Annual sales of the newer class (“second generation”) of antipsychotics (see below) in 2010 were $16.1 billion, growing by $1.4 billion since the previous year.^6^ This drug class had also become the most costly within the Medicaid program, far exceeding the costs of any other drug class.^7^

Antipsychotic medications are commonly categorized into two classes. First-generation antipsychotics (FGAs) were developed in the 1950s, while second-generation antipsychotics (SGAs) emerged in the 1980s. Each class is considered to have a distinct side-effect profile, although there is considerable overlap between them. FGAs are mainly associated with dry mouth, sedation, and extrapyramidal symptoms, which are movement disorders characterized by repetitive, involuntary muscle movements, restlessness, or an inability to initiate movement. Neuroleptic malignant syndrome is a rare but serious adverse effect. In the United States there has been a near disappearance of the use of FGAs over the last two decades.^8^ A shift towards SGAs was partly driven by the lower risk of extrapyramidal symptoms with their use, and other adverse events caused by the persistent dopamine receptor blockade by FGAs. The pharmacology of SGAs is diverse (based on action at several types of receptors) with associated heterogeneity in effects and harms; nevertheless, this class is thought as more prone than FGAs to adverse effects such as weight gain, elevated lipid and prolactin levels, and development of metabolic syndrome.^9–11^ This risk profile has led to great concern, because of the known associations between weight gain and obesity with diabetes, dyslipidemia, and hypertension, all of which are leading risk factors for future cardiovascular morbidity and mortality.^12^ This risk profile necessitates safety monitoring and prescription choices based on benefit-risk assessments.

For most FGAs and SGAs, the U.S. Food and Drug Administration (FDA)–approved indications for children (≤ 18 years of age) are restricted to the treatment of schizophrenia and bipolar mania. Other pediatric indications approved by the FDA include treatment of irritability associated with autism in children 5 years or older (risperidone in 2006 and aripiprazole in 2009) and of Tourette’s syndrome in children aged 6–18 (aripiprazole in 2014) or over 8 years (pimozide). Off-label use of antipsychotics is common in children and adults.^13^ Twenty-four to 31 percent of antipsychotic-treated children have attention deficit hyperactivity disorder (ADHD),^1,14^ and 34.5 percent of antipsychotic-treated young adults have depression.^5^ In Medicaid-enrolled children, ADHD accounted for 50 percent of total antipsychotic use in 2007, and ADHD together with mood disorders not otherwise specified were the most common uses (32% and 37.2%, respectively) for antipsychotics in a sample of Medicaid-insured children in Vermont during 2012.^13^ In these cases or other conditions such as conduct disorders or depression, antipsychotics are usually given for adjunctive treatment of severe behavioral symptoms (e.g., aggression), rather than for psychoses.^5,7^ They may also be prescribed for mood instability or relatively minor symptomatology (e.g., insomnia) of a condition, or even outside the context of a condition;^13^ these uses are accompanied by considerable controversy because of concerns regarding the balance of benefits and harms. This is particularly relevant when other treatment options exist for many conditions; for instance, fewer than half of very young, privately insured children taking antipsychotics received formal mental health services in 2007.^1^

Because of the marked increase in FDA-approved and off-label use of antipsychotics, prescribing practices have been under ongoing scrutiny (including use of prior authorization by Medicaid in many U.S. States),^15^ and there is a need for ongoing investigation into the comparative effectiveness and harms of available medications. Practice parameters for antipsychotic use produced by the American Academy of Child and Adolescent Psychiatry (AACAP) are referred to when assessing practice for pediatrics in the United States,^16^ but these parameters may be considered outdated (all studies cited in the parameters were published prior to 2012) for providing the best evidence. This Comparative Effectiveness Review (CER) covers many psychiatric conditions, as well as behavioral issues, for which antipsychotics are being prescribed as mono- or adjunctive therapy, such that a diverse range of stakeholders can be provided with evidence on the relative benefits and harms of antipsychotics to make informed decisions.

### Use of Antipsychotics

The following sections describe the main features and uses of antipsychotics in the conditions covered by this CER.

#### Schizophrenia and Schizophrenia-Related Psychosis

Schizophrenia and schizophrenia-related psychosis are grouped together because psychotic symptoms are prominent features of both conditions. The category includes schizophrenia, schizoaffective disorder, substance/medication-induced psychotic disorder, or prodromal phase (ultra high-risk). Schizophrenia and related psychoses are uncommon in preadolescent children; the prevalence of childhood-onset schizophrenia is approximately 1 in 40,000.^17^ In adolescents, the prevalence is estimated to be 0.1 percent, and about twice as many boys are affected as girls.^18^ The onset of the condition is usually insidious, with symptoms gradually becoming apparent over an extended period of time. Typically, psychotic symptoms are classed as either being positive (e.g., hallucinations or delusions) or negative (e.g., anhedonia or lack of motivation). Treatment of psychotic disorders or psychotic features includes long-term use of antipsychotic medications.

#### Bipolar Disorder

Bipolar disorder is characterized by unstable mood. There are several types of bipolar disorder: bipolar type I (manic episodes and depressive episodes occur independently), bipolar type II (hypomanic episodes and depressive episodes occur independently), cyclothymic disorder (episodes not meeting criteria for bipolar I or II), and (most prevalent) other or unspecific bipolar disorder (not meeting criteria for mania or hypomanic episodes in duration).^19^ The latter disorder appears to be the most prevalent (3% of children in the community); Bipolar I and bipolar II disorders are less common (approximately 1% and 0.5% prevalence, respectively) but are associated with higher morbidity.^20^ Children with bipolar disorders of any type often have multiple co-occurring mental health problems. Antipsychotics may be used as the first-line medication, primarily for mania, even when psychosis is not present.

#### Autism Spectrum Disorders

Autism spectrum disorders (ASD) include autism, pervasive developmental disorders, Asperger’s disorder, and pervasive developmental disorders not otherwise specified.^19^ These disorders are characterized by: 1) deficits in social communication and social interaction and 2) restricted repetitive patterns of behavior, interests, and activities. The median prevalence of childhood autistic spectrum disorders (e.g., autism, Asperger’s disorder, pervasive developmental disorders not otherwise specified) across many studies is 13 in 10,000.^21, 22^ The U.S. National Health Interview Survey data indicated a prevalence of 1 in 88 children and nearly a four-fold increase in autism from 1997–1999 to 2006–2008.^23^ This rising trend may be due to broadening diagnostic criteria, better ascertainment, and/or increased incidence.^24^ Antipsychotics have been used to manage irritability or aggressive outbursts, reduce hyperactivity or repetitive behaviors, or promote sleep onset and continuity.^25^

#### Attention Deficit Hyperactivity Disorder and Disruptive, Impulse-Control, and Conduct Disorders

Attention deficit hyperactivity disorder (ADHD) and disruptive, impulse-control, and conduct disorders are so named because the core symptoms disrupt the daily functioning of children and their families. These disorders are the most common reason for presentation to child psychiatry clinics. Based on parent reports of healthcare provider diagnosis, the 2011/12 U.S. National Survey of Children’s Health estimates that 11 percent of school-aged children have received a diagnosis of ADHD; this represents a 42 percent increase from 2003.^26^ Smaller prevalence estimates (4.6% in 2007) have been reported for oppositional defiant disorder; the prevalence of conduct disorder may be slightly lower.^27^ The rates of disorder vary by age and sex, but the most marked difference is the 6 to 1 ratio of boys to girls with ADHD prior to puberty. Antipsychotics may be used to manage impulsive aggression and other conduct problems; they may also be used to reduce hyperactivity or help regulate negative emotions, or (in small doses) to promote somnolence (an intended side effect), as many people with ADHD have sleep disturbance.

#### Obsessive-Compulsive Disorder

Obsessive-compulsive disorder (OCD) is a chronic condition characterized by obsessions (repetitive thoughts) or compulsions (repetitive behaviors) that cause distress and/or interfere with functioning. More than 90 percent of lifetime OCD diagnoses met the criteria for another psychiatric disorder including anxiety disorders (75.8%), followed by mood disorders (63.3%), impulse-control disorders (55.9%), and substance abuse disorders (38.6%).^28^ Because of failure for many patients in response to first-line treatment with antidepressants and other therapies, treatment is often augmented with antipsychotics.^29^

#### Substance Use Disorder

The essential feature of a substance use disorder is a cluster of cognitive, behavioral, and physiological symptoms indicating that the individual continues using the substance despite significant substance-related problems.^19^ Dopamine-related behaviors, including impulsivity, aggression, and sensation seeking, have been shown to limit effectiveness of intensive outpatient therapies. Because of their blockade of dopamine transmission, antipsychotics may be used to reduce the reinforcing properties of certain substances (e.g., cocaine and psychostimulants).^30^ The use of antipsychotics in other cases, such as for alcohol use disorders, may in part rely on the dopamine-enhancing properties of some of these medications.^31^

#### Major and Persistent Depressive Disorders, and Disruptive Mood Dysregulation Disorder

Of the depressive disorders, major depressive disorder (MDD) represents the classic condition. It is characterized by discrete episodes of at least 2 weeks duration, involving changes in affect, cognition, and neurovegetative functions (i.e., sleep, appetite). Persistent depressive disorder requires symptoms of at least one year (two in adults). To address concerns about potential overdiagnosis and overtreatment of bipolar disorder in children, a new diagnosis, disruptive mood dysregulation disorder, is included for children up to age 18 years who exhibit persistent irritability and frequent episodes of extreme behavioral dyscontrol.^19^ Antipsychotics are often used as adjunctive therapy for depressive disorders (i.e., aripiprazole, quetiapine, and olanzapine are indicated for treatment for major depression in adults), and have been shown to result in improvements in core symptoms of the condition for adults.^32^

#### Anxiety Disorders

Anxiety may occur in the course of another condition (e.g., bipolar, posttraumatic stress, OCD), but there are also several primary anxiety disorders (DSM-V does not classify OCD or posttraumatic stress disorder [PTSD] as anxiety disorders).^19^ Prevalence rates of anxiety disorders (excluding rates for OCD and PTSD) in adolescence and in 18 to 29 year olds are substantial (21–25% from the National Comorbidity Surveys). When onset is before adolescence, some disorders such as separation anxiety are more common; despite this, generalized anxiety disorder occurs in children and has a 12-month prevalence of 0.9 percent in the United States.^19^ The median age of onset of anxiety disorders in children has been reported to be six years of age. Apart from anxiety symptoms, irritability and sleep disturbances are examples of symptoms which may be treated with antipsychotics.^33^

#### Posttraumatic Stress Disorder

Posttraumatic stress disorder develops following a reaction of intense fear, helplessness, or horror resulting from a traumatic event.^34, 35^ Symptoms of PTSD include a persistent re-experience of the traumatic event (i.e., intrusions, flashbacks), persistent avoidance of stimuli associated with the trauma, numbing of general responsiveness, and persistent symptoms of increased arousal.^19^ Individuals with PTSD may also experience psychotic symptoms such as paranoia, agitation, and delusional beliefs.^36^ Median age of onset for a representative sample of adults in the United States’ National Comorbidity Surveys was 23 years.^37^ A national sample of adolescents (12–17 years old) indicated that 3.7 percent of male and 6.3 percent of female adolescents met full diagnostic criteria for PTSD.^38^ Antipsychotics have been studied for use as monotherapy or adjunctive treatment (with antidepressants) for various symptoms in adults with PTSD.^39, 40^

#### Eating Disorders

Eating disorders are characterized by a persistent disturbance of eating or eating-related behavior that results in the altered consumption or absorption of food and that significantly impairs physical health or psychosocial functioning.^19^ The prevalence of anorexia is reported to be approximately 0.13 percent in females aged 15 to 20. In males, it is approximately one-tenth of that.^19^ The incidence of anorexia nervosa appears to have increased in recent decades.

SGAs have been prescribed off-label as an adjunctive to treatment for agitation, anxiety and ruminations.^41^ Use may also reflect an attempt to promote weight gain in boys and girls who are underweight as a result of their disorder.

#### Tic Disorders

Tics are involuntary motor movements or vocalizations. Although some individuals have only motor or verbal tics, those with Tourette’s syndrome have both types. The U.S. prevalence was estimated in 2007 at 0.3 percent of children aged 6–17, with two times as many boys affected as girls.^23^ For a diagnosis of Tourette syndrome, the onset of symptoms must occur before age 18. In most cases, Tourette’s syndrome is associated with co-morbid neuropsychiatric disorders—most commonly OCD or ADHD.^23, 42^ Medications that inhibit dopamine reuptake, such as antipsychotics, generally help to reduce tics, but may induce tics in some cases. Antipsychotics may also have a beneficial impact on comorbid conditions.

## Objectives

In February 2012, the Agency of Healthcare Research and Quality (AHRQ) published the results of Comparative Effectiveness Review (CER) No. 39, “First- and Second-Generation Antipsychotics for Children and Young Adults,” prepared by the University of Alberta Evidence-based Practice Center (EPC).^43^ CER No. 39 examined evidence on benefits and harms for comparisons within and between classes of FGAs and SGAs across a broad range of conditions. The only findings having a moderate strength of evidence included: (1) olanzapine caused more dyslipidemia and weight gain, but fewer prolactin-related events, than risperidone, (2) olanzapine caused more weight gain than quetiapine, and (3) compared with placebo, SGAs improved clinical global impressions (schizophrenia, bipolar, and ADHD/disruptive behavior disorders) and diminished positive and negative symptoms (schizophrenia), behavior symptoms (disruptive behavior disorders), and tics (Tourette syndrome). The large majority of comparisons between and within classes of antipsychotics offered low or insufficient evidence about comparative effectiveness or harms.

Due to the popularity, potential impact, and use in clinical practice guidelines of reviews on this topic, in August, 2014, AHRQ’s Comparative Effectiveness Review Surveillance Program^44^ assessed the need for CER No. 39 to be updated. Many of the newer studies identified had the potential to change several of the conclusions in the review, or add results for conditions (e.g., eating disorders) and antipsychotics not previously studied (e.g., lurasidone, asenapine). The scope of this review is quite similar to CER No. 39, with key changes being the addition of (1) three newly approved SGAs (i.e., brexpiprazole, asenapine, lurasidone) and the previously discontinued FGA molindone, (2) some conditions of interest (i.e., anxiety, depression, substance use), and (3) modification to some key outcomes to be more specific to symptoms targeted by clinicians when prescribing antipsychotics. A detailed explanation of all changes made for this systematic review is included in Appendix A.

The purpose of this systematic review is to provide a comprehensive synthesis of the evidence examining the benefits and harms associated with the use of FDA-approved FGAs and SGAs in children, adolescents, and young adults ≤24 years of age. The findings from this update will be useful for multiple stakeholders, and inform efforts by professional societies to develop evidence-based recommendations and clinical practice guidelines to guide appropriate use in practice.

## Scope of Review and Key Questions

### Conditions of Interest

- Schizophrenia and schizophrenia-related psychoses, including schizoaffective disorder and substance/medication-induced psychotic disorder, and prodromic (ultra high-risk) psychosis.
- Autism spectrum disorders, including pervasive developmental disorder, autism, Rett’s disorder, childhood disintegrative disorder, Asperger’s disorder, and pervasive developmental disorder not otherwise specified.
- Bipolar disorder.
- Attention deficit hyperactivity disorder, or disruptive, impulse-control, and conduct disorders, including conduct disorder, oppositional defiant disorder, intermittent explosive disorder, and other specified/unspecified disruptive, impulse-control, or conduct disorders.
- Obsessive-compulsive disorder.
- Substance use disorder.
- Major and persistent depressive disorders, or disruptive mood dysregulation disorder.
- Anxiety disorders.
- Posttraumatic stress disorder.
- Eating disorders (i.e., anorexia nervosa, bulimia nervosa, binge-eating disorder).
- Tic disorders (e.g., Tourette’s syndrome).
- Behavioral issues outside the context of a mental disorder, including aggression, agitation, anxiety, behavioral dyscontrol, irritability, mood lability, self-injurious behaviors, and insomnia.

### Key Questions

#### For Each Condition of Interest

Key Question 1 What are the benefits, in terms of intermediate and effectiveness outcomes, of first and second generation antipsychotics—at the level of individual antipsychotics and across each class—in comparisons with placebo, different doses of the same antipsychotic, or different antipsychotics in children and young adults (≤24 years)?
  a. Do the benefits vary with respect to patient characteristics, such as age, sex, race/ethnicity, medical comorbidities, phase or features of disorder, and antipsychotic treatment history?
  b. Do the benefits vary with respect to clinical characteristics such as dose of antipsychotic or cotreatments including other antipsychotics, other medications, or nonpharmacologic therapy?

#### Across All Conditions

Key Question 2 Across all conditions of interest, what are the harms of first and second generation antipsychotics—at the level of individual antipsychotics and across each class—in comparisons with placebo, different doses of the same antipsychotic, or different antipsychotics in children and young adults (≤24 years)?
  a. Do the harms vary with respect to patient characteristics, such as age, sex, race/ethnicity, diagnosis, medical comorbidities, phase of disorder, and prior exposure to antipsychotics?
  b. Do the harms vary with respect to clinical characteristics such as dose of antipsychotic or cotreatments including other antipsychotics, other medications, or nonpharmacologic therapy?

## Analytic Framework

Figure 1 is an analytic framework that depicts the structure used to address the Key Questions (KQs) for evaluating the benefits and harms of FGAs and SGAs in children and young adults (≤24 years of age). We examined the benefits and harms of FDA-approved FGAs and SGAs in a population of children and young adults (≤ 24 years) diagnosed with one of the psychiatric conditions identified, or experiencing behavioral issues outside the context of a psychiatric diagnosis (e.g., sleep difficulties, agitation, aggression). In KQ1, benefit was determined (by condition) for intermediate outcomes (e.g., short-term disorder-specific and nonspecific symptoms, short-term medication adherence, lifestyle behaviors), and effectiveness outcomes (e.g., long-term symptoms, growth and maturation, health status and quality of life, caregiver burden/strain). In KQ2, we assessed harms across conditions in terms of medication-associated adverse effects categorized as major (e.g., mortality, development of diabetes) and general (e.g., extrapyramidal effects, weight gain, hyperprolactinemia). Within each KQ, we assessed outcomes for subgroups of patients or studies based on patient and clinical/treatment characteristics.

Figure 1 Analytic framework for the Key Questions evaluating the comparative effectiveness of FDA-approved first- and second-generation antipsychotics in children and young adults 24 years old and under

FDA = Food and Drug Administration; KQ = Key Question

Figure 1 displays an analytical framework for the key questions evaluating the comparative effectiveness of FDA-approved FGAs and SGAs in children and young adults ≤24 years old diagnosed with included disorders or behaviour issues outside of the context of a disorder. The figure displays a high level description of the information and outcomes collected for each key question covering KQ1a and KQ2a: patient characteristics (sex, age, race/ethnicity, comorbidities/co-conditions, phase and features of disorder, and history of treatment); KQ1b and 2b: clinical characteristics (cotreatments, medication dose); KQ2: harms (any adverse effects, any adverse effect limiting treatment, major adverse effects, major adverse effects limiting treatment, specific adverse effects (major and general)); KQ1: intermediate outcomes for <6 month follow up (short-term disorder-specific (core) and nonspecific symptoms (e.g. response rates combining symptoms), medication adherence, short-term global impressions, short-term school performance and attendance, short-term legal or justice system interaction (e.g. arrests, detention), lifestyle behaviours (i.e. changes to diet or physical activity, substance use), and effectiveness outcomes for ≥6 month follow up (long-term disorder specific and nonspecific symptoms, long-term global impressions, growth and maturation, cognitive and emotional development and functioning, suicide-related behaviours and death by suicide, long-term school performance and attendance, health status and quality of life (e.g. patient and family functional, health-related quality of life, quality of life, well-being instruments using validated instruments), caregiver burden/strain, long-term legal or justice system interaction, and health care system utilization).

## Organization of This Report

The remainder of the report describes our methods in detail and presents the results of our synthesis of the evidence with key points, detailed syntheses, and our assessment of the strength of evidence for our key outcomes. The first part of the results, evaluating benefit outcomes, is organized by condition; the second part focuses on harms with findings reported across all conditions. The results are divided to specifically address the different types of comparisons of interest (as possible depending on data): aggregate (across class) data for FGAs versus SGAs, within-class comparisons between individual FGAs and individual SGAs (other drug or dose), and then aggregate and individual data for FGAs versus placebo, and SGAs versus placebo. The discussion section offers our conclusions, summarizes our findings, and provides other information relevant to the interpretation of this work for clinical practice and future research. References and a list of abbreviations and acronyms follow the discussion section.

The report includes a number of appendices to provide further detail on our methods, the studies assessed, the quality assessments for individual studies, and findings not presented in the main body of the report. The appendixes are as follows:

- Appendix A: Changes From Original Review
- Appendix B: Literature Search Strategies
- Appendix C: Quality Assessment Ratings
- Appendix D: Study Characteristics
- Appendix E: Associated Publications
- Appendix F: Excluded Studies
- Appendix G: Analytical Models and Code, and Additional Results for Key Question 2 From Network Meta-Analysis and for General Adverse Effects