# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Nathan Blum, M.D.
  Chief, Division of Developmental and Behavioral Pediatrics
  The Children’s Hospital of Philadelphia
  Professor of Pediatrics, Pereleman School of Medicine at the University of Pennsylvania
  Philadelphia, PA
- Rongwei (Rochelle) Fu, Ph.D.
  Professor of Biostatistics
  School of Public Health
  Oregon Health & Science University
  Portland, OR
- Renee Hilliard, Pharm.D., C.G.P.
  Pharmacist, Policy, Quality and Clinical Pharm.D.
  Centers for Medicare & Medicaid Services
  Baltimore, MD