# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Oscar G. Bukstein, M.D., M.P.H.^*^
  Vice-Chair, Department of Psychiatry
  Boston Children’s Hospital
  Boston, MA
- Jana Davidson, M.D., FRCPC^*^
  Psychiatrist-in-Chief, B.C. Children’s Hospital, PHSA
  Clinical Professor, Psychiatry
  Head, Division of Child & Adolescent Psychiatry
  University of British Columbia
  Vancouver, BC, Canada
- Tiffany Farchione, M.D.^*^
  Deputy Director, Division of Psychiatry Products
  Food and Drug Administration/CDER
  Silver Spring, MD
- Christopher Fonnesbeck, Ph.D.^*^
  Assistant Professor of Biostatistics, Vanderbilt University
  Vanderbilt Evidence-based Practice Center
  Nashville, TN
- Charissa Fotinos, M.D., M.Sc.^*^
  Deputy Chief Medical Officer, Washington State Healthcare Authority
  Seattle, WA
- Michael Naylor, M.D.
  Director, Behavioral Health and Welfare Program
  Director, Comprehensive Assessment and Response Training System
  Director, Clinical Services in Psychopharmacology, Institute for Juvenile Research
  Associate Professor of Psychiatry, Clinical Teaching Track
  Department of Psychiatry, University of Illinois at Chicago
  Chicago, IL
- Benedetto Vitiello, M.D.^*^
  Chief, Treatment and Prevention Intervention Branch
  Division of Services and Intervention Research
  National Institute of Mental Health
  Bethesda, MD

* Provided input on draft report.