# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Oscar G. Bukstein, M.D., M.P.H.
  Vice-Chair, Department of Psychiatry
  Boston Children’s Hospital
  Boston, MA
- Christoph U. Correll, M.D.
  Medical Director, Recognition and Prevention Program (RAP)
  Zucker Hillside Hospital
  Professor, Psychiatry and Molecular Medicine
  Hofstra North Shore-LIJ School of Medicine
  Investigator, Feinstein Institute for Medical Research
  Glen Oaks, NY
- Jana Davidson, M.D., FRCPC
  Psychiatrist-in-Chief, B.C. Children’s Hospital, PHSA
  Clinical Professor, Psychiatry
  Head, Division of Child & Adolescent Psychiatry
  University of British Columbia
  Vancouver, BC, Canada
- Gregory Gale, M.D.
  Medical Director, Behavioral Health
  LifeSynch-HUMANA
  Irving, TX
- Michael Naylor, M.D.
  Director, Behavioral Health and Welfare Program
  Director, Comprehensive Assessment and Response Training System
  Director, Clinical Services in Psychopharmacology, Institute for Juvenile Research
  Associate Professor of Psychiatry, Clinical Teaching Track
  University of Illinois at Chicago, Department of Psychiatry
  Chicago, IL
- Theresa Nguyen, L.S.W.
  Director of Policy and Programming
  Mental Health America
  Alexandria, VA