# Acknowledgments

We acknowledge with appreciation the staff at AHRQ, Laura Pincock and Christine Chang, for their efforts in helping us engage with Key Informants and the Technical Expert Panel for this review; they also provided constructive comments on our draft report. Additionally, we greatly value the time spent and excellent comments on our report by EPC Associate Editor Marian McDonagh.