# Discussion

## Key Findings for Intermediate and Effectiveness Outcomes Within Each Condition (Key Question 1)

The findings for key intermediate and effectiveness outcomes are summarized below. With the exception of studies examining schizophrenia, the evidence comparing FGAs with SGAs and antipsychotics within each class was limited. For most conditions, the majority of the findings focused on the comparison of SGAs versus placebo. Comparisons and outcomes for which the evidence was graded as insufficient (i.e., we had no confidence in the findings) are not discussed.

Schizophrenia and Related Psychosis. There appears to be little or no difference between FGAs and SGAs for negative symptoms, positive symptoms, response rates, and global impressions of illness severity. Between olanzapine and risperidone, there may be little or no difference for negative and positive symptoms, response rates, and global impressions of severity. Low (5 mg/day) and high (10 mg/day) doses of asenapine may not differ, or may differ little, in terms of response rates and illness severity. There is probably little or no difference between low- (400 mg/day) and high- (600/800 mg/day) dose quetiapine for clinician impressions of severity or global functioning, and may be little or no difference for negative symptom reduction or response rates. Compared with placebo, SGAs likely decrease negative and positive symptoms, increase response rates, and improve global impressions of improvement, severity, and functioning. The only outcome that seemed to result in a clinically meaningful benefit was response rates (RR, 1.52; 95% CrI, 1.15 to 2.02); the effect estimates for all other outcomes were of a small magnitude, which appears to be influenced by a substantial placebo effect in many cases. SGAs appear to make little or no difference for depression symptoms, suicide attempts, completed suicide, suicide ideations, or suicide behaviors in short-term studies. Studies of maintenance versus acute treatment, and of the prodrome phase of psychosis, did not contribute much heterogeneity to the results.

Bipolar Disorder. Most of the outcomes supported by low or higher SOE were for SGA versus placebo comparisons. One dose comparison offered low SOE to make some conclusions; a higher (10 mg/day) dose of asenapine may reduce manic symptoms slightly more than a lower (5 mg/day) dose, and the doses appear to offer little or no difference for global impressions of severity or for depression. SGAs probably reduced manic and depression symptoms, but the effect on mania was greater than for depression. SGAs likely increase response and remission rates for patients experiencing manic/mixed phases; clinical and statistical heterogeneity was introduced when including two RCTs examining quetiapine for patients with depressive episodes. SGAs probably improve slightly symptom severity and global functioning. For individual SGAs, the findings for aripiprazole were similar to those across all SGAs. Quetiapine likely reduces manic symptoms in patients experiencing manic/mixed episodes; however, it probably makes little or no difference for depression symptoms and appears to offer little or no difference response.

No different patterns from overall results for manic/mixed phases were found for patients with prodromal bipolar disorder or comorbid ADHD. Few studies examined subgroups of interest; however, concomitant use of psychostimulants does not seem to moderate effects for manic symptoms, and comorbid diagnosis of ADHD or a DICD may not affect results either for mania or depression.

For effectiveness outcomes, SGAs may make little or no difference for suicide ideations and attempts when compared with placebo.

Autism Spectrum Disorders. At least low SOE was only found for intermediate outcomes in comparisons between SGA and placebo. Insufficient SOE was found for all effectiveness outcomes and thus no conclusions could be drawn. SGAs likely improve: irritability, lethargy/social withdrawal, stereotypy, inappropriate speech, response rates, and global impressions of severity (all moderate SOE); they may increase global impressions of improvement. Only the results for irritability, response rates, and global symptom improvement reached a level that would likely be considered clinically meaningful. Maintenance treatment with an SGA appears to decrease remission rates.

Aripiprazole and risperidone showed similar effects for irritability and stereotypy (SOE reduced to low for risperidone), but conclusions were of little or no apparent difference for lethargy/social withdrawal and inappropriate speech, or unable to be drawn for other outcomes. The smaller sample sizes contributing to the evidence for each drug likely affected the ability to obtain a significant finding for most outcomes, with the exception of irritability which overall had the larger magnitude of effect.

ADHD and Disruptive, Impulse-Control, or Conduct Disorders (DICD). Most RCTs of ADHD and/or DICD examined acute phase treatment in patients either naïve to or not taking antipsychotics upon enrollment. RCTs varied in terms of whether concomitant stimulant use was permitted. All evidence graded as having at least low SOE was for outcomes between SGAs and placebo. SGAs, and risperidone alone, likely reduce conduct problems and aggression. Risperidone probably reduces hyperactivity, although our confidence in this finding is specific to studies of children having a primary diagnosis of DICD, or of patients with ADHD not responding to stimulants; a study^153^ of children responding to stimulants found no benefit for risperidone on hyperactivity. SGAs (and risperidone) may improve clinical severity in treatment of children with a primary diagnosis of DICD; risperidone may make little or no difference for illness severity when it is used to augment treatment with parent training and/or stimulants. There appears to be little or no difference between SGAs and placebo for global impression of improvement. Risperidone may make little or no difference to response rates when treating patients with primarily ADHD and aggression.

From between-study observations, risperidone may preferentially reduce illness severity, and increase global improvement ratings, for DICD compared with ADHD particularly when used for ADHD as adjunctive treatment. Our meta-analysis favored SGAs for hyperactivity, but this may relate best to children with DICD, or with ADHD and not responding to stimulants. Sensitivity analyses removing the small study^152^ enrolling children with a long-term history of response to risperidone did not affect the results. We did not find any evidence of a differential effect between studies having different inclusion criteria related to intellectual functioning.

Several studies examined outcomes from risperidone use in different subpopulations. Two RCTs found no difference based on age for the effects on aggression^156^ or risk of symptom recurrence,^157^ and another found no impact of comorbidities (including global developmental delay).^158^ Cotreatment with psychostimulants did not impact effects on conduct problems or on hyperactivity in two RCTs.^149, 151, 158^ Findings based on prior treatment history were conflicting.^154, 158^

Eating Disorders. No conclusions were able to be drawn for olanzapine or risperidone compared with placebo in terms of increased body weight (favorable for this condition) or reduced eating disorder symptomatology.

Tic Disorders. Tic severity may be reduced in patients receiving SGAs (aripiprazole, risperidone, and ziprasidone); SOE was low, however, the magnitude of the estimated effect reached clinical significance.^176^

Obsessive-Compulsive Disorder, Depression, and Behavioral Issues. Evidence was very limited and provided insufficient SOE on all outcomes in these conditions.

## Key Findings for Harms Across All Conditions (Key Question 2)

All Comparisons: Network Meta-Analyses for Body Composition Outcomes. These analyses differed from the main analyses of pair-wise comparisons by incorporating data from comparisons of antipsychotics with placebo/no treatment and between two different antipsychotics; because of this more studies contributed to the findings, although our results should be considered exploratory in nature due to the use (i.e., modelling) of direct and indirect comparisons. Most antipsychotics resulted in more weight gain compared with placebo, and not all SGAs appear to contribute to more weight gain than FGAs. Results for olanzapine clearly separated this SGA as more harmful than most other SGAs. For BMI, olanzapine and clozapine showed the most harm. Most studies in these analyses had short-term treatment durations, and some of the antipsychotics—particularly molindone, pimozide, chlorpromazine, and lurasidone—had few patients contributing data to the findings which resulted in wide credible intervals. Nevertheless, findings are quite consistent with those from the pair-wise/direct comparisons described.

FGAs Versus SGAs, other FGAs, or Placebo. There was insufficient SOE for all major AE outcomes between FGAs and SGAs, but some conclusions could be drawn for general AEs. SGAs may have a lower risk for any EPS symptoms, and FGAs probably cause less weight gain and increase in BMI. The class of antipsychotic may make little or no difference for sedation. There was insufficient evidence to draw any conclusions for FGAs versus FGAs, or for FGAs versus placebo.

SGAs Versus SGAs: Comparison of Different Drugs or Different Doses of SGAs. Aripiprazole appears to reduce the risk for development of diabetes compared with risperidone. One large retrospective review of a Medicaid database found that patients newly initiating antipsychotics were at higher risk for developing diabetes if taking aripiprazole (HR 7.72, 95% CI 3.70 to 16.12) compared with risperidone (HR 2.20, 95% CI 1.14 to 4.26).^193^ Another long-term study of various SGAs only had one incidence of diabetes in a patient taking clozapine.^102^

Risperidone probably causes slightly less weight gain (short-term) and BMI changes (short-and long-term) than olanzapine; similar findings were found for quetiapine versus olanzapine over the long-term, but not short-term where there may be little or no difference between the SGAs. Olanzapine and clozapine appear not to differ, or to differ little, for weight gain over short-term treatment. Probably little or no difference exists for changes in body composition between quetiapine and risperidone in the short-term (moderate SOE for BMI and ≥ 7% increase in weight), and there appears to be little or no difference for weight or BMI over the long-term. Quetiapine may reduce the risk for hyperprolactinemia compared with risperidone. There appears to be little or no difference between olanzapine and risperidone in risk for sedation.

Dose of asenapine probably makes little or no difference in risk for ≥7 percent weight gain or somnolence; and may make little or no difference for increase in BMI or risk for hyperprolactinemia (all short-term). High versus low doses of aripiprazole appears to make little or no difference for any EPS symptom, body composition, risk for high cholesterol or triglycerides, or for somnolence. There is probably little or no difference for ≥7 percent weight gain, somnolence, or sedation between high- and low-dose quetiapine. It may make little or no difference for risk of any EPS symptom or somnolence when treating with high or low doses of risperidone. All findings were for short-term treatment.

SGAs Versus Placebo. Moderate SOE showed that there is probably little or no difference in the short-term across all SGAs compared with placebo for mortality or prolonged QT interval. Patients newly initiated on SGAs may have a higher risk for developing type 2 diabetes than those not receiving this treatment over at least 1 year of treatment (HR 2.89, 95% CI 1.64 to 5.10).^193^

There is probably some degree of harm from SGAs for seven short-term general AEs: EPS symptoms, increase in body composition (weight, BMI, and ≥7% weight gain), and increased risk for hypertriglyceridemia, sedation, and somnolence. SGAs appear to increase risk for high total cholesterol, and make little to no difference in risk for akathisia. When looking at the effects from individual SGAs, rather than the class as a whole, aripiprazole, quetiapine, and risperidone likely increase weight gain slightly, olanzapine has a greater effect on weight gain, and ziprasidone may make little or no difference. Findings of little or no apparent difference between quetiapine and ziprasidone were shown for somnolence. The SOE was insufficient for all SGAs except aripiprazole (may increase risk) for any EPS symptoms.

Between- and Within Study Subgroup Effects. Bayesian univariate meta-regression analyses assessed the effect of mean age, percent male, proportion treatment naïve, and treatment duration on weight change, proportion gaining ≥ 7 percent weight, somnolence, and EPS symptoms. The only analysis with statistically significant findings was for treatment duration on weight change, with small increases in weight gain for longer treatment duration (0.43 kg per extra week). Observations based on diagnostic condition did not find any variability in effect; harms appeared to occur to a similar magnitude in different conditions regardless of the typical dose used.

Findings from 26 studies reporting subgroup analyses were often inconsistent on whether there are any moderating effects by various subgroup variables on harms. Body composition, fasting glucose, and prolactin elevations do not appear to differ in patients taking SGAs based on concurrent use of psychostimulants. Dose of SGAs—particularly when considering cumulative doses—appears to increase the risk for metabolic effects including increased glucose levels and development of diabetes. Risperidone appears to increase serum prolactin more in females than males; few studies reported on other subgroup variables.

## Applicability of Findings

Study populations seem moderately applicable to general practice in terms of age, gender and existence of common comorbid diagnoses (e.g., ADHD comorbidity within primary diagnosis of bipolar or tic disorders) within each condition category. Findings will not be as applicable for patients with complex clinical diagnoses, less-than-moderate symptom severity, and (with the exception of studies of clozapine in schizophrenia) a history of poor response to antipsychotics.

The mean age for all condition categories was over 8 years, therefore the evidence is not highly applicable to young children. The majority of the studies excluded young adults; therefore, the results may have limited applicability to this population. Young adults were included in approximately 25 percent of studies of schizophrenia, despite the natural history of schizophrenia which typically has its peak onset during these years. Although this population would be included in studies of adults, there are numerous unique issues associated with patients between the ages of 19 and 24, particularly because patients frequently lose access to services once they become legal adults at age 18. Many studies excluded patients with some comorbidities such as global developmental delay, psychosis, and substance abuse. Patients with a history of various adverse events, including tardive dyskinesia, suicide-related behaviors, neuroleptic malignant syndrome, or abnormal lab values, were often excluded. Additional restrictions that were commonly applied were use of adjunctive medications (e.g., mood stabilizers or antidepressants) and previous unresponsiveness to the study medication. Patients often needed to meet minimum criteria indicating at least moderate severity in symptomatology. In addition, several studies excluded patients who did not meet minimum response criteria or were nonadherent during the run-in period prior to the double-blind treatment phase. Because patients in clinical practice often have multiple diagnoses and undergo cotreatment with several drugs, these restrictions reduce the applicability of this body of evidence. Exclusion of patients with comorbidities, a history of various adverse events, and or less-than-moderate symptom severity may have overestimated estimates of efficacy and underestimated harms. Certainly the benefit-harm trade-offs in some patient populations would be different than those for the majority of patients in some studies.

Another factor restricting applicability is the short duration of followup. Adequate trials of antipsychotic treatment to assess response can be considered within 4 to 6 weeks,^16^ which supports applicability from the evaluated studies for these outcomes at least over the short term; nevertheless, issues impacting longterm treatment success, such as treatment compliance and resistance, were not accounted for in many studies. Data on most effectiveness outcomes were deficient, and few studies allowed for conclusions on major adverse effects―especially those often arising with longterm treatment (e.g., tardive dyskinesias, diabetes). Adverse effects may have been underestimated due to the short followup periods; not all effects are likely to become evident in all patients within the 1–2 month treatment phase commonly investigated.

Applicability may also be limited due to monitoring practices within the trial settings to ensure treatment adherence as well as perform dose adjustments based on response and tolerability assessments. In typical practice settings, it is likely that patients will have lower rates of medication adherence—and therefore less symptom improvement—and may have higher rates of AEs because of poor monitoring. Although comprehensive and individualized monitoring for AEs has been recommended for several years,^14,202,203^ there is evidence from Medicaid claims data^204–206^ and clinician self-reports^207^ that these practices remain inadequate. Guidelines for screening and monitoring have been developed, especially in the area of schizophrenia where antipsychotics are the primary treatment, although there has been some critique of their degree of rigor (e.g., use of systematic reviews of the evidence), stakeholder involvement, and efforts to make recommendations on organizational aspects.^208^

## Findings in Relation to What Is Known

This section focuses on harms which were analyzed across all conditions. Our network meta-analysis revealed that olanzapine had the greatest potential to induce weight gain, followed by clozapine, risperidone, quetiapine, and aripiprazole. This finding is consistent with several published reviews,^11, 209–211^ although there are inconsistencies in the rankings with some reports of clozapine being the worst.^13^ Regarding change in BMI, our analysis suggested that clozapine was worse than olanzapine although it is difficult to draw firm conclusions because of the small sample size that contributed to the findings for clozapine. Unclear findings on this rank order effect on BMI is consistent with other work.^13,210^

Several published studies have reported on the effects of antipsychotics on metabolic parameters based on serum levels of glucose, total cholesterol, lipids (HDL, LDL), and/or triglycerides. In a meta-analysis,^210^ risperidone and olanzapine significantly increased glucose levels, while quetiapine and olanzapine significantly increased cholesterol and triglyceride levels when compared with placebo; analyses for the proportion of patients with clinically meaningful increases in these parameters were not conducted as these variables were poorly reported. In another meta-analysis,^209^ a statistically significant increase in serum glucose and total cholesterol was reported for olanzapine, while some studies included in the analyses reported no change in these parameters when comparing risperidone and aripiprazole with placebo. One systematic review and meta-analysis of short term head-to-head comparisons, ranked SGAs (clozapine=olanzapine>risperidone) for impact on metabolic abnormalities.^13^ From the short-term, placebo-controlled trials assessed, olanzapine caused elevation in triglycerides, total cholesterol, and LDL cholesterol; quetiapine and clozapine caused elevation in triglycerides only; aripiprazole did not cause any metabolic abnormalities, and data on the use of ziprasidone in children was reported as scarce. Authors of a descriptive review reported that a large proportion of data was not available.^11^

Our findings on metabolic effects are generally consistent with those of others. We chose to take advantage of the relatively large number of studies included in our review that reported on proportions of patients having abnormal levels of serum lipids, triglycerides, etcetera, to enhance the clinical relevance of the findings for decisionmakers. We also incorporated controlled observational studies which reported on several harm outcomes. Other studies did not quantify their confidence in the findings based on assessment of the quality of the body of work, and some of their conclusions were made based on what might be considered insufficient strength of evidence; we graded several of the outcomes as having insufficient SOE in comparisons between SGAs, and between individual SGAs and placebo.

Several studies have reported a decrease in prolactin levels with aripiprazole and statistically significant increases with other atypical antipsychotics when compared with placebo.^11, 13, 209, 210^ This inconsistency between drug effects was one reason for our findings on hyperprolactinemia to have insufficient SOE when examining all SGAs versus placebo; we assessed the findings as insufficient for individual drugs compared with placebo but may have found different SOE had we compared serum prolactin rather than hyperprolactinemia.

In one meta-analysis^210^ for combined sedation and somnolence in short-term studies, all SGAs significantly increased the risk of these outcomes compared with placebo. Clozapine was associated with the greatest risk, while quetiapine with the lowest. We conducted separate meta-analyses for sedation and somnolence and found similar findings for all SGAs versus placebo. For individual SGAs, we found no that there may be little or no difference between placebo and quetiapine or ziprasidone (low SOE).

All SGAs except quetiapine were reported from one review to significantly increase the risk of EPS when compared with placebo;^210^ clozapine was not included in the analysis due to lack of data. We report similar findings from our meta-analysis for all SGAs versus placebo; however, except for aripiprazole (low SOE favoring placebo) there was insufficient SOE to make any conclusions for comparisons of individual drugs. Authors of a descriptive review of select studies^11^ reported that SGAs were associated with less risk of akathisia and parkinsonism than FGAs, and that treatment with risperidone was associated with higher dystonia rates that other SGAs. For these rare events large samples are required to make any firm conclusions, such that we found insufficient SOE for these harms in comparisons between or within classes of FGAs and SGAs.

## Implications for Clinical and Policy Decisionmakers

There are some conclusions which can support clinician decisionmaking despite at best moderate SOE. SGAs showed benefit over placebo manic and mixed states in bipolar disorder, irritability and other symptoms in autism, and aggression and conduct problems in children with DICD with or without comorbid ADHD. It is not clear that antipsychotics improve clinical impressions of severity and hyperactivity in youth who have previously responded to psychostimulant medications. Moderate evidence for clinical benefit in these symptoms is present only for those for whom stimulant medications have not produced clinically significant reductions in ADHD symptoms, or for whom DICD is the primary diagnosis. Interestingly, comorbid ADHD did not impact the treatment effect across many conditions, and there was a significant placebo effect for treatment of positive and negative symptoms of schizophrenia. Limited evidence suggests that SGAs are effective for reduction in tic severity. It should also be noted that the effect on depressive symptoms may be small and possibly nonsignificant for bipolar disorder and schizophrenia. Reliance on findings from placebo-controlled studies for schizophrenia may not offer great help to those needing to choose between different antipsychotics for this condition which often relies on this treatment. Some of the findings for harms are quite considerable in light of the short-term duration of treatment of many of the studies contributing data. Nevertheless, some findings on harms—such as the low impact on weight suggested by studies of molindone—may provide some assistance when choosing between treatment alternatives. Continued guidance related to ongoing benefit-harm assessments for individual patients, regardless of which antipsychotic is prescribed, seems prudent.

Consistent with the role of systematic reviewers, we did not incorporate contextual considerations in our assessment of the SOE as may guideline developers.^61^ For example, our assessment of precision in findings should be interpreted in view of our confidence in the direction and magnitude of the average effect and an estimated threshold rather than having a (possibly greater) threshold based on various benefit-harm considerations. Several of the findings for intermediate outcomes only support small effects, although the placebo effect in several studies (especially for schizophrenia) was substantial which makes some findings difficult to interpret in light of real-world practice. Likewise, we did not downgrade any evidence for lack of directness related to the comparability of study populations with those treated in clinical practice, for which there may be important differences.

## Limitations of This CER

This review followed rigorous methodological standards, which were detailed a priori. Nevertheless, several limitations are inherent within systematic reviews in general.

First, there is a possibility of selective reporting bias (e.g., researchers only reporting positive outcomes) and publication bias, whereby large trials with unexpectedly strong results are selectively reported. In terms of selective outcome reporting, we were able to locate several trial registries and protocols to compare planned and published outcome reporting; most studies were judged as having low or medium bias in this respect. We also searched for, and located, regulatory documents containing data on harms that were not reported in the primary articles (see Associated Publications in Appendix E). Our pre-specified tests for publication bias (small study effects) indicated potential bias for some harm outcomes (i.e., akathisia, dystonia, sedation, somnolence, 7% or greater weight gain); we believe this is not so much related to systemic publication/reporting bias but rather poor reporting practices for harms particularly in older studies where many of the harms were unanticipated. These outcomes were not usually the primary outcomes reported by studies, which would reduce their likelihood of leading to publication bias. We focused on studies published in English because we felt that these reports would be most applicable to the end-users of this review who create recommendations for antipsychotic use within the United States. Moreover, effect sizes in language restricted reviews have shown to not differ significantly (overestimating effect sizes by 2%) from those not having restrictions.^212^ Non-English publications are thought most important to seek for reviews of certain interventions, such as complimentary or alternative medicine, or when the prevalence of the condition or use of the intervention is particularly high in foreign countries.^212–213^ We based our assessments of methodological quality on study publications and did not contact authors to verify the methods used. Some studies may have been adequately conducted, but the methods were poorly reported.

Our findings from the sensitivity analyses and meta-regressions for subgroup variables are based on study-level data and because of this should be considered observational in nature. Some of our statistical analyses indicated heterogeneity between studies; we performed sensitivity analyses in several cases to explore and discuss possible reasons for heterogeneity. Combining data from trials and observational studies for harms outcomes may have added heterogeneity to the results, although close inspection of the data plots (e.g., Figures 82–85) indicated high variability within both types of study design and no indication of a systematic bias in any direction. Our reports of within-study subgroup analysis and our meta-regressions attempted to help explain some of this variability. The findings from our network meta-analyses should also be considered exploratory in nature. Apart from the assumptions made for all meta-analyses, the network approach assumes transitivity, where we assume that all treatment nodes not present in any trial are missing at random, and there is nothing systematically different about the populations or interventions in the various trials. Because of these limitations we did not use these results for making our assessments of the strength of the body of evidence. We note, however, that the consistency between direct and indirect evidence was acceptable, and that the adjusted analysis factoring in treatment duration (shown as significant treatment modifier from the pairwise meta-analysis) did not change the results.

This report was limited to direct comparisons of various antipsychotics and comparisons of antipsychotics with placebo. As such, evidence on the use of other drug classes (e.g., anticonvulsants, mood-stabilizers) that are frequently used in the treatment of these patient populations is not considered.

Systematic reviews may become outdated, at least in part, if new studies are published that change some or all of their conclusions. Although our comprehensive search was only undertaken to April 2016, we are quite confident there has been no evidence as of September 2016 which would change our findings in such a manner (e.g., to moderate or higher SOE for any outcome). A search update in Medline for April to September 8, 2016 identified three RCTs and one retrospective cohort study examining: (i) twice weekly versus daily aripiprazole in tic disorders (N=36, 6–18 year olds), without evidence of difference for tic severity at 8 weeks,^214^ (ii) aripiprazole versus risperidone for ODD with ADHD (N=40, 3–6 year olds), showing no significant difference in clinical severity but higher serum prolactin from risperidone at 8 weeks,^215^ (iii) aripiprazole versus risperidone for ASD comorbid with ADHD (N=44, 6–13 year olds), with no differences between these SGAs for illness severity or ADHD symptoms but higher prolactin from risperidone at 26 weeks,^216^ and (iv) treatment of ASD with five SGAs for up to 5 years (N=202), with olanzapine showing greatest harm for weight gain, and quetiapine and ziprasidone showing insignificant increases in BMI z-scores.^217^ There does, though, appear to be a trend for more comparative research between different SGAs, if not also between SGAs and FGAs as suggested from our findings.

## Limitations of the Evidence Base

The evidence base was inadequate to fully answer the Key Questions, particularly with respect to some harms. Several effectiveness outcomes of importance to patients and policymakers, such as quality of life, school and occupational performance, and health care utilization, were reported by too few studies to confidently support conclusions of effect.

Many trials had methodological limitations introducing some risk of bias. Half of the trials had incomplete outcome data due to loss to followup and inadequate handling of missing data in the reporting and analyses, which may exaggerate treatment effects. Measures employed by study investigators to ensure that the allocation sequence was truly random and that allocation occurred without foreknowledge of treatment assignments was often unclear in the trials. These features can always be employed in trials and should be used routinely to avoid selection bias. The main reasons we downgraded the SOE was for risk of bias and imprecision from small samples or when the results included possibility of substantial benefit or harm when insignificant findings were found (i.e., limiting confidence in findings of no difference). It should be recognized that attaining high SOE from trials of antipsychotics in children with psychiatric conditions is likely very difficult and the overall evidence reviewed should not be interpreted as lacking in credibility.

Although some outcomes and scales were assessed fairly consistently for some conditions, there was great diversity in the scales used in studies for the other conditions. To capture as much data as possible and where feasible, we combined different scales for some outcomes (e.g., hyperactivity, aggression) using standardized mean differences; our findings based on these values may be difficult to interpret. Further, response and remission were based on different outcome measures and criteria across studies making comparisons across studies and interventions challenging. There were few outcomes (e.g., tic severity, psychotic symptoms) for which we found clear evidence supporting a particular clinically important magnitude of effect; for most outcomes we relied on clinicians to help determine values for use in our assessments (e.g., >1 point change on the Clinical Global Impressions [CGI] scales, approximately a 10% mean difference for most measurement scales [10 points for scale of 1 to 100], RR values <0.75 for harm or >1.25 for benefit); effect sizes below these thresholds but having low or higher SOE for a difference were considered slight or small.

The duration of followup was brief in many studies but especially in trials, therefore our findings need to be interpreted with this in mind. Although many of the trials included open-label extension phases to assess efficacy or harms, the majority failed to provide comparative data, precluding evaluation of effects between groups. In general, the small number of comparions between different antipsychotics is a limitation in the evidence base. Providing long-term comparative data for studies evaluating an active treatment versus placebo may not be feasible. As such, more high-quality observational studies are needed to provide data on patients using different antipsychotics over the course of several years to determine the comparative benefits and risks associated with these drugs.

## Research Gaps

The following general recommendations for future research are based on the preceding discussion regarding limitations of the current evidence:

- Studies examining long-term efficacy and, particularly, safety of antipsychotics (and differences between different antipsychotics) over the course of several years are needed. Future research should evaluate long-term developmental outcomes, such as growth, maturation, and cognitive and emotional development.
- Future studies should evaluate outcomes that are important to patients and parents, including health-related quality of life, school performance, and involvement with the legal system.
- Studies examining the impact of key patient subpopulations on important outcomes are needed to inform clinical practice. In particular, subgroup analyses examining young adults would be helpful in guiding clinical decisions due to the unique issues associated with this population.
- Consensus on outcomes and outcome measures is needed to ensure consistency and comparability across future studies. Moreover, consensus on minimal clinically important differences is needed to guide study design and interpretation of results.
- Large-scale effectiveness studies that are inclusive with respect to patient-selection criteria and closely match typical clinical practice are needed for greater applicability of results. Data on the real-world benefits and harms across groups defined by race/ethnicity, socioeconomic status, and geographical region would be informative.
- Studies incorporating therapeutic drug monitoring over long-term periods in naturalistic settings should be encouraged to help create quality standards and provide insight into operational considerations to inform recommendations for monitoring.
- Considering antipsychotics are recommended for use as adjunctive, or add-on, treatment for many conditions, more studies examining these approaches (e.g., behavioral/family interventions with and without antipsychotics for hyperactivity or irritability) may help practitioners create guidance on when to start a trial of antipsychotics.

## Conclusions

The efficacy and safety of FGAs and SGAs have been studied in children, adolescents, and young adults (ages ≤ 24 years) for a wide array of psychiatric conditions. SGAs probably improve to some extent key intermediate outcomes for which they are usually prescribed, but they have a poorer harms profile than placebo or no antipsychotic treatment particularly for body composition and somnolence. Overall, data for head-to-head comparisons (FGAs vs. SGAs, FGAs vs. FGAs, and SGAs vs. SGAs) were generally of insufficient or low SOE; therefore, few conclusions regarding the relative benefits and harms of different antipsychotics could be drawn. For schizophrenia, there appears to be little or no difference between FGAs and SGAs for negative symptoms, positive symptoms, response rates, and global impressions of illness severity; deciding on which antipsychotic to use for this condition likely relies on close examination of the relative harms including considerations of their tolerance, management, and reversibility. The evidence examined suggests there may be little difference in effects between different doses of antipsychotics, although longer-term data would help clarify these findings. Evidence was sparse for several patient- and family-important outcomes, such as health-related quality of life, involvement with the legal system, and school performance. Few studies reported long-term data.

Treatment benefit and risks were examined most frequently for schizophrenia. Fewer studies examined other conditions; only one study was eligible for each of depression and obsessive-compulsive disorder, and there were no eligible studies exclusively examining posttraumatic stress disorder, anxiety disorders, or substance use disorder. Young adults were rarely examined, particularly for conditions other than schizophrenia; young children were also not studied to any great extent. Additional research is needed to assess the treatment efficacy, and particularly the harms, of antipsychotics in these populations.

This review identified several areas where the evidence is sparse and which are priorities for future research. One of the greatest priorities is the systematic evaluation of harms. Studies incorporating therapeutic drug monitoring over long-term periods in naturalistic settings will hopefully help create a more accurate picture of the comparative harms between the large number of antipsychotics. They may also help define quality standards and provide insight into operational considerations to inform recommendations for monitoring. Comprehensive comparative effectiveness reviews such as this one, combined with active involvement of patients, families, and multidisciplinary practitioners may improve the applicability and usefulness of guidelines and help ensure uptake of their recommendations.