# Appendix G Analytical Models and Code, and Additional Results for Key Question 2 From Network Meta-Analysis and for General Adverse Effects

## 1 Mathematical models and WinBUGS code for (i) pairwise meta-analyses, (ii) meta-regressions, and (iii) network meta-analyses

### i Pairwise Meta-analysis Model and Code

All pairwise meta-analyses were conducted using a Bayesian random effects model. The following model was used:

Y_i_~N(δ_i_, V_i_) i = 1, …, Nstud

δ_i_~N(d, τ^2^)

d~N(0,10000)

τ~Uniform(0,m)

Where Y_i_ is the observed effect in study in i with variance V_i_, δ_i_ is the true (unknown) study specific effect, and Nstud is the number of studies in the meta-analysis. The δ_i_’s are allowed to be different from each other and are assumed to come from a normal distribution with mean d and variance τ^2^. The d parameter is the main parameter of interest that is estimated from the model with 95% credible interval, while τ^2^ is the between study variance nuisance parameter. The d parameter is given a non -informative prior distribution with mean 0 and variance of 10000, while the between study standard deviation (the square root of the variance) was given a uniform prior with 0 as the lower bound and varying upper bounds (here classified as m) that varied depending on the units of the analysis.

For continuous analyses, δ_i_ represents the mean difference as the parameter of interest. For dichotomous analyses, it represents the log of the risk ratio. In the former case the variance estimates were either computed, imputed, or taken directly from the individual studies. For the latter case the variance of the log risk ratio estimates was computed as V = 1/a + 1/c − 1/n_1_ − 1/n_2_ where a and c are the number of events and n_1_ and n_2_ are the total sample sizes respectively in the two groups. In dichotomous outcomes, studies with 0 events in both groups (i.e. a = c = 0) were excluded from the analysis. For studies with 0 events in exactly 1 arm, we added 0.5 to a and c, while adding 1 to n_1_ and n_2_ in order to be able to compute a risk ratio.

#### Code

model
{
   for (i in 1:21)
      {
          V[i] <- sd[i]*sd[i]
          P[i] <- 1/V[i]
                      u[i] ~ dnorm(delta[i], P[i])
                      delta[i] ~ dnorm(d, prec)
                  }
                  d ~ dnorm(0, 1.0E-5)
                  rr <- exp(d)
                  tau~dunif(0,2)
                  tau.sq<-tau*tau
                  prec<-1/(tau.sq)
}


Data

u[]            sd[]
-1.02914783            0.754132191
-1.174119841          0.800623643
-1.037987667          1.620563325
-0.076961041          0.858939915
1.594092343           0.731173426
0.395514777           0.455271048
-0.826678573          0.826459748
1.309135281           1.472655401
1.704748092           1.037402144
0.415317405           1.141851348
-0.721318058          0.978539566
2.301259712           1.429374769
1.193922468           1.573454027
-0.622051259          0.649521535
2.315007613           1.470780216
-0.43936666            0.273272415
0.95403106             0.756218287
1.55283205             1.052105011
0.70345655             0.627665478
0.830348302           1.590886564
1.861851846           1.457376123

END



Initial Values

list(d=0, delta=c(0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0 ), tau=1)

### ii Meta-regression Model and Code

The Bayesian random effects meta-regressions analysis done in this review used the same model as listed above in the pairwise analysis, with the exception that a covariate term was added:

Y_i_~N(δ_i_ + βx_i_, V_i_) i = 1, …, Nstud

Where β is the regression coefficient and x_i_ is the value of the covariate of the ith study. The β parameter is of primary interest in this analysis and is given anon -informative uniform prior:

β~N(0,10000)

With this exception all other parametrizations are identical to those stated in the pairwise analysis.

#### Code

model
{
  for (i in 1:22)
   {
       V[i] <- sd[i]*sd[i]
       P[i] <- 1/V[i]
                   mu[i] <- delta[i]+beta*(cv[i]-mean(cv[]))
                   u[i] ~ dnorm(mu[i], P[i])
                   delta[i] ~ dnorm(d, prec)
            }
            d ~ dnorm(0, 1.0E-5)
            rr <- exp(d)
            beta ~ dnorm(0,1.0E-5)


            tau~dunif(0,2)
            tau.sq<-tau*tau
            prec<-1/(tau.sq)
}


Data

u[]          sd[]             cv[]
0.070617567             0.787114445          0
-1.02914783              0.754132191          82
-1.174119841            0.800623643          79
-1.037987667            1.620563325          76.5
1.542799048             0.732970776          43
0.395514777             0.455271048          26
1.309135281             1.472655401          34
1.704748092             1.037402144          32
-0.721318058            0.978539566          24
2.301259712             1.429374769          10
1.193922468             1.573454027          15.8
-0.117783036            1.97026507            72
1.18302963               1.061397515          79.8
1.742969305             1.538349069          100
-1.609437912            1.508310313          0
-0.622051259            0.649521535          68
2.315007613             1.470780216          91
1.861851846             1.457376123          64.5
0.733152515             0.678221198          95
1.994700313             1.479221159          77.5
-0.43936666              0.273272415          0
1.55283205               1.052105011          100

END



Initial Values

list(d=0, delta=c(0,0,0,0,0, 0,0,0,0,0,  0,0,0,0,0, 0,0,0,0,0, 0,0), tau=1,beta=0)

### iii Network Meta-analysis Model and Code

The network meta-analyses were conducted using a Bayesian random effects model. The following model was used:

δ_(j,b,k)~N(d_(b,k),σ^2)~N(d_(P,k)−d_(P,b)); j=1,..,Nstud; b,k=1,....,Ntreat b<k

d_(P,k)~N(0,10000);k=2,…,Ntreat

σ~Unif(0,m)

In this model δ_(j,b,k) represents the study level differences between treatments b and k. Similar to the pairwise model, these are allowed to differ by study. Since this is a consistency model, all treatments are compared to the reference standard (placebo—coded P), so the actual quantity being estimated is the equivalent parameter of “difference between treatment k and placebo minus difference between treatment b and placebo” (d_(P,k)-d_(P,b)). This parametrization helps facilitate the running of the model in WinBUGS. Each difference between a treatment intervention and the placebo is given a prior distribution with mean 0 and variance 10000. The between study variance is represented is represented here by σ^2 and similar to the pairwise analysis, it was given a uniform distribution with a varying upper bound depending upon the unit being measured. Model convergence was verified using autocorrelation, paying particular attention to prior distributions on between study variance parameters. Goodness of fit was evaluated by monitoring deviance parameters in each analysis.

#### Code

#Random effects model for multi-arm trials (any number of arms)
model{
for(i in 1:NS){
          w[i,1] <-0
                        delta[i,1]<-0
                        mu[i] ~ dnorm(0,.0001)                                                # vague priors for trial baselines
                        for (k in 1:na[i])     {
                                pr[i,k]<-1/(o[i,k]*o[i,k])
                                      u[i,k]~dnorm(mean[i,t[i,k]],pr[i,k])          # normal likelihood
                                      mean[i,t[i,k]]<-mu[i] + delta[i,k] }             # model
                                      for (k in 2:na[i]) {
                  delta[i,k] ~ dnorm(md[i,k],taud[i,k])                 # trial-specific mean distributions
                  md[i,k] <- d[t[i,k]] - d[t[i,1]]     + sw[i,k]                   # mean of distributions
                  taud[i,k] <- tau *2*(k-1)/k                                          #precision of distributions
                  w[i,k] <- (delta[i,k]     - d[t[i,k]] + d[t[i,1]])          #adjustment, multi-arm RCTs
                  sw[i,k] <-sum(w[i,1:k-1])/(k-1) }                      # cumulative adjustment for multi-arm trials
}

d[1]<-0
for (k in 2:NT){d[k] ~ dnorm(0,.0001) }                             #  vague priors for basic parameters

sd~dunif(0,10)                                                 # vague prior for random effects standard
deviation
tau<-1/pow(sd,2)

# ranking
for (k in 1:NT) { rk[k]<-rank(d[],k)
                         worst[k]<-equals(rk[k],NT)}

# pairwise values
for (c in 1:(NT-1))
           { for (k in (c+1):NT)
                  { diff[c,k] <- d[k] - d[c]                    # Use this for differences
                                                                                      log(rr[c,k]) <- diff[c,k]             # Use this for risk ratios
                                       }
           }
}

# NT=no. treatments, NS=no. studies;
# NB : set up M vectors each r[,]. n[,] and t[,],  where M is the Maximum number of treatments
#         per trial in the dataset. In this dataset M is 3.

list(NT=15,NS=71)

u[,1]      o[,1]         u[,2]         o[,2]          u[,3]       o[,3]         u[,4]          o[,4]         t[,1]         t[,2]         t[,3]         t[,4]         na[]
0.6         0.391964748            2.2            0.406051781           NA            NA           NA          NA          1              2              NA
              NA           2
0.3         0.294058818            1.4            0.163484778           NA            NA           NA          NA          1              2              NA
              NA           2
0.8         0.295739154            2               0.308066862           NA            NA           NA          NA          1              2              NA
              NA           2
0.72       0.52          1.2           0.612825877           NA           NA            NA           NA          1              2              NA          NA
              2
-0.8        0.262639662            0.2           0.185714286            NA            NA           NA          NA          1              2              NA
              NA           2
0.2         0.315682075            1.6           0.353553391            NA            NA           NA          NA          1              2              NA
              NA           2
0.68       0.304105245            3.4           0.889981273            NA            NA           NA          NA          1              3              NA
              NA           2
0.3         0.227258215            3.66         0.210748555            NA            NA           NA          NA          1              3              NA
              NA           2
0.1         0.480196038            4.3           0.38890873              NA            NA           NA          NA          1              3              NA
              NA           2
0            0.235247054            0.9           0.163027152            NA            NA           NA          NA          1              4              NA
              NA           2
1.1         1.116284014            2.3           1.176666667            NA            NA           NA          NA          1              5              NA
              NA           2
2.5         0.542217668            4.2           0.826236447            NA            NA           NA          NA          1              5              NA
              NA           2
0.9         0.154919334            2.3           0.145521375            NA            NA           NA          NA          1              5              NA
              NA           2
0.6         0.239        1.3           0.223110423           NA           NA            NA           NA          1              5              NA          NA
              2
0.4         0.181303919            1.7           0.155480202            NA            NA           NA          NA          1              5              NA
              NA            2
-0.4        0.242487113            2              0.263931552           NA            NA           NA          NA          1              5              NA
              NA            2
0.9         0.188982237            2.2           0.24271195             NA            NA           NA          NA          1              6              NA
              NA            2
-1.2        1.312035065            1.8           1.633360908           NA            NA           NA          NA          1              6              NA
               NA           2
-0.6        3.301852918            0.9           2.728846047           NA            NA           NA          NA          1              6              NA
               NA           2
0.74        0.284604989           4.2           0.221359436           NA            NA           NA          NA          1              6              NA
               NA           2
0.2          0.421996009           2.2           0.437630757           NA            NA           NA          NA          1              6              NA
               NA           2
0.7          0.201146713           2.4           0.371782975           NA            NA           NA          NA          1              6              NA
               NA           2
0.8          0.305085108           2.7           0.414285714           NA            NA           NA          NA          1              6              NA
               NA           2
1             0.259554274           2.7           0.316227766           NA            NA           NA          NA          1              6              NA
               NA           2
0.7          0.249482222           1.63         0.184136651           NA            NA           NA          NA          1              6              NA
               NA           2
0.1         1.700840129            1.8           1.24922198             NA            NA           NA          NA          1              6              NA
              NA            2
0.6         4.573370123            1.8           7.062695425           NA            NA           NA          NA          1              6              NA
              NA            2
0.8         0.353553391            0.7           0.204124145           NA            NA           NA          NA          1              7              NA
              NA            2
0            0.277350098            -0.1          0.207328422           NA            NA           NA          NA          1              7              NA
              NA            2
0.8         0.66395281              0.7           0.375      NA           NA            NA           NA          1              7              NA          NA
              2
4.09       0.649114782            1.45         0.926723619           NA            NA           NA          NA          3              8              NA
              NA           2
7.2         1.374772708            3.9           1.047445873           1.1            1.166726189            NA           NA         3              6
              8               NA           3
7.2         6.5375      4.9            5.322445026         3.6            6.30005291               NA          NA          3              6              8
              NA           3
4.3         2.444885287            4.6           4.634670071           NA            NA           NA          NA          6              8              NA
              NA           2
4.5         4.315693262            2.7           6.784462291           NA            NA           NA          NA          6              9              NA
              NA           2
1.9         4.118012423            1              4.118012423           NA            NA           NA          NA          6              9              NA
              NA           2
1.28       0.246777685            1.68         0.333243949           NA            NA           NA          NA          2              8              NA
              NA           2
0.94       0.871367786            0.9           2.045993646           NA            NA           NA          NA          8              10            NA
              NA           2
4.4         0.559016994            3.6           0.360555128           2.1            1.511857892            NA          NA           3              6
              10             NA          3
3.4         1.449568901            5              1.549193338           NA            NA           NA          NA          3              10            NA
              NA           2
87          3.983368201            76.3         3.633286285           NA            NA           NA          NA          3              10            NA
              NA           2
3.6         1.109400392            3.8           1.732050808           NA            NA           NA          NA          3              10            NA
              NA           2
4.48       0.377790328            8.6           0.59491596             6.11          0.594794082            5.38         0.272345413          2
              3               5              6              4
3.2         1.309068371            2.2           0.96        NA           NA           NA           NA           3              6              NA          NA
              2
2.24       0.654368062            1.96         0.599319381           NA           NA           NA          NA          3              6              NA
              NA           2
5.27       0.889582789            1              0.353009043           NA           NA           NA          NA          3              6              NA
              NA           2
5.78       0.937700282            4.45         0.956666667           NA           NA           NA          NA          3              6              NA
              NA           2
3.6         0.981155781            4.5          1.3           NA           NA           NA           NA          3              6              NA          NA
              2
11.52     1.370369061            6.27        1.428018267            7.08         0.742220803            NA          NA          3              5
              6               NA          3
16.2       3.111269837            7.2          1.67600716              9.5           2.685268453            NA          NA          3              6
              10             NA          3
11.1       1.744133022            2.5         1.388044188             5              1.023363439            NA          NA          3              5
              6               NA          3
11.1       1.553160549            11          1.287485552             7.6           3.06740933              NA          NA          3              6
              11             NA          3
15.5       1.529705854            5.4         1.388044188             NA           NA           NA         NA          3              5              NA
              NA           2
-0.2        0.172317299            2.1         0.20587307              NA           NA           NA          NA          1              6              NA
              NA           2
0.61       0.317542648            2.96        0.762823702           NA           NA           NA          NA          1              6              NA
              NA           2
1.71       0.290688837            2.81        0.468008097           NA           NA           NA          NA          1              6              NA
              NA           2
0.1         1.061873701            7             0.854874734           NA           NA           NA          NA          1              6              NA
              NA           2
0.42       0.230043474            2.61        0.708387841           NA           NA           NA          NA          1              2              NA
              NA           2
0.3         0.787348234            8.79        1.652296382           NA           NA           NA          NA          1              3              NA
              NA           2
0.4         0.404605071            2.3          0.360011161           NA           NA           NA          NA          2              4              NA
              NA           2
36.36     0.312420657            37.21      0.312420657           NA           NA           NA          NA          1              6              NA
              NA           2
33.61     0.229797012            33.74      0.229797012           NA           NA           NA          NA          1              13            NA
              NA           2
0.6         2.934681063            2.3          3.968892196           NA           NA           NA          NA          1              6              NA
              NA           2
44.13     0.252357307            44.22      0.252357307           NA           NA           NA          NA          1              6              NA
              NA           2
0.56       0.265434332            0.95        0.163576992           NA           NA           NA          NA          1              2              NA
              NA           2
0.48       0.156220839            1.6          0.117388809           NA           NA           NA          NA          1              12            NA
              NA          2
12          2.670881445            14           3.644790803           10            2.101438283            NA          NA           3              5
              6              NA           3
0.12       0.40824829              1.396      0.294174203           NA           NA           NA          NA          1              6              NA
              NA         2
9.7        1.607533401             10.8        1.48045234             NA           NA           NA          NA          5              6              NA
              NA         2
-0.9       0.942857143             1.769      0.603     NA            NA           NA           NA          1             14             NA          NA
             2
7.7        1.200438516             5.6          1.2          NA           NA           NA           NA          3             15             NA          NA
             2
END





list(
d=c(NA,0,0,0,0,0,0,0,0,0,0,0,0,0,0),
sd=5,
mu=c(0,0,0,0,0,  0,0,0,0,0,  0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0,  0,0,0,0,0,  0,0,0,0,0,  0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0,
0,0,0,0,0, 0,0,0,0,0, 0)
)

## 2 Figures of star plots and inconsistency factor plotting for network meta-analyses

Figure G1 Weight network analysis star plot

Figure G1 displays the direct comparisons present in all the studies used in the network meta-analysis for BMI. Each intervention is displayed with a circle--the larger the circle the more studies that used that intervention. A line connecting each intervention to another intervention shows that there was direct evidence between those two interventions (i.e. at least one study compared the two interventions). The thicker the line, the more studies that made that comparison. The plot shows that Risperidone and Olanzapine were the most commonly used treatments, each with direct comparisons to seven other treatments. The most common pairwise comparisons were Risperidone versus Olanzapine and Risperidone versus Placebo.

Figure G2 Weight inconsistency factor plot

1. Placebo
2. Aripiprazole
3. Olanzapine
4. Paliperidone
5. Quetiapine
6. Risperidone
7. Ziprasidone
8. Haloperidol
9. Pimozide
10. Clozapine
11. Molindone
12. Asenapine
13. Thioridazine
14. Lurasidone

Figure G2 displays a plot of the closed loops in the network meta-analysis for BMI and their level of inconsistency with respect to direct versus indirect evidence. The larger the value, the more inconsistency is present within the loop. Only one loop in this meta-analysis showed statistically significant heterogeneity--namely the Aripiprazole-Olanzapine-Quetiapine loop. This shows reasonable consistency within the network.

Figure G3 BMI network analysis star plot

Figure G1 displays the direct comparisons present in all the studies used in the network meta-analysis for Weight. Each intervention is displayed with a circle--the larger the circle the more studies that used that intervention. A line connecting each intervention to another intervention shows that there was direct evidence between those two interventions (i.e. at least one study compared the two interventions). The thicker the line, the more studies that made that comparison. The plot shows that Risperidone, Olanzapine, and placebo were the most commonly used treatments, each with direct comparisons to eight, eight, and seven other treatments respectively. The most common pairwise comparisons were Risperidone versus Placebo and Risperidone versus Olanzapine.

Figure G4 BMI inconsistency factor plot

1. Placebo
2. Aripiprazole
3. Olanzapine
4. Paliperidone
5. Quetiapine
6. Risperidone
7. Asenapine
8. Haloperidol
9. Molindone
10. Clozapine
11. Lurasidone

Figure G4 displays a plot of the closed loops in the network meta-analysis for weight and their level of inconsistency with respect to direct versus indirect evidence. The larger the value, the more inconsistency is present within the loop. No loops in this meta-analysis showed statistically significant heterogeneity, indicating good consistency within the network.

## 3 Pairwise comparisons from network meta-analyses

Table G1 Pairwise comparsions from network meta-analysis for weight gain

| Placebo | Aripiprazole | Olanzapine | Paliperidone | Quetiapine | Risperidone | Ziprasidone | Haloperidol | Pimozide | Clozapine | Molindone | Asenapine | Thioridazine | Lurasidone
Aripiprazole | 0.88 (0.26, 1.50)
Olanzapine | 4.12 (3.43, 4.88) | 3.24 (2.38, 4.17)
Paliperidone | 1.72 (0.36, 3.12) | 0.84 (-0.53, 2.26) | -2.40 (-3.96, -0.89)
Quetiapine | 1.25 (0.51, 1.95) | 0.37 (-0.58, 1.27) | -2.87 (-3.89,-1.95) | -0.47 (-2.07, 1.03)
Risperidone | 1.85 (1.40, 2.35) | 0.98 (0.25, 1.75) | -2.27 (-2.97,-1.58) | 0.13 (-1.30, 1.59) | 0.60 (-0.17, 1.47)
Ziprasidone | -0.10 (-1.25, 1.05) | -0.98 (-2.28, 0.32) | -4.22 (-5.62,-2.90) | -1.82 (-3.63,-0.04) | -1.35 (-2.68, 0.04) | -1.95 (-3.22,-0.74)
Haloperidol | 0.97 (-0.43, 2.38) | 0.10 (-1.30, 1.49) | -3.15 (-4.62,-1.74) | -0.74 (-2.69, 1.16) | -0.28 (-1.81, 1.30) | -0.88 (-2.32, 0.53) | 1.07 (-0.74, 2.89)
Pimozide | 0.71 (-8.87, 9.95) | -0.18, (-9.77, 9.10) | -3.42 (-13.02, 5.83) | -1.03 (-10.67, 8.34) | -0.54 (-10.12, 8.76) | -1.16 (-10.72, 8.10) | 0.81 (-8.85, 10.12) | -0.27 (-9.93, 9.05)
Clozapine | 2.38 (0.37, 4.40) | 1.50 (-0.55, 3.58) | -1.74 (-3.71, 0.21) | 0.66 (-1.75, 3.09) | 1.13 (-0.97, 3.27) | 0.52 (-1.47, 2.52) | 2.48 (0.17, 4.80) | 1.41 (-0.81, 3.66) | 1.70 (-7.78, 11.46)
Molindone | -0.68 (-7.29, 5.80) | -1.56 (-8.19, 4.95) | -4.81 (-11.39, 1.69) | -2.41 (-9.12, 4.23) | -1.92 (-8.55, 4.59) | -2.54 (-9.13, -3.92) | -0.58 (-7.29, 6.00) | -1.66 (-8.37, 4.94) | -1.33 (-12.92, 10.06) | -3.07 (-9.95, 3.73)
Asenapine | 1.12 (-0.65, 2.90) | 0.24 (-1.65, 2.12) | -3.00 (-4.97,-1.13) | -0.60 (-2.87, 1.64) | -0.14 (-2.02, 1.81) | -0.73 (-2.60, 1.07) | 1.22 (-0.90, 3.34) | 0.15 (-2.12, 2.40) | 0.41 (-9.03, 10.14) | -1.26 (-3.95, 1.40) | 1.81 (-4.92, 8.61)
Thioridazine | 0.13 (-1.71, 1.98) | -0.74 (-2.69, 1.19) | -3.98 (-6.00,-2.06) | -1.59 (-3.90, 0.69) | -1.12 (-3.06, 0.89) | -1.72 (-3.65, 0.16) | 0.23 (-1.93, 2.40) | -0.84 (-3.15, 1.47) | -0.57 (-10.02, 9.20) | -2.25 (-4.98, 0.45) | 0.82 (-5.93, 7.66) | -0.99 (-3.54, 1.58)
Lurasidone | 0.45 (-1.28, 2.19) | -0.43 (-2.27, 1.41) | -3.66 (-5.59, -1.85) | -1.27 (-3.50, 0.93) | -0.80 (-2.64, 1.10) | -1.40 (-3.23, 0.37) | 0.55 (-1.54, 2.63) | -0.52 (-2.75, 1.71) | -0.25 (-9.69, 9.45) | -1.93 (-4.59, 0.69) | 1.14 (-5.57, 7.95) | -0.67 (-3.16, 1.82) | 0.32 (-2.22, 2.83)
Chlorpromazine | 2.04 (-1.79, 5.85) | 1.16 (-2.72, 5.01) | -2.09 (-5.86, 1.64) | 0.32 (-3.76, 4.36) | 0.80 (-3.09, 4.67) | 0.18 (-3.67, 3.99) | 2.14 (-1.85, 6.12) | 1.06 (-2.95, 5.09) | 1.31 (-8.64, 11.58) | -0.35 (-4.58, 3.88) | 2.73 (-4.79, 10.27) | 0.92 (-3.29, 5.14) | 1.90 (-2.34, 6.15) | 1.59 (-2.61, 5.79)

All results are row minus column. Positive values indicate that row drug had higher weight; negative values indicate that column value had higher weight.

Table G2 Pairwise comparisons from network meta-analysis for BMI

| Placebo | Aripiprazole | Olanzapine | Paliperidone | Quetiapine | Risperidone | Asenapine | Haloperidol | Molindone | Clozapine
Aripiprazole | 0.32 (0.11, 0.55)
Olanzapine | 1.51 (1.28, 1.84) | 1.19 (0.90, 1.56)
Paliperidone | 1.02 (0.43, 1.62) | 0.70 (0.14, 1.26) | -0.49 (-1.18, 0.11)
Quetiapine | 0.47 (0.08, 0.76) | 0.16 (-0.30, 0.49) | -1.04 (-1.55, -0.66) | -0.54 (-1.29, 0.08)
Risperidone | 0.59 (0.40, 0.81) | 0.27 (0.01, 0.56) | -0.92 (-1.21, -0.68) | -0.43 (-1.04, 0.20) | 0.12 (-0.21, 0.55)
Asenapine | 0.52 (0.07, 0.98) | 0.21 (-0.31, 0.70) | -0.97 (-1.58, -0.52) | -0.49 (-1.25, 0.24) | 0.04 (-0.45, 0.68) | -0.06 (-0.59, 0.41)
Haloperidol | -0.42 (-1.46, 0.66) | -0.73 (-1.80, 0.35) | -1.93 (-2.98, -0.86) | -1.43 (-2.63, -0.21) | -0.88 (-1.96, 0.25) | -1.01 (-2.05, 0.05) | -0.94 (-2.07, 0.23)
Molindone | 0.30 (-2.06, 2.54) | -0.01 (-2.39, 2.22) | -1.22 (-3.59, 1.01) | -0.71 (-3.17, 1.58) | -0.16 (-2.53, 2.10) | -0.29 (-2.66, 1.93) | -0.22 (-2.63, 2.06) | 0.70 (-1.89, 3.14)
Clozapine | 1.96 (0.55, 3.36) | 1.65 (0.21, 3.05) | 0.45 (-0.98, 1.84) | 0.94 (-0.58, 2.45) | 1.50 (0.05, 2.93) | 1.37 (-0.04, 2.75) | 1.45 (-0.04, 2.90) | 2.38 (0.65, 4.09) | 1.67 (-1.02, 4.41)
Lurasidone | 0.14 (-0.29, 0.57) | -0.17 (-0.67, 0.29) | -1.35 (-1.95, 0.94) | -0.88 (-1.62, -0.16) | -0.34 (-0.81, 0.27) | -0.45 (-0.95, 0.00) | -0.38 (-1.01, 0.24) | 0.56 (-0.60, 1.67) | -0.16 (-2.43, 2.24) | -1.82 (-3.28, -0.35)

All results are row minus column. Positive values indicate that row drug had higher weight; negative values indicate that column value had higher weight.

## 4 Findings tables for general adverse effects

Table G3 Findings for GAE: FGA versus SGA

Comparison (G1 vs. G2) | Outcome | N Studies, N Patients | G1 Events | G1 N | G2 Events | G2 N | Relative Effects
FGA vs. SGA | Any AE | 3, 204 | 89 | 97 | 86 | 107 | RR, 1.16; 95% CrI, 0.71 to 1.92^1, 2^
FGA vs. SGA
FGA vs. SGA | Any AE (6to<12) | 2, 74 | 17 | 20 | 15 | 21 | RR, 1.19; 95% CI, 0.56 to 1.65^1^
FGA vs. SGA | Any AE (6to<12) | | 17 | 20 | 13 | 13 | RR, 0.86; 95% CI, 0.70 to 1.07^1^
FGA vs. SGA
FGA vs. SGA | AE limiting treatment | 6, 343 | 39 | 163 | 23 | 180 | RR, 1.82; 95% Crl, 0.90 to 4.42^1–3, 68^
FGA vs. SGA | AE limiting treatment | 2, 50 | | | | | Not estimable^4^
FGA vs. SGA
FGA vs. SGA | AE limiting treatment (12+) | 5, 234 | 13 | 127 | 27 | 107 | RR, 0.42; 95% Crl, 0.11 to 1.19^1, 5^
FGA vs. SGA
FGA vs. SGA | Any EPS | 4, 110 | 16 | 37 | 13 | 73 | RR, 2.59; 95% Crl, 1.00 to 7.00^4, 6, 7^
FGA vs. SGA
FGA vs. SGA | Akathisia | 4, 115 | 10 | 44 | 3 | 71 | RR, 4.30; 95% CrI, 0.93 to 22.71^3, 4^
FGA vs. SGA
FGA vs. SGA | Dystonia | 4, 115 | 8 | 44 | 1 | 71 | RR, 6.53; 95% Crl, 1.29 to 34.18^3, 4^
FGA vs. SGA
FGA vs. SGA | Weight (kg) | 14, 506 | NA | 190 | NA | 316 | MD, −2.67; 95% Crl, −4.61 to −0.70^1–4, 6, 8–12, 68^
FGA vs. SGA
FGA vs. SGA | Weight (kg) (6to<12) | 2, 54 | NA | 10 | NA | 13 | MD, −3.50; 95% CI, −10.24 to 3.24^1^
FGA vs. SGA | Weight (kg) (6to<12) | | NA | 10 | NA | 21 | MD, −3.40; 95% CI, −9.92 to 3.12^1^
FGA vs. SGA
FGA vs. SGA | BMI (kg·m^−2^) | 7, 236 | NA | 73 | NA | 163 | MD, −1.57; 95% Crl, −2.49 to −0.53^1, 3, 4, 13^
FGA vs. SGA
FGA vs. SGA | BMI (kg·m^−2^) (6to<12) | 2, 54 | NA | 10 | NA | 13 | MD, −0.70; 95% CI, −3.08 to 1.68^1^
FGA vs. SGA | BMI (kg·m^−2^) (6to<12) | | NA | 10 | NA | 21 | MD, −0.80; 95% CI, −3.15 to 1.55^1^
FGA vs. SGA
FGA vs. SGA | ≥7% increase in weight, see haloperidol vs. olanzapine | 2, 41
FGA vs. SGA
FGA vs. SGA | Increased total cholesterol, see various FGA’s vs. various SGA’s | 1, 48
FGA vs. SGA
FGA vs. SGA | Increased LDL | 0
FGA vs. SGA
FGA vs. SGA | Decreased HDL | 0
FGA vs. SGA
FGA vs. SGA | Increased triglycerides, see various FGA’s vs. various SGA’s | 1, 48
FGA vs. SGA
FGA vs. SGA | Increased fasting glucose, see various FGA’s vs. various SGA’s | 1, 48
FGA vs. SGA
FGA vs. SGA | Sedation | 7, 345 | 70 | 160 | 79 | 185 | RR, 1.05; 95% CrI, 0.75 to 1.89^1, 3, 4, 68^
FGA vs. SGA
FGA vs. SGA | Sedation (6to<12) | 2, 74 | 5 | 20 | 2 | 21 | RR, 2.63; 95% CI, 0.57 to 12.02^1^
FGA vs. SGA | Sedation (6to<12) | | 5 | 20 | 3 | 13 | RR, 1.08; 95% CI, 0.31 to 3.78^1^
FGA vs. SGA
FGA vs. SGA | Sedation (12+) | 3, 160 | 18 | 87 | 5 | 73 | RR, 2.84; 95% CrI, 0.34 to 92.81^5^
FGA vs. SGA
FGA vs. SGA | Somnolence | 3, 83 | 15 | 41 | 26 | 42 | RR, 0.53; 95% CrI, 0.14 to 1.75^6, 9, 12^
FGA vs. SGA
FGA vs. SGA | Hyperprolactinemia | 2, 45 | 9 | 10 | 0 | 15 | RR, 27.64; 95% CI, 1.79 to 427.25^14^
FGA vs. SGA | Hyperprolactinemia | | 9 | 10 | 7 | 10 | RR, 1.29; 95% CI, 0.82 to 2.03^14^
FGA vs. SGA
FGA vs. SGA | Hyperprolactinemia (12+) | 3, 160 | 0 | 29 | 0 | 28 | Not estimable^5^
FGA vs. SGA | Hyperprolactinemia (12+) | | 0 | 29 | 2 | 12 | RR, 0.09; 95% CI, 0.00 to 1.68^5^
FGA vs. SGA | Hyperprolactinemia (12+) | | 0 | 29 | 6 | 33 | RR, 0.09; 95% CI, 0.01 to 1.48^5^
FGA vs. SGA
FGA vs. SGA | Prolactin-related events | 3, 106 | 14 | 50 | 13 | 56 | RR, 1.20; 95% CrI, 0.39 to 3.85^3, 15^
FGA vs. SGA
FGA vs. SGA | Prolactin-related events (12+) | 3, 160 | 0 | 29 | 0 | 28 | Not estimable^5^
FGA vs. SGA | Prolactin-related events (12+) | | 0 | 29 | 0 | 12 | Not estimable^5^
FGA vs. SGA | Prolactin-related events (12+) | | 0 | 29 | 1 | 33 | RR, 0.38; 95% CI, 0.02 to 8.93^5^
Chlorpromazine vs Olanzapine | Any AE | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | AE limiting treatment | 1, 74 | 3 | 36 | 2 | 38 | RR, 1.58; 95% CI, 0.28 to 8.93^68^
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Any EPS | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Akathisia | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Dystonia | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Weight (kg) | 1, 74 | - | 36 | - | 38 | MD, −2.62; 95% Crl, −4.35 to −0.86^68^
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | BMI (kg·m^−2^) | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | ≥7% increase in weight | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Increased total cholesterol | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Increased LDL | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Decreased HDL | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Increased triglycerides | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Increased fasting glucose | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Sedation | 1, 74 | 32 | 36 | 33 | 38 | RR, 1.04; 95% CI, 0.86 to 1.37^68^
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Somnolence | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Hyperprolactinemia | 0
Chlorpromazine vs Olanzapine
Chlorpromazine vs Olanzapine | Prolactin-related events | 0
Haloperidol vs. aripiprazole | Any AE | 1, 48 | 17 | 17 | 25 | 31 | RR, 1.22; 95% CI, 1.01 to 1.48^2^
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | AE limiting treatment | 1, 48 | 6 | 17 | 5 | 31 | RR, 2.19; 95% CI, 0.78 to 6.12^2^
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Any EPS | 1, 48 | 7 | 17 | 6 | 31 | RR, 2.13; 95% CI, 0.85 to 5.32^2^
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Akathisia | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Dystonia | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Weight (kg) | 1, 48 | NA | 17 | NA | 31 | MD, 0.40; 95% CI, −0.41 to 1.21^2^
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | BMI (kg·m^−2^) | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | ≥7% increase in weight | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Increased total cholesterol | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Increased LDL | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Decreased HDL | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Increased triglycerides | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Increased fasting glucose | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Sedation | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Somnolence | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Hyperprolactinemia | 0
Haloperidol vs. aripiprazole
Haloperidol vs. aripiprazole | Prolactin-related events | 0
Haloperidol vs. clozapine | Any AE | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | AE limiting treatment | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | AE limiting treatment (12+) | 1, 57 | 1 | 29 | 4 | 28 | RR, 0.24; 95% CI, 0.03 to 2.03^5^
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Any EPS | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Akathisia | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Dystonia | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Weight (kg) | 1, 21 | NA | 11 | NA | 10 | MD, 0.04; 95% CI, −4.32 to 4.40^12^
Haloperidol vs. clozapine
Haloperidol vs. clozapine | BMI (kg·m^−2^) | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | ≥7% increase in weight | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Increased total cholesterol | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Increased LDL | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Decreased HDL | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Increased triglycerides | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Increased fasting glucose | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Sedation | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Sedation (12+) | 1, 57 | 6 | 29 | 4 | 28 | RR, 1.45; 95% CI, 0.46 to 4.59^5^
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Somnolence | 1, 21 | 3 | 11 | 9 | 10 | RR, 0.30; 95% CI, 0.11 to 0.81^12^
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Hyperprolactinemia | 1, 25 | 9 | 10 | 0 | 15 | RR, 27.64; 95% CI, 1.79 to 427.25^14^
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Hyperprolactinemia (12+) | 1, 57 | 0 | 29 | 0 | 28 | Not estimable^5^
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Prolactin-related events | 0
Haloperidol vs. clozapine
Haloperidol vs. clozapine | Prolactin-related events (12+) | 1, 57 | 0 | 29 | 0 | 28 | Not estimable^5^
Haloperidol vs. olanzapine | Any AE | 0
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | AE limiting treatment | 2, 57 | 0 | 7 | 0 | 19 | Not estimable^4^
Haloperidol vs. olanzapine | AE limiting treatment | | 7 | 15 | 0 | 16 | RR, 15.94; 95% CI, 0.99 to 256.93^3^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | AE limiting treatment (12+) | 1, 41 | 1 | 29 | 4 | 12 | RR, 0.10; 95% CI, 0.01 to 0.83^5^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Any EPS | 2, 38 | 1 | 6 | 0 | 6 | RR, 3.00; 95% CI, 0.15 to 61.74^6^
Haloperidol vs. olanzapine | Any EPS | | 4 | 7 | 3 | 19 | RR, 3.62; 95% CI, 1.07 to 12.27^4^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Akathisia | 2, 57 | 3 | 7 | 0 | 19 | RR, 17.50; 95% CI, 1.01 to 301.78^4^
Haloperidol vs. olanzapine | Akathisia | | 2 | 15 | 2 | 16 | RR, 1.07; 95% CI, 0.17 to 6.64^3^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Dystonia | 2, 57 | 2 | 7 | 0 | 19 | RR, 12.50; 95% CI, 0.67 to 232.59^4^
Haloperidol vs. olanzapine | Dystonia | | 2 | 15 | 0 | 16 | RR, 5.31; 95% CI, 0.28 to 102.38^3^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Weight (kg) | 3, 61 | NA | 18 | NA | 43 | MD, −3.87; 95% Crl, −11.3 to 2.80^3, 4, 6^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | BMI (kg·m^−2^) | 3, 69 | NA | 22 | NA | 47 | MD, −1.87; 95% Crl, −4.36 to 0.93^3, 4, 13^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | ≥7% increase in weight | 2, 41 | 2 | 6 | 6 | 6 | RR, 0.38; 95% CI, 0.14 to 1.06^6^
Haloperidol vs. olanzapine | ≥7% increase in weight | | 1 | 8 | 19 | 21 | RR, 0.14; 95% CI, 0.02 to 0.87^4^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Increased total cholesterol | 0
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Increased LDL | 0
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Decreased HDL | 0
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Increased triglycerides | 0
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Increased fasting glucose | 0
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Sedation | 2, 57 | 3 | 7 | 9 | 19 | RR, 0.90; 95% CI, 0.34 to 2.41^4^
Haloperidol vs. olanzapine | Sedation | | 14 | 15 | 15 | 16 | RR, 1.00; 95% CI, 0.83 to 1.20^3^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Sedation (12+) | 1, 41 | 6 | 29 | 0 | 12 | RR, 5.63; 95% CI 0.34 to 92.81^5^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Somnolence | 1, 12 | 2 | 6 | 5 | 6 | RR, 0.40; 95% CI, 0.12 to 1.31^6^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Hyperprolactinemia | 1, 20 | 9 | 10 | 7 | 10 | RR, 1.29; 95% CI, 0.82 to 2.03^14^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Hyperprolactinemia (12+) | 1, 41 | 0 | 29 | 2 | 12 | RR, 0.09; 95% CI, 0.00 to 1.68^5^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Prolactin-related events | 1, 31 | 4 | 15 | 3 | 16 | RR, 1.42; 95% CI, 0.38 to 5.33^3^
Haloperidol vs. olanzapine
Haloperidol vs. olanzapine | Prolactin-related events (12+) | 1, 41 | 0 | 29 | 0 | 12 | Not estimable^5^
Haloperidol vs. risperidone | Any AE | 0
Haloperidol vs. risperidone
Haloperidol vs. risperidone | AE limiting treatment | 2, 58 | 0 | 7 | 0 | 17 | Not estimable^4^
Haloperidol vs. risperidone | AE limiting treatment | | 7 | 15 | 5 | 19 | RR, 1.77; 95% CI, 0.70 to 4.48^3^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | AE limiting treatment (12+) | 1, 62 | 1 | 29 | 9 | 33 | RR, 0.13; 95% CI, 0.02 to 0.94^5^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Any EPS | 1, 24 | 4 | 7 | 4 | 17 | RR, 2.43; 95% CI, 0.83 to 7.08^4^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Akathisia | 2, 58 | 3 | 7 | 1 | 17 | RR, 7.29; 95% CI, 0.91 to 58.61^4^
Haloperidol vs. risperidone | Akathisia | | 2 | 15 | 0 | 19 | RR, 6.25; 95% CI, 0.32 to 121.14^3^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Dystonia | 2, 58 | 2 | 7 | 1 | 17 | RR, 4.86; 95% CI, 0.52 to 45.32^4^
Haloperidol vs. risperidone | Dystonia | | 2 | 15 | 0 | 19 | RR, 6.25; 95% CI, 0.32 to 121.14^3^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Weight (kg) | 3, 81 | NA | 26 | NA | 55 | MD, −2.02; 95% Crl, −9.40 to 6.30^3, 4, 8^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | BMI (kg·m^−2^) | 2, 51 | NA | 4 | NA | 21 | MD, −1.00; 95% CI, −2.47 to 0.47^4^
Haloperidol vs. risperidone | BMI (kg·m^−2^) | | NA | 7 | NA | 19 | MD, −0.40; 95% CI, −8.03 to 7.23^3^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | ≥7% increase in weight | 0
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Increased total cholesterol | 0
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Increased LDL | 0
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Decreased HDL | 0
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Increased triglycerides | 0
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Increased fasting glucose | 0
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Sedation | 2, 58 | 3 | 7 | 3 | 17 | RR, 2.43; 95% CI, 0.64 to 9.24^4^
Haloperidol vs. risperidone | Sedation | | 14 | 15 | 17 | 19 | RR, 1.04; 95% CI, 0.85 to 1.28^3^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Sedation (12+) | 1, 62 | 6 | 29 | 1 | 33 | RR, 6.83; 95% CI, 0.87 to 53.43^5^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Somnolence | 0
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Hyperprolactinemia | 0
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Hyperprolactinemia (12+) | 1, 62 | 0 | 29 | 6 | 33 | RR, 0.09; 95% CI, 0.01 to 1.48^5^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Prolactin-related events | 2, 75 | 4 | 15 | 4 | 19 | RR, 1.27; 95% CI, 0.38 to 4.24^3^
Haloperidol vs. risperidone | Prolactin-related events | | 6 | 20 | 6 | 21 | RR, 1.05; 95% CI, 0.41 to 2.72^15^
Haloperidol vs. risperidone
Haloperidol vs. risperidone | Prolactin-related events (12+) | 1, 62 | 0 | 29 | 1 | 33 | RR, 0.38; 95% CI, 0.02 to 8.93^5^
Molindone vs. olanzapine | Any AE | 1, 75 | 36 | 40 | 26 | 35 | RR, 1.21; 95% CI, 0.97 to 1.51^1^
Molindone vs. olanzapine
Molindone vs. olanzapine | Any AE (6to<12) | 1, 33 | 17 | 20 | 13 | 13 | RR, 0.86; 95% CI, 0.70 to 1.07^1^
Molindone vs. olanzapine
Molindone vs. olanzapine | AE limiting treatment | 1, 75 | 8 | 40 | 6 | 35 | RR, 1.17; 95% CI 0.45 to 3.04^1^
Molindone vs. olanzapine
Molindone vs. olanzapine | AE limiting treatment (12+) | 1, 33 | 5 | 20 | 3 | 13 | RR, 1.08; 95% CI, 0.31 to 3.78^1^
Molindone vs. olanzapine
Molindone vs. olanzapine | Any EPS | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Akathisia | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Dystonia | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Weight (kg) | 1, 55 | NA | 20 | NA | 35 | MD, −5.80; 95% CI, −7.54 to −4.06^1^
Molindone vs. olanzapine
Molindone vs. olanzapine | Weight (kg) (6to<12) | 1, 23 | NA | 10 | NA | 13 | MD, −3.50; 95% CI, −10.24 to 3.24^1^
Molindone vs. olanzapine
Molindone vs. olanzapine | BMI (kg·m^−2^) | 1, 55 | NA | 20 | NA | 35 | MD, −2.05; 95% CI, −2.73 to −1.37^1^
Molindone vs. olanzapine
Molindone vs. olanzapine | BMI (kg·m^−2^) (6to< 12) | 1, 23 | NA | 10 | NA | 13 | MD, −0.70; 95% CI, −3.08 to 1.68^1^
Molindone vs. olanzapine
Molindone vs. olanzapine | ≥7% increase in weight | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Increased total cholesterol | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Increased LDL | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Decreased HDL | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Increased triglycerides | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Increased fasting glucose | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Sedation | 1, 75 | 2 | 40 | 1 | 35 | RR, 1.75; 95% CI, 0.17 to 18.48^1^
Molindone vs. olanzapine
Molindone vs. olanzapine | Sedation (6to<12) | 1, 33 | 5 | 20 | 3 | 13 | RR, 1.08; 95% CI, 0.31 to 3.78^1^
Molindone vs. olanzapine
Molindone vs. olanzapine | Somnolence | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Hyperprolactinemia | 0
Molindone vs. olanzapine
Molindone vs. olanzapine | Prolactin-related events | 0
Molindone vs. risperidone | Any AE | 1, 81 | 36 | 40 | 35 | 41 | RR, 1.05; 95% CI, 0.90 to 1.24^1^
Molindone vs. risperidone
Molindone vs. risperidone | Any AE (6to<12) | 1, 41 | 17 | 20 | 15 | 21 | RR, 1.19; 95% CI, 0.86 to 1.65^1^
Molindone vs. risperidone
Molindone vs. risperidone | AE limiting treatment | 1, 81 | 8 | 40 | 5 | 41 | RR, 1.64; 95% CI, 0.59 to 4.59^1^
Molindone vs. risperidone
Molindone vs. risperidone | AE limiting treatment (12+) | 1, 41 | 5 | 20 | 7 | 21 | RR, 0.75; 95% CI, 0.28 to 1.98^1^
Molindone vs. risperidone
Molindone vs. risperidone | Any EPS | 0
Molindone vs. risperidone
Molindone vs. risperidone | Akathisia | 0
Molindone vs. risperidone
Molindone vs. risperidone | Dystonia | 0
Molindone vs. risperidone
Molindone vs. risperidone | Weight (kg) | 1, 61 | NA | 20 | NA | 41 | MD, −3.30; 95% CI, −5.06 to −1.54^1^
Molindone vs. risperidone
Molindone vs. risperidone | Weight (kg) (6to<12) | 1, 31 | NA | 10 | NA | 21 | MD, −3.40; 95% CI, −9.92 to 3.12^1^
Molindone vs. risperidone
Molindone vs. risperidone | BMI (kg·m^−2^) | 1, 61 | NA | 20 | NA | 41 | MD, −1.15; 95% CI, −1.87 to −0.43^1^
Molindone vs. risperidone
Molindone vs. risperidone | BMI (kg·m^−2^) (6to<12) | 1, 31 | NA | 10 | NA | 21 | MD, −0.80; 95% CI, −3.15 to 1.55^1^
Molindone vs. risperidone
Molindone vs. risperidone | ≥7% increase in weight | 0
Molindone vs. risperidone
Molindone vs. risperidone | Increased total cholesterol | 0
Molindone vs. risperidone
Molindone vs. risperidone | Increased LDL | 0
Molindone vs. risperidone
Molindone vs. risperidone | Decreased HDL | 0
Molindone vs. risperidone
Molindone vs. risperidone | Increased triglycerides | 0
Molindone vs. risperidone
Molindone vs. risperidone | Increased fasting glucose | 0
Molindone vs. risperidone
Molindone vs. risperidone | Sedation | 1, 81 | 2 | 40 | 1 | 41 | RR, 2.05; 95% CI, 0.19 to 21.72^1^
Molindone vs. risperidone
Molindone vs. risperidone | Sedation (6to<12) | 1, 41 | 5 | 20 | 2 | 21 | RR, 2.63; 95% CI, 0.57 to 12.02^1^
Molindone vs. risperidone
Molindone vs. risperidone | Somnolence | 0
Molindone vs. risperidone
Molindone vs. risperidone | Hyperprolactinemia | 0
Molindone vs. risperidone
Molindone vs. risperidone | Prolactin-related events | 0
Pimozide vs. risperidone | Any AE | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | AE limiting treatment | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Any EPS | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Akathisia | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Dystonia | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Weight (kg) | 2, 57 | NA | 7 | NA | 12 | MD, −1.80; 95% CI, −18.53 to 14.93^9^
Pimozide vs. risperidone | Weight (kg) | | NA | 19 | NA | 19 | MD, −0.90; 95% CI, −12.31 to 10.51^10^
Pimozide vs. risperidone
Pimozide vs. risperidone | BMI (kg·m^−2^) | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | ≥7% increase in weight | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Increased total cholesterol | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Increased LDL | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Decreased HDL | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Increased triglycerides | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Increased fasting glucose | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Sedation | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Somnolence | 1, 50 | 10 | 24 | 12 | 26 | RR, 0.90; 95% CI, 0.48 to 1.69^9^
Pimozide vs. risperidone
Pimozide vs. risperidone | Hyperprolactinemia | 0
Pimozide vs. risperidone
Pimozide vs. risperidone | Prolactin-related events | 0
Various FGA’s vs various SGA’s | Any AE | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | AE limiting treatment | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Any EPS | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Akathisia | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Dystonia | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Weight (kg) | 1, 48 | NA | 16 | NA | 32 | MD, −2.80; 95% CI, −5.33 to −0.27^11^
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | BMI (kg·m^−2^) | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | ≥7% increase in weight | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Increased total cholesterol | 1, 48 | 1 | 16 | 3 | 32 | RR, 0.67; 95% CI, 0.08 to 5.91^11^
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Increased LDL | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Decreased HDL | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Increased triglycerides | 1, 48 | 3 | 16 | 1 | 32 | RR, 6.00; 95% CI, 0.68 to 53.19^11^
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Increased fasting glucose | 1, 48 | 0 | 16 | 0 | 32 | Not estimable^11^
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Sedation | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Somnolence | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Hyperprolactinemia | 0
Various FGA’s vs various SGA’s
Various FGA’s vs various SGA’s | Prolactin-related events | 0

AE = adverse event; BMI = body mass index; CI = confidence interval; EPS = extrapyramidal symptoms; FGA = first generation antipsychotic; G1 = group 1; G2 = group 2; HDL = high density lipoprotein; LDL = low density lipoprotein; MD = mean difference; N = number; NA = not applicable; RR = risk ratio; SGA = second generation antipsychotic

Table G4 Findings for GAE: FGA versus FGA

Comparison (G1 vs. G2) | Outcome | N Studies, N Patients | G1 Events | G1 N | G2 Events | G2 N | Relative Effects
FGA vs. FGA | Any AE | 0
FGA vs. FGA | AE limiting treatment, see haloperidol vs. pimozide | 1, 44
FGA vs. FGA | Any EPS | 0
FGA vs. FGA | Akathisia | 0
FGA vs. FGA | Dystonia | 0
FGA vs. FGA | Weight (kg) | 0
FGA vs. FGA | BMI (kg·m^−2^) | 0
FGA vs. FGA | ≥7% increase in weight | 0
FGA vs. FGA | Increased total cholesterol | 0
FGA vs. FGA | Increased LDL | 0
FGA vs. FGA | Decreased HDL | 0
FGA vs. FGA | Increased triglycerides | 0
FGA vs. FGA | Increased fasting glucose | 0
FGA vs. FGA | Sedation (6to<12), see haloperidol continuous vs. haloperidol discontinuous | 1, 120
FGA vs. FGA | Somnolence | 0
FGA vs. FGA | Hyperprolactinemia | 0
FGA vs. FGA | Prolactin-related events | 0
Haloperidol continuous vs. haloperidol discontinuous | Any AE | 0
Haloperidol continuous vs. haloperidol discontinuous | AE limiting treatment | 0
Haloperidol continuous vs. haloperidol discontinuous | Any EPS | 0
Haloperidol continuous vs. haloperidol discontinuous | Akathisia | 0
Haloperidol continuous vs. haloperidol discontinuous | Dystonia | 0
Haloperidol continuous vs. haloperidol discontinuous | Weight (kg) | 0
Haloperidol continuous vs. haloperidol discontinuous | BMI (kg·m^−2^) | 0
Haloperidol continuous vs. haloperidol discontinuous | ≥7% increase in weight | 0
Haloperidol continuous vs. haloperidol discontinuous | Increased total cholesterol | 0
Haloperidol continuous vs. haloperidol discontinuous | Increased LDL | 0
Haloperidol continuous vs. haloperidol discontinuous | Decreased HDL | 0
Haloperidol continuous vs. haloperidol discontinuous | Increased triglycerides | 0
Haloperidol continuous vs. haloperidol discontinuous | Increased fasting glucose | 0
Haloperidol continuous vs. haloperidol discontinuous | Sedation (6to<12) | 1, 120 | 0 | 60 | 0 | 60 | Not estimable^16^
Haloperidol continuous vs. haloperidol discontinuous | Somnolence | 0
Haloperidol continuous vs. haloperidol discontinuous | Hyperprolactinemia | 0
Haloperidol continuous vs. haloperidol discontinuous | Prolactin-related events | 0
Haloperidol vs. pimozide | Any AE | 0
Haloperidol vs. pimozide | AE limiting treatment | 1, 44 | 9 | 22 | 3 | 22 | RR, 3.00; 95% CI, 0.94 to 9.62^17^
Haloperidol vs. pimozide | Any EPS | 0
Haloperidol vs. pimozide | Akathisia | 0
Haloperidol vs. pimozide | Dystonia | 0
Haloperidol vs. pimozide | Weight (kg) | 0
Haloperidol vs. pimozide | BMI (kg·m^−2^) | 0
Haloperidol vs. pimozide | ≥7% increase in weight | 0
Haloperidol vs. pimozide | Increased total cholesterol | 0
Haloperidol vs. pimozide | Increased LDL | 0
Haloperidol vs. pimozide | Decreased HDL | 0
Haloperidol vs. pimozide | Increased triglycerides | 0
Haloperidol vs. pimozide | Increased fasting glucose | 0
Haloperidol vs. pimozide | Sedation | 0
Haloperidol vs. pimozide | Somnolence | 0
Haloperidol vs. pimozide | Hyperprolactinemia | 0
Haloperidol vs. pimozide | Prolactin-related events | 0

AE = adverse event; BMI = body mass index; CI = confidence interval; EPS = extrapyramidal symptoms; FGA = first generation antipsychotic; G1 = group 1; G2 = group 2; HDL = high density lipoprotein; LDL = low density lipoprotein; MD = mean difference; N = number; NA = not applicable; RR = risk ratio

Table G5 Findings for GAE: SGA versus SGA

Comparison (G1 vs. G2) | Outcome | N Studies, N Patients | G1 Events | G1 N | G2 Events | G2 N | Relative Effects
Aripiprazole vs. Olanzapine | Any AE | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | AE limiting treatment | 1, 124 | 4 | 66 | 1 | 58 | RR, 3.52; 95% CI, 0.40 to 30.56^18^
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Any EPS | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Akathisia | 1, 124 | 5 | 66 | 3 | 58 | RR, 1.46; 95% CI, 0.37 to 5.86^18^
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Dystonia | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Weight (kg) | 1, 99 | NA | 47 | NA | 52 | MD, −4.12; 95% CI, −5.50 to −2.74^18^
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | BMI (kg·m^−2^) | 1, 99 | NA | 47 | NA | 52 | MD, −1.34; 95% CI, −1.85 to −0.83^18^
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | ≥7% increase in weight | 1, 86 | 24 | 41 | 38 | 45 | RR, 0.69; 95% CI, 0.52 to 0.92^18^
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Increased total cholesterol | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Increased LDL | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Decreased HDL | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Increased triglycerides | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Increased fasting glucose | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Sedation | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Somnolence | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Hyperprolactinemia | 0
Aripiprazole vs. Olanzapine
Aripiprazole vs. Olanzapine | Prolactin-related events | 0
Aripiprazole vs. Paliperidone | Any AE | 1, 227 | 76 | 114 | 87 | 113 | RR, 0.87; 95% CI, 0.73 to 1.02^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | AE limiting treatment | 1, 228 | 0 | 115 | 5 | 113 | RR, 0.09; 95% CI, 0.00 to 1.60^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Any EPS | 0
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Akathisia | 0
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Akathesia (6to<12) | 1, 226 | 6 | 114 | 7 | 112 | RR, 0.84; 95% CI, 0.29 to 2.43^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Dystonia | 0
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Weight (kg) | 1, 226 | NA | 114 | NA | 112 | MD, −1.28; 95% CI, −1.95 to −0.61^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Weight (kg) (6to<12) | 1, 226 | NA | 114 | NA | 112 | MD, −1.90; 95% CI, −2.96 to −0.84^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | BMI (kg·m^−2^) | 1, 226 | NA | 114 | NA | 112 | MD, −0.50; 95% CI, −0.74 to −0.26^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | BMI (kg·m^−2^) (6to<12) | 1, 226 | NA | 114 | NA | 112 | MD, −0.70; 95% CI, −1.07 to −0.33^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | ≥7% increase in weight | 0
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | ≥7% increase in weight (6to<12) | 1, 226 | 20 | 114 | 29 | 112 | RR, 0.68; 95% CI, 0.41 to 1.12^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Increased total cholesterol | 0
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Increased LDL | 0
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Decreased HDL | 0
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Increased triglycerides | 0
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Increased fasting glucose | 0
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Sedation | 1, 227 | 3 | 114 | 6 | 113 | RR, 0.50; 95% CI, 0.13 to 1.93^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Somnolence | 1, 227 | 12 | 114 | 12 | 113 | RR, 0.99; 95% CI, 0.47 to 2.11^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Hyperprolactinemia | 0
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Hyperprolactinemia (6to<12) | 1, 227 | 5 | 114 | 59 | 113 | RR, 0.04; 95% CI, 0.02 to 0.11^19^
Aripiprazole vs. Paliperidone
Aripiprazole vs. Paliperidone | Prolactin-related events | 0
Aripiprazole vs. Quetiapine | Any AE | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Any AE (6to<12) | 1, 73 | 25 | 62 | 10 | 11 | RR, 0.44; 95% CI, 0.31 to 0.63^20^
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | AE limiting treatment | 1, 132 | 4 | 66 | 0 | 66 | RR, 9.00; 95% CI,0.49 to 163.90^18^
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Any EPS | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Akathisia | 1, 132 | 5 | 66 | 1 | 66 | RR, 5.00; 95% CI, 0.60 to 41.65^18^
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Akathesia (6to<12) | 1, 73 | 5 | 62 | 1 | 11 | RR, 0.89; 95% CI, 0.11 to 6.88^20^
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Dystonia | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Weight (kg) | 1, 92 | NA | 47 | NA | 45 | MD, −1.63; 95% CI, −3.01 to −0.25^18^
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | BMI (kg·m^−2^) | 1, 92 | NA | 47 | NA | 45 | MD, −0.45; 95% CI, −0.96 to 0.06^18^
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | ≥7% increase in weight | 1, 77 | 24 | 41 | 20 | 36 | RR, 1.05; 95% CI, 0.71 to 1.56^18^
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Increased total cholesterol | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Increased LDL | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Decreased HDL | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Increased triglycerides | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Increased fasting glucose | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Sedation | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Sedation (6to<12) | 1, 73 | 1 | 62 | 1 | 11 | RR, 0.18; 95% CI, 0.01 to 2.63^20^
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Somnolence | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Hyperprolactinemia | 0
Aripiprazole vs. Quetiapine
Aripiprazole vs. Quetiapine | Prolactin-related events | 0
Aripiprazole vs. Risperidone | Any AE | 1, 69 | 8 | 34 | 12 | 35 | RR, 0.69; 95% CI, 0.32 to 1.47^21^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Any AE (6to<12) | 1, 114 | 25 | 62 | 39 | 52 | RR, 0.54; 95% CI, 0.38 to 0.76^20^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | AE limiting treatment | 2, 272 | 0 | 34 | 0 | 35 | Not estimable^21^
Aripiprazole vs. Risperidone | AE limiting treatment | | 4 | 66 | 6 | 137 | RR, 1.38; 95% CI, 0.40 to 4.74^18^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Any EPS | 0
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Akathisia | 2, 263 | 5 | 66 | 7 | 137 | RR, 1.48; 95% CI, 0.49 to 4.50^18^
Aripiprazole vs. Risperidone | Akathisia | | 0 | 31 | 0 | 29 | Not estimable^22^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Akathesia (6to<12) | 1, 114 | 5 | 62 | 3 | 52 | RR, 1.40; 95% CI, 0.35 to 5.57^20^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Dystonia | 1, 59 | 3 | 29 | 1 | 30 | RR, 3.10; 95% CI, 0.34 to 28.15^23^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Weight (kg) | 1, 215 | NA | 47 | NA | 168 | MD, −0.90; 95% CI, −1.81 to 0.01^18^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | BMI (kg·m^−2^) | 1, 215 | NA | 47 | NA | 168 | MD, −0.25; 95% CI, −0.62 to 0.12^18^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | BMI (kg·m^−2^) (12+) | 1, 142 | NA | 70 | NA | 72 | MD, −0.31; 95% CI, −1.78 to 1.16^24^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | ≥7% increase in weight | 2, 245 | 24 | 41 | 87 | 135 | RR, 0.91; 95% CI, 0.68 to 1.21^18^
Aripiprazole vs. Risperidone | ≥7% increase in weight | | 0 | 34 | 7 | 35 | RR, 0.07; 95% CI, 0.58 to 1.04^21^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Increased total cholesterol | 0
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Increased LDL | 0
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Decreased HDL | 0
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Increased triglycerides | 0
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Increased fasting glucose | 0
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Sedation | 1, 56 | 1 | 27 | 0 | 29 | RR, 3.21; 95% CI, 0.14 to 75.68^23^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Sedation (6to<12) | 1, 114 | 1 | 62 | 2 | 52 | RR, 0.42; 95% CI, 0.04 to 4.49^20^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Somnolence | 2, 116 | 6 | 27 | 5 | 29 | RR, 1.29; 95% CI, 0.44 to 3.74^23^
Aripiprazole vs. Risperidone | Somnolence | | 8 | 31 | 5 | 29 | RR, 1.50; 95% CI, 0.55 to 4.05^22^
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Hyperprolactinemia | 0
Aripiprazole vs. Risperidone
Aripiprazole vs. Risperidone | Prolactin-related events | 0
Aripiprazole vs. Ziprasidone | Any AE | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | AE limiting treatment | 2, 115 | 2 | 20 | 6 | 14 | RR, 0.23; 95% CI, 0.05 to 0.99^25^
Aripiprazole vs. Ziprasidone | AE limiting treatment | | 4 | 66 | 0 | 15 | RR, 2.15; 95% CI, 0.12 to 37.92^18^
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Any EPS | 1, 34 | 2 | 40 | 0 | 14 | RR, 3.57; 95% CI, 0.18 to 69.14^25^
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Akathisia | 1, 81 | 5 | 66 | 0 | 15 | RR, 2.63; 95% CI, 0.15 to 45.11^18^
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Dystonia | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Weight (kg) | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | BMI (kg·m^−2^) | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | ≥7% increase in weight | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Increased total cholesterol | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Increased LDL | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Decreased HDL | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Increased triglycerides | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Increased fasting glucose | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Sedation | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Somnolence | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Hyperprolactinemia | 0
Aripiprazole vs. Ziprasidone
Aripiprazole vs. Ziprasidone | Prolactin-related events | 0
Clozapine vs. Olanzapine | Any AE | 2, 109 | 1 | 2 | 15 | 24 | RR, 0.80; 95% CI, 0.19 to 3.31^26^
Clozapine vs. Olanzapine | Any AE | | 12 | 55 | 13 | 28 | RR, 0.47; 95% CI, 0.25 to 0.89^27^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | AE limiting treatment | 2, 65 | 0 | 2 | 9 | 24 | RR, 0.44; 95% CI, 0.03 to 5.78^26^
Clozapine vs. Olanzapine | AE limiting treatment | | 2 | 18 | 1 | 21 | RR, 2.33; 95% CI, 0.23 to 23.66^28^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | AE limiting treatment (12+) | 2, 65 | 1 | 12 | 0 | 13 | RR, 3.23; 95% CI, 0.14 to 72.46^27^
Clozapine vs. Olanzapine | AE limiting treatment (12+) | | 4 | 28 | 4 | 12 | RR, 0.43; 95% CI, 0.13 to 1.44^5^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Any EPS | 0
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Akathisia | 1, 32 | 1 | 16 | 1 | 16 | RR, 1.00; 95% CI, 0.07 to 14.64^29^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Dystonia | 2, 58 | 0 | 2 | 1 | 24 | RR, 2.78; 95% CI, 0.14 to 54.04^26^
Clozapine vs. Olanzapine | Dystonia | | 1 | 16 | 1 | 16 | RR, 1.00; 95% CI, 0.07 to 14.64^29^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Weight (kg) | 5, 136 | NA | 62 | NA | 74 | MD, −1.56; 95% CrI, −5.12 to 1.57^27–31^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Weight (kg) (6to<12) | 1, 23 | NA | 15 | NA | 8 | MD, −6.70; 95% CI, −14.76 to 1.36^29^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | BMI (kg·m^−2^) | 3, 87 | NA | 40 | NA | 47 | MD, −0.66; 95% CrI, −2.59 to 1.23^27–29^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | BMI (kg·m^−2^) (6to<12) | 2, 40 | NA | 15 | NA | 8 | MD, −2.30; 95% CI, −5.42 to 0.82^29^
Clozapine vs. Olanzapine | BMI (kg·m^−2^) (6to<12) | | NA | 8 | NA | 9 | MD, 1.00; 95% CI, −2.67 to 4.67^32^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | ≥7% increase in weight | 2, 69 | 5 | 15 | 9 | 15 | RR, 0.56; 95% CI, 0.24 to 1.27^29^
Clozapine vs. Olanzapine | ≥7% increase in weight | | 3 | 18 | 2 | 21 | RR, 1.75; 95% CI, 0.33 to 9.34^28^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | ≥7% increase in weight (6to<12) | 2, 63 | 9 | 15 | 7 | 8 | RR, 0.69; 95% CI, 0.42 to 1.12^29^
Clozapine vs. Olanzapine | ≥7% increase in weight (6to<12) | | 1 | 28 | 3 | 12 | RR, 0.14; 95% CI, 0.02 to 1.24^32^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Increased total cholesterol | 2, 55 | 2 | 13 | 4 | 17 | RR, 0.65; 95% CI, 0.14 to 3.04^28^
Clozapine vs. Olanzapine | Increased total cholesterol | | 1 | 12 | 0 | 13 | RR, 3.23; 95% CI, 0.23 to 3.55^27^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Increased LDL | 0
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Decreased HDL | 0
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Increased triglycerides | 2, 57 | 10 | 14 | 8 | 18 | RR, 1.61; 95% CI, 0.87 to 2.97^28^
Clozapine vs. Olanzapine | Increased triglycerides | | 1 | 12 | 0 | 13 | RR, 3.23; 95% CI, 0.14 to 72.46^27^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Increased fasting glucose | 0
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Sedation | 1, 26 | 0 | 2 | 0 | 24 | Not estimable^26^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Sedation (12+) | 1, 40 | 4 | 28 | 0 | 12 | RR, 4.03; 95% CI, 0.23 to 69.58^5^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Somnolence | 3, 96 | 20 | 46 | 21 | 50 | RR, 1.09; 95% CrI, 0.41 to 2.75^27–29^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Hyperprolactinemia | 2, 51 | 0 | 2 | 2 | 24 | RR, 1.67; 95% CI, 0.10 to 27.14^26^
Clozapine vs. Olanzapine | Hyperprolactinemia | | 0 | 15 | 7 | 10 | RR, 0.05; 95% CI, 0.00 to 0.72^14^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Hyperprolactinemia (12+) | 1, 40 | 0 | 28 | 2 | 12 | RR, 0.09; 95% CI, 0.00 to 1.74^5^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Prolactin-related events | 1, 25 | 1 | 12 | 0 | 13 | RR, 3.23; 95% CI, 0.14 to 72.46^27^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | Prolactin-related events (12+) | 1, 40 | 0 | 28 | 0 | 12 | Not estimable^5^
Clozapine vs. Quetiapine | Any AE | 1, 4 | 1 | 2 | 1 | 2 | RR, 1.00; 95% CI, 0.14 to 7.10^26^
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | AE limiting treatment | 1, 4 | 0 | 2 | 1 | 2 | RR, 0.33; 95% CI, 0.02 to 5.33^26^
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Any EPS | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Akathisia | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Dystonia | 1, 4 | 0 | 2 | 0 | 2 | Not estimable^26^
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Weight (kg) | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | BMI (kg·m^−2^) | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | ≥7% increase in weight | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Increased total cholesterol | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Increased LDL | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Decreased HDL | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Increased triglycerides | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Increased fasting glucose | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Sedation | 1, 4 | 0 | 2 | 0 | 2 | Not estimable^26^
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Somnolence | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Hyperprolactinemia | 0
Clozapine vs. Quetiapine
Clozapine vs. Quetiapine | Prolactin-related events | 0
Clozapine vs. Risperidone | Any AE | 1, 47 | 1 | 2 | 33 | 45 | RR, 0.68; 95% CI, 0.17 to 2.76^26^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | AE limiting treatment | 1, 31 | 0 | 2 | 13 | 29 | RR, 0.37; 95% CI, 0.03 to 4.80^26^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | AE limiting treatment (12+) | 1, 61 | 4 | 28 | 9 | 33 | RR, 0.52; 95% CI, 0.18 to 1.52^5^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Any EPS | 0
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Akathisia | 1, 35 | 1 | 16 | 0 | 19 | RR, 3.53; 95% CI, 0.15 to 81.11^18^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Dystonia | 2, 82 | 0 | 2 | 1 | 45 | RR, 5.11; 95% CI, 0.26 to 100.62^26^
Clozapine vs. Risperidone | Dystonia | | 1 | 16 | 2 | 19 | RR, 0.59; 95% CI, 0.06 to 5.96^29^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Weight (kg) | 2, 89 | NA | 15 | NA | 15 | MD, −0.30; 95% CI, −1.91 to 1.31^29^
Clozapine vs. Risperidone | Weight (kg) | | NA | 7 | NA | 52 | MD,-1.50: 95% CI, −4.55 to 1.55^30^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Weight (kg) (6to<12) | 1, 25 | NA | 15 | NA | 10 | MD, 2.30; 95% CI, −3.90 to 8.50^29^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | BMI (kg·m^−2^) | 1, 30 | NA | 15 | NA | 15 | MD, −0.20; 95% CI, −0.77 to 0.37^29^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | BMI (kg·m^−2^) (6to<12) | 2, 57 | NA | 15 | NA | 10 | MD, 1.00; 95% CI, −0.95 to 2.85^29^
Clozapine vs. Risperidone | BMI (kg·m^−2^) (6to<12) | | NA | 8 | NA | 24 | MD, 3.80; 95% CI, 1.37 to 6.23^32^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | ≥7% increase in weight | 1, 30 | 5 | 15 | 4 | 15 | RR, 1.25; 95% CI, 0.41 to 3.77^29^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | ≥7% increase in weight (6to<12) | 2, 86 | 9 | 15 | 6 | 10 | RR, 1.00; 95% CI, 0.52 to 1.92^29^
Clozapine vs. Risperidone | ≥7% increase in weight (6to<12) | | 1 | 28 | 2 | 33 | RR, 0.59; 95% CI, 0.06 to 6.16^32^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Increased total cholesterol | 0
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Increased LDL | 0
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Decreased HDL | 0
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Increased triglycerides | 0
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Increased fasting glucose | 0
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Sedation | 1, 47 | 0 | 2 | 3 | 45 | RR, 2.19; 95% CI, 0.14 to 33.36^26^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Sedation (12+) | 1, 61 | 4 | 28 | 1 | 33 | RR, 4.71; 95% CI, 0.56 to 39.78^5^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Somnolence | 1, 35 | 9 | 16 | 6 | 19 | RR, 1.78; 95% CI, 0.81 to 3.93^29^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Hyperprolactinemia | 1, 47 | 0 | 2 | 11 | 45 | RR, 0.67; 95% CI, 0.05 to 8.79^26^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Hyperprolactinemia (12+) | 1, 61 | 0 | 28 | 6 | 33 | RR, 0.09; 95% CI, 0.01 to 1.53^5^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Prolactin-related events | 1, 47 | 0 | 2 | 5 | 45 | RR, 1.39; 95% CI, 0.10 to 19.71^26^
Clozapine vs. Risperidone
Clozapine vs. Risperidone | Prolactin-related events (12+) | 1, 61 | 0 | 28 | 1 | 33 | RR, 0.39; 95% CI, 0.02 to 9.23^5^
Olanzapine vs. Quetiapine | Any AE | 1, 26 | 15 | 24 | 1 | 2 | RR, 1.25; 95% CI, 0.30 to 5.17^26^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | AE limiting treatment | 2, 150 | 9 | 24 | 1 | 2 | RR, 0.75; 95% CI, 0.17 to 3.29^26^
Olanzapine vs. Quetiapine | AE limiting treatment | | 1 | 58 | 0 | 66 | RR, 3.41; 95% CI, 0.14 to 82.04^18^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | AE limiting treatment (6to<12) | 2, 84 | 0 | 26 | 0 | 24 | Not estimable^33^
Olanzapine vs. Quetiapine | AE limiting treatment (6to<12) | | 2 | 18 | 1 | 16 | RR, 1.78; 95% CI, 0.18 to 17.80^32^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | AE limiting treatment (12+) | 1, 34 | 5 | 18 | 1 | 16 | RR, 4.44; 95% CI, 0.58 to 34.14^32^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Any EPS
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Akathisia | 3, 194 | 13 | 94 | 8 | 100 | RR, 1.65; 95% CrI, 0.42 to 8.06^18, 33, 34^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Akathisia (6to<12) | 2, 79 | 8 | 26 | 6 | 24 | RR, 1.26; 95% CI, 0.50 to 3.03^33^
Olanzapine vs. Quetiapine | Akathisia (6to<12) | | 0 | 14 | 0 | 15 | Not estimable^32^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Dystonia | 1, 26 | 1 | 24 | 0 | 2 | RR, 0.36; 95% CI, 0.02 to 7.00^26^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Dystonia (6to<12) | 1, 29 | 0 | 14 | 0 | 15 | Not estimable^32^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Weight (kg) | 3, 232 | NA | 116 | NA | 116 | MD, 4.00; 95% CrI, −1.67 to 10.79^18, 35, 36^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Weight (kg) (6to<12) | 3, 185 | NA | 90 | NA | 95 | MD, 7.91; 95% CrI, 3.65 to 12.29^33, 35, 36^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | BMI (kg·m^−2^) | 3, 232 | NA | 116 | NA | 116 | MD, 1.36; 95% CrI, −0.29 to 3.40^18, 35, 36^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | BMI (kg·m^−2^) (6to<12) | 4, 203 | NA | 99 | NA | 104 | MD, 2.68; 95% CrI, 0.96 to 4.27^32, 33, 35, 36^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | ≥7% increase in weight | 3, 192 | 72 | 99 | 47 | 93 | RR, 1.41; 95% CrI, 0.65 to 2.83^18, 34, 35^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | ≥7% increase in weight (6to<12) | 1, 91 | 18 | 44 | 22 | 47 | RR, 0.87; 95% CI, 0.55 to 1.40^35^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Increased total cholesterol | 1, 33 | 0 | 13 | 1 | 20 | RR, 0.5; 95% CI, 0.02 to 11.42^37^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Increased LDL | 0
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Decreased HDL | 0
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Increased triglycerides | 1, 33 | 1 | 13 | 1 | 20 | RR, 1.54: 95% CI, 0.11 to 22.49^37^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Increased fasting glucose | 0
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Sedation | 2, 46 | 0 | 24 | 0 | 2 | Not estimable^26^
Olanzapine vs. Quetiapine | Sedation | | 3 | 10 | 1 | 10 | RR, 3.00; 95% CI, 0.37 to 24.17^34^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Sedation (6to<12) | 1, 50 | 12 | 26 | 11 | 24 | RR, 1.01; 95% CI, 0.55 to 1.84^33^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Somnolence | 0
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Hyperprolactinemia | 2, 45 | 2 | 24 | 0 | 2 | RR, 0.60; 95% CI, 0.04 to 9.77^26^
Olanzapine vs. Quetiapine | Hyperprolactinemia | | 5 | 13 | 1 | 6 | RR, 2.31; 95% CI, 0.34 to 15.69^38^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Hyperprolactinemia (12+) | 1, 28 | 3 | 12 | 2 | 16 | RR, 2.00; 95% CI, 0.39 to 10.16^37^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Prolactin-related events | 1, 19 | 3 | 13 | 2 | 6 | RR, 0.69; 95% CI, 0.15 to 3.12^38^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | Prolactin-related events (6to<12) | 1, 50 | 0 | 26 | 0 | 24 | Not estimable^33^
Olanzapine vs. Risperidone | Any AE | 3, 199 | 50 | 73 | 97 | 126 | RR, 0.87; 95% CrI, 0.49 to 1.55^1, 26, 39^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Any AE (6to<12) | 1, 34 | 13 | 13 | 15 | 21 | RR, 1.37; 95% CI, 1.03 to 1.83^1^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | AE limiting treatment | 6, 436 (1 Study n=36 no events) | 16 | 164 | 30 | 272 | RR, 0.87; 95% CrI, 0.21 to 2.18^1, 3, 4, 18, 26, 40^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | AE limiting treatment (6to<12) | 1, 69 | 2 | 18 | 5 | 51 | RR, 1.13; 95% CI, 0.24 to 5.34^32^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | AE limiting treatment (12+) | 3, 148 | 12 | 43 | 23 | 105 | RR, 1.23; 95% CrI, 0.36 to 4.09^1, 5, 32^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Any EPS | 3, 115 | 13 | 45 | 19 | 70 | RR, 0.94; 95% CrI, 0.30 to 2.82^4, 39, 40^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Akathisia | 9, 507 | 20 | 192 | 24 | 315 | RR, 1.17; 95% CrI, 0.59 to 2.40^1, 3, 4, 18, 29, 34, 39–41^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Akathisia (6to<12) | 1, 45 | 0 | 14 | 4 | 31 | RR, 0.24; 95%CI, 0.01 to 4.13^32^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Dystonia | 5, 270 | 10 | 108 | 13 | 162 | RR, 1.65; 95% CrI, 0.44 to 6.07^1, 3, 4, 26, 29, 39^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Dystonia (6to<12) | 1, 45 | 0 | 14 | 1 | 31 | RR, 0.71; 95% CI, 0.03 to 16.45^32^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Weight (kg) | 13, 936 | NA | 331 | NA | 605 | MD, 2.18; 95% CrI, 1.13 to 3.25^1, 3, 4, 18, 29, 30, 35, 36, 40–44^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Weight (kg) (6to<12) | 4, 295 | NA | 85 | NA | 210 | MD, 4.40; 95% CrI, −0.54 to 9.86^1, 33, 35, 36^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | BMI (kg·m^−2^) | 9, 737 | NA | 244 | NA | 493 | MD, 0.94; 95% CrI, 0.64 to 1.30^1, 3, 4, 18, 29, 35, 36, 44, 45^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | BMI (kg·m^−2^) (6to<12) | 5, 328 | NA | 94 | NA | 234 | MD, 1.66; 95% CrI, 0.19 to 3.42^1, 32, 33, 35, 36^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | ≥7% increase in weight | 6, 504 | 107 | 150 | 188 | 354 | RR, 1.36; 95% CrI, 0.93 to 2.04^4, 18, 29, 34, 35, 41^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | ≥7% increase in weight (6to<12) | 3, 264 | 28 | 64 | 64 | 200 | RR, 1.44; 95% CrI, 0.55 to 5.50}^5, 29, 35^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Increased total cholesterol | 1, 34 | 0 | 13 | 1 | 21 | RR, 0.52; 95% CI, 0.02 to 11.98^37^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Increased LDL | 0
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Decreased HDL | 0
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Increased triglycerides | 1, 34 | 1 | 13 | 5 | 21 | RR, 0.32; 95% CI, 0.04 to 2.47^37^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Increased fasting glucose | 1, 49 | 0 | 25 | 0 | 24 | Not estimable^45^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Sedation | 7, 321 | 35 | 133 | 36 | 188 | RR, 1.19; 95% CrI, 0.68 to 2.35^1, 3, 4, 26, 34, 39, 42^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Sedation (6to<12) | 1, 34 | 3 | 13 | 2 | 21 | RR, 2.42; 95% CI, 0.47 to 12.62^1^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Sedation (12+) | 1, 45 | 0 | 12 | 1 | 33 | RR, 0.87; 95% CI, 0.04 to 20.06^5^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Somnolence | 2, 66 | 9 | 16 | 6 | 19 | RR, 1.78; 95% CI, 0.81 to 3.93^29^
Olanzapine vs. Risperidone | Somnolence | | 3 | 12 | 13 | 19 | RR, 0.37; 95% CI, 0.13 to 1.02^41^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Hyperprolactinemia | 3, 128 | 7 | 49 | 27 | 79 | RR, 0.46; 95% CrI, 0.11 to 1.70^26, 38, 40^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Hyperprolactinemia (12+) | 2, 75 | 3 | 12 | 9 | 18 | RR, 0.50; 95% CI, 0.17 to 1.48^37^
Olanzapine vs. Risperidone | Hyperprolactinemia (12+) | | 2 | 12 | 6 | 33 | RR, 0.92; 95% CI, 0.21 to 3.94^5^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Prolactin-related events | 5, 221 | 7 | 84 | 16 | 137 | RR, 0.78; 95% CrI, 0.24 to 2.35^3, 26, 38, 41, 46^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Prolactin-related events (6to<12) | 1, 34 | 3 | 13 | 2 | 21 | RR, 2.42; 95% CI, 0.47 to 12.62^1^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | Prolactin-related events (12+) | 1, 45 | 0 | 12 | 1 | 33 | RR, 0.87; 95% CI, 0.04 to 20.06^5^
Olanzapine vs. Ziprasidone | Any AE | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | AE limiting treatment | 1, 73 | 1 | 58 | 0 | 15 | RR, 0.81; 95% CI, 0.03 to 19.03^18^
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Any EPS
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Akathisia | 1, 73 | 3 | 58 | 0 | 15 | RR, 1.90; 95% CI, 0.10 to 34.89)^18^
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Dystonia | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Weight (kg) | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | BMI (kg·m^−2^) | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | ≥7% increase in weight | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Increased total cholesterol | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Increased LDL | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Decreased HDL | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Increased triglycerides | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Increased fasting glucose | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Sedation | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Somnolence | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Hyperprolactinemia | 0
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | Prolactin-related events | 0
Quetiapine vs. Risperidone | Any AE | 1, 47 | 1 | 2 | 33 | 45 | RR, 0.68; 95% CI, 0.17 to 2.76^26^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Any AE (6to<12) | 1, 63 | 10 | 11 | 39 | 52 | RR, 1.21; 95% CI, 0.95 to 1.55^20^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | AE limiting treatment | 2, 250 | 1 | 2 | 13 | 45 | RR, 1.73; 95% CI, 0.40 to 7.45^26^
Quetiapine vs. Risperidone | AE limiting treatment | | 0 | 66 | 6 | 137 | RR, 0.16; 95% CI, 0.01 to 2.77^18^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | AE limiting treatment (6to<12) | 1, 67 | 1 | 16 | 5 | 51 | RR, 0.64; 95% CI, 0.08 to 5.06^32^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | AE limiting treatment (12+) | 1, 67 | 1 | 16 | 7 | 51 | RR, 0.46; 95% CI, 0.06 to 3.43^32^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Any EPS | 1, 22 | 0 | 12 | 0 | 10 | Not estimable^47^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Akathisia | 2, 223 | 1 | 66 | 7 | 137 | RR, 0.30; 95% CI, 0.04 to 2.36^18^
Quetiapine vs. Risperidone | Akathisia | | 1 | 10 | 4 | 10 | RR, 0.25; 95% CI, 0.03 to 1.86^34^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Akathisia (6to<12) | 2, 109 | 1 | 11 | 3 | 52 | RR, 1.58; 95% CI, 0.18 to 13.77^20^
Quetiapine vs. Risperidone | Akathisia (6to<12) | | 0 | 15 | 4 | 31 | RR, 0.22; 95% CI, 0.01 to 3.88^32^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Dystonia | 1, 47 | 0 | 2 | 1 | 45 | RR, 5.11; 95% CI, 0.26 to 100.62^26^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Dystonia (6to<12) | 1, 46 | 0 | 15 | 1 | 31 | RR, 0.67; 95% CI, 0.03 to 15.46^32^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Weight (kg) | 3, 463 | NA | 116 | NA | 347 | MD, 0.08; 95% CrI, −3.77 to 3.14^18, 35, 36^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Weight (kg) (6to<12) | 3, 295 | NA | 93 | NA | 202 | MD, −1.48; 95% CI, −4.16 to 1.18^35, 36, 71^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | BMI (kg·m^−2^) | 3, 463 | NA | 116 | NA | 347 | MD, 0.04; 95% CrI, −1.34 to 1.20^18, 35, 36^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | BMI (kg·m^−2^) (6to<12) | 4, 328 | NA | 102 | NA | 226 | MD, −0.32; 95% CrI, −1.56 to 1.12^32, 35, 36, 71^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | ≥7% increase in weight | 4, 417 | 55 | 104 | 176 | 313 | RR, 0.91; 95% CrI, 0.56 to 1.44^18, 34, 35, 48^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | ≥7% increase in weight (6to<12) | 1, 204 | 22 | 47 | 56 | 157 | RR, 1.31; 95% CI, 0.91 to 1.90^35^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Increased total cholesterol | 1, 41 | 1 | 20 | 1 | 21 | RR, 1.05; 95% CI, 0.07 to 15.68^37^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Increased LDL | 0
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Decreased HDL | 0
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Increased triglycerides | 1, 41 | 1 | 20 | 5 | 21 | RR, 0.21; 95% CI, 0.03 to 1.64^37^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Increased fasting glucose | 0
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Sedation | 3, 89 | 8 | 23 | 12 | 66 | RR, 0.98; 95% CrI, 0.22 to 4.28^26, 34, 48^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Sedation (6to<12) | 1, 63 | 1 | 11 | 2 | 52 | RR, 2.36; 95% CI, 0.23 to 23.83^20^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Somnolence | 1, 22 | 3 | 12 | 1 | 10 | RR, 2.50; 95% CI, 0.31 to 20.45^47^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Hyperprolactinemia | 4, 118 | 4 | 31 | 45 | 87 | RR, 0.20; 95% CrI, 0.06 to 0.73^26, 38, 47, 48^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Hyperprolactinemia (12+) | 1, 34 | 2 | 16 | 9 | 18 | RR, 0.25; 95% CI, 0.06 to 0.99^37^
Quetiapine vs. Risperidone
Quetiapine vs. Risperidone | Prolactin-related events | 2, 74 | 0 | 2 | 5 | 45 | RR, 1.39; 95% CI, 0.10 to 19.71^26^
Quetiapine vs. Risperidone | Prolactin-related events | | 2 | 6 | 5 | 21 | RR, 1.40; 95% CI, 0.36 to 5.49^38^
Quetiapine vs. Ziprasidone | Any AE | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | AE limiting treatment | 1, 81 | 0 | 66 | 0 | 15 | Not estimable^18^
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Any EPS | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Akathisia | 1, 81 | 1 | 66 | 0 | 15 | RR, 0.72; 95% CI, 0.03 to 16.78^18^
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Dystonia | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Weight (kg) | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | BMI (kg·m^−2^) | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | ≥7% increase in weight | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Increased total cholesterol | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Increased LDL | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Decreased HDL | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Increased triglycerides | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Increased fasting glucose | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Sedation | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Somnolence | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Hyperprolactinemia | 0
Quetiapine vs. Ziprasidone
Quetiapine vs. Ziprasidone | Prolactin-related events | 0
Risperidone vs. Ziprasidone | Any AE | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | AE limiting treatment | 1, 152 | 6 | 137 | 0 | 15 | RR, 1.51; 95% CI, 0.09 to 25.53^18^
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Any EPS
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Akathisia | 1, 152 | 7 | 137 | 0 | 15 | RR, 1.74; 95% CI, 0.10 to 29.05^18^
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Dystonia | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Weight (kg) | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | BMI (kg·m^−2^) | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | ≥7% increase in weight | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Increased total cholesterol | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Increased LDL | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Decreased HDL | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Increased triglycerides | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Increased fasting glucose | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Sedation | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Somnolence | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Hyperprolactinemia | 0
Risperidone vs. Ziprasidone
Risperidone vs. Ziprasidone | Prolactin-related events | 0

AE = adverse event; BMI = body mass index; CI = confidence interval; EPS = extrapyramidal symptoms; G1 = group 1; G2 = group 2; HDL = high density lipoprotein; LDL = low density lipoprotein; MD = mean difference; N = number; NA = not applicable; RR = risk ratio; SGA = second generation antipsychotic

Table G6 Findings for GAE: Dose comparisons - aripiprazole

Outcome | Author, Year | Low Dose | | Medium Dose | | High dose (1) | | High dose (2) | | High dose (3) | | High dose (4)
| Findling 2008a(1)^49^ | | | 10 mg/day | | | | | | | | 30mg/day
| Findling 2008b(2)^50^ | | | | | | | 20 mg/day | | 25 mg/day | | 30mg/day
| Findling 2009(3)^51^ | | | 10 mg/day | | | | | | | | 30 mg/day
| Marcus 2009(4)^52^ | 5 mg/day | | 10 mg/day | | 15 mg/day
| | Count | N | Count | N | Count | N | Count | N | Count | N | Count | N
Any AE | 2 | - | - | - | - | - | - | 8 | 8 | 7 | 7 | 6 | 6
Any AE | 3 | - | - | 72 | 98 | - | - | - | - | - | - | 75 | 99
Any AE | 4 | 45 | 52 | 53 | 59 | 45 | 54 | - | - | - | - | - | -
AE limiting treatment | 1 | - | - | 7 | 100 | - | - | - | - | - | - | 4 | 102
AE limiting treatment | 2 | - | - | - | - | - | - | 0 | 8 | 1 | 7 | 0 | 6
AE limiting treatment | 3 | - | - | 4 | 98 | - | - | - | - | - | - | 7 | 99
AE limiting treatment | 3 (6to<12) | - | - | 3 | 75 | - | - | - | - | - | - | 11 | 71
≥7% increase in weight | 4 | 5 | 52 | 8 | 59 | 4 | 54 | - | - | - | - | - | -
≥7% increase in weight | 1 | - | - | 11 | 99 | - | - | - | - | - | - | 9 | 97
≥7% increase in weight | 3 | - | - | 4 | 98 | - | - | - | - | - | - | 12 | 99
≥7% increase in weight | 4 | 17 | 52 | 9 | 59 | 16 | 54 | - | - | - | - | - | -
High cholesterol | 3 | - | - | 27 | 64 | - | - | - | - | - | - | 28 | 65
High cholesterol | 3 (6to<12) | - | - | 30 | 73 | - | - | - | - | - | - | 34 | 68
High cholesterol | 4 | 0 | 52 | 0 | 59 | 0 | 54 | - | - | - | - | - | -
High LDL | 4 | 0 | 52 | 0 | 59 | 0 | 54 | - | - | - | - | - | -
Low HDL | 3 | - | - | 10 | 65 | - | - | - | - | - | - | 9 | 65
Low HDL | 3 (6to<12) | - | - | 13 | 73 | - | - | - | - | - | - | 6 | 67
Low HDL | 4 | 1 | 52 | 0 | 59 | 2 | 54 | - | - | - | - | - | -
High triglycerides | 3 | - | - | 22 | 65 | - | - | - | - | - | - | 22 | 65
High triglycerides | 3 (6to<12) | - | - | 21 | 73 | - | - | - | - | - | - | 28 | 67
High triglycerides | 4 | 6 | 52 | 6 | 59 | 2 | 54 | - | - | - | - | - | -
High fasting glucose | 1 | - | - | 2 | 86 | - | - | - | - | - | - | 0 | 79
High fasting glucose | 3 | - | - | 1 | 65 | - | - | - | - | - | - | 2 | 64
High fasting glucose | 3 (6to<12) | - | - | 0 | 73 | - | - | - | - | - | - | 2 | 67
High fasting glucose | 4 | 6 | 52 | 6 | 59 | 1 | 54 | - | - | - | - | - | -
Prolactin-related events | 3 (6to<12) | - | - | 3 | 75 | - | - | - | - | - | - | 0 | 71
Any EPS | 3 | - | - | 23 | 98 | - | - | - | - | - | - | 39 | 99
Any EPS | 3 (6to<12) | - | - | 3 | 75 | - | - | - | - | - | - | 2 | 71
Any EPS | 4 | 12 | 52 | 13 | 59 | 12 | 54 | - | - | - | - | - | -
Akathisia | 1 | - | - | 5 | 100 | - | - | - | - | - | - | 12 | 102
Akathisia | 3 | - | - | 8 | 98 | - | - | - | - | - | - | 11 | 99
Akathisia | 3 (6to<12) | - | - | 1 | 75 | - | - | - | - | - | - | 2 | 71
Akathisia | 4 | 1 | 52 | 2 | 59 | 0 | 54 | - | - | - | - | - | -
Dystonia | 1 | - | - | 4 | 100 | - | - | - | - | - | - | 2 | 102
Dystonia | 2 | - | - | - | - | - | - | 1 | 8 | 1 | 7 | 0 | 6
Dystonia | 3 | - | - | 0 | 98 | - | - | - | - | - | - | 5 | 99
Dystonia | 3 (6to<12) | - | - | 2 | 75 | - | - | - | - | - | - | 1 | 71
Somnolence | 1 | - | - | 11 | 100 | - | - | - | - | - | - | 22 | 102
Somnolence | 2 | - | - | - | - | 1 | 8 | 0 | 7 | 1 | 6 | - | -
Somnolence | 3 | - | - | 19 | 98 | - | - | - | - | - | - | 27 | 99
Somnolence | 3 (6to<12) | - | - | 5 | 75 | - | - | - | - | - | - | 1 | 71
Somnolence | 4 | 4 | 52 | 5 | 59 | 5 | 54 | - | - | - | - | - | -
Sedation | 2 | - | - | - | - | - | - | 0 | 8 | 0 | 7 | 1 | 6
Sedation | 3 | - | - | 2 | 98 | - | - | - | - | - | - | 0 | 99
Sedation | 4 | 9 | 52 | 17 | 59 | 13 | 54 | - | - | - | - | - | -
| | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N
BMI (kg·m^−2^) | 1 | - | - | 0.0(0.8) | 99 | - | - | - | - | - | - | 0.0(0.8 | 97
BMI (kg·m^−2^) | 3 | - | - | 0.2(0.8) | 75 | - | - | - | - | - | - | 0.3(1.1) | 72
BMI (kg·m^−2^) | 4 | 0.6 (0.2) | 52 | 0.6(0.2) | 59 | 0.8 (0.2) | 59 | - | - | - | - | - | -
Weight (kg) | 1 | - | - | 0.0(2.1) | 100 | - | - | - | - | - | - | 0.2(2.3) | 102
Weight (kg) | 2 | - | - | - | - | - | - | −0.2(2.5) | 8 | 0.9(2.3) | 7 | 0.4(1.8) | 6
Weight (kg) | 3 | - | - | 0.8(1.7) | 75 | - | - | - | - | - | - | 1.1(2.3) | 73
Weight (kg) | 3 (6to<12) | - | - | 6.5(NR) | 75 | - | - | - | - | - | - | 6.6(NR) | 71
Weight (kg) | 4 | 1.3 (2.2) | 53 | 1.3 | 59 | 1.5(2.2) | 54 | - | - | - | - | - | -

AE = adverse event; BMI = body mass index; EPS = extrapyramidal symptoms; HDL = high density lipoprotein; LDL = low density lipoprotein; N = number

Table G7 Findings for GAE: Dose comparisons - asenapine

Outcome | Author, Year | Low Dose | | Medium Dose | | High dose
| Findling 2015a(1)^53^ | 5 mg/day | | 10 mg/day
| Findling 2015b(2)^54^ | 5 mg/day | | 10 mg/day | | 20 mg/day
| | Count | N | Count | N | Count | N
Any AE | 1 | 61 | 98 | 71 | 106 | - | -
Any AE | 2 | 78 | 104 | 72 | 99 | 85 | 99
AE limiting treatment | 1 | 6 | 98 | 8 | 106 | - | -
AE limiting treatment | 2 | 7 | 104 | 3 | 99 | 5 | 99
≥7% increase in weight | 1 | 9 | 95 | 10 | 99 | - | -
≥7% increase in weight | 2 | 11 | 92 | 8 | 90 | 7 | 87
Hyperprolactinemia | 1 | 23 | 98 | 20 | 106 | - | -
Any EPS | 1 | 5 | 98 | 11 | 106 | - | -
Any EPS | 2 | 4 | 104 | 4 | 99 | 5 | 99
Akathisia | 1 | 4 | 98 | 7 | 106 | - | -
Akathisia | 2 | 2 | 104 | 2 | 99 | 1 | 99
Somnolence | 1 | 24 | 98 | 31 | 106 | - | -
Somnolence | 2 | 49 | 104 | 52 | 99 | 48 | 99
Metabolic syndrome | 1 | 1 | 98 | 2 | 106 | - | -
| | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N
BMI (kg·m^−2^) | 2 | 0.60(0.79) | 104 | 0.57(0.89) | 99 | 0.49(0.81) | 99
Weight (kg) | 1 | 0.09(0.21) | 95 | 0.06(0.20) | 99 | - | -

AE = adverse event; BMI = body mass index; EPS = extrapyramidal symptoms; N = number

Table G8 Findings for GAE: Dose comparisons lurasidone

Outcome | Author, Year | Low Dose | | Medium Dose | | High dose (1) | | High dose (2) | | High dose (3) | | High dose (4)
| Findling 2015(1) ^69^ | 20 mg | | 40 mg | | | | 80 mg | | 120 mg | | 160 mg
| Loebel 2016(2) ^70^ | 20 mg | | | | 60mg
| | Count | N | Count | N | Count | N | Count | N | Count | N | Count | N
Any AE | 1 | 4 | 20 | 17 | 25 | - | - | 17 | 19 | 24 | 25 | 16 | 16
Any AE | 2 | 35 | 49 | | | 38 | 51
AE limiting treatment | 1 | 0 | 20 | 3 | 25 | - | - | 5 | 19 | 1 | 25 | 0 | 16
AE limiting treatment | 2 | 2 | 49 | | | 2 | 51
Akathisia | 2 | 3 | 49 | | | 3 | 51
Dystonia | 1 | 0 | 20 | 0 | 25 | - | - | 0 | 19 | 4 | 25 | 2 | 16
Sedation | 1 | 0 | 20 | 3 | 25 | - | - | 5 | 19 | 7 | 25 | 4 | 16
Sedation | 2 | 3 | 49 | | | 1 | 51
Somnolence | 1 | 0 | 20 | 11 | 25 | - | - | 7 | 19 | 16 | 25 | 10 | 16
Somnolence | 2 | 3 | 49 | | | 9 | 51
| | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N | Mean (SD)
BMI | 2 | 0.3(6.5) | 49 | | | 3.3(9.5) | 51
Weight (kg) | 2 | 0.8 (5.4) | 49 | | | 2.7(6.5) | 51

Table G9 Findings for GAE: Dose comparisons - paliperidone

Outcome | Author, Year | Low Dose | | Medium Dose | | High dose (1) | | High dose (2)
| Johnson 2011(1)^56^ | | | 6 mg/day | | 9 mg/day | | 12 mg/day
| Singh 2011(2)^57^ | 1.5 mg/day | | 3/6 mg/day | | | | 6/12 mg/day
| | Count | N | Count | N | Count | N | Count | N
Any AE | 1 | | | 3 | 8 | 6 | 9 | 6 | 8
Any AE | 2 | 27 | 54 | 32 | 48 | | | 36 | 48
AE limiting treatment | 1 | | | 0 | 8 | 0 | 9 | 0 | 8
AE limiting treatment | 2 | 1 | 54 | 1 | 48 | | | 1 | 48
≥7% increase in weight | 2 | 3 | 54 | 6 | 48 | - | - | 6 | 47
Hyperprolactinemia | 1 | - | - | 4 | 8 | 6 | 9 | 3 | 8
Prolactin-related events | 1 | | | 0 | 8 | 0 | 9 | 0 | 8
Prolactin-related events | 2 | 0 | 54 | 2 | 48 | | | 0 | 48
Akathisia | 2 | 2 | 54 | 4 | 48 | - | - | 7 | 47
Dystonia | 2 | 1 | 54 | 1 | 48 | - | - | 4 | 47
Somnolence | 2 | 3 | 54 | 7 | 48 | - | - | 10 | 48
| | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N
Weight (kg) | 2 | 0.3(1.52) | 54 | 1.1(2.13) | 48 | - | - | 1.4(2.16) | 48

AE = adverse event; N = number

Table G10 Findings for GAE: Dose comparisons - quetiapine

Outcome | Author, Year | Low Dose | | Medium Dose | | High dose (1) | | High dose (2)
| Berger 2008(1)^58^ | 200 mg/day | | 400 mg/day
| Findling 2012a(2)^59^ | | | 400 mg/day | | | | 800 mg/day
| Pathak 2013(3)^60^ | | | 400 mg/day | | 600 mg/day
| | Count | N | Count | N | Count | N | Count | N
Any AE | 1 | 1 | 46 | 3 | 45 | - | - | - | -
Any AE | 2 | - | - | 58 | 73 | - | - | 55 | 74
AE limiting treatment | 2 | - | - | 5 | 73 | - | - | 7 | 74
AE limiting treatment | 3 | - | - | 15 | 95 | 7 | 98 | - | -
≥7% increase in weight | 2 | - | - | 17 | 73 | - | - | 14 | 74
≥7% increase in weight | 3 | - | - | 14 | 95 | 10 | 98 | - | -
High cholesterol | 3 | - | - | 15 | 55 | 15 | 54 | - | -
High cholesterol | | - | - | - | - | - | - | - | -
High LDL | 3 | - | - | 0 | 90 | 1 | 85 | - | -
Low HDL | 3 | - | - | 2 | 77 | 13 | 77 | - | -
High Triglycerides | 3 | - | - | 14 | 76 | 15 | 73 | - | -
High fasting glucose | 3 | - | - | 1 | 86 | 1 | 81 | - | -
Hyperprolactinemia | 2 | - | - | 1 | 40 | - | - | 3 | 36
Hyperprolactinemia | 3 | - | - | 12 | 76 | 10 | 81 | - | -
Any EPS | 2 | 9 | 73 | - | - | 10 | 74
Any EPS | 3 | 4 | 95 | 3 | 98 | - | -
Somnolence | 2 | - | - | 20 | 73 | - | - | 22 | 74
Somnolence | 3 | - | - | 27 | 95 | 31 | 98 | - | -
Sedation | 2 | - | - | 4 | 73 | - | - | 4 | 74
Sedation | 3 | - | - | 22 | 95 | 25 | 98 | - | -
| | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N
Weight (kg) | 1 | - | - | 2.2(2.6) | 73 | - | - | 1.8(2.8) | 74
Weight (kg) | 2 | - | - | 1.7(1.98) | 95 | 1.7(2.34) | 98 | - | -

AE = adverse event; EPS = extrapyramidal symptoms; HDL = high density lipoprotein; LDL = low density lipoprotein; N = number

Table G11 Findings for GAE: Dose comparisons - risperidone

Outcome | Author, Year | Low Dose | | Medium Dose | | High dose (1) | | High dose (2)
| Haas 2009a(1)^61^ | 0.15–0.6 mg/day | | | | 1.5–6 mg/day
| Haas 2009b(2)^62^ | | | 1–3 mg/day | | | | 4–6 mg/day
| Haas 2009c(3)^63^ | | | 0.5–2.5 mg/day
| Kent 2013(4)^64^ | 0.125/0.175 mg/day | | 1.25/1.75 mg/day | | | | 3–6 mg/day
| | Count | N | Count | N | Count | N | Count | N
Any AE | 1 | 86 | 132 | - | - | 93 | 125 | - | -
Any AE | 2 | - | - | 41 | 55 | - | - | 39 | 51
Any AE | 3 | - | - | 45 | 50 | - | - | 58 | 61
Any AE | 4 | 18 | 30 | 27 | 31 | - | - | - | -
AE limiting treatment | 1 | 6 | 132 | - | - | 5 | 125 | - | -
AE limiting treatment | 2 | - | - | 3 | 55 | - | - | 4 | 51
AE limiting treatment | 3 | - | - | 3 | 50 | - | - | 10 | 61
AE limiting treatment | 4 | 0 | 30 | 1 | 31 | - | - | - | -
≥7% increase in weight | 3 | - | - | 7 | 50 | - | - | 6 | 61
Hyperprolactinemia | 1 | 55 | 132 | - | - | 70 | 125 | - | -
Prolactin-related events | 1 | 2 | 132 | - | - | 7 | 125 | - | -
Prolactin-related events | 2 | - | - | 0 | 55 | - | - | 0 | 51
Prolactin-related events | 3 | - | - | 2 | 50 | - | - | 3 | 61
Prolactin-related events | 4 | 0 | 30 | 1 | 31 | - | - | - | -
Any EPS | 1 | 13 | 132 | - | - | 41 | 125 | - | -
Any EPS | 2 | - | - | 18 | 55 | - | - | 20 | 51
Any EPS | 3 | - | | 4 | 50 | - | - | 15 | 61
Akathisia | 1 | 2 | 132 | - | - | 11 | 125 | - | -
Dystonia | 1 | 8 | 132 | - | - | 23 | 125 | - | -
Somnolence | 2 | - | - | 13 | 55 | - | - | 6 | 51
Somnolence | 3 | - | - | 21 | 50 | - | - | 34 | 61
Somnolence | 4 | 0 | 30 | 7 | 31 | - | - | - | -
Sedation | 3 | - | - | 10 | 50 | - | - | 13 | 61
Sedation | 4 | 1 | 30 | 8 | 31 | - | - | - | -
| | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N | Mean (SD) | N
BMI (kg·m^−2^) | 2 | - | - | 0.36(NR) | 55 | - | - | 0.48(NR) | 51
BMI (kg·m^−2^) | 3 | - | - | 0.7(0.9) | 50 | - | - | 0.5(0.9) | 61
BMI (kg·m^−2^) | 4 | 0.4(0.7) | 30 | 1.1(1.35) | 31 | - | - | - | -
Weight (kg) | 1 | 1.7 | 132 | - | - | 3.2(3.49) | 125 | - | -
Weight (kg) | 2 | - | - | 1.3(NR) | 55 | - | - | 1.5(NR) | 51
Weight (kg) | 3 | - | - | 1.9(1.7) | 50 | - | - | 1.4(2.4) | 61
Weight (kg) | 4 | 1.2 | 30 | 2.4(2.07) | 31 | - | - | - | -

AE = adverse event; BMI = body mass index; EPS = extrapyramidal symptoms; N = number

Table G12 Findings for GAE: Dose comparisons - ziprasidone

Outcome | Author, Year | Low Dose | | High Dose
| Delbello 2008(1)^65^ | 80 mg/day | | 160 mg/day
| | Count | N | Count | N
Any AE | 1 | 21 | 23 | 38 | 40
AE limiting treatment | 1 | 3 | 23 | 16 | 40
≥7% increase in weight | 1 | 3 | 23 | 1 | 40
High fasting glucose | 1 | 0 | 23 | 0 | 40
Akathisia | 1 | 1 | 23 | 3 | 40
Dystonia | 1 | 1 | 23 | 3 | 40
Somnolence | 1 | 5 | 23 | 15 | 40
Sedation | 1 | 5 | 23 | 15 | 40

AE = adverse event; N = number

Table G13 Findings for GAE: FGA versus placebo

Comparison (G1 vs. G2) | Outcome | N Studies, N Patients | G1 Events | G1 N | G2 Events | G2 N | Relative Effects
FGA vs. placebo | Any AE | 0
FGA vs. placebo
FGA vs. placebo | AE limiting treatment | 3, 153 | 22 | 77 | 11 | 76 | RR, 2.43; 95% Crl, 0.47 to 23.08^17, 66^
FGA vs. placebo
FGA vs. placebo | Any EPS | 0
FGA vs. placebo
FGA vs. placebo | Akathisia | 0
FGA vs. placebo
FGA vs. placebo | Dystonia, see haloperidol | 1, 66
FGA vs. placebo
FGA vs. placebo | Dystonia (12+), see haloperidol | 1, 66
FGA vs. placebo
FGA vs. placebo | Weight (kg), see various FGA’s | 2, 40
FGA vs. placebo
FGA vs. placebo | BMI (kg·m^−2^) | 0
FGA vs. placebo
FGA vs. placebo | ≥7% increase in weight | 0
FGA vs. placebo
FGA vs. placebo | Increased total cholesterol, see various FGA’s | 1, 40
FGA vs. placebo
FGA vs. placebo | Increased LDL | 0
FGA vs. placebo
FGA vs. placebo | Decreased HDL | 0
FGA vs. placebo
FGA vs. placebo | Increased triglycerides, see various FGA’s | 1, 40
FGA vs. placebo
FGA vs. placebo | Increased fasting glucose, see various FGA’s | 1, 40
FGA vs. placebo
FGA vs. placebo | Sedation | 0
FGA vs. placebo
FGA vs. placebo | Somnolence, see haloperidol | 1, 72
FGA vs. placebo
FGA vs. placebo | Hyperprolactinemia | 0
FGA vs. placebo
FGA vs. placebo | Prolactin-related events | 0
Haloperidol vs. placebo | Any AE | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | AE limiting treatment | 2, 109 | 10 | 33 | 11 | 32 | RR, 0.88; 95% CI, 0.44 to 1.78^66^
Haloperidol vs. placebo | AE limiting treatment | | 9 | 22 | 0 | 22 | RR, 19.00; 95% CI, 1.17 to 307.63^17^
Haloperidol vs. placebo
Haloperidol vs. placebo | Any EPS | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | Akathisia | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | Dystonia | 1, 66 | 1 | 33 | 0 | 33 | RR, 3.00; 95% CI, 0.13 to 71.07^66^
Haloperidol vs. placebo
Haloperidol vs. placebo | Dystonia (12+) | 1, 66 | 9 | 33 | 0 | 33 | RR, 19.00; 95% CI, 1.15 to 313.64^67^
Haloperidol vs. placebo
Haloperidol vs. placebo | Weight (kg) | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | BMI (kg·m^−2^) | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | ≥7% increase in weight | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | Increased total cholesterol | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | Increased LDL | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | Decreased HDL | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | Increased triglycerides | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | Increased fasting glucose | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | Sedation | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | Somnolence | 1, 72 | 5 | 36 | 0 | 36 | RR, 11.00; 95% CI, 0.63 to 191.88^66^
Haloperidol vs. placebo
Haloperidol vs. placebo | Hyperprolactinemia | 0
Haloperidol vs. placebo
Haloperidol vs. placebo | Prolactin-related events | 0
Pimozide vs. placebo | Any AE | 0
Pimozide vs. placebo
Pimozide vs. placebo | AE limiting treatment | 1, 44 | 3 | 22 | 0 | 22 | RR, 7.00; 95% CI, 0.38 to 128.02^17^
Pimozide vs. placebo
Pimozide vs. placebo | Any EPS | 0
Pimozide vs. placebo
Pimozide vs. placebo | Akathisia | 0
Pimozide vs. placebo
Pimozide vs. placebo | Dystonia | 0
Pimozide vs. placebo
Pimozide vs. placebo | Weight (kg) | 0
Pimozide vs. placebo
Pimozide vs. placebo | BMI (kg·m^−2^) | 0
Pimozide vs. placebo
Pimozide vs. placebo | ≥7% increase in weight | 0
Pimozide vs. placebo
Pimozide vs. placebo | Increased total cholesterol | 0
Pimozide vs. placebo
Pimozide vs. placebo | Increased LDL | 0
Pimozide vs. placebo
Pimozide vs. placebo | Decreased HDL | 0
Pimozide vs. placebo
Pimozide vs. placebo | Increased triglycerides | 0
Pimozide vs. placebo
Pimozide vs. placebo | Increased fasting glucose | 0
Pimozide vs. placebo
Pimozide vs. placebo | Sedation | 0
Pimozide vs. placebo
Pimozide vs. placebo | Somnolence | 0
Pimozide vs. placebo
Pimozide vs. placebo | Hyperprolactinemia | 0
Pimozide vs. placebo
Pimozide vs. placebo | Prolactin-related events | 0
Various FGA’s vs. placebo | Any AE | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | AE limiting treatment | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Any EPS | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Akathisia | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Dystonia | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Weight (kg) | 1, 40 | NA | 16 | NA | 24 | MD, 0.87; 95% CI, −1.58 to 3.32^11^
Various FGA’s vs. placebo
Various FGA’s vs. placebo | BMI (kg·m^−2^) | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | ≥7% increase in weight | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Increased total cholesterol | 1, 40 | 1 | 16 | 0 | 24 | RR, 4.41; 95% CI, 0.19 to 102.00^11^
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Increased LDL | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Decreased HDL | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Increased triglycerides | 1, 40 | 3 | 16 | 1 | 24 | RR, 4.50; 95% CI, 0.51 to 39.53^11^
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Increased fasting glucose | 1, 40 | 0 | 16 | 0 | 24 | Not estimable^11^
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Sedation | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Somnolence | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Hyperprolactinemia | 0
Various FGA’s vs. placebo
Various FGA’s vs. placebo | Prolactin-related events | 0

AE = adverse event; BMI = body mass index; CI = confidence interval; EPS = extrapyramidal symptoms;FGA = first generation antipsychotic; G1 = group 1; G2 = group 2; HDL = high density lipoprotein; LDL = low density lipoprotein; MD = mean difference; N = number; NA = not applicable; RR = risk ratio

Table G14 Findings for GAE: SGA versus placebo

Comparison (G1 vs. G2) | Outcome | N Studies, N Patients | G1 Events | G1 N | G2 Events | G2 N | Relative Effects
SGA vs. placebo | Any AE | 27, 3667 | 1448 | 2332 | 707 | 1335 | RR, 1.25; 95% CrI, 1.16 to 1.35^1–26, 70^
SGA vs. placebo
SGA vs. placebo | Any AE (6to<12) see risperidone | 1, 335
SGA vs. placebo
SGA vs. placebo | Any AE (12+) | 2, 233 | 10 | 43 | 13 | 44 | RR, 0.79; 95% CI, 0.39 to 1.60^27^
SGA vs. placebo | Any AE (12+) | | 41 | 98 | 25 | 48 | RR, 0.80; 95% CI, 0.56 to 1.15^28^
SGA vs. placebo
SGA vs. placebo | AE limiting treatment | 24, 4043 | 183 | 2644 | 65 | 1399 | RR, 1.47; 95% CrI, 1.05 to 2.13^2, 4–6, 8, 9, 11, 14, 17, 19, 21, 23–26, 29–31, 70^
SGA vs. placebo | AE limiting treatment | 5, 348 | | | | | Not estimable^1, 15, 18, 32, 33^
SGA vs. placebo
SGA vs. placebo | AE limiting treatment (6to<12) | 3, 584 | 14 | 146 | 0 | 64 | RR, 12.82; 95% CI, 0.78 to 211.72^5^
SGA vs. placebo | AE limiting treatment (6to<12) | | | | | | RR, 1.90; 95% CI, 0.17 to 20.70^34^
SGA vs. placebo | AE limiting treatment (6to<12) | | 2 | 172 | 1 | 163 | Not estimable^35^
SGA vs. placebo | AE limiting treatment (6to<12) | | 0 | 19 | 0 | 20
SGA vs. placebo
SGA vs. placebo | AE limiting treatment (12+) | 3, 266 | 0 | 30 | 0 | 30 | Not estimable^36^
SGA vs. placebo | AE limiting treatment (12+) | | 1 | 98 | 1 | 48 | RR, 0.49; 95% CI, 0.03 to 7.66^28^
SGA vs. placebo | AE limiting treatment (12+) | | 1 | 31 | 1 | 29 | RR, 0.94; 95% CI, 0.06 to 14.27^37^
SGA vs. placebo
SGA vs. placebo | Any EPS | 15, 2730 | 233 | 1757 | 40 | 973 | RR, 2.94; 95% CI, 2.02 to 4.27^1, 2, 5, 7, 9, 13, 14^ {^Snyder, 2002^ #^116, 20, 21, 23, 25, 29, 38, 39^
SGA vs. placebo | Any EPS | 2, 32 | | | | | Not estimable^31, 40^
SGA vs. placebo
SGA vs. placebo | Any EPS (6to<12) | 2, 629 | 62 | 197 | 7 | 97 | RR, 4.36; 95% CI, 2.08 to 9.17^5^
SGA vs. placebo | Any EPS (6to<12) | | 3 | 172 | 1 | 163 | RR, 2.84; 95% CI, 0.30 to 27.06^34^
SGA vs. placebo
SGA vs. placebo | Akathisia | 21, 3638 | 151 | 2433 | 56 | 1205 | RR, 1.29; 95% CrI, 0.81 to 2.27^2, 4, 5, 7–9, 11, 16, 19, 21, 23–26, 29, 30, 38, 41–43, 70^
SGA vs. placebo
SGA vs. placebo | Akathisia (6to<12) | 2, 629 | 20 | 197 | 2 | 97 | RR, 4.92; 95% CI, 1.17 to 20.64^5^
SGA vs. placebo | Akathisia (6to<12) | | 0 | 172 | 0 | 163 | Not estimable^34^
SGA vs. placebo
SGA vs. placebo | Dystonia | 6, 1497 | 21 | 1032 | 4 | 465 | RR, 1.65; 95% Crl, 0.44 to 6.07^5, 7, 8, 11, 24, 29^
SGA vs. placebo | Dystonia | 4, 194 | | | | | Not estimable^14, 16, 17, 44^
SGA vs. placebo
SGA vs. placebo | Dystonia (6to<12) | 3, 652 | 7 | 197 | 2 | 97 | RR, 1.72; 95% CI, 0.36 to 8.14^5^
SGA vs. placebo | Dystonia (6to<12) | | 2 | 172 | 1 | 163 | RR, 1.90; 95% CI, 0.17 to 20.70^34^
SGA vs. placebo | Dystonia (6to<12) | | 0 | 11 | 0 | 12 | Not estimable^44^
SGA vs. placebo
SGA vs. placebo | Weight (kg) | 37, 3919 | NA | 2384 | NA | 1535 | MD, 1.53; 95% CI, 1.11 to 1.98^1, 2, 4, 5, 7, 10–22, 24–26, 29, 30, 32, 33, 37–40, 42, 43, 45–49, 70^
SGA vs. placebo
SGA vs. placebo | Weight (kg) (6to<12), see risperidone | 4, 467
SGA vs. placebo
SGA vs. placebo | Weight (kg) (12+) | 2, 119 | NA | 30 | NA | 30 | MD, 2.19; 95% CI, 0.73 to 3.65^36^
SGA vs. placebo | Weight (kg) (12+) | | NA | 30 | NA | 29 | MD, 8.49; 95% CI, 4.90 to 12.08^37^
SGA vs. placebo
SGA vs. placebo | BMI (kg·m^−2^) | 16, 2462 | NA | 1582 | NA | 880 | MD, 0.66; 95% CI, 0.44 to 0.91^2, 4, 5, 7, 8, 15, 18, 19, 21, 29, 30, 34, 40, 42, 48, 70^
SGA vs. placebo
SGA vs. placebo | BMI (kg·m^−2^) (6to<12), see risperidone | 2, 405
SGA vs. placebo
SGA vs. placebo | ≥7% increase in weight | 17, 3057 | 337 | 2023 | 42 | 1034 | RR, 3.53; 95% Crl, 2.49 to 5.23^1, 2, 4, 5, 8–13, 21, 22, 29, 30, 37, 39, 42^
SGA vs. placebo
SGA vs. placebo | ≥7% increase in weight (6to<12), see risperidone | 1, 70
SGA vs. placebo
SGA vs. placebo | Increased total cholesterol | 6, 643 | 92 | 410 | 13 | 233 | RR, 3.17; 95% CI, 1.29 to 9.13^4, 5, 30, 39, 40, 49^
SGA vs. placebo | Increased total cholesterol | 2, 218 | | | | | Not estimable^2, 37^
SGA vs. placebo
SGA vs. placebo | Increased total cholesterol (6to<12), see aripiprazole | 1, 198
SGA vs. placebo
SGA vs. placebo | Increased LDL | 3, 384 | 4 | 239 | 0 | 145 | RR, 2.71; 95% CrI, 0.32 to 23.42^4, 39, 40^
SGA vs. placebo | Increased LDL | 2, 294 | | | | | Not estimable^2, 30^
SGA vs. placebo
SGA vs. placebo | Decreased HDL | 6, 839 | 46 | 564 | 24 | 275 | RR, 0.95; 95% Crl, 0.48 to 2.04^2, 4, 5, 30, 39, 40^
SGA vs. placebo
SGA vs. placebo | Decreased HDL (6to<12), see aripiprazole | 1, 197
SGA vs. placebo
SGA vs. placebo | Increased triglycerides | 10, 1383 | 130 | 897 | 38 | 486 | RR, 1.64; 95% Crl, 1.09 to 2.63^2, 4, 5, 13, 30, 39, 40, 42, 46, 49^
SGA vs. placebo
SGA vs. placebo | Increased triglycerides (6to<12), see aripiprazole | 1, 197
SGA vs. placebo
SGA vs. placebo | Increased fasting glucose | 7, 1204 | 10 | 797 | 5 | 407 | RR, 0.85; 95% Crl, 0.26 to 2.76^2, 5, 29, 30, 39, 40, 46^
SGA vs. placebo | Increased fasting glucose | 2, 154 | | | | | Not estimable^4, 49^
SGA vs. placebo
SGA vs. placebo | Increased fasting glucose (6to<12), see aripiprazole | 1, 197
SGA vs. placebo
SGA vs. placebo | Sedation | 21, 2710 | 288 | 1696 | 79 | 1014 | RR, 2.19; 95% CrI, 1.50 to 3.41^2, 4, 5, 7, 9, 10, 12, 13, 17, 19, 21, 24, 26, 32, 39, 40, 42, 43, 46, 50, 70^
SGA vs. placebo
SGA vs. placebo | Sedation (6to<12) see risperidone | 1, 23
SGA vs. placebo
SGA vs. placebo | Sedation (12+), see aripiprazole | 1, 60
SGA vs. placebo
SGA vs. placebo | Somnolence | 26, 3942 | 560 | 2481 | 119 | 1461 | RR, 2.91; 95% Crl, 2.27 to 3.86^2, 4, 5, 7, 9, 11–16, 18–21, 23–26, 29, 33, 37–39, 42, 70^
SGA vs. placebo
SGA vs. placebo | Somnolence (6to<12) | 2, 545 | 3 | 172 | 2 | 163 | RR, 1.42; 95% CI, 0.24 to 8.40^34^
SGA vs. placebo | Somnolence (6to<12) | | 6 | 146 | 0 | 64 | RR, 5.75; 95% CI, 0.33 to 100.53^5^
SGA vs. placebo
SGA vs. placebo | Somnolence (12+), see aripiprazole | 1, 146
SGA vs. placebo
SGA vs. placebo | Hyperprolactinemia | 12, 2009 | 231 | 1261 | 98 | 748 | RR, 2.04; 95% CrI, 0.82 to 5.44^4, 9, 13, 18, 24, 26, 29, 30, 32, 39, 42, 46^
SGA vs. placebo
SGA vs. placebo | Prolactin-related events | 6, 783 | 11 | 506 | 3 | 277 | RR, 1.47; 95% CrI, 0.41 to 5.37^5, 11, 18, 19, 21, 26^
SGA vs. placebo | Prolactin-related events | 5, 457 | | | | | Not estimable^14, 16, 23, 33, 47^
SGA vs. placebo
SGA vs. placebo | Prolactin-related events (6to<12) | 2, 545 | 3 | 146 | 2 | 64 | RR, 0.66; 95% CI, 0.11 to 3.84^5^
SGA vs. placebo | Prolactin-related events (6to<12) | | 5 | 172 | 0 | 163 | RR, 10.43; 95% CI, 0.58 to 187.10^34^
Aripiprazole vs. placebo | Any AE | 7, 840 | 266 | 531 | 123 | 309 | RR, 1.26; 95% Crl, 0.88 to 2.06^1–7^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Any AE (12+) | 1, 146 | 41 | 98 | 25 | 48 | RR, 0.80; 95% CI, 0.56 to 1.15^28^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | AE limiting treatment | 5, 969 | 46 | 641 | 12 | 328 | RR, 1.91; 95% Crl, 0.82 to 4.65^2, 4–6, 29^
Aripiprazole vs. placebo | AE limiting treatment | 1, 82 | | | | | Not estimable^1^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | AE limiting treatment (6to<12) | 1, 210 | 14 | 146 | 0 | 64 | RR, 12.82; 95% CI, 0.78 to 211.72^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | AE limiting treatment (12+) | 2, 206 | 0 | 30 | 0 | 30 | Not estimable^36^
Aripiprazole vs. placebo | AE limiting treatment (12+) | | 1 | 98 | 1 | 48 | RR, 0.49; 95% CI, 0.03 to 7.66^28^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Any EPS | 6, 1000 | 117 | 655 | 17 | 345 | RR, 3.10; 95% CrI, 1.26 to 7.01^1, 2, 5, 7, 29, 38^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Any EPS (6to<12) | 1, 294 | 62 | 197 | 7 | 97 | RR, 4.36; 95% CI, 2.08 to 9.17^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Akathisia | 7, 1325 | 48 | 873 | 23 | 452 | RR, 0.86; 95% Crl, 0.31 to 2.14^2, 4, 5, 7, 29, 38, 41^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Akathisia (6to<12) | 1, 294 | 20 | 197 | 2 | 97 | RR, 4.92; 95% CI, 1.17 to 20.64^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Dystonia | 3, 656 | 13 | 431 | 4 | 225 | RR, 1.42; 95% Crl, 0.21 to 8.90^5, 7, 29^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Dystonia (6to<12) | 1, 294 | 7 | 197 | 2 | 97 | RR, 1.72; 95% CI, 0.36 to 8.14^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Weight (kg) | 7, 1042 | NA | 647 | NA | 395 | MD, 0.98; 95% Crl, 0.54 to 1.48^1, 2, 4, 5, 7, 29, 38^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Weight (kg) (12+) | 1, 60 | NA | 30 | NA | 30 | MD, 2.19; 95% CI, 0.73 to 3.65^36^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | BMI (kg·m^−2^) | 5, 881 | NA | 587 | NA | 294 | MD, 0.33; 95% CI, 0.07 to 0.67^2, 4, 5, 7, 29^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | ≥7% increase in weight | 5, 991 | 93 | 647 | 15 | 344 | RR, 3.01; 95% Crl, 1.33 to 7.10^1, 2, 4, 5, 29^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Increased total cholesterol | 3, 511 | 0 | 52 | 0 | 166 | Not estimable^2^
Aripiprazole vs. placebo | Increased total cholesterol | | 1 | 47 | 0 | 51 | RR, 3.25; 95% CI, 0.14 to 77.88^4^
Aripiprazole vs. placebo | Increased total cholesterol | | 55 | 130 | 11 | 65 | RR, 2.50; 95% CI, 1.41 to 4.44^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Increased total cholesterol (6to<12) | 1, 198 | 64 | 141 | 15 | 57 | RR, 1.72; 95% CI, 1.08 to 2.76^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Increased LDL | 2, 316 | 0 | 52 | 0 | 166 | Not estimable^2^
Aripiprazole vs. placebo | Increased LDL | | 1 | 47 | 0 | 51 | RR, 3.25; 95% CI, 0.14 to 77.88^4^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Decreased HDL | 3, 509 | 22 | 342 | 13 | 167 | RR, 0.82; 95% Crl, 0.17 to 4.20^2, 4, 5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Decreased HDL (6to<12) | 1, 197 | 19 | 140 | 13 | 57 | RR, 0.60; 95% CI, 0.32 to 1.12^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Increased triglycerides | 3, 509 | 64 | 342 | 22 | 167 | RR, 1.51; 95% Crl, 0.53 to 4.65^2, 4, 5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Increased triglycerides (6to<12) | 1, 197 | 49 | 140 | 21 | 57 | RR, 0.95; 95% CI, 0.63 to 1.43^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Increased fasting glucose | 3, 651 | 7 | 459 | 3 | 192 | RR, 0.90; 95% Crl, 0.16 to 5.44^2, 5, 29^
Aripiprazole vs. placebo | Increased fasting glucose | 1, 98 | | | | | Not estimable^4^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Increased fasting glucose (6to<12) | 1, 197 | 2 | 140 | 1 | 57 | RR, 0.81; 95% CI, 0.08 to 8.80^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Sedation | 4, 667 | 50 | 441 | 7 | 226 | RR, 2.71; 95% Crl, 0.77 to 9.78^2, 4, 5, 7^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Sedation (12+) | 1, 60 | 3 | 30 | 2 | 30 | RR, 1.50; 95% CI, 0.27 to 8.34^36^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Somnolence | 6, 1012 | 119 | 661 | 29 | 351 | RR, 2.73; 95% Crl, 1.24 to 7.65^2, 4, 5, 7, 29, 38^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Somnolence (6to<12) | 1, 210 | 6 | 146 | 0 | 64 | RR, 5.75; 95% CI, 0.33 to 100.53^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Somnolence (12+) | 1, 146 | 0 | 98 | 0 | 48 | Not estimable^28^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Hyperprolactinemia | 1, 98 | 1 | 47 | 3 | 51 | RR, 0.36; 95% CI, 0.04 to 3.36^4^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Prolactin-related events | 1, 210 | 1 | 146 | 0 | 64 | RR, 1.33; 95% CI, 0.05 to 32.13^5^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Prolactin-related events (6to<12) | 1, 210 | 3 | 146 | 2 | 64 | RR, 0.66; 95% CI, 0.11 to 3.84^5^
Asenapine vs. placebo | Any AE | 2, 709 | 17 | 302 | 4 | 101 | RR, 1.42; 95% CI, 0.49 to 4.13^8^
Asenapine vs. placebo | Any AE | | 132 | 204 | 48 | 102 | RR, 1.38; 95% CI, 1.09 to 1.73^9^
Asenapine vs. placebo
Asenapine vs. placebo | AE limiting treatment | 2, 709 | 17 | 302 | 4 | 101 | RR, 1.42; 95% CI, 0.49 to 4.13^8^
Asenapine vs. placebo | AE limiting treatment | | 14 | 204 | 3 | 102 | RR, 2.33; 95% CI, 0.69 to 7.94^9^
Asenapine vs. placebo
Asenapine vs. placebo | Any EPS | 1, 306 | 16 | 204 | 4 | 102 | RR, 2.00; 95% CI, 0.69 to 5.83^9^
Asenapine vs. placebo
Asenapine vs. placebo | Akathisia | 2, 709 | 5 | 302 | 0 | 101 | RR, 3.70; 95% CI, 0.21 to 66.39^8^
Asenapine vs. placebo | Akathisia | | 11 | 204 | 1 | 102 | RR, 5.50; 95% CI, 0.72 to 42.01^9^
Asenapine vs. placebo
Asenapine vs. placebo | Dystonia | 1, 403 | 1 | 302 | 0 | 101 | RR, 1.01; 95% CI, 0.04 to 24.60^8^
Asenapine vs. placebo
Asenapine vs. placebo | Weight (kg) | 0
Asenapine vs. placebo
Asenapine vs. placebo | BMI (kg·m^−2^) | 1, 403 | NA | 302 | NA | 101 | MD, 0.52; 95% CI, 0.36 to 0.69^8^
Asenapine vs. placebo
Asenapine vs. placebo | ≥7% increase in weight | 2, 650 | 26 | 269 | 1 | 89 | RR, 8.60; 95% CI, 1.18 to 62.48^8^
Asenapine vs. placebo | ≥7% increase in weight | | 19 | 194 | 3 | 98 | RR, 3.20; 95% CI, 0.97 to 10.55^9^
Asenapine vs. placebo
Asenapine vs. placebo | Increased total cholesterol | 0
Asenapine vs. placebo
Asenapine vs. placebo | Increased LDL | 0
Asenapine vs. placebo
Asenapine vs. placebo | Decreased HDL | 0
Asenapine vs. placebo
Asenapine vs. placebo | Increased triglycerides | 0
Asenapine vs. placebo
Asenapine vs. placebo | Increased fasting glucose | 0
Asenapine vs. placebo
Asenapine vs. placebo | Sedation | 1, 306 | 16 | 204 | 2 | 102 | RR, 4.00; 95% CI, 0.94 to 17.06^9^
Asenapine vs. placebo
Asenapine vs. placebo | Somnolence | 1, 306 | 38 | 204 | 7 | 102 | RR, 2.71; 95% CI, 1.26 to 5.86^9^
Asenapine vs. placebo
Asenapine vs. placebo | Hyperprolactinemia | 1, 306 | 42 | 204 | 13 | 102 | RR, 1.62; 95% CI, 0.91 to 2.87^9^
Asenapine vs. placebo
Asenapine vs. placebo | Prolactin-related events | 0
Lurasidone va placebo | Any AE | 1, 149 | 73 | 100 | 28 | 49 | RR, 1.25; 95% Cl, 1.16 to 1.35^70^
Lurasidone va placebo
Lurasidone va placebo | AE limiting treatment | 1, 149 | 4 | 100 | 5 | 49 | RR, 1.47; 95% Cl, 1.05 to 2.13^70^
Lurasidone va placebo
Lurasidone va placebo | Any EPS | 0
Lurasidone va placebo
Lurasidone va placebo | Akathisia | 1, 149 | 6 | 100 | 0 | 49 | RR, 1.29; 95% Cl, 0.81 to 2.27^70^
Lurasidone va placebo
Lurasidone va placebo | Dystonia | 0
Lurasidone va placebo
Lurasidone va placebo | Weight (kg) | 1, 149 | NA | 100 | NA | 49 | MD, 1.53; 95% Crl, 1.11 to 1.98^70^
Lurasidone va placebo
Lurasidone va placebo | BMI (kg·m^−2^) | 1, 149 | NA | 100 | NA | 49 | MD, 0.66; 95% Crl, 0.44 to 2.27^70^
Lurasidone va placebo
Lurasidone va placebo | ≥7% increase in weight | 0
Lurasidone va placebo
Lurasidone va placebo | Increased total cholesterol | 0
Lurasidone va placebo
Lurasidone va placebo | Increased LDL | 0
Lurasidone va placebo
Lurasidone va placebo | Decreased HDL | 0
Lurasidone va placebo
Lurasidone va placebo | Increased triglycerides | 0
Lurasidone va placebo
Lurasidone va placebo | Increased fasting glucose | 0
Lurasidone va placebo
Lurasidone va placebo | Sedation | 1, 149 | 4 | 100 | 1 | 49 | RR, 2.19; 95% Cl, 1.50 to 3.41^70^
Lurasidone va placebo
Lurasidone va placebo | Somnolence | 1, 149 | 12 | 100 | 2 | 49 | RR, 2.91; 95% Cl, 2.27 to 3.86^70^
Lurasidone va placebo
Lurasidone va placebo | Hyperprolactinemia | 0
Lurasidone va placebo
Lurasidone va placebo | Prolactin-related events | 0
Olanzapine vs. placebo | Any AE | 1, 11 | 6 | 6 | 5 | 5 | RR, 1.00; 95% CI, 0.73 to 1.37^10^
Olanzapine vs. placebo
Olanzapine vs. placebo | AE limiting treatment | 1, 161 | 3 | 107 | 1 | 54 | RR, 1.51; 95% CI, 0.16 to 14.21^30^
Olanzapine vs. placebo
Olanzapine vs. placebo | AE limiting treatment (12+) | 1, 60 | 1 | 31 | 1 | 29 | RR, 0.94; 95% CI, 0.06 to 14.27^37^
Olanzapine vs. placebo
Olanzapine vs. placebo | Any EPS | 0
Olanzapine vs. placebo
Olanzapine vs. placebo | Akathisia | 2, 259 | 3 | 101 | 1 | 51 | RR, 1.51; 95% CI, 0.16 to 14.20^30^
Olanzapine vs. placebo | Akathisia | | 2 | 72 | 2 | 35 | RR, 0.49; 95% CI, 0.07 to 3.31^42^
Olanzapine vs. placebo
Olanzapine vs. placebo | Dystonia | 0
Olanzapine vs. placebo
Olanzapine vs. placebo | Weight (kg) | 4, 337 | NA | 215 | NA | 122 | MD, 3.96; 95% CI, 2.31 to 6.34^10, 30, 37, 42^
Olanzapine vs. placebo
Olanzapine vs. placebo | Weight (kg) (12+) | 1, 59 | NA | 30 | NA | 29 | MD, 8.49; 95% CI, 4.90 to 12.08^37^
Olanzapine vs. placebo
Olanzapine vs. placebo | BMI (kg·m^−2^) | 2, 267 | NA | 107 | NA | 54 | MD, 1.16; 95% CI, 0.93 to 1.39^30^
Olanzapine vs. placebo | BMI (kg·m^−2^) | | NA | 72 | NA | 34 | MD, 1.50; 95% CI, 1.06 to 1.94^42^
Olanzapine vs. placebo
Olanzapine vs. placebo | ≥7% increase in weight | 4, 337 | 99 | 215 | 8 | 122 | RR, 6.08; 95% Crl, 1.84 to 27.06^10, 30, 37, 42^
Olanzapine vs. placebo
Olanzapine vs. placebo | Increased total cholesterol | 1, 109 | 1 | 75 | 0 | 34 | RR, 1.38; 95% CI, 0.06 to 33.07^30^
Olanzapine vs. placebo
Olanzapine vs. placebo | Increased LDL | 1, 76 | 0 | 50 | 0 | 26 | Not estimable^30^
Olanzapine vs. placebo
Olanzapine vs. placebo | Decreased HDL | 1, 83 | 6 | 51 | 5 | 32 | RR, 0.75; 95% CI, 0.25 to 2.27^30^
Olanzapine vs. placebo
Olanzapine vs. placebo | Increased triglycerides | 2, 202 | 5 | 65 | 0 | 30 | RR, 5.17; 95% CI, 0.29 to 90.53^30^
Olanzapine vs. placebo | Increased triglycerides | | 20 | 72 | 6 | 35 | RR, 1.62; 95% CI, 0.72 to 3.67^42^
Olanzapine vs. placebo
Olanzapine vs. placebo | Increased fasting glucose | 1, 120 | 1 | 81 | 0 | 39 | RR, 1.46; 95% CI, 0.06 to 35.13^30^
Olanzapine vs. placebo
Olanzapine vs. placebo | Sedation | 3, 138 | 16 | 88 | 3 | 50 | RR, 2.93; 95% Crl, 0.62 to 14.41^10, 42, 50^
Olanzapine vs. placebo
Olanzapine vs. placebo | Somnolence | 2, 167 | 16 | 72 | 1 | 35 | RR, 7.78; 95% CI, 1.07 to 56.30^42^
Olanzapine vs. placebo | Somnolence | | 12 | 31 | 5 | 29 | RR, 2.25; 95% CI, 0.90 to 5.59^37^
Olanzapine vs. placebo
Olanzapine vs. placebo | Hyperprolactinemia | 2, 268 | 50 | 107 | 1 | 54 | RR, 25.53; 95% CI, 3.58 to 177.76^30^
Olanzapine vs. placebo | Hyperprolactinemia | | 58 | 72 | 6 | 35 | RR, 4.70; 95% CI, 2.25 to 9.82^42^
Olanzapine vs. placebo
Olanzapine vs. placebo | Prolactin-related events | 0
Paliperidone vs. placebo | Any AE | 1, 200 | 90 | 149 | 30 | 51 | RR, 1.03; 95% CI, 0.79 to 1.34^11^
Paliperidone vs. placebo
Paliperidone vs. placebo | AE limiting treatment | 1, 200 | 3 | 149 | 0 | 51 | RR, 2.43; 95% CI, 0.13 to 46.19^11^
Paliperidone vs. placebo
Paliperidone vs. placebo | Any EPS | 0
Paliperidone vs. placebo
Paliperidone vs. placebo | Akathisia | 1, 201 | 14 | 150 | 0 | 51 | RR, 9.99; 95% CI, 0.61 to 164.48^11^
Paliperidone vs. placebo
Paliperidone vs. placebo | Dystonia | 1, 201 | 6 | 150 | 0 | 51 | RR, 4.48; 95% CI, 0.26 to 78.10^11^
Paliperidone vs. placebo
Paliperidone vs. placebo | Weight (kg) | 1, 200 | NA | 149 | NA | 51 | MD, 0.90; 95% CI, 0.34 to 1.46^11^
Paliperidone vs. placebo
Paliperidone vs. placebo | BMI (kg·m^−2^) | 0
Paliperidone vs. placebo
Paliperidone vs. placebo | ≥7% increase in weight | 1, 200 | 15 | 149 | 1 | 51 | RR, 5.13; 95% CI, 0.70 to 37.90^11^
Paliperidone vs. placebo
Paliperidone vs. placebo | Increased total cholesterol | 0
Paliperidone vs. placebo
Paliperidone vs. placebo | Increased LDL | 0
Paliperidone vs. placebo
Paliperidone vs. placebo | Decreased HDL | 0
Paliperidone vs. placebo
Paliperidone vs. placebo | Increased triglycerides | 0
Paliperidone vs. placebo
Paliperidone vs. placebo | Increased fasting glucose | 0
Paliperidone vs. placebo
Paliperidone vs. placebo | Sedation | 0
Paliperidone vs. placebo
Paliperidone vs. placebo | Somnolence | 1, 201 | 18 | 150 | 1 | 51 | RR, 6.12; 95% CI, 0.84 to 44.70^11^
Paliperidone vs. placebo
Paliperidone vs. placebo | Hyperprolactinemia | 0
Paliperidone vs. placebo
Paliperidone vs. placebo | Prolactin-related events | 1, 200 | 3 | 149 | 0 | 51 | RR, 2.43; 95% CI, 0.13 to 46.19^11^
Quetiapine vs. placebo | Any AE | 2, 414 | 68 | 92 | 66 | 100 | RR, 1.12; 95% CI, 0.93 to 1.35^12^
Quetiapine vs. placebo | Any AE | | 112 | 147 | 45 | 75 | RR, 1.27; 95% CI, 1.03 to 1.56^13^
Quetiapine vs. placebo
Quetiapine vs. placebo | AE limiting treatment | 5, 748 | 38 | 458 | 19 | 290 | RR, 1.21; 95% Crl, 0.30 to 4.73^12, 13, 39, 40, 43^
Quetiapine vs. placebo | AE limiting treatment | 1, 30 | | | | | Not estimable^32^
Quetiapine vs. placebo
Quetiapine vs. placebo | Any EPS | 3, 537 | 0 | 17 | 0 | 15 | Not estimable^40^
Quetiapine vs. placebo | Any EPS | | 7 | 193 | 1 | 90 | RR, 3.26; 95% CI, 0.41 to 26.14^39^
Quetiapine vs. placebo | Any EPS | | 19 | 147 | 4 | 75 | RR, 2.42; 95% CI, 0.86 to 6.87^13^
Quetiapine vs. placebo
Quetiapine vs. placebo | Akathisia | 1, 19 | 1 | 9 | 0 | 10 | RR, 3.30; 95% CI, 0.15 to 72.08^43^
Quetiapine vs. placebo
Quetiapine vs. placebo | Dystonia | 0
Quetiapine vs. placebo
Quetiapine vs. placebo | Weight (kg) | 6, 778 | NA | 473 | NA | 305 | MD, 1.44; 95% CI, 0.60 to 2.31^12, 13, 32, 39, 40, 43^
Quetiapine vs. placebo
Quetiapine vs. placebo | BMI (kg·m^−2^) | 1, 32 | NA | 17 | NA | 15 | MD, 0.60; 95% CI, 0.39 to 0.81^40^
Quetiapine vs. placebo
Quetiapine vs. placebo | ≥7% increase in weight | 3, 697 | 70 | 432 | 11 | 265 | RR, 3.41; 95% Crl, 0.95 to 18.37^12, 13, 39^
Quetiapine vs. placebo
Quetiapine vs. placebo | Increased total cholesterol | 2, 185 | 2 | 17 | 0 | 15 | RR, 4.44; 95% CI, 0.23 to 85.83^40^
Quetiapine vs. placebo | Increased total cholesterol | | 30 | 109 | 2 | 44 | RR, 6.06; 95% CI, 1.51 to 24.26^39^
Quetiapine vs. placebo
Quetiapine vs. placebo | Increased LDL | 2, 286 | 2 | 17 | 0 | 15 | RR, 4.44; 95% CI, 0.23 to 85.83^40^
Quetiapine vs. placebo | Increased LDL | | 1 | 175 | 0 | 79 | RR, 1.36; 95% CI, 0.06 to 33.11^39^
Quetiapine vs. placebo
Quetiapine vs. placebo | Decreased HDL | 2, 247 | 3 | 17 | 2 | 15 | RR, 1.32; 95% CI, 0.25 to 6.88^40^
Quetiapine vs. placebo | Decreased HDL | | 15 | 154 | 4 | 61 | RR, 1.49; 95% CI, 0.51 to 4.30^39^
Quetiapine vs. placebo
Quetiapine vs. placebo | Increased triglycerides | 3, 463 | 39 | 313 | 9 | 150 | RR, 2.11; 95% Crl, 0.55 to 12.79^13, 39, 40^
Quetiapine vs. placebo
Quetiapine vs. placebo | Increased fasting glucose | 2, 280 | 0 | 17 | 1 | 15 | RR, 0.30; 95% CI, 0.01 to 6.77^40^
Quetiapine vs. placebo | Increased fasting glucose | | 2 | 167 | 0 | 81 | RR, 2.44; 95% CI, 0.12 to 50.25^39^
Quetiapine vs. placebo
Quetiapine vs. placebo | Sedation | 6, 778 | 90 | 473 | 32 | 305 | RR, 1.67; 95% Crl, 0.77 to 3.87^12, 13, 32, 39, 40, 43^
Quetiapine vs. placebo
Quetiapine vs. placebo | Somnolence | 3, 697 | 106 | 432 | 18 | 265 | RR, 2.95; 95% Crl, 0.92 to 8.62^12, 13, 39^
Quetiapine vs. placebo
Quetiapine vs. placebo | Hyperprolactinemia | 3, 535 | 33 | 355 | 12 | 180 | Value^13, 32, 39^
Quetiapine vs. placebo
Quetiapine vs. placebo | Prolactin-related events | 0
Risperidone vs. placebo | Any AE | 10, 796 | 384 | 443 | 244 | 353 | RR, 1.25; 95% Crl, 1.13 to 1.40^14–23^
Risperidone vs. placebo
Risperidone vs. placebo | Any AE (6to<12) | 1, 335 | 82 | 172 | 59 | 163 | RR, 1.32; 95% CI, 1.02 to 1.70^34^
Risperidone vs. placebo
Risperidone vs. placebo | Any AE (12+) | 1, 87 | 10 | 43 | 13 | 44 | RR, 0.79; 95% CI, 0.39 to 1.60^27^
Risperidone vs. placebo
Risperidone vs. placebo | AE limiting treatment | 6, 559 | 25 | 325 | 7 | 234 | RR, 1.97; 95% Crl, 0.71 to 5.92^14, 17, 19, 21, 23, 31^
Risperidone vs. placebo | AE limiting treatment | 3, 239 | | | | | Not estimable^15, 18, 33^
Risperidone vs. placebo
Risperidone vs. placebo | AE limiting treatment (6to<12) | 2, 374 | 2 | 172 | 1 | 163 | RR, 1.90; 95% CI, 0.17 to 20.70^34^
Risperidone vs. placebo | AE limiting treatment (6to<12) | | 0 | 19 | 0 | 20 | Not estimable^35^
Risperidone vs. placebo
Risperidone vs. placebo | Any EPS | 5, 636 | 52 | 365 | 13 | 271 | RR, 2.78; 95% CrI, 1.27 to 6.50^14, 18, 20, 21, 23^
Risperidone vs. placebo
Risperidone vs. placebo | Any EPS (6to<12) | 1, 335 | 3 | 172 | 1 | 163 | RR, 2.84; 95% CI, 0.30 to 27.06^34^
Risperidone vs. placebo
Risperidone vs. placebo | Akathisia | 4, 428 | 39 | 264 | 25 | 164 | RR, 1.03; 95% Crl, 0.35 to 4.98^16, 19, 21, 23^
Risperidone vs. placebo
Risperidone vs. placebo | Akathisia (6to<12) | 1, 335 | 0 | 172 | 0 | 163 | Not estimable^34^
Risperidone vs. placebo
Risperidone vs. placebo | Dystonia | 4, 194 | 0 | 52 | 0 | 63 | Not estimable^14^
Risperidone vs. placebo | Dystonia | | 0 | 19 | 0 | 17 | Not estimable^16^
Risperidone vs. placebo | Dystonia | | 0 | 10 | 0 | 10 | Not estimable^17^
Risperidone vs. placebo | Dystonia | | 0 | 11 | 0 | 12 | Not estimable^44^
Risperidone vs. placebo
Risperidone vs. placebo | Dystonia ( 6to<12) | 2, 358 | 2 | 172 | 1 | 163 | RR, 1.90; 95% CI, 0.17 to 20.70^34^
Risperidone vs. placebo | Dystonia ( 6to<12) | | 0 | 11 | 0 | 12 | Not estimable^44^
Risperidone vs. placebo
Risperidone vs. placebo | Weight (kg) | 14, 929 | NA | 522 | NA | 475 | MD, 1.52; 95% CI, 0.78 to 2.29^14–22, 33, 45–48^
Risperidone vs. placebo
Risperidone vs. placebo | Weight (kg) (6to<12) | 4, 467 | NA | 239 | NA | 228 | MD, 2.86; 95% Crl, −1.22 to 7.42^34, 35, 44, 51^
Risperidone vs. placebo
Risperidone vs. placebo | BMI (kg·m^−2^) | 6, 730 | NA | 397 | NA | 333 | MD, 0.68; 95% CI, 0.27 to 1.18^15, 18, 19, 21, 34, 48^
Risperidone vs. placebo
Risperidone vs. placebo | BMI (kg·m^−2^) (6to<12) | 2, 405 | NA | 172 | NA | 163 | MD, 0.70; 95% CI, 0.49 to 0.91^34^
Risperidone vs. placebo | BMI (kg·m^−2^) (6to<12) | | NA | 37 | NA | 33 | MD, 1.80; 95% CI, −0.61 to 4.21^51^
Risperidone vs. placebo
Risperidone vs. placebo | ≥7% increase in weight | 2, 182 | 13 | 111 | 3 | 58 | RR, 2.26; 95% CI, 0.67 to 7.63^21^
Risperidone vs. placebo | ≥7% increase in weight | | 2 | 6 | 0 | 7 | RR, 5.71; 95% CI, 0.33 to 99.97^22^
Risperidone vs. placebo
Risperidone vs. placebo | ≥7% increase in weight (6to<12) | 1, 62 | 29 | 37 | 6 | 33 | RR, 4.31; 95% CI, 2.05 to 9.06^51^
Risperidone vs. placebo
Risperidone vs. placebo | Increased total cholesterol | 0
Risperidone vs. placebo
Risperidone vs. placebo | Increased LDL | 0
Risperidone vs. placebo
Risperidone vs. placebo | Decreased HDL | 0
Risperidone vs. placebo
Risperidone vs. placebo | Increased triglycerides | 1, 153 | 1 | 73 | 0 | 80 | RR, 3.28; 95% CI, 0.14 to 79.36^46^
Risperidone vs. placebo
Risperidone vs. placebo | Increased fasting glucose | 1, 153 | 0 | 73 | 1 | 80 | RR, 0.36; 95% CI, 0.02 to 8.82^46^
Risperidone vs. placebo
Risperidone vs. placebo | Sedation | 4, 408 | 52 | 225 | 24 | 183 | RR, 2.58; 95% Crl, 0.70 to 14.89^17, 19, 21, 46^
Risperidone vs. placebo
Risperidone vs. placebo | Sedation (6to<12) | 1, 23 | 5 | 11 | 4 | 12 | RR, 1.36; 95% CI, 0.49 to 3.82^44^
Risperidone vs. placebo
Risperidone vs. placebo | Somnolence | 9, 862 | 163 | 473 | 43 | 389 | RR, 3.25; 95% Crl, 1.96 to 5.94^14–16, 18, 19, 33 20, 21, 23^
Risperidone vs. placebo
Risperidone vs. placebo | Somnolence (6to<12) | 1, 335 | 3 | 172 | 2 | 163 | RR, 1.42; 95% CI, 0.24 to 8.40^34^
Risperidone vs. placebo
Risperidone vs. placebo | Hyperprolactinemia | 2, 251 | 4 | 68 | 4 | 73 | RR, 1.07; 95% CI, 0.28 to 4.12^46^
Risperidone vs. placebo | Hyperprolactinemia | | 6 | 53 | 0 | 57 | RR, 13.96; 95% CI, 0.81 to 241.98^18^
Risperidone vs. placebo
Risperidone vs. placebo | Prolactin-related events | 3, 345 | 6 | 195 | 3 | 150 | RR, 1.21; 95% CrI, 0.19 to 7.69^18, 19, 21^
Risperidone vs. placebo | Prolactin-related events | 5, 457 | | | | | Not estimable^14, 16, 23, 33, 47^
Risperidone vs. placebo
Risperidone vs. placebo | Prolactin-related events (6to<12) | 1, 335 | 5 | 172 | 0 | 163 | RR, 10.43; 95% CI, 0.58 to 187.10^34^
Various SGA’s vs. placebo | Any AE | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | AE limiting treatment | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Any EPS | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Akathisia | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Dystonia | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Weight (kg) | 1, 56 | NA | 32 | NA | 24 | MD, 3.67; 95% CI, 1.92 to 5.42^49^
Various SGA’s vs. placebo
Various SGA’s vs. placebo | BMI (kg·m^−2^) | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | ≥7% increase in weight | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Increased total cholesterol | 1, 56 | 3 | 32 | 0 | 24 | RR, 5.30; 95% CI, 0.29 to 98.06^49^
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Increased LDL | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Decreased HDL | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Increased triglycerides | 1, 56 | 1 | 32 | 1 | 24 | RR, 0.75; 95% CI, 0.05 to 11.39^49^
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Increased fasting glucose | 1, 56 | 0 | 32 | 0 | 24 | Not estimable^49^
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Sedation | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Somnolence | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Hyperprolactinemia | 0
Various SGA’s vs. placebo
Various SGA’s vs. placebo | Prolactin-related events | 0
Ziprasidone vs. placebo | Any AE | 3, 548 | 300 | 358 | 114 | 190 | RR, 1.43; 95% Crl, 0.85 to 2.59^24–26^
Ziprasidone vs. placebo
Ziprasidone vs. placebo | AE limiting treatment | 3, 548 | 33 | 358 | 14 | 190 | RR, 1.36; 95% Crl, 0.37 to 6.34^24–26^
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Any EPS | 1, 283 | 22 | 193 | 1 | 90 | RR, 10.26; 95% CI, 1.40 to 74.93^25^
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Akathisia | 3, 548 | 22 | 358 | 4 | 190 | RR, 2.63; 95% Crl, 0.55 to 13.39^24–26^
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Dystonia | 1, 237 | 1 | 149 | 0 | 88 | RR, 1.78; 95% CI, 0.07 to 43.23^24^
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Weight (kg) | 3, 360 | NA | 246 | NA | 114 | MD, −0.10; 95% CI, −1.34 to 1.13^24–26^
Ziprasidone vs. placebo
Ziprasidone vs. placebo | BMI (kg·m^−2^) | 0
Ziprasidone vs. placebo
Ziprasidone vs. placebo | ≥7% increase in weight | 0
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Increased total cholesterol | 0
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Increased LDL | 0
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Decreased HDL | 0
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Increased triglycerides | 0
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Increased fasting glucose | 0
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Sedation | 2, 264 | 49 | 149 | 5 | 88 | RR, 5.79; 95% CI, 2.40 to 13.98^24^
Ziprasidone vs. placebo | Sedation | | 11 | 16 | 5 | 11 | RR, 1.51; 95% CI, 0.73 to 3.13^26^
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Somnolence | 3, 548 | 76 | 358 | 13 | 190 | RR, 2.97; 95% Crl, 0.84 to 9.96^24–26^
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Hyperprolactinemia | 2, 265 | 17 | 149 | 2 | 88 | RR, 5.02; 95% CI, 1.19 to 21.22^24^
Ziprasidone vs. placebo | Hyperprolactinemia | | 5 | 16 | 0 | 12 | RR, 8.41; 95% CI, 0.51 to 138.82^26^
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Prolactin-related events | 1, 28 | 1 | 16 | 0 | 12 | RR, 2.29; 95% CI, 0.10 to 51.85^26^

AE = adverse event; BMI = body mass index; CI = confidence interval; EPS = extrapyramidal symptoms; G1 = group 1; G2 = group 2; HDL = high density lipoprotein; LDL = low density lipoprotein; MD = mean difference; N = number; NA = not applicable; RR = risk ratio; SGA = second generation antipsychotic

## References

1 Sikich L, Frazier JA, Mcclellan J, . Double-blind comparison of first- and second-generation antipsychotics in early-onset schizophrenia and schizo-affective disorder: findings from the treatment of early-onset schizophrenia spectrum disorders (teoss) study. Am J Psychiatry. 2008;165(11):1420–31. PMID: 18794207.18794207
2 Yoo HK, Lee JS, Paik KW, . Open-label study comparing the efficacy and tolerability of aripiprazole and haloperidol in the treatment of pediatric tic disorders. Eur Child Adolesc Psychiatry. 2011;20(3):127–35. PMID: 21188439.21188439
3 Sikich L, Hamer RM, Bashford RA, . A pilot study of risperidone, olanzapine, and haloperidol in psychotic youth: a double-blind, randomized, 8-week trial. Neuropsychopharmacology. 2004;29(1):133–45. PMID: 14583740.14583740
4 Ratzoni G, Gothelf D, Brand-Gothelf A, . Weight gain associated with olanzapine and risperidone in adolescent patients: a comparative prospective study. J Am Acad Child Adolesc Psychiatry. 2002;41(3):337–43. PMID: 11886029.11886029
5 Cianchetti C, Ledda MG. Effectiveness and safety of antipsychotics in early onset psychoses: a long-term comparison. Psychiatry Res. 2011;189(3):349–56. PMID: 21570128.21570128
6 Malone RP, Cater J, Sheikh RM, . Olanzapine versus haloperidol in children with autistic disorder: an open pilot study. J Am Acad Child Adolesc Psychiatry. 2001;40(8):887–94. PMID: 11501687.11501687
7 Yoo HK, Joung YS, Lee JS, . A multicenter, randomized, double-blind, placebo-controlled study of aripiprazole in children and adolescents with tourette’s disorder. J Clin Psychiatry. 2013;74(8):e772–80. PMID: 24021518.24021518
8 Miral S, Gencer O, Inal-Emiroglu FN, . Risperidone versus haloperidol in children and adolescents with ad: a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry. 2008;17(1):1–8. PMID: 18080171.18080171
9 Bruggeman R, Van Der LC, Buitelaar JK, . Risperidone versus pimozide in tourette’s disorder: a comparative double-blind parallel-group study. J Clin Psychiatry. 2001;62(1):50–6. PMID: 11235929.11235929
10 Gilbert DL, Batterson JR, Sethuraman G, . Tic reduction with risperidone versus pimozide in a randomized, double-blind, crossover trial. J Am Acad Child Adolesc Psychiatry. 2004;43(2):206–14. PMID: 14726728.14726728
11 Ebert T, Midbari Y, Shmilovitz R, . Metabolic effects of antipsychotics in prepubertal children: a retrospective chart review. J Child Adolesc Psychopharmacol. 2014;24(4):218–22. PMID: 24816004.24816004
12 Kumra S, Frazier JA, Jacobsen LK, . Childhood-onset schizophrenia. A double-blind clozapine-haloperidol comparison. Arch Gen Psychiatry. 1996;53(12):1090–7. PMID: 8956674.8956674
13 Gothelf D, Falk B, Singer P, . Weight gain associated with increased food intake and low habitual activity levels in male adolescent schizophrenic inpatients treated with olanzapine. Am J Psychiatry. 2002;159(6):1055–7. PMID: 12042200.12042200
14 Wudarsky M, Nicolson R, Hamburger SD, . Elevated prolactin in pediatric patients on typical and atypical antipsychotics. J Child Adolesc Psychopharmacol 1999(4):239–45. PMID: 10630453.10630453
15 Yen YC, Lung F-W, Chong MY. Adverse effects of risperidone and haloperidol treatment in schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2004;28(2):285–90. PMID: 14751424.14751424
16 Perry R, Campbell M, Adams P, . Long-term efficacy of haloperidol in autistic children: continuous versus discontinuous drug administration. J Am Acad Child Adolesc Psychiatry. 1989;28(1):87–92. PMID: 2914841.2914841
17 Sallee FR, Nesbitt L, Jackson C, . Relative efficacy of haloperidol and pimozide in children and adolescents with tourette’s disorder. Am J Psychiatry. 1997;154(8):1057–62. PMID: 9247389.9247389
18 Correll CU, Manu P, Olshanskiy V, . Cardiometabolic risk of second-generation antipsychotic medications during first-time use in children and adolescents. JAMA 2009(16):1765–73. PMID: 19861668.19861668
19 Savitz AJ, Lane R, Nuamah I, . Efficacy and safety of paliperidone extended release in adolescents with schizophrenia: a randomized, double-blind study. J Am Acad Child Adolesc Psychiatry. 2015;54(2):126–37.e1. PMID: 25617253.25617253
20 Oh J, Chang JG, Lee SB, . Comparison of aripiprazole and other atypical antipsychotics for pediatric bipolar disorder: a retrospective chart review of efficacy and tolerability. Clin. 2013;11(2):72–9. PMID: 24023551.24023551
21 Masi G, Pfanner C, Brovedani P. Antipsychotic augmentation of selective serotonin reuptake inhibitors in resistant tic-related obsessive-compulsive disorder in children and adolescents: a naturalistic comparative study. J Psychiatr Res. 2013;47(8):1007–12. PMID: 23664673.23664673
22 Ghanizadeh A, Haghighi A. Aripiprazole versus risperidone for treating children and adolescents with tic disorder: a randomized double blind clinical trial. Child Psychiatry Hum Dev. 2014b;45(5):596–603. PMID: 24343476.24343476
23 Ghanizadeh A, Sahraeizadeh A, Berk M. A head-to-head comparison of aripiprazole and risperidone for safety and treating autistic disorders, a randomized double blind clinical trial. Child Psychiatry Hum Dev. 2014a;45(2):185–92. PMID: 23801256.23801256
24 Wink LK, Early M, Schaefer T, . Body mass index change in autism spectrum disorders: comparison of treatment with risperidone and aripiprazole. J Child Adolesc Psychopharmacol. 2014;24(2):78–82. PMID: 24564519.24564519
25 Bastiaens L. A non-randomized, open study with aripiprazole and ziprasidone for the treatment of aggressive behavior in youth in a community clinic. Community Ment Health J 2009(1):73–7. PMID: 18597173.18597173
26 Alacqua M, Trifiro G, Arcoraci V, . Use and tolerability of newer antipsychotics and antidepressants: a chart review in a paediatric setting. Pharm World Sci. 2008;30(1):44–50. PMID: 17588130.17588130
27 Shaw P, Sporn A, Gogtay N, . Childhood-onset schizophrenia: a double-blind, randomized clozapine-olanzapine comparison. Arch Gen Psychiatry. 2006;63(7):721–30. PMID: 16818861.16818861
28 Kumra S, Kranzler H, Gerbino-Rosen G, . Clozapine and “high-dose” olanzapine in refractory early-onset schizophrenia: a 12-week randomized and double-blind comparison. Biol Psychiatry. 2008;63(5):524–9. PMID: 17651705.17651705
29 Fleischhaker C, Heiser P, Hennighausen K, . Clinical drug monitoring in child and adolescent psychiatry: side effects of atypical neuroleptics. J Child Adolesc Psychopharmacol. 2006;16(3):308–16. PMID: 16768638.16768638
30 Hrdlicka M, Zedkova I, Blatny M, . Weight gain associated with atypical and typical antipsychotics during treatment of adolescent schizophrenic psychoses: a retrospective study. Neuroendocrinology Lett. 2009;30(2):256–61. PMID: N/A.
31 Kumra S, Jacobsen LK, Lenane M, . Childhood-onset schizophrenia: an open-label study of olanzapine in adolescents. J Am Acad Child Adolesc Psychiatry. 1998;37(4):377–85. PMID: 9549958.9549958
32 Castro-Fornieles J, Parellada M, Soutullo CA, . Antipsychotic treatment in child and adolescent first-episode psychosis: a longitudinal naturalistic approach. J Child Adolesc Psychopharmacol. 2008;18(4):327–36. PMID: 18759642.18759642
33 Arango C, Robles O, Parellada M, . Olanzapine compared to quetiapine in adolescents with a first psychotic episode. Eur Child Adolesc Psychiatry. 2009;18(7):418–28. PMID: 19198920.19198920
34 Jensen JB, Kumra S, Leitten W, . A comparative pilot study of second-generation antipsychotics in children and adolescents with schizophrenia-spectrum disorders. J Child Adolesc Psychopharmacol. 2008;18(4):317–26. PMID: 18759641.18759641
35 Arango C, Giraldez M, Merchan-Naranjo J, . Second-generation antipsychotic use in children and adolescents: a six-month prospective cohort study in drug-naive patients. J Am Acad Child Adolesc Psychiatry. 2014;53(11):1179–90,90.e1–4. PMID: 25440308.25440308
36 Fraguas D, Merchan-Naranjo J, Laita P, . Metabolic and hormonal side effects in children and adolescents treated with second-generation antipsychotics. J Clin Psychiatry. 2008;69(7):1166–75. PMID: 18588363.18588363
37 Cuerda C, Merchan-Naranjo J, Velasco C, . Influence of resting energy expenditure on weight gain in adolescents taking second-generation antipsychotics. Clin Nutr. 2011;30(5):616–23. PMID: 21492975.21492975
38 Saito E, Correll CU, Gallelli K, . A prospective study of hyperprolactinemia in children and adolescents treated with atypical antipsychotic agents. J Child Adolesc Psychopharmacol. 2004;14(3):350–8. PMID: 15650492.15650492
39 Friedlander R, Lazar S, Klancnik J. Atypical antipsychotic use in treating adolescents and young adults with developmental disabilities. Can J Psychiatry. 2001;46(8):741–5. PMID: 11692977.11692977
40 Mozes T, Ebert T, Michal SE, . An open-label randomized comparison of olanzapine versus risperidone in the treatment of childhood-onset schizophrenia. J Child Adolesc Psychopharmacol. 2006;16(4):393–403. PMID: 16958565.16958565
41 Van Bruggen J, Tijssen J, Dingemans P, . Symptom response and side-effects of olanzapine and risperidone in young adults with recent onset schizophrenia. Int Clin Psychopharmacol. 2003;18(6):341–6. PMID: 14571154.14571154
42 Biederman J, Mick E, Hammerness P, . Open-label, 8-week trial of olanzapine and risperidone for the treatment of bipolar disorder in preschool-age children. Biol Psychiatry. 2005;58(7):589–94. PMID: 16239162.16239162
43 Pogge DL, Singer MB, Harvey PD. Rates and predictors of adherence with atypical antipsychotic medication: A follow-up study of adolescent inpatients. J Child Adolesc Psychopharmacol. 2005;15(6):901–12. PMID: 16379510.16379510
44 Crocq MA, Guillon MS, Bailey PE, . Orally disintegrating olanzapine induces less weight gain in adolescents than standard oral tablets. Eur Psychiatry. 2007;22(7):453–4. PMID: 17761403.17761403
45 Khan RA, Mican LM, Suehs BT. Effects of olanzapine and risperidone on metabolic factors in children and adolescents: a retrospective evaluation. J Psychiatr Pract. 2009 Jul;15(4):320–8. PMID: 19625888.19625888
46 Migliardi G, Spina E, D’arrigo C, . Short- and long-term effects on prolactin of risperidone and olanzapine treatments in children and adolescents. Prog Neuropsychopharmacol Biol Psychiatry. 2009;33(8):1496–501. PMID: 19706318.19706318
47 Masi G, Milone A, Stawinoga A, . Efficacy and safety of risperidone and quetiapine in adolescents with bipolar II disorder comorbid with conduct disorder. J Clin Psychopharmacol. 2015;35(5):587–90. PMID: 26226481.26226481
48 Swadi HS, Craig BJ, Pirwani NZ, . A trial of quetiapine compared with risperidone in the treatment of first onset psychosis among 15-to 18-year-old adolescents. Int Clin Psychopharmacol. 2010;25(1):1–6. PMID: 19809337.19809337
49 Findling RL, Robb A, Nyilas M, . A multiple-center, randomized, double-blind, placebo-controlled study of oral aripiprazole for treatment of adolescents with schizophrenia. Am J Psychiatry. 2008a;165(11):1432–41. PMID: 18765484.18765484
50 Findling RL, Kauffman RE, Sallee FR, . Tolerability and pharmacokinetics of aripiprazole in children and adolescents with psychiatric disorders: an open-label, dose-escalation study. J Clin Psychopharmacol. 2008b;28(4):441–6. PMID: 18626272.18626272
51 Findling RL, Nyilas M, Forbes RA, . Acute treatment of pediatric bipolar I disorder, manic or mixed episode, with aripiprazole: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2009;70(10):1441–51. PMID: 19906348.19906348
52 Marcus RN, Owen R, Kamen L, . A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry. 2009;48(11):1110–9. PMID: 19797985.19797985
53 Findling RL, Landbloom RP, Mackle M, . Safety and efficacy from an 8 week double-blind trial and a 26 week open-label extension of asenapine in adolescents with schizophrenia. J Child Adolesc Psychopharmacol. 2015a;25(5):384–96. PMID: 26091193.26091193
54 Findling RL, Landbloom RL, Szegedi A, . Asenapine for the acute treatment of pediatric manic or mixed episode of bipolar I disorder. J Am Acad Child Adolesc Psychiatry. 2015b;54(12):1032–41. PMID: 26598478.26598478
55 Stocks JD, Taneja BK, Baroldi P, . A phase 2a randomized, parallel group, dose-ranging study of molindone in children with attention-deficit/hyperactivity disorder and persistent, serious conduct problems. J Child Adolesc Psychopharmacol. 2012;22(2):102–11. PMID: 22372512.22372512
56 Johnson & Johnson Pharmaceutical Research & Development. Open-label study to evaluate the safety and pharmacokinetics of single- and multiple-dose extended-release paliperidone in pediatric subjects (10 to 17 years of age) with schizophrenia, schizoaffective disorder, or schizophreniform disorder. 2011. http://filehosting.pharmacm.com/DownloadService.ashx?client=CTR_JNJ_6051&studyid=473&filename=CR002371_CSR.pdf. Accessed September 28, 2015.
57 Singh J, Robb A, Vijapurkar U, . A randomized, double-blind study of paliperidone extended-release in treatment of acute schizophrenia in adolescents. Biol Psychiatry. 2011;70(12):1179–87. PMID: 21831359.21831359
58 Berger GE, Proffitt TM, Mcconchie M, . Dosing quetiapine in drug-naive first-episode psychosis: A controlled, double-blind, randomized, single-center study investigating efficacy, tolerability, and safety of 200 mg/day vs. 400 mg/day of quetiapine fumarate in 141 patients aged 15 to 25 years. J Clin Psychiatry. 2008;69(11):1702–14. PMID: 19036233.19036233
59 Findling RL, Mckenna K, Earley WR, . Efficacy and safety of quetiapine in adolescents with schizophrenia investigated in a 6-week, double-blind, placebo-controlled trial. J Child Adolesc Psychopharmacol. 2012a;22(5):327–42. PMID: 23083020.23083020
60 Pathak S., Findling RL, Earley WR, . Efficacy and safety of quetiapine in children and adolescents with mania associated with bipolar I disorder: a 3-week, double-blind, placebo-controlled trial. J Clin Psychiatry. 2013;74(1):e100–9. PMID: 23419231.23419231
61 Haas M, Eerdekens M, Kushner S, . Efficacy, safety and tolerability of two dosing regimens in adolescent schizophrenia: double-blind study. Br J Psychiatry. 2009a;194(2):158–64. PMID: 19182179.19182179
62 Haas M, Unis AS, Armenteros J, . A 6-week, randomized, double-blind, placebo-controlled study of the efficacy and safety of risperidone in adolescents with schizophrenia. J Child Adolesc Psychopharmacol. 2009b;19(6):611–21. PMID: 20035579.20035579
63 Haas M, Delbello MP, Pandina G, . Risperidone for the treatment of acute mania in children and adolescents with bipolar disorder: a randomized, double-blind, placebo-controlled study. Bipolar Disord. 2009c;11(7):687–700. PMID: 19839994.19839994
64 Kent JM, Kushner S, Ning X, . Risperidone dosing in children and adolescents with autistic disorder: a double-blind, placebo-controlled study. J Autism Dev Disord. 2013;43(8):1773–83. PMID: 23212807.23212807
65 Delbello MP, Versavel M, Ice K, . Tolerability of oral ziprasidone in children and adolescents with bipolar mania, schizophrenia, or schizoaffective disorder. J Child Adolesc Psychopharmacol. 2008;18(5):491–9. PMID: 18928413.18928413
66 Remington G, Sloman L, Konstantareas M, . Clomipramine versus haloperidol in the treatment of autistic disorder: a double-blind, placebo-controlled, crossover study. J Clin Psychopharmacol. 2001;21(4):440–4. PMID: 11476129.11476129
67 Anderson LT, Campbell M, Adams P, . The effects of haloperidol on discrimination learning and behavioral symptoms in autistic children. J Autism Dev Disord. 1989;19(2):227–39. PMID 2663834.2663834
68 Conus P, Berk M, Cotton SM, . Olanzapine or chlorpromazine plus lithium in first episode psychotic mania: An 8-week randomised controlled trial. Eur Psychiatry. 2015;30(8):975–82. PMID: 26485297.26485297
69 Findling RL, Goldman R, Chiu YY, . Pharmacokinetics and tolerability of lurasidone in children and adolescents with psychiatric disorders. Clin Ther. 2015;37(12):2788–97. PMID: 26631428.26631428
70 Loebel A, Brams M, Goldman RS, . Lurasidone for the treatment of irritability associated with austistic disorder. J Autism Dev Discord. 2016:46(4):1153–63. PMID: 26659550.26659550
71 Ronsley R, Nguyen D, Davidson J, . Increased risk of obesity and metabolic dysregulation following 12 months of second-generation antipsychotic treatment in children: a prospective cohort study. Can J Psychiatry. 2015;60(10):441–50. PMID: 2672019126720191