# Appendix F Excluded Studies

1 Adler BA, Wink LK, Early M, . Drug-refractory aggression, self-injurious behavior, and severe tantrums in autism spectrum disorders: a chart review study. Autism. 2015;19(1):102–6. DOI: 10.1177/1362361314524641. PMID: 24571823. EXCLUDE: Study Design.24571823
2 Adelugba O, Mela M, Haq I. Involuntary treatment of psychiatric inpatients certified under the Saskatchewan Mental Health Services Act in a secure forensic psychiatric treatment center. Med Sci Law. 2015;55(2):113–20. PMID: 2464420. EXCLUDE: Age24644230
3 Adis Medical W. Effective treatment of attention-deficit hyperactivity disorder also helps control symptoms of comorbid oppositional defiant disorder. Drugs and Ther Perspect. 2016;32(3):104–9. doi: http://dx.doi.org/10.1007/s40267-015-0269-y. PMID: 20160145075. EXCLUDE: Publication Type.
4 Anderson VM, Goldstein ME, Kydd RR, . Extensive gray matter volume reduction in treatment-resistant schizophrenia. Int J Neuropsychopharmacology 2015;18(7):pyv016. doi:http://dx.doi.org/10.1093/ijnp/pyv016. PMID: 25716781. EXCLUDE: Age.25716781
5 Akkaya C, Sarandol A, Cangur S, . Retrospective database analysis on the effectiveness of typical and atypical antipsychotic drugs in an outpatient clinic setting. Hum Psychopharmacol. 2007;22(8):515–28. DOI: 10.1002/hup.882. PMID: 17868197. EXCLUDE: Age.17868197
6 Alessi NE. Ziprasidone in autism. J Am Acad Child Adol Psychiatry. 2003;42(6):622–3. DOI: http://dx.doi.org/10.1097/01.CHI.0000046853.56865.10. PMID: 12921465. EXCLUDE: Publication Type.12921465
7 Alfaro CL, Wudarsky M, Nicolson R, . Correlation of antipsychotic and prolactin concentrations in children and adolescents acutely treated with haloperidol, clozapine, or olanzapine. J Child Adol Psychopharmacol. 2002;12(2):83–91. PMID: 12188977. EXCLUDE: Study Design.12188977
8 Archie S, Zangeneh-Kazemi A, Akhtar-Danesh N. First-episode affective psychosis and lipid monitoring: Survival analysis of the first abnormal lipid test. Early Interv Psychiatry. 2015;9(6):507–11. doi: http://dx.doi.org/10.1111/eip.12180. PMID: 2014754223. EXCLUDE: Age.25130568
9 Aman M, Buitelaar J, Smedt GD, . Pharmacotherapy of disruptive behavior and item changes on a standardized rating scale: pooled analysis of risperidone effects in children with subaverage IQ. J Child Adol Psychopharmacol. 2005;15(2):220–32. DOI:10.1089/cap.2005.15.220. PMID: 15910206. EXCLUDE: Outcomes.15910206
10 Aman M, Rettiganti M, Nagaraja HN, . Tolerability, safety, and benefits of risperidone in children and adolescents with autism: 21-month follow-up after 8-week placebo-controlled trial. J Child Adol Psychopharmacol. 2015;25(6):482–93. doi: http://dx.doi.org/10.1089/cap.2015.0005. PMID: 26262903. EXCLUDE: Intervention.26262903
11 Aman MG, Kasper W, Manos G, . Line-item analysis of the Aberrant Behavior Checklist: results from two studies of aripiprazole in the treatment of irritability associated with autistic disorder. J Child Adol Psychopharmacol. 2010;20(5):415–22. doi: http://dx.doi.org/10.1089/cap.2009.0120. PMID: 20973712. EXCLUDE: Outcomes.20973712
12 Aman MG, White AJ. Thioridazine dose effects with reference to stereotypic behavior in mentally retarded residents. J Autism Dev Disord. 1988;18(3):355–66. doi: http://dx.doi.org/10.1007/BF02212192. PMID: 1988228303. EXCLUDE: Intervention.3170454
13 Amann BL, Pogarell O, Mergl R, . EEG abnormalities associated with antipsychotics: a comparison of quetiapine, olanzapine, haloperidol and healthy subjects. Hum Psychopharmacol. 2003;18(8):641–6. DOI: 10.1002/hup.537. PMID: 14696024. EXCLUDE: Age.14696024
14 Andrade SE, Lo JC, Roblin D, . Antipsychotic medication use among children and risk of diabetes mellitus. Pediatrics. 2011;128(6):1135–41. DOI: http://dx.doi.org/10.1542/peds.2011-0855. PMID: 22106077. EXCLUDE: Intervention.22106077
15 Andrezina R, Josiassen RC, Marcus RN, . Intramuscular aripiprazole for the treatment of acute agitation in patients with schizophrenia or schizoaffective disorder: a double-blind, placebo-controlled comparison with intramuscular haloperidol. Psychopharmacology. 2006;188(3):281–92. PMID: 16953381. EXCLUDE: Age.16953381
16 Apiquian R, Fresan A, Herrera K, . Minimum effective doses of haloperidol for the treatment of first psychotic episode: a comparative study with risperidone and olanzapine. Int J Neuropsychopharmacol. 2003;6(4):403–8. PMID: 14604455. EXCLUDE: Age.14604455
17 Arato M, O’Connor R, Meltzer HY, . A 1-year, double-blind, placebo-controlled trial of ziprasidone 40, 80 and 160 mg/day in chronic schizophrenia: the Ziprasidone Extended Use in Schizophrenia (ZEUS) study. Int Clin Psychopharmacol. 2002;17(5):207–15. PMID: 12177583. EXCLUDE: Age.12177583
18 Aripiprazole and adolescent schizophrenia: a simple neuroleptic. No comparison with standard neuroleptic in adolescents. Prescrire Int. 2009;18(104):251. PMID: 20025091. EXCLUDE: Publication Type.20025091
19 Aripiprazole and adolescent schizophrenia: a simple neuroleptic. No comparison with standard neuroleptic in adolescents. Prescrire Int. 2009;18(104):251. PMID: 20025091. EXCLUDE: Publication Type.20025091
20 Aripiprazole at adult doses effective in youths with schizophrenia. Brown University Child & Adolescent Psychopharmacology Update. 2008;10(11):1–7. PMID: N/A EXCLUDE: Outcomes.
21 Aripiprazole effective in treating irritability in autistic youth. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(2):4–5. PMID: N/A. EXCLUDE: Publication Type.
22 Armour A, Gottschlich MM, Khoury J, . A randomized, controlled prospective trial of zolpidem and haloperidol for use as sleeping agents in pediatric burn patients. J Burn Care Res. 2008;29(1):238–47. doi: PMID: 18182928. EXCLUDE: Diagnosis.18182928
23 Arranz B, San L, Duenas RM, . Lower weight gain with the orally disintegrating olanzapine than with standard tablets in first-episode never treated psychotic patients. Hum Psychopharmacol. 2007;22(1):11–5. PMID: 17191265. EXCLUDE: Age.17191265
24 Arvanitis LA, Miller BG. Multiple fixed doses of “Seroquel” (quetiapine) in patients with acute exacerbation of schizophrenia: a comparison with haloperidol and placebo. The Seroquel Trial 13 Study Group. Biol Psychiatry. 1997;42(4):233–46. PMID: 9270900. EXCLUDE: Age.9270900
25 Atmaca M, Kuloglu M, Tezcan E, . Quetiapine is not associated with increase in prolactin secretion in contrast to haloperidol. Arch Med Res. 2002;33(6):562–5. PMID: 12505103. EXCLUDE: Age.12505103
26 Atmaca M, Kuloglu M, Tezcan E, . Quetiapine augmentation in patients with treatment resistant obsessive-compulsive disorder: a single-blind, placebo-controlled study. Int Clin Psychopharmacol. 2002;17(3):115–9. PMID: 11981352. EXCLUDE: Age.11981352
27 Attard A, Olofinjana O, Cornelius V, . Paliperidone palmitate long-acting injection--prospective year-long follow-up of use in clinical practice. Acta Psychiatr Scand. 2014;130(1):46–51. PMID: 24117209. EXCLUDE: Study Design.24117209
28 Azorin JM, Spiegel R, Remington G, . A double-blind comparative study of clozapine and risperidone in the management of severe chronic schizophrenia. Am J Psychiatr. 2001;158(8):1305–13. PMID: 11481167. EXCLUDE: Age.11481167
29 Bachmann CJ, Gebhardt S, Lehr D, . Subjective and biological weight-related parameters in adolescents and young adults with schizophrenia spectrum disorder under clozapine or olanzapine treatment. Z Kinder Jugendpsychiatr Psychother. 2012;40(3):151–8. PMID: 22532107. EXCLUDE: Study Design.22532107
30 Bai YM, Chen TT, Wu B, . A comparative efficacy and safety study of long-acting risperidone injection and risperidone oral tablets among hospitalized patients: 12-week randomized, single-blind study. Pharmacopsychiatry. 2006;39(4):135–41. PMID: 16900609. EXCLUDE: Age.16900609
31 Baker RW, Kinon BJ, Maguire GA, . Effectiveness of rapid initial dose escalation of up to forty milligrams per day of oral olanzapine in acute agitation. J Clin Psychopharmacol. 2003;23(4):342–8. PMID: 12920409. EXCLUDE: Age.12920409
32 Baldessarini RJ, Hennen J, Wilson M, . Olanzapine versus placebo in acute mania: treatment responses in subgroups. J Clin Psychopharmacol. 2003;23(4):370–6. PMID: 12920413. EXCLUDE: Age.12920413
33 Bali V, Kamble PS, Aparasu RR. Predictors of concomitant use of antipsychotics and stimulants and its impact on stimulant persistence in pediatric attention deficit hyperactivity disorder. J Manag Care Spec Pharm. 2015;21(6):486–98. PMID: 26011550. EXCLUDE: Outcomes.26011550
34 Bartzokis G, Lu PH, Nuechterlein KH, . Differential effects of typical and atypical antipsychotics on brain myelination in schizophrenia.[Erratum appears in Schizophr Res. 2008;99(1–3):379]. Schizophr Res. 2007;93(1–3):13–22. PMID: 17407804. EXCLUDE: Age.17407804
35 Battaglia J, Moss S, Rush J, . Haloperidol, lorazepam, or both for psychotic agitation? A multicenter, prospective, double-blind, emergency department study. Am J Emerg Med. 1997;15(4):335–40. PMID: 9217519. EXCLUDE: Age.9217519
36 Bauer M, Thase ME, Liu S, . Analysis of potentially predictive factors of efficacy of adjunct extended-release quetiapine fumarate in patients with major depressive disorder. J Psychopharmacol. 2015;29(5):565–74. PMID: 25257148. EXCLUDE: Age.25257148
37 Beasley CM, Jr., Sutton VK, Hamilton SH, . A double-blind, randomized, placebo-controlled trial of olanzapine in the prevention of psychotic relapse. J Clin Psychopharmacol. 2003;23(6):582–94. PMID: 14624189. EXCLUDE: Age.14624189
38 Beasley CM, Jr., Sutton VK, Taylor CC, . Is quality of life among minimally symptomatic patients with schizophrenia better following withdrawal or continuation of antipsychotic treatment? J Clin Psychopharmacol. 2006;26(1):40–4. PMID: 16415704. EXCLUDE: Age.16415704
39 Beasley CM, Jr., Tollefson G, Tran P, . Olanzapine versus placebo and haloperidol: acute phase results of the North American double-blind olanzapine trial. Neuropsychopharmacology. 1996;14(2):111–23. PMID: 8822534. EXCLUDE: Age.8822534
40 Beer F, Heinrich H, Springer S, . Quetiapine in the treatment of psychotic adolescents: a case series of 23 patients with severe early onset psychosis. World J Biol Psychiatr. 2007;8(1):38–41. PMID: 17366348. EXCLUDE: Study Design.17366348
41 Berling I, Isbister GK. Prolonged QT Risk Assessment in Antipsychotic Overdose Using the QT Nomogram. Ann Emerg Med. 2015;66(2):154–64. PMID: 25639523. EXCLUDE: Age.25639523
42 Berman RM, Fava M, Thase ME, . Aripiprazole augmentation in major depressive disorder: a double-blind, placebo-controlled study in patients with inadequate response to antidepressants. CNS Spectr. 2009;14(4):197–206. PMID: 19407731. EXCLUDE: Age.19407731
43 Berwaerts J, Liu Y, Gopal S, . Efficacy and Safety of the 3-Month Formulation of Paliperidone Palmitate vs Placebo for Relapse Prevention of Schizophrenia: A Randomized Clinical Trial. JAMA Psychiatry. 2015;72(8):830–9. PMID: 25820612. EXCLUDE: Age.25820612
44 Bhowmik D, Aparasu RR, Rajan SS, . The utilization of psychopharmacological treatment and medication adherence among Medicaid enrolled children and adolescents with bipolar depression. J Affect Disord 2013;150(2)424–9. PMID: 23747210. EXCLUDE: Intervention.23747210
45 Bhowmik D, Aparasu RR, Rajan SS, . Risk of manic switch associated with antidepressant therapy in pediatric bipolar depression. J Child Adol Psychopharmacol. 2014;24(10):551–61. PMID: 25470655. EXCLUDE: Intervention.25470655
46 Berk M, Tiller JW, Zhao J, . Effects of asenapine in bipolar I patients meeting proxy criteria for moderate-to-severe mixed major depressive episodes: a post hoc analysis. J Clin Psychiatr. 2015;76(6):728–34. PMID: 25612216. EXCLUDE: Age.25612216
47 Berling I, Isbister GK. Prolonged QT Risk Assessment in Antipsychotic Overdose Using the QT Nomogram. Ann Emerg Med. 2015;66(2):154–64. PMID: 25639523. EXCLUDE: Age.25639523
48 Berwaerts J, Liu Y, Gopal S, . Efficacy and Safety of the 3-Month Formulation of Paliperidone Palmitate vs Placebo for Relapse Prevention of Schizophrenia: A Randomized Clinical Trial. JAMA Psychiatry. 2015;72(8):830–9. PMID: 25820612. EXCLUDE: Age.25820612
49 Biederman J, Hammerness P, Doyle R, . Risperidone treatment for ADHD in children and adolescents with bipolar disorder. Neuropsychiatr Dis Treat. 2008;4(1B):203–7. PMID: 18728799. EXCLUDE: Study Design.18728799
50 Biederman J, McDonnell MA, Wozniak J, . Aripiprazole in the treatment of pediatric bipolar disorder: a systematic chart review. CNS Spectr. 2005;10(2):141–8. PMID: 15685125. EXCLUDE: Study Design.15685125
51 Biederman J, Mick E. Comparative open-label trial of atypical neuroleptics in children and adolescents with bipolar disorder. Eur Neuropsychopharmacol. 2004;14(suppI3):S211–S2. PMID: N/A. EXCLUDE: Publication Type.
52 Bildik T, Ozbaran NB, Kose S, . Gunluk uygulamada ayaktan tedavi goren bir ergen hasta populasyonunda aripiprazolun etkinlik ve tolerabilitesi. [Effectiveness and tolerability of aripiprazole in a real-world outpatient population of youth]. Klinik Psikofarmakoloji Bulteni. 2012;22(3):225–34. PMID: 2012576016. EXCLUDE: Study Design.
53 Bissada H, Tasca GA, Barber AM, . Olanzapine in the treatment of low body weight and obsessive thinking in women with anorexia nervosa: a randomized, double-blind, placebo-controlled trial. Am J Psychiatr. 2008;165(10):1281–8. PMID: 18558642. EXCLUDE: Age.18558642
54 Bishop JR, Reilly JL, Harris MS, . Pharmacogenetic associations of the type-3 metabotropic glutamate receptor (GRM3) gene with working memory and clinical symptom response to antipsychotics in first-episode schizophrenia. Psychopharmacology. 2015;232(1):145–54. PMID: 25096017. EXCLUDE: Age.25096017
55 Bitter I, Dossenbach MR, Brook S, . Olanzapine versus clozapine in treatment-resistant or treatment-intolerant schizophrenia. Prog Neuropsychopharmacol Biol Psychiatr. 2004;28(1):173–80. PMID: 14687871. EXCLUDE: Age.14687871
56 Blader JC. Pharmacotherapy and postdischarge outcomes of child inpatients admitted for aggressive behavior. J Clin Psychopharmacol. 2006;26(4):419–25. PMID: 16855463. EXCLUDE: Intervention.16855463
57 Blankenship K, Erickson CA, Stigler KA, . Aripiprazole for irritability associated with autistic disorder in children and adolescents aged 6–17 years. Pediatr Health. 2010;4(4):375–81. PMID: 21359119. EXCLUDE: Publication Type.21359119
58 Blasi G, Selvaggi P, Fazio L, . Variation in Dopamine D2 and Serotonin 5-HT2A Receptor Genes is Associated with Working Memory Processing and Response to Treatment with Antipsychotics. Neuropsychopharmacology. 2015;40(7):1600–8. PMID: 25563748. EXCLUDE: Diagnosis.25563748
59 Blin O, Azorin JM, Bouhours P. Antipsychotic and anxiolytic properties of risperidone, haloperidol, and methotrimeprazine in schizophrenic patients. J Clin Psychopharmacol. 1996;16(1):38–44. PMID: 8834417. EXCLUDE: Age.8834417
60 Bobes J, Gibert J, Ciudad A, . Safety and effectiveness of olanzapine versus conventional antipsychotics in the acute treatment of first-episode schizophrenic inpatients. Prog Neuropsychopharmacol Biol Psychiatr. 2003;27(3):473–81. PMID: 12691783. EXCLUDE: Age.12691783
61 Bogenschutz MP, George Nurnberg H. Olanzapine versus placebo in the treatment of borderline personality disorder. J Clin Psychiatr. 2004;65(1):104–9. PMID: 14744178. EXCLUDE: Age.14744178
62 Bola JR, Mosher LR. At issue: predicting drug-free treatment response in acute psychosis from the Soteria project. Schizophr Bull. 2002;28(4):559–75. PMID: 12795491. EXCLUDE: Study Design.12795491
63 Bola JR, Mosher LR. Treatment of acute psychosis without neuroleptics: two-year outcomes from the Soteria project. J Nerv Ment Dis. 2003;191(4):219–29. PMID: 12695732. EXCLUDE: Intervention.12695732
64 Bondolfi G, Dufour H, Patris M, . Risperidone versus clozapine in treatment-resistant chronic schizophrenia: a randomized double-blind study. The Risperidone Study Group. Am J Psychiatr. 1998;155(4):499–504. PMID: 9545995. EXCLUDE: Age.9545995
65 Booth C, Brown AS, Carico H. Male eating disorders: An update on an underrecognized population. U.S. Pharmacist. 2015;40(10):52–6. PMID: 2015453748. EXCLUDE: Publication Type.
66 Borison RL, Arvanitis LA, Miller BG. ICI 204,636, an atypical antipsychotic: efficacy and safety in a multicenter, placebo-controlled trial in patients with schizophrenia. U.S. SEROQUEL Study Group. J Clin Psychopharmacol. 1996;16(2):158–69. PMID: 8690831. EXCLUDE: Age.8690831
67 Borison RL, Diamond B, Pathiraja A, . Pharmacokinetics of risperidone in chronic schizophrenic patients. Psychopharmacol Bull. 1994;30(2):193–7. PMID: 7530379. EXCLUDE: Age.7530379
68 Bornstein RA, Yang V. Neuropsychological performance in medicated and unmedicated patients with Tourette’s disorder. Am J Psychiatr. 1991;148(4):468–71. DOI: PMID: 1672484. EXCLUDE: Intervention.1672484
69 Borovcanin M, Jovanovic I, Dejanovic SD, . Increase systemic levels of IL-23 as a possible constitutive marker in schizophrenia. Psychoneuroendocrinology. 2015;56:143–7. PMID: 25827958. EXCLUDE: Age.25827958
70 Boter H, Peuskens J, Libiger J, . Effectiveness of antipsychotics in first-episode schizophrenia and schizophreniform disorder on response and remission: an open randomized clinical trial (EUFEST). Schizophr Res. 2009;115(2–3):97–103. PMID: 19819114. EXCLUDE: Age.19819114
71 Bowden CL, Grunze H, Mullen J, . A randomized, double-blind, placebo-controlled efficacy and safety study of quetiapine or lithium as monotherapy for mania in bipolar disorder. J Clin Psychiatr. 2005;66(1):111–21PMID: 15669897. EXCLUDE: Age.15669897
72 Breier A, Meehan K, Birkett M, . A double-blind, placebo-controlled dose-response comparison of intramuscular olanzapine and haloperidol in the treatment of acute agitation in schizophrenia. Arch Gen Psychiatr. 2002;59(5):441–8. PMID: 11982448. EXCLUDE: Age.11982448
73 Broerse A, Crawford TJ, den Boer JA. Differential effects of olanzapine and risperidone on cognition in schizophrenia? A saccadic eye movement study. J Neuropsychiatry Clin Neurosc. 2002;14(4):454–60. PMID: 12426415. EXCLUDE: Age.12426415
74 Buck TR, Viskochil J, Farley M, . Psychiatric comorbidity and medication use in adults with autism spectrum disorder. J Autism Dev Disord. 2014 2014;44(12):3063–71. DOI: EXCLUDE: Study Design.24958436
75 Butterfield MI, Becker ME, Connor KM, . Olanzapine in the treatment of post-traumatic stress disorder: a pilot study. Int Clin Psychopharmacol. 2001;16(4):197–203. PMID: 11459333. EXCLUDE: Age.11459333
76 Byerly MJ, Nakonezny PA, Bettcher BM, . Sexual dysfunction associated with second-generation antipsychotics in outpatients with schizophrenia or schizoaffective disorder: an empirical evaluation of olanzapine, risperidone, and quetiapine. Schizophr Res. 2006;86(1–3):244–50. PMID: 16730951. EXCLUDE: Age.16730951
77 Caicedo C, Williams SH. Risperidone improves behavior in children with autism. J Fam Pract. 2002 Nov;51(11):915. PMID: 12485538. EXCLUDE: Publication Type.12485538
78 Calabrese JR, Keck PE, Jr., Macfadden W, . A randomized, double-blind, placebo-controlled trial of quetiapine in the treatment of bipolar I or II depression. Am J Psychiatr. 2005;162(7):1351–60. PMID: 15994719. EXCLUDE: Age.15994719
79 Calarge CA, Acion L, Kuperman S, . Weight gain and metabolic abnormalities during extended risperidone treatment in children and adolescents. J Child Adolesc Psychopharmacol. 2009;19(2):101–9. PMID: 19364288. EXCLUDE: Study Design.19364288
80 Calarge CA, Burns TL, Schlechte JA, . Longitudinal examination of the skeletal effects of selective serotonin reuptake inhibitors and risperidone in boys. J Clin Psychiatr. 2015;76(5):607–13. PMID: 26035190. EXCLUDE: Intervention.26035190
81 Bressington D, Stock J, Hulbert S, . A retrospective observational study of the effectiveness of paliperidone palmitate on acute inpatient hospitalization rates. Int Clin Psychopharmacol. 2015;30(4):230–6. PMID: 25882381. EXCLUDE: Age.25882381
82 Bridler R, Haberle A, Muller ST, . Psychopharmacological treatment of 2195 in-patients with borderline personality disorder: A comparison with other psychiatric disorders. Euro Neuropsychopharmacology. 2015;25(6):763–72. PMID: 25907249. EXCLUDE: Diagnosis.25907249
83 Brown R, James A. Practical pharmacotherapy in child psychiatry: An update. Adv Psychiatr Treat. 2015;21(6):387–95. PMID: 2015540704. EXCLUDE: Publication Type.
84 Bruno A, Zoccali RA, Abenavoli E, . Augmentation of clozapine with agomelatine in partial-responder schizophrenia: a 16-week, open-label, uncontrolled pilot study. J Clin Psychopharmacol. 2014;34(4):491–4. PMID: 24911437. EXCLUDE: Age.24911437
85 Calarge CA, Nicol G, Xie D, . Correlates of weight gain during long-term risperidone treatment in children and adolescents. Child Adolsc Psychiatr Ment Health. 2012;6(1):21. PMID: 22643087. EXCLUDE: Study Design.22643087
86 Caldwell MF, Malterer M, Umstead D, . A retrospective evaluation of adjunctive risperidone treatment in severely behaviorally disordered boys receiving psychosocial treatment. J Child Adolesc Psychopharmacol. 2008;18(1):34–43. DOI: PMID: 18294087. EXCLUDE: Outcomes.18294087
87 Camm AJ, Karayal ON, Meltzer H, . Ziprasidone and the corrected QT interval: a comprehensive summary of clinical data. CNS Drugs. 2012;26(4):351–65. PMID: 22452529. EXCLUDE: Age.22452529
88 Campbell M, Adams P, Perry R, . Tardive and withdrawal dyskinesia in autistic children: a prospective study. Psychopharmacol Bull. 1988;24(2):251–5. PMID: 3212157. EXCLUDE: Study Design.3212157
89 Campbell M, Armenteros JL, Malone RP, . Neuroleptic-related dyskinesias in autistic children: a prospective, longitudinal study. J Am Acad Child Adolesc Psychiatr. 1997;36(6):835–43. PMID: 9183140. EXCLUDE: Study Design.9183140
90 Campbell M, Locascio JJ, Choroco MC, . Stereotypies and tardive dyskinesia: abnormal movements in autistic children. Psychopharmacol Bull. 1990;26(2):260–6. PMID: 2236468. EXCLUDE: Study Design.2236468
91 Canuso CM, Dirks B, Carothers J, . Randomized, double-blind, placebo-controlled study of paliperidone extended-release and quetiapine in inpatients with recently exacerbated schizophrenia. Am J Psychiatr. 2009;166(6):691–701. PMID: 19411369. EXCLUDE: Age.19411369
92 Carey PD, Vythilingum B, Seedat S, . Quetiapine augmentation of SRIs in treatment refractory obsessive-compulsive disorder: a double-blind, randomised, placebo-controlled study. BMC Psychiatry. 2005;5:5. PMID: 15667657. EXCLUDE: Age.15667657
93 Carlson GA, Lavelle J, Bromet EJ. Medication treatment in adolescents vs. adults with psychotic mania. J Child Adolesc Psychopharmacol. 1999;9(3):221–31. PMID: 10521014. EXCLUDE: Intervention.10521014
94 Carrasco JL, Gutierrez M, Gomez JC, . Treatment of severely psychotic inpatients with schizophrenia: olanzapine versus other antipsychotic drugs. Int Clin Psychopharmacol. 2002;17(6):287–95. PMID: 12409682. EXCLUDE: Age.12409682
95 Calver L, Drinkwater V, Gupta R, . Droperidol v. haloperidol for sedation of aggressive behaviour in acute mental health: randomised controlled trial. Br J Psychiatr. 2015;206(3):223–8. doi: PMID: 25395689. EXCLUDE: Age.25395689
96 Centorrino F, Masters GA, Talamo A, . Metabolic syndrome in psychiatrically hospitalized patients treated with antipsychotics and other psychotropics. Hum Psychopharmacol. 2012;27(5):521–6. PMID: 22996619. EXCLUDE: Publication Type.22996619
97 Chang JS, Hwang SS, Yi SH, . Evaluating subjective domains of antipsychotic-induced adverse effects using heart rate variability. Psychiatry Clin Neurosci. 2015;69(5):283–91. PMID: 25066617. EXCLUDE: Age.25066617
98 Chappell P, Sallee F. The tolerability and efficacy of ziprasidone in the treatment of children and adolescents with Tourette’s syndrome [abstract]. 11th European College of Neuropsychopharmacology Congress; Paris, France. 1998:P2.017. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/327/CN-00279327/frame.html. EXCLUDE: Publication Type.
99 Chaves C, Marque CR, Maia-de-Oliveira JP, . Effects of minocycline add-on treatment on brain morphometry and cerebral perfusion in recent-onset schizophrenia. Schizophr Res. 2015;161(2–3):439–45. PMID: 25497439. EXCLUDE: Age.25497439
100 Chen VCH, Liao YT, Lai TJ, . Survival analysis of the use of first and second generation antipsychotics among patients suffering schizophrenia: A nationwide population-based cohort study. Schizophr Res. 2015;169(1–3):406–11. PMID: 20151062335. EXCLUDE: Intervention.26481616
101 Chen JX, Su YA, Bian QT, . Adjunctive aripiprazole in the treatment of risperidone-induced hyperprolactinemia: A randomized, double-blind, placebo-controlled, dose-response study. Psychoneuroendocrinology. 2015;58:130–40. PMID: 25981348. EXCLUDE: Age.25981348
102 Chiu CC, Chen KP, Liu HC, . The early effect of olanzapine and risperidone on insulin secretion in atypical-naive schizophrenic patients. J Clin Psychopharmacol. 2006;26(5):504–7. PMID: 16974193. EXCLUDE: Age.16974193
103 Chouinard G. A placebo-controlled clinical trial of remoxipride and chlorpromazine in newly admitted schizophrenic patients with acute exacerbation. Acta Psychiatr Scand Suppl. 1990;358:111–9. PMID: 1978469. EXCLUDE: Age.1978469
104 Chrzanowski WK, Marcus RN, Torbeyns A, . Effectiveness of long-term aripiprazole therapy in patients with acutely relapsing or chronic, stable schizophrenia: a 52-week, open-label comparison with olanzapine. Psychopharmacology. 2006;189(2):259–66. PMID: 17058105. EXCLUDE: Age.17058105
105 Chue P, Eerdekens M, Augustyns I, . Comparative efficacy and safety of long-acting risperidone and risperidone oral tablets. European Neuropsychopharmacology. 2005;15(1):111–7. PMID: 15572280. EXCLUDE: Age.15572280
106 Citrome L, Volavka J, Czobor P, . Efficacy of ziprasidone against hostility in schizophrenia: Post hoc analysis of randomized, open-label study data. J Clin Psychiatry. 2006;67(4):638–42. PMID: 16669729. EXCLUDE: Age.16669729
107 Ciudad A, Olivares JM, Bousono M, . Improvement in social functioning in outpatients with schizophrenia with prominent negative symptoms treated with olanzapine or risperidone in a 1 year randomized, open-label trial. Progr Neuropsychopharmacol Biol Psychiatry. 2006;30(8):1515–22. PMID: 16820255. EXCLUDE: Age.16820255
108 Clozapine more effective than high-dose olanzapine in early-onset schizophrenia. Brown University Child & Adolescent Psychopharmacology Update. 2007;9(10):1–4. PMID: 105971262. EXCLUDE: Outcomes.
109 Clozapine versus olanzapine for COS. Brown University Child & Adolescent Psychopharmacology Update. 2006;8(9):4. PMID: 106223379. EXCLUDE: Publication Type.
110 Cohen BM, Lipinski JF, Waternaux C. A fixed dose study of the plasma concentration and clinical effects of thioridazine and its major metabolites. Psychopharmacology. 1989;97(4):481–8. PMID: 2498945. EXCLUDE: Age.2498945
111 Cohen LS. Quetiapine in treatment-resistant obsessive-compulsive disorder. J Am Acad Child Adolesc Psychiatry. 2003;42(6):623–4. PMID: 12921466. EXCLUDE: Study Design.12921466
112 Coley KC, Carter CS, DaPos SV, . Effectiveness of antipsychotic therapy in a naturalistic setting: a comparison between risperidone, perphenazine, and haloperidol. J Clin Psychiatry. 1999;60(12):850–6. PMID: 10665632. EXCLUDE: Age.10665632
113 Conley RR, Kelly DL, Nelson MW, . Risperidone, quetiapine, and fluphenazine in the treatment of patients with therapy-refractory schizophrenia. Clin Neuropharmacol. 2005;28(4):163–8. PMID: 16062094. EXCLUDE: Age.16062094
114 Connor DF, Fletcher KE, Wood JS. Neuroleptic-related dyskinesias in children and adolescents. J Clin Psychiatry. 2001;62(12):967–74. PMID: 11780878. EXCLUDE: Intervention.11780878
115 Consoli A, Brunelle J, Bodeau N, . Medication use in adolescents treated in a French psychiatric setting for acute manic or mixed episode. J Canadian Acad Child Adolesc Psychiatry. 2009;18(3):231–8. PMID: 19718424. EXCLUDE: Study Design.19718424
116 Cookson J, Keck PE, Jr., Ketter TA, . Number needed to treat and time to response/remission for quetiapine monotherapy efficacy in acute bipolar depression: evidence from a large, randomized, placebo-controlled study. Int Clin Psychopharmacol. 2007;22(2):93–100. PMID: 17293709. EXCLUDE: Age.17293709
117 Cooper SJ, Tweed J, Raniwalla J, . A placebo-controlled comparison of zotepine versus chlorpromazine in patients with acute exacerbation of schizophrenia. Acta Psychiatr Scand. 2000;101(3):218–25. PMID: 10721870. EXCLUDE: Age.10721870
118 Coraci LM. Atypical neuroleptic response in non-psychotic adolescents [Ph.D.]. Ann Arbor: Fairleigh Dickinson University; 2008. EXCLUDE: Study Design.
119 Coraci LM. Atypical neuroleptic response in non-psychotic adolescents. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009;69(7-B). EXCLUDE: Study Design.
120 Correll CU. Antipsychotic medications. http://dx.doi.org.login.ezproxy.library.ualberta.ca/10.1176/appi.books.9781615370306.md38. Dulcan, Mina K [Ed]. 2016. EXCLUDE: Publication Type.
121 Correia CT, Almeida JP, Santos PE, . Pharmacogenetics of risperidone therapy in autism: association analysis of eight candidate genes with drug efficacy and adverse drug reactions. Pharmacogenomics J. 2010;10(5):418–30. PMID: 19997080. EXCLUDE: Study Design.19997080
122 Correll CU, Zhao J, Carson W, . Early antipsychotic response to aripiprazole in adolescents with schizophrenia: predictive value for clinical outcomes. J Am Acad Child Adolesc Psychiatry. 2013;52(7):689–98.e3. PMID: 23800482. EXCLUDE: Intervention.23800482
123 Corrigan MH, Gallen CC, Bonura ML, . Effectiveness of the selective D4 antagonist sonepiprazole in schizophrenia: a placebo-controlled trial. Biol Psychiatry. 2004;55(5):445–51. PMID: 15023570. EXCLUDE: Age.15023570
124 Cote AT, Devlin AM, Panagiotopoulos C. Initial screening of children treated with second-generation antipsychotics points to an association between physical activity and insulin resistance. Pediatr Exe Sci. 2014;26(4):455–62. PMID: 103912834. EXCLUDE: Study Design.
125 Court A, Mulder C, Kerr M, . Investigating the effectiveness, safety and tolerability of quetiapine in the treatment of anorexia nervosa in young people: a pilot study. J Psychiatr Res. 2010;44(15):1027–34. PMID: 20447652. EXCLUDE: Age.20447652
126 Covington L, Cola PA. Clozapine vs. Haloperidol: antipsychotic effects on sexual function in schizophrenia. Sex Disabil. 2000;18(1):41–8. PMID: N/A. EXCLUDE: Age.
127 Crespo-Facorro B, Carrasco-Marin E, Perez-Iglesias R, . Interleukin-12 plasma levels in drug-naive patients with a first episode of psychosis: Effects of antipsychotic drugs. Psychiatry Res. 2008;158(2):206–16. PMID: 18243335. EXCLUDE: Age.18243335
128 Crespo-Facorro B, Perez-Iglesias R, Ramirez-Bonilla M, . A practical clinical trial comparing haloperidol, risperidone, and olanzapine for the acute treatment of first-episode nonaffective psychosis. J Clin Psychiatry. 2006;67(10):1511–21. PMID: 17107241. EXCLUDE: Age.17107241
129 Cressman AM, Macdonald EM, Huang A, . Prescription stimulant use and hospitalization for psychosis or mania: A population-based study. J Clin Psychopharmacol. 2015;35(6):667–71. PMID: 2015466252. EXCLUDE: Intervention.26485338
130 Cuesta MJ, Jalon EG, Campos MS, . Cognitive effectiveness of olanzapine and risperidone in first-episode psychosis. Br J Psychiatry. 2009;194(5):439–45. PMID: 19407274. EXCLUDE: Age.19407274
131 Curran MP. Aripiprazole in the treatment of irritability associated with autistic disorder in paediatric patients: profile report. CNS Drugs. 2011 Sep 1;25(9):801–2. PMID: 21870890. EXCLUDE: Publication Type.21870890
132 Curran MP. Aripiprazole: in the treatment of irritability associated with autistic disorder in pediatric patients. Paediatr Drugs. 2011;13(3):197–204. PMID: 21500873. EXCLUDE: Publication Type.21500873
133 Currier GW, Chou JC, Feifel D, . Acute treatment of psychotic agitation: a randomized comparison of oral treatment with risperidone and lorazepam versus intramuscular treatment with haloperidol and lorazepam. J Clin Psychiatry. 2004;65(3):386–94. PMID: 15096079. EXCLUDE: Age.15096079
134 Curtis J, Henry C, Watkins A, . Metabolic abnormalities in an early psychosis service: a retrospective, naturalistic cross-sectional study. Early Interv Psychiatry. 2011;5(2):108–14. PMID: 21470374. EXCLUDE: Study Design.21470374
135 Cutler AJ, Kalali AH, Weiden PJ, . Four-week, double-blind, placebo- and ziprasidone-controlled trial of iloperidone in patients with acute exacerbations of schizophrenia. J Clin Psychopharmacol. 2008;28(2 Suppl 1):S20–8. PMID: 18334909. EXCLUDE: Age.18334909
136 Czobor P, Volavka J, Meibach RC. Effect of risperidone on hostility in schizophrenia. J Clin Psychopharmacol. 1995;15(4):243–9. PMID: 7593706. EXCLUDE: Age.7593706
137 Daglas R, Cotton SM, Allott K, . A single-blind, randomised controlled trial on the effects of lithium and quetiapine monotherapy on the trajectory of cognitive functioning in first episode mania: A 12-month follow-up study. Eur Psychiatr. 2016;31:20–8. PMID: 26655594. EXCLUDE: Intervention.26655594
138 Daniel DG, Currier GW, Zimbroff DL, . Efficacy and safety of oral aripiprazole compared with haloperidol in patients transitioning from acute treatment with intramuscular formulations. J Psychiat Pract. 2007;13(3):170–7. PMID: 17522560. EXCLUDE: Age.17522560
139 Daniel DG, Zimbroff DL, Potkin SG, . Ziprasidone 80 mg/day and 160 mg/day in the acute exacerbation of schizophrenia and schizoaffective disorder: a 6-week placebo-controlled trial. Ziprasidone Study Group. Neuropsychopharmacology. 1999;20(5):491–505. PMID: 10192829. EXCLUDE: Age.10192829
140 Davidson M, Galderisi S, Weiser M, . Cognitive effects of antipsychotic drugs in first-episode schizophrenia and schizophreniform disorder: a randomized, open-label clinical trial (EUFEST).[Erratum appears in Am J Psychiatry. 2009 Jun;166(6):731]. Am J Psychiatry. 2009;166(6):675–82. PMID: 19369319. EXCLUDE: Age.19369319
141 de Haan L, van Amelsvoort T, Rosien K, . Weight loss after switching from conventional olanzapine tablets to orally disintegrating olanzapine tablets. Psychopharmacology. 2004;175(3):389–90. PMID: 15322727. EXCLUDE: Age.15322727
142 De Hert M, Schreurs V, Sweers K, . Typical and atypical antipsychotics differentially affect long-term incidence rates of the metabolic syndrome in first-episode patients with schizophrenia: a retrospective chart review. Schizophr Res. 2008;101(1–3):295–303. PMID: 18299188. EXCLUDE: Age.18299188
143 de Hoogd S, Overbeek WA, Heerdink ER, . Differences in body mass index z-scores and weight status in a Dutch pediatric psychiatric population with and without use of second-generation antipsychotics. J Child Adolesc Psychopharmacol. 2012;22(2):166–73. PMID: 22506734. EXCLUDE: Study Design.22506734
144 Degrauw RS, Li JZ, Gilbert DL. Body mass index changes and chronic neuroleptic drug treatment for Tourette syndrome. Pediatr Neurol. 2009;41(3):183-PMID: 19664533. EXCLUDE: Intervention.19664533
145 Delate T, Kauffman YS, Botts SR, . Metabolic monitoring in commercially insured pediatric patients newly initiated to take a second-generation antipsychotic. JAMA Pediatr. 2014;168(7):679–81. PMID: 24796974. EXCLUDE: Intervention.24796974
146 DelBello M, Detke HC, Landry J, . Safety and efficacy of olanzapine/fluoxetine combination versus placebo in patients aged 10 to 17 in the acute treatment of major depressive episodes associated with bipolar i disorder. Neuropsychopharmacology 2012:S99–s100. 10.1016/j.jaac.2014.12.012. EXCLUDE: Publication Type.
147 DelBello M, Versave M, Ice K, . An open-label study of ziprasidone in pediatric patients with bipolar disorder: safety, tolerability, efficacy, and functional outcomes. Bipolar Disord 2006:27. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/725/CN-00712725/frame.html. EXCLUDE: Publication Type.
148 Detke HC, DelBello MP, Landry J, . Olanzapine/Fluoxetine combination in children and adolescents with bipolar I depression: a randomized, double-blind, placebo-controlled trial. J Am Acad Child Adolesc Psychiatry. 2015;54(3):217–24. PMID: 25721187. EXCLUDE: Intervention.25721187
149 Dion Y, Annable L, Sandor P, . Risperidone in the treatment of tourette syndrome: a double-blind, placebo-controlled trial. J Clin Psychopharmacol. 2002;22(1):31–9. PMID: 11799340. EXCLUDE: Age.11799340
150 Dowling Bruun R. Subtle and underrecognized side effects of neuroleptic treatment in children with Tourette’s disorder. Am J Psychiatry. 1988;145(5):621–4. PMID: 2895987. EXCLUDE: Publication Type.2895987
151 Edelsohn GA, Parthasarathy M, Terhorst L, . Measurement of metabolic monitoring in youth and adult medicaid recipients prescribed antipsychotics. J Manag Care Pharm. 2015;21(9):769–77. PMID: 2015499690. EXCLUDE: Diagnosis.
152 Effects of quetiapine on adolescent conduct disorder. Brown University Child & Adolescent Psychopharmacology Update. 2008;10(7):3–4. PMID: 105796599. EXCLUDE: Publication Type.
153 Effects of risperidone on cognitive function in children with disruptive behaviors. Brown University Child & Adolescent Psychopharmacology Update. 2007;9(9):4–5. PMID: 105969211. EXCLUDE: Publication Type.
154 Elbe D, Barr AM, Honer WG, . Managing ADHD and disruptive behaviour disorders with combination psychostimulant and antipsychotic treatment. J Psychiatry and Neurosci. 2014;39(3):32–3. PMID: 24758945. EXCLUDE: Publication Type.24758945
155 El-Missiry A, Elbatrawy A, El-Missiry M, . Comparing cognitive functions in medication adherent and non-adherent patients with schizophrenia. J Psychiatric Res. 2015;70:106–12. doi: PMID: 2015432869. EXCLUDE: Age.
156 Emsley RA. Risperidone in the treatment of first-episode psychotic patients: a double-blind multicenter study. Risperidone Working Group. Schizophr Bull. 1999;25(4):721–9. PMID: 10667742. EXCLUDE: Age.10667742
157 Emsley RA, Raniwalla J, Bailey PJ, . A comparison of the effects of quetiapine (‘seroquel’) and haloperidol in schizophrenic patients with a history of and a demonstrated, partial response to conventional antipsychotic treatment. PRIZE Study Group. Int Clin Psychopharmacol. 2000;15(3):121–31. PMID: 10870870. EXCLUDE: Age.10870870
158 Endicott J, Paulsson B, Gustafsson U, . Quetiapine monotherapy in the treatment of depressive episodes of bipolar I and II disorder: Improvements in quality of life and quality of sleep. J Affect Disord. 2008;111(2–3):306–19. PMID: 18774180. EXCLUDE: Age.18774180
159 Endicott J, Rajagopalan K, Minkwitz M, . A randomized, double-blind, placebo-controlled study of quetiapine in the treatment of bipolar I and II depression: improvements in quality of life. Int Clin Psychopharmacol. 2007;22(1):29–37. PMID: 17159457. EXCLUDE: Age.17159457
160 Ercan ES, Ardic UA, Ercan E, . A promising preliminary study of aripiprazole for treatment-resistant childhood obsessive-compulsive disorder. J Child Adolesc Psychopharmacol. 2015;25(7):580–4. PMID: 26375768. EXCLUDE: Intervention.26375768
161 Erzegovesi S, Guglielmo E, Siliprandi F, . Low-dose risperidone augmentation of fluvoxamine treatment in obsessive-compulsive disorder: a double-blind, placebo-controlled study. Eur Neuropsychopharmacol. 2005;15(1):69–74. PMID: 15572275. EXCLUDE: Age.15572275
162 Esbensen AJ, Greenberg JS, Seltzer MM, . A longitudinal investigation of psychotropic and non-psychotropic medication use among adolescents and adults with autism spectrum disorders. J Autism Dev Disord. 2009;39(9):1339–49. PMID: 19434487. EXCLUDE: Outcomes.19434487
163 Fakra E, Khalfa S, Da Fonseca D, . Effect of risperidone versus haloperidol on emotional responding in schizophrenic patients. Psychopharmacology. 2008;200(2):261–72. PMID: 18575849. EXCLUDE: Age.18575849
164 Farag M, Stern JS, Simmons H, . Serial pharmacological prescribing practices for tic management in Tourette syndrome. Hum Psychopharmacology. 2015;30(6):435–41. PMID: 2015333020. EXCLUDE: Age.
165 Farmer CA, Brown NV, Gadow KD, . Comorbid symptomatology moderates response to risperidone, stimulant, and parent training in children with severe aggression, disruptive behavior disorder, and attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2015;25(3):213–24. PMID: 25885011. EXCLUDE: Outcomes.25885011
166 Faulkner MJ. Factors contributing to weight gain in children who take atypical antipsychotics: University of New Mexico; 2013. EXCLUDE: Publication Type.
167 Fava M, Wisniewski SR, Thase ME, . Metabolic assessment of aripiprazole as adjunctive therapy in major depressive disorder: a pooled analysis of 2 studies. J Clin Psychopharmacol. 2009;29(4):362–7. PMID: 19593176. EXCLUDE: Age.19593176
168 Fedorenko OY, Loonen AJ, Lang F, . Association study indicates a protective role of phosphatidylinositol-4-phosphate-5-kinase against tardive dyskinesia. Int J Neuropsychopharmacol 2015;18(6PMID: 25548108. EXCLUDE: Age.25548108
169 Fervaha G, Takeuchi H, Lee J, . Antipsychotics and amotivation. Neuropsychopharmacology. 2015;40(6):1539–48. PMID: 25567425. EXCLUDE: Age.25567425
170 Findling R, Chiu YY, Silva R, . Pharmacokinetic and safety evaluation of lurasidone in pediatric patients with psychiatric disorders. Schizophr Bull 2015;S31. EXCLUDE: Diagnosis.
171 Findling RL, Daneman D. Prolactin levels during long-term risperidone treatment in children and adolescents: A reanalysis of data. J Clin Psychiatr. 2016;77(2):e155–e70. PMID: 20160192775. EXCLUDE: Publication Type.
172 Findling R, DelBello M, Wang P, . Safety and efficacy of ziprasidone in pediatric bipolar disorder. Eur Neuropsychopharmacol 2009:S682–s3. PMID: N/A. EXCLUDE: Publication Type
173 Findling RL, Frazier JA, Gerbino-Rosen G, . Is there a role for clozapine in the treatment of children and adolescents? J Am Acad Child Adolesc Psychiatry. 2007;46(3):423–8. PMID: 17314729. EXCLUDE: Publication Type.17314729
174 Findling RL, Pathak S, Earley WR, . Safety, tolerability, and efficacy of quetiapine in youth with schizophrenia or bipolar I disorder: a 26-week, open-label, continuation study. J Child Adolesc Psychopharmacol. 2013;23(7):490–501. PMID: 24024534. EXCLUDE: Study Design.24024534
175 Findling RL, Robb A, Nyilas M, . A multiple-center, randomized, double-blind, placebo-controlled study of oral aripiprazole for treatment of adolescents with schizophrenia. Am J Psychiatry. 2008;165(11):1432–41. PMID: 18765484. EXCLUDE: Duplicate.18765484
176 Findling RL, Youngstrom EA, Zhao J, . Respondent and item level patterns of response of aripiprazole in the acute treatment of pediatric bipolar I disorder. J Affect Disord. 2012;143(1–3):231–5. PMID: 23044285. EXCLUDE: Outcomes.23044285
177 Fleischhacker WW, McQuade RD, Marcus RN, . A double-blind, randomized comparative study of aripiprazole and olanzapine in patients with schizophrenia. Biol Psychiatry. 2009;65(6):510–7. PMID: 18986646. EXCLUDE: Age.18986646
178 Foley DL, Mackinnon A, Morgan VA, . Effect of age, family history of diabetes, and antipsychotic drug treatment on risk of diabetes in people with psychosis: a population-based cross-sectional study. The Lancet. Psychiatry. 2015;2(12):1092–8. PMID: 26477242. EXCLUDE: Age.26477242
179 Fraguas D, Llorente C, Rapado-Castro M, . Attitude toward antipsychotic medication as a predictor of antipsychotic treatment discontinuation in first-episode early-onset psychosis. Rev Psiquiatr Salud Ment. 2008;1(1):10–7. PMID: 23040428. EXCLUDE: Outcomes.23040428
180 Frazier JA, Giuliano AJ, Johnson JL, . Neurocognitive outcomes in the treatment of early-onset schizophrenia spectrum disorders study. J Am Acad Child Adolesc Psychiatry. 2012;51(5):496–505. PMID: 22525956. EXCLUDE: Intervention.22525956
181 Frazier TW, Youngstrom EA, Haycook T, . Effectiveness of medication combined with intensive behavioral intervention for reducing aggression in youth with autism spectrum disorder. J Child Adolesc Psychopharmacol. 2010;20(3):167–77. PMID: 20578929. EXCLUDE: Intervention.20578929
182 Fusar-Poli P, Frascarelli M, Valmaggia L, . Antidepressant, antipsychotic and psychological interventions in subjects at high clinical risk for psychosis: OASIS 6-year naturalistic study. Psychol Med. 2015;45(6):1327–39.. PMID: 25335776. EXCLUDE: Age.25335776
183 Gaebel W, Moller HJ, Buchkremer G, . Pharmacological long-term treatment strategies in first episode schizophrenia--study design and preliminary results of an ongoing RCT within the German Research Network on Schizophrenia. Eur Arch Psychiatry Clin Neurosci. 2004;254(2):129–40. PMID: 15146342. EXCLUDE: Age.15146342
184 Gagiano C, Read S, Thorpe L, . Short- and long-term efficacy and safety of risperidone in adults with disruptive behavior disorders. Psychopharmacology. 2005;179(3):629–36. PMID: 15668818. EXCLUDE: Age.15668818
185 Gallego JA, Robinson DG, Sevy SM, . Time to treatment response in first-episode schizophrenia: should acute treatment trials last several months? J Clin Psychiatry. 2011;72(12):1691–6. PMID: 21939612. EXCLUDE: Age.21939612
186 Galler A, Bollow E, Meusers M, . Comparison of glycemic and metabolic control in youth with type 1 diabetes with and without antipsychotic medication: analysis from the nationwide German/Austrian Diabetes Survey (DPV). Diabetes Care. 2015;38(6):1051–7. PMID: 25784664. EXCLUDE: Intervention.25784664
187 Garakani A, Martinez JM, Marcus S, . A randomized, double-blind, and placebo-controlled trial of quetiapine augmentation of fluoxetine in major depressive disorder. Int Clin Psychopharmacol. 2008;23(5):269–75. PMID: 18703936. EXCLUDE: Age.18703936
188 Gardner DM, Abidi S, Ursuliak Z, . Incidence of oculogyri ccrisis and long-term out comes with second-generation antipsychotics in a first-episode psychosis program. J Clin Psychopharmacol. 2015;35(6):715–8. PMID: 2015466234. EXCLUDE: Age.26485339
189 Gearing RE, Charach A. Medication adherence for children and adolescents with first-episode psychosis following hospitalization. Eur Child Adolesc Psychiatry. 2009;18(10):587–95. PMID: 19381709. EXCLUDE: Intervention.19381709
190 Geddes JR, Gardiner A, Rendell J, . Comparative evaluation of quetiapine plus lamotrigine combination versus quetiapine monotherapy (and folic acid versus placebo) in bipolar depression (CEQUEL): A 2 × 2 factorial randomised trial. Lancet Psychiatry. 2016;3(1):31–9. PMID: 20151042200. EXCLUDE: Age.26687300
191 Ghaziuddin N, Merchant C, Dopp R, . A naturalistic study of suicidal adolescents treated with an SSRI: Suicidal ideation and behavior during 3-month post-hospitalization period. Asian J Psychiatry. 2014;11:13–9. PMID: 2014724645. EXCLUDE: Intervention.
192 Gitlin M, Nuechterlein K, Subotnik KL, . Clinical outcome following neuroleptic discontinuation in patients with remitted recent-onset schizophrenia. Am J Psychiatry. 2001;158(11):1835–42. PMID: 11691689. EXCLUDE: Age.11691689
193 Godleski LS, Goldsmith LJ, Vieweg WV, . Switching from depot antipsychotic drugs to olanzapine in patients with chronic schizophrenia. J Clin Psychiatry. 2003;64(2):119–22. PMID: 12633119. EXCLUDE: Age.12633119
194 Gomez JC, Sacristan JA, Hernandez J, . The safety of olanzapine compared with other antipsychotic drugs: results of an observational prospective study in patients with schizophrenia (EFESO Study). Pharmacoepidemiologic Study of Olanzapine in Schizophrenia. J Clin Psychiatry. 2000;61(5):335–43. PMID: 10847307. EXCLUDE: Age.10847307
195 Gonzalez-Heydrich J, Raches D, Wilens TE, . Retrospective study of hepatic enzyme elevations in children treated with olanzapine, divalproex, and their combination. J Am Acad Child Adolesc Psychiatry. 2003;42(10):1227–33. PMID: 14560173. EXCLUDE: Study Design.14560173
196 Green AI, Lieberman JA, Hamer RM, . Olanzapine and haloperidol in first episode psychosis: two-year data. Schizophr Res. 2006;86(1–3):234–43. PMID: 16887334. EXCLUDE: Age.16887334
197 Green AI, Tohen MF, Hamer RM, . First episode schizophrenia-related psychosis and substance use disorders: acute response to olanzapine and haloperidol. Schizophr Res. 2004;66(2–3):125–35. PMID: 15061244. EXCLUDE: Age.15061244
198 Goldberg PH, Martin P, Biernacki C, . Treatments for pediatric bipolar disorder. Nathan, Peter E [Ed]. 2015. Exclude: Publication Type.
199 Goldstein ME, Anderson VM, Pillai A, . Glutamatergic neurometabolites in clozapine-responsive and -resistant schizophrenia. Int J Neuropsychopharmacol 2015;18 (6) PMID: 25603859. EXCLUDE: Age.25603859
200 Gonzalez-Rodriguez A, Studerus E, Spitz A, . Gender differences in the psychopathology of emerging psychosis. Isr J Psychiatry Relat Sci. 2014;51(2):85–92. PMID: 25372557. EXCLUDE: Age.25372557
201 Green WH, Padron-Gayol M, Hardesty AS, . Schizophrenia with childhood onset: a phenomenological study of 38 cases. J Am Acad Child Adolesc Psychiatry. 1992;31(5):968–76. PMID: 1400132. EXCLUDE: Outcomes.1400132
202 Greenhill LL, Halperin JM, Barmack J. Cognitive effects of neuroleptic treatment in children with conduct disorder. Richardson, Mary Ann [Ed]. 1996. EXCLUDE: Publication Type.
203 Guler AS, Yazgan Y, Pelin AU. Dikkat eksikligi hiperaktivite bozuklugu olan cocuklarda otizm spektrumuna ozgu ozellikler ve risperidon kullanim kararini belirleyen faktorler. [Autistic traits and factors related to a clinical decision to use risperidone in children with attention deficit hyperactivity disorder]. Bull Clin Psychopharmacol. 2014;24(4):333–41. DOI: http://dx.doi.org/10.5455/bcp.20140616123454. PMID: N/A. EXCLUDE: Study Design.
204 Gunther T, Herpertz-Dahlmann B, Jolles J, . The influence of risperidone on attentional functions in children and adolescents with attention-deficit/hyperactivity disorder and co-morbid disruptive behavior disorder. J Child Adolesc Psychopharmacol. 2006;16(6):725–35. PMID: 17201616. EXCLUDE: Intervention.17201616
205 Gurpegui M, Alvarez E, Bousono M, . Effect of olanzapine or risperidone treatment on some cognitive functions in a one-year follow-up of schizophrenia outpatients with prominent negative symptoms. Eur Neuropsychopharmacol. 2007;17(11):725–34. PMID: 17543505. EXCLUDE: Age.17543505
206 Haas M, Eerdekens M, Kushner S, . Efficacy, safety and tolerability of two dosing regimens in adolescent schizophrenia: double-blind study. Br J Psychiatry. 2009;194(2):158–64. PMID: 19182179. EXCLUDE: Duplicate.19182179
207 Haas M, Unis AS, Armenteros J, . A 6-week, randomized, double-blind, placebo-controlled study of the efficacy and safety of risperidone in adolescents with schizophrenia. J Child Adolesc Psychopharmacol. 2009;19(6):611–21. PMID: 20035579. EXCLUDE: Duplicate.20035579
208 Habibi N, Dodangi N, Nazeri A. Efficacy and Safety of Aripiprazole for Treatment of Irritability in Children with Autistic Disorder: An Open-Label Study. Iran J Med Sci. 2015;40(6):548–9 2p. PMID: 110966669. EXCLUDE: Publication Type.26538787
209 Hamilton SH, Revicki DA, Genduso LA, . Olanzapine versus placebo and haloperidol: quality of life and efficacy results of the North American double-blind trial. Neuropsychopharmacology. 1998;18(1):41–9. PMID: 9408917. EXCLUDE: Age.9408917
210 Haro JM, Novick D, Suarez D, . Antipsychotic treatment discontinuation in previously untreated patients with schizophrenia: 36-month results from the SOHO study. J Psychiatr Res. 2009;43(3):265–73. PMID: 18644606. EXCLUDE: Age.18644606
211 Harrigan EP, Miceli JJ, Anziano R, . A randomized evaluation of the effects of six antipsychotic agents on QTC, in the absence and presence of metabolic inhibition. J Clin Psychopharmacol. 2004;24(1):62–9. PMID: 14709949. EXCLUDE: Age.14709949
212 Harvey PD, Green MF, McGurk SR, . Changes in cognitive functioning with risperidone and olanzapine treatment: a large-scale, double-blind, randomized study. Psychopharmacology. 2003;169(3–4):404–11. PMID: 12590356. EXCLUDE: Age.12590356
213 Harvey PD, Patterson TL, Potter LS, . Improvement in social competence with short-term atypical antipsychotic treatment: a randomized, double-blind comparison of quetiapine versus risperidone for social competence, social cognition, and neuropsychological functioning. Am J Psychiatry. 2006;163(11):1918–25. PMID: 17074943. EXCLUDE: Age.17074943
214 Hassan M, Madhavan SS, Kalsekar ID, . Comparing adherence to and persistence with antipsychotic therapy among patients with bipolar disorder. Ann Pharmacother. 2007;41(11):1812–8. PMID: 17925501. EXCLUDE: Age.17925501
215 Hayes RD, Downs J, Chang CK, . The effect of clozapine on premature mortality: an assessment of clinical monitoring and other potential confounders. Schizophr Bull. 2015;41(3):644–55. PMID: 25154620. EXCLUDE: Age.25154620
216 Heresco-Levy U, Greenberg D, Lerer B, . Trial of maintenance neuroleptic dose reduction in schizophrenic outpatients: two-year outcome. J Clin Psychiatry. 1993;54(2):59–62. PMID: 8095259. EXCLUDE: Age.8095259
217 Hellings JA, Jadhav M, Jain S, . Low Dose Loxapine: Neuromotor Side Effects and Tolerability in Autism Spectrum Disorders. J Child Adolesc Psychopharmacol. 2015;25(8):618–24. PMID: 2015481269. EXCLUDE: Intervention.26485086
218 Hoekstra PJ, Troost PW, Lahuis BE, . Risperidone-induced weight gain in referred children with autism spectrum disorders is associated with a common polymorphism in the 5-hydroxytryptamine 2C receptor gene. J Child Adolesc Psychopharmacol. 2010;20(6):473–7. PMID: 21186965. EXCLUDE: Study Design.21186965
219 Honer WG, Kopala LC, Rabinowitz J. Extrapyramidal symptoms and signs in first-episode, antipsychotic exposed and non-exposed patients with schizophrenia or related psychotic illness. J Psychopharmacol. 2005;19(3):277–85. PMID: 15888513. EXCLUDE: Age.15888513
220 Hong IS, Bishop JR. Anticholinergic use in children and adolescents after initiation of antipsychotic therapy. Ann Pharmacother. 2010;44(7–8):1171–80. PMID: 20587746. EXCLUDE: Outcomes.20587746
221 Hongkaew Y, Ngamsamut N, Puangpetch A, . Hyperprolactinemia in Thai children and adolescents with autism spectrum disorder treated with risperidone. Neuropsychiatr Dis Treat. 2015;11:191–6. PMID: 25653528. EXCLUDE: Study Design.25653528
222 Howland RH. Use of atypical antipsychotics in children and adolescents. J Psychosoc Nurs Ment Health Serv. 2005;43(8):15–8. PMID: 16149723. EXCLUDE: Publication Type.16149723
223 Huang YS, Yeh CB, Tang CS, . Effectiveness of aripiprazole in adolescents and young adults with schizophrenia spectrum disorders: comparison of first-episode to recurrent psychosis. Early Interv Psychiatry. 2013;7(1):89–93. PMID: 22816371. EXCLUDE: Study Design.22816371
224 Hugenholtz GW, Heerdink ER, Meijer WE, . Reasons for switching between antipsychotics in daily clinical practice. Pharmacopsychiatry. 2005;38(3):122–4. PMID: 15902582. EXCLUDE: Age.15902582
225 Hugenholtz GW, Heerdink ER, Nolen WA, . Less medication switching after initial start with atypical antipsychotics. Eur Neuropsychopharmacol. 2004;14(1):1–5. PMID: 14659981. EXCLUDE: Age.14659981
226 Huq ZU, Investigators R-G. A trial of low doses of risperidone in the treatment of patients with first-episode schizophrenia, schizophreniform disorder, or schizoaffective disorder. J Clin Psychopharmacol. 2004;24(2):220–4. PMID: 15206670. EXCLUDE: Age.15206670
227 Ingole S, Belorkar NR, Waradkar P, . Comparison of effects of olanzapine and risperidone on body mass index and blood sugar level in schizophrenic patients. Indian J Physiol Pharmacol. 2009;53(1):47–54. PMID: 19810576. EXCLUDE: Age.19810576
228 Iqbal E, Mallah R, Jackson RG, . Identification of adverse drug events from free text electronic patient records and information in a large mental health case register. PLoS ONE [Electronic Resource]. 2015;10 (8) (no pagination)(e0134208) EXCLUDE: Intervention.
229 Jain S, Andridge R, Hellings JA. Loxapine for reversal of antipsychotic-induced metabolic disturbances: A chart review. J Autism Dev Disord. 2016;46(4):1344–53. doi: http://dx.doi.org/10.1007/s10803-015-2675-3. EXCLUDE: Intervention.26687568
230 Jakubovski E, Carlson JP, Bloch MH. Prognostic subgroups for remission, response, and treatment continuation in the Clinical Antipsychotic Trials of Intervention Effectiveness (CATIE) trial. J Clin Psychiatr. 2015;76(11):1535–45. PMID: 26581028. EXCLUDE: Age.26581028
231 Jalota R, Bond C, Jose RJ. Quetiapine and the development of the metabolic syndrome. QJM. 2015;108(3):245–7. PMID: 22908317. EXCLUDE: Study Design.22908317
232 Jarskog LF, Lowy MT, Grove RA, . A Phase II study of a histamine H3 receptor antagonist GSK239512 for cognitive impairment in stable schizophrenia subjects on antipsychotic therapy. Schizophr Res. 2015;164(1–3):136–42. PMID: 25728831. EXCLUDE: Age.25728831
233 Jaselskis CA, Cook EH, Jr., Fletcher KE, . Clonidine treatment of hyperactive and impulsive children with autistic disorder. J Clin Psychopharmacol. 1992;12(5):322–7. PMID: 1479049. EXCLUDE: Intervention.1479049
234 Jefferson AM, Markowitz JS, Brewerton TD. Atypical antipsychotics. J Am Acad Child Adolesc Psychiatry. 1998;37(12):1243–4. EXCLUDE: Publication Type.9847493
235 Jerrell JM. Pharmacotherapy in the community-based treatment of children with bipolar I disorder. Hum Psychopharmacol. 2008;23(1):53–9. PMID: 17957821. EXCLUDE: Intervention.17957821
236 Jerrell JM. Neurological and cardiovascular adverse events associated with antimanic treatment in children and adolescents. CNS Neurosci Ther. 2010;16(1):25–31. PMID: 19769597. EXCLUDE: Intervention.19769597
237 Jerrell JM, Tripathi A, Rizvi AA, . The risk of developing type 2 diabetes mellitus associated with psychotropic drug use in children and adolescents: a retrospective cohort analysis. Prim Care Companion CNS Disord 2012;14. (1) PMID: 22690363. EXCLUDE: Study Design.22690363
238 Jiao F, Zhang X, Wang J. Clinical observation on treatment of Tourette syndrome in Chinese children by clonidine adhesive patch. Eur J Paediatr Neurology. 2016;20(1):80–4. PMID: 26602699. EXCLUDE: Intervention.26602699
239 Jing Y. Health outcomes assessment for children and adolescents with bipolar disorder treated with and without atypical antipsychotics [Ph.D.]. Ann Arbor: University of Cincinnati; 2009. EXCLUDE: Unable to Retrieve.
240 Jones PB, Barnes TR, Davies L, . Randomized controlled trial of the effect on quality of life of second-vs first-generation antipsychotic drugs in schizophrenia: Cost Utility of the Latest Antipsychotic Drugs in Schizophrenia Study (CUtLASS 1). Arch Gen Psychiatry. 2006;63(10):1079–87. PMID: 17015810. EXCLUDE: Age.17015810
241 Joshi G, Biederman J, Wozniak J, . Response to second generation antipsychotics in youth with comorbid bipolar disorder and autism spectrum disorder. CNS Neurosci Ther. 2012;18(1):28–33.. PMID: 21114638. EXCLUDE: Intervention.21114638
242 Joshi G, Mick E, Wozniak J, . Impact of obsessive-compulsive disorder on the antimanic response to olanzapine therapy in youth with bipolar disorder. Bipolar Disord. 2010;12(2):196–204. PMID: 20402712. EXCLUDE: Study Design.20402712
243 Joshi G, Petty C, Wozniak J, . A prospective open-label trial of quetiapine monotherapy in preschool and school age children with bipolar spectrum disorder. J Affect Disord. 2012;136(3):1143–53. PMID: 22035648. EXCLUDE: Study Design.22035648
244 Joshi G, Petty C, Wozniak J, . A prospective open-label trial of paliperidone monotherapy for the treatment of bipolar spectrum disorders in children and adolescents. Psychopharmacology. 2013;227(3):449–58. PMID: 23397049. EXCLUDE: Intervention.23397049
245 Joshi PT, Hamel L, Joshi AR, . Use of droperidol in hospitalized children. J Am Acad Child Adolesc Psychiatry. 1998;37(2):228–30. PMID: 9473921. EXCLUDE: Study Design.9473921
246 Joyce C, Witcher R, Herrup E, . Evaluation of the Safety of Quetiapine in Treating Delirium in Critically Ill Children: A Retrospective Review. J Child & Adolesc Psychopharmacol. 2015;25(9):666–70. PMID: 26469214. EXCLUDE: Diagnosis.26469214
247 Juven-Wetzler A, Fostick L, Cwikel-Hamzany S, . Treatment with Ziprasidone for schizophrenia patients with OCD. Eur Neuropsychopharmacol. 2014;24(9):1454–62. PMID: 25048540. EXCLUDE: Age.25048540
248 Kahn RS, Fleischhacker WW, Boter H, . Effectiveness of antipsychotic drugs in first-episode schizophrenia and schizophreniform disorder: an open randomised clinical trial. Lancet. 2008;371(9618):1085–97. PMID: 18374841. EXCLUDE: Age.18374841
249 Kalkan Ucar S, Ozbaran B, Demiral N, . Clinical overview of children with mucopolysaccharidosis type III A and effect of Risperidone treatment on children and their mothers psychological status. Brain Dev. 2010;32(2):156–61. PMID: 19217229. EXCLUDE: Diagnosis.19217229
250 Kampman KM, Pettinati H, Lynch KG, . A pilot trial of olanzapine for the treatment of cocaine dependence. Drug Alcohol Depend 20035;70(3):265–73. PMID: 12757964. EXCLUDE: Age.12757964
251 Kane JM, Detke HC, Naber D, . Olanzapine long-acting injection: a 24-week, randomized, double-blind trial of maintenance treatment in patients with schizophrenia. Am J Psychiatry. 2010;167(2):181–9. PMID: 20008947. EXCLUDE: Age.20008947
252 Kane JM, Eerdekens M, Lindenmayer JP, . Long-acting injectable risperidone: efficacy and safety of the first long-acting atypical antipsychotic. Am J Psychiatry. 2003;160(6):1125–32. PMID: 12777271. EXCLUDE: Age.12777271
253 Kane JM, Skuban A, Ouyang J, . A multicenter, randomized, double-blind, controlled phase 3 trial of fixed-dose brexpiprazole for the treatment of adults with acute schizophrenia. Schizophr Res. 2015;164(1–3):127–35. PMID: 25682550. EXCLUDE: Age.25682550
254 Kapur S, Arenovich T, Agid O, . Evidence for onset of antipsychotic effects within the first 24 hours of treatment. Am J Psychiatry. 2005;162(5):939–46. PMID: 15863796. EXCLUDE: Age.15863796
255 Karagianis J, Grossman L, Landry J, . A randomized controlled trial of the effect of sublingual orally disintegrating olanzapine versus oral olanzapine on body mass index: the PLATYPUS Study.[Erratum appears in Schizophr Res. 2011;133(1–3):266]. Schizophr Res. 2009;113(1):41–8. PMID: 19535229. EXCLUDE: Age.19535229
256 Karaman MG, Ozdemir E, Yurteri N, . Risperidone and serum lipid profile changes in child and adolescent patients. Neurol Psychiatry Brain Res. 2011;17(1):16–20. PMID: N/A EXCLUDE: Study Design.
257 Kass E, Posner JE, Greenhill LL. Pharmacological treatments for attention-deficit/hyperactivity disorder and disruptive behavior disorders. Nathan, Peter E [Ed]. 2015. EXCLUDE: Publication Type.
258 Kaster TS, de Jesus D, Radhu N, . Clozapine potentiation of GABA mediated cortical inhibition in treatment resistant schizophrenia. Schizophr Res. 2015;165(2–3):157–62. PMID: 25957485. EXCLUDE: Age.25957485
259 Kaur H, Jajodia A, Grover S, . Genetic variations of PIP4K2A confer vulnerability to poor antipsychotic response in severely ill schizophrenia patients. 2014;9(7):e102556. PMID: 25025909. EXCLUDE: Age.25025909
260 Keck P, Jr., Buffenstein A, Ferguson J, . Ziprasidone 40 and 120 mg/day in the acute exacerbation of schizophrenia and schizoaffective disorder: a 4-week placebo-controlled trial. Psychopharmacology. 1998;140(2):173–84. PMID: 9860108. EXCLUDE: Age.9860108
261 Keck PE, Orsulak PJ, Cutler AJ, . Aripiprazole monotherapy in the treatment of acute bipolar I mania: a randomized, double-blind, placebo- and lithium-controlled study. J Affect Disord. 2009;112(1–3):36–49. PMID: 18835043. EXCLUDE: Age.18835043
262 Keck PE, Jr., Reeves KR, Harrigan EP, . Ziprasidone in the short-term treatment of patients with schizoaffective disorder: results from two double-blind, placebo-controlled, multicenter studies. J Clin Psychopharmacol. 2001;21(1):27–35. PMID: 11199944. EXCLUDE: Age.11199944
263 Keefe RS, Seidman LJ, Christensen BK, . Comparative effect of atypical and conventional antipsychotic drugs on neurocognition in first-episode psychosis: a randomized, double-blind trial of olanzapine versus low doses of haloperidol. Am J Psychiatry. 2004;161(6):985–95 PMID: 15169686. EXCLUDE: Age15169686
264 Keefe RSE. The longitudinal course of cognitive impairment in schizophrenia: An examination of data from premorbid through posttreatment phases of illness. J Clin Psychiatr. 2014;75(Suppl 2):8–13. EXCLUDE: Publication Type.
265 Keefe RS, Young CA, Rock SL, . One-year double-blind study of the neurocognitive efficacy of olanzapine, risperidone, and haloperidol in schizophrenia. Schizophr Res. 2006;81(1):1–15. PMID: 16202565. EXCLUDE: Age.16202565
266 Keefe RSE. The longitudinal course of cognitive impairment in schizophrenia: An examination of data from premorbid through posttreatment phases of illness. J Clin Psychiatr. 2014;75(Suppl 2):8–13. doi: http://dx.doi.org/10.4088/JCP.13065su1.02. EXCLUDE: Publication Type.
267 Keinanen J, Mantere O, Kieseppa T, . Early insulin resistance predicts weight gain and waist circumference increase in first-episode psychosis--A one year follow-up study. Schizophr Res. 2015;169(1–3):458–63. PMID: 26589392. EXCLUDE: Age.26589392
268 Kelly AC, Sheitman BB, Hamer RM, . A naturalistic comparison of the long-term metabolic adverse effects of clozapine versus other antipsychotics for patients with psychotic illnesses. J Clin Psychopharmacol. 2014;34(4):441–5. PMID: 24943389. EXCLUDE: Age.24943389
269 Kelly DL, Conley RR, Love RC, . Weight gain in adolescents treated with risperidone and conventional antipsychotics over six months. J Child Adolesc Psychopharmacol. 1998;8(3):151–9. PMID: 9853689. EXCLUDE: Diagnosis.9853689
270 Kelly DL, Love RC, MacKowick M, . Atypical antipsychotic use in a state hospital inpatient adolescent population. J Child Adolesc Psychopharmacol. 2004;14(1):75–85. PMID: 15142394. EXCLUDE: Study Design.15142394
271 Kemp DE, Correll CU, Tohen M, . Associations among obesity, acute weight gain, and response to treatment with olanzapine in adolescent schizophrenia. J Child Adolesc Psychopharmacol. 2013;23(8):522–30. PMID: 24111982. EXCLUDE: Outcomes.24111982
272 Kent JM, Hough D, Singh J, . An open-label extension study of the safety and efficacy of risperidone in children and adolescents with autistic disorder. J Child Adolesc Psychopharmacol. 2013;23(10):676–86. PMID: 24350813. EXCLUDE: Study Design.24350813
273 Kerwin R, Millet B, Herman E, . A multicentre, randomized, naturalistic, open-label study between aripiprazole and standard of care in the management of community-treated schizophrenic patients Schizophrenia Trial of Aripiprazole: (STAR) study. Eur Psychiatry. 2007;22(7):433–43. PMID: 17555947. EXCLUDE: Age.17555947
274 Kessing LV, Hansen HV, Christensen EM, . Do young adults with bipolar disorder benefit from early intervention? J Affect Disord 2014;152–154:403–8. PMID: 24268595. EXCLUDE: Intervention.25618002
275 Ketter TA, Jones M, Paulsson B. Rates of remission/euthymia with quetiapine monotherapy compared with placebo in patients with acute mania. J Affect Disord. 2007;100 Suppl 1:S45–53. PMID: 17383011. EXCLUDE: Age17383011
276 Khamker N. First episode schizophrenia. SAFP. 2015;57(5):29–33. PMID: 2015520958. EXCLUDE: Publication Type.
277 Khanna S, Rosen J, Blevins D, . Psychosis and catatonia after dancing with a dangerous partner. Current Psychiatry. 2015;14(11):58–63. PMID: 20160122672. EXCLUDE: Publication Type.
278 Khodaie-Ardakani MR, Khosravi M, Zarinfard R, . A Placebo-Controlled Study of Raloxifene Added to Risperidone in Men with Chronic Schizophrenia. Acta Med Irani. 2015;53(6):337–45. PMID: 26069170. EXCLUDE: Age.26069170
279 Kilian R, Dietrich S, Toumi M, . Quality of life in persons with schizophrenia in out-patient treatment with first-or second-generation antipsychotics. Acta Psychiatr Scand. 2004;110(2):108–18. PMID: 15233711. EXCLUDE: Age.15233711
280 Kim JH, Kim D, Marder SR. Time to rehospitalization of clozapine versus risperidone in the naturalistic treatment of comorbid alcohol use disorder and schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2008;32(4):984–8. PMID: 18262321. EXCLUDE: Age.18262321
281 King DJ, Link CG, Kowalcyk B. A comparison of bd and tid dose regimens of quetiapine (Seroquel) in the treatment of schizophrenia. Psychopharmacology. 1998;137(2):139–46. PMID: 9630000. EXCLUDE: Age.9630000
282 Kinon BJ, Kane JM, Johns C, . Treatment of neuroleptic-resistant schizophrenic relapse. Psychopharmacol Bull. 1993;29(2):309–14. PMID: 7904762. EXCLUDE: Age.7904762
283 Kinon BJ, Stauffer VL, Kollack-Walker S, . Olanzapine versus aripiprazole for the treatment of agitation in acutely ill patients with schizophrenia. J Clin Psychopharmacol. 2008;28(6):601–7. PMID: 19011427. EXCLUDE: Age.19011427
284 Kinon BJ, Volavka J, Stauffer V, . Standard and higher dose of olanzapine in patients with schizophrenia or schizoaffective disorder: a randomized, double-blind, fixed-dose study. J Clin Psychopharmacol. 2008;28(4):392–400. PMID: 18626265. EXCLUDE: Age.18626265
285 Klein RG. Thioridazine effects on the cognitive performance of children with attention-deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 1990;1(4):1990–1. EXCLUDE: Language.
286 Kluge M, Schuld A, Himmerich H, . Clozapine and olanzapine are associated with food craving and binge eating: results from a randomized double-blind study. J Clin Psychopharmacol. 2007;27(6):662–6. PMID: 18004133. EXCLUDE: Age.18004133
287 Knegtering R, Castelein S, Bous H, . A randomized open-label study of the impact of quetiapine versus risperidone on sexual functioning. J Clin Psychopharmacol. 2004;24(1):56–61. PMID: 14709948. EXCLUDE: Age.14709948
288 Kompoliti K, Stebbins GT, Goetz CG, . Association between antipsychotics and body mass index when treating patients with tics. J Child Adolesc Psychopharmacol. 2010;20(4):277–81. PMID: 20807065. EXCLUDE: Age.20807065
289 Kopala LC, Good KP, Honer WG. Extrapyramidal signs and clinical symptoms in first-episode schizophrenia: response to low-dose risperidone. J Clin Psychopharmacol. 1997;17(4):308–13. PMID: 9241011. EXCLUDE: Age.9241011
290 Kordon A, Wahl K, Koch N, . Quetiapine addition to serotonin reuptake inhibitors in patients with severe obsessive-compulsive disorder: a double-blind, randomized, placebo-controlled study. J Clin Psychopharmacol. 2008;28(5):550–4. PMID: 18794652. EXCLUDE: Age.18794652
291 Kowatch RA, Sethuraman G, Hume JH, . Combination pharmacotherapy in children and adolescents with bipolar disorder. Biol Psychiatry. 2003;53(11):978–84. PMID: 12788243. EXCLUDE: Intervention.12788243
292 Krakowski M, Czobor P, Citrome L. Weight gain, metabolic parameters, and the impact of race in aggressive inpatients randomized to double-blind clozapine, olanzapine or haloperidol. Schizophr Res. 2009;110(1–3):95–102. PMID: 19269139. EXCLUDE: Age.19269139
293 Kraus JE, Sheitman BB, Cook A, . Olanzapine versus risperidone in newly admitted acutely ill psychotic patients. J Clin Psychiatry. 2005;66(12):1564–8. PMID: 16401158. EXCLUDE: Age.16401158
294 Kristensen D, Hageman I, Bauer J, . Antipsychotic polypharmacy in a treatment-refractory schizophrenia population receiving adjunctive treatment with electroconvulsive therapy. J ECT. 2013;29(4):271–6. PMID: 23859980. EXCLUDE: Study Design.23859980
295 Kryzhanovskaya LA, Robertson-Plouch CK, Xu W, . The safety of olanzapine in adolescents with schizophrenia or bipolar I disorder: a pooled analysis of 4 clinical trials.[Erratum appears in J Clin Psychiatry 2009;70(12):1729]. J Clin Psychiatry. 2009;70(2):247–58. DOI: 10.4088/JCP.08m03538 PMID: 19210948. EXCLUDE: Publication Type.19210948
296 Kubik P. New indication: Asenapine for pediatric bipolar. Curr Psychiatr. 2015;14(8):60–1. PMID: NA. EXCLUDE: Publication Type.
297 Kumar SR, Sinha VK, Tikka SK, . Gamma activity model for treatment-resistant bipolar psychotic mania. Indian J Pharmacol. 2015;47(2):215–8. PMID: 25878386. EXCLUDE: Age.25878386
298 Kumari V, Ettinger U, Lee SE, . Common and distinct neural effects of risperidone and olanzapine during procedural learning in schizophrenia: a randomised longitudinal fMRI study. Psychopharmacology. 2015;232(17):3135–47. PMID: 25980483. EXCLUDE: Age.25980483
299 Kumra S, Frazier JA, Jacobsen LK, . Childhood-onset schizophrenia: A double-blind clozapine-haloperidol comparison. Hertzig, Margaret E [Ed]. 1998. EXCLUDE: Publication Type.
300 Kumra S, Jacobsen LK, Rapoport JL. Childhood-Onset Schizophrenia - A Double-Blind Clozapine Trial (DUP). 149th Annual Meeting of the American Psychiatric Association. New York, New York, USA. 4–9th May, 1996. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/348/CN-00657348/frame.html. EXCLUDE: Publication Type.
301 Kuperman S, Calarge C, Kolar A, . An open-label trial of aripiprazole in the treatment of aggression in male adolescents diagnosed with conduct disorder. Ann Clin Psychiatry. 2011;23(4):270–6. PMID: 22073384. EXCLUDE: Study Design.22073384
302 Lage MJ, Hassan MK. The relationship between antipsychotic medication adherence and patient outcomes among individuals diagnosed with bipolar disorder: a retrospective study. Ann Gen Psychiatry. 2009;8:9. PMID: 105380351. EXCLUDE: Age.19419541
303 Lambert M, Conus P, Schimmelmann BG, . Comparison of olanzapine and risperidone in 367 first-episode patients with non-affective or affective psychosis: results of an open retrospective medical record study. Pharmacopsychiatry. 2005;38(5):206–13. PMID: 16189747. EXCLUDE: Age.16189747
304 Lasich A. Attention deficit hyperactivity disorder and co-morbidity: a clinic study. South Afr J Child Adolesc Psychiatry. 1992;4(1):8–12. DOI: http://dx.doi.org/10.1080/16826108.1992.9631475. PMID: N/A EXCLUDE: Publication Type.
305 Lahon K, Shetty HM, Paramel A, . Adverse drug reaction monitoring of antipsychotics, antidepressants and mood stabilizers in the psychiatric outpatient unit of a teaching hospital - A retrospective study. Int J Pharma and Bio Sci. 2012;3(1):P470–P8. PMID: 2014902008. EXCLUDE: Age.
306 Lauriello J, Lambert T, Andersen S, . An 8-week, double-blind, randomized, placebo-controlled study of olanzapine long-acting injection in acutely ill patients with schizophrenia.[Erratum appears in J Clin Psychiatry. 2011 Aug;72(8):1157]. J Clin Psychiatry. 2008;69(5):790–9. PMID: 18452346. EXCLUDE: Age.18452346
307 Lauriello J, McEvoy JP, Rodriguez S, . Long-acting risperidone vs. placebo in the treatment of hospital inpatients with schizophrenia. Schizophr Res 2005 1;72(2–3):249–58. PMID: 15560969. EXCLUDE: Age.15560969
308 Latoo J, Omodunbi O, Hindley D, . Physical health of people with severe mental illness: Don’t just screen... intervene! British Journal of Medical Practitioners 2015;8 (3) (no pagination)(a821) PMID: 2015441730. EXCLUDE: Intervention.
309 LeBlanc JC, Binder CE, Armenteros JL, . Risperidone reduces aggression in boys with a disruptive behaviour disorder and below average intelligence quotient: analysis of two placebo-controlled randomized trials. Int Clin Psychopharmacol. 2005;20(5):275–83. PMID: 16096518. EXCLUDE: Outcomes.16096518
310 Lee BH, Hong JP, Hwang JA, . Alterations in plasma vascular endothelial growth factor levels in patients with schizophrenia before and after treatment. Psychiatr Res. 2015;30;228(1):95–9. PMID: 25977072. EXCLUDE: Age.25977072
311 Lee CS, Williamson LR, Martin SE, . Adverse events in very young children prescribed psychotropic medications: preliminary findings from an acute clinical sample. J Child Adolesc Psychopharmacol. 2015;25(6):509–13. PMID: 26262905. EXCLUDE: Intervention.26262905
312 Lejeune J, Larmo I, Chrzanowski W, . Oral risperidone plus oral lorazepam versus standard care with intramuscular conventional neuroleptics in the initial phase of treating individuals with acute psychosis. Int Clin Psychopharmacol. 2004;19(5):259–69. PMID: 15289699. EXCLUDE: Age.15289699
313 Lepping P, Freudenmann RW. Delusional infestation. Merrick, Joav [Ed]. 2015. EXCLUDE: Publication Type.
314 Levine SZ, Kodesh A, Goldberg Y, . Initial severity and efficacy of risperidone in autism: Results from the RUPP trial. Eur Psychiatr. 2016;32:16–20. PMID: 20160180335. EXCLUDE: outcomes
315 Lewis SW, Barnes TR, Davies L, . Randomized controlled trial of effect of prescription of clozapine versus other second-generation antipsychotic drugs in resistant schizophrenia. Schizophr Bull. 2006;32(4):715–23. PMID: 16540702. EXCLUDE: Age.16540702
316 Lewis SW, Davies L, Jones PB, . Randomised controlled trials of conventional antipsychotic versus new atypical drugs, and new atypical drugs versus clozapine, in people with schizophrenia responding poorly to, or intolerant of, current drug treatment. Health Technol Assess 2006;10(17):iii–iv, ix–xi, 1–165. PMID: 16707074. EXCLUDE: Age.16707074
317 Lieberman JA, Phillips M, Gu H, . Atypical and conventional antipsychotic drugs in treatment-naive first-episode schizophrenia: a 52-week randomized trial of clozapine vs chlorpromazine. Neuropsychopharmacology. 2003;28(5):995–1003. PMID: 12700715. EXCLUDE: Age.12700715
318 Lieberman JA, Tollefson G, Tohen M, . Comparative efficacy and safety of atypical and conventional antipsychotic drugs in first-episode psychosis: a randomized, double-blind trial of olanzapine versus haloperidol. Am J Psychiatry. 2003;160(8):1396–404. PMID: 12900300. EXCLUDE: Age.12900300
319 Liu W, Yu H, Jiang B, . The predictive value of baseline NAA/Cr for treatment response of first-episode schizophrenia: A 1H MRS study. Neurosci Lett. 2015;600:199–205. PMID: 26099422. EXCLUDE: Age.26099422
320 Liu X, Kubilis P, Xu D, . Psychotropic drug utilization in children with concurrent attention-deficit/hyperactivity disorder and anxiety. J Anxiety Disord. 2014;28(6):530–6. PMID: 24981018. EXCLUDE: Study Design.24981018
321 Locascio JJ, Malone RP, Small AM, . Factors related to haloperidol response and dyskinesias in autistic children. Psychopharmacol Bull. 1991;27(2):119–26. PMID: 1924657. EXCLUDE: Language.1924657
322 Long-term treatment with risperidone yields benefits in treating disruptive behavior disorders. Brown University Child & Adolescent Psychopharmacology Update. 2006;8(5):1. PMID: 106343185. EXCLUDE: Publication Type.
323 Loze JY, Pikalov A, Baker R, . Effects of aripiprazole on glucose, lipids and weight in adolescent patients: a pooled analysis of 2 clinical trials. Eur Neuropsychopharmacol 2009:S689–s90. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/749/CN-01008749/frame.html. EXCLUDE: Outcomes.
324 Lyseng-Williamson KA. Paliperidone extended release: a guide to its use in schizophrenia in adolescents aged >15 years. Drugs Ther Perspect. 2014;30(11):380–5. DOI: http://dx.doi.org/10.1007/s40267-014-0157-x. PMID: N/A. EXCLUDE: Publication Type.
325 Macfadden W, Adler CM, Turkoz I, . Adjunctive long-acting risperidone in patients with bipolar disorder who relapse frequently and have active mood symptoms. BMC Psychiatry. 2011;11:171. PMID: 22034906. EXCLUDE: Age.22034906
326 Maldari LA. The treatment of adolescent psychiatric inpatients with atypical neuroleptics: an investigation of cognitive change, functional outcome and satisfaction. Diss Abst Int: Section B: The Sciences and Engineering 2008;69(6-B). EXCLUDE: Study Design.
327 Malla A, Norman R, Scholten D, . A comparison of two novel antipsychotics in first episode non-affective psychosis: one-year outcome on symptoms, motor side effects and cognition. Psychiatry Res. 2004 15;129(2):159–69. PMID: 15590043. EXCLUDE: Age.15590043
328 Mancini C, Van Ameringen M, Patterson B, . Trichotillomania in youth: a retrospective case series. Depress Anxiety. 2009;26(7):661–5. PMID: 19496078. EXCLUDE: Intervention.19496078
329 Mankoski R, Zhao J, Carson WH, . Young mania rating scale line item analysis in pediatric subjects with bipolar I disorder treated with aripiprazole in a short-term, double-blind, randomized study. J Child Adolesc Psychopharmacol. 2011;21(4):359–64. PMID: 21823911. EXCLUDE: Outcomes.21823911
330 Marcus RN, Owen R, Manos G, . Aripiprazole in the treatment of irritability in pediatric patients (aged 6–17 years) with autistic disorder: results from a 52-week, open-label study. J Child Adolesc Psychopharmacol. 2011;21(3):229–36. PMID: 21663425. EXCLUDE: Study Design.21663425
331 Marder SR, Davis JM, Chouinard G. The effects of risperidone on the five dimensions of schizophrenia derived by factor analysis: combined results of the North American trials.[Erratum appears in J Clin Psychiatry. 1998 Apr;59(4):200]. J Clin Psychiatry. 1997;58(12):538–46. PMID: 9448657. EXCLUDE: Age.9448657
332 Marder SR, Glynn SM, Wirshing WC, . Maintenance treatment of schizophrenia with risperidone or haloperidol: 2-year outcomes. Am J Psychiatry. 2003;160(8):1405–12. PMID: 12900301. EXCLUDE: Age.12900301
333 Marder SR, Meibach RC. Risperidone in the treatment of schizophrenia. Am J Psychiatry. 1994;151(6):825–35. PMID: 7514366. EXCLUDE: Age.7514366
334 Margari L, Matera E, Craig F, . Tolerability and safety profile of risperidone in a sample of children and adolescents. Int Clin Psychopharmacol. 2013;28(4):177–83. PMID: 23689836. EXCLUDE: Study Design.23689836
335 Margari L, Matera E, Petruzzelli MG, . Prolactin variations during risperidone therapy in a sample of drug-naive children and adolescents. Int Clin Psychopharmacol. 2015;30(2):103–8. PMID: 25514607. EXCLUDE: Intervention.25514607
336 Marsanic VB, Dodig-Curkovic K, Juretic Z. Outpatient treatment of children and adolescents with antipsychotic drugs in Croatia. Nord J Psychiatry. 2012;66(1):2–7. PMID: 21306199. EXCLUDE: Study Design.21306199
337 Martin Otano L, Barbadillo Izquierdo L, Galdeano Mondragon A, . After six months of anti-psychotic treatment: Is the improvement in mental health at the expense of physical health? Rev Psiquiatr Salud Ment. 2013;6(1):26–32. PMID: 23084806. EXCLUDE: Age.23084806
338 Masi G, Millepiedi S, Perugi G, . Pharmacotherapy in paediatric obsessive-compulsive disorder: a naturalistic, retrospective study. CNS Drugs. 2009;23(3):241–52. PMID: 19320532. EXCLUDE: Intervention.19320532
339 Masi G, Milone A, Canepa G, . Olanzapine treatment in adolescents with severe conduct disorder. Eur Psychiatry. 2006;21(1):51–7. PMID: 16487906. EXCLUDE: Study Design.16487906
340 Masi G, Milone A, Manfredi A, . Combined pharmacotherapy-multimodal psychotherapy in children with Disruptive Behavior Disorders. Psychiatr Res. 2016;238:8–13. doi: PMID: 20160222674. EXCLUDE: Intervention.
341 Matsunaga H, Nagata T, Hayashida K, . A long-term trial of the effectiveness and safety of atypical antipsychotic agents in augmenting SSRI-refractory obsessive-compulsive disorder. J Clin Psychiatry. 2009;70(6):863–8. PMID: 19422759. EXCLUDE: Age.19422759
342 Matsuura Y, Fujino H, Hashimoto R, . Standing postural instability in patients with schizophrenia: Relationships with psychiatric symptoms, anxiety, and the use of neuroleptic medications. Gait Posture. 2015;41(3):847–51. PMID: 25813604. EXCLUDE: Age.25813604
343 Martsenkovsky I, Martsenkovska I, Martsenkovskyi D. Risperidon and atomoxetine in the treatment of several and challending behaviors in children with PDD. Eur Psychiatr; 2015. p. 195. EXCLUDE: Intervention.
344 McDougle CJ, Goodman WK, Leckman JF, . Haloperidol addition in fluvoxamine-refractory obsessive-compulsive disorder. A double-blind, placebo-controlled study in patients with and without tics. Arch Gen Psychiatry. 1994;51(4):302–8. PMID: 8161290. EXCLUDE: Age.8161290
345 McEvoy JP, Hogarty GE, Steingard S. Optimal dose of neuroleptic in acute schizophrenia. A controlled study of the neuroleptic threshold and higher haloperidol dose. Arch Gen Psychiatry. 1991;48(8):739–45. PMID: 1883257. EXCLUDE: Age.1883257
346 McEvoy JP, Johnson J, Perkins D, . Insight in first-episode psychosis. Psychol Med. 2006;36(10):1385–93. PMID: 16740175. EXCLUDE: Age.16740175
347 McEvoy JP, Lieberman JA, Perkins DO, . Efficacy and tolerability of olanzapine, quetiapine, and risperidone in the treatment of early psychosis: a randomized, double-blind 52-week comparison. Am J Psychiatry. 2007;164(7):1050–60. PMID: 17606657. EXCLUDE: Age.17606657
348 McIntyre RS, Cohen M, Zhao J, . Asenapine versus olanzapine in acute mania: a double-blind extension study.[Erratum appears in Bipolar Disord. 2010 Feb;12(1):112]. Bipolar Disord. 2009;11(8):815–26. PMID: 19832806. EXCLUDE: Age.19832806
349 McIntyre RS, Cohen M, Zhao J, . A 3-week, randomized, placebo-controlled trial of asenapine in the treatment of acute mania in bipolar mania and mixed states.[Erratum appears in Bipolar Disord. 2010 May;12(3):350]. Bipolar Disord. 2009;11(7):673–86. PMID: 19839993. EXCLUDE: Age.19839993
350 McIntyre RS, Mancini DA, Srinivasan J, . The antidepressant effects of risperidone and olanzapine in bipolar disorder. Can J Clin Pharmacol. 2004;11(2):e218–26. PMID: 15520475. EXCLUDE: Age.15520475
351 Meltzer HY, Alphs L, Green AI, . Clozapine treatment for suicidality in schizophrenia: International Suicide Prevention Trial (InterSePT).[Erratum appears in Arch Gen Psychiatry. 2003;60(7):735]. Arch Gen Psychiatry. 2003;60(1):82–91. PMID: 12511175. EXCLUDE: Age.12511175
352 Meltzer HY, Bobo WV, Roy A, . A randomized, double-blind comparison of clozapine and high-dose olanzapine in treatment-resistant patients with schizophrenia. J Clin Psychiatry. 2008;69(2):274–85. PMID: 18232726. EXCLUDE: Age.18232726
353 Menard ML, Thummler S, Auby P, . Preliminary and ongoing French multicenter prospective naturalistic study of adverse events of antipsychotic treatment in naive children and adolescents. Child & Adolescent Psychiatry & Mental Health. [Electronic Resource]. 2014;8:18. PMID: 24991232. EXCLUDE: Study Design.24991232
354 Menard ML, Thummler S, Giannitelli M, . Incidence of adverse events in antipsychotic-naive children and adolescents treated with antipsychotic drugs: a French multicentre naturalistic study protocol (ETAPE). BMJ Open. 2016;6(4):e011020. PMID: 27053275. EXCLUDE: Publication Type.27053275
355 Merchan-Naranjo J, Tapia C, Bailon C, . Secondary effects of antipsychotic treatment in naive or quasi-naive children and adolescents: design of a follow-up protocol and baseline results. Rev Psiquiatr Salud Ment. 2012;5(4):217–28. PMID: 23021294. EXCLUDE: Publication Type.23021294
356 Meyer N, Gee S, Whiskey E, . Optimizing outcomes in clozapine rechallenge following neutropenia: a cohort analysis. J Clin Psychiatr. 2015;76(11):e1410–6. PMID: 26646037. EXCLUDE: Age.26646037
357 Mick E, Biederman J. Risperidone for the treatment of ADHD in children with bipolar disorder. 158th Annual Meeting of the American Psychiatric Association; 2005 May 21–26; Atlanta, GA. 2005 http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/774/CN-00592774/frame.html. EXCLUDE: Study Design.
358 Midbari Y, Ebert T, Kosov I, . Hematological and cardiometabolic safety of clozapine in the treatment of very early onset schizophrenia: a retrospective chart review. J Child Adolesc Psychopharmacol. 2013;23(8):516–21. PMID: 24111981. EXCLUDE: Intervention.24111981
359 Miller DD, Caroff SN, Davis SM, . Extrapyramidal side-effects of antipsychotics in a randomised trial. Br J Psychiatry. 2008;193(4):279–88. PMID: 18827289. EXCLUDE: Age.18827289
360 Moeller KE, Shireman TI, Liskow BI. Relapse rates in patients with schizophrenia receiving aripiprazole in comparison with other atypical antipsychotics. J Clin Psychiatry. 2006;67(12):1942–7. PMID: 17194273. EXCLUDE: Age.17194273
361 Moilanen J, Haapea M, Miettunen J, . Characteristics of subjects with schizophrenia spectrum disorder with and without antipsychotic medication - A 10-year follow-up of the Northern Finland 1966 Birth Cohort study. Eur Psychiatry. 2013;28(1):53–8. PMID: 21920710. EXCLUDE: Publication Type.21920710
362 Mojtabai R, Lavelle J, Gibson PJ, . Atypical antipsychotics in first admission schizophrenia: medication continuation and outcomes. Schizophr Bull. 2003;29(3):519–30. PMID: 14609245. EXCLUDE: Age.14609245
363 Moller HJ, Johnson S, Mateva T, . Evaluation of the feasibility of switching from immediate release quetiapine to extended release quetiapine fumarate in stable outpatients with schizophrenia. Int Clin Psychopharmacol. 2008;23(2):95–105. PMID: 18301124. EXCLUDE: Age.18301124
364 Moller HJ, Riedel M, Jager M, . Short-term treatment with risperidone or haloperidol in first-episode schizophrenia: 8-week results of a randomized controlled trial within the German Research Network on Schizophrenia. Int J Neuropsychopharmacol. 2008;11(7):985–97. PMID: 18466670. EXCLUDE: Age.18466670
365 Moon KT. Bipolar disorder I in children: Which treatment works best? Am Fam Physician. 2012;86(9):848–53. PMID: N/A. EXCLUDE: Publication Type.
366 Moosavi SM, Ahmadi M, Mojtahedi D, . Comparison of Quetiapine and Risperidone in Treatment of Acute Psychosis: A Double-Blind, Randomized-Controlled Study. Glob J Health Sci. 2015;7(5):359–63. PMID: 26156901. EXCLUDE: Age.26156901
367 Moreno C, Merchan-Naranjo J, Alvarez M, . Metabolic effects of second-generation antipsychotics in bipolar youth: comparison with other psychotic and nonpsychotic diagnoses. Bipolar Disord. 2010;12(2):172–84. PMID: 20402710. EXCLUDE: Intervention.20402710
368 Morrato EH, Parks J, Campagna EJ, . Comparative effectiveness of injectable paliperidone palmitate versus oral atypical antipsychotics: early postmarketing evidence. J Comp Eff Res. 2015;4(2):89–99. PMID: 25251693. EXCLUDE: Age.25251693
369 Mullen J, Jibson MD, Sweitzer D. A comparison of the relative safety, efficacy, and tolerability of quetiapine and risperidone in outpatients with schizophrenia and other psychotic disorders: the quetiapine experience with safety and tolerability (QUEST) study. Clin Ther. 2001;23(11):1839–54. PMID: 11768836. EXCLUDE: Age.11768836
370 Mullins CD, Obeidat NA, Cuffel BJ, . Risk of discontinuation of atypical antipsychotic agents in the treatment of schizophrenia. Schizophr Res. 2008;98(1–3):8–15. PMID: 17596914. EXCLUDE: Age.17596914
371 Murphy AL, Gardner DM, Kisely S, . A qualitative study of antipsychotic medication experiences of youth. J Can Acad Child Adolesc Psychiatry. 2015;24(1):61–9. PMID: 26336383. EXCLUDE: Study Design.26336383
372 Mutlu C, Sukran Uneri O, Tanidir C, . Agresif ve yikici davranissal belirtileri olan okul oncesi cocuklarda risperidon kullanimi [Risperidone use in preschool children with aggressive and destructive behavioral symptoms]. Anadolu Psikiyatri Dergisi. 2015;16(3):212–9. DOI: 10.5455/apd.167083. PMID: N/A. EXCLUDE: Language.
373 Naber D, Riedel M, Klimke A, . Randomized double blind comparison of olanzapine vs. clozapine on subjective well-being and clinical outcome in patients with schizophrenia. Acta Psychiatr Scand. 2005;111(2):106–15. PMID: 15667429. EXCLUDE: Age.15667429
374 Naguy A, At-Tajali A. Ziprasidone monotherapy for Tourette syndrome with comorbid ADHD. Afr J Psychiatry (South Africa). 2015;18(SpecialIssue):1–2. PMID: 2015508318. EXCLUDE: Publication Type.
375 Nahshoni E, Spitzer S, Berant M, . QT interval and dispersion in very young children treated with antipsychotic drugs: a retrospective chart review. J Child Adolesc Psychopharmacol. 2007;17(2):187–94. PMID: 17489713. EXCLUDE: Intervention.17489713
376 Nair NP. Therapeutic equivalence of risperidone given once daily and twice daily in patients with schizophrenia. The Risperidone Study Group. J Clin Psychopharmacol. 1998;18(2):103–10. PMID: 9555595. EXCLUDE: Age.9555595
377 Nakamura M, Ogasa M, Guarino J, . Lurasidone in the treatment of acute schizophrenia: a double-blind, placebo-controlled trial. J Clin Psychiatry. 2009;70(6):829–36. PMID: 19497249. EXCLUDE: Age.19497249
378 Newcomer JW, Campos JA, Marcus RN, . A multicenter, randomized, double-blind study of the effects of aripiprazole in overweight subjects with schizophrenia or schizoaffective disorder switched from olanzapine. J Clin Psychiatry. 2008;69(7):1046–56. PMID: 18605811. EXCLUDE: Age.18605811
379 Newcomer JW, Ratner RE, Eriksson JW, . A 24-week, multicenter, open-label, randomized study to compare changes in glucose metabolism in patients with schizophrenia receiving treatment with olanzapine, quetiapine, or risperidone. J Clin Psychiatry. 2009;70(4):487–99. DOI: PMID: 19358783. EXCLUDE: Age.19358783
380 Ngai YF, Sabatini P, Nguyen D, . Quetiapine treatment in youth is associated with decreased insulin secretion. J Clin Psychopharmacol. 2014;34(3):359–64. PMID: 24633003. EXCLUDE: Study Design.24633003
381 Nielsen RE, Laursen MF, Lammers Vernal D, . Risk of diabetes in children and adolescents exposed to antipsychotics: A nationwide 12-year case-control study. J Am Acad Child Adoles Psychiatry. 2014;53(9):971–9.e6. PMID: 25151420. EXCLUDE: Intervention.25151420
382 Norris ML, Spettigue W, Buchholz A, . Factors influencing research drug trials in adolescents with anorexia nervosa. Brunner-Mazel Eating Disorders Monograph Series. 2010;18(3):210–7. PMID: 20419525. EXCLUDE: Study Design.20419525
383 Noto C, Ota VK, Gouvea ES, . Effects of risperidone on cytokine profile in drug-naive first-episode psychosis. Int J Neuropsychopharmacol 2015;18 (4) PMID: 25522386. EXCLUDE: Age.25522386
384 Nuechterlein KH, Green MF, Calkins ME, . Attention/vigilance in schizophrenia: performance results from a large multi-site study of the Consortium on the Genetics of Schizophrenia (COGS). Schizophr Res. 2015;163(1–3):38–46. PMID: 25749017. EXCLUDE: Age25749017
385 Nussbaum L, Gradinaru R, Andreescu N, . The response to atypical antipsychotic drugs in correlation with the cyp2d6 genotype: clinical implications and perspectives. Farmacia. 2014;62(6):1191–201. PMID: N/A. EXCLUDE: Intervention.
386 Okazaki M, Adachi N, Akanuma N, . Do antipsychotic drugs increase seizure frequency in epilepsy patients? Eur Neuropsychopharmacol. 2014;24(11):1738–44. PMID: 25453222. EXCLUDE: Age.25453222
387 Ono S, Suzuki Y, Fukui N, . GIPR Gene Polymorphism and Weight Gain in Patients With Schizophrenia Treated With Olanzapine. J Neuropsychiatr Clin Neuroscie. 2015;27(2):162–4. PMID: 25321336. EXCLUDE: Age.25321336
388 Oosthuizen P, Emsley R, Jadri Turner H, . A randomized, controlled comparison of the efficacy and tolerability of low and high doses of haloperidol in the treatment of first-episode psychosis. Int J Neuropsychopharmacol. 2004;7(2):125–31. PMID: 15003147. EXCLUDE: Age.15003147
389 Opjordsmoen S, Melle I, Friis S, . Stability of medication in early psychosis: a comparison between second-generation and low-dose first-generation antipsychotics. Early Int Psychiatry. 2009;3(1):58–65. PMID: 21352176. EXCLUDE: Age.21352176
390 Padala PR, Madison J, Monnahan M, . Risperidone monotherapy for post-traumatic stress disorder related to sexual assault and domestic abuse in women. Int Clin Psychopharmacol. 2006;21(5):275–80. PMID: 16877898. EXCLUDE: Age.16877898
391 Pae CU, Kim JJ, Lee CU, . Rapid versus conventional initiation of quetiapine in the treatment of schizophrenia: a randomized, parallel-group trial. J Clin Psychiatry. 2007;68(3):399–405. PMID: 17388709. EXCLUDE: Age.17388709
392 Pae CU, Nassir Ghaemi S, Kim TS, . Rapid titration versus conventional titration of quetiapine in the treatment of bipolar mania: a preliminary trial. Int Clin Psychopharmacol. 2005;20(6):327–30. PMID: 16192842. EXCLUDE: Age.16192842
393 Pae CU, Nassir Ghaemi S, Patkar A, . Adjunctive risperidone, olanzapine and quetiapine for the treatment of hospitalized patients with bipolar I disorder: a retrospective study. Prog Neuropsychopharmacol Biol Psychiatry. 2006;30(7):1322–5. PMID: 16631294. EXCLUDE: Age.16631294
394 Pae CU, Serretti A, Chiesa A, . Immediate versus gradual suspension of previous treatments during switch to aripiprazole: results of a randomized, open label study. Eur Neuropsychopharmacol. 2009;19(8):562–70. PMID: 19442491. EXCLUDE: Age.19442491
395 Paixao MJ. Atypical antipsychotics for disruptive behavior disorders in children and youths. Am J Nurs. 2013;113(6):60. PMID: 23702768. EXCLUDE: Publication Type.23702768
396 Pan PY, Lee MS, Yeh CB. The efficacy and safety of once-daily quetiapine extended release in patients with schizophrenia switched from other antipsychotics: an open-label study in Chinese population. BMC Psychiatry. 2015;15:1. PMID: 25609320. EXCLUDE: Age.25609320
397 Pandina GJ, Revicki DA, Kleinman L, . Psychometric evaluation of a patient-rated troubling symptom scale for generalized anxiety disorder clinical trials. Psychopharmacol Bull. 2008;41(3):68–90. PMID: 18779777. EXCLUDE: Age.18779777
398 Patel JK, Buckley PF, Woolson S, . Metabolic profiles of second-generation antipsychotics in early psychosis: findings from the CAFE study. Schizophr Res. 2009;111(1–3):9–16 PMID: 19398192. EXCLUDE: Age.19398192
399 Patel NC, DelBello MP, Keck PE, Jr., . Ethnic differences in maintenance antipsychotic prescription among adolescents with bipolar disorder. J Child Adolesc Psychopharmacol. 2005;15(6):938–46. PMID: 16379514. EXCLUDE: Intervention.16379514
400 Patel NC, Dorson PG, Edwards N, . One-year rehospitalization rates of patients discharged on atypical versus conventional antipsychotics. Psychiatric Serv. 2002;53(7):891–3. PMID: 12096177. EXCLUDE: Age.12096177
401 Patel NC, Kistler JS, James EB, . A retrospective analysis of the short-term effects of olanzapine and quetiapine on weight and body mass index in children and adolescents. Pharmacotherapy. 2004;24(7 I):824–30. PMID: 15303445. EXCLUDE: Diagnosis.15303445
402 Patkar AA, Peindl K, Mago R, . An open-label, rater-blinded, augmentation study of aripiprazole in treatment-resistant depression. Prim Care Companion J Clin Psychiatry. 2006;8(2):82–7. PMID: 16862232. EXCLUDE: Age.16862232
403 Pavuluri MN, Henry DB, Carbray JA, . A one-year open-label trial of risperidone augmentation in lithium nonresponder youth with preschool-onset bipolar disorder. J Child Adolesc Psychopharmacol. 2006;16(3):336–50. PMID: 16768641. EXCLUDE: Study Design.16768641
404 Perez-Iglesias R, Crespo-Facorro B, Amado JA, . A 12-week randomized clinical trial to evaluate metabolic changes in drug-naive, first-episode psychosis patients treated with haloperidol, olanzapine, or risperidone. J Clin Psychiatry. 2007;68(11):1733–40. PMID: 18052567. EXCLUDE: Age.18052567
405 Perez-Iglesias R, Crespo-Facorro B, Martinez-Garcia O, . Weight gain induced by haloperidol, risperidone and olanzapine after 1 year: findings of a randomized clinical trial in a drug-naive population. Schizophr Res. 2008;99(1–3):13–22. PMID: 18053689. EXCLUDE: Age.18053689
406 Perez-Iglesias R, Mata I, Pelayo-Teran JM, . Glucose and lipid disturbances after 1 year of antipsychotic treatment in a drug-naive population. Schizophr Res. 2009;107(2–3):115–21. PMID: 18993033. EXCLUDE: Age.18993033
407 Perez-Iglesias R, Vazquez-Barquero JL, Amado JA, . Effect of antipsychotics on peptides involved in energy balance in drug-naive psychotic patients after 1 year of treatment. J Clin Psychopharmacol. 2008;28(3):289–95. PMID: 18480685. EXCLUDE: Age.18480685
408 Perry CM. Paliperidone extended release: in adolescents with schizophrenia. Paediatr Drugs. 2012;14(6):417–27. PMID: 23050744. EXCLUDE: Publication Type.23050744
409 Perry R, Pataki C, Munoz-Silva DM, . Risperidone in children and adolescents with pervasive developmental disorder: pilot trial and follow-up. J Child Adolesc Psychopharmacol. 1997;7(3):167–79. PMID: 9466234. EXCLUDE: Publication Type.9466234
410 Peuskens J, Van Baelen B, De Smedt C, . Effects of risperidone on affective symptoms in patients with schizophrenia. Int Clin Psychopharmacol. 2000;15(6):343–9. PMID: 11110010. EXCLUDE: Age.11110010
411 Phillips LJ, Nelson B, Yuen HP, . Randomized controlled trial of interventions for young people at ultra-high risk of psychosis: study design and baseline characteristics. Aust NZ J Psychiatry. 2009;43(9):818–29. PMID: 19670055. EXCLUDE: Publication Type.19670055
412 Pijnenborg GH, Timmerman ME, Derks EM, . Differential effects of antipsychotic drugs on insight in first episode schizophrenia: Data from the European First-Episode Schizophrenia Trial (EUFEST). Eur Neuropsychopharmacol. 2015;25(6):808–16. PMID: 25907250. EXCLUDE: Age.25907250
413 Pisano S, Catone G, Pascotto A, . Second generation antipsychotics in adolescent anorexia nervosa: a new hypothesis of eligibility criteria. J Child Adolesc Psychopharmacol. 2014;24(5):293–5. PMID: 24827862 EXCLUDE: Study Design.24827862
414 Piscitelli SC, Frazier JA, McKenna K, . Plasma clozapine and haloperidol concentrations in adolescents with childhood-onset schizophrenia: association with response. J Clin Psychiatry. 1994;55 Suppl B:94–7. PMID: 7961584. EXCLUDE: Outcomes.7961584
415 Podobnik J, Foller Podobnik I, Grgic N, . The effect of add-on treatment with quetiapine on measures of depression, aggression, irritability and suicidal tendencies in children and adolescents. Psychopharmacology. 2012;220(3):639–41. PMID: 22173852. EXCLUDE: Diagnosis.22173852
416 Pogge DL, Young K, Insalaco B, . Use of atypical antipsychotic medications in adolescent psychiatric inpatients: a comparison with inpatients who did not receive antipsychotic medications during their stay. Int J Clin Pract. 2007;61(6):896–902. PMID: 17504351. EXCLUDE: Study Design.17504351
417 Post RM, Leverich GS, Kupka R, . Clinical correlates of sustained response to individual drugs used in naturalistic treatment of patients with bipolar disorder. Compr Psychiatry. 2016;66:146–56. PMID: 20160224122. EXCLUDE: Age.26995248
418 Post RM. Treatment of Bipolar Depression: Evolving Recommendations. Psychiatr Clin North Am. 2016;39(1):11–33. PMID: 20160123691. EXCLUDE: Publication Type.26876316
419 Potkin SG, Gharabawi GM, Greenspan AJ, . A double-blind comparison of risperidone, quetiapine and placebo in patients with schizophrenia experiencing an acute exacerbation requiring hospitalization. Schizophr Res. 2006;85(1–3):254–65. PMID: 16797162. EXCLUDE: Age.16797162
420 Potkin SG, Thyrum PT, Alva G, . The safety and pharmacokinetics of quetiapine when coadministered with haloperidol, risperidone, or thioridazine. J Clin Psychopharmacol. 2002;22(2):121–30. PMID: 11910256. EXCLUDE: Age.11910256
421 Potkin SG, Weiden PJ, Loebel AD, . Remission in schizophrenia: 196-week, double-blind treatment with ziprasidone vs. haloperidol. Int J Neuropsychopharmacol. 2009;12(9):1233–48. PMID: 19419595. EXCLUDE: Age.19419595
422 Potvin S, Aubin G, Stip E. Antipsychotic-induced parkinsonism is associated with working memory deficits in schizophrenia-spectrum disorders Eur Arch Psychiatry Clin Neurosci. 2015;265(2):147–54. PMID: 24925606. EXCLUDE: Age.24925606
423 Pozzi M, Cattaneo D, Baldelli S, . Therapeutic drug monitoring of second-generation antipsychotics in pediatric patients: An observational study in real-life settings. Eur J Clin Pharmacol. 2016;72(3):285–93. doi: PMID: 2015552239. EXCLUDE: outcomes26613956
424 Preskorn SH. Prediction of individual response to antidepressants and antipsychotics: an integrated concept. Dialogues Clin Neurosci. 2014;16(4):545–54. PMID: 25733958. EXCLUDE: Publication Type.25733958
425 Preval H, Klotz SG, Southard R, . Rapid-acting IM ziprasidone in a psychiatric emergency service: a naturalistic study. Gen Hosp Psychiatry. 2005;27(2):140–4. PMID: 15763126. EXCLUDE: Age.15763126
426 Pribylova L, Kolek M, Vesela S, . De novo cost-utility analysis of oral paliperidone in the treatment of schizoaffective disorder. J Psychiatr Res. 2015;70:33–7. PMID: 2015432861. EXCLUDE: Age.26424421
427 Pringsheim T, Pearce M. Complications of antipsychotic therapy in children with tourette syndrome. Pediatr Neurol. 2010;43(1):17–20. DOI: http://dx.doi.org/10.1016/j.pediatrneurol.2010.02.01. EXCLUDE: Study Design.20682197
428 Purdon SE, Woodward N, Lindborg SR, . Procedural learning in schizophrenia after 6 months of double-blind treatment with olanzapine, risperidone, and haloperidol. Psychopharmacology. 2003;169(3–4):390–7. PMID: 12827347. EXCLUDE: Age.12827347
429 Questions remain about use of newer antipsychotics in pediatric population. Brown University Psychopharmacology Update. 2009;20(1):1–7. PMID: 105598357. EXCLUDE: Publication Type.
430 Quetiapine equal to placebo for teen bipolar depression. Brown University Child & Adolescent Psychopharmacology Update. 2009;11(9):4–5. PMID: 105418595. EXCLUDE: Publication Type.
431 Quetiapine versus risperidone in first-onset adolescent psychosis. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(2):5–6. PMID: 105306061. EXCLUDE: Outcomes.
432 Quetiapine vs. risperidone in psychosis. Brown University Child & Adolescent Psychopharmacology Update. 2009;11(12):4–5. PMID: 105259630. EXCLUDE: Outcomes.
433 Quintana H, Wilson MS, 2nd, Purnell W, . An open-label study of olanzapine in children and adolescents with schizophrenia. J Psychiatr Pract. 2007;13(2):86–96. PMID: 17414684. EXCLUDE: Study Design.17414684
434 Rabinowitz J, Harvey PD, Eerdekens M, . Premorbid functioning and treatment response in recent-onset schizophrenia. Br J Psychiatry. 2006;189:31–5. PMID: 16816303. EXCLUDE: Age.16816303
435 Rabinowitz J, Werbeloff N, Caers I, . Determinants of antipsychotic response in schizophrenia: implications for practice and future clinical trials. J Clin Psychiatry. 2014;75(4):e308–16. PMID: 24813414. EXCLUDE: Age.24813414
436 Rahman A, Mican LM, Fischer C, . Evaluating the incidence of leukopenia and neutropenia with valproate, quetiapine, or the combination in children and adolescents. Ann Pharmacother. 2009;43(5):822–30. PMID: 19401471. EXCLUDE: Diagnosis.19401471
437 Rani FA, Byrne P, Cranswick N, . Mortality in children and adolescents prescribed antipsychotic medication: a retrospective cohort study using the UK general practice research database. Drug Saf. 2011;34(9):773–81. PMID: 21830839. EXCLUDE: Study Design.21830839
438 Rani FA, Byrne PJ, Murray ML, . Paediatric Atypical Antipsychotic Monitoring Safety (PAMS) study: pilot study in children and adolescents in secondary- and tertiary-care settings. Drug Saf. 2009;32(4):325–33. PMID: 19388723. EXCLUDE: Diagnosis.19388723
439 Rapoport J, Kumra S, Jacobsen LK. The spectrum of extrapyramidal symptoms in children and young adults conference abstract. 150th Annual Meeting of the American Psychiatric Association. San Diego, California, USA. 17–22 May, 1997. 1997 http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/867/CN-00283867/frame.html. EXCLUDE: Publication Type.
440 Ravindran A, Silverstone P, Lacroix D, . Risperidone does not affect steady-state pharmacokinetics of divalproex sodium in patients with bipolar disorder. Clin Pharmacokinet. 2004;43(11):733–40. PMID: 15301577. EXCLUDE: Age.15301577
441 Reed E, Vance A, Luk E, . Single and combined psychotropic medication use in a child and adolescent mental health service. Aust NZ J Psychiatry. 2004;38(4):204–11.. PMID: 15038798. EXCLUDE: Intervention.15038798
442 Reich DB, Winternitz S, Hennen J, . A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. J Clin Psychiatry. 2004;65(12):1601–6. PMID: 15641864. EXCLUDE: Age.15641864
443 Remschmidt H, Schulz E, Martin PDM. An open trial of clozapine in thirty-six adolescents with schizophrenia. J Child Adolesc Psychopharmacol. 1994;4(1):31–41. PMID: 1994156335. EXCLUDE: Publication Type.
444 Ren XS, Qian S, Lee AF, . Treatment persistence: a comparison among patients with schizophrenia who were initiated on atypical antipsychotic agents. J Clin Pharmacy Ther. 2006;31(1):57–65. PMID: 16476121. EXCLUDE: Age.16476121
445 Reyes M, Croonenberghs J, Augustyns I, . Long-term use of risperidone in children with disruptive behavior disorders and subaverage intelligence: efficacy, safety, and tolerability. J Child Adolesc Psychopharmacol. 2006;16(3):260–72. PMID: 16768634. EXCLUDE: Study Design.16768634
446 Reyes M, Olah R, Csaba K, . Long-term safety and efficacy of risperidone in children with disruptive behaviour disorders. Results of a 2-year extension study. Eur Child Adolesc Psychiatry. 2006;15(2):97–104. PMID: 16523250. EXCLUDE: Study Design.16523250
447 Riedel M, Muller N, Spellmann I, . Efficacy of olanzapine versus quetiapine on cognitive dysfunctions in patients with an acute episode of schizophrenia. Eur Arch Psychiatry Clin Neurosci. 2007;257(7):402–12. PMID: 17629725. EXCLUDE: Age.17629725
448 Ritchie B, Norris ML. QTc prolongation associated with atypical antipsychotic use in the treatment of adolescent-onset anorexia nervosa. J Can Acad Child Adolesc Psychiatry. 2009;18(1):60–3. PMID: 19270852. EXCLUDE: Study Design.19270852
449 Ritsner MS, Gibel A. The effectiveness and predictors of response to antipsychotic agents to treat impaired quality of life in schizophrenia: a 12-month naturalistic follow-up study with implications for confounding factors, antidepressants, anxiolytics, and mood stabilizers. Prog Neuropsychopharmacol Biol Psychiatry. 2006;30(8):1442–52. PMID: 16842897. EXCLUDE: Age.16842897
450 Robertson MM, Scull DA, Eapen V, . Risperidone in the treatment of Tourette syndrome: a retrospective case note study. J Psychopharmacol. 1996;10(4):317–20. PMID: 22302981. EXCLUDE: Study Design.22302981
451 Robinson DG, Gallego JA, John M, . A Randomized Comparison of Aripiprazole and Risperidone for the Acute Treatment of First-Episode Schizophrenia and Related Disorders: 3-Month Outcomes. Schizophr Bull. 2015;41(6):1227–36. PMID: 2015496122. EXCLUDE: Age.26338693
452 Robles O, Zabala A, Bombin I, . Cognitive efficacy of quetiapine and olanzapine in early-onset first-episode psychosis. Schizophr Bull. 2011;37(2):405–15. PMID: 19706697. EXCLUDE: Duplicate.19706697
453 Rojo LE, Gaspar PA, Silva H, . Metabolic syndrome and obesity among users of second generation antipsychotics: A global challenge for modern psychopharmacology. Pharmacol Res. 2015;101:74–85. PMID: 2015322038. EXCLUDE: Publication Type.26218604
454 Roke Y, Buitelaar JK, Boot AM, . Risk of hyperprolactinemia and sexual side effects in males 10–20 years old diagnosed with autism spectrum disorders or disruptive behavior disorder and treated with risperidone. J Child Adolesc Psychopharmacol. 2012;22(6):432–9. PMID: 23234586. EXCLUDE: Study Design.23234586
455 Roke Y, van Harten PN, Buitelaar JK, . Antipsychotic-induced hyperprolactinemia and testosterone levels in boys. Horm Res Pediatr. 2012;77(4):235–40. PMID: 22538969. EXCLUDE: Study Design.22538969
456 Roke Y, van Harten PN, Buitelaar JK, . Bone mineral density in male adolescents with autism spectrum disorders and disruptive behavior disorder with or without antipsychotic treatment. Eur J Endocrinol. 2012;167(6):855–63. PMID: 23011870. EXCLUDE: Study Design.23011870
457 Rothbaum BO, Killeen TK, Davidson JR, . Placebo-controlled trial of risperidone augmentation for selective serotonin reuptake inhibitor-resistant civilian posttraumatic stress disorder. J Clin Psychiatry. 2008;69(4):520–5. PMID: 18278987. EXCLUDE: Age.18278987
458 Ruan L, Hu S, Huang M, . Efficacy and safety of long-acting risperidone on early onset schizophrenia in adolescent patients. Afr J Pharmacy Pharmacol. 2010;4(5):184–92. PMID: N/A EXCLUDE: Study Design.
459 Rybakowski JK, Vansteelandt K, Remlinger-Molenda A, . Extrapyramidal symptoms during treatment of first schizophrenia episode: results from EUFEST. Eur Neuropsychopharmacol. 2014;24(9):1500–5. PMID: 25085534. EXCLUDE: Age.25085534
460 Sacchetti E, Galluzzo A, Valsecchi P, . Ziprasidone vs clozapine in schizophrenia patients refractory to multiple antipsychotic treatments: the MOZART study. Schizophr Res. 2009;110(1–3):80–9. PMID: 19269791. EXCLUDE: Age.19269791
461 Sacchetti E, Galluzzo A, Valsecchi P, . Ziprasidone vs clozapine in schizophrenia patients refractory to multiple antipsychotic treatments: the MOZART study.[Erratum appears in Schizophr Res. 2010 Aug;121(1–3)281 Note: multiple investigator names added]. Schizophr Res. 2009;113(1):112–21. PMID: 19606529. EXCLUDE: Age.19606529
462 Sachs GS, Grossman F, Ghaemi SN, . Combination of a mood stabilizer with risperidone or haloperidol for treatment of acute mania: a double-blind, placebo-controlled comparison of efficacy and safety. Am J Psychiatry. 2002;159(7):1146–54. PMID: 12091192. EXCLUDE: Age.12091192
463 Safa M, Sadr S, Delfan B, . Metabolic effects of olanzapine and risperidone in patients with psychotic disorders. Int J Psychiatry Clin Pract. 2008;12(4):299–302. PMID: 24937718. EXCLUDE: Age.24937718
464 Safety concerns prompt changes to study of drugs for early-onset schizophrenia. Brown University Child & Adolescent Psychopharmacology Update. 2007;9(10):1–7. PMID: 105971263. Language: English. EXCLUDE: Outcomes.
465 Saljoughian M. Atypical antipsychotics: safety and use in pediatric patients. US Pharmacist 2015;40(5) PMID: N/A. EXCLUDE: Publication Type.
466 Sallee FR, Miceli JJ, Tensfeldt T, . Single-dose pharmacokinetics and safety of ziprasidone in children and adolescents. J Am Acad Child Adolesc Psychiatry. 2006;45(6):720–8. PMID: 16721322. EXCLUDE: Study Design.16721322
467 Sallee FR, Nesbit L, Jackson C. Double-blind, controlled comparison of haloperidol and pimozide in children with gilles de la Tourette’s Syndrome. 149th Annual Meeting of the American Psychiatric Association; 1996 May 4–9; New York. 1996:0199. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/273/CN-00284273/frame.html. EXCLUDE: Publication Type.
468 Saloner B, Matone M, Kreider AR, . Second-generation antipsychotic use among stimulant-using children, by organization of medicaid mental health. Psychiatr Serv. 2014;65(12):1458–64. PMID: 25179737. EXCLUDE: Publication Type.25179737
469 Salpekar JA, Joshi PT, Axelson DA, . Depression and Suicidality Outcomes in the Treatment of Early Age Mania Study. J Am Acad Child Adolesc Psychiatry. 2015;54(12):999–1007.e4. PMID: 26598475. EXCLUDE: Intervention.26598475
470 Sandor P, Musisi S, Moldofsky H, . Tourette syndrome: a follow-up study. J Clin Psychopharmacol. 1990;10(3):197–9. PMID: 2115892. EXCLUDE: Age.2115892
471 Sanford M, Keating GM. Aripiprazole: in adolescents with schizophrenia. Paediatr Drugs. 2007;9(6):419–23. PMID: 18052412. EXCLUDE: Publication Type.18052412
472 Scahill L, Sukhodolsky DG, Anderberg E, . Sensitivity of the modified Children’s Yale-Brown Obsessive Compulsive Scale to detect change: Results from two multi-site trials. Autism. 2016;20(2):145–52. PMID: 25882391. EXCLUDE: Intervention.25882391
473 Scheidemantel T, Korobkova I, Rej S, . Asenapine for bipolar disorder. Neuropsychiatr Dis Treat. 2015;11:3007–17. PMID: 26674884. EXCLUDE: Publication Type.26674884
474 Schulz E, Fleischhaker C, Remschmidt HE. Correlated changes in symptoms and neurotransmitter indices during maintenance treatment with clozapine or conventional neuroleptics in adolescents and young adults with schizophrenia. J Child Adolesc Psychopharmacol. 1996;6(2):119–31. PMID: 9231304. EXCLUDE: Intervention.9231304
475 Scott EM, Hermens DF, White D, . Body mass, cardiovascular risk and metabolic characteristics of young persons presenting for mental healthcare in Sydney, Australia. BMJ Open. 2015;5(3):e007066. PMID: 25818274. EXCLUDE: Publication Type.25818274
476 Sernyak MJ, Desai R, Stolar M, . Impact of clozapine on completed suicide. Am J Psychiatry. 2001;158(6):931–7. PMID: 2001216017. EXCLUDE: Age.11384902
477 Shahrivar Z, Alaghband-Rad J, Mahmoudi Gharaie J, . The efficacy of an integrated treatment in comparison with treatment as usual in a group of youths with first-episode psychosis. Neuropsychiatr Enfance Adolesc 2012:S284–s5. PMID: N/A EXCLUDE: Intervention.
478 Shapira NA, Ward HE, Mandoki M, . A double-blind, placebo-controlled trial of olanzapine addition in fluoxetine-refractory obsessive-compulsive disorder. Biol Psychiatry. 2004;55(5):553–5. PMID: 15023585. EXCLUDE: Age.15023585
479 Shapiro AK, Shapiro E, Fulop G. Pimozide treatment of tic and Tourette disorders. Pediatrics. 1987;79(6):1032–9. PMID: 3295739. EXCLUDE: Publication Type.3295739
480 Shapiro E, Shapiro AK, Fulop G, . Controlled study of haloperidol, pimozide and placebo for the treatment of Gilles de la Tourette’s syndrome. Arch Gen Psychiatry. 1989;46(8):722–30. PMID: 2665687. EXCLUDE: Age.2665687
481 Sharma PS, Kongasseri S, Praharaj SK. Outcome of mood stabilizer discontinuation in bipolar disorder after 5 years of euthymia. J Clin Psychopharmacol. 2014;34(4):504–7PMID: 24943387. EXCLUDE: Age.24943387
482 Shaygannejad V, Khatoonabadi SAR, Shafiei B, . Olanzapine versus haloperidol: Which can control stuttering better? Int J Preventive Med. 2013;4:S270–S3. PMID: 2015433931. EXCLUDE: Diagnosis.
483 Sheehan DV, McElroy SL, Harnett-Sheehan K, . Randomized, placebo-controlled trial of risperidone for acute treatment of bipolar anxiety. J Affect Disord. 2009;115(3):376–85. PMID: 19042026. EXCLUDE: Age.19042026
484 Sikich L, Frazier JA, McClellan J, . Double-blind comparison of first- and second-generation antipsychotics in early-onset schizophrenia and schizo-affective disorder: findings from the treatment of early-onset schizophrenia spectrum disorders (TEOSS) study.[Erratum appears in Am J Psychiatry. 2008 Nov;165(11):1495]. Am J Psychiatry.2008;165(11):1420–31. PMID: 18794207. EXCLUDE: Duplicate.18794207
485 Sikirica V, Pliszka SR, Betts KA, . Impact of atypical antipsychotic use among adolescents with attention-deficit/hyperactivity disorder. Am J Manag Care. 2014;20(9):711–21. PMID: 25365746. EXCLUDE: Intervention.25365746
486 Silva RR, Malone RP, Anderson LT, . Haloperidol withdrawal and weight changes in autistic children. Psychopharmacol Bull. 1993;29(2):287–91. PMID: 8290679. EXCLUDE: Study Design.8290679
487 Simpson GM, Glick ID, Weiden PJ, . Randomized, controlled, double-blind multicenter comparison of the efficacy and tolerability of ziprasidone and olanzapine in acutely ill inpatients with schizophrenia or schizoaffective disorder. Am J Psychiatry. 2004;161(10):1837–47. PMID: 15465981. EXCLUDE: Age.15465981
488 Sinclair T, Beckman D, Cobb M, . Obesity rates and psychotropic medication use: differences between a juvenile detained and committed populations in an urban setting. J Forensic Psychol Pract. 2014;14(3):213–20. DOI: http://dx.doi.org/10.1080/15228932.2014.918477. PMID: N/A EXCLUDE: Study Design.
489 Singer MB. Variables related to compliance with neuroleptic medication in adolescent psychiatric patients after discharge from a psychiatric hospitalization. Diss Abstr Int: Section B: The Sciences and Engineering. 2003;63(9-B). PMID: N/A. EXCLUDE: Publication Type.
490 Sloman L, Remington G, Konstantareas M, . Haloperidol versus clomipramine in autistic disorder. 151st Annual Meeting of the American Psychiatric Association; 1998 May 30 – Jun 4; Toronto. 1998 http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/668/CN-00284668/frame.html. PMID: N/A. EXCLUDE: Publication Type.
491 Smith DH. Thematic issue on child and adolescent psychiatry. Can Child Adolesc Psychiatr Rev/La Revue canadienne de psychiatrie. 2015;60(10):415–6. Exclude: Publication Type.
492 Smulevich AB, Khanna S, Eerdekens M, . Acute and continuation risperidone monotherapy in bipolar mania: a 3-week placebo-controlled trial followed by a 9-week double-blind trial of risperidone and haloperidol. Eur Neuropsychopharmacol. 2005;15(1):75–84. PMID: 15572276. EXCLUDE: Age.15572276
493 Sohn M. The off-label use of atypical antipsychotics and its impact on Attention Deficit/Hyperactivity Disorder (ADHD). Dissertation Abstracts International: Section B: Sci Eng. 2015;76(4-B E). EXCLUDE: Diagnosis.
494 Sohn M, Talbert J, Blumenschein K, . Atypical antipsychotic initiation and the risk of type II diabetes in children and adolescents. Adv Pharmacoepidemiol Drug Saf. 2015;24(6):583–91. PMID: 25808613. EXCLUDE: outcomes25808613
495 Sohn M. The off-label use of atypical antipsychotics and its impact on attention deficit/hyperactivity disorder (ADHD) [Ph.D.]. Ann Arbor: University of Kentucky; 2014. PMID: N/A. EXCLUDE: Diagnosis.
496 Soria-Saucedo R, Walter HJ, Cabral H, . Receipt of Evidence-Based Pharmacotherapy and Psychotherapy Among Children and Adolescents With New Diagnoses of Depression. Psychiatr Serv. 2016;67(3):316–23. PMID: 26725295. EXCLUDE: Intervention.26725295
497 Souza VB, Moura Filho FJ, Souza FG, . Cataract occurrence in patients treated with antipsychotic drugs. Rev Bras Psiquiatr. 2008;30(3):222–6. PMID: 18833422. EXCLUDE: Age.18833422
498 Spivak B, Shabash E, Sheitman B, . The effects of clozapine versus haloperidol on measures of impulsive aggression and suicidality in chronic schizophrenia patients: an open, nonrandomized, 6-month study. J Clin Psychiatry. 2003;64(7):755–60. PMID: 12934974. EXCLUDE: Age.12934974
499 Srihari VH, Tek C, Kucukgoncu S, . First-Episode Services for Psychotic Disorders in the U.S. Public Sector: A Pragmatic Randomized Controlled Trial. Psychiatr Serv. 2015;66(7):705–12. PMID: 25639994. EXCLUDE: Age.25639994
500 Staller JA. Intramuscular ziprasidone in youth: a retrospective chart review. J Child Adolesc Psychopharmacol. 2004;14(4):590–2. PMID: 15662151. EXCLUDE: Study Design.15662151
501 Staller JA. Psychopharmacologic treatment of aggressive preschoolers: a chart review. Prog Neuropsychopharmacol Biol Psychiatry. 2007;31(1):131–5. PMID: 17007977. EXCLUDE: Study Design.17007977
502 Stefanovic V, Mihajlovic G, Nenadovic M, . The effect of antipsychotic drugs on nonspecific inflammation markers in the first episode of schizophrenia. Vojnosanit Pregl. 2015;72(12):1085–92. PMID: 26898032. EXCLUDE: Age.26898032
503 Steinhausen H-C, Helenius D. “The association between medication for attention-deficit/hyperactivity disorder and cancer”: Correction. J Child Adolesc Psychopharmacol. 2014;24(2):107–8. EXCLUDE: Publication Type.
504 Stentebjerg-Olesen M, Ganocy SJ, Findling RL, . Early response or nonresponse at week 2 and week 3 predict ultimate response or nonresponse in adolescents with schizophrenia treated with olanzapine: results from a 6-week randomized, placebo-controlled trial. Eur Child Adolesc Psychiatry. 2015;24(12):1485–96. PMID: 26032132 EXCLUDE: Study Design.26032132
505 Stentebjerg-Olesen M, Jeppesen P, Pagsberg AK, . Early nonresponse determined by the clinical global impressions scale predicts poorer outcomes in youth with schizophrenia spectrum disorders naturalistically treated with second-generation antipsychotics. J Child Adolesc Psychopharmacol. 2013;23(10):665–75. PMID: 24266529. EXCLUDE: Study Design.24266529
506 Stevens JR, Kymissis PI, Baker AJL. Elevated prolactin levels in male youths treated with risperidone and quetiapine. J Child Adolesc Psychopharmacol. 2005;15(6):893–900. PMID: 16379509. EXCLUDE: Study Design.16379509
507 Stoklosa J, Rose AB, Liebson ES, . Intensely Suicidal Behavior with a First Manic Episode. Harv Rev Psychiatry. 2015;23(4):288–95. PMID: 20160065262. EXCLUDE: Publication Type.26146756
508 Straiton ML, Powell K, Reneflot A, . Managing Mental Health Problems Among Immigrant Women Attending Primary Health Care Services. Health Care Women Int. 2016;37(1):118–39 22p. PMID: 111902586. EXCLUDE: Age.26251953
509 Strous RD, Kupchik M, Roitman S, . Comparison between risperidone, olanzapine, and clozapine in the management of chronic schizophrenia: a naturalistic prospective 12-week observational study. Hum Psychopharmacol. 2006;21(4):235–43. PMID: 16783815. EXCLUDE: Age.16783815
510 Study of risperidone with autistic children finds no detrimental cognitive effects. Brown University Child & Adolescent Psychopharmacology Update. 2008;10(9):3–4. PMID: 105681306. EXCLUDE: Publication Type.
511 Subotnik KL, Casaus LR, Ventura J, . Long-Acting Injectable Risperidone for Relapse Prevention and Control of Breakthrough Symptoms After a Recent First Episode of Schizophrenia. A Randomized Clinical Trial. JAMA Psychiatr. 2015;72(8):822–9PMID: 26107752. EXCLUDE: Age.26107752
512 Sun X, Hamer R, McEvoy J. Asenapine once daily versus twice daily: impact on patient acceptance in a randomized, open-label, 14-day clinical trial. J Clin Psychiatr; 2015;992–3. EXCLUDE: Age.
513 Sundar Raj M, Prasath M, Adalarasu K. Autism spectrum disorder. Int J Pharm Technol. 2015;7(2):8638–47. PMID: 2015453923. EXCLUDE: Publication Type.
514 Svestka J, Synek O, Tomanova J, . Differences in the effect of second-generation antipsychotics on prolactinaemia: six weeks open-label trial in female in-patients. Neuroendocrinol Lett. 2007;28(6):881–8. PMID: 18063941. EXCLUDE: Age.18063941
515 Sylvia LG, Thase ME, Reilly-Harrington NA, . Psychotherapy use in bipolar disorder: Association with functioning and illness severity. Aust N Z J Psychiatry. 2015;49(5):453–61. PMID: 25680360. EXCLUDE: Age.25680360
516 Swanson JW, Swartz MS, Elbogen EB. Effectiveness of atypical antipsychotic medications in reducing violent behavior among persons with schizophrenia in community-based treatment. Schizophr Bull. 2004;30(1):3–20. PMID: 15176758. EXCLUDE: Age.15176758
517 Swanson JW, Swartz MS, Van Dorn RA, . Comparison of antipsychotic medication effects on reducing violence in people with schizophrenia. Br J Psychiatry. 2008;193(1):37–43. PMID: 18700216. EXCLUDE: Age.18700216
518 Takahashi S, Suzuki M, Uchiyama M. One-year follow-up of serum prolactin level in schizophrenia patients treated with blonanserin: A case series. Psychiatry Investig. 2015;12(4):566–8. PMID: 2015502075. EXCLUDE: Publication Type.
519 Tasca GA, Keating L, Maxwell H, . Predictors of treatment acceptance and of participation in a randomized controlled trial among women with anorexia nervosa. Eur Eat Disord Rev. 2012;20(2):155–61. PMID: 21751299. EXCLUDE: Study Design21751299
520 Taylor D, Hanssens L, Loze JY, . Preference of medicine and patient-reported quality of life in community-treated schizophrenic patients receiving aripiprazole vs standard of care: results from the STAR study. Eur Psychiatry. 2008;23(5):336–43. PMID: 18423987. EXCLUDE: Age.18423987
521 Taylor DM, Douglas-Hall P, Olofinjana B, . Reasons for discontinuing clozapine: matched, case-control comparison with risperidone long-acting injection. Br J Psychiatry. 2009;194(2):165–7. PMID: 19182180. EXCLUDE: Age.19182180
522 Taylor M, Turner M, Watt L, . Atypical anti-psychotics in the real world--a naturalistic comparative outcome study. Scott Med J. 2005;50(3):102–6. PMID: 16163994. EXCLUDE: Age.16163994
523 TEOSS: maintenance safety and effectiveness findings. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(7):3–4. PMID: 105045864. EXCLUDE: Outcomes.
524 Thase ME, Macfadden W, Weisler RH, . Efficacy of quetiapine monotherapy in bipolar I and II depression: a double-blind, placebo-controlled study (the BOLDER II study). J Clin Psychopharmacol 2006:600–9. PMID: 17110817 EXCLUDE: Age.17110817
525 Thase ME, Youakim JM, Skuban A, . Efficacy and safety of adjunctive brexpiprazole 2 mg in major depressive disorder: a phase 3, randomized, placebo-controlled study in patients with inadequate response to antidepressants. J Clin Psychiatr. 2015;76(9):1224–31. PMID: 26301701. EXCLUDE: Age.26301701
526 Thase ME, Youakim JM, Skuban A, . Adjunctive brexpiprazole 1 and 3 mg for patients with major depressive disorder following inadequate response to antidepressants: a phase 3, randomized, double-blind study. J Clin Psychiatr. 2015;76(9):1232–40. PMID: 26301771. EXCLUDE: Age.26301771
527 Tiihonen J, Wahlbeck K, Lonnqvist J, . Effectiveness of antipsychotic treatments in a nationwide cohort of patients in community care after first hospitalisation due to schizophrenia and schizoaffective disorder: observational follow-up study. BMJ. 2006;333(7561):224–7. PMID: 16825203. EXCLUDE: Age.16825203
528 Tobiasova Z, van der Lingen KH, Scahill L, . Risperidone-related improvement of irritability in children with autism is not associated with changes in serum of epidermal growth factor and interleukin-13. J Child Adoles Psychopharmacol. 2011;21(6):555–64. PMID: 22070180. EXCLUDE: Outcomes.22070180
529 Tohen M, Bowden CL, Smulevich AB, . Olanzapine plus carbamazepine v. carbamazepine alone in treating manic episodes. Br J Psychiatry. 2008;192(2):135–43. PMID: 18245032. EXCLUDE: Age.18245032
530 Tohen M, Jacobs TG, Grundy SL, . Efficacy of olanzapine in acute bipolar mania: a double-blind, placebo-controlled study. The Olanzipine HGGW Study Group.[Erratum appears in Arch Gen Psychiatry 2002;59(1):91]. Arch Gen Psychiatry. 2000;57(9):841–9. PMID: 10986547. EXCLUDE: Age.10986547
531 Tohen M, Kryzhanovskaya L, Carlson G, . Efficacy of olanzapine for the treatment of acute mania in subtypes of adolescent patients: A 3-week randomized double-blind placebo controlled study. Bipolar Disord 2006:26. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/064/CN-00634064/frame.html. EXCLUDE: Duplicate.
532 Tohen M, Sanger TM, McElroy SL, . Olanzapine versus placebo in the treatment of acute mania. Olanzapine HGEH Study Group. Am J Psychiatry. 1999;156(5):702–9. PMID: 10327902. EXCLUDE: Age.10327902
533 Tohen M, Vieta E, Goodwin GM, . Olanzapine versus divalproex versus placebo in the treatment of mild to moderate mania: a randomized, 12-week, double-blind study. J Clin Psychiatry. 2008;69(11):1776–89. PMID: 19014751. EXCLUDE: Age.19014751
534 Tollefson GD, Beasley CM, Jr., Tran PV, . Olanzapine versus haloperidol in the treatment of schizophrenia and schizoaffective and schizophreniform disorders: results of an international collaborative trial. Am J Psychiatry. 1997;154(4):457–65. PMID: 9090331. EXCLUDE: Age.9090331
535 Tollefson GD, Sanger TM. Negative symptoms: a path analytic approach to a double-blind, placebo- and haloperidol-controlled clinical trial with olanzapine. Am J Psychiatry. 1997;154(4):466–74. PMID: 9090332. EXCLUDE: Age.9090332
536 Torniainen M, Mittendorfer-Rutz E, Tanskanen A, . Antipsychotic treatment and mortality in schizophrenia. Schizophr Bull. 2015;41(3):656–63. PMID: 25422511. Exclude: Age.25422511
537 Torres IJ, Kozicky J, Popuri S, . 12-month longitudinal cognitive functioning in patients recently diagnosed with bipolar disorder. Bipolar Disord. 2014;16(2):159–71. PMID: 24636366. EXCLUDE: Intervention.24636366
538 Treating first psychotic episode in adolescents. Brown University Child & Adolescent Psychopharmacology Update. 2009;11(4):3–4. PMID: 105495563. EXCLUDE: Outcomes.
539 Tsay ME, Klein-Schwartz W, Anderson B. Toxicity and clinical outcomes of paliperidone exposures reported to U.S. Poison Centers. Clin Toxicol. 2014;52(3):207–13. PMID: 22364403. EXCLUDE: Study Design.22364403
540 Turkel SB, Jacobson J, Munzig E, . Atypical antipsychotic medications to control symptoms of delirium in children and adolescents. J Child Adolesc Psychopharmacol. 2012;22(2):126–30. PMID: 22364403. EXCLUDE: Diagnosis.22364403
541 Tyrer P, Oliver-Africano P, Romeo R, . Neuroleptics in the treatment of aggressive challenging behaviour for people with intellectual disabilities: a randomised controlled trial (NACHBID). Health Technol Assess 2009;13(21):iii–iv, ix–xi, 1–54. PMID: 19397849. EXCLUDE: Age.19397849
542 Urben S, Baumann P, Barcellona S, . Cognitive efficacy of quetiapine in early-onset first-episode psychosis: a 12-week open label trial. Psychiatr Q. 2012;83(3):311–24. PMID: 22101738. EXCLUDE: Intervention.22101738
543 Uttley L, Kearns B, Ren S, . Aripiprazole for the treatment and prevention of acute manic and mixed episodes in bipolar I disorder in children and adolescents: a NICE single technology appraisal. Pharmacoeconomics. 2013;31(11):981–90. PMID: 24092620. EXCLUDE: Publication Type.24092620
544 van Nimwegen LJ, de Haan L, van Beveren NJ, . Effect of olanzapine and risperidone on subjective well-being and craving for cannabis in patients with schizophrenia or related disorders: a double-blind randomized controlled trial. Can J Psychiatry. 2008;53(6):400–5. PMID: 18616861. EXCLUDE: Age.18616861
545 van Wattum PJ, Fabius C, Roos C, . Polypharmacy reduction in youth in a residential treatment center leads to positive treatment outcomes and significant cost savings. J Child Adolesc Psychopharmacol. 2013;23(9):620–7. PMID: 24251644. EXCLUDE: Intervention.24251644
546 Vanden Borre R, Vermote R, Buttiens M, . Risperidone as add-on therapy in behavioural disturbances in mental retardation: a double-blind placebo-controlled cross-over study. Acta Psychiatr Scand. 1993;87(3):167–71. PMID: 7682029. EXCLUDE: Age.7682029
547 Vazquez-Bourgon J, Arranz MJ, Mata I, . Serotonin transporter polymorphisms and early response to antipsychotic treatment in first episode of psychosis. Psychiatry Res. 2010;175(3):189–94. PMID: 20031235. EXCLUDE: Age.20031235
548 Velligan DI, Carroll C, Lage MJ, . Outcomes of medicaid beneficiaries with schizophrenia receiving clozapine only or antipsychotic combinations. Psychiatr Serv. 2015;66(2):127–33. PMID: 25321616. EXCLUDE: Age.25321616
549 Ventura J, Subotnik KL, Gitlin MJ, . Negative symptoms and functioning during the first year after a recent onset of schizophrenia and 8 years later. Schizophr Res. 2015;161(2–3):407–13. PMID: 25499044. EXCLUDE: Age.25499044
550 Vernal DL, Kapoor S, Al-Jadiri A, . Outcome of youth with early-phase schizophrenia-spectrum disorders and psychosis not otherwise specified treated with second-generation antipsychotics: 12 week results from a prospective, naturalistic cohort study. J Child Adolesc Psychopharmacol. 2015;25(7):535–47. PMID: 26375767. EXCLUDE: Intervention.26375767
551 Veser FH, Veser BD, McMullan JT, . Risperidone versus haloperidol, in combination with lorazepam, in the treatment of acute agitation and psychosis: a pilot, randomized, double-blind, placebo-controlled trial. J Psychiatr Pract. 2006;12(2):103–8. PMID: 16728906. EXCLUDE: Age.16728906
552 Vieta E, Bourin M, Sanchez R, . Effectiveness of aripiprazole v. haloperidol in acute bipolar mania: double-blind, randomised, comparative 12-week trial. Br J Psychiatry. 2005;187:235–42PMID: 16135860. EXCLUDE: Age.16135860
553 Vieta E, Suppes T, Eggens I, . Efficacy and safety of quetiapine in combination with lithium or divalproex for maintenance of patients with bipolar I disorder (international trial 126). J Affect Disord. 2008;109(3):251–63. PMID: 18579216. EXCLUDE: Age.18579216
554 Vik-Mo AO, Birkenaes AB, Ferno J, . Increased expression of lipid biosynthesis genes in peripheral blood cells of olanzapine-treated patients. Int J Neuropsychopharmacol. 2008;11(5):679–84. PMID: 18241359. EXCLUDE: Age.18241359
555 Villari V, Rocca P, Fonzo V, . Oral risperidone, olanzapine and quetiapine versus haloperidol in psychotic agitation. Prog Neuropsychopharmacol Biol Psychiatry. 2008;32(2):405–13. PMID: 17900775. EXCLUDE: Age.17900775
556 Volavka J, Czobor P, Sheitman B, . Clozapine, olanzapine, risperidone, and haloperidol in the treatment of patients with chronic schizophrenia and schizoaffective disorder.[Erratum appears in Am J Psychiatry 2002;159(12):2132]. Am J Psychiatry. 2002;159(2):255–62. PMID: 11823268. EXCLUDE: Age.11823268
557 Voruganti LP, Awad AG, Parker G, . Cognition, functioning and quality of life in schizophrenia treatment: results of a one-year randomized controlled trial of olanzapine and quetiapine. Schizophr Res. 2007;96(1–3):146–55. PMID: 17728106. EXCLUDE: Age.17728106
558 Vulink NC, Denys D, Fluitman SB, . Quetiapine augments the effect of citalopram in non-refractory obsessive-compulsive disorder: a randomized, double-blind, placebo-controlled study of 76 patients. J Clinl Psychiatry. 2009;70(7):1001–8. PMID: 19497245. EXCLUDE: Age.19497245
559 Walkup JT, Wagner KD, Miller L, . Treatment of Early-Age Mania: Outcomes for Partial and Nonresponders to Initial Treatment. J Am Acad Child Adolesc Psychiatry. 2015 Dec;54(12):1008–19 PMID: 26598476. EXCLUDE: Intervention.26598476
560 Wang J, Hu MR, Guo XF, . Cognitive effects of atypical antipsychotic drugs in first-episode drug-naive schizophrenic patients. Neural Regen Res. 2013;8(3):277–86. PMID: 2015864151. EXCLUDE: Age.25206599
561 Waugaman RM. Potential lower efficacy of molindone among first-generation antipsychotics. Am J Psychiatry. 2009;166(4):491. PMID: 19339370. EXCLUDE: Publication Type.19339370
562 Weiden PJ, Daniel DG, Simpson G, . Improvement in indices of health status in outpatients with schizophrenia switched to ziprasidone. J Clin Psychopharmacol. 2003;23(6):595–600. PMID: 14624190. EXCLUDE: Age.14624190
563 Weiden PJ, Schooler NR, Weedon JC, . A randomized controlled trial of long-acting injectable risperidone vs continuation on oral atypical antipsychotics for first-episode schizophrenia patients: initial adherence outcome. J Clin Psychiatry. 2009;70(10):1397–406. PMID: 19906343. EXCLUDE: Age.19906343
564 Weight gain and metabolic changes in children and adolescents treated with atypical antipsychotics. Drug Benefit Trends. 2009;21(11):358. PMID: 2010089448. EXCLUDE: Publication Type.
565 Weiser M, Shneider-Beeri M, Nakash N, . Improvement in cognition associated with novel antipsychotic drugs: a direct drug effect or reduction of EPS? Schizophr Res. 2000;46(2–3):81–9. PMID: 11120419. EXCLUDE: Age.11120419
566 Weiss M, Panagiotopoulos C, Giles L, . A naturalistic study of predictors and risks of atypical antipsychotic use in an attention-deficit/hyperactivity disorder clinic. J Child Adolesc Psychopharmacol. 2009;19(5):575–82. PMID: 19877982. EXCLUDE: Study Design.19877982
567 West AE, Celio CI, Henry DB, . Child Mania Rating Scale-Parent Version: a valid measure of symptom change due to pharmacotherapy. J Affect Disord. 2011;128(1–2):112–9. PMID: 20858565. EXCLUDE: Intervention.20858565
568 West AE, Weinstein SM, Celio CI, . Co-morbid disruptive behavior disorder and aggression predict functional outcomes and differential response to risperidone versus divalproex in pharmacotherapy for pediatric bipolar disorder. J Child Adolesc Psychopharmacol. 2011;21(6):545–53. PMID: 22136096. EXCLUDE: Intervention.22136096
569 Wetterling T, Mussigbrodt HE. Weight gain: side effect of atypical neuroleptics? J Clin Psychopharmacol. 1999;19(4):316–21. PMID: 10440458. EXCLUDE: Age.10440458
570 Wilhelm S, Schacht A, Wagner T. Use of antipsychotics and benzodiazepines in patients with psychiatric emergencies: results of an observational trial. BMC Psychiatry. 2008;8:61. PMID: 18647402. EXCLUDE: Age.18647402
571 Winter HR, Earley WR, Hamer-Maansson JE, . Steady-state pharmacokinetic, safety, and tolerability profiles of quetiapine, norquetiapine, and other quetiapine metabolites in pediatric and adult patients with psychotic disorders. J Child Adolesc Psychopharmacol. 2008;18(1):81–98. PMID: 18294091. EXCLUDE: Study Design.18294091
572 Wright P, Birkett M, David SR, . Double-blind, placebo-controlled comparison of intramuscular olanzapine and intramuscular haloperidol in the treatment of acute agitation in schizophrenia. Am J Psychiatry. 2001;158(7):1149–51. PMID: 11431240. EXCLUDE: Age.11431240
573 Wu JQ, Chen DC, Tan YL, . Cognitive impairments in first-episode drug-naive and chronic medicated schizophrenia: MATRICS consensus cognitive battery in a Chinese Han population. Psychiatr Res. 2016;238:196–202. PMID: 20160162360. EXCLUDE: Age.
574 Wunderink L, Nienhuis FJ, Sytema S, . Guided discontinuation versus maintenance treatment in remitted first-episode psychosis: relapse rates and functional outcome. J Clin Psychiatry. 2007;68(5):654–61. PMID: 17503973. EXCLUDE: Age.17503973
575 Yatham LN, Paulsson B, Mullen J, . Quetiapine versus placebo in combination with lithium or divalproex for the treatment of bipolar mania. J Clin Psychopharmacol 2004:599–606. PMID: 15538120. EXCLUDE: Age.15538120
576 Young AH, Oren DA, Lowy A, . Aripiprazole monotherapy in acute mania: 12-week randomised placebo- and haloperidol-controlled study. Br J Psychiatry. 2009;194(1):40–8. PMID: 19118324. EXCLUDE: Age.19118324
577 Youngstrom E, Zhao J, Mankoski R, . Item level patterns of response of aripiprazole for the acute treatment of pediatric bipolar I disorder. Neuropsychopharmacology 2010:S170. 10.1038/npp.2010.216. PMID: N/A. EXCLUDE: Publication Type.
578 Younis IR, Laughren TP, Wang Y, . An integrated approach for establishing dosing recommendations: paliperidone for the treatment of adolescent schizophrenia. J Clin Psychopharmacol. 2013;33(2):152–6. PMID: 23422374. EXCLUDE: Publication Type.23422374
579 Yu AP, Atanasov P, Ben-Hamadi R, . Resource utilization and costs of schizophrenia patients treated with olanzapine versus quetiapine in a Medicaid population. Value Health. 2009;12(5):708–15. PMID: 19508658. EXCLUDE: Age.19508658
580 Yung A, Amminger P, Berger G, . Randomized controlled trial of antipsychotic and cognitive therapy in young people at ultra-high risk of psychosis. Early Interv Psychiatry 2012:11. PMID: 21034687 EXCLUDE: Publication Type.21034687
581 Zarcone JR, Lindauer SE, Morse PS, . Effects of risperidone on destructive behavior of persons with developmental disabilities: III. Functional analysis. Am J Ment Retard. 2004;109(4):310–21. PMID: 15176916. EXCLUDE: Age.15176916
582 Zedkova I, Dudova I, Urbanek T, . Onset of action of atypical and typical antipsychotics in the treatment of adolescent schizophrenic psychoses. Neuroendocrinol Lett. 2011;32(5):667–70. PMID: 22167144. EXCLUDE: Intervention.22167144
583 Zeni CP, Tramontina S, Ketzer CR, . Methylphenidate combined with aripiprazole in children and adolescents with bipolar disorder and attention-deficit/hyperactivity disorder: a randomized crossover trial. J Child Adolesc Psychopharmacol. 2009;19(5):553–61. PMID: 19877980. EXCLUDE: Intervention.19877980
584 Zhang H, Li H, Liu Y, . Safety and efficacy of paliperidone extended-release in chinese patients with schizophrenia: A 24-week, open-label extension of a randomized, double-blind, placebo-controlled study. Neuropsychiatr Dis Treat. 2016;12:69–77 PMID: 20160049641. EXCLUDE: Age.26811679
585 Zhang JP, Robinson DG, Gallego JA, . Association of a Schizophrenia Risk Variant at the DRD2 Locus with Antipsychotic Treatment Response in First-Episode Psychosis. Schizophr Bull. 2015;41(6):1248–55. PMID: 2015496131. EXCLUDE: Age.26320194
586 Zheng Y, Zhang Z-J, Han X-M, . A proprietary herbal medicine (5- Ling Granule) for Tourette syndrome: a randomized controlled trial. J Child Psychol Psychiatr. 2016;57(1):74–83 10p. PMID: 111554275. EXCLUDE: Intervention.
587 Zink M, Kuwilsky A, Krumm B, . Efficacy and tolerability of ziprasidone versus risperidone as augmentation in patients partially responsive to clozapine: a randomised controlled clinical trial. J Psychopharmacol. 2009;23(3):305–14. PMID: 18562423. EXCLUDE: Age.18562423
588 Zipursky RB, Christensen BK, Daskalakis Z, . Treatment response to olanzapine and haloperidol and its association with dopamine D receptor occupancy in first-episode psychosis. Can J Psychiatry. 2005;50(8):462–9. PMID: 16127964. EXCLUDE: Age.16127964
589 Zong X, Hu M, Li Z, . N-acetylaspartate reduction in the medial prefrontal cortex following 8 weeks of risperidone treatment in first-episode drug-naive schizophrenia patients. Sci Rep. 2015;5:9109. PMID: 25778460. EXCLUDE: Age.25778460
590 Zuddas A, Di Martino A, Muglia P, . Long-term risperidone for pervasive developmental disorder: efficacy, tolerability, and discontinuation. J Child Adolesc Psychopharmacol. 2000;10(2):79–90. PMID: 10933118. EXCLUDE: Study Design.10933118