# Appendix E Associated Publications

Main Publication | Associated Publications
Aman MG, Marks RE, Turbott SH, et al. Clinical effects of methylphenidate and thioridazine in intellectually subaverage children. Journal of the American Academy of Child & Adolescent Psychiatry. 1991 Mar;30(2):246–56. PMID: 2016229. | Aman MG, Marks RE, Turbott SH et al. Methylphenidate and thioridazine in the treatment of intellectually subaverage children: effects on cognitive-motor performance. Journal of the American Academy of Child & Adolescent Psychiatry, 1991;30(5), 816–824.
Aman MG, De Smedt G, Derivan, A, et al. Double-blind, placebo-controlled study of risperidone for the treatment of disruptive behaviors in children with subaverage intelligence. Am J Psychiatry 2002;159(8):1337–46. | Aman M, Findling A, Derivan U. Risperidone versus placebo for severe conduct disorder in children with mental retardation. Int J Neuropsychopharmacol 2000:S144.
| Aman MG, Findling RL, Derivan AT, et al. Effects of risperidone on the behavior of children with subaverage IQ’s and conduct disorder or oppositional defiant disorder. Annual Meeting of the American Psychiatric Association; 2001.
| Aman MG, Findling RL. Effects of risperidone on the behavior of children with subaverage IQ’s and conduct disorder or oppositional defiant disorder. 155th Annual Meeting of the American Psychiatric Association; 2002.
| Biederman J, Mick E, Faraone SV, et al. Risperidone for the treatment of affective symptoms in children with disruptive behavior disorder: a post hoc analysis of data from a 6-week, multicenter, randomized, double-blind, parallel-arm study. Clin Ther 2006;28(5):794–800.
| Findling RL, Aman MG, Eerdekens M, et al. Long-term, open-label study of risperidone in children with severe disruptive behaviors and below-average IQ. Am J Psychiatry 2004;161(4):677–84.
| Turgay A. Risperidone in children with disruptive behavior disorder and ADHD. 154th Annual Meeting of the American Psychiatric Association; 2001.
Aman MG, Bukstein OG, Gadow KD, et al. What does risperidone add to parent training and stimulant for severe aggression in child attention-deficit/hyperactivity disorder? Journal of the American Academy of Child & Adolescent Psychiatry. 2014 Jan;53(1):47–60.e1. PMID: 24342385. | Arnold LE, Gadow KD, Farmer CA, et al. Comorbid anxiety and social avoidance in treatment of severe childhood aggression: response to adding risperidone to stimulant and parent training; mediation of disruptive symptom response. Journal of Child & Adolescent Psychopharmacology, 2015;25(3), 203–212.
| Gadow KD, Arnold, LE, Molina, BS, et al. Risperidone added to parent training and stimulant medication: effects on attention-deficit/hyperactivity disorder, oppositional defiant disorder, conduct disorder, and peer aggression. Journal of the American Academy of Child & Adolescent Psychiatry. 2014;53(9), 948–959.e941.
Arango C, Robles O, Parellada M, et al. Olanzapine compared to quetiapine in adolescents with a first psychotic episode. Eur Child Adolesc Psychiatry 2009;18(7):418–28. | Robles O, Zabala A, Bombin I, et al. Cognitive Efficacy of Quetiapine and Olanzapine in Early-Onset First-Episode Psychosis. Schizophr Bull 2009:1–11.
Arango C, Giraldez M, Merchan-Naranjo J, et al. Second-generation antipsychotic use in children and adolescents: A six-month prospective cohort study in drug-naive patients. Journal of the American Academy of Child & Adolescent Psychiatry. 2014 Nov;53(11):1179–90,90.e1–4. PMID: 25440308. | Merchan-Naranjo J, Tapia C, Bailon C, et al. Secondary effects of antipsychotic treatment in naive or quasi-naive children and adolescents: design of a follow-up protocol and baseline results. Revista de Psiquiatria y Salud Mental. 2012;5(4), 217–228.
| Garcia-Amador, M, Merchn-Naranjo, J, Tapia, C, et al. Neurological Adverse Effects of Antipsychotics in Children and Adolescents. Jounral of Clinical Psychopharmacology. 2015:35(6), 686–693.
Buitelaar JK, van der Gaag RJ, Cohen-Kettenis P, et al. A randomized controlled trial of risperidone in the treatment of aggression in hospitalized adolescents with subaverage cognitive abilities. J Clin Psychiatry 2001;62(4):239–48. | Buitelaar JK, van der Gaag RJ, Melman CT. Risperidone in the treatment of aggressive behaviour disorders in adolescents with mild mental retardation: a prospective, randomised, double-blind, placebo-controlled trial. Paris: 11th European College of Neuropsychopharmacology Congress; 1998.
Castro-Fornieles J, Parellada M, Soutullo CA, et al. Antipsychotic treatment in child and adolescent first-episode psychosis: A longitudinal naturalistic approach. Journal of Child & Adolescent Psychopharmacology. 2008 Aug;18(4):327–36. PMID: 18759642. | Noguera A, Ballesta P, Baeza I, et al. Twenty-four months of antipsychotic treatment in children and adolescents with first psychotic episode: discontinuation and tolerability. Journal of Clinical Psychopharmacology. 2013;33(4), 463–471.
Correll CU, Manu P, Olshanskiy V, et al. Cardiometabolic risk of second-generation antipsychotic medications during first-time use in children and adolescents. JAMA - Journal of the American Medical Association302(16)()(pp 1765–1773), 2009 Date of Publication: 2009. 2009(16):1765–73. | Carbon M, Kapoor S, Sheridan E, et al. Neuromotor Adverse Effects in 342 Youth During 12 Weeks of Naturalistic Treatment With 5 Second-Generation Antipsychotics. Journal of the American Academy of Child & Adolescent Psychiatry. 2015; 54(9), 718–727.e713.
| Penzner JB, Dudas M, Saito E, et al. Lack of effect of stimulant combination with second-generation antipsychotics on weight gain, metabolic changes, prolactin levels, and sedation in youth with clinically relevant aggression or oppositionality. Journal of Child & Adolescent Psychopharmacology. 2009; 19(5), 563–573.
Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry 2000;39(4):509–16. | Findling RL, McNamara NK, Branicky LA. Conduct disorder in children treated with risperidone. 37th Annual Meeting of the American College of Neuropsychopharmacology; 1998 Dec 14–18; Las Croabas; 1998.
Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry 2000;39(4):509–16. | Findling RL, Branicky LA, Branicky LA, et al. Conduct disorder in children treated with risperidone. 152nd Annual Meeting of the American Psychiatric Association; 1999.
Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry 2000;39(4):509–16. | Findling RL, McNamara NK, Branicky LA, et al. Risperidone in children with conduct disorder conference abstract. Schizophrenia Research. Abstracts of The VIIth International Congress on Schizophrenia Research; Santa Fe, NM; 1999:17–21.
Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry 2000;39(4):509–16. | Findling RL. Risperidone in children with conduct disorder. Eur Neuropsychopharmacol 1999:S358
Findling RL, Robb A, Nyilas M, et al. A multiple-center, randomized, double-blind, placebo-controlled study of oral aripiprazole for treatment of adolescents with schizophrenia. Am J Psychiatry 2008;165(11):1432–41. | Loze JY, Mathew SJ, McQuade RD, et al. Somnolence and sedation in adolescents with schizophrenia treated with aripiprazole (acute and long term follow-up). European Neuropsychopharmacology. 2009;S690–s691.
| Robb AS, Carson WH, Nyilas M, et al. Changes in positive and negative syndrome scale-derived hostility factor in adolescents with schizophrenia treated with aripiprazole: post hoc analysis of randomized clinical trial data. J Child Adolesc Psychopharmacol 2010;20(1):33–8.
| Center for Drug Evaluation and Research. Otsuka Pharmaceutical. NDA# 021–436, 021–713, 021–729, 021–866. October 2007. http://www.accessdata.fda.gov.
Findling RL, Nyilas M, Forbes RA, et al. Acute treatment of pediatric bipolar i disorder, manic or mixed episode, with aripiprazole: A randomized, double-blind, placebo-controlled study. Journal of Clinical Psychiatry. 2009;70(10):1441–51. | Findling RL, Youngstrom EA, Zhao J, et al. Respondent and item level patterns of response of aripiprazole in the acute treatment of pediatric bipolar I disorder. Journal of Affective Disorders. 2012;143(1–3), 231–235.
| Findling RL, Correll CU, Nyilas M, et al. Aripiprazole for the treatment of pediatric bipolar I disorder: a 30-week, randomized, placebo-controlled study. Bipolar Disorders. 2013 15(2), 138–149.
| Mankoski R, Zhao J, Carson WH, et al. Young mania rating scale line item analysis in pediatric subjects with bipolar I disorder treated with aripiprazole in a short-term, double-blind, randomized study. Journal of Child & Adolescent Psychopharmacology. 2011;21(4), 359–364.
| Youngstrom E, Zhao J, Mankoski R, et al. Clinical significance of treatment effects with aripiprazole versus placebo in a study of manic or mixed episodes associated with pediatric bipolar I disorder. Journal of Child & Adolescent Psychopharmacology. 2013; 23(2), 72–79.
Fleischhaker C, Heiser P, Hennighausen K, et al. Clinical drug monitoring in child and adolescent psychiatry: side effects of atypical neuroleptics. J Child Adolesc Psychopharmacol 2006;16(3):308–16. | Fleischhaker C, Heiser P, Hennighausen K, et al. Weight gain associated with clozapine, olanzapine and risperidone in children and adolescents. J Neural Transm 2007;114(2):273–80.
Fleischhaker C, Heiser P, Hennighausen K, et al. Clinical drug monitoring in child and adolescent psychiatry: side effects of atypical neuroleptics. J Child Adolesc Psychopharmacol 2006;16(3):308–16. | Fleischhaker C, Heiser P, Hennighausen K, et al. Weight gain in children and adolescents during 45 weeks treatment with clozapine, olanzapine and risperidone. J Neural Transm 2008;115(11):1599–608.
Haas M, Delbello MP, Pandina G, et al. Risperidone for the treatment of acute mania in children and adolescents with bipolar disorder: a randomized, double-blind, placebo-controlled study. Bipolar Disord 2009;11(7):687–700. | Delbello M. Research on the effectiveness of risperidone in bipolar disorder in adolescents and children (REACH): a double-blind, randomized, placebo-controlled study of the efficacy and safety of risperidone for the treatment of acute mania in bipolar I disorder. Johnson & Johnson Pharmaceutical Research; 2010.
Hellings JA, Zarcone JR, Reese RM, et al. A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord 2006;36(3):401–11. | Hellings JA, Zarcone JR, Crandall K, et al. Weight gain in a controlled study of risperidone in children, adolescents and adults with mental retardation and autism J Child Adolesc Psychopharmacol 2001;11(3):229–38.
Hellings JA, Zarcone JR, Reese RM, et al. A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord 2006;36(3):401–11. | Hellings JA, Zarcone JR, Valdovinos MG, et al. Risperidone-induced prolactin elevation in a prospective study of children, adolescents, and adults with mental retardation and pervasive developmental disorders. J Child Adolesc Psychopharmacol 2005;15(6):885–92.
Hellings JA, Zarcone JR, Reese RM, et al. A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord 2006;36(3):401–11. | Zarcone JR, Hellings JA, Crandall K, et al. Effects of risperidone on aberrant behavior of persons with developmental disabilities: a double-blind crossover study using multiple measures. Am J Ment Retard 2001;106(6):525–38.
Jerrell JM, Mcintyre RS. Adverse events in children and adolescents treated with antipsychotic medications. Hum. 2008 Jun;23(4):283–90. PMID: 18302312. | Jerrell JM, Hwang TL, Livingston TS. Neurological adverse events associated with antipsychotic treatment in children and adolescents. Journal of Child Neurology. 2008;23(12), 1392–1399.
Jerrell JM, Mcintyre RS. Adverse events in children and adolescents treated with antipsychotic medications. Hum. 2008 Jun;23(4):283–90. PMID: 18302312. | Jerrell JM. Adverse events associated with psychotropic treatment in African American children and adolescents. Journal of the National Medical Association. 2010;102(5), 375–383.
Kryzhanovskaya L, Schulz SC, McDougle C, et al. Olanzapine versus placebo in adolescents with schizophrenia: a 6-week, randomized, double-blind, placebo-controlled trial. J Am Acad Child Adoles Psychiatry 2009;48(1): 60–70. | Olanzapine versus placebo in the treatment of adolescents with schizophrenia. Clinical Study Summary: Study F1D-MC-HGIN, Summary ID# 4066. 1–49. Eli Lilly and co.; April 2007. Available at http://www.lillytrials.com/results/Zyprexa.pdf.
| Center for Drug Evaluation and Research. Eli Lilly and Company. NDA# 020592. July 2008. http://www.accessdata.fda.gov.
Kumra S, Kranzler H, Gerbino-Rosen G, et al. Clozapine and “high-dose” olanzapine in refractory early-onset schizophrenia: a 12-week randomized and double-blind comparison. Biol Psychiatry 2008;63(5):524–9. | Kumra S, Kranzler H, Gerbino-Rosen G, et al. Clozapine versus “high-dose” olanzapine in refractory early-onset schizophrenia: an open-label extension study. J Child Adolesc Psychopharmacol 2008;18(4):307–16.
Marcus RN, Owen R, Kamen L, et al. A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry 2009;48(11):1110–9. | Robb AS, Andersson C, Bellocchio EE, et al. Safety and tolerability of aripiprazole in the treatment of irritability associated with autistic disorder in pediatric subjects (6–17 years old):results from a pooled analysis of 2 studies. The Primary Care Companion to CNS Disorders. 2011; 13(1).
| Varni JW, Handen BL, Corey-Lisle PK, et al. Effect of aripiprazole 2 to 15 mg/d on health-related quality of life in the treatment of irritability associated with autistic disorder in children: a post hoc analysis of two controlled trials. Clinical Therapeutics. 2012; 34(4), 980–992.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Aman MG, Arnold LE, McDougle CJ, et al. Acute and long-term safety and tolerability of risperidone in children with autism. J Child Adolesc Psychopharmacol 2005;15(6):869–84.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Aman MG, Hollway JA, McDougle CJ, et al. Cognitive effects of risperidone in children with autism and irritable behavior. J Child Adolesc Psychopharmacol 2008;18(3):227–36.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Anderson GM, Scahill L, McCracken JT, et al. Effects of short-and long-term risperidone treatment on prolactin levels in children with autism. Biol Psychiatry 2007;61(4):545–50.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Arnold LE, Vitiello B, McDougle C, et al. Parent-defined target symptoms respond to risperidone in RUPP autism study: customer approach to clinical trials. J Am Acad Child Adolesc Psychiatry 2003;42(12):1443–50.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Arnold LE, Farmer C, Kraemer HC, et al. Moderators, mediators, and other predictors of risperidone response in children with autistic disorder and irritability. Journal of Child & Adolescent Psychopharmacology. 2010; 20(2), 83–93.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Lindsay RL, Eugene AL, Aman MG, et al. Dietary status and impact of risperidone on nutritional balance in children with autism: a pilot study. J Intellect Dev Disabil 2006;31(4):204–9.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Martin A, Scahill L, Anderson GM, et al. Weight and leptin changes among risperidone-treated youths with autism: 6-month prospective data. Am J Psychiatry 2004;161(6):1125–7.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | McDougle CJ, Scahill L, Aman MG, et al. Risperidone for the core symptom domains of autism: results from the study by the autism network of the research units on pediatric psychopharmacology. Am J Psychiatry 2005;162(6):1142–8.
McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002;347(5):314–21. | Scahill L, McCracken J, McDougle CJ, et al. Methodological issues in designing a multisite trial of risperidone in children and adolescents with autism. J Child Adolesc Psychopharmacol 2001;11(4):377–88.
Mcgorry PD, Nelson B, Phillips LJ, et al. Randomized controlled trial of interventions for young people at ultra-high risk of psychosis: Twelve-month outcome. Journal of Clinical Psychiatry. 2013 Apr;74(4):349–56. PMID: 23218022. | Phillips LJ, Nelson B, Yuen HP, et al. Randomized controlled trial of interventions for young people at ultra-high risk of psychosis: study design and baseline characteristics. Australian & New Zealand Journal of Psychiatry. 2009; 43(9), 818–829.
| Yung AR, Phillips LJ, Nelson B, et al. Randomized controlled trial of interventions for young people at ultra high risk for psychosis: 6-month analysis. Journal of Clinical Psychiatry. 2011; 72(4), 430–440.
Miral S, Gencer O, Inal-Emiroglu FN, et al. Risperidone versus haloperidol in children and adolescents with AD: a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry 2008;17(1):1–8. | Gencer O, Inal-Emiroglu FN, Miral S, et al. Comparison of long-term efficacy and safety of risperidone and haloperidol in children and adolescents with autistic disorder. An open label maintenance study. Eur Child Adolesc Psychiatry 2008;17(4):217–25.
Owen R, Sikich L, Marcus RN, et al. Aripiprazole in the treatment of irritability in children and adolescents with autistic disorder. Pediatrics. 2009;124(6):1533–40. PMID: 19948625. | Robb AS, Andersson C, Bellocchio EE, et al. Safety and tolerability of aripiprazole in the treatment of irritability associated with autistic disorder in pediatric subjects (6–17 years old):results from a pooled analysis of 2 studies. The Primary Care Companion to CNS Disorders. 2011; 13(1).
Owen R, Sikich L, Marcus RN, et al. Aripiprazole in the treatment of irritability in children and adolescents with autistic disorder. Pediatrics. 2009;124(6):1533–40. PMID: 19948625. | Varni JW, Handen BL, Corey-Lisle PK, et al. Effect of aripiprazole 2 to 15 mg/d on health-related quality of life in the treatment of irritability associated with autistic disorder in children: a post hoc analysis of two controlled trials. Clinical Therapeutics. 2012; 34(4), 980–992.
Ratzoni G, Gothelf D, Brand-Gothelf A, et al. Weight gain associated with olanzapine and risperidone in adolescent patients: a comparative prospective study. Journal of the J Am Acad Child Adolesc Psychiatry 2002;41(3):337–43. | Gothelf D, Apter A, Reidman J, et al. Olanzapine, risperidone and haloperidol in the treatment of adolescent patients with schizophrenia. J Neural Transm 2003;110(5):545–60.
Research Units on Pediatric Psychopharmacology Autism Network. Risperidone treatment of autistic disorder: longer-term benefits and blinded discontinuation after 6 months. Am J Psychiatry 2005;162(7):1361–9. | Aman MG, Arnold LE, McDougle CJ, et al. Acute and long-term safety and tolerability of risperidone in children with autism. J Child Adolesc Psychopharmacol 2005;15(6):869–84.
Reyes M, Buitelaar J, Toren P, et al. A randomized, double-blind, placebo-controlled study of risperidone maintenance treatment in children and adolescents with disruptive behavior disorders. Am J Psychiatry 2006;163(3):402–10. | Haas M, Karcher K, Pandina GJ. Treating disruptive behavior disorders with risperidone: a 1-year, open-label safety study in children and adolescents. J Child Adolesc Psychopharmacol 2008;18(4):337–46.
| Pandina GJ, Zhu Y, Cornblatt B. Cognitive function with long-term risperidone in children and adolescents with disruptive behavior disorder. Journal of Child & Adolescent Psychopharmacology. 2009; 19(6), 749–756.
Sallee FR, Sethuraman G, Rock CM. Effects of pimozide on cognition in children with Tourette syndrome: interaction with comorbid attention deficit hyperactivity disorder. Acta Psychiatr Scand 1994;90(1):4–9. | Sallee FR, Rock CM, Head LA. Cognitive effects of neuroleptic use in children with Tourette syndrome. In: Richardson, Mary Ann, editors: Use of neuroleptics in children. Washington, DC; 1996. p.171–184.
Sallee FR, Nesbitt L, Jackson C, et al. Relative efficacy of haloperidol and pimozide in children and adolescents with Tourette disorder. Am J Psychiatry 1997;154(8):1057–62. | Sallee FR, Dougherty D, Sethuraman G, et al. Prolactin monitoring of haloperidol and pimozide treatment in children with Tourette syndrome. Biol Psychiatry 1996;40(10):1044–50.
Sallee FR, Kurlan R, Goetz CG, et al. Ziprasidone treatment of children and adolescents with Tourette syndrome: a pilot study. J Am Acad Child Adolesc Psychiatry 2000;39(3):292–9. | Chappell P, Sallee F. The tolerability and efficacy of ziprasidone in the treatment of children and adolescents with Tourette syndrome. 9th Congress of the Association of European Psychiatrists; Copenhagen; 1998.
Shea S, Turgay A, Carroll A, et al. Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatrics 2004;114(5):e634–41. | Pandina GJ, Bossie CA, Youssef E, et al. Risperidone improves behavioral symptoms in children with autism in a randomized, double-blind, placebo-controlled trial. J Autism Dev Disord 2007;37(2):367–73.
Sikich L, Frazier JA, McClellan J, et al. Double-blind comparison of first- and second-generation antipsychotics in early-onset schizophrenia and schizo-affective disorder: findings from the treatment of early-onset schizophrenia spectrum disorders (TEOSS) study. Am J Psychiatry 2008;165(11):1420–31. | Findling RL, Johnson JL, McClellan J, et al. Double-blind maintenance safety and effectiveness findings from the Treatment of Early-Onset Schizophrenia Spectrum (TEOSS) Study. J Am Acad Child Adolesc Psychiatry 2010;49(6):583–94.
| Frazier JA, McClellan J, Findling RL, et al. Treatment of early-onset schizophrenia spectrum disorders (TEOSS): demographic and clinical characteristics. J Am Acad Child Adolesc Psychiatry 2007;46(8):979–88.
| McClellan J, Sikich L, Findling RL, et al. Treatment of early-onset schizophrenia spectrum disorders (TEOSS): rationale, design, and methods. J Am Acad Child Adolesc Psychiatry 2007;46(8):969–78.
Singh J, Robb A, Vijapurkar, U, et al. A randomized, double-blind study of paliperidone extended-release in treatment of acute schizophrenia in adolescents. Biol Psychiatry. 2011; 70(12): 1179–1187. | Center for Drug Evaluation and Research. Johnson and Johnson. NDA# 022264. February 2009. http://www.accessdata.fda.gov.
Snyder R, Turgay A, Aman M, et al. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry 2002;41(9):1026–36. | Turgay A, Binder C, Snyder R, et al. Long-term safety and efficacy of risperidone for the treatment of disruptive behavior disorders in children with subaverage IQs. Pediatrics 2002;110(3):e34–46.
Snyder R, Turgay A, Aman M, et al. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry 2002;41(9):1026–36. | Turgay A. Risperidone in children with disruptive behavior disorder and ADHD. 155th Annual Meeting of the American Psychiatric Association; 2002.
Spencer EK, Campbell M. Children with schizophrenia: diagnosis, phenomenology, and pharmacotherapy. Schizophr Bull 1994;20(4):713–25. | Spencer EK, Kafantaris V, Padron-Gayol MV, et al. Haloperidol in schizophrenic children: early findings from a study in progress. Psychopharmacol Bull 1992;28(2):183–6.
Spencer EK, Campbell M. Children with schizophrenia: diagnosis, phenomenology, and pharmacotherapy. Schizophr Bull 1994;20(4):713–25. | Spencer EK, Alpert M, Pouget ER. Scales for the assessment of neuroleptic response in schizophrenic children: specific measures derived from the CPRS. Psychopharmacol Bull 1994;30(2):199–202.
Spencer EK, Campbell M. Children with schizophrenia: diagnosis, phenomenology, and pharmacotherapy. Schizophr Bull 1994;20(4):713–25. | Spencer EK, Kafantaris V, Padron-Gayol MV, et al. Haloperidol in hospitalized schizophrenic children. In: Richardson, Mary Ann, editors: Use of neuroleptics in children. Washington, DC; 1996. p. 67–83.
Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry 2007;164(10):1547–56. | Olsen BT, Ganocy SJ, Bitter SM, et al. Health-related quality of life as measured by the child health questionnaire in adolescents with bipolar disorder treated with olanzapine. Comprehensive Psychiatry. 2012; 53(7), 1000–1005.
Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry 2007;164(10):1547–56. | Robertson-Plouch C. Olanzapine useful in adolescent mania. Academy of Adolescent and Child Psychiatry 2006;31(12):727.
Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry 2007;164(10):1547–56. | Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine in the treatment of acute mania in adolescents with bipolar I disorder: a 3-week randomized double-blind placebo-controlled study. Neuropsychopharmacol 2005;7:S176.
Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry 2007;164(10):1547–56. | Center for Drug Evaluation and Research. Eli Lilly and Company. NDA# 020592. July 2008. http://www.accessdata.fda.gov.
Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry 2007;164(10):1547–56. | Olanzapine versus placebo in the treatment of mania in Adolescents with bipolar 1 disorder. Clinical Study Summary: Study F1D-MC-HGIU, Summary ID# 4360. 1–46. Eli Lilly and co.; February 2007. Available at http://www.lillytrials.com/results/Zyprexa.pdf.
Troost PW, Lahuis BE, Steenhuis MP, et al. Long-term effects of risperidone in children with autism spectrum disorders: a placebo discontinuation study. J Am Acad Child Adolesc Psychiatry 2005;44(11):1137–44. | Troost PW, Althaus M, Lahuis BE, et al. Neuropsychological effects of risperidone in children with pervasive developmental disorders: a blinded discontinuation study. J Child Adolesc Psychopharmacol 2006;16(5):561–73.
van Bruggen J, Tijssen J, Dingemans P, et al. Symptom response and side-effects of olanzapine and risperidone in young adults with recent onset schizophrenia. Int Clin Psychopharmacol 2003;18(6):341–6. | Lavalaye J, Linszen DH, Booij J, et al. Dopamine D2 receptor occupancy by olanzapine or risperidone in young patients with schizophrenia. Psychiatry Res 1999;92(1):33–44.
Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry 2003;54(4):453–64. | Hawkins KA, Keefe RS, Christensen BK, et al. Neuropsychological course in the prodrome and first episode of psychosis: findings from the PRIME North America Double Blind Treatment Study. Schizophr Res 2008;105(1–3):1–9.
Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry 2003;54(4):453–64. | Keefe RS, Perkins DO, Gu H, et al. A longitudinal study of neurocognitive function in individuals at-risk for psychosis. Schizophr Res 2006;88(1–3):26–35.
Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry 2003;54(4):453–64. | McGlashan TH, Zipursky RB, Perkins D, et al. The PRIME North America randomized double-blind clinical trial of olanzapine versus placebo in patients at risk of being prodromally symptomatic for psychosis: study rationale and design. Schizophr Res 2003;61(1):7–18.
Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry 2003;54(4):453–64. | McGlashan TH, Zipursky RB, Perkins D, et al. Randomized, double-blind trial of olanzapine versus placebo in patients prodromally symptomatic for psychosis. Am J Psychiatry 2006;(5):790–9.
Woods SW, Breier A, Zipursky RB, et al. Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry 2003;54(4):453–64. | Miller TJ, Zipursky RB, Perkins D, et al. The PRIME North America randomized double-blind clinical trial of olanzapine versus placebo in patients at risk of being prodromally symptomatic for psychosis: baseline characteristics of the “prodromal” sample. Schizophr Res 2003;61(1):19–30.