# Appendix D Study Characteristics

Table D1 Study characteristics

## References

1 Aman MG, Marks RE, Turbott SH, . Clinical effects of methylphenidate and thioridazine in intellectually subaverage children. J Am Acad Child Adolesc Psychiatry. 1991;30(2):246–56. PMID: 2016229.2016229
2 Aman MG, De SG, Derivan A, . Double-blind, placebo-controlled study of risperidone for the treatment of disruptive behaviors in children with subaverage intelligence. Am J Psychiatry. 2002;159(8):1337–46. PMID: 12153826.12153826
3 Aman MG, Hollway JA, Leone S, . Effects of risperidone on cognitive-motor performance and motor movements in chronically medicated children. Res Dev Disabil. 2009;30(2):386–96. PMID: 18768293.18768293
4 Aman MG, Bukstein OG, Gadow KD, . What does risperidone add to parent training and stimulant for severe aggression in child attention-deficit/hyperactivity disorder? J Am Acad Child Adolesc Psychiatry. 2014;53(1):47–60.e1. PMID: 24342385.24342385
5 Anderson LT, Campbell M, Adams P, . The effects of haloperidol on discrimination learning and behavioral symptoms in autistic children. J Autism Dev Disord. 1989;19(2):227–39. PMID: 2663834.2663834
6 Arango C, Robles O, Parellada M, . Olanzapine compared to quetiapine in adolescents with a first psychotic episode. Eur Child Adolesc Psychiatry. 2009;18(7):418–28. PMID: 19198920.19198920
7 Armenteros JL Lewis JE, Davalos M. Risperidone augmentation for treatment-resistant aggression in attention-deficit/hyperactivity disorder: a placebo-controlled pilot study. J Am Acad Child Adolesc Psychiatry 2007(5):558–65. PMID: 17450046.17450046
8 Berger GE, Proffitt TM, Mcconchie M, . Dosing quetiapine in drug-naive first-episode psychosis: a controlled, double-blind, randomized, single-center study investigating efficacy, tolerability, and safety of 200 mg/day vs. 400 mg/day of quetiapine fumarate in 141 patients aged 15 to 25 years. J Clin Psychiatry. 2008;69(11):1702–14. PMID: 19036233.19036233
9 Biederman J, Mick E, Hammerness P, . Open-label, 8-week trial of olanzapine and risperidone for the treatment of bipolar disorder in preschool-age children. Biol Psychiatry. 2005;58(7):589–94. PMID: 16239162.16239162
10 Bruggeman R, Van Der LC, Buitelaar JK, . Risperidone versus pimozide in tourette’s disorder: a comparative double-blind parallel-group study. J Clin Psychiatry. 2001;62(1):50–6. PMID: 11235929.11235929
11 Buchsbaum MS, Haznedar MM, Aronowitz J, . FDG-PET in never-previously medicated psychotic adolescents treated with olanzapine or haloperidol. Schizophr Res. 2007;94(1–3):293–305. PMID: 17574821.17574821
12 Buitelaar JK, Van Der Gaag RJ, Cohen-Kettenis P, . A randomized controlled trial of risperidone in the treatment of aggression in hospitalized adolescents with subaverage cognitive abilities. J Clin Psychiatry. 2001;62(4):239–48. PMID: 11379837.11379837
13 Connor DF, Mclaughlin TJ, Jeffers-Terry M. Randomized controlled pilot study of quetiapine in the treatment of adolescent conduct disorder. J Child Adolesc Psychopharmacol. 2008;18(2):140–56. PMID: 18439112.18439112
14 Conus P, Berk M, Cotton SM, . Olanzapine or chlorpromazine plus lithium in first episode psychotic mania: An 8-week randomised controlled trial. Eur Psychiatry. 2015;30(8):975–82. PMID: 26485297.26485297
15 Crocq MA, Guillon MS, Bailey PE, . Orally disintegrating olanzapine induces less weight gain in adolescents than standard oral tablets. Eur Psychiatry. 2007;22(7):453–4. PMID: 17761403.17761403
16 de Haan L, Van Bruggen M, Lavalaye J, . Subjective experience and d2 receptor occupancy in patients with recent-onset schizophrenia treated with low-dose olanzapine or haloperidol: a randomized, double-blind study. Am J Psychiatry. 2003;160(2):303–9. PMID: 12562577.12562577
17 Delbello MP, Schwiers ML, Rosenberg HL, . A double-blind, randomized, placebo-controlled study of quetiapine as adjunctive treatment for adolescent mania. J Am Acad Child Adoles Psychiatry. 2002;41(10):1216–23. PMID: 12364843.12364843
18 Delbello MP, Versavel M, Ice K, . Tolerability of oral ziprasidone in children and adolescents with bipolar mania, schizophrenia, or schizoaffective disorder. J Child Adolesc Psychopharmacol. 2008;18(5):491–9. PMID: 18928413.18928413
19 Delbello MP, Chang K, Welge JA, . A double-blind, placebo-controlled pilot study of quetiapine for depressed adolescents with bipolar disorder. Bipolar Disord. 2009;11(5):483–93. PMID: 19624387.19624387
20 Findling RL, Mcnamara NK, Branicky LA, . A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry. 2000;39(4):509–16. PMID: 10761354.10761354
21 Findling RL, Robb A, Nyilas M, . A multiple-center, randomized, double-blind, placebo-controlled study of oral aripiprazole for treatment of adolescents with schizophrenia. Am J Psychiatry. 2008a;165(11):1432–41. PMID: 18765484.18765484
22 Findling RL, Nyilas M, Forbes RA, . Acute treatment of pediatric bipolar I disorder, manic or mixed episode, with aripiprazole: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2009;70(10):1441–51. PMID: 19906348.19906348
23 Findling RL, Mckenna K, Earley WR, . Efficacy and safety of quetiapine in adolescents with schizophrenia investigated in a 6-week, double-blind, placebo-controlled trial. J Child Adolesc Psychopharmacol. 2012a Oct;22(5):327–42. PMID: 23083020.23083020
24 Findling RL, Youngstrom EA, Mcnamara NK, . Double-blind, randomized, placebo-controlled long-term maintenance study of aripiprazole in children with bipolar disorder. J Clin Psychiatry. 2012b;73(1):57–63. PMID: 22152402.22152402
25 Findling RL, Cavus I, Pappadopulos E, . Ziprasidone in adolescents with schizophrenia: Results from a placebo-controlled efficacy and long-term open-extension study. J Child Adolesc Psychopharmacol. 2013a;23(8):531–44. PMID: 24111983.24111983
26 Findling RL, Cavus I, Pappadopulos E, . Efficacy, long-term safety, and tolerability of ziprasidone in children and adolescents with bipolar disorder. J Child Adolesc Psychopharmacol. 2013b;23(8):545–57. PMID: 24111980.24111980
27 Findling RL, Pathak S, Earley WR, . Efficacy and safety of extended-release quetiapine fumarate in youth with bipolar depression: an 8 week, double-blind, placebo-controlled trial. J Child Adoles Psychopharmacol. 2014b;24(6):325–35. PMID: 24956042.24956042
28 Findling RL, Mankoski R, Timko K, . A randomized controlled trial investigating the safety and efficacy of aripiprazole in the long-term maintenance treatment of pediatric patients with irritability associated with autistic disorder. J Clin Psychiatry. 2014b;75(1):22–30. PMID: 24502859.24502859
29 Findling RL, Landbloom RP, Mackle M, . Safety and efficacy from an 8 week double-blind trial and a 26 week open-label extension of asenapine in adolescents with schizophrenia. J Child Adolesc Psychopharmacol. 2015a;25(5):384–96. PMID: 26091193.26091193
30 Findling RL, Landbloom RL, Szegedi A, . Asenapine for the acute treatment of pediatric manic or mixed episode of bipolar I disorder. J Am Acad Child Adolesc Psychiatry. 2015b;54(12):1032–41. PMID: 26598478.26598478
31 Findling RL, Goldman R, Chiu YY, . Pharmacokinetics and tolerability of lurasidone in children and adolescents with psychiatric disorders. Clin Ther. 2015;37(12):2788–97. PMID: 26631428.26631428
32 Ghanizadeh A, Sahraeizadeh A, Berk M. A head-to-head comparison of aripiprazole and risperidone for safety and treating autistic disorders, a randomized double blind clinical trial. Child Psychiatry Hum Dev. 2014a;45(2):185–92. PMID: 23801256.23801256
33 Ghanizadeh A, Haghighi A. Aripiprazole versus risperidone for treating children and adolescents with tic disorder: a randomized double blind clinical trial. Child Psychiatry Hum Dev. 2014b;45(5):596–603. PMID: 24343476.24343476
34 Gilbert DL, Batterson JR, Sethuraman G, . Tic reduction with risperidone versus pimozide in a randomized, double-blind, crossover trial. J Am Acad Child Adolesc Psychiatry. 2004;43(2):206–14. PMID: 14726728.14726728
35 Gulisano M, Cali PV, Cavanna AE, . Cardiovascular safety of aripiprazole and pimozide in young patients with tourette syndrome. Neurol Sci. 2011;32(6):1213–7. PMID: 21732066.21732066
36 Haas M, Eerdekens M, Kushner S, . Efficacy, safety and tolerability of two dosing regimens in adolescent schizophrenia: double-blind study. Br J Psychiatry. 2009a;194(2):158–64. PMID: 19182179.19182179
37 Haas M, Unis AS, Armenteros J, . A 6-week, randomized, double-blind, placebo-controlled study of the efficacy and safety of risperidone in adolescents with schizophrenia. J Child AdolescPsychopharmacol. 2009b;19(6):611–21. PMID: 20035579.20035579
38 Haas M, Delbello MP, Pandina G, . Risperidone for the treatment of acute mania in children and adolescents with bipolar disorder: a randomized, double-blind, placebo-controlled study. Bipolar Disord. 2009c;11(7):687–700. PMID: 19839994.19839994
39 Hagman J, Gralla J, Sigel E, . A double-blind, placebo-controlled study of risperidone for the treatment of adolescents and young adults with anorexia nervosa: a pilot study. J Am Acad Child Adolesc Psychiatry. 2011;50(9):915–24. PMID: 21871373.21871373
40 Hellings JA, Zarcone JR, Reese RM, . A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord. 2006;36(3):401–11. PMID: 16596465.16596465
41 Hollander E, Wasserman S, Swanson EN, . A double-blind placebo-controlled pilot study of olanzapine in childhood/adolescent pervasive developmental disorder. J Child Adolesc Psychopharmacol. 2006;16(5):541–8. PMID: 17069543.17069543
42 Jensen JB, Kumra S, Leitten W, . A comparative pilot study of second-generation antipsychotics in children and adolescents with schizophrenia-spectrum disorders. J Child Adolesc Psychopharmacol. 2008;18(4):317–26. PMID: 18759641.18759641
43 Johnson & Johnson Pharmaceutical Research & Development. Open-label study to evaluate the safety and pharmacokinetics of single- and multiple-dose extended-release paliperidone in pediatric subjects (10 to 17 years of age) with schizophrenia, schizoaffective disorder, or schizophreniform disorder. 2011. http://filehosting.pharmacm.com/DownloadService.ashx?client=CTR_JNJ_6051&studyid=473&filename=CR002371_CSR.pdf. Accessed September 28, 2015.
44 Kafantaris V, Leigh E, Hertz S, . A placebo-controlled pilot study of adjunctive olanzapine for adolescents with anorexia nervosa. J Child Adolesc Psychopharmacol. 2011;21(3):207–12. PMID: 21663423.21663423
45 Kent JM, Kushner S, Ning X, . Risperidone dosing in children and adolescents with autistic disorder: a double-blind, placebo-controlled study. J Autism Dev Disord. 2013;43(8):1773–83. PMID: 23212807.23212807
46 Kowatch RA, Scheffer RE, Monroe E, . Placebo-controlled trial of valproic acid versus risperidone in children 3–7 years of age with bipolar I disorder. J Child Adolesc Psychopharmacol. 2015;25(4):306–13. PMID: 25978742.25978742
47 Kryzhanovskaya L, Schulz SC, Mcdougle C, . Olanzapine versus placebo in adolescents with schizophrenia: a 6-week, randomized, double-blind, placebo-controlled trial. J Am Acad Child Adolesc Psychiatry. 2009;48(1):60–70. PMID: 19057413.19057413
48 Kumra S, Frazier JA, Jacobsen LK, . Childhood-onset schizophrenia. A double-blind clozapine-haloperidol comparison. Arch Gen Psychiatry. 1996;53(12):1090–7. PMID: 8956674.8956674
49 Kumra S, Kranzler H, Gerbino-Rosen G, . Clozapine and “high-dose” olanzapine in refractory early-onset schizophrenia: a 12-week randomized and double-blind comparison. Biol Psychiatry. 2008;63(5):524–9. PMID: 17651705.17651705
50 Loebel A, Brams M, Goldman RS, . Lurasidone for the treatment of irritability associated with austistic disorder. J Autism Dev Disord. 2016:46(4):1153–63. PMID: 26659550.26659550
51 Luby J, Mrakotsky C, Stalets MM, . Risperidone in preschool children with autistic spectrum disorders: an investigation of safety and efficacy. J Child Adoles Psychopharmacol. 2006;16(5):575–87. PMID: 17069546.17069546
52 Malone RP, Cater J, Sheikh RM, . Olanzapine versus haloperidol in children with autistic disorder: an open pilot study. J Am Acad Child Adolesc Psychiatry. 2001;40(8):887–94. PMID: 11501687.11501687
53 Marcus RN, Owen R, Kamen L, . A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry. 2009;48(11):1110–9. PMID: 19797985.19797985
54 Masi G, Pfanner C, Brovedani P. Antipsychotic augmentation of selective serotonin reuptake inhibitors in resistant tic-related obsessive-compulsive disorder in children and adolescents: a naturalistic comparative study. J Psychiatr Res. 2013;47(8):1007–12. PMID: 23664673.23664673
55 Masi G, Milone A, Stawinoga A, . Efficacy and safety of risperidone and quetiapine in adolescents with bipolar II disorder comorbid with conduct disorder. J Clin Psychopharmacol. 2015;35(5):587–90. PMID: 26226481.26226481
56 Mccracken JT, Mcgough J, Shah B, . Risperidone in children with autism and serious behavioral problems. N Engl J Med. 2002;347(5):314–21. PMID: 12151468.12151468
57 Mcgorry PD, Nelson B, Phillips LJ, . Randomized controlled trial of interventions for young people at ultra-high risk of psychosis: twelve-month outcome. J Clin Psychiatry. 2013;74(4):349–56. PMID: 23218022.23218022
58 Miral S, Gencer O, Inal-Emiroglu FN, . Risperidone versus haloperidol in children and adolescents with ad: a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry. 2008;17(1):1–8. PMID: 18080171.18080171
59 Mozes T, Ebert T, Michal SE, . An open-label randomized comparison of olanzapine versus risperidone in the treatment of childhood-onset schizophrenia. J Child Adolesc Psychopharmacol. 2006;16(4):393–403. PMID: 16958565.16958565
60 Nagaraj R, Singhi P, Malhi P. Risperidone in children with autism: randomized, placebo-controlled, double-blind study. J Child Neurol. 2006;21(6):450–5. PMID: 16948927.16948927
61 NCT00194012. Study of aripiprazole (abilify) versus placebo in children with subsyndromal bipolar disorder. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2013. [cited: 2016 Apr 13]. https://clinicaltrials.gov/ct2/show/NCT00194012. NLM Identifier: NCT00194012.
62 NCT01149655. Efficacy & safety study of oral aripiprazole in adolescents with schizophrenia. 2014. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2013. [cited: 2016 Apr 13]. https://clinicaltrials.gov/ct2/show/NCT01149655. NML Identifier: NCT01149655.
63 Omranifard V, Najafi M, Sharbafchi MR, . Risperidone as a treatment for childhood habitual behavior. J Res Pharm Pract. 2013;2(1):29–33. PMID: 24991601.24991601
64 Owen R, Sikich L, Marcus RN, . Aripiprazole in the treatment of irritability in children and adolescents with autistic disorder. Pediatrics. 2009;124(6):1533–40. PMID: 19948625.19948625
65 Pathak S., Findling RL, Earley WR, . Efficacy and safety of quetiapine in children and adolescents with mania associated with bipolar I disorder: a 3-week, double-blind, placebo-controlled trial. J Clin Psychiatry. 2013;74(1):e100–9. PMID: 23419231.23419231
66 Perry R, Campbell M, Adams P, . Long-term efficacy of haloperidol in autistic children: continuous versus discontinuous drug administration. J Am Acad Child Adolesc Psychiatry. 1989;28(1):87–92. PMID: 2914841.2914841
67 Remington G, Sloman L, Konstantareas M, . Clomipramine versus haloperidol in the treatment of autistic disorder: a double-blind, placebo-controlled, crossover study. J Clin Psychopharmacol. 2001;21(4):440–4. PMID: 11476129.11476129
68 Reyes M, Buitelaar J, Toren P, . A randomized, double-blind, placebo-controlled study of risperidone maintenance treatment in children and adolescents with disruptive behavior disorders. Am J Psychiatry. 2006;163(3):402–10. PMID: 16513860.16513860
69 Rizzo R, Eddy CM, Cali P, . Metabolic effects of aripiprazole and pimozide in children with tourette syndrome. Pediatr Neurol. 2012;47(6):419–22. PMID: 23127261.23127261
70 Research Units on Pediatric Psychopharmacology Autism N. Risperidone treatment of autistic disorder: Longer-term benefits and blinded discontinuation after 6 months. Am J Psychiatry. 2005;162(7):1361–9. PMID: 15994720.15994720
71 Sallee FR, Sethuraman G, Rock CM. Effects of pimozide on cognition in children with tourette syndrome: Interaction with comorbid attention deficit hyperactivity disorder. Acta Psychiatr Scand. 1994;90(1):4–9. PMID: 7976448.7976448
72 Sallee FR, Nesbitt L, Jackson C, . Relative efficacy of haloperidol and pimozide in children and adolescents with tourette’s disorder. Am J Psychiatry. 1997;154(8):1057–62. PMID: 9247389.9247389
73 Sallee FR, Kurlan R, Goetz CG, . Ziprasidone treatment of children and adolescents with tourette’s syndrome: a pilot study. J Am Acad Child Adolesc Psychiatry. 2000;39(3):292–9. PMID: 10714048.10714048
74 Savitz AJ, Lane R, Nuamah I, . Efficacy and safety of paliperidone extended release in adolescents with schizophrenia: a randomized, double-blind study. J Am Acad Child Adolesc Psychiatry. 2015;54(2):126–37.e1. PMID: 25617253.25617253
75 Scahill L, Leckman JF, Schultz RT, . A placebo-controlled trial of risperidone in tourette syndrome. Neurology. 2003;60(7):1130–5. PMID: 12682319.12682319
76 Schneider MR, Adler CM, Whitsel R, . The effects of ziprasidone on prefrontal and amygdalar activation in manic youth with bipolar disorder. Isr J Psychiatry Relat Sci. 2012;49(2):112–20. PMID: 22801290.22801290
77 Sehgal N. Short-term versus longer term pimozide therapy in tourette’s syndrome: a preliminary study. Neurology. 1999;52(4):874–7. PMID: 10078748.10078748
78 Shaw P, Sporn A, Gogtay N, . Childhood-onset schizophrenia: a double-blind, randomized clozapine-olanzapine comparison. Arch Gen Psychiatry. 2006;63(7):721–30. PMID: 16818861.16818861
79 Shea S, Turgay A, Carroll A, . Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatrics. 2004;114(5):e634–e41. PMID: 15492353.15492353
80 Sikich L, Hamer RM, Bashford RA, . A pilot study of risperidone, olanzapine, and haloperidol in psychotic youth: a double-blind, randomized, 8-week trial. Neuropsychopharmacology. 2004;29(1):133–45. PMID: 14583740.14583740
81 Sikich L, Frazier JA, Mcclellan J, . Double-blind comparison of first- and second-generation antipsychotics in early-onset schizophrenia and schizo-affective disorder: findings from the treatment of early-onset schizophrenia spectrum disorders (teoss) study. Am J Psychiatry. 2008;165(11):1420–31. PMID: 18794207.18794207
82 Singh J, Robb A, Vijapurkar U, . A randomized, double-blind study of paliperidone extended-release in treatment of acute schizophrenia in adolescents. Biol Psychiatry. 2011 Dec 15;70(12):1179–87. PMID: 21831359.21831359
83 Snyder R, Turgay A, Aman M, . Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage iqs. J Am Acad Child Adolesc Psychiatry. 2002;41(9):1026–36. PMID: 12218423.12218423
84 Spencer EK, Campbell M. Children with schizophrenia: Diagnosis, phenomenology, and pharmacotherapy. Schizophr Bull. 1994;20(4):713–25. PMID: 7701278.7701278
85 Stocks JD, Taneja BK, Baroldi P, . A phase 2a randomized, parallel group, dose-ranging study of molindone in children with attention-deficit/hyperactivity disorder and persistent, serious conduct problems. J Child Adolesc Psychopharmacol. 2012;22(2):102–11. PMID: 22372512.22372512
86 Swadi HS, Craig BJ, Pirwani NZ, . A trial of quetiapine compared with risperidone in the treatment of first onset psychosis among 15-to 18-year-old adolescents. Int Clin Psychopharmacol. 2010;25(1):1–6. PMID: 19809337.19809337
87 Tohen M, Kryzhanovskaya L, Carlson G, . Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry. 2007;164(10):1547–56. PMID: 17898346.17898346
88 Tramontina S, Zeni CP, Ketzer CR, . Aripiprazole in children and adolescents with bipolar disorder comorbid with attention-deficit/hyperactivity disorder: a pilot randomized clinical trial. J Clin Psychiatry. 2009;70(5):756–64. PMID: 19389329.19389329
89 Troost PW, Lahuis BE, Steenhuis MP, . Long-term effects of risperidone in children with autism spectrum disorders: a placebo discontinuation study. J Am Acad Child Adolesc Psychiatry. 2005;44(11):1137–44. PMID: 16239862.16239862
90 Van Bellinghen M, De Troch C. Risperidone in the treatment of behavioral disturbances in children and adolescents with borderline intellectual functioning: a double-blind, placebo-controlled pilot trial. J Child Adolesc Psychopharmacol. 2001;11(1):5–13. PMID: 11322745.11322745
91 Van Bruggen J, Tijssen J, Dingemans P, . Symptom response and side-effects of olanzapine and risperidone in young adults with recent onset schizophrenia. Int Clin Psychopharmacol. 2003;18(6):341–6. PMID: 14571154.14571154
92 Woods SW, Breier A, Zipursky RB, . Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry. 2003;54(4):453–64. PMID: 12915290.12915290
93 Yen YC, Lung F-W, Chong MY. Adverse effects of risperidone and haloperidol treatment in schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2004;28(2):285–90. PMID: 14751424.14751424
94 Yoo HK, Lee JS, Paik KW, . Open-label study comparing the efficacy and tolerability of aripiprazole and haloperidol in the treatment of pediatric tic disorders. Eur Child Adolesc Psychiatry. 2011;20(3):127–35. PMID: 21188439.21188439
95 Yoo HK, Joung YS, Lee JS, . A multicenter, randomized, double-blind, placebo-controlled study of aripiprazole in children and adolescents with tourette’s disorder. J Clin Psychiatry. 2013;74(8):e772–80. PMID: 24021518.24021518
96 Alacqua M, Trifiro G, Arcoraci V, . Use and tolerability of newer antipsychotics and antidepressants: a chart review in a paediatric setting. Pharm World Sci. 2008;30(1):44–50. PMID: 17588130.17588130
97 Aman MG, Binder C, Turgay A. Risperidone effects in the presence/absence of psychostimulant medicine in children with adhd, other disruptive behavior disorders, and subaverage IQ. J Child Adolesc Psychopharmacol. 2004;14(2):243–54. PMID: 15319021.15319021
98 Arango C, Giraldez M, Merchan-Naranjo J, . Second-generation antipsychotic use in children and adolescents: A six-month prospective cohort study in drug-naive patients. J Am Acad Child Adolesc Psychiatry. 2014;53(11):1179–90,90.e1–4. PMID: 25440308.25440308
99 Bastiaens L. A non-randomized, open study with aripiprazole and ziprasidone for the treatment of aggressive behavior in youth in a community clinic. Community Men Health J. 2009;45(1);73–7. PMID: 18597173.18597173
100 Bobo WV, Cooper WO, Stein CM, . Antipsychotics and the risk of type 2 diabetes mellitus in children and youth. JAMA Psychiatry. 2013;70(10):1067–75. PMID: 23965896.23965896
101 Calarge CA, Nicol G, Schlechte JA, . Cardiometabolic outcomes in children and adolescents following discontinuation of long-term risperidone treatment. J Child Adolesc Psychopharmacol. 2014;24(3):120–9. PMID: 24725198.24725198
102 Castro-Fornieles J, Parellada M, Soutullo CA, . Antipsychotic treatment in child and adolescent first-episode psychosis: a longitudinal naturalistic approach. J Child Adolesc Psychopharmacol. 2008;18(4):327–36. PMID: 18759642.18759642
103 Cianchetti C, Ledda MG. Effectiveness and safety of antipsychotics in early onset psychoses: a long-term comparison. Psychiatry Res. 2011;189(3):349–56. PMID: 21570128.21570128
104 Correll CU, Manu P, Olshanskiy V, . Cardiometabolic risk of second-generation antipsychotic medications during first-time use in children and adolescents. JAMA. 2009;302(16):1765–73. PMID: 19861668.19861668
105 Cuerda C, Merchan-Naranjo J, Velasco C, . Influence of resting energy expenditure on weight gain in adolescents taking second-generation antipsychotics. Clin Nutr. 2011;30(5):616–23. PMID: 21492975.21492975
106 Ebert T, Midbari Y, Shmilovitz R, . Metabolic effects of antipsychotics in prepubertal children: a retrospective chart review. J Child Adolesc Psychopharmacol. 2014;24(4):218–22. PMID: 24816004.24816004
107 Findling RL, Kauffman RE, Sallee FR, . Tolerability and pharmacokinetics of aripiprazole in children and adolescents with psychiatric disorders: an open-label, dose-escalation study. J Clin Psychopharmacol. 2008b;28(4):441–6. PMID: 18626272.18626272
108 Fleischhaker C, Heiser P, Hennighausen K, . Clinical drug monitoring in child and adolescent psychiatry: Side effects of atypical neuroleptics. J Child Adolesc Psychopharmacol. 2006;16(3):308–16. PMID: 16768638.16768638
109 Fraguas D, Merchan-Naranjo J, Laita P, . Metabolic and hormonal side effects in children and adolescents treated with second-generation antipsychotics. J Clin Psychiatry. 2008;69(7):1166–75. PMID: 18588363.18588363
110 Friedlander R, Lazar S, Klancnik J. Atypical antipsychotic use in treating adolescents and young adults with developmental disabilities. Can J Psychiatry. 2001;46(8):741–5. PMID: 11692977.11692977
111 Germano E, Italiano D, Lamberti M, . ECG parameters in children and adolescents treated with aripiprazole and risperidone. Prog Neuropsychopharmacol Biol Psychiatry. 2014;51:23–7. PMID: 24211841.24211841
112 Gothelf D, Falk B, Singer P, . Weight gain associated with increased food intake and low habitual activity levels in male adolescent schizophrenic inpatients treated with olanzapine. Am J Psychiatry. 2002;159(6):1055–7. PMID: 12042200.12042200
113 Hrdlicka M, Zedkova I, Blatny M, . Weight gain associated with atypical and typical antipsychotics during treatment of adolescent schizophrenic psychoses: a retrospective study. Neuroendocrinology Lett. 2009;30(2):256–61. PMID: N/A.
114 Jerrell JM, Mcintyre RS. Adverse events in children and adolescents treated with antipsychotic medications. Hum Psychopharmacol. 2008;23(4):283–90. PMID: 18302312.18302312
115 Khan RA, Mican LM, Suehs BT. Effects of olanzapine and risperidone on metabolic factors in children and adolescents: a retrospective evaluation. J Psychiatr Pract. 2009;15(4):320–8. PMID: 19625888.19625888
116 Khan SS, Mican LM. A naturalistic evaluation of intramuscular ziprasidone versus intramuscular olanzapine for the management of acute agitation and aggression in children and adolescents. J Child Adolesc Psychopharmacol. 2006;16(6):671–7. PMID: 17201611.17201611
117 Kumra S, Jacobsen LK, Lenane M, . Childhood-onset schizophrenia: An open-label study of olanzapine in adolescents. J Am Acad Child Adolesc Psychiatry. 1998;37(4):377–85. PMID: 9549958.9549958
118 Mankoski R, Stockton G, Manos G, . Aripiprazole treatment of irritability associated with autistic disorder and the relationship between prior antipsychotic exposure, adverse events, and weight change. J Child Adolesc Psychopharmacol. 2013;23(8):572–6. PMID: 24138011.24138011
119 Martin A, Landau J, Leebens P, . Risperidone-associated weight gain in children and adolescents: a retrospective chart review. J Child Adolesc Psychopharmacol. 2000;10(4):259–68. PMID: 11191686.11191686
120 Migliardi G, Spina E, D’arrigo C, . Short- and long-term effects on prolactin of risperidone and olanzapine treatments in children and adolescents. Prog Neuropsychopharmacol Biol Psychiatry. 2009;33(8):1496–501. PMID: 19706318.19706318
121 NCT00619190. Study of aripiprazole to treat children and adolescents with autism. 2013. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2013. [cited: 2016 Apr 13]. https://clinicaltrials.gov/ct2/show/NCT00619190. NLM Identifier: NCT00619190.
122 Norris ML, Spettigue W, Buchholz A, . Olanzapine use for the adjunctive treatment of adolescents with anorexia nervosa. J Child Adolesc Psychopharmacol. 2011;21(3):213–20. PMID: 21510781.21510781
123 Novaes CM, Ponde MP, Freire AC. Control of psychomotor agitation and aggressive behavior in patients with autistic disorder: A retrospective chart review. Arq Neuropsiquiatr. 2008;66(3B):646–51. PMID: 18949256.18949256
124 O’donoghue B, Schafer MR, Becker J, . Metabolic changes in first-episode early-onset schizophrenia with second-generation antipsychotics. Early Interv Psychiatry. 2014;8(3):276–80. PMID: 23968390.23968390
125 Oh J, Chang JG, Lee SB, . Comparison of aripiprazole and other atypical antipsychotics for pediatric bipolar disorder: A retrospective chart review of efficacy and tolerability. Clin Psychopharmacol Neurosci. 2013;11(2):72–9. PMID: 24023551.24023551
126 Olfson M, Gerhard T, Huang C, . Comparative effectiveness of second-generation antipsychotic medications in early-onset schizophrenia. Schizophr Bull. 2012;38(4):845–53. PMID: 21307041.21307041
127 Pandina GJ, Bilder R, Harvey PD, . Risperidone and cognitive function in children with disruptive behavior disorders. Biol Psychiatry. 2007;62(3):226–34. PMID: 17210137.17210137
128 Pogge DL, Singer MB, Harvey PD. Rates and predictors of adherence with atypical antipsychotic medication: a follow-up study of adolescent inpatients. J Child Adolesc Psychopharmacol. 2005;15(6):901–12. PMID: 16379510.16379510
129 Ratzoni G, Gothelf D, Brand-Gothelf A, . Weight gain associated with olanzapine and risperidone in adolescent patients: a comparative prospective study. J Am Acad Child Adolesc Psychiatry. 2002;41(3):337–43. PMID: 11886029.11886029
130 Ronsley R, Nguyen D, Davidson J, . Increased risk of obesity and metabolic dysregulation following 12 months of second-generation antipsychotic treatment in children: a prospective cohort study. Can J Psychiatry. 2015;60(10):441–50. PMID: 26720191.26720191
131 Saito E, Correll CU, Gallelli K, . A prospective study of hyperprolactinemia in children and adolescents treated with atypical antipsychotic agents. J Child AdolescPsychopharmacol. 2004;14(3):350–8. PMID: 15650492.15650492
132 Weisler RH, Khan A, Trivedi MH, . Analysis of suicidality in pooled data from 2 double-blind, placebo-controlled aripiprazole adjunctive therapy trials in major depressive disorder. J Clin Psychiatry. 2011;72(4):548–55. PMID: 20816039.20816039
133 Wink LK, Early M, Schaefer T, . Body mass index change in autism spectrum disorders: comparison of treatment with risperidone and aripiprazole. J Child Adolesc Psychopharmacol. 2014;24(2):78–82. PMID: 24564519.24564519
134 Wonodi I, Reeves G, Carmichael D, . Tardive dyskinesia in children treated with atypical antipsychotic medications. Mov Disord. 2007;22(12):1777–82. PMID: 17580328.17580328
135 Wudarsky M, Nicolson R, Hamburger SD, . Elevated prolactin in pediatric patients on typical and atypical antipsychotics. J Child Adolesc