# Appendix C Quality Assessment Ratings

References for Appendix C found at the end of Appendix D.

Table C1 Risk of bias assessments for trials

Author, Year | Sequence Generation | Allocation Concealment | Blinding-PP (Subjective) | Blinding-PP (Objective) | Blinding-OA (Subjective) | Blinding-OA (Objective) | Incomplete Outcome (Subjective) | Incomplete Outcome (Objective) | Other Sources of Bias | Overall (Subjective) | Overall (Objective)
Aman et al., 1991 ^1^ | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Unclear | Unclear
Aman et al., 2002 ^2^ | Yes | Unclear | Yes | Yes | N/A | Unclear | No | No | Yes | High | High
Aman et al., 2009 ^3^ | Yes | Unclear | Yes | Yes | N/A | N/A | Yes | Yes | Yes | Unclear | Unclear
Aman et al., 2014 ^4^ | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear
Anderson et al., 1989 ^5^ | Unclear | Unclear | Yes | Yes | Yes | Yes | No | Yes | Unclear | High | Unclear
Arango et al., 2009 ^6^ | Unclear | Unclear | No | No | No | No | No | No | Yes | High | High
Armenteros et al., 2007 ^7^ | Yes | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear
Berger et al., 2008 ^8^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Low | Low
Biederman et al., 2005 ^9^ | Unclear | Unclear | No | No | Unclear | Unclear | No | No | Yes | High | High
Bruggeman et al., 2001 ^10^ | Yes | Unclear | NA | Yes | NA | Unclear | NA | Yes | Yes | NA | Unclear
Buchsbaum et al., 2007 ^11^ | Unclear | Unclear | Unclear | NA | Unclear | NA | Unclear | NA | Yes | Unclear | NA
Buitelaar et al., 2001 ^12^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear
Connor et al., 2008 ^13^ | Unclear | Yes | Yes | Yes | NA | Yes | No | No | Yes | High | High
Conus et al., 2015 ^14^ | Yes | Unclear | No | No | Yes | Unclear | No | No | Yes | High | High
Crocq et al., 2007 ^15^ | No | No | NA | Yes | NA | Yes | NA | Unclear | Unclear | NA | High
de Haan et al., 2003 ^16^ | Yes | Unclear | Unclear | Unclear | Unclear | Unclear | No | No | Yes | High | High
DelBello et al., 2002 ^17^ | Yes | Yes | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear
DelBello et al., 2008 ^18^ | Unclear | Unclear | No | Unclear | Unclear | Unclear | No | No | Yes | High | High
DelBello et al., 2009 ^19^ | Yes | Yes | Unclear | Unclear | Unclear | Unclear | No | No | Yes | High | High
Findling et al., 2000 ^20^ | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | High | High
Findling et al., 2008a ^21^ | Yes | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear
Findling et al., 2009 ^22^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear
Findling et al., 2012a ^23^ | Yes | Unclear | Yes | Yes | Yes | Yes | No | No | No | High | High
Findling et al., 2012b ^24^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | No | No | No | High | High
Findling et al., 2013a ^25^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | No | No | Unclear | High | High
Findling et al., 2013b ^26^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | No | No | Unclear | High | High
Findling et al., 2014a ^27^ | Yes | Unclear | Unclear | Unclear | Unclear | Unclear | No | No | Yes | High | High
Findling et al., 2014b ^28^ | Unclear | Yes | Unclear | Unclear | Unclear | Unclear | No | No | Yes | High | High
Findling et al., 2015a ^29^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Low | Low
Findling et al., 2015b ^30^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Low | Low
Findling et al., 2015 ^31^ | Yes | Unclear | NA | No | NA | No | NA | Unclear | Yes | NA | High
Ghanizadeh et al., 2014a ^32^ | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear
Ghanizadeh et al., 2014b ^33^ | Yes | Unclear | Unclear | Yes | Yes | Yes | No | No | Unclear | High | High
Gilbert et al., 2004 ^34^ | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | High | High
Gulisano et al., 2011 ^35^ | Unclear | Unclear | NA | Yes | NA | Yes | NA | Yes | Yes | NA | Unclear
Haas et al., 2009a ^36^ | Yes | Unclear | Unclear | Yes | Unclear | Yes | No | No | Yes | High | High
Haas et al., 2009b ^37^ | Yes | Unclear | Unclear | N/A | Unclear | Yes | No | No | Yes | High | High
Haas et al., 2009c ^38^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | No | No | Yes | High | High
Hagman et al., 2011 ^39^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear
Hellings et al., 2006 ^40^ | Unclear | Yes | Unclear | Yes | Unclear | Yes | No | No | No | High | High
Hollander et al., 2006 ^41^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | No | No | Yes | High | High
Jensen et al., 2008 ^42^ | Yes | Unclear | No | Yes | No | Yes | No | No | Yes | High | High
Johnson & Johnson, 2011 ^43^ | Unclear | Unclear | No | No | No | No | Yes | Yes | Yes | High | High
Kafantaris et al., 2011 ^44^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear
Kent et al., 2013 ^45^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear
Kowatch et al., 2015 ^46^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear
Kryzhanovskaya et al., 2009 ^47^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | No | No | Yes | High | High
Kumra et al., 1996 ^48^ | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | High | High
Kumra et al., 2008 ^49^ | Yes | Yes | Unclear | Yes | Unclear | Yes | No | No | Yes | High | High
Loebel et al., 2016 ^50^ | Yes | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear
Luby et al., 2006 ^51^ | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Low
Malone et al., 2001 ^52^ | Yes | Unclear | No | Yes | No | Yes | Yes | Yes | Yes | High | Unclear
Marcus et al., 2009 ^53^ | Yes | Yes | Unclear | Yes | Unclear | Yes | No | No | Yes | High | High
Masi et al., 2013 ^54^ | Unclear | No | No | Yes | No | Yes | Yes | Yes | Yes | High | Unclear
Masi et al., 2015 ^55^ | Unclear | Unclear | No | No | No | No | Yes | Yes | Yes | High | High
McCracken et al., 2002 ^56^ | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear
McGorry et al., 2013 ^57^ | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | High | High
Miral et al., 2008 ^58^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear
Mozes et al., 2006 ^59^ | Unclear | Unclear | No | Yes | No | Yes | No | No | Yes | High | High
Nagaraj et al., 2006 ^60^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Low | Low
NCT00194012, 2013 ^61^ | Unclear | Unclear | Yes | Yes | Yes | Yes | No | No | Yes | High | High
NCT01149655, 2014 ^62^ | Unclear | Unclear | Yes | Yes | Yes | Yes | No | No | No | High | High
Omranifard et al., 2013 ^63^ | Unclear | Unclear | No | NA | No | NA | Yes | NA | Yes | High | NA
Owen et al., 2009 ^64^ | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Low
Pathak et al., 2013 ^65^ | Yes | Yes | Yes | Yes | Unclear | Unclear | No | No | Yes | High | High
Perry et al., 1989 ^66^ | Unclear | Unclear | Yes | Yes | Yes | Yes | No | No | Yes | High | High
Remington et al., 2001 ^67^ | Yes | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | No | High | High
Reyes et al., 2006 ^68^ | Unclear | Unclear | Yes | Yes | Yes | Yes | No | No | Yes | High | High
Rizzo et al., 2012 ^69^ | No | No | No | Yes | No | Yes | Yes | Yes | Yes | High | High
RUPP et al., 2005 ^70^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear
Sallee et al., 1994 ^71^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Unclear | Unclear
Sallee et al., 1997 ^72^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | High | High
Sallee et al., 2000 ^73^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear
Savitz et al., 2015 ^74^ | Yes | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear
Scahill et al., 2003 ^75^ | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear
Schneider et al., 2012 ^76^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | No | No | No | High | High
Sehgal et al., 1999 ^77^ | Unclear | Yes | Yes | NA | Yes | NA | Yes | NA | Yes | Unclear | NA
Shaw et al., 2006 ^78^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear
Shea et al., 2004 ^79^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear
Sikich et al., 2004 ^80^ | Yes | Unclear | Yes | NA | Yes | NA | No | No | Yes | High | High
Sikich et al., 2008 ^81^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Low | Low
Singh et al., 2011 ^82^ | Unclear | Unclear | No | Yes | No | Yes | Yes | Yes | Yes | High | Unclear
Snyder et al., 2002 ^83^ | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | High | High
Spencer et al., 1994 ^84^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear
Stocks et al., 2012 ^85^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | No | No | Yes | High | High
Swadi et al., 2010 ^86^ | Yes | Unclear | No | Yes | No | Yes | No | No | Yes | High | High
Tohen et al., 2007 ^87^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear
Tramontina et al., 2009 ^88^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Low | Low
Troost et al., 2005 ^89^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Low | Low
Van Bellinghen et al., 2001 ^90^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear
Van Bruggen et al., 2003 ^91^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | No | High | High
Woods et al., 2003 ^92^ | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | High | High
Yen et al., 2004 ^93^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | No | No | Yes | High | High
Yoo et al., 2011 ^94^ | No | No | No | Yes | No | Yes | No | No | Yes | High | High
Yoo et al., 2013 ^95^ | Yes | Unclear | Yes | Yes | Yes | Yes | No | No | Yes | High | High

Blinding of OA = blinding of outcome assessors; Blinding of PP = blinding of participants and personnel; NA = not applicable

Table C2 Quality assessment ratings for observational studies using Newcastle-Ottawa Scale

Author, Year Study Design | Selection 1 | Selection 2 | Selection 3 | Comparability | Outcome 1 | Outcome 2 | Outcome 3 | Total Stars
Alacqua et al., 2008 ^96^ RCS | B | A | A | C | B | A | A | 6
Aman et al., 2004 ^97^ PCS | A | A | B | A and B | A | A | C | 7
Arango et al., 2014 ^98^ PCS | A | A | C | A and B | D | A | C | 5
Bastiaens et al., 2009 ^99^ RCS | B | A | A | A and B | E | A | C | 6
Bobo et al., 2013 ^100^ RCS | A | A | A | A and B | A | A | A | 8
Calarge et al., 2014 ^101^ PCS | D | A | A | A | B | A | C | 5
Castro-Fornieles et al., 2008 ^102^ PCS | A | A | B | A and B | D | A | C | 6
Cianchetti et al., 2011 ^103^ PCS | A | A | B | C | D | A | B | 5
Correll et al., 2009 ^104^ PCS | A | A | A | A and B | B | A | A | 8
Cuerda et al., 2011 ^105^ PCS | A | A | D | A | B | A | C | 6
Ebert et al., 2014 ^106^ RCS | A | A | A | C | D | A | A | 5
Findling et al., 2008b ^107^ PCS | B | A | A | C | C | A | B | 5
Fleischhaker et al., 2006 ^108^ PCS | D | C | B | C | E | A | A | 3
Fraguas et al., 2008 ^109^ PCS | A | A | A | A and B | D | A | C | 6
Friedlander et al., 2001 ^110^ RCS | C | A | A | C | E | A | A | 4
Germano et al., 2014 ^111^ PCS | A | A | A | C | D | A | B | 5
Gothelf et al., 2002 ^112^ PCS | C | C | A | C | B | A | D | 3
Hrdlicka et al., 2009 ^113^ RCS | A | A | A | C | B | A | C | 5
Jerrell et al., 2008 ^114^ RCS | A | A | A | C | B | A | A | 6
Khan et al., 2009 ^115^ RCS | A | A | A | C | B | A | A | 6
Khan et al., 2006 ^116^ RCS | D | C | A | C | B | A | A | 4
Kumra et al., 1998 ^117^ PCS | B | A | B | C | E | A | A | 5
Mankoski et al., 2013 ^118^ PCS | A | A | D | A and B | D | A | A | 6
Martin et al., 2000 ^119^ PCS | A | A | A | C | B | A | A | 6
Migliardi et al., 2009 ^120^ RCS | B | A | A | B | B | A | A | 7
NCT00619190, 2013 ^121^ PCS | A | C | B | C | D | A | B | 4
Norris et al., 2011 ^122^ RCS | A | A | A | A and B | B | A | A | 7
Novaes et al., 2008 ^123^ RCS | A | A | A | A and B | B | A | A | 8
O’Donoghue et al., 2014 ^124^ PCS | A | A | D | C | D | A | C | 3
Oh et al., 2013 ^125^ PCS | A | A | A | B | B | A | C | 6
Olfson et al., 2012 ^126^ RCS | A | A | A | A | B | A | A | 7
Pandina et al., 2007 ^127^ PCS | A | A | D | A and B | D | A | A | 6
Pogge et al., 2005 ^128^ RCS | A | A | A | C | A | A | A | 6
Ratzoni et al., 2002 ^129^ PCS | D | C | B | C | E | A | A | 3
Ronsley et al., 2015 ^130^ PCS | A | A | D | A | D | A | C | 4
Saito et al., 2004 ^131^ PCS | B | A | A | B | D | A | A | 6
Weisler et al., 2011 ^132^ RCS | A | A | A | A and B | D | A | B | 6
Wink et al., 2014 ^133^ RCS | A | A | A | B | B | A | A | 7
Wonodi et al., 2007 ^134^ RCS | A | A | A | A and B | A | A | A | 8
Wudarsky et al., 1999 ^135^ PCS | A | A | A | A | A | A | A | 7

PCS = prospective cohort study; RCS = retrospective cohort study