# Appendix B Literature Search Strategies

## MEDLINE

Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) 1946 to Present

Search Title: Antipsychotics_Child_Update

Search Date: 15 Oct 2015 (updated in April 2016)

Results: 6164

1. Adjustment Disorders/
2. Anorexia/
3. Anxiety/
4. exp Anxiety Disorders/
5. exp "Attention Deficit and Disruptive Behavior Disorders"/
6. exp Behavioral Symptoms/
7. Child Behavior Disorders/
8. exp Child Development Disorders, Pervasive/
9. exp Eating Disorders/
10. exp Hyperphagia/
11. exp Impulse Control Disorders/
12. exp Impulsive Behavior/
13. Irritable Mood/
14. Mental Disorders/
15. exp Mood Disorders/
16. Movement Disorders/
17. "Off-Label Use"/
18. Psychomotor Agitation/
19. Rett Syndrome/
20. exp "Schizophrenia and Disorders with Psychotic Features"/
21. Schizophrenia, Childhood/
22. exp Sleep Disorders/
23. exp Substance-Related Disorders/
24. exp Tic Disorders/
25. Violence/
26. (ADHD* or (attention deficit adj2 disorder*) or hyperkinetic syndrome).tw,kf.
27. ((adjustment or reactive) adj disorder*).tw,kf.
28. (affective adj2 (disorder* or disregulation or dysregulation)).tw,kf.
29. (aggressi* or agitat*).tw,kf.
30. agoraphobi*.tw,kf.
31. ((alcohol* or drug* or cannabi* or cocaine* or heroin or marijuana* or narcotic* or opiate* or opioid* or substance*) adj2 (abus* or addict* or depend* or disorder* or withdrawal*)).tw,kf.
32. ((addicti* or compulsi* or explosive or impuls*) adj2 (behavio* or disorder*)).tw,kf.
33. (((anankastic or compulsiv* or obsessive) adj (behavio* or disorder* or neuros* or personalit*)) or OCD).tw,kf.
34. anorexi*.tw,kf.
35. anxiety.tw,kf.
36. (autis* or asperger* or kanner* syndrome).tw,kf.
37. (behavio* adj2 (disorder* or disturb* or disrupt* or dyscontrol* or illness* or issue* or outburst* or problem*)).tw,kf.
38. (((behavio* or disorder* or episod*) adj (hypomanic or manic)) or mania*).tw,kf.
39. (binge adj (drink* or eat*)).tw,kf.
40. (bi polar or bipolar).tw,kf.
41. bulimi*.tw,kf.
42. (claustrophobi* or phobia* or phobic).tw,kf.
43. ((combat or war) adj (disorder* or neuros*)).tw,kf.
44. conduct disorder*.tw,kf.
45. cyclothymi*.tw,kf.
46. ((defiant or disrupt* or oppositional) adj (behavio* or disorder*)).tw,kf.
47. delusion*.tw,kf.
48. dementia praecox.tw,kf.
49. depress*.tw,kf.
50. ((dis integrative or disintegrative or dys integrative or dysintegrative) adj disorder*).tw,kf.
51. (dys somnia* or dyssomnia* or insomnia* or para somnia* or parasomnia*).tw,kf.
52. dysthymi*.tw,kf.
53. eating disorder*.tw,kf.
54. ((emotion* or mood) adj2 (disorder* or dis regulation or disregulation or dys regulation or dysregulation)).tw,kf.
55. (hoarder* or hoarding).tw,kf.
56. (hyper activ* or hyperactiv*).tw,kf.
57. hyperphagia*.tw,kf.
58. irritab*.tw,kf.
59. kleptomania*.tw,kf.
60. (minimal brain adj (dis function* or disfunction* or dys function* or dysfunction*)).tw,kf.
61. (mood adj2 (labil* or swing*)).tw,kf.
62. (off label* or offlabel* or unlabeled indication* or unlabeled use*).tw,kf.
63. (panic* adj (attack* or disorder*)).tw,kf.
64. (para suicid* or parasuicid*).tw,kf.
65. paranoi*.tw,kf.
66. pervasive development* disorder*.tw,kf.
67. ((post traumatic or posttraumatic) adj2 (disorder* or neuros*)).tw,kf.
68. ((psycho* or sociopath*) adj (disorder* or personalit*)).tw,kf.
69. psychos*.tw,kf.
70. PTSD*.tw,kf.
71. (rett* adj (syndrome* or disorder*)).tw,kf.
72. (self adj (destruct* or harm* or injur* or mutilat*)).tw,kf.
73. (schizo affect* or schizoaffect*).tw,kf.
74. schizophreni*.tw,kf.
75. shell shock*.tw,kf.
76. (sleep adj2 (disorder* or dysfunction*)).tw,kf.
77. stress disorder*.tw,kf.
78. tourette*.tw,kf.
79. tic disorder*.tw,kf.
80. unstable mood*.tw,kf.
81. violen*.tw,kf.
82. or/1–81
83. exp Antipsychotic Agents/
84. exp Butyrophenones/
85. exp Phenothiazines/
86. exp Thioxanthenes/
87. abilify.mp.
88. adasuve.mp.
89. aldazine.mp.
90. anatensol.mp.
91. anti naus.mp.
92. (anti psychotic* or antipsychotic*).mp.
93. aripiprazole.mp.
94. 82VFR53I78.rn.
95. arizole.mp.
96. asenapine.mp.
97. JKZ19V908O.rn.
98. atrolak.mp.
99. biquelle.mp.
100. brexpiprazole.mp.
101. 2J3YBM1K8C.rn.
102. buccastem.mp.
103. calmazine.mp.
104. cariprazine.mp.
105. chloractil.mp.
106. chlorpromanyl.mp.
107. chlorpromazine.mp.
108. U42B7VYA4P.rn.
109. clopine.mp.
110. clozapine.mp.
111. J60AR2IKIC.rn.
112. clozaril.mp.
113. compazine.mp.
114. compro.mp.
115. decazate.mp.
116. delucon.mp.
117. denzapine.mp.
118. dozic.mp.
119. droleptan.mp.
120. droperidol.mp.
121. O9U0F09D5X.rn.
122. ebesque.mp.
123. fanapt.mp.
124. fazaclo.mp.
125. fazalco.mp.
126. fentazin.mp.
127. fluphenazine.mp.
128. S79426A41Z.rn.
129. fortunan.mp.
130. geodon.mp.
131. haldol.mp.
132. halo peridol.mp.
133. haloperidol.mp.
134. J6292F8L3D.rn.
135. halperon.mp.
136. iloperidone.mp.
137. 133454-47-4.rn.
138. inapsine.mp.
139. invega.mp.
140. lanzek.mp.
141. largactil.mp.
142. latuda.mp.
143. loxapac.mp.
144. loxapine.mp.
145. LER583670J.rn.
146. loxitane.mp.
147. lurasidone.mp.
148. 22IC88528T.rn.
149. (major adj (tranquili?er* or tranquilli?er*)).mp.
150. mellaril*.mp.
151. melleril.mp.
152. mintreleq.mp.
153. moban.mp.
154. modecate.mp.
155. moditen.mp.
156. molindone.mp.
157. RT3Y3QMF8N.rn.
158. nausetil.mp.
159. navane.mp.
160. neuroleptic*.mp.
161. novo flurazine.mp.
162. novo peridol.mp.
163. novo ridazine.mp.
164. novo trifluzine.mp.
165. nu prochlor.mp.
166. olanzaccord.mp.
167. olanzapine.mp.
168. 132539-06-1.rn.
169. orap.mp.
170. ormazine.mp.
171. ozidal.mp.
172. ozin.mp.
173. paliperidone.mp.
174. 838F01T721.rn.
175. permitil.mp.
176. perphenazine.mp.
177. FTA7XXY4EZ.rn.
178. pimozide.mp.
179. 1HIZ4DL86F.rn.
180. procalm.mp.
181. prochlorazine.mp.
182. prochlorperazine.mp.
183. YHP6YLT61T.rn.
184. procomp.mp.
185. prolixin.mp.
186. promapar.mp.
187. prorazin.mp.
188. protran.mp.
189. proziere.mp.
190. prozine.mp.
191. quetiapine.mp.
192. BGL0JSY5SI.rn.
193. quetiaccord.mp.
194. quetin.mp.
195. resdone.mp.
196. rexulti.mp.
197. rideril.mp.
198. rispa.mp.
199. risperdal.mp.
200. risperidone.mp.
201. L6UH7ZF8HC.rn.
202. rispernia.mp.
203. rixadone.mp.
204. saphris.mp.
205. seotiapim.mp.
206. sequase.mp.
207. serenace.mp.
208. seronia.mp.
209. seroquel.mp.
210. solazine.mp.
211. sonazine.mp.
212. sondate.mp.
213. stelazine.mp.
214. stemetil.mp.
215. stemzine.mp.
216. sycrest.mp.
217. syquet.mp.
218. terfluzine.mp.
219. thioridazine.mp.
220. N3D6TG58NI.rn.
221. thiothixene.mp.
222. 7318FJ13YJ.rn.
223. thorazine.mp.
224. tiotixene.mp.
225. trifluoperazine.mp.
226. 214IZI85K3.rn.
227. trilafon.mp.
228. versacloz.mp.
229. vertigon.mp.
230. vraylar.mp.
231. xeplion.mp.
232. xomolix.mp.
233. xylac.mp.
234. zaluron.mp.
235. zaponex.mp.
236. zeldox.mp.
237. ziprasidone.mp.
238. 6UKA5VEJ6X.rn.
239. zylap.mp.
240. zypadhera.mp.
241. zypine.mp.
242. zyprexa.mp.
243. or/83–242
244. and/82,243
245. Adolescent/
246. Adolescent Medicine/
247. exp Child/
248. exp Minors/
249. exp Pediatrics/
250. exp Puberty/
251. Students/
252. Young Adult/
253. adolescen*.mp.
254. (boy* or girl* or teen*).mp.
255. (child* or grade school* or kid or kids or kindergar?en* or minors* or preschool* or pre school* or school age* or schoolchild* or toddler*).mp.
256. ((colleg* or high school* or highschool* or middle school* or universit*) adj2 (age* or student*)).mp.
257. (paediatric* or peadiatric* or pediatric*).mp.
258. (prepubescen* or pubescen* or pubert*).mp.
259. (young* adj (adult* or men or mens or people* or person* or women*)).mp.
260. (youth or youths).mp.
261. or/245–260
262. and/244,261
263. exp Epidemiologic Studies/
264. controlled clinical trial.pt.
265. randomized controlled trial.pt.
266. drug therapy.fs.
267. (case control or cohort* or follow up or followup or longitudinal or prospective* or retrospective).tw,kf.
268. ((compari* or epidemiologic* or experimental or observational) adj2 (analy* or study or studies)).tw,kf.
269. groups.ab.
270. placebo.ab.
271. random*.ab.
272. trial.ab.
273. or/263–272
274. exp animals/not humans.sh.
275. 273 not 274
276. and/262,275
277. (case reports or comment or editorial or letter).pt.
278. 276 not 277
279. limit 278 to english
280. limit 279 to yr="1987-current"

## CENTRAL

Database: CENTRAL via Cochrane Library

Search Title: Antipsychotics_Child_Update

Date Searched: 19 Oct 2015 (updated in April 2016)

Results: 1569

1. [mh ^"Adjustment Disorders"]
2. [mh ^Anorexia]
3. [mh ^Anxiety]
4. [mh "Anxiety Disorders"]
5. [mh "Attention Deficit and Disruptive Behavior Disorders"]
6. [mh "Behavioral Symptoms"]
7. [mh ^"Child Behavior Disorders"]
8. [mh "Child Development Disorders, Pervasive"]
9. [mh "Eating Disorders"]
10. [mh Hyperphagia]
11. [mh "Impulse Control Disorders"]
12. [mh "Impulsive Behavior"]
13. [mh ^"Irritable Mood"]
14. [mh ^"Mental Disorders"]
15. [mh "Mood Disorders"]
16. [mh ^"Movement Disorders"]
17. [mh ^"Off-Label Use"]
18. [mh ^"Psychomotor Agitation"]
19. [mh ^"Rett Syndrome"]
20. [mh "Schizophrenia and Disorders with Psychotic Features"]
21. [mh ^"Schizophrenia, Childhood"]
22. [mh "Sleep Disorders"]
23. [mh "Substance-Related Disorders"]
24. [mh "Tic Disorders"]
25. [mh ^Violence]
26. (ADHD* or ("attention deficit" n/2 disorder*) or "hyperkinetic syndrome"):ti,ab,kw
27. ((adjustment or reactive) next disorder*):ti,ab,kw
28. (affective n/2 (disorder* or disregulation or dysregulation)):ti,ab,kw
29. (aggressi* or agitat*):ti,ab,kw
30. agoraphobi*:ti,ab,kw
31. ((alcohol* or drug* or cannabi* or cocaine* or heroin or marijuana* or narcotic* or opiate* or opioid* or substance*) n/2 (abus* or addict* or depend* or disorder* or withdrawal*)):ti,ab,kw
32. ((addicti* or compulsi* or explosive or impuls*) n/2 (behavio* or disorder*)):ti,ab,kw
33. (((anankastic or compulsiv* or obsessive) next (behavio* or disorder* or neuros* or personalit*)) or OCD):ti,ab,kw
34. anorexi*:ti,ab,kw
35. anxiety:ti,ab,kw
36. (autis* or asperger* or (kanner* next syndrome)):ti,ab,kw
37. (behavio* n/2 (disorder* or disturb* or disrupt* or dyscontrol* or illness* or issue* or outburst* or problem*)):ti,ab,kw
38. (((behavio* or disorder* or episod*) next (hypomanic or manic)) or mania*):ti,ab,kw
39. (binge next (drink* or eat*)):ti,ab,kw
40. ("bi polar" or bipolar):ti,ab,kw
41. bulimi*:ti,ab,kw
42. (claustrophobi* or phobia* or phobic):ti,ab,kw
43. ((combat or war) next (disorder* or neuros*)):ti,ab,kw
44. (conduct next disorder*):ti,ab,kw
45. cyclothymi*:ti,ab,kw
46. ((defiant or disrupt* or oppositional) next (behavio* or disorder*)):ti,ab,kw
47. delusion*:ti,ab,kw
48. "dementia praecox":ti,ab,kw
49. depress*:ti,ab,kw
50. (("dis integrative" or disintegrative or "dys integrative" or dysintegrative) next disorder*):ti,ab,kw
51. ((dys next somnia*) or dyssomnia* or insomnia* or (para next somnia*) or parasomnia*):ti,ab,kw
52. dysthymi*:ti,ab,kw
53. (eating next disorder*):ti,ab,kw
54. ((emotion* or mood) n/2 (disorder* or "dis regulation" or disregulation or "dys regulation" or dysregulation)):ti,ab,kw
55. (hoarder* or hoarding):ti,ab,kw
56. ((hyper next activ*) or hyperactiv*):ti,ab,kw
57. (hyperphagia*):ti,ab,kw
58. (irritab*):ti,ab,kw
59. (kleptomania*):ti,ab,kw
60. ("minimal brain" next ((dis next function*) or disfunction* or (dys next function*) or dysfunction*)):ti,ab,kw
61. (mood n/2 (labil* or swing*)):ti,ab,kw
62. ((off next label*) or offlabel* or (unlabeled next indication*) or (unlabeled next use*)):ti,ab,kw
63. (panic* next (attack* or disorder*)):ti,ab,kw
64. ((para next suicid*) or parasuicid*):ti,ab,kw
65. (paranoi*):ti,ab,kw
66. (pervasive next development* next disorder*):ti,ab,kw
67. (("post traumatic" or posttraumatic) n/2 (disorder* or neuros*)):ti,ab,kw
68. ((psycho* or sociopath*) next (disorder* or personalit*)):ti,ab,kw
69. (psychos*):ti,ab,kw
70. (PTSD*):ti,ab,kw
71. (rett* next (syndrome* or disorder*)):ti,ab,kw
72. (self next (destruct* or harm* or injur* or mutilat*)):ti,ab,kw
73. ((schizo next affect*) or schizoaffect*):ti,ab,kw
74. (schizophreni*):ti,ab,kw
75. (shell next shock*):ti,ab,kw
76. (sleep n/2 (disorder* or dysfunction*)):ti,ab,kw
77. (stress next disorder*):ti,ab,kw
78. (tourette*):ti,ab,kw
79. (tic next disorder*):ti,ab,kw
80. (unstable next mood*):ti,ab,kw
81. violen*:ti,ab,kw
82. {or #1–#81}
83. [mh "Antipsychotic Agents"]
84. [mh Butyrophenones]
85. [mh Phenothiazines]
86. [mh Thioxanthenes]
87. (abilify or adasuve or aldazine or anatensol or "anti naus"):ti,ab,kw
88. ((anti next psychotic*) or antipsychotic*):ti,ab,kw
89. (aripiprazole or arizole or asenapine or atrolak or biquelle):ti,ab,kw
90. (brexpiprazole or buccastem or calmazine or cariprazine or chloractil):ti,ab,kw
91. (chlorpromanyl or chlorpromazine or clopine or clozapine or clozaril):ti,ab,kw
92. (compazine or compro or decazate or delucon or denzapine):ti,ab,kw
93. (dozic or droleptan or droperidol or ebesque or fanapt):ti,ab,kw
94. (fazaclo or fazalco or fentazin or fluphenazine or fortunan):ti,ab,kw
95. (geodon or haldol or "halo peridol" or haloperidol or halperon):ti,ab,kw
96. (iloperidone or inapsine or invega or lanzek or largactil):ti,ab,kw
97. (latuda or loxapac or loxapine or loxitane or lurasidone):ti,ab,kw
98. (major next (tranquili?er* or tranquilli?er*)):ti,ab,kw
99. (mellaril* or melleril or mintreleq or moban or modecate):ti,ab,kw
100. (moditen or molindone or nausetil or navane):ti,ab,kw
101. (neuroleptic*):ti,ab,kw
102. ("novo flurazine" or "novo peridol" or "novo ridazine" or "novo trifluzine" or "nu prochlor"):ti,ab,kw
103. (olanzaccord or olanzapine or orap or ormazine or ozidal):ti,ab,kw
104. (ozin or paliperidone or permitil or perphenazine or pimozide):ti,ab,kw
105. (procalm or prochlorazine or prochlorperazine or procomp or prolixin):ti,ab,kw
106. (promapar or prorazin or protran or proziere or prozine):ti,ab,kw
107. (quetiapine or quetiaccord or quetin or resdone or rexulti):ti,ab,kw
108. (rideril or rispa or risperdal or risperidone or rispernia):ti,ab,kw
109. (rixadone or saphris or seotiapim or sequase or serenace):ti,ab,kw
110. (seronia or seroquel or solazine or sonazine or sondate):ti,ab,kw
111. (stelazine or stemetil or stemzine or sycrest or syquet):ti,ab,kw
112. (terfluzine or thioridazine or thiothixene or thorazine or tiotixene):ti,ab,kw
113. (trifluoperazine or trilafon or versacloz or vertigon or vraylar):ti,ab,kw
114. (xeplion or xomolix or xylac or zaluron or zaponex):ti,ab,kw
115. (zeldox or ziprasidone or zylap or zypadhera or zypine or zyprexa):ti,ab,kw
116. {or #83–#115}
117. #82 and #116
118. [mh ^Adolescent]
119. [mh ^"Adolescent Medicine"]
120. [mh Child]
121. [mh Minors]
122. [mh Pediatrics]
123. [mh Puberty]
124. [mh ^Students]
125. [mh ^"Young Adult"]
126. (adolescen*):ti,ab,kw
127. (boy* or girl* or teen*):ti,ab,kw
128. (child* or (grade next school*) or kid or kids or kindergar?en* or minors* or preschool* or (pre next school*) or (school next age*) or schoolchild* or toddler*):ti,ab,kw
129. ((colleg* or (high next school*) or highschool* or (middle next school*) or universit*) n/2 (age* or student*)):ti,ab,kw
130. (paediatric* or peadiatric* or pediatric*):ti,ab,kw
131. (prepubescen* or pubescen* or pubert*):ti,ab,kw
132. (young* next (adult* or men or mens or people* or person* or women*)):ti,ab,kw
133. (youth or youths):ti,ab,kw
134. {or #118–#133}
135. #117 and #134 Publication Year from 1987 to 2015, in Trials

Note: Excluded 73 non-English language records in EndNote

## CINAHL

Database: CINAHL Plus with Full Text via EbscoHOST

Search Title: Antipsychotics_Child_Update

Date Searched: 21 Oct 2015 (updated in April 2916)

Results: 1142

S1 MH "Adjustment Disorders+"
S2 MH "Affective Disorders+"
S3 MH "Affective Disorders, Psychotic+"
S4 MH "Affective Symptoms+"
S5 MH "Anxiety Disorders+"
S6 MH "Attention Deficit Hyperactivity Disorder"
S7 MH "Behavior, Addictive+"
S8 MH "Behavioral Symptoms"
S9 MH "Child Behavior Disorders"
S10 MH "Child Development Disorders, Pervasive+"
S11 MH "Compulsive Behavior"
S12 MH "Drugs, Off-Label"
S13 MH "Eating Disorders+"
S14 MH "Impulse Control Disorders+"
S15 MH "Mental Disorders"
S16 MH "Mental Disorders Diagnosed in Childhood"
S17 MH "Paranoid Disorders"
S18 MH "Psychomotor Agitation"
S19 MH "Psychomotor Disorders"
S20 MH "Psychotic Disorders+"
S21 MH "Rett Syndrome"
S22 MH "Schizoaffective Disorder"
S23 MH "Schizophrenia+"
S24 MH "Sleep Disorders+"
S25 MH "Substance Use Disorders+"
S26 MH "Suicide+"
S27 MH "Tourette Syndrome"
S28 MH "Violence"
S29 (ADHD* or ("attention deficit" N2 disorder*) or "hyperkinetic syndrome")
S30 ((adjustment or reactive) N1 disorder*)
S31 (affective N2 (disorder* or disregulation or dysregulation))
S32 (aggressi* or agitat*)
S33 agoraphobi*
S34 ((alcohol* or drug* or cannabi* or cocaine* or heroin or marijuana* or narcotic* or opiate* or opioid* or substance*) N2 (abus* or addict* or depend* or disorder* or withdrawal*))
S35 ((addicti* or compulsi* or explosive or impuls*) N2 (behavio* or disorder*))
S36 (((anankastic or compulsiv* or obsessive) N1 (behavio* or disorder* or neuros* or personalit*)) or OCD)
S37 anorexi*
S38 anxiety
S39 (autis* or asperger* or "kanner* syndrome")
S40 (behavio* N2 (disorder* or disturb* or disrupt* or dyscontrol* or illness* or issue* or outburst* or problem*))
S41 (((behavio* or disorder* or episod*) N1 (hypomanic or manic)) or mania*)
S42 (binge N1 (drink* or eat*))
S43 ("bi polar" or bipolar)
S44 bulimi*
S45 (claustrophobi* or phobia* or phobic)
S46 ((combat or war) N1 (disorder* or neuros*))
S47 "conduct disorder*"
S48 cyclothymi*
S49 ((defiant or disrupt* or oppositional) N1 (behavio* or disorder*))
S50 delusion*
S51 "dementia praecox"
S52 depress*
S53 (("dis integrative" or disintegrative or "dys integrative" or dysintegrative) N1 disorder*)
S54 ("dys somnia*" or dyssomnia* or insomnia* or "para somnia*" or parasomnia*)
S55 dysthymi*
S56 "eating disorder*"
S57 ((emotion* or mood) N2 (disorder* or "dis regulation" or disregulation or "dys regulation" or dysregulation))
S58 (hoarder* or hoarding)
S59 ("hyper activ*" or hyperactiv*)
S60 hyperphagia*
S61 irritab*
S62 kleptomania*
S63 ("minimal brain" N1 ("dis function*" or disfunction* or "dys function*" or dysfunction*))
S64 (mood N2 (labil* or swing*))
S65 ("off label*" or offlabel* or "unlabeled indication*" or "unlabeled use*")
S66 (panic* N1 (attack* or disorder*))
S67 ("para suicid*" or parasuicid*)
S68 paranoi*
S69 "pervasive development* disorder*"
S70 (("post traumatic" or posttraumatic) N2 (disorder* or neuros*))
S71 ((psycho* or sociopath*) N1 (disorder* or personalit*))
S72 psychos*
S73 PTSD*
S74 (rett* N1 (syndrome* or disorder*))
S75 (self N1 (destruct* or harm* or injur* or mutilat*))
S76 ("schizo affect*" or schizoaffect*)
S77 schizophreni*
S78 "shell shock*"
S79 (sleep N2 (disorder* or dysfunction*))
S80 "stress disorder*"
S81 tourette*
S82 "tic disorder*"
S83 "unstable mood*"
S84 violen*
S85 S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 OR S42 OR S43 OR S44 OR S45 OR S46 OR S47 OR S48 OR S49 OR S50 OR S51 OR S52 OR S53 OR S54 OR S55 OR S56 OR S57 OR S58 OR S59 OR S60 OR S61 OR S62 OR S63 OR S64 OR S65 OR S66 OR S67 OR S68 OR S69 OR S70 OR S71 OR S72 OR S73 OR S74 OR S75 OR S76 OR S77 OR S78 OR S79 OR S80 OR S81 OR S82 OR S83 OR S84
S86 MH "Antipsychotic Agents+"
S87 (abilify or adasuve or aldazine or anatensol or "anti naus")
S88 ("anti psychotic*" or antipsychotic*)
S89 (aripiprazole or arizole or asenapine or atrolak or biquelle)
S90 (brexpiprazole or buccastem or calmazine or cariprazine or chloractil)
S91 (chlorpromanyl or chlorpromazine or clopine or clozapine or clozaril)
S92 (compazine or compro or decazate or delucon or denzapine)
S93 (dozic or droleptan or droperidol or ebesque or fanapt)
S94 (fazaclo or fazalco or fentazin or fluphenazine or fortunan)
S95 (geodon or haldol or "halo peridol" or haloperidol or halperon)
S96 (iloperidone or inapsine or invega or lanzek or largactil)
S97 (latuda or loxapac or loxapine or loxitane or lurasidone)
S98 (major N1 (tranquili?er* or tranquilli?er*))
S99 (mellaril* or melleril or mintreleq or moban or modecate)
S100 (moditen or molindone or nausetil or navane)
S101 neuroleptic*
S102 (novo N1 (flurazine or peridol or ridazine or trifluzine))
S103 ("nu prochlor" or olanzaccord or olanzapine or orap or ormazine)
S104 (ozidal or ozin or paliperidone or permitil or perphenazine)
S105 (pimozide or procalm or prochlorazine or prochlorperazine or procomp)
S106 (prolixin or promapar or prorazin or protran or proziere)
S107 (prozine or quetiapine or quetiaccord or quetin or resdone)
S108 (rexulti or rideril or rispa or risperdal or risperidone)
S109 (rispernia or rixadone or saphris or seotiapim or sequase)
S110 (serenace or seronia or seroquel or solazine or sonazine)
S111 (sondate or stelazine or stemetil or stemzine or sycrest)
S112 (syquet or terfluzine or thioridazine or thiothixene or thorazine)
S113 (tiotixene or trifluoperazine or trilafon or versacloz or vertigon)
S114 (vraylar or xeplion or xomolix or xylac or zaluron)
S115 (zaponex or zeldox or ziprasidone or zylap or zypadhera)
S116 (zypine or zyprexa)
S117 S86 OR S87 OR S88 OR S89 OR S90 OR S91 OR S92 OR S93 OR S94 OR S95 OR S96 OR S97 OR S98 OR S99 OR S100 OR S101 OR S102 OR S103 OR S104 OR S105 OR S106 OR S107 OR S108 OR S109 OR S110 OR S111 OR S112 OR S113 OR S114 OR S115 OR S116
S118 S85 AND S117
S119 MH "Adolescence+"
S120 MH "Adolescent Medicine"
S121 MH "Child"
S122 MH "Child, Preschool"
S123 MH "Minors (Legal)"
S124 MH "Pediatrics"
S125 MH "Puberty"
S126 MH "Students, Elementary"
S127 MH "Students, High School"
S128 MH "Students, Middle School"
S129 MH "Students, Undergraduate"
S130 MH "Young Adult"
S131 adolescen*
S132 (boy* or girl* or teen*)
S133 (child* or "grade school*" or kid or kids or kindergar?en* or minors* or preschool* or "pre school*" or "school age*" or schoolchild* or toddler*)
S134 ((colleg* or "high school*" or highschool* or "middle school*" or universit*) N2 (age* or student*))
S135 (paediatric* or peadiatric* or pediatric*)
S136 (prepubescen* or pubescen* or pubert*)
S137 (young* N1 (adult* or men or mens or people* or person* or women*))
S138 (youth or youths)
S139 S119 OR S120 OR S121 OR S122 OR S123 OR S124 OR S125 OR S126 OR S127 OR S128 OR S129 OR S130 OR S131 OR S132 OR S133 OR S134 OR S135 OR S136 OR S137 OR S138
S140 S118 AND S139
S141 MH "Clinical Research+"
S142 MH "Comparative Studies"
S143 MH "Drug Therapy"
S144 MH "Experimental Studies+"
S145 MH "Nonexperimental Studies+"
S146 MH "Retrospective Design"
S147 Limiters - Publication Type: Clinical Trial, Randomized Controlled Trial
S148 ("case control" or cohort* or "follow up" or followup or longitudinal or prospective* or retrospective)
S149 ((compari* or epidemiologic* or experimental or observational) N2 (analy* or study or studies))
S150 AB groups
S151 AB placebo
S152 AB random*
S153 AB trial
S154 S141 OR S142 OR S143 OR S144 OR S145 OR S146 OR S147 OR S148 OR S149 OR S150 OR S151 OR S152 OR S153
S155 (MH "Animals+") not (MH "Humans")
S156 S154 NOT S155
S157 S140 AND S156
S158 PT (“case reports” or comment or editorial or letter)
S159 S157 NOT S158
S160 S159 Limiters – Language: English
S161 S160 Limiters – English Language; Published Date: 19870101-20151231

## Ovid EMBASE

Database: Ovid Embase 1980 to 2015 Week 41

Search Title: Antipsychotics_Child_Update_1

Date Searched: 16 Oct 2015 (updated in April 2016)

Results: 7376

1. abnormal behavior/
2. exp addiction/
3. adjustment disorder/
4. aggression/
5. aggressiveness/
6. exp anger/
7. anorexia/
8. anxiety/
9. exp anxiety disorder/
10. attention deficit disorder/
11. exp autism/
12. automutilation/
13. behavior disorder/
14. disruptive behavior/
15. exp eating disorder/
16. exp impulse control disorder/
17. impulsiveness/
18. intermittent explosive disorder/
19. irritability/
20. kleptomania/
21. oppositional defiant disorder/
22. exp psychosis/
23. exp psychosocial disorder/
24. exp "substance use"/
25. exp suicidal behavior/
26. mental disease/
27. minimal brain dysfunction/
28. exp mood disorder/
29. motor dysfunction/
30. "off label drug use"/
31. restlessness/
32. exp sleep disorder/
33. exp tic/
34. exp violence/
35. (ADHD* or (attention deficit adj2 disorder*) or hyperkinetic syndrome).tw.
36. ((adjustment or reactive) adj disorder*).tw.
37. (affective adj2 (disorder* or disregulation or dysregulation)).tw.
38. (aggressi* or agitat*).tw.
39. agoraphobi*.tw.
40. ((alcohol* or drug* or cannabi* or cocaine* or heroin or marijuana* or narcotic* or opiate* or opioid* or substance*) adj2 (abus* or addict* or depend* or disorder* or withdrawal*)).tw.
41. ((addicti* or compulsi* or explosive or impuls*) adj2 (behavio* or disorder*)).tw.
42. (((anankastic or compulsiv* or obsessive) adj (behavio* or disorder* or neuros* or personalit*)) or OCD).tw.
43. anorexi*.tw.
44. anxiety.tw.
45. (autis* or asperger* or kanner* syndrome).tw.
46. (behavio* adj2 (disorder* or disturb* or disrupt* or dyscontrol* or illness* or issue* or outburst* or problem*)).tw.
47. (((behavio* or disorder* or episod*) adj (hypomanic or manic)) or mania*).tw.
48. (binge adj (drink* or eat*)).tw.
49. (bi polar or bipolar).tw.
50. bulimi*.tw.
51. (claustrophobi* or phobia* or phobic).tw.
52. ((combat or war) adj (disorder* or neuros*)).tw.
53. conduct disorder*.tw.
54. cyclothymi*.tw.
55. ((defiant or disrupt* or oppositional) adj (behavio* or disorder*)).tw.
56. delusion*.tw.
57. dementia praecox.tw.
58. depress*.tw.
59. ((dis integrative or disintegrative or dys integrative or dysintegrative) adj disorder*).tw.
60. (dys somnia* or dyssomnia* or insomnia* or para somnia* or parasomnia*).tw.
61. dysthymi*.tw.
62. eating disorder*.tw.
63. ((emotion* or mood) adj2 (disorder* or dis regulation or disregulation or dys regulation or dysregulation)).tw.
64. (hoarder* or hoarding).tw.
65. (hyper activ* or hyperactiv*).tw.
66. hyperphagia*.tw.
67. irritab*.tw.
68. kleptomania*.tw.
69. (minimal brain adj (dis function* or disfunction* or dys function* or dysfunction*)).tw.
70. (mood adj2 (labil* or swing*)).tw.
71. (off label* or offlabel* or unlabeled indication* or unlabeled use*).tw.
72. (panic* adj (attack* or disorder*)).tw.
73. (para suicid* or parasuicid*).tw.
74. paranoi*.tw.
75. pervasive development* disorder*.tw.
76. ((post traumatic or posttraumatic) adj2 (disorder* or neuros*)).tw.
77. ((psycho* or sociopath*) adj (disorder* or personalit*)).tw.
78. psychos*.tw.
79. PTSD*.tw.
80. (rett* adj (syndrome* or disorder*)).tw.
81. (self adj (destruct* or harm* or injur* or mutilat*)).tw.
82. (schizo affect* or schizoaffect*).tw.
83. schizophreni*.tw.
84. shell shock*.tw.
85. (sleep adj2 (disorder* or dysfunction*)).tw.
86. stress disorder*.tw.
87. tourette*.tw.
88. tic disorder*.tw.
89. unstable mood*.tw.
90. violen*.tw.
91. or/1–90
92. abilify.mp.
93. adasuve.mp.
94. aldazine.mp.
95. anatensol.mp.
96. anti naus.mp.
97. (anti psychotic* or antipsychotic*).tw.
98. aripiprazole.mp.
99. arizole.mp.
100. asenapine.mp.
101. atrolak.mp.
102. biquelle.mp.
103. brexpiprazole.mp.
104. buccastem.mp.
105. calmazine.mp.
106. cariprazine.mp.
107. chloractil.mp.
108. chlorpromanyl.mp.
109. chlorpromazine.mp.
110. clopine.mp.
111. clozapine.mp.
112. clozaril.mp.
113. compazine.mp.
114. compro.mp.
115. decazate.mp.
116. delucon.mp.
117. denzapine.mp.
118. dozic.mp.
119. droleptan.mp.
120. droperidol.mp.
121. ebesque.mp.
122. fanapt.mp.
123. fazaclo.mp.
124. fazalco.mp.
125. fentazin.mp.
126. fluphenazine.mp.
127. fortunan.mp.
128. geodon.mp.
129. haldol.mp.
130. halo peridol.mp.
131. haloperidol.mp.
132. halperon.mp.
133. iloperidone.mp.
134. inapsine.mp.
135. invega.mp.
136. lanzek.mp.
137. largactil.mp.
138. latuda.mp.
139. loxapac.mp.
140. loxapine.mp.
141. loxitane.mp.
142. lurasidone.mp.
143. (major adj (tranquili?er* or tranquilli?er*)).tw.
144. mellaril*.mp.
145. melleril.mp.
146. mintreleq.mp.
147. moban.mp.
148. modecate.mp.
149. moditen.mp.
150. molindone.mp.
151. nausetil.mp.
152. navane.mp.
153. neuroleptic*.tw.
154. novo flurazine.mp.
155. novo peridol.mp.
156. novo ridazine.mp.
157. novo trifluzine.mp.
158. nu prochlor.mp.
159. olanzaccord.mp.
160. olanzapine.mp.
161. orap.mp.
162. ormazine.mp.
163. ozidal.mp.
164. ozin.mp.
165. paliperidone.mp.
166. permitil.mp.
167. perphenazine.mp.
168. pimozide.mp.
169. procalm.mp.
170. prochlorazine.mp.
171. prochlorperazine.mp.
172. procomp.mp.
173. prolixin.mp.
174. promapar.mp.
175. prorazin.mp.
176. protran.mp.
177. proziere.mp.
178. prozine.mp.
179. quetiapine.mp.
180. quetiaccord.mp.
181. quetin.mp.
182. resdone.mp.
183. rexulti.mp.
184. rideril.mp.
185. rispa.mp.
186. risperdal.mp.
187. risperidone.mp.
188. rispernia.mp.
189. rixadone.mp.
190. saphris.mp.
191. seotiapim.mp.
192. sequase.mp.
193. serenace.mp.
194. seronia.mp.
195. seroquel.mp.
196. solazine.mp.
197. sonazine.mp.
198. sondate.mp.
199. stelazine.mp.
200. stemetil.mp.
201. stemzine.mp.
202. sycrest.mp.
203. syquet.mp.
204. terfluzine.mp.
205. thioridazine.mp.
206. thiothixene.mp.
207. thorazine.mp.
208. tiotixene.mp.
209. trifluoperazine.mp.
210. trilafon.mp.
211. versacloz.mp.
212. vertigon.mp.
213. vraylar.mp.
214. xeplion.mp.
215. xomolix.mp.
216. xylac.mp.
217. zaluron.mp.
218. zaponex.mp.
219. zeldox.mp.
220. ziprasidone.mp.
221. zylap.mp.
222. zypadhera.mp.
223. zypine.mp.
224. zyprexa.mp.
225. or/92–224
226. and/91,225
227. adolescen*.mp.
228. (boy* or girl* or teen*).mp.
229. (child* or grade school* or kid or kids or kindergar?en* or minors* or preschool* or pre school* or school age* or schoolchild* or toddler*).mp.
230. (paediatric* or peadiatric* or pediatric*).mp.
231. (prepubescen* or pubescen* or pubert*).mp.
232. (young* adj (adult* or men or mens or people* or person* or women*)).mp.
233. (youth or youths).mp.
234. or/227–233
235. and/226,234
236. exp comparative study/
237. exp controlled study/
238. experimental study/
239. observational study/
240. dt.fs.
241. (case control or cohort* or follow up or followup or longitudinal or prospective* or retrospective).tw.
242. ((compari* or epidemiologic* or experimental or observational) adj2 (analy* or study or studies)).tw.
243. groups.ab.
244. placebo.ab.
245. random*.ab.
246. trial.ab.
247. or/236–246
248. animals/not (animals/and humans/)
249. 247 not 248
250. and/235,249
251. (conference* or editorial or letter).pt.
252. 250 not 251
253. limit 252 to english
254. limit 253 to yr="1987-current"

## Ovid PsycINFO

Database: Ovid PsycINFO 1987 to October Week 2 2015

Search Title: Antipsychotics_Child_Update_2

Date Searched: 20 Oct 2015 (updated in April 2016)

Results: 2296

1. Adjustment Disorders/
2. exp Affective Disorders/
3. Aggressive Behavior/
4. Agitation/
5. Anxiety/
6. exp Anxiety Disorders/
7. exp Attention Deficit Disorder/
8. exp Behavior Disorders/
9. exp Behavior Problems/
10. Conduct Disorder/
11. exp Drug Usage/
12. exp Eating Disorders/
13. exp Impulse Control Disorders/
14. Impulsiveness/
15. Irritability/
16. Kleptomania/
17. Mental Disorders/
18. Movement Disorders/
19. Oppositional Defiant Disorder/
20. exp Pervasive Developmental Disorders/
21. Psychiatric Patients/
22. Psychiatric Symptoms/
23. exp Psychosis/
24. Schizoaffective Disorder/
25. exp Sleep Disorders/
26. Tics/
27. Tourette Syndrome/
28. Violence/
29. (ADHD* or (attention deficit adj2 disorder*) or hyperkinetic syndrome).tw.
30. ((adjustment or reactive) adj disorder*).tw.
31. (affective adj2 (disorder* or disregulation or dysregulation)).tw.
32. (aggressi* or agitat*).tw.
33. agoraphobi*.tw.
34. ((alcohol* or drug* or cannabi* or cocaine* or heroin or marijuana* or narcotic* or opiate* or opioid* or substance*) adj2 (abus* or addict* or depend* or disorder* or withdrawal*)).tw.
35. ((addicti* or compulsi* or explosive or impuls*) adj2 (behavio* or disorder*)).tw.
36. (((anankastic or compulsiv* or obsessive) adj (behavio* or disorder* or neuros* or personalit*)) or OCD).tw.
37. anorexi*.tw.
38. anxiety.tw.
39. (autis* or asperger* or kanner* syndrome).tw.
40. (behavio* adj2 (disorder* or disturb* or disrupt* or dyscontrol* or illness* or issue* or outburst* or problem*)).tw.
41. (((behavio* or disorder* or episod*) adj (hypomanic or manic)) or mania*).tw.
42. (binge adj (drink* or eat*)).tw.
43. (bi polar or bipolar).tw.
44. bulimi*.tw.
45. (claustrophobi* or phobia* or phobic).tw.
46. ((combat or war) adj (disorder* or neuros*)).tw.
47. conduct disorder*.tw.
48. cyclothymi*.tw.
49. ((defiant or disrupt* or oppositional) adj (behavio* or disorder*)).tw.
50. delusion*.tw.
51. dementia praecox.tw.
52. depress*.tw.
53. ((dis integrative or disintegrative or dys integrative or dysintegrative) adj disorder*).tw.
54. (dys somnia* or dyssomnia* or insomnia* or para somnia* or parasomnia*).tw.
55. dysthymi*.tw.
56. eating disorder*.tw.
57. ((emotion* or mood) adj2 (disorder* or dis regulation or disregulation or dys regulation or dysregulation)).tw.
58. (hoarder* or hoarding).tw.
59. (hyper activ* or hyperactiv*).tw.
60. hyperphagia*.tw.
61. irritab*.tw.
62. kleptomania*.tw.
63. (minimal brain adj (dis function* or disfunction* or dys function* or dysfunction*)).tw.
64. (mood adj2 (labil* or swing*)).tw.
65. (off label* or offlabel* or unlabeled indication* or unlabeled use*).tw.
66. (panic* adj (attack* or disorder*)).tw.
67. (para suicid* or parasuicid*).tw.
68. paranoi*.tw.
69. pervasive development* disorder*.tw.
70. ((post traumatic or posttraumatic) adj2 (disorder* or neuros*)).tw.
71. ((psycho* or sociopath*) adj (disorder* or personalit*)).tw.
72. psychos*.tw.
73. PTSD*.tw.
74. (rett* adj (syndrome* or disorder*)).tw.
75. (self adj (destruct* or harm* or injur* or mutilat*)).tw.
76. (schizo affect* or schizoaffect*).tw.
77. schizophreni*.tw.
78. shell shock*.tw.
79. (sleep adj2 (disorder* or dysfunction*)).tw.
80. stress disorder*.tw.
81. tourette*.tw.
82. tic disorder*.tw.
83. unstable mood*.tw.
84. violen*.tw.
85. or/1–84
86. Neuroleptic Drugs/
87. Phenothiazine Derivatives/
88. (abilify or adasuve or aldazine or anatensol or anti naus).mp.
89. (anti psychotic* or antipsychotic*).mp.
90. (aripiprazole or arizole or asenapine or atrolak or biquelle).mp.
91. (brexpiprazole or buccastem or calmazine or cariprazine or chloractil).mp.
92. (chlorpromanyl or chlorpromazine or clopine or clozapine or clozaril).mp.
93. (compazine or compro or decazate or delucon or denzapine).mp.
94. (dozic or droleptan or droperidol or ebesque or fanapt).mp.
95. (fazaclo or fazalco or fentazin or fluphenazine or fortunan).mp.
96. (geodon or haldol or halo peridol or haloperidol or halperon).mp.
97. (iloperidone or inapsine or invega or lanzek or largactil).mp.
98. (latuda or loxapac or loxapine or loxitane or lurasidone).mp.
99. (major adj (tranquili?er* or tranquilli?er*)).mp.
100. (mellaril* or melleril or mintreleq or moban or modecate).mp.
101. (moditen or molindone or nausetil or navane).mp.
102. neuroleptic*.mp.
103. (novo adj (flurazine or peridol or ridazine or trifluzine)).mp.
104. (nu prochlor or olanzaccord or olanzapine or orap or ormazine).mp.
105. (ozidal or ozin or paliperidone or permitil or perphenazine).mp.
106. (pimozide or procalm or prochlorazine or prochlorperazine or procomp).mp.
107. (prolixin or promapar or prorazin or protran or proziere).mp.
108. (prozine or quetiapine or quetiaccord or quetin or resdone).mp.
109. (rexulti or rideril or rispa or risperdal or risperidone).mp.
110. (rispernia or rixadone or saphris or seotiapim or sequase).mp.
111. (serenace or seronia or seroquel or solazine or sonazine).mp.
112. (sondate or stelazine or stemetil or stemzine or sycrest).mp.
113. (syquet or terfluzine or thioridazine or thiothixene or thorazine).mp.
114. (tiotixene or trifluoperazine or trilafon or versacloz or vertigon).mp.
115. (vraylar or xeplion or xomolix or xylac or zaluron).mp.
116. (zaponex or zeldox or ziprasidone or zylap or zypadhera).mp.
117. (zypine or zyprexa).mp.
118. or/86–117
119. and/85,118
120. Adolescent Psychiatry/
121. Child Psychiatry/
122. exp Elementary School Students/
123. High School Students/
124. Junior High School Students/
125. Kindergarten Students/
126. Pediatrics/
127. adolescen*.mp.
128. (boy* or girl* or teen*).mp.
129. (child* or grade school* or kid or kids or kindergar?en* or minors* or preschool* or pre school* or school age* or schoolchild* or toddler*).mp.
130. ((colleg* or high school* or highschool* or middle school* or universit*) adj2 (age* or student*)).mp.
131. (paediatric* or peadiatric* or pediatric*).mp.
132. (prepubescen* or pubescen* or pubert*).mp.
133. (young* adj (adult* or men or mens or people* or person* or women*)).mp.
134. (youth or youths).mp.
135. or/120–134
136. and/119,135
137. Drug Therapy/
138. exp Experimental Design/
139. Observation Methods/
140. Treatment Effectiveness Evaluation/
141. (case control or cohort* or follow up or followup or longitudinal or prospective* or retrospective).tw.
142. ((compari* or epidemiologic* or experimental or observational) adj2 (analy* or study or studies)).tw.
143. groups.ab.
144. placebo.ab.
145. random*.ab.
146. trial.ab.
147. or/137–146
148. exp animals/not humans.sh.
149. 147 not 148
150. and/136,149
151. limit 150 to English

## Dissertations and Theses International

Database: ProQuest Dissertations & Theses Global

Search Title: Antipsychotics_Child_Update

Date Searched: 22 Oct 2015

Results: 51

((su.Exact("addictions" OR "addictive behaviors" OR "alcohol use" OR "alcoholism" OR "anorexia" OR "attention deficit disorder" OR "autism" OR "behavioral psychology" OR "bipolar disorder" OR "bulimia" OR "drug abuse" OR "drug addiction" OR "drug use" OR "eating disorders" OR "emotional disorders" OR "fear & phobias" OR "hyperactivity" OR "insomnia" OR "mental depression" OR "mental disorders" OR "panic attacks" OR "post traumatic stress disorder" OR "schizophrenia" OR "sleep disorders" OR "tourette syndrome" OR "violence") OR AB,TI(((addicti* OR compulsi* OR explosive OR impuls*) NEAR/2 (behavio* OR disorder*)) OR ADHD* OR aggressi* OR agitat* OR ((alcohol* OR drug* OR substance*) NEAR/2 (abus* OR addict* OR depend* OR disorder* OR withdrawal*)) OR (((compulsiv* OR obsessive) NEAR/1 (behavio* OR disorder* OR personalit*)) OR OCD) OR anorexi* OR anxiety OR asperger* OR "attention deficit" OR autis*) OR AB,TI((behavio* NEAR/2 (disorder* OR disturb* OR disrupt* OR illness* OR problem*)) OR "bi polar" OR (binge NEAR/1 (drink* OR eat*)) OR bipolar OR bulimi* OR ((combat OR war) NEAR/1 disorder*) OR "conduct disorder*" OR cyclothymi* OR depress*) OR AB,TI("eating disorder*" OR ((emotion* OR mood) NEAR/2 disorder) OR hyperactiv* OR hyperphagia* OR insomnia* OR irritab* OR mania* OR "off label*" OR offlabel* OR (panic* NEAR/1 (attack* OR disorder*)) OR paranoi* OR "pervasive development* disorder*" OR phobia* OR phobic OR (("post traumatic" OR posttraumatic) NEAR/2 (disorder* OR neuros*)) OR psychos* OR PTSD*) OR AB,TI("reactive disorder*" OR schizophreni* OR (self NEAR/1 (destruct* OR harm* OR injur* OR mutilat*)) OR "sleep disorder*" OR "stress disorder*" OR tourette* OR "tic disorder*" OR "unlabeled indication*" OR "unlabeled use*" OR "unstable mood*" OR violen*)) AND AB,TI("anti psychotic*" OR antipsychotic* OR aripiprazole OR asenapine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR (major NEAR/1 (tranquili?er* OR tranquilli?er*)) OR molindone OR neuroleptic* OR olanzapine OR paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone) AND ALL(adolescen* OR boy* OR child* OR girl* OR kid OR kids OR minors OR paediatric* OR pediatric* OR peadiatric* OR prepubescen* OR pubert* OR pubescen* OR "school age*" OR schoolchild* OR teen* OR (young NEAR/1 (adult* OR men OR mens OR people* OR person* OR women*)) OR youth OR youths)) NOT ALL("animal model*" OR cadaver OR nonhuman OR primate* OR rat OR rats OR zebrafish)

Additional limits - Date: From January 01 1987 to December 31 2015; Language: English

## TOXLINE

Database: TOXLINE (Toxicology Literature Online) - http://toxnet.nlm.nih.gov/cgi-bin/sis/search2

Search Title: N/A

Date Searched: 22 Oct 2015

Results: 183

### Advanced Search

- Search Term: exact words
- Records with: all the words
- Search Fields: all fields
- Do not – add chemical synonyms and CAS numbers to search
- Do not – include PubMed records
- No maximum number of results specified
- Year of publication: 1987 through 2015
- Language: English

1. (adjustment disorders [mh] OR anorexia [mh] OR anxiety [mh] OR anxiety disorders [mh] OR "Attention Deficit and Disruptive Behavior Disorders" [mh] OR behavioral symptoms [mh] OR child behavior disorders [mh] OR child development disorders, pervasive [mh] OR eating disorders [mh] OR hyperphagia [mh] OR impulse control disorders [mh] OR impulsive behavior [mh] OR irritable mood [mh] OR mental disorders [mh] OR mood disorders [mh] OR "off-label use" [mh] OR psychomotor agitation [mh] OR rett syndrome [mh] OR "schizophrenia and disorders with psychotic features" [mh] OR schizophrenia, childhood [mh] OR sleep disorders [mh] OR substance-related disorders [mh] OR tic disorders [mh] OR violence [mh])
2. (ADHD* [ab] OR "attention deficit" [ab] OR "adjustment disorder*" [ab] OR "affective disorder*" [ab] OR aggressi* [ab] OR agitat* [ab] OR "alcohol abuse" [ab] OR "alcohol addiction*" [ab] OR anorexi* [ab] OR anxiety [ab] OR autis* [ab] OR asperger* [ab] OR "bi polar" [ab] OR bipolar [ab] OR bulimi* [ab] OR "compulsive behavior*" [ab] OR "compulsive behaviour*" [ab] OR "compulsive disorder*" [ab] OR depress* [ab] OR "disintegrative disorder" OR "drug abuse" [ab] OR "drug addiction*" [ab] OR "eating disorder*" [ab])
3. (hyperactiv* [ab] OR insomnia [ab] OR irritab* [ab] OR "minimal brain dysfunction" [ab] OR "off label" [ab] OR offlabel [ab] OR "panic attack*" [ab] OR "pervasive development disorder" [ab] OR "post traumatic" [ab] OR posttraumatic [ab] OR psychos* [ab] OR PTSD* [ab] OR "schizo affect*" [ab] OR schizoaffect* [ab] OR schizophreni* [ab] OR"self harm" [ab] OR "self injury" [ ab] OR "self mutilation" [ab] OR "sleep disorder*" [ab] OR "stress disorder*" [ab] OR "substance abuse" [ab] OR "substance addiction" [ab] OR tourette* [ab] OR "tic disorder*" [ab] OR "unlabeled indication*" [ab] OR "unlabeled use*" [ab] OR violen* [ab])
4. #1 OR #2 OR #3
5. (antipsychotic agents [mh] OR butyrophenones [mh] OR phenothiazines [mh] OR thioxanthenes [mh] OR antipsychotic* OR aripiprazole OR asenapine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR molindone OR neuroleptic* OR olanzapine OR paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone)
6. #4 AND #5
7. (adolescent [mh] OR child [mh] OR pediatrics [mh] OR young adult [mh] OR adolescen* [ab] OR child* [ab] OR paediatric* [ab] OR pediatric* [ab] OR teen* [ab] OR "young adult*" [ab])
8. #6 AND #7
9. (animals [mh] OR bovine [ti] OR mice [ti] OR mouse [ti] OR nonhuman [ti] OR pig [ti] OR pigs [ti] OR porcine [ti] OR rabbit* [ti] OR rat [ti] OR rats [ti] OR zebrafish [ti])
10. #8 NOT #9

## ClinicalTrials.gov

Registry: ClinicalTrials.gov - https://clinicaltrials.gov/

Search Title: N/A

Date Searched: 26 Oct 2015

Results: 1498

### Advanced Search

1. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Adjustment Disorders" OR "Affective Disorders, Psychotic" OR "Affective Symptoms" OR Aggression OR Agoraphobia OR "Alcohol Drinking" OR "Alcohol-Related Disorders" OR Alcoholism OR "Anorexia Nervosa" OR "Anxiety Disorders" OR "Asperger Syndrome"
  Interventions >
  antipsychotics OR "anti psychotics" OR aripiprazole OR asenapine OR brexpiprazole OR cariprazine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR molindone OR olanzapine
  Age Group: Child (birth -17)
  Results: 104
2. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Adjustment Disorders" OR "Affective Disorders, Psychotic" OR "Affective Symptoms" OR Aggression OR Agoraphobia OR "Alcohol Drinking" OR "Alcohol-Related Disorders" OR Alcoholism OR "Anorexia Nervosa" OR "Anxiety Disorders" OR "Asperger Syndrome"
  Interventions>
  paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone
  Age Group: Child (birth -17)
  Results: 51
3. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Attention Deficit Disorder with Hyperactivity" OR "Attention Deficit and Disruptive Behavior Disorders" OR "Autistic Disorder" OR "Behavior, Addictive" OR " Behavioral Symptoms" OR "Binge Drinking" OR "Bipolar Disorder" OR " Bulimia Nervosa"
  Interventions >
  antipsychotics OR "anti psychotics" OR aripiprazole OR asenapine OR brexpiprazole OR cariprazine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR molindone OR olanzapine
  Age Group: Child (birth -17)
  Results: 144
4. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Attention Deficit Disorder with Hyperactivity" OR "Attention Deficit and Disruptive Behavior Disorders" OR "Autistic Disorder" OR "Behavior, Addictive" OR " Behavioral Symptoms" OR "Binge Drinking" OR "Bipolar Disorder" OR " Bulimia Nervosa"
  Interventions >
  paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone
  Age Group: Child (birth -17)
  Results: 68
5. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Child Behavior Disorders" OR " Child Development Disorders, Pervasive" OR " Cocaine-Related Disorders" OR " Combat Disorders" OR "Compulsive Behavior" OR "Conduct Disorder" OR "Cyclothymic Disorder" OR Depression OR "Depressive Disorder"
  Interventions >
  antipsychotics OR "anti psychotics" OR aripiprazole OR asenapine OR brexpiprazole OR cariprazine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR molindone OR olanzapine
  Age Group: Child (birth -17)
  Results: 66
6. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Child Behavior Disorders" OR " Child Development Disorders, Pervasive" OR " Cocaine-Related Disorders" OR " Combat Disorders" OR "Compulsive Behavior" OR "Conduct Disorder" OR "Cyclothymic Disorder" OR Depression OR "Depressive Disorder"
  Interventions >
  paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone
  Age Group: Child (birth -17)
  Results: 31
7. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Depressive Disorder, Major" OR " Depressive Disorder, Treatment-Resistant" OR "Dissociative Disorders" OR "Drinking Behavior" OR "Drug-Seeking Behavior" OR Dyssomnias OR "Dysthymic Disorder" OR "Eating Disorders"
  Interventions >
  antipsychotics OR "anti psychotics" OR aripiprazole OR asenapine OR brexpiprazole OR cariprazine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR molindone OR olanzapine
  Age Group: Child (birth -17)
  Results: 17
8. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Depressive Disorder, Major" OR " Depressive Disorder, Treatment-Resistant" OR "Dissociative Disorders" OR "Drinking Behavior" OR "Drug-Seeking Behavior" OR Dyssomnias OR "Dysthymic Disorder" OR "Eating Disorders"
  Interventions >
  paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone
  Age Group: Child (birth -17)
  Results: 5
9. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Feeding and Eating Disorders of Childhood" OR "Heroin Dependence" OR "Impulse Control Disorders" OR "Impulsive Behavior" OR "Marijuana Abuse" OR "Mental Disorders" OR "Mental Disorders Diagnosed in Childhood" OR "Mood Disorders"
  Interventions >
  antipsychotics OR "anti psychotics" OR aripiprazole OR asenapine OR brexpiprazole OR cariprazine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR molindone OR olanzapine
  Age Group: Child (birth -17)
  Results: 272
10. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Feeding and Eating Disorders of Childhood" OR "Heroin Dependence" OR "Impulse Control Disorders" OR "Impulsive Behavior" OR "Marijuana Abuse" OR "Mental Disorders" OR "Mental Disorders Diagnosed in Childhood" OR "Mood Disorders"
  Interventions >
  paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone
  Age Group: Child (birth -17)
  Results: 130
11. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Obsessive-Compulsive Disorder" OR "Opioid-Related Disorders" OR "Panic Disorder" OR Parasomnias OR "Phobic Disorders" OR "Psychomotor Agitation" OR "Psychotic Disorders" OR Schizophrenia OR "Schizophrenia and Disorders with Psychotic Features"
  Interventions >
  antipsychotics OR "anti psychotics" OR aripiprazole OR asenapine OR brexpiprazole OR cariprazine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR molindone OR olanzapine
  Age Group: Child (birth -17)
  Results: 279
12. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Obsessive-Compulsive Disorder" OR "Opioid-Related Disorders" OR "Panic Disorder" OR Parasomnias OR "Phobic Disorders" OR "Psychomotor Agitation" OR "Psychotic Disorders" OR Schizophrenia OR "Schizophrenia and Disorders with Psychotic Features"
  Interventions >
  paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone
  Age Group: Child (birth -17)
  Results: 133
13. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Schizophrenia and Disorders with Psychotic Features" OR "Schizophrenia, Childhood" OR "Schizophrenia, Disorganized" OR "Schizophrenia, Paranoid" OR "Schizotypal Personality Disorder" OR "Self Mutilation" OR "Self-Injurious Behavior"
  Interventions >
  antipsychotics OR "anti psychotics" OR aripiprazole OR asenapine OR brexpiprazole OR cariprazine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR molindone OR olanzapine
  Age Group: Child (birth -17)
  Results: 118
14. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Schizophrenia and Disorders with Psychotic Features" OR "Schizophrenia, Childhood" OR "Schizophrenia, Disorganized" OR "Schizophrenia, Paranoid" OR "Schizotypal Personality Disorder" OR "Self Mutilation" OR "Self-Injurious Behavior"
  Interventions >
  paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone
  Age Group: Child (birth -17)
  Results: 53
15. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Sleep Disorders" OR "Stress Disorders, Post-Traumatic" OR "Stress Disorders, Traumatic" OR "Stress Disorders, Traumatic, Acute" OR "Substance-Related Disorders" OR "Suicidal Ideation" OR "Tic Disorders" OR "Tourette Syndrome"
  Interventions >
  antipsychotics OR "anti psychotics" OR aripiprazole OR asenapine OR brexpiprazole OR cariprazine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR molindone OR olanzapine
  Age Group: Child (birth -17)
  Results: 22
16. First Received: From 01/01/1987 to 12/31/2015
  Targeted Search –
  Conditions by category > Behaviors and Mental Disorders
  "Sleep Disorders" OR "Stress Disorders, Post-Traumatic" OR "Stress Disorders, Traumatic" OR "Stress Disorders, Traumatic, Acute" OR "Substance-Related Disorders" OR "Suicidal Ideation" OR "Tic Disorders" OR "Tourette Syndrome"
  Interventions >
  paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone
  Age Group: Child (birth -17)
  Results: 5
  Total records downloaded: 1498
  Total unique records: 295

## WHO ICTRP

Registry: WHO International Clinical Trials Registry Platform

Search Title: N/A

Date Searched: 27 Oct 2015

Results: 317

### Advanced Search

1. Search for clinical trials in children (0–18)
  Recruitment status is: ALL
  Intervention >
  antipsychotics OR aripiprazole OR asenapine OR brexpiprazole OR cariprazine OR chlorpromazine OR clozapine OR droperidol OR fluphenazine OR haloperidol OR iloperidone OR loxapine OR lurasidone OR molindone OR olanzapine
  Results: 153
2. Search for clinical trials in children (0–18)
  Recruitment status is: ALL
  Intervention >
  paliperidone OR perphenazine OR pimozide OR prochlorperazine OR quetiapine OR risperidone OR thiothixene OR thioridazine OR trifluoperazine OR ziprasidone
  Results: 164