# Appendix A Changes From Original Review

The Key Questions (KQs) from the original CER were reviewed by a stakeholder panel and underwent a public comment process via the AHRQ Effective Health Care Program website. There have been a few changes to the KQs. Rather than distinguishing between benefit outcomes primarily by type of outcome (symptom vs. other outcomes), they will be reported by timing and importance to patients; there is now only one KQ for benefits. Moreover, to enhance reporting on subgroups the previous KQ on subgroups has been integrated into the KQs on benefits and harms. The original CER used terminology specific to the Diagnostic and Statistical Manual of Mental Disorders – Fourth Edition (DSM-IV), and the conditions for this update have been revised according to changes in the DSM-V (e.g., pervasive developmental disorders is currently classified as an autism spectrum disorder) published in 2013.^1^ None of these changes were anticipated to impact the categorization or inclusion of previous studies for this update. Diagnosis of study participants based on DSM-V was not mandatory for study inclusion. Specific changes are described below in terms of the PICOTS (population, intervention, comparators, outcomes, timing, and setting).

## Population

In terms of the study population, there has been the (1) addition of depressive disorders, anxiety disorders, and substance use disorders; (2) broadening of anorexia nervosa to include other eating disorders, and of Tourette’s syndrome to include all tic disorders; and (3) specification that the category of behavioral issues includes treatment of symptoms outside the context of a disorder, as for example when antipsychotics are prescribed for sedation/sleep within certain environmental contexts (e.g., residential facilities). While these latter uses of antipsychotics are not endorsed by guidelines or indicated for antipsychotic use as per FDA approval, it was thought important by our stakeholders to review the evidence on all current uses of antipsychotics to provide information of benefit and harms for a broad range of stakeholders. The subgroups have been modified slightly to include phase and features of disorder (e.g., acute vs. maintenance treatment), medication dose, and use for cases of refractory treatment; these reflect some major components of the uncertainty currently faced by many clinicians. We have indicated the difference between patient- and intervention-level characteristics (i.e., dose and co-interventions).

## Interventions and Comparators

One long-standing FDA-approved FGA (molindone) was discontinued at the time of the original CER, but a generic has recently received approval for marketing and therefore this FGA has been added as an eligible antipsychotic. The SGA lurasidone was approved by the FDA in 2010 (for schizophrenia and later for bipolar depression, both in adults) and was not reviewed in the original CER. Two other SGAs were approved in 2015: brexpiprazole in July for schizophrenia and adjunctive treatment of major depression in adults, and cariprazine in September for schizophrenia and bipolar disorder in adults. The comparators remain the same: placebo/no treatment, same antipsychotic of different dose, and another antipsychotic.

## Outcomes

There have been changes to the terminology and classification of some outcomes, for example removal of the wording “patient- or family-reported outcomes” from a single outcome, because several of the outcomes are measured by patient/family report. Despite changes, all of the previous included outcomes will be captured in some manner. There has been the addition of an outcome for global impressions, which captures symptoms and overall clinical improvement, severity, and functioning. The outcomes related to harms have been modified slightly to have better consistency with the categories of major and general adverse effects. The outcomes that will be graded for strength of evidence have been modified to be more precise for symptoms that are treated with antipsychotics for each condition (e.g., “autistic symptoms” has been replaced with irritability) and to reflect any changes to terminology and classification.

## Timing and Setting

The same criteria will be used for timing (1987 or later) and setting (all settings). Outcomes will be categorized in terms of short- (<6 months) and long- (≥ 6 months – <12 months; 12 months+) term followup.

## Study Design

The original inclusion criteria for study design have been broadened slightly to include additional forms of observational studies beyond comparative cohort studies; we included controlled before-and-after studies as well as pooled analysis of individual patient data from trials.

## Methods

There were a few methodological changes to align the methods with current guidance of AHRQ’s EPC program, and to potentially enhance our ability to inform decisions in some areas. The original assessment of SOE was frequently downgraded due to high risk of bias for the relevant studies, which included consideration of industry funding. Refinement in EPC program methods guidance on risk of bias assessments of individual studies, in particular in relation to the role of industry funding, may not lead to similar assessments in the updated review.^2^ For some outcomes (especially harms which were evaluated across disorders), the use of mixed-comparison meta-analytical techniques (i.e., combining placebo and head-to-head trials across a variety of drug comparison) may be possible and allow for more quantitative assessment of differences between antipsychotics in the absence of many head-to-head trials. Moreover, the assessment of findings for patient and clinical subgroups relied upon within-study analyses which were highly variable and did not encompass harms data; applying analytical techniques with study-level data—although exploratory in nature^3^—would allow for examining the related key questions (KQ1a, b; KQ2 a, b) to a greater extent. Lastly, differences in some harms outcomes (e.g., weight gain and metabolic risks) have been shown to vary by condition,^4, 5^ such that only using aggregate data on harms across conditions may not capture some information important for patient-level decision making. We attempted to differentiate the impact on harms within as well as across conditions.

## References

1 Association AP. Diagnostic and statistical manual of mental disorders, fifth edition. Washington, DC: American Psychiatric Association 2013.
2 Viswanathan M, Ansari MT, Berkman ND, . Assessing the risk of bias of individual studies in systematic reviews of health care interventions methods guide for effectiveness and comparative effectiveness reviews. Rockville MD 2008.
3 Higgins JPT, Green, S. Chapter 9: Analyzing data and undertaking meta-analysis Cochrane Handbook for Systematic Reviews of Interventions: The Cochrane Collaboration; 2009.
4 De Hert M, Dobbelaere M, Sheridan EM, . Metabolic and endocrine adverse effects of second-generation antipsychotics in children and adolescents: A systematic review of randomized, placebo controlled trials and guidelines for clinical practice. Eur Psychiatry. 2011 Apr;26(3):144–58. PMID: 21295450.21295450
5 Maayan L, Correll CU. Weight gain and metabolic risks associated with antipsychotic medications in children and adolescents. J Child Adolesc Psychopharmacol. 2011 Dec;21(6):517–35. PMID: 22166172.22166172