# Abbreviations and Acronyms

AACAP: American Academy of Child and Adolescent Psychiatry
AD: anxiety disorders
ADHD: attention-deficit/hyperactivity disorder
ADHD/DICD: attention-deficit/hyperactivity disorder, or disruptive, impulse-control, or conduct disorders
AE: adverse effect
AHRQ: Agency of Healthcare Research and Quality
ASD: autism spectrum disorders
BD: bipolar disorder
BI: behavioral issues outside of diagnosis
Bid: ‘bis in die’ or ‘twice a day’
BMI: body mass index
CD: conduct disorder
CER: comparative effectiveness review
CI: confidence interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CPT: continuous performance task
CrI: credible interval (reported when applying Bayesian meta-analyses)
CVLT: continuous verbal learning test
DBD: disruptive behavior disorder
DD: depressive disorders
DSM-IV: Diagnostics and Statistical Manual of Mental Disorders, 4^th^ Edition
DSM-IV-TR: Diagnostics and Statistical Manual of Mental Disorders, 4^th^ Edition, Text Revision
DSM-V: Diagnostics and Statistical Manual of Mental Disorders, 5^th^ Edition
EBSCO: Elton B. Stephens Co.
ECG: echocardiographic
ED: eating disorder
EMBASE: Excerpta Medica dataBASE
EPC: evidence-based practice center
EPS: extrapyramidal symptoms
ER: extended release
FDA: Food and Drug Administration
FGA: first-generation antipsychotic
G: group
GAD: general anxiety disorder
HDL: high-density lipoprotein
HR: hazard ratio
I^2^: test for heterogeneity
IQ: intelligence quotient
IQR: interquartile range
kg: kilogram
kg·m^−2^: kilogram per meter square
KI: key informant
KQ: key question
LDL: low-density lipoprotein
m: meter
MAE: major adverse effect
MD: mean difference
MDD: major depressive disorder
MEDLINE: Medical Literature Analysis and Retrieval System Online
mg: milligram
mg/day: milligram per day
mg/kg/day: milligram per kilogram per day
mo: month
MR: mental retardation
N: number
NA: not applicable
NMS: neuroleptic malignant syndrome
NOS: not otherwise specified
NR: not reported
NRCT: nonrandomized controlled trial
OCD: obsessive-compulsive disorder
ODD: oppositional defiant disorder
PDD: pervasive developmental disorder
PDD-NOS: pervasive developmental disorder- not otherwise specified
PICOTS: populations, interventions, comparators, outcomes, timing, settings
PICOTS-D: populations, interventions, comparators, outcomes, timing, settings, digital data
PTSD: posttraumatic stress disorder
QTc: corrected QT interval
QTcB: Bazett’s corrected QT interval
QTcF: Fridericia’s corrected QT interval
QTcLD: QT interval corrected for heart rate using the population specified linear derived method
RCT: randomized controlled trial
ROB: risk of bias
RR: risk ratio
SA: substance abuse
SD: standard deviation
SGA: second-generation antipsychotic
SMD: standardized mean difference
SOE: strength of evidence
SSRIs: selective serotonin reuptake inhibitors
Std.: standardized
SUD: substance use disorder
SZ: schizophrenia and related psychosis
TD: tic disorders
TEP: technical expert panel
TOXLINE: toxicology literature online
vs.: versus
wk: week
yr: year

Outcome measures (with ranges for scales used in assessment of strength of evidence)
ABC: Aberrant Behavior Checklist subscale score (subscales: irritability [range 0–45], lethargy/social withdrawal [range 0–48], stereotypic behavior [range 0–21], hyperactivity/noncompliance [range 0–48], inappropriate speech [range 0–12]).
ABC-I: Aberrant Behavior Checklist Irritability subscale
ADHD-SC4: ADHD Symptom Checklist-4
BPRS: Brief Psychiatric Rating Scale (range 24–168)
CARS: Childhood Autism Rating Scale
CASI-4R: Child and Adolescent Symptom Inventory-4R
CDRS-R: Children’s Depression Rating Scale-Revised (17–113)
C-GAS: Global Assessment Scale for Children (range 1–100)
CGI-BP: Clinical Global Impressions for Bipolar Illness
CGI-I: Clinical Global Impression-Improvement score (7-point scale)
CGI-S: Clinical Global Impression-Severity score (7-points scale)
CHQ-PF50: Child Health Questionnaire
CPRS: Conners Parent Rating Scale (subscores: conduct problem, learning problem, psychosomatic, impulsive-hyperactive, anxiety, and hyperactivity index)
CY-BOCS: Children’s Yale-Brown Obsessive Compulsive Scale (total 0–40; compulsions subscore 0–20)
GAF: Global Assessment of Functioning (range 1–100)
HAM-D: Hamilton Depression Rating Scale
IDS: Inventory of Depressive Symptomatology
MADRS: Montgomery-Åsberg Depression Rating Scale
NCBRF: Nisonger Child Behavior Rating Form (Problem Behaviors subscale score [conduct problem (range 0–16); insecure/anxious; hyperactive (range 0–9); self-injury/stereotypic; self-isolated/ritualistic; overly sensitive])
OAS: Overt Aggression Scale
PANSS: Positive and Negative Syndrome Scale (PANSS Total (range 30–210), PANSS Negative subscale (range 7–49), PANSS Positive subscale (range 7–49), PANSS General psychopathology; cluster for PANSS Anxiety/depression)
RAAPP: Rating of Aggression Against People and/or Property
SANS: Scale for the Assessment of Negative Symptoms (range 0–25)
SNAP-IV: Swanson, Nolan, and Pelham rating scale
TSGS: Tourette Syndrome Global Scale
YMRS: Young Mania Rating Scale (11-items; total range 0–60)
YGTSS: Yale Global Tic Severity Scale (Total 0–100; Total Tics 0–50)