# Results

## Results of Literature Searches for Key Questions

We identified 9608 nonduplicative titles or abstracts with potential relevance, with 1966 proceeding to full text review (Figure 1). We excluded 1725 studies at full text review. We included 218 unique studies (241 publications) in the review. These 218 studies included 165 comparative studies and 53 case series or database or registry studies providing data on harms only.

Figure 1 Disposition of studies identified for this review

† 3 papers each reported 2 unique studies in each paper. Numbers next to each Key Question indicate number of unique studies addressing the question. Studies could address more than one Key Question.

* Numbers do not tally as studies could be excluded for multiple reasons.

Abbreviations: KQ = Key Question; n = Number.

Figure 1 outlines the disposition of studies identified for this review. We identified 9608 nonduplicative titles or abstracts with potential relevance, with 1966 proceeding to full text review. We excluded 1725 studies at full text review. We included 218 unique studies (241 publications) in the review.

### Description of Included Studies

The 218 unique included studies (reported in multiple publications) comprised 141 randomized controlled trials (RCTs),^6, 9, 38-192^12 nonrandomized trials,^6, 179, 193-202^ seven prospective^203-209^ and five retrospective cohort studies,^210-214^ 53 database or registry studies or case series with at least 1000 children (Table 5).^21, 215-276^ We used database and registry studies and case series for harms data only. We considered 67 studies to have low risk of bias, ^21, 39-41, 43, 49-54, 56, 57, 59, 69, 70, 75, 76, 88-90, 93, 94, 97, 98, 105, 112, 113, 115, 118-120, 123, 125, 128, 131-136, 144, 146, 151, 155, 156, 163, 167-170, 217-222, 225, 226, 228, 229, 231, 233, 235, 236, 241, 247, 248, 250, 251, 258, 266-271^ 110 to have moderate risk, ^9, 38, 42, 44-48, 58, 60, 62-64, 66, 71, 72, 74, 78-80, 82-87, 91, 92, 95, 96, 103, 106, 107, 109-111, 114, 116, 117, 121, 122, 124, 126, 127, 130, 138, 139, 141, 142, 145, 147-150, 152, 154, 157-161, 164, 166, 171-186, 190-192, 194-197, 200, 201, 203, 206, 207, 210, 211, 213-216, 223, 224, 227, 230, 232, 234, 238, 242, 245, 246, 249, 252, 253, 255-257, 259-263, 272-277^ and 41 to have high risk.^6, 55, 61, 65, 67, 68, 73, 77, 81, 99-102, 104, 108, 129, 137, 140, 143, 153, 162, 187-189, 193, 198, 199, 202, 204, 205, 208, 212, 237, 239, 240, 243, 244, 264, 265, 278^

Table 5 Overview of studies addressing tonsillectomy in children

Characteristic | RCTs (n=141) | Nonrandomized Trials (n=12) | Prospective Cohort Studies (n=7) | Retrospective Cohort Studies (n=5) | Case Series, Database, or Registry Studies Reporting Harms (n=53) | Total Literature
Key Question
KQ1 and 1a-d | 3 | 1 | 6^*^ | 3 | 0 | 13
KQ2 | 5 | 2 | 0 | 2 | 0 | 9
KQ3 | 20 | 2 | 0 | 0 | 0 | 22
KQ4 | 54 | 4 | 1 | 0 | 0 | 59
KQ5 | 48 | 1 | 0 | 0 | 0 | 49
KQ6 | 11 | 2 | 0 | 0 | 0 | 13
Harms | 99 | 10 | 1 | 2 | 53 | 165
Surgical Indication
OSDB | 27 | 3 | 5 | 3 | 4 | 42
Throat Infection | 14 | 5 | 0 | 2 | 1 | 22
OSDB+Throat Infection | 42 | 2 | 1 | 0 | 20 | 66
Not Specified | 58 | 2 | 1 | 0 | 28 | 89
Region of Study Conduct
Africa | 11 | 1 | 0 | 0 | 0 | 12
Asia | 55 | 5 | 2 | 0 | 5 | 67
Australia/New Zealand | 6 | 0 | 1 | 0 | 3 | 10
Europe | 35 | 4 | 2 | 1 | 22 | 64
North America | 33 | 2 | 0 | 4 | 23 | 62
South America | 1 | 0 | 2 | 0 | 0 | 3
Risk of Bias
Low | 48 | 0 | 0 | 0 | 19 | 67
Moderate | 69 | 7 | 3 | 4 | 27 | 110
High | 24 | 5 | 4 | 1 | 7 | 41
Total N participants | 17506 | 2875 | 518 | 14350 | 1810403 | 1845652

* One prospective cohort study addressed both KQ1 and KQ2.^209^ This table includes the study only under KQ1.

KQ = Key Question; N = Number; OSDB = Obstructive Sleep-Disordered Breathing; RCT = Randomized Controlled Trial

Studies were conducted globally (Table 5), with most conducted in the United States (n=56, including 4 unique studies published in 2 papers),^6, 9, 21, 47, 54, 66, 68, 70, 77, 85, 90, 92, 93, 95, 97-99, 107, 108, 110, 112, 114, 116, 120, 122, 124, 126, 130, 151, 171-178, 191, 201, 211-214, 223, 224, 227, 228, 232-237, 247, 248, 256, 261, 266-268, 270, 272, 273, 279^

United Kingdom (n=22, including 2 unique studies reported in one paper), ^56, 75, 102, 103, 123, 125, 131, 134, 179, 210, 217-219, 225, 226, 231, 238, 241, 243, 245, 259, 260, 262, 274^ Turkey (n=19), ^45, 48, 61, 65, 67, 73, 76, 80, 84, 101, 104-106, 113, 121, 139, 143, 194, 195^ and Egypt (n=12).^40, 42, 51, 52, 100, 119, 142, 152, 158, 159, 163, 196^ Sixty-nine studies were conducted in developing or emerging nations (including, among others, Turkey, Egypt, Iran, Pakistan, Brazil, India, and China) according to United Nations classification.^39, 40, 42, 44-46, 48, 50-52, 55, 61-63, 65, 67, 71-73, 76, 79, 80, 84, 87, 91, 100, 101, 104-106, 109, 113, 117, 119, 121, 139-144, 146-149, 152, 154, 156-163, 188, 189, 194-196, 200, 202, 204-206, 208, 244, 246, 265,280^ Ages of children in studies ranged widely from less than 1 to over 18 (mean age ≤18 in all studies), and studies included a total of 1,845,683 children. Most studies did not specify an indication for tonsillectomy (n=89); ^38, 39, 42, 46, 47, 49, 50, 64, 72, 73, 75, 76, 79, 87, 88, 92-94, 100, 103, 105, 106, 109, 112, 113, 115, 117-119, 121-123, 126-128, 132, 133, 135-138, 140, 141, 146-150, 153, 154, 156-159, 161, 167, 168, 188, 190, 199, 202, 207, 216, 225-229, 231-234, 241-243, 245-248, 250, 251, 255, 257, 259, 261, 262, 265, 268, 271, 272, 274-276^ 65 studies included children with both obstructive sleep-disordered breathing (OSDB) and throat infections; ^9, 21, 41, 43, 48, 54, 57, 59-62, 65, 66, 68-70, 74, 78, 81-83, 89, 96, 99, 102, 104, 108, 110, 111, 116, 120, 130, 131, 134, 144, 145, 155, 162, 164-166, 169, 170, 182-184, 192, 194, 195, 209, 215, 217-219, 223, 224, 235-240, 249, 252, 253, 256, 258, 260, 263, 266, 267, 270, 273^ 42 specifically noted OSDB as the surgical indication;^44, 53, 58, 63, 67, 71, 77, 84-86, 90, 95, 97, 98, 101, 107, 114, 124, 129, 139, 143, 151, 160, 171-178, 185-187, 189, 191, 193, 198, 201, 203-206, 208, 211, 212, 214, 220-222, 230, 264, 269^ and 22 specifically noted recurrent throat infections as the indication.^6, 40, 45, 51, 52, 55, 56, 80, 91, 125, 142, 152, 163, 179-181, 196, 197, 200, 210, 213, 244^

### Gray Literature

We did not receive any materials from Federal Register notices. We sought reports of study protocols identified in ClinicalTrials.gov and other registers to assess for reporting bias but identified very few trials (n=8). Our gray literature searches did not contribute additional studies not identified in our database searches.

## Key Question 1 Effectiveness of Tonsillectomy Versus No Surgery for OSDB

### Key Points

- In five studies of children with polysomnography (PSG) proven OSDB, respiratory parameters measured using the Apnea Hypopnea Index (AHI) improved more in children receiving tonsillectomy than those not undergoing surgery. In a meta-analysis of three studies, children who underwent tonsillectomy had a 4.8-point improvement in AHI scores compared with those who did not have surgery (95% credible interval: -6.5 to -3.1). The clinical significance of this improvement is likely influenced by baseline disease severity and may be most obvious in children with mild or moderate OSDB (i.e., AHI scores of 1 to 10).
- For tonsillectomy compared with no surgery, we found greater improvement in AHI and negative behaviors with tonsillectomy vs. watchful waiting. Our confidence in these conclusions is low (low strength of evidence). We also found consistently greater improvement in sleep-related quality of life with tonsillectomy vs. watchful waiting and have greater confidence in this conclusion (moderate strength of evidence).
- We could not make conclusions about effects on executive function or intelligence quotient (IQ) (insufficient strength of evidence).
- We could not make conclusions about outcomes following tonsillectomy compared with continuous positive airway pressure (CPAP) and in studies assessing outcomes in sub-populations such as children with Down syndrome (KQ1a-d) (insufficient strength of evidence).

### Overview of the Literature

We identified 13 unique studies (20 papers, 1180 participants) addressing tonsillectomy in children with OSDB (Table 6).^44, 114, 171, 172, 174-178, 191, 201, 203-206, 208, 209, 211, 212, 214^ One prospective cohort study included both children with OSDB and recurrent throat infection and did not report baseline data or outcomes by indication.^209^

Table 6 Overview of studies addressing tonsillectomy in children with OSDB

Characteristic | RCTs | Nonrandomized Trial | Prospective Cohort Studies | Retrospective Cohort Studies | Total Literature
Comparisons
Watchful Waiting or No Surgery | 2 | 1 | 6 | 2 | 11
CPAP | 1 | 0 | 0 | 1 | 2
Effectiveness Outcomes Frequently Reported
AHI | 3 | 0 | 2 | 3 | 8
Sleep-related Quality of Life (OSA-18, M-ESS, PSQ) | 2 | 1 | 1^*^ | 1 | 5
Executive Function, Cognitive, or Behavioral Measure | 1 | 0 | 2 | 1 | 4
Risk of Bias
Low | 0 | 0 | 0 | 0 | 0
Moderate | 3 | 1 | 2 | 2 | 8
High | 0 | 0 | 4 | 1 | 5
Total N participants | 529 | 64 | 386 | 106 | 1085

AHI = Apnea–Hypopnea Index; CPAP = Continuous Positive Airway Pressure; M-ESS = Modified Epworth Sleepiness Scale; N = Number; OSA-18 = Obstructive Sleep Apnea-18; OSDB = Obstructive Sleep-Disordered Breathing; PSQ = Pediatric Sleep Questionnaire; RCT = Randomized Controlled Trial

* Reports the T14 Pediatric Throat Disorders Outcome Test

Most studies were conducted in the United States (n=6),^114, 171-176, 178, 191, 201, 211, 212, 214^ two in Brazil,^205, 281^ two in Israel,^204, 206^ and one each in Ireland,^209^ Australia^203^ and India.^44^ Three studies were RCTs, including one multiple-publication study.^44, 114, 171-178^ Six were prospective^203-206, 208, 209^ and three were retrospective cohort studies.^211, 212, 214^ One study was a nonrandomized trial.^201^

Eleven studies compared tonsillectomy to watchful waiting (which could have included supportive treatment with medications such as nasal steroids) or no surgery.^114, 171-178, 191, 201, 203-206, 208, 209, 211, 214^ Two studies compared CPAP or oxygen with tonsillectomy.^44, 212^ Participant ages ranged from less than 2 years to 16 years across studies. Studies frequently reported change in AHI and cognitive or behavioral outcomes.

We considered eight studies to have moderate risk of bias^44, 114, 171-178, 191, 201, 203, 206, 211, 214^ and five to have high risk of bias.^204, 205, 208, 209, 212^ Major sources of bias in these studies included the use of unblinded outcome assessors and unclear impact of concurrent interventions or variations in study execution. Given the relatively few studies addressing this question, we retained retrospective studies with low or moderate risk of bias as part of the evidence base. We retained high risk of bias studies in meta-analyses after sensitivity analyses reveal no significant effects on findings.

### Detailed Analysis

#### Tonsillectomy Versus No Surgery or Watchful Waiting With Supportive Care

##### OSDB-Related Outcomes

Five studies (reported in multiple publications) of moderate^114, 171-178, 191, 203, 211, 214^ risk of bias evaluated the improvement in AHI among children with PSG-proven OSDB. Two studies were RCTs, including the multi-publication Childhood Adenotonsillectomy Trial (CHAT);^114, 171-178^ one was a prospective^203^ and two were retrospective cohort studies,^211, 214^ All reported improvement in children after tonsillectomy compared with observation without intervention or with supportive/medical management (excluding CPAP). The watchful waiting groups also improved from baseline in three studies.^114, 171-178, 191, 211^ Differences in AHI between tonsillectomy and watchful waiting groups were statistically significant in three studies^171-178, 191, 211, 214^ and not significant in two (Table 7).^114, 203^ This benefit was consistent across age ranges (1-18 years), though data were most frequently available on children ages 4 to 12. Benefits seemed durable, with followup ranging from 6 months to 4 years. Where reported, the respiratory disturbance index and oxygen saturation improved significantly after tonsillectomy.^114, 172^ Further, in a single, small low risk of bias study, tonsillectomy was associated with clinical benefit in symptoms of children with diagnoses of sleep apnea based on history, but with negative polysomnograms.^114^ This study is quite small, however, with fewer than 40 participants.

Table 7 Key OSDB-related outcomes in studies comparing tonsillectomy with watchful waiting in children with OSDB

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Baseline AHI Scores (Mean±SD) | Followup AHI Scores (Mean±SD)
Trosman 2016^214^ Retrospective Cohort Moderate ROB | G1: Tonsillectomy (18) G1a: Tonsillectomy – obese children (8) G1b: Tonsillectomy – Syndromic children (6) G2: Watchful waiting with supportive care (44) G2a: Watchful waiting with supportive care, obese children (11) G2b: Watchful waiting with supportive care, Syndromic children (9) | G1: 3.5 ± 1.1 G1a: 3.83 G1b: 3.08 G2: 3.09 ± 1.1 G2a: 3.2 G2b: 3.31 | 16-month followup (IQR) G1: 2.69 (1.48 to 3.9) G1a: 3.08 G1b: 2.03 G2: 5.18 (2.46 to 7.9) G2a: 3.4 G2b: 2.84 G1 vs G2: p=0.03 G1a vs G2a: p=0.25 G1b vs G2b: p=0.36
Marcus 2014^171-178, 191^ RCT Moderate ROB | G1: Tonsillectomy (193) G2: Watchful Waiting with Supportive Care (208) | Events/hour, median (IQR) G1: 4.8 (2.7 to 8.8) G2: 4.5 (2.5 to 8.9) | Events/hour, change from baseline to 7 months (IQR) G1: -3.5 (-7.1 to -1.8) G2: -1.6 (-3.7 to 0.5) G1 vs. G2: p < 0.001 Effect size: 0.57
Biggs 2014^203^ Prospective Cohort Moderate ROB | G1: Tonsillectomy or Nasal Steroids (12) G2: Watchful waiting with supportive care (27) | Events/hour G1: 9.4 ± 9.9 G2: 1.0 ± 1.2 | Events/hour (4 year followup) G1: 1.8 ± 5.2 G2: 1.7 ± 6.0 G1 vs. G2: p=NS
Burstein 2013^211^ Retrospective Cohort^*^ Moderate ROB | G1: Tonsillectomy (16) G2: Watchful waiting with supportive care (16) | G1: 14.4 (median) G2: 9.3 (median) | G1: 1.1 (median), median change=10.3 G2: 3.7 (median), median change=6.5 G1 vs. G2, median change: p=0.04
Goldstein 2004^114^ RCT Moderate ROB | G1: PSG+ plus Tonsillectomy (21) G2: PSG- plus Tonsillectomy (11) G3: PSG- plus Watchful Waiting (9) | G1: 6.2 (median) G2: 0.5 (median) G3: 0.6 (median) | 6-month followup G1: 0.9 (median) G2: 0.4 (median) G3: 0 G2 vs. G3: p=NS

* Note: Followup periods differed in this study: mean 1.4 years in the tonsillectomy group and 2.0 years in the no surgery group, p=0.02^211^ IQR = Interquartile Range; n = Number; OSDB = Obstructive Sleep-Disordered Breathing; PSG = Polysomnography; NR = Not Reported; NS = Not Significant; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

We combined three studies (the CHAT RCT, reported in multiple publications,^171-178, 191^ and one prospective^211^ and retrospective^204^ study) reporting AHI outcomes in a fixed effects meta-analysis. We estimated an effect size of -4.81 (95% credible interval: -6.5 to -3.1), indicating a reduction (improvement) in AHI of 4.81 points in children receiving tonsillectomy compared with those not undergoing surgery. The clinical significance of this improvement is likely influenced by baseline disease severity and may be most obvious in children with mild or moderate OSDB (i.e., AHI scores of 1 to 10).Whether this degree of change is clinically important to patients' quality of life is not clear.

##### Sleep-Related Quality of Life

Two RCTs,^114, 171, 172, 174-178^ one nonrandomized trial,^201^ and one retrospective cohort^211^(all rated as moderate risk of bias) assessed comparative effectiveness of tonsillectomy versus no surgery in the improvement of sleep quality (Table 8). Studies used several different parent-reported quality measures to assess sleep quality outcomes, limiting the ability to compare effectiveness directly across studies, although outcomes were consistently better in children receiving tonsillectomy.

Table 8 Key sleep-related quality of life outcomes in studies comparing tonsillectomy and no surgery in children with OSDB

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Outcome Measure Baseline (Mean±SD) | Outcome Measure Followup (Mean±SD)
Volksy 2014^201^ Nonrandomized trial G1: Tonsillectomy (30) G2: Observation (34) Moderate ROB | G1: Tonsillectomy (30) G2: Watchful waiting with supportive care (34) | OSA-18 Total Score G1: 72.3 ± 20 G2: 58.5 ± 21.5 | 3 months followup OSA-18 Total Score G1: 33.9 ± 14.6 G2: 58.2 ± 24.5 G1 vs G2: p=0.0001 8 months followup OSA-18 Total Score G1: 33.6 ± 8.6 G2: 45.1 ± 21.9 G1 vs G2: p=NS
Marcus 2014^171-178, 191^ RCT Moderate ROB | G1: Tonsillectomy (193) G2: Watchful waiting with supportive care (208) | OSA-18 Total Score G1: 53.1 ± 18.3 G2: 54.1 ± 18.8 PSQ G1: 0.5 ± 0.2 G2: 0.5 ± 0.2 M-ESS G1: 7.1 ± 4.7 G2: 7.5 ± 5.2 PedsQL G1: 77.3 ± 15.3 G2: 76.5 ± 15.7 | OSA-18 Total Score, change from baseline G1: -21 ±16.5 G2: -4.5 ± 19.3 G1 vs. G2: p≤0.01 Effect size:-0.93 PSQ, change from baseline G1: -0.3 ±0.2 G2: -0.0 ± 0.2 G1 vs. G2: p≤0.01 Effect size: -1.35 M-ESS, change from baseline G1: -2.01 ± 4.7 G2: 0.28 ± 4.1 G1 vs. G2: p < 0.01 Effect size: -0.42 PedsQL, change from baseline to 7 months G1: 5.9 ± 13.6 G2: 0.9 ± 13.3 G1 vs. G2: p≤0.001 Effect size: 0.37
Burstein 2013^211^ Retrospective Cohort Moderate ROB | G1: Tonsillectomy (16) G2: Watchful waiting with supportive care (16) | CAS-15 G1: NR G2: NR | CAS-15 G1: 8.9 ± 6.1 G2: 29.4 ± 16.2 G1 vs. G2: p<0.001
Goldstein 2004^114^ RCT Low ROB | G1: PSG+ plus Tonsillectomy (21) G2: PSG- plus Tonsillectomy (11) G3: PSG- plus Watchful Waiting (9) | CAS-15 (median) G1: 77 G2: 64 G3: 50 | CAS-15 (median) G1: 59 G2: 49 G3: 8 G2 vs. G3: p=0.001

CAS-15 = Clinical Assessment Score-15; M-ESS = Modified Epworth Sleepiness Scale; G = Group; N = Number; NA = Not Applicable; OSA-18 = Obstructive Sleep Apnea-18 ; PedsQL = Pediatric Quality of Life Inventory; PSG = Polysomnography; PSQ = Pediatric Sleep Questionnaire; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

One RCT and a retrospective cohort used the CAS-15 (Clinical Assessment Score),^114, 211^ and both reported significant reduction in scores in the tonsillectomy compared with no tonsillectomy groups, indicating improvement in sleep quality following tonsillectomy. In the one study reporting baseline data, scores in the watchful waiting group improved from baseline to the 6-month followup (p=not reported [NR]).^114^The CHAT RCT used the Modified Epworth Sleepiness Scale (M-ESS) and OSA-18 as a measure of quality of life; while control group scores improved over baseline scores (p=NR), children who had tonsillectomy had significantly greater improvements in sleep quality as measured on both scales (p values ≤ 0.01).^171, 172, 174-178^ This RCT also used the Pediatric Sleep Questionnaire Sleep-related Breathing Disorder scale (PSQ-SRBD), which showed significant improvements in sleep quality after tonsillectomy versus watchful waiting (p ≤ 0.01), and small improvements in the control group from baseline (p=NR). In a nonrandomized trial (moderate risk of bias), children with PSG-proven mild OSA self-allocated to tonsillectomy or observation.^201^ At a 4-month followup, quality of life assessed with the OSA-18 was significantly improved in children who had surgery (p=0.001) but not in the control group. Differences between groups, however, were not significant at the 8-month followup.

Finally, overall quality of life as measured by the Pediatric Quality of Life Inventory (PedsQL) improved significantly after tonsillectomy, compared with the untreated group in one RCT.^171, 172, 174-178, 203^ Scores improved slightly in the control group from baseline (p=NR). Results for the benefit of tonsillectomy to improve sleep quality in children suffering from OSDB were positive across a number of outcomes and outcome domains. Many parents' chief complaint in bringing their child with OSDB to medical attention related to impaired quality of life. Results were consistently positive for tonsillectomy relative to observation in short time frames, with limited data available in the longer term.

##### Behavioral Outcomes

The CHAT RCT^171-177^ and one prospective^203^ and one retrospective cohort study^211^ addressed behavioral outcomes (Table 9). All studies had a moderate risk of bias and used different scales to assess outcomes, again limiting our ability to compare effectiveness directly across studies. Two studies used the Child Behavior Checklist (CBC) to measure internalizing (emotionally reactive, anxious/depressed, somatic complaints, withdrawn behavior) and externalizing (attention problems and aggressive behavior) behaviors. Total problem scores on the scale reflect the sum of these domains, and lower scores equate to fewer behavioral problems. In all studies reporting baseline data, scores on behavioral measures were not indicative of clinical concern.

Table 9 Key OSDB-related behavioral outcomes in studies comparing tonsillectomy and no surgery in children with OSDB

Author, Year Study Type Groups (N) Risk of Bias | Comparison Groups (N) | Outcome Measure Baseline (Mean±SD) | Outcome Measure Followup (Mean±SD)
Marcus 2014^171-177^ RCT Moderate ROB | G1: Tonsillectomy (193) G2: Watchful waiting with supportive care (208) | Conners' (CGI) caregiver G1: 52.5 ± 11.6 G2: 52.6 ± 11.7 Conners' (CGI) teacher G1: 56.4 ± 14.4 G2: 55.1 ± 12.8 | Conners' (CGI) caregiver, change from baseline to 7 months G1: -2.9 ± 9.9 G2: -0.2 ± 9.4 G1 vs. G2: p=0.01 Conners' (CGI) teacher, change from baseline to 7 months G1: -4.9 ± 12.9 G2: -1.5 ± 10.7 G1 vs. G2: p=0.04
Biggs 2014^203^ Prospective Cohort Moderate ROB | G1: Tonsillectomy or Nasal Steroids (12) G2: Watchful waiting with supportive care (27) | CBC Total Problem G1: 64 ± 9 G2: 59 ± 10 | CBC Total Problem (4 years post-tonsillectomy) G1: 61 ± 15 G2: 57 ± 12 G1 vs. G2: p=NS
Burstein 2013^211^ Retrospective Cohort Moderate ROB | G1: Tonsillectomy (16) G2: Watchful waiting with supportive care (16) | CBC Total Problem G1: NR G2: NR | CBC Total Problem (1.66-1.97 years post-tonsillectomy) G1: 43.9 G2: 58.9 G1 vs. G2: p < 0.001

CBC = Child Behavior Checklist; CGI = Connors Global Index; G = Group; N = Number; NA = Not Applicable; OSDB = Obstructive Sleep Disordered Breathing; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

Scores on the CBC improved from baseline in both groups in one cohort study, with no significant group differences.^203^ In the second study, scores were significantly better in the tonsillectomy compared with no tonsillectomy group at followup, but baseline measures were not reported.^211^

CHAT investigators used the Conners' rating scale to assess behavioral issues including emotional lability and reported improvements (i.e., lowering of scores) in both groups from baseline, with significantly greater improvements in the tonsillectomy arm compared with no tonsillectomy on both teacher and parent-reported scales.^171-177^ While children's behaviors improved in these studies, the clinical significance of the improvement is not clear.

##### Executive Function

One RCT and one prospective cohort study used the Developmental NEuroPSYchological Assessment (NEPSY) to evaluate attention and the Behavior Rating Inventory of Executive Function (BRIEF) to assess behavioral regulation and meta-cognition (Table 10).^171-177, 203^ In the RCT, scores on the NEPSY improved from baseline in both groups, but group differences were not significant. Global scores on the BRIEF improved significantly among treated children compared with untreated children when evaluated by caregivers.^171-177, 203^When BRIEF was completed by teachers in a single study, both groups improved, and differences between groups were not significant.^171-177^

Table 10 Key OSDB-related executive function outcomes in studies comparing tonsillectomy and no surgery in children with OSDB

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Outcome Measure Baseline (Mean) | Outcome Measure Followup (Mean)
Marcus 2014^171, 172, 174-177^ RCT Moderate ROB | G1: Tonsillectomy (193) G2: Watchful waiting with supportive care (208) | NEPSY^*^ G1: 101.5 ± 15.9 G2: 101.1 ± 15 BRIEF (GEC) caregiver G1: 50.1 ± 11.2 G2: 50.1 ± 11.5 BRIEF (GEC) teacher G1: 57.2 ± 14.1 G2: 56.4 ± 11.7 | Change from baseline to 7 months NEPSY^*^ G1: 7.1 ± 13.9 G2: 5.1 ± 13.4 G1 vs. G2: p=NS Effect size: 0.15 BRIEF (GEC) caregiver G1: -3.3 ± 8.5 G2: 0.4 ± 8.8 G1 vs. G2: p < 0.001 Effect size: 0.28 BRIEF (GEC) teacher G1: -3.1 ± 12.6 G2: -1.0 ± 11.2 G1 vs. G2: p=NS Effect size: 0.18
Biggs 2014^203^ Prospective Cohort Moderate ROB | G1: Tonsillectomy or Nasal Steroids (12) G2: Watchful waiting with supportive care (27) | BRIEF (GEC) caregiver G1: 62 ± 11 G2: 58 ± 11 | BRIEF (GEC) caregiver (4 years post-tonsillectomy) G1: 58 ± 16 G2: 57 ± 12 G1 vs. G2: p < 0.05

BRIEF (GEC) = Behavior Rating Inventory of Executive Function (Global Executive Composite); G = Group; N = Number; NA = Not Applicable; NEPSY = Neuropsychological Assessment; NS = Not Significant; OSDB = Obstructive Sleep-Disordered Breathing; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

* NEPSY attention and executive function

##### Cardiopulmonary and Physiologic Outcomes

One RCT reported in multiple publications^171-178^ (moderate risk of bias) addressed outcomes including cardiometabolic measures. Evidence was insufficient to comment on physiologic parameters, with a single RCT reporting no change in cardiometabolic measures, including insulin, lipids, and C-reactive protein levels.^171, 172, 174-178^ Underweight children also showed a significant increase in weight and BMI in this RCT.^171-178^

##### Utilization and Other Outcomes

Two cohort studies with moderate risk of bias assessed health care utilization, measured by number of clinician contacts or antibiotic prescriptions, or cognitive outcomes (Table 11). A single moderate risk of bias cohort study reported a 33 percent reduction in gross health care utilization, including a 60 percent reduction in hospital admissions over one year following tonsillectomy in children with PSG-proven OSDB, while admissions in the untreated group increased (p=NR).^206^

Table 11 Other outcomes in studies comparing tonsillectomy with watchful waiting in children with OSDB

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Outcome Measure Baseline (Mean) | Outcome Measure Followup (Mean)
Tarasiuk 2004^206^ Prospective cohort Moderate ROB | G1: Tonsillectomy (130) G2: Watchful waiting with supportive care (90) | G1+G2: NR | Number of new admissions, mean±standard error/patient/year Year 1 G1: 0.15±0.04 G2: 0.08±0.03 Year 2 G1: 0.06±0.02 G2: 0.25±0.07 Number of emergency department visits, mean±standard error/patient/year Year 1 G1: 0.57±0.09 G2: 0.52±0.09 Year 2 G1: 0.35±0.05 G2: 0.37±0.10 Number of consultations, mean±standard error/patient/year Year 1 G1: 3.6±0.37 G2: 4.4±0.40 G1 vs. G2: p= NR Year 2 G1: 1.9±0.26 G2: 3.5±0.46 G1 vs. G2: p= NR
Biggs 2014^203^ Prospective Cohort Moderate ROB | G1: Tonsillectomy (12) G2: Watchful waiting with supportive care (27) | WASI Full Scale IQ G1:102 ± 13 G2: 106 ±14 | WASI Full Scale IQ 4 Years Post-tonsillectomy G1: 101 ± 12 G2: 104 ± 15 G1 vs. G2: p=NS

G = Group; IQ = Intelligence Quotient; N = Number; NA = Not Applicable; NS = Not significant; ROB = Risk of Bias; SD = Standard Deviation; WASI = Wechsler Abbreviated Scale of Intelligence

One cohort study using the Weschler Abbreviated Scale of Intelligence reported a significant improvement in performance IQ at 4-years post-tonsillectomy in children undergoing tonsillectomy, but both the tonsillectomy and no surgery groups had declines or no change in full scale IQ and verbal IQ over the same period.^203^

#### Tonsillectomy Versus CPAP

##### OSDB-Related and Sleep Outcomes

One RCTwith moderate risk of bias addressed OSDB- and sleep-related outcomes in children with OSDB who received tonsillectomy compared with CPAP^44^ (Table 12). Children in the RCT had concomitant Down syndrome or mucopolysaccharidoses (n=32). AHI scores improved from baseline in both groups, but group differences were not significant in this small study.^44^ More children in the tonsillectomy arm had resolution of OSDB (defined as AHI < 1, 91.8% vs. 86.1%, p=NR). The RCT also evaluated sleep outcomes using the ESS and OSA-18. Both groups improved on these measures from baseline with no significant group differences.^44^ Immediate improvement occurred on initiation with CPAP versus a gradual progression with tonsillectomy.

Table 12 OSDB resolution and sleep outcomes in studies comparing tonsillectomy with CPAP

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Outcome Measure Baseline | Outcome Measure Followup
Sudarsan 2014^44^ RCT Moderate ROB | G1: Tonsillectomy (37) G2: CPAP (36) | AHI, mean±SD G1: 3.83 ± 1.36 G2: 3.46 ± 0.87 Sleep Outcomes OSA-18 Total Score, mean±SD G1:116.97 ± 2.25 G2: 116.87 ± 1.3 ESS-C G1: 13.76 ± 1.32 G2: 14.44 ± 2.18 | AHI, mean±SD G1: 1.06 ± 0.74 G2: 1.07 ± 0.57 G1 vs. G2: p=NS Resolution rate (resolution=AHI < 1), (%) G1: 91.8 G2: 86.1 G1 vs. G2: p= NR AHI < 1, % G1+G2: 89 Sleep Outcomes OSA-18 Total Score, mean±SD G1: 73.59 ± 4.14 G2: 75.02 ± 2.5 G1 vs. G2: p=NS ESS-C G1: 5.46 ± 1.35 G2: 7.86 ± 1.69 G1 vs. G2: p=NS

AHI = Apnea-Hypopnea Index; CI = Confidence Interval; CPAP = Continuous Positive Airway Pressure; ESS-C = Epworth Sleepiness Scale - Child ; G = Group; M-ESS = Modified Epworth Sleepiness Scale; N = Number; NR = Not Reported; NS = Not Significant; OSDB = Obstructive Sleep Disordered Breathing; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

## Key Question 1a Effectiveness of Tonsillectomy for Children With OSDB and Neuromuscular or Craniofacial Abnormalities

A single RCT (moderate risk of bias) compared the efficacy of tonsillectomy to immediate initiation of CPAP in children with Down syndrome and mucopolysaccharidoses who were diagnosed with obstructive sleep apnea by polysomnogram.^44^ Both groups showed improvement in AHI at 6-month followup, with maintenance at 12-month followup (no significant group differences). Within this study, three patients (8.1%) who underwent tonsillectomy had persistent symptoms of OSDB and five patients (13.8%) who initiated CPAP had persistent OSDB symptoms. Baseline mean AHI scores for children in this study were far higher than normative scores reported in studies of healthy patients. One retrospective cohort study that included 15 children with syndromic comorbidities (7 with Down syndrome, 1 with Pierre Robin Sequence and 1 with Digeorge syndrome) reported no significant group differences in improvements in AHI in children with syndromic conditions.^214^

## Key Question 1b Effectiveness of Tonsillectomy for Children With OSDB Under 3 Years of Age

We did not identify studies addressing the question. While several studies included children under 3, these data were not extractable from the aggregate data of the entire study population.

## Key Question 1c Effectiveness of Tonsillectomy for Children With OSDB and Down Syndrome

One RCT and one retrospective cohort study (both with moderate risk of bias) specifically studied children with Down syndrome.^44, 214^ Data were reported along with children with mucopolysaccharidoses in the RCT and along with patients with various syndromic comorbidities in the cohort. These studies are discussed in detail above.

## Key Question 1d Effectiveness of Tonsillectomy for Children With OSDB and Obesity

One retrospective cohort study (moderate risk of bias) examining a mostly overweight/obese population with PSG-proven OSDB reported a significant improvement in AHI in children who received tonsillectomy compared with those who did not; however, data were insufficient to suggest effect modification by obesity/overweight status in this single, small study.^211^ In another retrospective cohort including children with mild OSA, analysis of subgroups of obese children and those with syndromic comorbidities showed no significant benefit between groups in these populations.^214^

## Key Question 2 Effectiveness of Tonsillectomy Versus No Surgery for Recurrent Throat Infection

### Key Points

- Overall, children undergoing tonsillectomy to improve number of throat infections, associated health care utilization, and days of work/school missed had improvements in these outcomes in the first postsurgical year vs. children not receiving surgery. These benefits did not persist over time. Data on long-term outcomes of children with recurrent sore throat who do not undergo tonsillectomy are limited.
- We have moderate confidence in the conclusion that, compared with no surgery, tonsillectomy reduces throat infections or streptococcal infections in the short term (≤12 months) (moderate strength of evidence).
- Compared with no surgery, tonsillectomy reduced utilization (clinician contacts), and missed school/work in the short term. We have low confidence in this conclusion (low strength of evidence).
- In the longer term (>12 months) we found no difference between groups in reduction in streptococcal infections. We have low confidence in this conclusion (low strength of evidence).We found no differences between groups in missed school/work or quality of life in the long term (>12 months) and have low confidence in this conclusion (low strength of evidence).
- We could not make a conclusion about effects of tonsillectomy on throat infections in the long term (>12 months) (insufficient strength of evidence)

### Overview of the Literature

We identified ten unique studies addressing tonsillectomy specifically for recurrent throat infections (Table 13).^6, 9, 164-166, 179-181, 209, 210, 213^ As noted above, one study included both children with recurrent throat infection and OSDB.^209^ Four unique studies (3 RCTs and 1 nonrandomized trial) were reported in two papers,^6, 9^ and one set of investigators reported RCT and nonrandomized trial results together in multiple papers.^179-181^ Another RCT was reported in multiple papers.^164-166^ Five studies were conducted in the United States,^6, 9, 213^ three in the United Kingdom,^179-181, 210^ one in Ireland,^209^ and one in the Netherlands.^164-166^Studies included five RCTs,^6, 9, 164-166, 179-181^ two nonrandomized trials,^6, 179-181^ and one prospective^209^ and two retrospective cohorts.^210, 213^ Studies compared tonsillectomy to watchful waiting, which could have included medical treatment including antibiotics or other conventional medical management^6, 9, 164-166, 179-181, 209, 210, 213^ Studies included a total of 15,754 participants (at time of randomization or the start of the study) ranging in age from 2 to 16 years. Outcomes reported in most studies included number of throat infections or streptococcal infections.

Table 13 Overview of studies addressing tonsillectomy in children with recurrent throat infections

Characteristic | RCTs | Nonrandomized Trials | Prospective Cohort Studies | Retrospective Cohort Studies | Total Literature
Surgical Indication
Throat Infection | 2 | 2 | 0 | 2 | 6
OSDB+Throat Infection | 3 | 0 | 1 | 0 | 3
Effectiveness Outcomes Frequently Reported
Number Throat Infections | 5 | 2 | 0 | 1 | 8
Number Streptococcal Infections | 3 | 1 | 0 | 1 | 5
Utilization (# clinician consultations or antibiotic prescriptions) | 1 | 1 | 0 | 1 | 3
Missed School or Work | 4 | 1 | 0 | 0 | 5
Quality of life | 1 | 1 | 1 | 0 | 3
Risk of Bias
Low | 0 | 0 | 0 | 0 | 0
Moderate | 4 | 1 | 0 | 2 | 7
High | 1 | 1 | 1 | 0 | 2
Total N participants | 944 | 557 | 71 | 14182 | 15754

N = number; OSDB = obstructive sleep-disordered breathing; RCT = randomized controlled trial

Four RCTs and one nonrandomized trial and two retrospective cohort studies had moderate risk of bias,^9, 164-166, 179-181, 210, 213^ and one RCT, one prospective cohort study, and one nonrandomized trial had high risk of bias.^6, 209^ Major sources of bias in these studies included unclear concealment of study group allocation and unclear fidelity to the intervention protocol. Given the relatively few studies addressing this question, we retained retrospective studies as part of the evidence base.

### Detailed Analysis

#### Tonsillectomy Versus No Surgery/Watchful Waiting

Four RCTs^9, 164-166, 179-181^ (including 2 reported in one publication^9^ and 2 reported in multiple publications^164-166, 179-181^), one nonrandomized trial^179-181^ and one retrospective cohort study^213^ included children with at least 3 throat infections in the 3 months to one year prior to surgery and reported on recurrent throat infections and clinician visits following surgery or no surgery (Tables 14-15). We considered four RCTs (including 2 published in one paper^9^) to have moderate risk of bias.^9, 164, 166, 179-181, 277^ Another nonrandomized trial had moderate risk of bias.^179-181^ We considered one retrospective cohort study addressing these outcomes to have moderate risk of bias.^213^

Table 14 Key infection outcomes in studies comparing tonsillectomy and no surgery in children with recurrent throat infections

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Outcome Measure Baseline (Mean) | Outcome Measure Followup (Mean)
Lock 2010^179-181^ RCT G1: Tonsillectomy (119) G2: Medical management, (112) Moderate ROB | G1: Tonsillectomy (119) G2: Watchful waiting with supportive care (112) | [underlined: Throat Infections] N sore throats, 3 months prior to study entry, mean±SD G1: 3.09±2.08 G2: 3.34±2.63 [underlined: Utilization] # general practitioner consultations in 2 years prior to study entry, mean±SD G1+G2: 10.3±6.3 # consultations for sore throat in 2 years prior to study entry, mean±SD G1+G2: 6.0±3.7 [underlined: Quality of Life] N respondents G1: 111 G2: 108 PedsQL 4.0 Physical Health G1: 76.26±19.50 G2: 78.75±18.01 N respondents G1: 111 G2: 110 PedsQL 4.0 Psychosocial Health G1: 70.95±14.18 G2: 72.33±14.86 | [underlined: Throat Infections] Sore throats/month, mean±SD Year 1 G1: 0.50±0.43 (n respondents=119) G2: 0.64±0.49 (n respondents=112) RR=0.70 (95% CI: 0.61 to 0.80), p < 0.001 Year 2 G1: 0.13±0.21(n respondents=83) G2: 0.33±0.43 (n respondents=74) RR=0.54 (95%CI: 042 to 0.70), p < 0.001 [underlined: Utilization] Year 1 # clinician consultations, mean±SD G1: 3.99±3.74 G2: 4.38±3.48 RR: 0.91 (95% CI: 0.71 to 1.17) # sore throat consultations, mean±SD G1: 1.90±2.84 G2: 2.35±2.35 RR: 0.81 (95% CI: 0.59 to 1.10)
Lock 2010^179-181^ RCT G1: Tonsillectomy (119) G2: Medical management, (112) Moderate ROB | G1: Tonsillectomy (119) G2: Watchful waiting with supportive care (112) | | Year 2 # clinician consultations, mean±SD G1: 2.84±2.90 G2: 3.40±3.20 RR: 0.83 (95% CI: 0.63 to 1.10) # sore throat consultations, mean±SD G1: 0.89±1.44 G2: 1.33±1.56 RR: 0.67 (95% CI: 0.46 to 0.97) [underlined: Quality of Life] 12 months, N respondents G1: 71 G2: 52 PedsQL 4.0 Physical Health G1: 89.95±16.37 (adjusted effect size: 3.08 [95% CI: 3.11 to 9.27]) G2: 85.34±17.86 PedsQL 4.0 Psychosocial Health G1: 83.81±15.31 (adjusted effect size: 2.43 [95% CI: -3.08 to 7.03]) G2: 79.97±17.49 24 months, N respondents G1: 63 G2: 53 PedsQL 4.0 Physical Health G1: 88.79±17.66 (adjusted effect size: 0.31 [95% CI: -5.74 to 6.37]) G2: 88.05±12.76 PedsQL 4.0 Psychosocial Health G1: 84.30±15.02 (adjusted effect size: 0.39 [95% CI: -4.52 to 5.29]) G2: 83.897±12.95
Lock 2010^179-181^ Nonrandomized trial G1: Tonsillectomy (349) G2: Medical management, (67) Moderate ROB | G1: Tonsillectomy (349) G2: Watchful waiting with supportive care (67) | [underlined: Throat Infections] N sore throat lasting < 2 weeks in 3 months prior to study entry, mean±SD G1: 3.6±2.5 G2: 2.7±1.6 [underlined: Utilization] # general practitioner consultations in 2 years prior to study entry, mean±SD G1: 8.6±5.8 G2: 10.3±6.9 # consultations for sore throat in 2 years prior to study entry, mean±SD G1: 5.4±3.4 G2: 6.2±4.2 [underlined: Quality of Life] N respondents G1: 338 G2: 65 PedsQL 4.0 Physical Health G1: 76.26±19.50 G2: 78.75±18.01 N respondents G1: 334 G2: 66 PedsQL 4.0 Psychosocial Health G1: 70.95±14.18 G2: 72.33±14.86 | [underlined: Throat Infections] Sore throats/month, mean±SD Year 1 G1: 0.71±0.50 G2: 0.59±0.44 Year 2 G1: 0.19±0.36 G2: 0.38±0.34 [underlined: Utilization] Year 1 # clinician consultations, mean±SD G1: 3.69±3.33 G2: 3.16±3.14 # sore throat consultations, mean±SD G1: 1.86±2.23 G2: 1.63±1.98 Year 2 # clinician consultations, mean±SD G1: 2.71±3.51 G2: 3.12±3.10 # sore throat consultations, mean±SD G1: 0.78±1.31 G2: 1.45±2.07 [underlined: Quality of Life—12 months] N respondents G1: 117 G2: 27 PedsQL 4.0 Physical Health G1: 87.15±15.00 G2: 84.66±16.00 N respondents G1: 118 G2: 27 PedsQL 4.0 Psychosocial Health G1: 82.27±15.83 G2: 82.78±16.12 24 months N respondents G1: 96 G2: 25 PedsQL 4.0 Physical Health G1: 91.35±14.48 G2: 91.88±9.59 N respondents G1: 95 G2: 25 PedsQL 4.0 Psychosocial Health G1: 85.85±13.78 G2: 87.46±10.38
Orvidas 2006^213^ Retrospective Cohort Moderate ROB | G1: Tonsillectomy (145) G2: Watchful waiting with supportive care (145) | [underlined: Throat Infections] N with infection within one year prior to tonsillectomy/study entry, (%) G1: 141 (97.2) G2: 130 (89.7) | [underlined: Throat Infections] Cumulative Incidence of Developing Group A Beta-hemolytic Streptococcal Throat Infection, % (95%CI) At 6 months G1: 13.2 (7.5 to 18.6) Number still at risk: 124 G2: 39.3 (30.8 to 46.8) Number still at risk: 87 At 1 year G1: 23.1 (15.9 to 29.7) Number still at risk: 107 G2: 58.5 (49.6 to 65.9) Number still at risk: 57 At 2 years G1: 38.5 (29.8 to 46) Number still at risk: 83 G2: 74.8 (66.4 to 81.1) Number still at risk: 34 At 3 years G1: 46.1 (37.1 to 53.9) Number still at risk: 65 G2: 82.2 (74.5 to 87.6) Number still at risk: 21 At 4 years G1: 51.9 (42.4 to 59.8) Number still at risk: 39 G2: 84.6 (76.7 to 89.8) Number still at risk: 12
Van Staaij 2004^164-166^ RCT Moderate ROB | G1: Tonsillectomy (133) G2: Watchful waiting with supportive care (124) | [underlined: Throat Infections] Throat infections in year prior to study, median (range) G1: 3 (0-6) G2: 3 (0-6) | [underlined: Throat Infections] Episodes of throat infection/person year, n G1: 0.56 G2: 0.83 Difference: -0.21 (95% CI: -0.36 to -0.06) Incidence rate G1+G2: 0.73 (95% CI: 0.58 to 0.92) Quality of Life Data in figures only; study notes no clinically significant differences
Paradise 2002^9^ RCT A Moderate ROB | G1: Tonsillectomy (58 randomized, 52 received intervention) G2: Adenotonsillectomy (59 randomized, 50 received intervention) G3: Watchful waiting with supportive care (60 randomized, 60 received intervention) | [underlined: Throat Infections] G1+G2: NR | [underlined: Throat Infections] Episodes of Any Throat Infection, Mean (95% CI) Years 1-3 G1: 1.55 (95% CI: 1.33 to 1.82) G2: 1.63 (95% CI: 1.37 to 1.93) G3: 2.77 (95% CI: 2.52 to 3.13) G1 vs. G3: p < 0.001 G2 vs. G3: p < 0.001 Episodes of Group A Beta-hemolytic Streptococcal Throat Infection, Mean (95% CI) Years 1-3 G1: 0.29 (95% CI: 0.20 to 0.41) G2: 0.20 (95% CI: 0.12 to 0.32) G3: 0.82 (95% CI: 0.67 to 1.01) G1 vs. G3: p < 0.001 G2 vs. G3: p < 0.001 Episodes of Moderate or Severe Throat Infection, Mean (95% CI) Years 1-3 G1: 0.09 (95% CI: 0.04 to 0.17) G2: 0.08 (95% CI: 0.03 to 0.17) G3: 0.33 (95% CI: 0.24 to 0.45) G1 vs. G3: p=0.002 G2 vs. G3: p=0.003
Paradise 2002^9^ RCT B Moderate ROB | G1: Adenotonsillectomy (73 randomized, 63 received intervention) G2: Watchful waiting with supportive care (78 randomized, 78 received intervention) | [underlined: Throat Infections] G1+G2: NR | [underlined: Throat Infections] Episodes of Any Throat Infection, Mean (95% CI) Years 1-3 G1: 1.74 (95% CI: 1.54 to 2.00) G2: 2.93 (95% CI: 2.69 to 3.22) G1 vs. G2: p < 0.001 Episodes of Group A Beta-hemolytic Streptococcal Throat Infection, Mean (95% CI) Years 1-3 G1: 0.29 (95% CI: 0.21 to 0.40) G2: 0.77 (95% CI: 0.65 to 0.92) G1 vs. G2: p < 0.001 Episodes of Moderate or Severe Throat Infection, Mean (95% CI) Years 1-3 G1: 0.07 (95% CI: 0.03 to 0.13) G2: 0.28 (95% CI: 0.21 to 0.37) G1 vs. G2: p=0.003
Koshy 2015^210^ Retrospective Cohort G1: Tonsillectomy and ≤3 acute throat infection consultations (450) G2: No tonsillectomy and ≤3 acute throat infection (13442) Moderate ROB | G1: Tonsillectomy and ≤3 acute throat infection consultations (450) G2: No tonsillectomy and ≤3 acute throat infection (13442) | [underlined: Utilization] # throat infection consultations in 3 years prior to study index date, mean±SD G1: 1.3±1.1 G2: 0.4±0.8 G1 vs. G2: p < 0.001 | [underlined: Utilization] # throat infection consultations 4-6 years post-index date, mean G1: 0.6 G2: 0.93 Mean difference in consultations, baseline to followup G1: −0.72 (95% CI: −0.88 to −0.56), p < 0.001 G2: +0.49 (95% CI: 0.46 to 0.52), p < 0.001

CI = Confidence Interval; G = Group; n = Number; NR = Not Reported; NS = Not Significant; PedsQL = Pediatric Quality of Life Questionnaire; ROB = Risk of Bias

Table 15 Missed school or work outcomes reported in studies comparing tonsillectomy and no surgery in children with recurrent throat infections

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Sore Throat-Associated School Absences, Mean±SD Days/Year (Number Days/Year)
Van Staaij 2004^164-166^ RCT Moderate ROB | G1: Tonsillectomy (133) G2: Watchful waiting with supportive care 124) | Difference in school absences G1 vs. G2: 0.09 (95% CI: -0.27 to 0.44)
Paradise 2002^9^ RCT A G1: Tonsillectomy (58 randomized, 52 received intervention) G2: Adenotonsillectomy (59 randomized, 50 received intervention) G3: No surgery (60 randomized, 60 received intervention) Moderate ROB | G1: Tonsillectomy (58 randomized, 52 received intervention) G2: Adenotonsillectomy (59 randomized, 50 received intervention) G3: No sur Watchful waiting with supportive care (60 randomized, 60 received intervention) | Year 1 G1: 3.3±4.0 (42) G2: 3.9±3.7 (44) G3: 5.3±4.7 (50) G1 vs. G3: p < 0.05 Year 2 G1: 3.2±3.9 (39) G2: 2.4±3.2 (38) G3: 5.0±5.2 (44) G2 vs. G3: p < 0.05 Year 3 G1: 2.5±3.2 (37) G2: 2.9±2.9 (29) G3: 3.7±3.2 (42) G2 vs. G3: p=NS
Paradise 2002^9^ RCT B Moderate ROB | G1: Tonsillectomy (73 randomized, 63 received intervention) G2: Watchful waiting with supportive care (78 randomized, 78 received intervention) | Year 1 G1: 3.5±4.2 (52) G2: 6.6±6.2 (58) G1 vs. G2: p < 0.01 Year 2 G1: 3.2±4.1 (47) G2: 5.4±6.7 (56) G1 vs. G2: p=NS Year 3 G1: 2.6±3.4 (45) G2: 4.2±5.2 (55) G1 vs. G2: p=NS

G = Group; n = Number; NS = Not Significant; RCT = Randomized Controlled Trial; ROB = Risk of Bias

In all studies reporting baseline data, number of infections decreased from baseline in both groups, with significantly greater decreases in sore throat days and diagnosed Group A streptococcal throat infections in children who received tonsillectomy vs. no surgery/watchful waiting with supportive care in the short term ( < 12 months). As noted, in two papers in this section, investigators report multiple RCTs and/or nonrandomized trials conducted by the same team (but with unique populations) in single papers. In one such paper, both the RCT and nonrandomized trial^179-181^ reported that children in both studies who received tonsillectomy had fewer recorded days of sore throat in a symptom diary than children who had medical management. Using an intention-to-treat analysis for the RCT patients, the study found a decrease of 3.5 (95% CI: 1.8 to 5.2) sore throat episodes over the full 2-year study period for children who underwent tonsillectomy. The benefit was greatest in those quick to receive tonsillectomy after the onset of infections, with the relative benefit decreasing with longer times to intervention. Children who underwent tonsillectomy within 4 weeks of enrollment had an estimated 8.5 episodes of sore throat avoided, whereas children who waited longer times (up to 52 weeks) had 3.5 episodes of sore throats saved. Limitations of this study family include strong parental preference for surgery when the child had more severe symptoms, thus affecting the generalizability of the patients who were randomized. The study points out that the children who were ultimately randomized fell into the middle of the pack in terms of how much they were impacted by their symptoms. The study also had significant attrition in return of the symptom diaries over time and difficulty obtaining provider records for review.

In another paper reporting two unique RCTs, benefits of tonsillectomy or adenotonsillectomy were reported for children who experienced at least one sore throat.^282^ These studies had surgical and watchful waiting groups, and while the surgical groups had fewer visits for sore throat after surgery, the number of visits for sore throat in the watchful waiting groups was also low. The first year postsurgery, the tonsillectomy group had 1.74 (95% CI: 1.54 to 2.00) episodes of throat infection while the control group had 2.93 (95% CI: 2.69 to 3.22) episodes. Although statistically significant, it is unclear whether this difference is clinically meaningful. ,

In another RCT (moderate risk of bias) including children with mild symptoms of throat infection or hypertrophy (< 7 or more throat infections in prior year or 5 or more in prior 2 years or 3 or more in prior 3 years and Brouillette's OSA score of less than 3.5—i.e., in no apnea or possible apnea range), children who received tonsillectomy had fewer throat infections (throat pain+fever) compared with those who had no surgery (0.56/person year vs. 0.77, p= NR).^164-166^ Of note, many children originally allocated to no surgery/watchful waiting (n=50 of 149) crossed over to the surgery arm.

One retrospective cohort found that children who did not undergo tonsillectomy were 3.1 times (95% CI: 2.1 to 4.6, p < 0.001) more likely to test positive for Group A streptococcal (GAS) throat infection that their counterparts who underwent surgery.^213^Children who did not have tonsillectomy also experienced GAS infection at a shorter time interval than the children without tonsils.

Two RCTs and one nonrandomized trial reported quality of life data, which were not markedly different between any of the study arms at any time point.^164, 179-181^ Overall, comparative effectiveness assessment of tonsillectomy vs. no surgery to improve number of throat infections, associated health care utilization, and work/school absences shows a benefit in the first postsurgical year. These benefits did not persist over time. Quality of life improved in both groups (p=NR).

One retrospective cohort study included children who may have had fewer than three throat infections in the prior year.^210^ The study reported a net reduction in the 3-year mean sore throat visits for children who underwent tonsillectomy compared with those who did not. , This reduction decreased over time with 2.46 fewer visits (95% CI: 2.29 to 2.63, p < 0.001) in years 1-3 and 1.21 fewer visits (95% CI: 1.04 to 1.38, p < 0.001) in years 4-6, or 0.61 sore throat visits per child per year (over the 6 year study period). This study focused on provider visits rather than sore throat episodes that did not generate a provider visit, or visits with multiple concerns, coded under another primary complaint.

Fewer days of missed school or work were associated with tonsillectomy in the short term, with differences diminishing over time in two RCTs^9^ while another RCT noted comparable school absences between groups^164-166^ (Table 15).

## Key Question 3 Effectiveness of Partial Versus Total Tonsillectomy

### Key Points

- Few studies compared the same surgical technique for partial or total tonsillectomy. In studies comparing partial and total cold dissection tonsillectomy, return to normal diet and activity was faster in children undergoing partial tonsillectomy. Our confidence in this conclusion is low (low strength of evidence).
- In studies comparing partial and total cold dissection tonsillectomy, we could not make conclusions about effects on throat infections or OSDB persistence (insufficient strength of evidence).
- In studies comparing either partial and total coblation tonsillectomy or partial and total electrocautery tonsillectomy, we could not make conclusions about effects on return to normal diet or activity (insufficient strength of evidence).
- In studies comparing mixed techniques for partial or total tonsillectomy, return to normal diet and activity was more favorable in children undergoing partial versus total tonsillectomy. Our confidence in this conclusion is low (low strength of evidence). These effects may be due to confounding by indication as indication varied across studies.
- In studies comparing mixed techniques for partial or total tonsillectomy, we found no difference in effects on long-term (>12 months) persistence of OSDB symptoms, quality of life, behavioral outcomes, or throat infections between partial and total tonsillectomy. Our confidence in these conclusions is low (low strength of evidence).

### Overview of the Literature

We identified 22 unique studies (20 RCTs,^53, 71, 84-86, 90, 95, 97, 98, 101, 107, 110, 129, 139, 151, 158, 182-187, 189^ and 2 nonrandomized trials^193, 198^) addressing partial tonsillectomy compared with total tonsillectomy (Table 16). Most studies were conducted in Europe^53, 84, 86, 101, 129, 185, 186, 193, 198^ or North America.^85, 90, 95, 97, 98, 107, 110, 151^ Four studies were conducted in Asia,^71, 139, 187, 189^ and one in Africa.^158^ Participants (n=2925) ranged in age from 1 to 18 years. In addition to comparing partial with total tonsil removal, most studies (n=16) also compared surgical techniques including microdebrider, laser, coblation, and electrocautery partial tonsillectomy and cold dissection, coblation, and electrocautery total tonsillectomy. In studies comparing both extent of surgical removal (i.e., partial vs. total removal) and different surgical techniques (e.g., partial coblation vs. total electrocautery), it is not possible to determine whether effects are due to the technique or due to the extent of surgery. Thus, except for in those studies that compared partial or total removal of the tonsils using the same technique (e.g., partial cold dissection vs. total cold dissection), we considered the comparison of interest broadly as partial vs. total tonsil removal. We present results by partial vs. total cold dissection, partial vs. total coblation or electrocautery; and partial vs. total regardless of technique below.

Table 16 Overview of studies comparing partial versus total tonsillectomy

Characteristic | RCTs | Nonrandomized Trials | Total Literature
Comparisons
Total cold dissection vs. partial cold dissection | 3 | 1 | 4
Total coblation vs. partial coblation | 1 | 0 | 1
Total electrocautery vs. partial electrocautery | 1 | 0 | 1
Partial vs. total | 15 | 1 | 16
Surgical Indication
OSDB | 17 | 2 | 19
OSDB+Throat Infection | 2 | 0 | 2
Not specified | 1 | 0 | 1
Effectiveness Outcomes Frequently Reported
Return to normal diet or activity | 10 | 0 | 10
Number of throat infections | 6 | 0 | 6
Tonsillar regrowth | 5 | 1 | 6
Risk of Bias
Low | 5 | 0 | 5
Moderate | 11 | 0 | 11
High | 4 | 2 | 6
Total N participants | 1709 | 1216 | 2925

n = Number; OSDB = Obstructive Sleep-Disordered Breathing; RCT = Randomized Controlled Trial

Across studies, definitions of “partial” tonsillectomy varied or were not explicit. Five studies explicitly noted leaving anywhere from 10 to 70 percent of the tonsil intact,^53, 84, 86, 110, 129^ while others noted leaving a thin rim of tissue or removing the bulk of the tonsil,^71, 85, 90, 107, 189, 198^ and yet others reported removing the obstructive or protruding portion of the tonsil only.^182-187, 193^ Six studies did not describe the portion of tissue removed.^95, 97, 98, 139, 151, 158^

We considered five RCTs to have low risk of bias.^53, 90, 97, 98, 151, 158^ Eleven RCTs^71, 84-86, 95, 107, 110, 139, 182-186^ had moderate risk of bias, and four RCTs^187, 189, 283, 284^ and two nonrandomized trials^193, 198^ had high risk of bias. Major sources of bias in these studies include unclear methods for randomization and unclear methods for concealment of treatment group allocation. We do not discuss high risk of bias studies in the detailed analyses below.

### Detailed Analysis

#### Partial Cold Dissection Versus Total Cold Dissection Tonsillectomy

Three RCTs and one nonrandomized trial compared total and partial cold dissection and included 348 children in the partial tonsillectomy arms and 378 in the total tonsillectomy arms.^53, 84, 86, 198^Few of these studies reported the same outcomes (Table 17).

Table 17 Comparative effectiveness outcomes in studies addressing partial versus total cold dissection tonsillectomy

Author, Year Study Design Risk of Bias | Comparison Groups (N) | OSDB Persistence | Tonsillar Regrowth | Return to Normal Diet or Activity | Throat Infections
Chaidas 2013^53^ RCT Low ROB | G1: Partial cold tonsillectomy (50) G2: Total cold tonsillectomy (51) | Snoring (6-years post-tonsillectomy) G1: 13/43 (30.2) G2: 12/48 (25) G1 vs. G2: p=NS Episodes of apnea (6-years post-tonsillectomy) G1: 2/43 (4.7) G2: 0 (0) G1 vs. G2: p=NS | Tonsillar regrowth, 6 years postsurgery, n (%) G1: 6/13 (46.2) G2: NA Tonsillar regrowth requiring revision surgery, n (%) G1: 2/13 (5) G2: 0 | Time to return to normal diet, mean days ± SD G1: 3.8 ± 0.2 G2: 7.1 ± 0.3 G1 vs.G2: P < 0.001 | At least 1 episode of tonsillitis/year, 1-6 years post-tonsillectomy, n (%) G1: 5 (11.6) G2: 0 G1 vs. G2: p= NR Number throat infections/year, 1-6 years post-tonsillectomy, median (IQR) G1: 0 (0-1) G2: 0 (0-1) G1 vs. G2: p=NS
Korkmaz 2008^84^ RCT Moderate ROB | G1: Partial cold tonsillectomy (40) G2: Total cold tonsillectomy (41) | NR | Tonsillar regrowth within 2-years post-tonsillectomy, n G1+G2: 0/68 | NR | NR
Skoulakis 2007^86^ RCT Moderate ROB | G1: Partial cold tonsillectomy (15) G2: Total cold tonsillectomy (15) | NR | NR | Time to return to normal diet G1: 4 days earlier than G2 G1 < G2: p < 0.001 | NR

G = Group; N = Number; NA = Not Applicable; NR = Not Reported; NS = Not Significant; OSDB = Obstructive Sleep Disordered Breathing; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

##### OSDB Persistence

In one RCT (low risk of bias) reporting on the persistence of OSDB, children in both arms had recurrence of snoring.^53^ Differences were not statistically significant.

##### Tonsillar Regrowth and Reoperation

Two RCTs (low^53^ and moderate^84^ risk of bias) addressed regrowth and/or revision surgery. In one RCT including 40 children with OSDB undergoing partial tonsillectomy and 41 undergoing total, no children had tonsillar regrowth (0 of 68 followed up) in the 2-year followup period.^84^ In a second study, 6 out of 43 children undergoing partial tonsillectomy and followed for 6 years had regrowth, in two cases requiring total tonsillectomy.^53^

##### Growth

No studies provided baseline comparative data that could be used to assess the comparative effectiveness of surgery on growth outcomes.

##### Return to Normal Diet or Activity

Children in the partial tonsillectomy arm had significantly faster return to normal diet in the two RCTs (low and moderate risk of bias) addressing this outcome (p values< 0.001).^53, 86^

##### Throat Infection

In one low risk of bias RCT with 6-year followup, no children (0/91) in either group had throat infections, although the study reports that five children in the partial tonsillectomy arm had at least one episode of tonsillitis/year in the followup period.^53^ The study did not define throat infection or tonsillitis.

#### Partial Coblation or Electrocautery Versus Total Coblation or Electrocautery

Two small RCTs with low^90^ and moderate^85^ risk of bias addressed outcomes following partial vs. total coblation or electrocautery and reported only on return to usual diet or activity (Table 18). In the coblation study, children in the partial tonsillectomy arm consumed a significantly greater percentage of their normal diet and were engaged in a greater portion of their normal activity than were children in the total tonsillectomy arm at all time points assessed.^85^ In the one study comparing partial vs. total electrocautery tonsillectomy, differences in return to normal activity were not statistically significantly different between groups.^90^

Table 18 Return to usual diet or activity in studies addressing partial versus total tonsillectomy with coblation or electrocautery

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Time to Return to Normal Diet or Activity, N (%)
Chang 2008^85^ RCT Moderate ROB | G1: Partial coblation tonsillectomy (34) G2: Total coblation tonsillectomy (35) | Mean % of normal diet resumed (POD1-2) G1: 56 G2: 42 G1 vs.G2: p = 0.05 Mean % of normal diet resumed (POD5-6) G1: 73 G2: 48 G1 vs.G2: p < 0.05 Mean % of normal activity resumed (POD1-2) G1: 65 G2: 49 G1 vs.G2: p = 0.031 Mean % of normal activity resumed (POD5-6) G1: 84 G2: 64 G1 vs.G2: p = 0.002
Park 2007^90^ RCT Low ROB | G1: Partial electrocautery tonsillectomy (19) G2: Total electrocautery tonsillectomy (21) | Time to return to normal activity G1 vs.G2: p = NS

G = Group; N = Number; NS = Not Significant; OSDB = Obstructive Sleep Disordered Breathing; POD = Postoperative Day; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

#### Partial Tonsillectomy Versus Total Tonsillectomy With Mixed Surgical Approaches

Among the studies with low or moderate risk of bias addressing partial vs. total tonsillectomy without using the same surgical technique, eight (reported in multiple publications) addressed effectiveness outcomes^95, 97, 98, 107, 110, 139, 182-186^ and three reported only harms (addressed in Harms section).^71, 151, 158^ As with the studies outlined above, few studies addressed the same outcomes and because these studies differ in both extent of surgery and surgical technique, it is difficult to isolate the effect of partial tonsillectomy.

##### OSDB Persistence

Three RCTs (in multiple publications) addressed outcomes related to the persistence of OSDB (Table 19).^110, 182-186^ In two studies with low^90^ and moderate^185, 186^ risk of bias, obstructive symptoms including snoring worsened in the short term in the partial tonsillectomy arm compared with total tonsillectomy, but differences between groups were not significant at longer-term followup (12-24 months post-tonsillectomy. In the third RCT, no children in either group had snoring or apnea at 1 and 3 years postoperatively.^182-184^

Table 19 OSDB persistence reported in studies comparing partial and total tonsillectomy

Study, Year Study Design Risk of Bias | Comparison Groups (N) | OSDB Persistence
Chan 2004^110^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (27) G2: Total tonsillectomy-electrocautery (28) | Worsening of obstructive symptoms (3-months post-tonsillectomy), n (%) G1: 10/21 (48) G2: 6/19 (25) p=NR Improvement in obstructive symptoms (12 months post-tonsillectomy) G1 vs. G2: p=NS
Ericsson 2009^185, 186^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (35) G2: Total tonsillectomy-cold dissection (32) | Persistence of snoring 6-months post-tonsillectomy Greater number of children in G1 vs. G2 had snoring, p < 0.05 24-months post-tonsillectomy G1 vs. G2; p=NS
Hultcrantz 2004^182-184^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (49) G2: Total tonsillectomy-cold dissection (43) | Persistence of snoring 12-months and 3-years post-tonsillectomy No difference in frequency or loudness of snoring between groups Presence of apnea,1-3 years post-tonsillectomy G1: 0 G2: 0

G = Group; N = Number; NR = Not Reported; NS = Not Significant; OSDB = Obstructive Sleep Disordered Breathing; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

##### Tonsillar Regrowth

Two RCTs (moderate risk of bias) reported low rates of tonsillar regrowth after partial tonsillectomy (Table 20).^182-186^ Out of an estimated 126 children providing followup data, three (2.4%) reported regrowth and had total tonsillectomy.

Table 20 Tonsillar regrowth or reoperation after partial tonsillectomy

Study, Year Study Design Risk of Bias | Comparison Groups (N) | Tonsillar Regrowth
Ericsson 2009^185, 186^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (35) G2: Total tonsillectomy-cold dissection (32) | Total tonsillectomy for OSDB-symptom persistence, n (%) G1: 2/35 (5.7) G2: NA
Hultcrantz 2004^182-184^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (49) G2: Total tonsillectomy-Cold dissection (43) | Total tonsillectomy for OSDB-symptom persistence, n G1: 1 (denominator not clear, 91 children in both groups assessed at 1 year) G2: NA

G = Group; N = Number; NA = Not Applicable; OSDB = Obstructive Sleep Disordered Breathing; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

##### Return to Normal Diet or Activity

Six RCTs (four with moderate and two with low risk of bias) addressed time to return to normal diet or activity (Table 21).^95, 97, 98, 107, 110, 185, 186^ Studies were typically small ( < 100 children) with short term followup and used a variety of methods for assessing these outcomes (e.g., mean days, mean percentage, number of children). In all six studies addressing return to normal diet, children in the partial tonsillectomy arms had more favorable outcomes compared with those receiving total tonsillectomy. Two studies reported that children undergoing partial surgeries either consumed a significantly greater proportion of their normal diet^107^ or returned to normal diet in fewer days^97^ than did children in total tonsillectomy arms. Four RCTs reported faster return in the partial tonsillectomy groups or greater numbers of children consuming a normal diet after partial compared with total tonsillectomy, but differences were not statistically significant^98, 185, 186^ or significance was not assessed.^95, 110^

Table 21 Return to normal diet or activity in studies comparing partial and total tonsillectomy

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Time to Return to Normal Diet or Activity, N (%)
Chang 2005 ^107^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (52) G2: Total tonsillectomy-electrocautery (49) | Mean % of normal diet resumed (POD1-2) G1: 49 G2: 30 G1 vs.G2: p < 0.005 Mean % of normal diet resumed (POD5-6) G1: 74 G2: 42 G1 vs.G2: p < 0.005 Mean % of normal activity resumed (POD1-2) G1: 53 G2: 42 G1 vs.G2: p = NS Mean % of normal activity resumed (POD5-6) G1: 82 G2: 56 G1 vs.G2: p < 0.005
Chan 2004 ^110^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (25) G2: Total tonsillectomy-electrosurgery (25) | Time to return to normal diet, median days G1: 4.4 G2: 7.5 G1 vs.G2: p = NR Time to return to normal activity, median days G1: 4.1 G2: 8 G1 vs.G2: p = NR
Coticchia 2006^95^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (13) G2: Total tonsillectomy-cold (10) | N children resuming normal diet by POD7, (%) G1: 11 (85) G2: 0 (0) G1 vs.G2: p = NR
Sobol 2006^97^ RCT Low ROB | G1: Partial tonsillectomy-microdebrider (36) G2: Total tonsillectomy-electrocautery (38) | Time to return to normal diet, mean days ± SD G1: 2.7 ± 2.3 G2: 4.4 ± 3.4 G1 vs.G2: p = 0.04 Time to return to normal activity, mean days ± SD G1: 2.4 ± 1.8 G2: 3.8 ± 3 G1 vs.G2: p = NS
Derkay 2006^98^ RCT Low ROB | G1: Partial tonsillectomy-microdebrider (150) G2: Total tonsillectomy-electrocautery (150) | Time to return to normal diet, median days (Q1 – Q3) G1: 3 (1.5-6) G2: 3.5 (1.5-6.5) G1 vs.G2: p = NS Time to return to normal activity, median days(Q1 – Q3) G1: 2.5 (1-5) G2: 4 (2.5-6.5) G1 vs.G2: p < 0.01
Ericsson 2009^185, 186^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (35) G2: Total tonsillectomy-cold dissection (32) | Time to return to normal diet G1: 4 days earlier than G2 G1 vs. G2: p=NS Time to return to normal activity G1: 3 days earlier than G2 G1 vs. G2: p=NS

G = Group; N = Number; NR = Not Reported; NS = Not Significant; POD = Postoperative Day; OSDB = Obstructive Sleep Disordered Breathing; Q=quartile; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

Five RCTs (2 low and 3 moderate risk of bias) addressed return to normal activity.^97, 98, 107, 110, 185, 186^ As with diet, in all studies children undergoing partial tonsillectomy had a faster return to normal activity or engaged in a greater percentage of normal activity than did children who had total tonsillectomy. Differences were statistically significant in two RCTs^98, 107^

##### Throat Infections

Four RCTs (multiple publications, all moderate risk of bias) addressed recurrent throat infections (Table 22).^110, 139, 182-186^ One study included children with OSDB (hypertrophy causing obstruction) as the primary indication for surgery,^285^ while the others included children with both OSDB and recurrent throat infections. Two studies explicitly reported on baseline or previous throat infections (number of episodes/year),^110, 182-184^ and one explicitly excluded children with >3 streptococcal throat infections in the 2 years prior to surgery.^139^ One study reported that 21 percent of all children had had ≤ one episode of tonsillitis before the 3 months prior to surgery.^185, 186^ In three of the four studies, children in the partial tonsillectomy arm had more throat infections than did those in the total tonsillectomy arms, though differences were not statistically significant in three studies.^110, 182-186^ In two studies, children experienced fewer infections compared with baseline rates,^182-186^ but other studies did not comment on changes from baseline.

Table 22 Throat infections following partial or total tonsillectomy

Study, Year Study Design Risk of Bias | Comparison Groups (N) | Throat Infections
Ericsson 2009^185, 186^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (35) G2: Total tonsillectomy-cold dissection (32) | Sore throats requiring antibiotics, 6-months post-tonsillectomy, n G1: 4 G2: 2 G1 vs. G2: p=NS Sore throats requiring antibiotics, 24-months post-tonsillectomy, n G1: 8 G2: 1 G1 vs. G2: p= NR
Hultcrantz 2004^182-184^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (49) G2: Total tonsillectomy-cold dissection (43) | Sore throats requiring antibiotics, 12-months post-tonsillectomy, n G1: 6 G2: 4 G1 vs. G2: p=NS Sore throats requiring antibiotics, 1-3 years post-tonsillectomy, n G1: 6 G2: 5 G1 vs. G2: p=NS
Beriat 2013^139^ RCT Moderate ROB | G1: Partial tonsillectomy-microdebrider (37) G2: Total tonsillectomy-cold dissection (45) | Recurrent throat infection (within 12-months post-tonsillectomy), n G1: 2 G2: 0 G1 vs. G2: p= NR
Chan 2004^110^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (27) G2: Total tonsillectomy-electrocautery (28) | Incidence of sore throat or antibiotic use (3 and 12 months post-tonsillectomy) G1 vs. G2: p=NS

G = Group; N = Number; NR = Not Reported; NS = Not Significant; OSDB = Obstructive Sleep Disordered Breathing; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

##### Quality of Life

Three RCTs (1 low and 2 moderate risk of bias) assessed quality of life using different scales and at different time points (Table 23).^98, 182-186^ In one study with assessment at 1-month postsurgery, changes in physical suffering, sleep disturbances, speech issues, or caregiver concerns did not differ significantly between groups, but decreases in emotional distress and in activity limitations were greater in the partial tonsillectomy arm than in the total tonsillectomy arm.^98^ In two additional studies (one using the OSA-18, which uses a 7-point scale to assess frequency of symptoms from 1 [none of the time] to 7 [all of the time] and also assesses disease-specific quality of life) and one using the Glasgow Children's Benefit Inventory [GCBI]), changes in quality of life were not significantly different between groups, and both groups improved from baseline. In one study more than 30 percent of children in both arms had large improvements in disease-specific quality of life at 6 months and 2 years postsurgery, but group differences were not significant.^185, 186^

Table 23 Quality of life following partial or total tonsillectomy

Study, Year Study Design Risk of Bias | Comparison Groups (N) | Baseline Outcome Measure, Mean±SD | Followup Outcome Measure, Mean±SD
Derkay 2006^98^ RCT Low ROB | G1: Partial tonsillectomy-microdebrider (150) G2: Total tonsillectomy-electrocautery (150) | NR | Baseline to postoperative changes in physical suffering, sleep disturbance, speech or swallowing problems, and caregiver concerns, 1 month post-tonsillectomy G1 vs. G2: p=NS Decrease in emotional distress G1>G2: p < 0.01 Decrease in activity limitation G1>G2: p < 0.01
Ericsson 2009^185, 186^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (35) G2: Total tonsillectomy-cold dissection (32) | OSA-18 (Total), Mean±SD G1: 3.5±1.0 G2: 3.4±1.0 | OSA-18 (Total) Change score 6-months post-tonsillectomy G1: 1.8±1.2 G2: 1.8±1.0 G1 vs. G2: p=NS Change score 24-months post-tonsillectomy G1: 1.8±1.2 G2: 1.9±1.4 G1 vs. G2: p=NS Disease-specific quality of life data in figures only
Hultcrantz 2004^182-184^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (49) G2: Total tonsillectomy-cold dissection (43) | Glasgow Children's Benefit Inventory G1+G2: NR | Glasgow Children's Benefit Inventory, % 33 months post-tonsillectomy Overall QoL-Much better G1: 61 G2: 79 Overall QoL-A little better G1: 35 G2: 18 Overall QoL-No change G1: 5 G2: 3 G1 vs. G2: all p=NS

G = Group; IQR = Interquartile Range; N = Number; NR = Not Reported; NS = Not Significant; OSA-18 = Obstructive Sleep Apnea - 18; OSDB = Obstructive Sleep Disordered Breathing; QoL = Quality of Life; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

##### Behavioral Outcomes

Two RCTs with moderate risk of bias reported changes in behavior using the Child Behavior Checklist (CBC) (Table 24).^182-186^ Both groups improved from baseline overall and in each domain assessed (internalization, externalization), with no significant differences between groups in the short or longer (≥12 months) term. One study also assessed behavior changes with the GCBI and reported no significant differences between groups.^182-184^

Table 24 Behavioral outcomes following partial or total tonsillectomy

Study, Year Study Design Risk of Bias | Comparison Groups (N) | Baseline Outcome Measure, Mean±SD | Followup Outcome Measure, Mean±SD
Ericsson 2009^185, 186^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (35) G2: Total tonsillectomy-cold dissection (32) | Child Behavior Checklist, Total Score G1: 25.6±19.1 G2: 20.9±12.4 G1 vs. G2: p=NS | Child Behavior Checklist, Total Score 6-months post-tonsillectomy G1: 19.5 ±18.4 G2: 13.5 ±9.8 G1 vs. G2: p=NS 24-months post-tonsillectomy G1: 13.9±12.9 G2: 13.6±21.7 G1 vs. G2: p=NS
Hultcrantz 2004^182-184^ RCT Moderate ROB | G1: Partial tonsillectomy-coblation (49) G2: Total tonsillectomy-cold dissection (43) | Child Behavior Checklist, Total Score, Mean±SD G1: 21.3±17.4 G2: 17.3±12.8 G1 vs. G2: p < 0.001 | Child Behavior Checklist, Total Score 12-months post-tonsillectomy No differences in degree of improvement between groups Glasgow Children's Benefit Inventory, % 33 months post-tonsillectomy Behavior-Much better G1: 19 G2: 10 Behavior-A little better G1: 19 G2: 15 Behavior-No change G1: 62 G2: 74 G1 vs. G2: all p=NS

G = Group; N = Number; NS = Not Significant; OSDB = Obstructive Sleep Disordered Breathing; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

##### Other Outcomes

Two RCTs with moderate risk of bias also addressed enuresis.^182-186^ One study reported a second partial tonsillectomy in a child with pre-existing enuresis and encopresis temporarily improved by the index partial tonsillectomy; encopresis did not improve after the second surgery.^185, 186^ Another reported that 7 children undergoing total tonsillectomy and 3 undergoing partial had baseline enuresis, which improved in nine children (treatment group not specified) postoperatively.^182-184^

## Key Question 4 Effectiveness of Surgical Techniques

### Key Points

- Few studies reported effectiveness outcomes. In those that did, commonly used “hot” techniques such as coblation and electrocautery were generally associated with faster return to normal diet or activity compared with cold dissection (roughly 1 to 3 days). We found a faster return to diet with coblation or electrocautery tonsillectomy compared with cold dissection and have low confidence in these conclusions (low strength of evidence).
- Few studies, typically addressing different measures and using different comparison techniques, addressed newer techniques such as thermal welding, laser, or harmonic scalpel, thus limiting our ability to draw conclusions about these approaches.
- We could not make conclusions about effects associated with other techniques (insufficient strength of evidence).

### Overview of the Literature

We identified 59 unique studies (reported in 61 publications) comparing surgical techniques for tonsillectomy (Table 25).^43, 48, 56, 58, 61, 63-70, 74, 75, 77, 79-83, 87, 89, 91, 93, 96, 99, 100, 102-104, 108, 111, 116, 120, 123-125, 127, 130, 131, 134, 141, 143-145, 152-154, 160, 163, 167-170, 192, 195-197, 200, 207^ Most (n=54) studies were RCTs;^43, 48, 56, 58, 61, 63-70, 74, 75, 77, 79-83, 87, 89, 91, 93, 96, 99, 100, 102-104, 108, 111, 116, 120, 123-125, 127, 130, 131, 134, 141, 143-145, 152-154, 160, 163, 167-170, 192^ four were nonrandomized trials,^195-197, 200^ and one was a prospective cohort study.^207^ Twenty-two studies were conducted in Europe.^43, 56, 58, 69, 74, 75, 82, 83, 89, 102, 103, 111, 123, 125, 131, 134, 145, 167-170, 192, 197, 207^ Nineteen studies were conducted in Asia (including Turkey),^48, 61, 63-65, 67, 79-81, 87, 91, 104, 141, 143, 144, 153, 154, 195, 200^ and 12 in North America (11 in the United States).^66, 68, 70, 77, 93, 99, 108, 116, 120, 124, 127, 130^ Four studies were conducted in Egypt,^100, 152, 163, 196^ and one each in New Zealand^96^ and Brazil.^160^ Study participants (n=6984) ranged in age from 6 months to 41 years (mean age in study under 18 years). Studies compared multiple techniques including coblation, cold dissection, electrocautery, laser, harmonic scalpel, and thermal welding, and the majority of studies reported only harms data. Twenty-one studies reported effectiveness data, chiefly time to return to normal diet or activity.^66, 75, 80, 83, 89, 91, 93, 103, 111, 116, 124, 127, 130, 131, 134, 144, 152, 163, 169, 170, 195, 197^

Table 25 Overview of studies comparing surgical techniques for tonsillectomy

Characteristic | RCTs | Nonrandomized Trials | Prospective Cohort Studies | Total Literature
Comparisons
Coblation vs. Cold Techniques | 6 | 1 | 0 | 7
Coblation vs. Electrocautery | 7 | 0 | 0 | 7
Coblation vs. Laser | 2 | 0 | 0 | 2
Cold Techniques vs. Electrocautery | 11 | 2 | 1 | 14
Cold Techniques vs. Harmonic Scalpel | 4 | 0 | 0 | 4
Cold Techniques vs. Laser | 2 | 0 | 0 | 2
Cold Techniques vs. Thermal Welding | 3 | 0 | 0 | 3
Electrocautery vs. Electrocautery | 1 | 1 | 0 | 2
Electrocautery vs. Harmonic Scalpel | 5 | 0 | 0 | 5
Other^*^ | 13 | 0 | 0 | 13
Study Characteristics
Allocates Intervention by Tonsil | 8 | 2 | 0 | 10
Assesses Total Tonsillectomy | 51 | 4 | 1 | 56
Assesses Partial Tonsillectomy | 3 | 0 | 0 | 3
Surgical Indication
Throat Infection | 6 | 3 | 0 | 9
OSDB | 7 | 0 | 0 | 7
OSDB+Throat Infection | 28 | 1 | 0 | 29
Not specified | 13 | 0 | 1 | 14
Effectiveness Outcomes Frequently Reported
Time to Return to Normal Diet | 14 | 1 | 0 | 15
Time to Return to Normal Activity | 6 | 1 | 0 | 7
Risk of Bias
Low | 16 | 1 | 1 | 18
Moderate | 25 | 3 | 0 | 28
High | 13 | 0 | 0 | 13
Total N participants | 6446 | 478 | 60 | 6984

* Includes comparisons of 3 techniques;^43, 77, 82, 99, 163^ cold techniques vs. other cold techniques^56^ or molecular resonance;^83, 192^ electrocautery vs. laser^111^ or molecular resonance,^64^ or unspecified tonsillectomy;^141^ coblation vs. molecular resonance;^74^ and laser vs. other lasers.^58^

N = number; OSDB = obstructive sleep-disordered breathing; RCT = randomized controlled trial

We considered 16 studies to have low risk of bias^43, 56, 69, 70, 75, 89, 93, 120, 123, 125, 131, 134, 144, 163, 167-170^ 30 to have moderate risk,^48, 58, 63, 64, 66, 74, 79, 80, 82, 83, 87, 91, 96, 103, 111, 116, 124, 127, 130, 141, 145, 152, 154, 160, 192, 195-197, 200, 207^ and 13 to have high risk.^61, 65, 67, 68, 77, 81, 99, 100, 102, 104, 108, 143, 153^ Major sources of bias in these studies included unclear methods for randomization, for accounting for potential confounding or modifying variables, and for handling imbalances between study groups. We do not discuss high risk of bias studies in the detailed analyses below.

### Detailed Analysis

As noted, most studies reported harms data (see Harms of Tonsillectomy section below). Nineteen studies (17 RCTs and 2 nonrandomized trials)—eight with low^75, 89, 93, 131, 134, 144, 163, 169, 170^and 11 with moderate risk of bias^66, 80, 91, 103, 111, 116, 124, 127, 130, 152, 197^—reported on return to normal diet or activity—the only usable effectiveness outcomes reported.

#### Findings By Surgical Comparison

##### Coblation Versus Cold Dissection Tonsillectomy

Five RCTs (4 low^89, 93, 144, 169, 170^ and 1 moderate^75^ risk of bias) and one nonrandomized trial with moderate risk of bias^197^ compared coblation and cold dissection tonsillectomy (Table 26). Across these small, short-term studies, coblation tonsillectomy was generally associated with faster return to normal diet or activity. Four studies reported on return to normal diet, with mixed results. In two low risk of bias studies, children receiving coblation tonsillectomy returned to normal diet sooner (roughly 2-3 days) than those undergoing cold dissection;^89, 144^ in two other studies (one low, one moderate risk of bias), differences were not significant between groups.^75, 93^ Return to normal activity occurred significantly earlier after coblation in three low risk of bias studies.^89, 144, 169, 170^ In one moderate risk of bias nonrandomized study, children undergoing coblation tonsillectomy had fewer post-procedure school absences than those receiving cold dissection (mean 5.3 vs. 8.9 days, p<0.001).^197^

Table 26 Return to normal diet and activity in studies comparing coblation and cold dissection tonsillectomy

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Return to Normal Diet or Activity
Omrani 2012^144^ RCT Low ROB | G1: Coblation tonsillectomy(47) G2: Cold dissection Tonsillectomy (47) | Time to return to normal diet, mean days ± SD G1: 6.27 ± 1.07 G2: 9.25 ± 1.3 G1 vs. G2: p < 0.0001 Time to return to normal activity, mean days ± SD G1: 7.63 ± 1.16 G2: 11.7 ± 1.68 G1 vs. G2: p < 0.0001
Roje 2009^169, 170^ RCT Low ROB | G1: Coblation tonsillectomy (50) G2: Cold dissection tonsillectomy (50) | Time to return to normal activity, mean days (range) G1: 2 (1-7) G2: 4 (1-9) G1 vs. G2: p < 0.001
Parker 2009^75^ RCT Moderate ROB | G1: Coblation tonsillectomy (35) G2: Cold steel tonsillectomy (35) | Return to normal diet, days Data reported only in figures G1 vs.G2: p=NS
Di Rienzo Businco 2008^197^ Nonrandomized trial Moderate ROB | G1: Coblation tonsillectomy (21) G2: Cold dissection tonsillectomy (21) | Days absent from school post-procedure, mean±SD G1: 5.3 ± 1.7 G2: 8.9 ± 1.5 G1 vs. G2: p<0.001
Shapiro 2007^93^ RCT Low ROB | G1: Coblation tonsillectomy (23) G2: Cold dissection tonsillectomy (23) | Time to return to normal diet, mean days G1: 4 G2: 3 G1 vs. G2: p = NS
Mitic 2007^89^ RCT Low ROB | G1: Coblation tonsillectomy (20) G2: Cold dissection tonsillectomy (20) | Expected postoperative day to achieve normal diet G1: 6.80 G2: 8.93 G1 vs. G2: p<0.001 Expected postoperative day to achieve normal activity G1: 6.62 G2: 8.45 G1 vs. G2: p<0.001

G=group; N=number; NS=not significant; ROB=risk of bias

##### Electrocautery Versus Cold Dissection Tonsillectomy

Electrocautery was generally associated with more favorable results in three small RCTs addressing this comparison (one with low^134^ and two with moderate risk of bias^79, 127^) (Table 27). Electrocautery was superior to cold dissection in a faster return to normal diet in two studies^79, 134^ and did not differ in the third.^127^ Return to activity was significantly faster in the electrocautery arm in one study,^134^ but no different in two others.^79, 127^

Table 27 Return to normal diet and activity in studies comparing electrocautery and cold dissection tonsillectomy

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Return to Normal Diet or Activity
Nunez 2000^134^ RCT Low ROB | G1: Electrocautery tonsillectomy (24) G2: Cold dissection tonsillectomy (26) | Time to return to normal diet, median days (95% CI) G1: 7.5 (5-8) G2: 5 (3-7) G1 vs. G2: p < 0.05 Time to return to normal activity, median days (95% CI) G1: 7 (5-8) G2: 5 (3-8) G1 vs. G2: p < 0.05
Hesham 2009^79^ RCT Moderate ROB | G1: Electrocautery tonsillectomy (71) G2: Cold dissection tonsillectomy (69) | Mean % of normal diet resumed (POD1), mean ± SD G1: 54.67 ± 13.69 G2: 48.53 ± 21.54 G1 vs.G2: p <0.05 Mean % of normal diet resumed (POD7), mean ± SD G1: 84 ± 19 G2: 91.3 ± 14.17 G1 vs.G2: p <0.05 Mean % of normal activity resumed (POD1), mean ± SD G1: 73.33 ± 19.68 G2: 78.13 ± 16.9 G1 vs. G2: p=NS Mean % of normal activity resumed (POD7), mean ± SD G1: 92.67 ± 14.92 G2: 96 ± 7.17 G1 vs. G2: p=NS
Young 2001^127^ RCT Moderate ROB | G1: Electrocautery tonsillectomy (26) G2: Cold dissection tonsillectomy (31) | Time to return to normal diet and activity G1 vs.G2: p=NS

G=group; N=number; NS=not significant; POD=postoperative day; ROB=risk of bias

##### Coblation Versus Electrocautery Tonsillectomy

Four RCTs with moderate risk of bias compared coblation and electrocautery tonsillectomy with mixed results (Table 28).^66, 116, 124, 131^ Children who underwent coblation returned to normal diet more quickly than those who underwent electrocautery tonsillectomy in two studies,^66, 131^ but return did not differ significantly between groups in two others.^116, 124^ Children who underwent coblation also returned to normal activity roughly two days more quickly than those who underwent electrocautery in two studies.^116, 124^

Table 28 Return to normal diet and activity in studies comparing coblation and electrocautery tonsillectomy

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Return to Normal Diet or Activity
Temple 2001^131^ RCT Low ROB | G1: Coblation tonsillectomy (18) G2: Electrocautery tonsillectomy (20) | Time to return to normal diet, mean days G1: 2.4 G2: 7.6 G1 vs. G2: p < 0.0001
Parker 2011^66^ RCT Moderate ROB | G1: Coblation tonsillectomy (40) G2: Electrocautery tonsillectomy (40) | Time to return to normal diet, mean days G1: 5.2 G2: 6.2 G1 vs.G2: p=0.04
Stoker 2004^116^ RCT Moderate ROB | G1: Coblation tonsillectomy (44) G2: Electrocautery tonsillectomy (45) | Time to return to normal diet, mean days ± SD G1: 4.6 ± 2.1 G2: 5.2 ± 2 G1 vs. G2: p = NS Time to return to normal activity, mean days ± SD G1: 7.4 ± 1.9 G2: 6.7 ± 1.8 G1 vs. G2: p = NS
Shah 2002^124^ RCT Moderate ROB | G1: Coblation tonsillectomy (17) G2: Electrocautery tonsillectomy (17) | Time to return to normal diet for >50% of participants G1: within 7 days postoperatively G2: >10 days postoperatively G1 vs.G2: p=NS Time to return to normal activity for >50% of participants G1: 8 days postoperatively G2: 10 days postoperatively G1 vs.G2: p=NR Parental return to work G1 vs. G2: p=NS

G=group; N=number; NR=not reported; NS=not significant; POD=postoperative day; ROB=risk of bias

##### Harmonic Scalpel Versus Other Tonsillectomy Techniques

Three RCTs with moderate risk of bias evaluated tonsillectomy with a harmonic scalpel (which uses ultrasonic frequency to cut and cauterize tissue) compared with electrocautery,^130^ coblation,^152^ or cold dissection^103^ (Table 29). Studies compared different measures of return to normal diet or activity, thus limiting our ability to draw conclusions about differences in effectiveness. In the most recent RCT, children who had harmonic scalpel tonsillectomy returned to school after surgery in a median of 6 days compared with 8 who had coblation (p=NR). Another RCT comparing harmonic scalpel and cold dissection reported “dietary intake scores” ranging from zero to 3, with a score of zero indicating fluids only and a score of 3 indicating fluids plus normal diet.^103^ Children in the harmonic scalpel group had better dietary scores at each postoperative measurement (days 1, 3, 5, 7, 9), but scores in both groups declined over time. A final RCT reported the number of children who returned to normal diet and activity.^130^ Significantly more children in the harmonic scalpel group resumed their normal diet or activity compared with children undergoing electrocautery at postoperative day 1 and day 3.

Table 29 Return to normal diet and activity in studies comparing harmonic scalpel and other techniques for tonsillectomy

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Return to Normal Diet or Activity
Salama 2012^152^ RCT Moderate ROB | G1: Harmonic scalpel tonsillectomy (75) G2: Coblation tonsillectomy (75) | Days to return to school post-tonsillectomy, median G1: 6 G2: 8
Oko 2005^103^ RCT Moderate ROB | G1: Harmonic scalpel tonsillectomy (45) G2: Cold dissection (48) | Dietary intake scores, median (range) POD1 G1: 1 (0-1) G2: 0 (0-1) G1 vs. G2: p<0.0001 POD9 G1: 0 (0-1) G2: 0 (0-1) G1 vs. G2: p=0.006
Walker 2001^130^ RCT Moderate ROB | G1: Harmonic scalpel tonsillectomy (97) G2: Electrocautery tonsillectomy (75) | N returned to normal diet by POD1 G1: 43 (44.3) G2: 17 (22.7) G1 vs. G2: p = 0.004 N returned to normal diet by POD3 G1: 72 (74.2) G2: 35 (46.7) G1 vs. G2: p = 0.001 N returned to normal activity by POD1 G1: 27 (27.8) G2: 9 (12) G1 vs. G2: p = 0.011 N returned to normal activity by POD3 G1: 48 (49.5) G2: 17 (22.7) G1 vs. G2: p = 0.001

G=group; N=number; NR=not reported; POD=postoperative day; ROB=risk of bias

##### Laser Versus Coblation and/or Cold Dissection Tonsillectomy

Only two small RCTs addressed laser and did not provide sufficient data to draw conclusions about effectiveness compared with more standard techniques (Table 30). Two RCTs with low^163^ and moderate^91^ risk of bias comparing either potassium titanyl phosphate (KTP) laser or diode laser tonsillectomy to coblation and/or cold dissection reported no significant group differences in time to return to normal diet.

Table 30 Return to normal diet and activity in studies comparing laser and coblation and/or cold dissection for tonsillectomy

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Return to Normal Diet or Activity
Elabdawey 2015^163^ RCT G1: Coblation tonsillectomy (40) G2: Cold dissection tonsillectomy (40) G3: Diode laser tonsillectomy (40) Low ROB | G1: Laser tonsillectomy (40) G3: Coblation tonsillectomy (40) G2: Cold dissection tonsillectomy (40) | Time to return to normal diet, mean day G1: 5 G2: 4 G3: 4 G1 vs.G2 vs.G3: p = NS
Hegazy 2008^91^ RCT Moderate ROB | G1: Laser tonsillectomy (40) G2: Coblation tonsillectomy (40) | Time to return to normal diet or activity G1 vs.G2: p = NS

G=group; N=number; NS=not significant; ROB=risk of bias

##### Thermal Welding Versus Cold Dissection and/or Electrocautery Tonsillectomy

Two studies compared thermal welding tonsillectomy (a newer tonsillectomy technique which uses heated forceps to cut and cauterize tissue) and either cold dissection^80^ or cold dissection and electrocautery (Table 31).^195^ Studies reported different measures, which limits our ability to draw conclusions. The RCT comparing thermal welding and cold dissection (moderate risk of bias) reported no differences in return to normal activity (mean of 5 days post-tonsillectomy).^80^ Time to return to normal diet was lowest in the cold dissection group followed by thermal welding (p<0.001) followed by the electrocautery arm in the nonrandomized trial.^195^

Table 31 Return to normal diet and activity in studies comparing thermal welding and other techniques for tonsillectomy

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Return to Normal Diet or Activity
Ozkiris 2012^195^ Nonrandomized trial Moderate ROB | G1: Thermal welding tonsillectomy (104) G2: Cold dissection tonsillectomy (99) G3: Electrocautery tonsillectomy (102) | Time to return to normal diet, mean days ± SD (range) G1: 7.3 ± 0.7 (7-9) G2: 7 ± 1.5 (6-9) G3: 9.3 ± 1.7 (9-11) G1 vs.G2: p < 0.001 Other p values=NR
Sezen 2008^80^ RCT Moderate ROB | G1: Thermal welding tonsillectomy (25) G2: Cold dissection tonsillectomy (25) | Time to return to normal activity, mean days G1+G2: 5 G1 vs.G2: p = NS

G = group; N = number, NR = not reported; NS = not significant; ROB = risk of bias

## Harms of Tonsillectomy

### Key Points

- We found a low frequency of post-tonsillectomy hemorrhage (PTH) and utilization harms across surgical techniques and have confidence in these findings (high strength of evidence).
- In meta-analyses, the frequency of primary and secondary PTH associated with total and partial tonsillectomy was below 4 percent for any technique and with overlapping confidence bounds. Overall, estimates of PTH and utilization harms associated with tonsillectomy were below 8 percent.
- The pooled frequency (without adjustment) of PTH was below 5 percent overall (4.2% for total tonsillectomy; 1.5% for partial tonsillectomy) in comparative studies.
- We found a low frequency of revisits or readmission for dehydration associated with partial tonsillectomy. Our confidence in this conclusion is low (low strength of evidence). We have greater confidence in a low frequency of nonbleeding readmissions/revisits associated with total tonsillectomy (moderate strength of evidence).
- We could not draw conclusions about effects on admissions or revisits for pain or postoperative nausea and vomiting (PONV) associated with partial tonsillectomy given the few comparative studies addressing the outcome (insufficient strength of evidence).
- Overall unadjusted frequencies of revisits for pain, dehydration, or PONV were below 5 percent.
- Other harms were disparate and generally not clinically significant. No comparative studies reported deaths.
- The frequency of harms in case series and database or registry studies was consistent with that in comparative studies. At least four deaths were reported in case series including 1,778,342 children.

### Overview of the Literature

In order to account fully for potential harms of tonsillectomy, primarily PTH, readmission and reoperation, we compiled all comparative studies and examined rates of harms by arm, then reviewed case series and database studies, which were not included in the effectiveness analysis. We considered PTH to comprise any report of post-tonsillectomy bleeding, including the entire of range of bleeding as reported in each study, from bloody sputum to frank bleeding requiring readmission or reoperation. We did not assess harms separately by indication because there is no reason to expect that they would differ; therefore, we do not separate them into the KQ1 through KQ4 results sections but combine surgical harms here.

We present the data obtained from comparative studies that had low or moderate risk of bias followed by that of the case series and database studies (low or moderate risk of bias) and comment on their consistency. Finally, we conducted a Bayesian meta-analysis to estimate predicted primary PTH, secondary PTH, reoperation and readmission by partial and total tonsillectomy, and by surgical approach.

#### Comparative Study Arms Reporting PTH or Other Harms Data

One-hundred and one comparative studies of low or moderate risk of bias reported harms data.^6, 9, 38-41, 43-45, 47-49, 52-54, 56-60, 63, 64, 66, 69, 71, 74, 75, 78-80, 82, 84-87, 89-91, 93, 95, 96, 98, 103, 105-108, 110-112, 114-117, 119-125, 127, 128, 130-132, 134, 136, 138, 139, 141, 144, 145, 148, 150-155, 158, 160, 161, 163-172, 174-178, 182-186, 190, 192, 194-197, 199, 200, 207, 212, 213, 286^ Most studies (n=85) reported PTH-related outcomes including number of PTH, which may have been reported as primary (generally defined as occurring within 24 hours of surgery), secondary (generally defined as occurring more than 24 hours postoperatively), or at an undefined or unspecified time.^9, 38, 40, 41, 43-45, 47, 48, 53, 54, 56-60, 63, 64, 66, 69, 71, 74, 75, 78-80, 82, 84-87, 89-91, 93, 95, 96, 98, 103, 105, 106, 108, 110-112, 115-117, 119, 120, 123-125, 127, 130, 131, 134, 138, 139, 141, 144, 145, 148, 150-153, 158, 160, 161, 163-178, 182-186, 192, 194-197, 199, 200, 207^ Other frequently reported harms in comparative studies (n=32) included revisits or readmissions for postoperative pain, dehydration, or PONV.^39, 43, 52, 66, 69, 74, 85, 93, 98, 103, 107, 111, 112, 114, 116, 119, 121-125, 130, 134, 139, 148, 154, 164-166, 171-178, 185, 186, 207, 212, 213^ Twenty-four studies also reported other non-PTH harms of surgical procedures.^6, 9, 43, 44, 54, 58, 69, 70, 85, 107, 111, 112, 114, 120, 124, 125, 130, 145, 158, 196, 207, 213, 287^

We present detailed harms tables in Appendix H. The tables in this appendix report pooled frequency of harms without adjustment, typically presented by technique (e.g., coblation, cold dissection), extent of surgery (partial or total tonsillectomy), and indication (OSDB, throat infection, mixed [OSDB and throat infection], or unspecified) where possible. We included studies with low or moderate risk of bias in our unadjusted estimates.

#### Studies Reporting Harms Combined in Meta-Analysis

Seventy-three studies contributed data to the meta-analysis (66 RCTs,^43, 44, 48, 53, 56, 58, 61, 63-66, 69, 71, 74, 75, 77, 79-86, 89-91, 93, 95-100, 102-104, 108, 110, 111, 116, 120, 123-125, 127, 129-131, 134, 139, 141, 143-145, 151-153, 158, 160, 163, 169, 170, 182-184, 187, 189, 192^ 6 nonrandomized trials,^193, 195-198, 200^ and 1 prospective cohort study^207^). We included study arms in the meta-analysis if they evaluated total (71 arms^43, 44, 48, 53, 56, 61, 63-66, 69, 71, 74, 75, 77, 79-86, 89-91, 93, 95, 96, 98-100, 102, 103, 108, 110, 111, 116, 120, 123-125, 127, 129-131, 134, 139, 141, 143-145, 151-153, 158, 160, 163, 169, 170, 182-184, 187, 189, 192, 193, 195-198, 200, 207, 286^) or partial tonsillectomy (20 arms^53, 58, 71, 84-86, 90, 95, 98, 110, 129, 139, 143, 151, 158, 182-184, 187, 189, 193, 198^). The resulting subset of studies included the following tonsillectomy techniques: cold dissection, electrocautery, coblation, harmonic scalpel, laser, molecular resonance, thermal welding, and microdebrider. We further partitioned data based on PTH outcomes, and included primary (occurring within 24 hours of surgery) PTH (21 studies, 44 arms), secondary (occurring >24 hours postsurgery) PTH (30 studies, 63 arms), non-operative readmission associated with PTH (19 studies, 39 arms), and reoperation associated with PTH (30 studies, 64 arms).

Twenty studies included in the meta-analysis had low risk of bias;^43, 53, 56, 66, 69, 75, 89, 90, 93, 97, 98, 120, 123, 125, 131, 134, 144, 151, 163, 169, 170^ 37 had moderate risk,^44, 48, 58, 63, 64, 71, 74, 79, 80, 82-86, 91, 95, 96, 103, 110, 111, 116, 124, 127, 130, 139, 141, 145, 152, 158, 160, 182-184, 192, 195-197, 200, 207^ and 16 had high risk.^61, 65, 77, 81, 99, 100, 102, 104, 108, 129, 143, 153, 187, 189, 193, 198^ As noted, in sensitivity analyses, high risk of bias studies did not affect findings, so we included them in final analyses.

#### Case Series and Database Studies Reporting Harms

In addition, we captured PTH reported in case series and database analyses to determine whether the frequency supported findings in the comparative literature and to assess harms in larger study populations. We identified 53 unique database or registry studies or case series with ≥ 1000 children (reported in 63 papers) addressing PTH or other harms including readmissions or revisits for dehydration or nausea.^21, 215-276^ Twenty-three studies were conducted in North America.^21, 215, 223, 224, 227, 228, 232-237, 239, 247, 248, 256, 257, 261, 266-268, 270-273^ Twenty-two were conducted in Europe;^216-222, 225, 226, 229, 231, 238, 241, 243, 245, 250-255, 258-260, 262-264, 269, 274, 276^ five in Asia;^230, 244, 246, 249, 265^ and three in Australia or New Zealand.^240, 242, 275^ We rated 19 studies as low risk of bias^21, 217-221, 225, 226, 228, 229, 231, 233, 235-237, 239-241, 243, 244, 247, 248, 250, 251, 258, 266-271^and 27 as moderate.^215, 216, 223, 224, 227, 230, 232, 234, 238, 242, 245, 246, 249, 252-257, 259-263, 272-276^ We considered seven studies^237, 239, 240, 243, 244, 264, 265^ to have a high risk of bias and do not present them in the detailed analysis.

Studies included a total of 1,808,568 children, with numbers of participants ranging from 1,109 to over 500,000 across studies. Most studies (n=36) reported generally on PTH or other sequelae of tonsillectomy without specifying surgical technique.^21, 215, 216, 223, 225-229, 231-233, 237-244, 247, 248, 255, 257-259, 262, 265-268, 270-272, 274-276^ Twelve studies reported PTH or other harms by surgical technique or instrument,^217-221, 224, 245, 246, 249-254, 256, 261, 263, 264^ three reported specifically on PTH related to dexamethasone or nonsteroidal anti-inflammatory drug (NSAID) use,^230, 234, 236, 271^ and four reported PTH by surgical indication and technique,^220, 221, 230, 256, 260^ one reported readmission data by comorbidity,^238^ and one reported specifically on reoperation following partial or total tonsillectomy.^269^

PTH was reported in nearly all studies. Eleven studies reported on readmission for non-PTH indications.^21, 220-222, 224, 232, 233, 235, 236, 242, 248, 255, 260, 275, 288^ Twelve studies reported mortality or other harms.^224, 228, 232, 238, 245, 247, 250-255, 262, 270, 275^ Appendix H provides more details on harms reported in each study and tables of unadjusted pooled frequency of PTH and other harms reported in studies with low or moderate risk of bias.

### Detailed Analysis

#### Unadjusted PTH-Related Outcomes in Comparative Studies Addressing Tonsillectomy

##### Total Tonsillectomy

One-hundred and four study arms reported postoperative PTH after total tonsillectomy.^9, 43, 44, 48, 53, 56, 63, 64, 66, 69, 71, 74, 75, 79, 80, 82, 84, 86, 87, 89-91, 93, 95, 96, 98, 103, 108, 110, 111, 116, 120, 123-125, 127, 130, 131, 134, 139, 141, 144, 145, 151-153, 158, 160, 163-166, 169-178, 185, 186, 192, 195-197, 200, 207, 213^ We first present unadjusted PTH frequency. The 6299 children across studies who were treated with total tonsillectomy experienced 265 episodes (4.2%) of PTH (Table 32). Among these episodes, 33 were primary (typically occurring within 24 hours of tonsillectomy), 166 were secondary (occurring more than 24 hours post-tonsillectomy), and for 66, timing was not specified. Sixty-eight children required reoperation to control PTH (2.2%), and 80 had nonoperative revisits or readmissions for PTH (3.0%). Children who underwent tonsillectomy with harmonic scalpel had the highest frequency of PTH (11.3%), although few children underwent this procedure (n=397). Few children also had laser tonsillectomy (n=189), with 5.3 percent experiencing PTH. Frequencies were similar among techniques that are more commonly used: cold dissection=3.8 percent; electrocautery =4.9 percent; and coblation=3.2 percent. The frequency of revisits and reoperations overall was typically less than 6 percent. Tables in Appendix H outline rates associated with each technique in each study arm.

Table 32 Unadjusted PTH-related outcomes in study arms evaluating total tonsillectomy

Technique (N arms) | Total N | Total PTH (%) | Total Primary PTH (%) | Total Secondary PTH (%) | Total Unspecified PTH (%) | Total Nonoperative Revisits/Readmissions for PTH (%) | Total Reoperations for PTH (%)
All arms (105) | 6299 | 265 (4.2) | 33 (1.3) | 166 (4.8) | 66 (2.7) | 80 (3) | 68 (2.2)
Electrocautery (29) | 1668 | 82 (4.9) | 5 (0.37) | 62 (6.3) | 15 (2.3) | 36 (5) | 21 (2.6)
Cold dissection (34) | 1904 | 72 (3.8) | 6 (0.54) | 49 (4) | 17 (2.7) | 9 (1.6) | 19 (2.3)
Coblation (19) | 728 | 23 (3.2) | 3 (2.1) | 7 (2.4) | 12 (2.7) | 2 (1.1) | 4 (2.5)
Unspecified/other technique (5) | 748 | 25 (3.3) | 9 (3.1) | NR | 16 (3.5) | 8 (2) | 10 (2.3)
Molecular resonance (5) | 466 | 4 (0.86) | 0 (0) | 4 (1.22) | 0 (0) | 1 (0.23) | 1 (0.31)
Harmonic scalpel (5) | 397 | 45 (11.3) | 1 (0.63) | 38 (11.3) | 6 (9.8) | 15 (5.5) | 9 (2.8)
Thermal welding (4) | 199 | 5 (2.5) | 0 (0) | 5 (2.96) | 0 (0) | NR | 1 (0.96)
Laser (4) | 189 | 10 (5.3) | 9 (11.4) | 1 (0.91) | NR | 9 (11.4) | 3 (2.8)

Note: Percentages for primary and secondary PTH, readmissions/revisits, and reoperations reflect the number of each instance of bleeding or reencounter divided by the total number of patients in the studies reporting such data, and not in the total number of participants across all studies in a given row.

N = Number; PTH = Post-Tonsillectomy Hemorrhage

##### Partial Tonsillectomy

Total PTH did not exceed 5 percent among the 18 study arms contributing data to assess bleeding after partial tonsillectomy (Table 33).^53, 58, 71, 84-86, 90, 95, 98, 110, 139, 151, 158, 167, 168, 183-186, 289^ PTH was highest after coblation tonsillectomy (4.2%). No PTH was associated with laser approaches, but few studies assessed this modality.^58, 167, 168^

Table 33 Unadjusted PTH-related outcomes in study arms evaluating partial tonsillectomy

Technique (n arms) | Total N | Total PTH (%) | Total Primary PTH (%) | Total Secondary PTH (%) | Total Undefined PTH (%) | Total Nonoperative Revisits/Readmissions for PTH (%) | Total Reoperations for PTH (%)
All arms (18) | 599 | 8 (1.5) | 0 (0) | 2 (1.6) | 6 (1.4) | 5 (1.8) | 1 (0.64)
Microdebrider (5) | 252 | 3 (1.2) | NR | NR | 3 (1.2) | 3 (1.5) | NR
Coblation (6) | 169 | 4 (4.2) | 0 (0) | 2 (6.3) | 2 (2.2) | 2 (2.8) | 0 (0)
Cold dissection (4) | 124 | 1 (0.81) | 0 (0) | 0 (0) | 1 (1.4) | NR | 1 (1.1)
Laser (3) | 54 | 0 (0) | 0 (0) | 0 (0) | 0 (0) | NR | NR

Note: Percentages for primary and secondary PTH, readmissions/revisits, and reoperations reflect the number of each instance of bleeding or reencounter divided by the total number of patients in the studies reporting such data, and not in the total number of participants across all studies in a given row.

N = Number; PTH = Post-Tonsillectomy Hemorrhage

##### PTH by Indication

Across all techniques and types of tonsillectomy (partial or total), the overall occurrence of PTH after surgery was lowest in children with OSDB (Table 34).

Table 34 Unadjusted PTH-related outcomes by indication in study arms evaluating total or partial tonsillectomy

Indication (N arms) | Total N | Total PTH (%) | Total Primary PTH (%) | Total Secondary PTH (%) | Total Undefined PTH (%) | Total Nonoperative Revisits/Readmissions for PTH (%) | Total Reoperations for PTH (%)
OSDB (28) | 1219 | 22 (1.9) | 2 (0.4) | 11 (2.1) | 9 (1.4) | 8 (1.4) | 3 (0.85)
Throat infection (28) | 1764 | 88 (5.0) | 12 (1.8) | 64 (6.2) | 12 (2.3) | 29 (3.4) | 10 (1.6)

Note: Percentages for primary and secondary PTH, readmissions/revisits, and reoperations reflect the number of each instance of bleeding or reencounter divided by the total number of patients in the studies reporting such data, and not in the total number of participants across all studies in a given row.

N = Number; PTH = Post-Tonsillectomy Hemorrhage

##### Revisits for Pain, Dehydration, or PONV Following Tonsillectomy Reported in Comparative Studies

Revisits for pain, dehydration, or PONV typically occurred in less than 10 percent of children (Table 35). Eight studies reported zero revisits for non-PTH indications associated with interventions studied.^52, 93, 114, 119, 121, 125, 134, 148^ Two studies reported that more than 10 percent of children had revisits or readmissions (see Appendix H for full details).^116, 123^ One RCT comparing KTP laser and cold dissection total tonsillectomy as day-stay procedures reported 25 total admissions for pain (13 for cold dissection and 12 in laser) and 29 for vomiting (16 in cold dissection arm and 13 in laser) on the day of surgery.^123^ In another RCT comparing electrocautery and coblation tonsillectomy, revisits comprised both return visits and phone calls to the provider; thus, numbers are higher than those reported in other studies.^116^

Table 35 Unadjusted revisits for pain, dehydration, or PONV reported after tonsillectomy in arms of comparative studies

Technique (N arms) | Total Arm N | Pain Revisits/Readmissions, n (%) | Dehydration Revisits/Readmissions, n (%) | PONV Revisits/Readmissions, n (%) | Other Revisits/Readmissions, n (%)
All arms (37) | 2969 | 45 (1.5) | 39 (1.6) | 45 (1.5) | 3 (0.09)
Electrocautery-total (12) | 883 | 12 (7.3) | 20 (2.3) | 7 (5.1) | NR
Cold dissection-total (9) | 622 | 14 (5.4) | 1 (0.21) | 16 (10.5) | NR
Unspecified tonsillectomy (4) | 529 | NR | 9 (2.4) | 5 (0.85) | NR
Molecular resonance-total (2) | 362 | NR | 0 | NR | NR
Harmonic scalpel-total (2) | 216 | NR | 2 (1.3) | NR | 3 (4.9)
Coblation-total (5) | 198 | 6 (8.8) | 7 (3.5) | 4 (9.8) | NR
Laser-total (3) | 159 | 13 (10.1) | 0 | 13 (16.5) | NR
Microdebrider-partial (2) | 187 | 0 | 5 (2.5) | NR | NR
Coblation-partial (1) | 34 | NR | 0 | NR | NR

Note: Percents for readmissions/revisits reflect the number of each reencounter divided by the total number of patients in the studies reporting such data, and not in the total number of participants across all studies in a given row.

N = Number, NR = Not Reported; PONV = Postoperative Nausea and Vomiting

##### Other Harms Following Tonsillectomy Reported in Comparative Studies

Twenty-three studies also reported other non-PTH harms of surgical procedures.^6, 9, 43, 44, 54, 58, 69, 70, 85, 107, 111, 112, 114, 120, 124, 125, 130, 145, 158, 196, 207, 213, 287^ Harms were largely minor and included burns or unspecified breathing complications (Table 36), and two studies including children with OSDB reported velopharyngeal insufficiency (VPI).^85, 124^ One study noted that VPI resolved within two months,^85^ and the other did not comment on resolution or severity.^124^ Eight studies explicitly reported that no non-PTH harms occurred (not shown in table);^58, 70, 107, 120, 125, 145, 158, 207^ Seven studies (15 arms) explicitly reported that no deaths occurred,^43, 54, 69, 74, 111, 130, 213^and two studies reported that no cases of VPI occurred.^107, 125^

Table 36 Other harms reported in studies of surgical techniques compared with medical treatment or other surgical techniques

Nonbleeding Harms of Surgical Techniques | Number of Studies (# Participants With Harm/Total Participants) | Reported Occurrence Across Studies
Electrocautery total tonsillectomy
Thermal burns in oral mucosa and tongue or other burns^196^ | 1 (14/91) | 15%
Burn to thigh from improper grounding of electrocautery unit –hospitalized 3 days^114^ | 1 (1/21) | 4.7%
Coblation total tonsillectomy
VPI^85, 124^ | 2 (2/52) | 2.8%-5.8%
Airway obstruction^124^ | 1 (2/34) | 5.9%
Cold dissection partial tonsillectomy
Breathing complications^198^ | 1 (1/243) | 0.4%
Other complications^198^ | 1 (0/243) | 0%
Cold dissection total tonsillectomy
Lip burn from cautery^112^ | 1 (1/57) | 1.7%
Breathing complications^198^ | 1 (2/780) | 0.2%
Other (unspecified) complications^198^ | 1 (1/780) | 0.1%
CPAP
Rash from mask^44^ | 1 (1/36) | 2.7%
Total tonsillectomy (not specified)
Complications from GABHS infection or medical treatment of infection (drug reaction, peritonsillar abscess, scarlet fever)^213^ | 1 (16/145) | 5.7%
Erythematous rash from penicillin for throat infection^6^ | 1 (1/96)^*^ | 1%
Erythematous rash while receiving antimicrobial drug^9^ | 2 (4/190)^*^ | 2.1%

Note: 4 children in a no tonsillectomy arm also experienced erythematous rash while receiving penicillin in studies described in one publication,^6^ and three children in nonsurgical arms in another publication reporting 2 studies developed an antibiotic-associated erythematous rash.^9^ The table notes one study reporting these outcomes as the publications combined data from each of the 2 studies reported in each paper and did not present harms data by study.

CPAP = Continuous Positive Airway Pressure

#### Meta-Analysis Results

##### Harms Associated With Total Tonsillectomy

Frequency of primary PTH associated with total tonsillectomy in the meta-analysis was below 4 percent and with overlapping confidence bounds (Table 37). Electrocautery and harmonic scalpel were associated with the highest frequency of secondary PTH (occurring >24 hours postprocedure), with estimates of 4.2 to 4.3 percent and wide 95% Bayesian credible intervals (BCI). Readmission ranged from 0.2 percent to 6 percent. Although laser tonsillectomy was associated with the highest estimated readmissions, the confidence bounds were very wide.

Table 37 PTH and PTH-associated readmissions or revisits after total tonsillectomy: percent (95% BCI)

Technique | Primary PTH | Secondary PTH | Nonoperative Revisit or Readmission | Reoperation
Cold | 0.7 (0.1 to 1.5) | 3.3 (1.9 to 5.3) | 2.7 (0.7 to 4.9) | 1.3 (0.5 to 2.1)
Electrocautery | 0.6 (0 to 1.5) | 4.2 (2.4 to 6.5) | 2.9 (0.7 to 5.3) | 1.2 (0.5 to 1.9)
Coblation | 1.1 (0 to 3.0) | 2.3 (0.7 to 4.4) | 1.4 (0.1 to 3.3) | 1.2 (0.3 to 2.4)
Harmonic Scalpel | 1.0 (0 to 3.3) | 4.3 (1.8 to 7) | 1.5 (0.2 to 3.1) | 3.9 (1.6 to 6.9)
Laser | 2.2 (1.0 to 5.8) | 1.2 (0 to 3.4) | 5.7 (0.7 to 12.6) | 5.2 (0.2 to 13.7)
Molecular Resonance | 0.6 (0 to 2.5) | 1.1 (0.2 to 2.4) | 0.2 (0 to 0.6) | 0.2 (0 to 0.5)
Thermal Welding | 0.5 (0 to 2.1) | 3.6 (0.5 to 7.5) | 2.7 (0 to 12.7) | 0.8 (0 to 2.4)

BCI = Bayesian credible interval; PTH = post-tonsillectomy hemorrhage

##### Harms Associated With Partial Tonsillectomy

Primary PTH associated with partial tonsillectomy was predicted to be below 4 percent regardless of technique, and secondary bleeding at or below 3 percent. Data on readmissions and reoperations were sparse; thus confidence bounds are very wide, and it is difficult to predict PTH and PTH-related outcomes with any certainty (Table 38).

Table 38 PTH and PTH-associated readmissions or revisits after partial tonsillectomy: percent (95% BCI)

Technique | Primary PTH | Secondary PTH | Nonoperative Revisit or Readmission | Reoperation
Cold | 1.5 (0 to 4.7) | 2.3 (1 to 5.9) | 3.7 (0.1 to 10.3) | 0.5 (0 to 1.3)
Electrocautery | 1.5 (0 to 5.3) | 3 (0.2 to 8) | 4 (0.2 to 12.3) | 0.4 (0 to 1.2)
Coblation | 1.5 (0.1 to 4.2) | 1.4 (1 to 3.5) | 1.4 (0.1 to 3.1) | 0.4 (0 to 1.1)
Harmonic Scalpel | 2.2 (0 to 8.3) | 3 (1 to 7.9) | 2.1 (0 to 6.3) | 1.4 (0 to 3.9)
Laser | 3.9 (0 to 12.9) | 0.7 (0 to 2.4) | 7.3 (0.2 to 20.7) | 1.8 (0 to 5.4)
Molecular Resonance | 1.4 (0 to 6) | 0.8 (0 to 2.3) | 0.3 (0 to 1) | 0.1 (0 to 2)
Thermal Welding | 1 (0 to 4.5) | 2.6 (0 to 7.7) | 3.4 (0 to 17) | 0.3 (0 to 1)

BCI = Bayesian credible interval; PTH = post-tonsillectomy hemorrhage

#### Case Series and Database Analyses

Overall, 2.1 percent of children in case series experienced a PTH episode (Appendix H). Few children in these studies required readmission or reoperation for PTH (0.41% to 0.72%).

Few cases of revisits for pain, dehydration, or PONV (ranging from 1% to 11%) were reported in the 11 studies providing data. At least four deaths were reported across four case series or database studies reporting mortality.^247, 252, 253, 270, 275, 290^ In one study, a 10-year old child with muscular dystrophy and other comorbidities died from suspected ventricular fibrillation one month after tonsillectomy;^275^ investigators did not consider the death related to surgery. In another, a 42-month old child with recurrent PTH died from bleeding-related shock after he was discharged 6 days post-tonsillectomy.^252, 253, 290^ Another database study reported two deaths (out of 36,221 tonsillectomies, 0.006%) but did not report cause of death.^247^ Finally, a fourth database study did not report exact numbers or cause of death but compared tonsillectomy complications occurring in different hospital types (teaching or nonteaching children's hospitals, nonteaching hospitals).^270^ In each hospital type ≤10 deaths occurred, but the study does not report specific numbers.

Other harms reported in these studies were disparate and typically not clinically significant (Appendix H). One registry specifically examined the rate of reoperation following partial vs. total tonsillectomy and reported a greater risk of reoperation after partial tonsillectomy (hazard ratio=7.16, 95% CI: 5.52 to 9.13).^269^ Seventy-five of 11,741(0.6%) children who underwent total tonsillectomy required reoperation compared with 609 of 15,794 who underwent partial (3.9%, p<0.0001). The most common indication for reoperation after either type of tonsillectomy was upper airway obstruction (80% of cases). Three studies reported respiratory-related harms (Appendix H). In one database study, 383 out of 40,591 children had respiratory failure requiring mechanical ventilation (0.94%).^270^ In another database study evaluating outcomes in 21,434 obese or non-obese children undergoing tonsillectomy, 5 percent of obese children had major respiratory complications (pulmonary insufficiency, respiratory failure) compared with 3 percent of non-obese children.^228^ One case series including 1735 children reported postoperative desaturation, pulmonary edema, or lung collapse in 13 children (0.75%).^238^

## Key Question 5 Effectiveness of Perioperative Medications To Improve Outcomes

### Key Points

- We found a reduced need for analgesia with NSAIDs compared with placebo. Our confidence in this conclusion is low (low strength of evidence).
- We found no difference in effects on return to normal diet or activity with perioperative NSAIDs compared with placebo. Our confidence in this conclusion is low (low strength of evidence).
- We found a low frequency of PTH and associated utilization with perioperative NSAIDs. Our confidence in this conclusion is low (low strength of evidence).
- We could not make conclusions about non-PTH related readmissions or revisits following NSAID use as few studies addressed these outcomes (insufficient strength of evidence).
- We found a reduced need for analgesics or antiemetics associated with steroids (IV or infiltrated dexamethasone) compared with placebo. Our confidence in this conclusion is low (low strength of evidence).
- Studies of steroids reported few cases of PTH and PTH-related utilization. We have moderate confidence that steroids are associated with a low frequency of PTH (moderate strength of evidence).
- Meta-analysis of nine studies comparing steroids and placebo did not indicate a significantly increased risk of PTH with steroids vs. placebo; confidence bounds were wide for all estimates, and we have low confidence in this conclusion (low strength of evidence).
- We could not make conclusions about the effects of steroids on time to return to normal diet or activity or non-PTH-related readmissions or revisits (insufficient strength of evidence).
- We found a reduced need for postoperative antiemetics in studies of perioperative antiemetics; our confidence in this conclusion is low (low strength of evidence).
- We found no effect of 5-hydroxytryptamine (5-HT) perioperative antiemetics on postoperative analgesia requirements. We have moderate confidence in this conclusion (moderate strength of evidence).

### Overview of the Literature

Forty-nine studies (48 RCTs ^39, 40, 42, 45-47, 50-52, 54, 57, 59, 62, 72, 73, 76, 78, 88, 92, 94, 105, 106, 109, 112, 113, 117-119, 121, 122, 126, 128, 132, 133, 135, 136, 140, 142, 146-150, 156, 157, 161, 162, 188^ and one nonrandomized trial^199^) involving 5817 children ranging in age from less than 1 to 18 years addressed perioperative medications (NSAIDs, steroids, antiemetics, alone or in combination) for improving post-tonsillectomy outcomes (Table 39). Studies were primarily conducted in Asia (including China, India, Turkey, and Japan).^39, 45, 46, 50, 59, 62, 72, 73, 76, 105, 106, 109, 113, 117, 118, 121, 132, 133, 140, 146-150, 156, 157, 161, 162, 188, 199^ Six studies were conducted in Europe,^57, 78, 94, 128, 135, 136^ and six in North America (United States).^47, 54, 92, 112, 122, 126^ Six studies were conducted in Africa,^40, 42, 51, 52, 119, 142^ and one in Australia.^88^

Table 39 Overview of studies addressing perioperative pharmacologic agents to improve outcomes

Characteristic | NSAIDs | Steroids | Antiemetics | Multi-agent Therapy^*^ | Total Literature
Study design
RCT | 14 | 18 | 6 | 10 | 48
Nonrandomized trial | 0 | 1 | 0 | 0 | 1
Surgical Indication
Throat Infection | 2 | 0 | 0 | 2 | 4
OSDB +Throat Infection | 0 | 6 | 0 | 1 | 7
Unspecified | 11 | 12 | 5 | 10 | 38
Key Effectiveness Outcomes Reported
Rescue analgesics | 7 | 12 | 1 | 11 | 31
Rescue antiemetics | 1 | 12 | 2 | 7 | 22
Time to return to normal diet/activity | 2 | 2 | 0 | 3 | 7
Risk of Bias
Low | 3 | 8 | 5 | 7 | 23
Moderate | 9 | 6 | 0 | 6 | 21
High | 1 | 4 | 0 | 0 | 5
Total N participants | 1103 | 2368 | 1040 | 1306 | 5817

* Combination of drug classes. NSAIDs = nonsteroidal anti-inflammatory drugs; OSDB = obstructive sleep-disordered breathing; RCT = randomized controlled trial

Twenty-three studies had low risk of bias;^39, 40, 50-52, 54, 57, 59, 76, 88, 94, 105, 112, 113, 118, 119, 128, 132, 133, 135, 136, 146, 156^ 21 had moderate; ^42, 45-47, 62, 72, 78, 92, 106, 109, 117, 121, 122, 126, 142, 147-150, 157, 161^and five had high.^73, 140, 162, 188, 199^ Major sources of bias in these studies included unclear methods for randomization and for concealment of study group allocation. We do not discuss high risk of bias studies in the detailed analyses below.

Outcomes reported varied among studies: PTH, use of rescue medications, and use of rescue antiemetics were most frequently reported.

### Detailed Analysis

Most studies addressed the outcomes of time to return to normal diet or activity or need for rescue medications, which we defined as the need for additional or higher doses of pain medications or antiemetics beyond those given as part of the standard surgical protocol. We discuss findings by agent and key outcome below. Appendix H includes a detailed table of findings for each study.

#### NSAIDs

##### Return to Normal Diet and Activity

In two RCTs with moderate risk of bias comparing diclofenac suppository with or without other analgesics (acetaminophen plus tramadol) to lidocaine^72^ or placebo,^126^ time to resume normal activity or diet did not differ significantly between groups.

##### Need for Rescue Analgesics

###### Diclofenac

Analgesics. Two low ^52, 156^ and three moderate ^72, 121, 149^ risk of bias RCTs evaluated perioperative diclofenac. Two RCTs compared diclofenac suppository to placebo.^121, 156^ In both, consumption of opioids was significantly lower in diclofenac groups. Another study comparing oral gabapentin, diclofenac suppository, and placebo found the mean 24h opioid consumption was equivalent in gabapentin and diclofenac groups but significantly less than placebo.^156^

Other trials were not placebo-controlled and used a variety of comparative treatments. One that compared 2 percent viscous lidocaine post-tonsillectomy vs. diclofenac suppository reported no difference in analgesic need during the immediate 2 postoperative hours.^72^ Another study comparing diclofenac suppository vs. intravenous [IV] pethidine found fewer children in the diclofenac arm required analgesia medication and used a significantly lower mean paracetamol dose in the first 24 postoperative hours.^149^ A third trial compared triple analgesic regimen (diclofenac suppository, IV paracetamol, and IV tramadol) vs. placebo and reported that, in the immediate 4-6 postoperative period, no child in study group used rescue analgesia compared with 70 percent and 45 percent of controls who required rescue analgesia in the PACU and on the day surgery ward, respectively.^52^

Antiemetics. A single moderate risk of bias study that evaluated effectiveness of peritonsillar bupivacaine infiltration vs. diclofenac suppository reported no difference in antiemetic rescue use between arms.^161^

###### Ibuprofen

Analgesics. Three moderate risk of bias RCTs compared the effect of perioperative ibuprofen treatment vs. multiple different comparators and assessed postoperative analgesic requirements.^47, 106, 157^ Two evaluated IV ibuprofen,^47, 157^ while one used ibuprofen syrup.^106^ One trial comparing IV paracetamol alone, IV paracetamol + mefenamic acid, and IV paracetamol + ibuprofen reported that over the 24 hour followup period, the ibuprofen group used significantly less postoperative analgesia than paracetamol alone.^157^ A second trial compared single dose IV ibuprofen vs. placebo and assessed opioid use in the PACU.^47^ In intent to treat analysis, percentage of opioid use did not differ between groups, mean number of rescue opioid doses, or mean dose. Another trial compared ibuprofen syrup (administered 1 hour pre-operatively) + peri-tonsillar infiltrated epinephrine vs. infiltrated lidocaine with epinephrine and reported no differences in mean paracetamol dose between arms.^106^

###### Ketoprofen

Analgesics. Two low risk of bias RCTs evaluated the post-tonsillectomy analgesic use among patients treated with ketoprofen vs. placebo.^94, 128^ Study results differed. In one trial, no difference was observed in mean dose or proportion of patients receiving analgesia between those treated with IV ketoprofen at induction, IV ketoprofen after surgery, or placebo^128^ Another RCT compared ketoprofen, tramadol, and placebo and reported that patient-controlled analgesia requests were significantly lower in the ketoprofen group. No difference was observed in 24 hour total opioid use.^94^

###### Lornoxicam

Analgesics. A single moderate risk of bias RCT comparing IV lornoxicam, infiltrated lornoxicam, and placebo, reported rescue diclofenac consumption during first 24 hours was significantly lower in the IV group compared with either infiltration or placebo group (p<0.000).^142^ No difference was observed between infiltration and placebo groups.

###### Ketorolac

Analgesics. A single moderate risk of bias trial compared IV ketorolac vs. fentanyl and reported that fewer children in the ketorolac arm required rescue analgesia than in fentanyl arm (8% [n=2] vs. 28% [n=9]) in the immediate postoperative period in PACU.^117^ No overall difference in use of rescue medications was observed the first 24-hours postoperatively.

#### Steroids

##### Return to Normal Diet and Activity

Two low risk of bias RCTs assessed whether steroids affected time to return to normal diet post-tonsillectomy.^112, 135^ One comparing IV dexamethasone vs. placebo found that those treated with steroids were ingesting a significantly higher percentage of their normal diet than those in the placebo group on postoperative day (POD) one.^112^ A second trial comparing tropisetron and tropisetron + dexamethasone found no difference in the percentage of children returning to normal diet on POD one or five.^135^

A single low risk of bias RCT compared time to normal activity between children treated with IV dexamethasone vs. no steroid (both groups had peritonsillar infiltration of ropivacaine + clonidine) and found a nonsignificant longer time to resume normal activity in the steroid group.^52^

##### Need for Rescue Medications

###### Dose Escalation Trials

Analgesics. Four low- and moderate-risk of bias RCTs evaluated the efficacy of escalating doses of dexamethasone on post-tonsillectomy analgesia requirements.^57, 78, 92, 113^ Doses studied varied by trial, ranging from 0.05 to 1 mg/kg. Three of four trials of dexamethasone at escalating doses,^92^or escalating doses and placebo,^57^ or doses of dexamethasone compared with ondansetron or placebo,^113^ showed no differences in postoperative analgesic requirements by dose.^57, 92, 113^

In contrast, one placebo controlled dose-escalation trial showed that children who received dexamethasone required significantly less ibuprofen during 24 hour followup.^78^ Higher doses of dexamethasone did not significantly alter ibuprofen requirements.

Antiemetics. Two dexamethasone dose escalation trials assessed the postoperative need for antiemetic rescue.^57, 78^ Both studies showed significantly reduced use in groups treated with dexamethasone vs. placebo. One compared dexamethasone 0.05, 0.15, or 0.5 mg/kg vs. placebo after induction of anesthesia and found the need for rescue antiemetic to be significantly less in all steroid arms at 24 hour followup.^78^ A second study comparing IV dexamethasone at 0.15 mg/kg, 0.5 mg/kg vs. placebo reported that the use of alizapride was significantly lower in the steroid groups than placebo. In contrast, the use of tropisetron did not differ between arms.^57^

###### IV Dexamethasone Versus Placebo

Analgesics. Eight trials compared outcomes among children treated with IV dexamethasone vs. placebo.^50, 105, 109, 119, 126, 146-148^ This included four low ^50, 105, 119, 146^ and four moderate^109, 126, 147, 148^ risk of bias studies. Time of followup varied from assessment of PACU or surgical ward analgesic use,^50, 105, 119, 126, 146^ to 24 hours postoperatively,^109, 147, 148^ to 3 postoperative days.^126^The majority of studies found steroid treatment significantly reduced postoperative analgesic requirements vs. placebo or other agents such as ropivacaine.^50, 119, 146-148^ However, in three studies, no differences between those treated with dexamethasone or placebo were observed.^105, 109, 126^

Antiemetics. Two of five placebo-controlled studies showed reduced antiemetic use in children treated with dexamethasone.^105, 109, 119, 126, 146^ One trial comparing IV dexamethasone vs. placebo reported significantly lower 24 hour antiemetic requirement in the dexamethasone arm.^146^ Another trial that compared IV dexamethasone and placebo found no difference in antiemetic use in the PACU, but did show significantly reduced 24 hour and overall antiemetic rescue use in steroid arm.^119^

In contrast, three trials demonstrated no difference in need for antiemetic rescue between dexamethasone and placebo. For example, one trial found no difference in PACU or day surgical ward use of rescue metoclopramide or ondansetron between groups.^105^ A second trial comparing IV dexamethasone vs. placebo (both groups receiving peritonsillar infiltration of ropivacaine + clonidine) found no group differences in antiemetic rescue us in the first 4 hours postoperatively.^126^ A third trial found no statistical difference in PACU need for rescue antiemetic.^109^

###### Dexamethasone Versus Other Comparators

Analgesics. Four RCTs including one low^59^ and three moderate ^42, 46, 62^ risk of bias studies compared postoperative analgesic requirements between IV dexamethasone and other comparators. One found no difference in PACU or 24 hour followup doses of morphine or paracetamol between those treated with a single dose of IV dexamethasone vs. IV methylprednisolone.^59^ Another trial that compared IV dexamethasone vs. oral gabapentin, vs. the combination for 18 hours post-tonsillectomy found that the combined treatment group had fewer rescue medication (pethidine) requirements.^42^ Intravenous dexamethasone was compared with IV acetaminophen in another trial that observed no difference in meperidine usage during 24 hour followup. A fourth trial compared IV dexamethasone vs. IV ketamine vs. the combination vs. placebo and found the combined therapy group had no 24-hour postoperative analgesia requirements. Both the steroid and ketamine alone groups had lower analgesia needs than placebo.^62^

Antiemetics. One trial comparing IV dexamethasone vs. IV methylprednisolone observed no difference in percentage of patients receiving antiemetic medications in the PACU.^59^ Another study assessed effectiveness of IV dexamethasone + infiltrated ropivacaine vs. ropivacaine alone showed a significantly reduced rate of antiemetic use in the dexamethasone arm.^50^ Another RCT compared IV dexamethasone vs. ketamine vs. the combination, vs. placebo showed that all treatment groups had significantly lower antiemetic use (ondansetron) than placebo.^62^

###### IV Versus Infiltrated Dexamethasone

Analgesics. Two low-risk of bias RCTs evaluated the efficacy of IV versus peritonsillar infiltrated dexamethasone with or without concomitant levobupivacaine among children undergoing tonsillectomy.^39, 51^ Both RCTs found infiltrated dexamethasone reduced postoperative analgesic requirements significantly.

Antiemetics. A single RCT compared IV vs. infiltrated dexamethasone vs. placebo and found use of postoperative rescue anti-emetic medications was significantly lower in both steroid groups compared with placebo.^39^ Investigators observed no differences between dexamethasone groups.

###### Infiltrated Dexamethasone Versus Placebo

Analgesics. One moderate risk of bias trial compared dexamethasone infiltration, 0.25-percent levobupivacaine with epinephrine infiltration, and saline placebo.^45^ The total doses of rescue analgesia were significantly fewer for dexamethasone than other groups at all time points during the first postoperative week.

#### Antiemetics

##### Need for Rescue Medications

Analgesics. Five RCTs ( four low risk of bias^88, 118, 132, 133^ and one moderate^122^) evaluated the effect of perioperative antiemetic use on post-tonsillectomy analgesic requirements. All studies evaluated 5-HT receptor antagonists including ramosetron,^118, 133^ granisetron,^132, 133^ ondansetron,^88, 122^ and dolasetron.^122^ Antiemetic medications did not have any effect on pain control in any trial.

Two compared different 5-HT antagonists. In one trial, children were randomized to IV granisetron vs. ramosetron at the end of surgery and demonstrated no difference in analgesics administered 24 hour postoperatively.^133^Another compared IV ondansetron vs. dolasetron, vs. placebo and found opioid use in the PACU did not differ between arms.

Two compared 5-HT antagonists to antiemetic from other classes including droperidol,^132^ metoclopramide.^88, 132^ In one trial that assessed the effectiveness of IV granisetron vs. droperidol vs. metoclopramide found no difference in analgesic use during 24 hour postoperatively.^132^ Another RCT compared ondansetron vs. metoclopramide and also reported no difference in opioid use in the first 24 hours.^88^

One dose-escalating trial of ramosetron evaluated IV placebo vs. IV ramosetron at 3, 6, or 12 microgram/kg immediately after end of surgery.^118^ It found no difference in 24 hour post-tonsillectomy analgesia use between groups.

Postoperative antiemetics. Three studies including two low ^118, 136^ and one moderate ^122^ risk of bias RCTs assessed the effect of pre-emptive antiemetic use in reducing need for postoperative antiemetic rescue. Pre-emptive use of 5-HT receptor antagonists reduced the need for immediate postoperative anti-emetic use compared with placebo.

One study that compared IV tropisetron vs. placebo found significantly reduced 24 hour need for postoperative rescue-antiemetic use in the tropisetron arm (tropisetron 1/35, placebo 12/36, p<0.01). A second trial assessed preoperative IV ondansetron vs. dolasetron vs. placebo with each group pretreated with dexamethasone.^122^ Both 5-HT receptor antagonists had significantly less antiemetic rescue needs in PACU than placebo (ondansetron 4%, dolasetron 6%, placebo 22%, p<0.05). No child in any arm required antiemetic rescue in the 48 hours post-PACU. However, the overall antiemetic rescue requirement was significantly less overall for 5-HT receptor antagonists (ondansetron 4%, dolasetron 8%, placebo 24%, p<0.05). A third trial compared placebo vs. escalating ramosetron doses (3, 6, or 12 μg/kg).^118^ Requirement for antiemetic rescue in first 24 hours were 30 percent for placebo, 25 percent for 3 μg/kg (p=NS), while none required rescue in higher dose ramosetron arms. Similarly, during 24-48 hour followup, 25 percent of placebo and 25 percent of the 3 μg/kg-ramosetron arm required rescue antiemetic, while none in higher dose arms needed it.

#### Harms Associated With Perioperative Medications

##### PTH

Seventeen studies provided data on PTH associated with perioperative medications for pain.^40, 45, 47, 54, 57, 59, 78, 105, 106, 112, 117, 119, 148, 150, 161, 291^ PTH frequency overall ranged from 0 percent to 8.9 percent, with higher PTH frequency reported in patients who received anesthetics and steroids than those in other perioperative medications.

NSAIDs. Few studies of NSAIDs (6 studies,^40, 47, 106, 117, 150, 161^ 7 treatment arms) reported PTH (6 PTH in 277 treated children, 2.6%). Three cases of PTH were associated with diclofenac,^161^ two with ibuprofen,^47^ and one with ketorolac.^150^ Two studies (one of ketorolac and one of lornoxicam) reported no cases of PTH.^40, 117^

Steroids. Dexamethasone was the most commonly used steroid (9/10 studies).^45, 54, 57, 59, 78, 105, 112, 119, 148, 199^ The tenth study used methylprednisolone.^59^ Three steroid studies explicitly noted no PTH,^45, 59, 119^and three did not explicitly note number of bleeds but reported that no children receiving steroids had revisits or reoperation for PTH.^57, 105, 148^Another study did not explicitly note number of bleeds but reported that one child in the placebo and one in the steroid arm required reoperation.^112^

In one study comparing dexamethasone with placebo, 17 children in the steroid arm and 13 in the placebo arm had PTH (p=NR).^54^ Revisits and reoperations differed significantly between groups, with more revisits occurring in the placebo arm (3.2% vs. 1.9%, p<0.001) but more reoperations for hemostasis in the steroid arm (1.9% vs. 0.6%, p=0.002). In another RCT comparing 3 doses of dexamethasone (0.05, 0.15, or 0.5 mg/kg) with placebo, dexamethasone decreased the incidence of PONV but increased the risk of PTH.^78^ In total 22 children experienced 26 PTH episodes, which included any PTH, with or without evidence at clinical examination (placebo, n=2, dexamethasone 0.05 mg, n=6, dexamethasone 0.15 mg, n=2, and dexamethasone 0.5 mg, n=12, p=.003). The highest dose of dexamethasone was associated with the greatest PTH risk (adjusted RR compared with placebo=6.80; 95% CI: 1.77 to16.5. p=0.05). Eight children, all receiving steroids, required reoperation for hemostasis. In a third study comparing dexamethasone with placebo, two children in each arm had PTH requiring readmission but not reoperation for hemostasis.^199^

We combined nine studies comparing dexamethasone with placebo in a random effects meta-analysis to assess effects on risk of PTH. These studies comprised eight RCTs with low,^54, 57, 105, 112, 119^ moderate,^78, 148^ and high^188^ risk of bias and one nonrandomized trial with high risk of bias.^199^ We retained high risk of bias studies as an analysis indicated no systematic effects on the model. To account for the relatively high number of zero cases of PTH in the data, we used a zero-inflated binomial model. Sixteen percent of studies had no PTH; among the 84 percent that did, the odds of primary, secondary, and undefined (either primary or secondary) PTH and PTH-associated reoperation or readmission were each nominally ≥ 1, with wide 95% credible intervals (Table 40). Pooling the outcomes did not systematically affect the estimates. These wide intervals prohibit firm conclusions about the effects of dexamethasone on PTH. Table 41 lists the unadjusted frequency of PTH in these studies.

Table 40 Odds estimates in meta-analysis of PTH risk associated with perioperative dexamethasone compared with placebo

Outcome | Odds Ratio | 95% Credible Interval
Primary PTH | 1.9 | 0.03 to 6
Secondary PTH | 1.3 | 0.04 to 3.3
Undefined PTH | 2.1 | 0.9 to 3.7
PTH-associated revisit or readmission | 1.0 | 0.1 to 2.2
PTH-associated reoperation | 3.1 | 0.3 to 7.8

Table 41 Unadjusted PTH-related outcomes in study arms evaluating perioperative medications for pain

Drug Class (n arms) | Total N | Total PTH (%) | Total Primary PTH (%) | Total Secondary PTH (%) | Total Other/Undefined PTH (%) | Total Non-operative Readmission or Revisit for PTH (%) | Total Re-operation for PTH (%)
All arms | 1839 | 69 (3.8) | 4 (0.7) | 3 (0.66) | 61 (4.3) | 13 (1.4) | 14 (1.2)
Steroids (14) | 811 | 38 (4.7) | 2 (0.61) | 0 (0) | 36 (5.3) | 4 (0.84) | 11 (1.8)
Placebo (12) | 672 | 21 (3.3) | 2 (0.89) | 3 (1.8) | 16 (3.6) | 9 (2.1) | 2 (0.43)
NSAIDs (7) | 227 | 6 (2.6) | NR | NR | 5 (2.96) | 0 (0) | 1 (0.93)
Anesthetics (2) | 45 | 4 (8.9) | 0 (0) | 0 (0) | 4 (8.9) | 0 (0) | 0 (0)
Non-NSAID Analgesics (3) | 84 | 0 (0) | NR | 0 (0) | 0 (0) | NR | NR

Note: Percentages for primary and secondary PTH, readmissions/revisits, and reoperations reflect the number of each instance of bleeding or reencounter divided by the total number of patients in the studies reporting such data, and not in the total number of participants across all studies in a given row.

Other medications. Among arms addressing anesthetics (reported in two studies^45, 161^), four cases of PTH occurred with bupivacaine in one study,^161^ and none with levobupivacaine.^45^No PTH was reported with non-NSAID analgesics (propacetamol, fentanyl) in the two studies addressing these agents.^117, 150^

##### Concordance With Case Series and Database Studies

Four case series or database studies reported PTH associated with perioperative medications.^230, 234-236, 271^ One study evaluated differences in PTH requiring reoperation among children (≤ age 15) who had (n=1680) and had not (n=30254) received perioperative steroids (intravenous dexamethasone or hydrocortisone).^230^Most children had obstructive symptoms (over 65% in each arm), and 20 children in the steroid arm (1.2%) and 140 control children (0.5) had PTH requiring reoperation (p<0.001). Steroid use was associated with an increased rate of reoperation in children but not in adults in this study (OR for children=2.50, 95% CI: 1.47 to 4.23, p=0.001). Age was also noted as a risk factor in children (OR=1.10, 95% CI: 1.04 to 1.17, p<0.001) but the direction of effect was not clearly reported. Female children were also less likely to require reoperation than male (OR=0.73, 95%CI: 0.54 to 1.00, p=0.05).^230^

Another study evaluating adherence to 2011 AAO-HNSF guideline recommendations related to perioperative dexamethasone and antibiotic use also reported PTH associated with these medications.^234^ Out of all 15950 children (1-18 years of age) included in analyses, 432 experienced PTH (2.7%). PTH occurred in 92 of 7432 children in the pre-guideline era (1.2%) and in 229 of 8518 children after guidelines were issued (2.7%). Differences between physicians or hospitals that did or did not use these medications perioperatively, either before or after the publication of guidelines, were not significant.

Another study assessed how well hospitals adhered to evidence-based process measures including use of perioperative dexamethasone and antibiotics using data from the Pediatric Health Information System database and reported a significantly greater risk of PTH-associated revisits in children who received dexamethasone (3.11%, 95% CI: 2.99% to 3.23%) compared with those who did not (2.71% , 95% CI: 2.50% to 2.91%; standardized difference=0.40%, 95% CI: 0.13% to 0.67%, p=0.003). A final case series evaluated PTH after tonsillectomy with perioperative ibuprofen and reported 98 readmissions for PTH among 2697 children (3.6%).^271^ Fifty-eight children (2.2%) required reoperation for hemostasis.

###### Non-PTH Revisits

Few studies evaluating perioperative agents reported any revisits for non-PTH indications^39, 52, 112, 119, 121, 148^ (Table 42); in 8 of 11 study arms, no revisits or readmissions occurred. Higher, though still low, frequency of revisits typically occurred with combination agents such as dexamethasone plus antiemetics^122^ or in placebo arms.^112, 122, 148^ In one study that compared perioperative IV dexamethasone with placebo, four children in the placebo arm (11%) were readmitted for dysphagia and throat pain compared with none in the dexamethasone arm (p=NR).^148^

Table 42 Unadjusted revisits or readmissions for pain, dehydration, and PONV reported in comparative study arms addressing perioperative agents

Drug Class (N arms) | Total Arm N | N Pain Revisits/Readmissions (%) | N Dehydration Revisits/Readmissions (%) | N PONV Revisits/Readmissions (%)
All arms (11) | 542 | 4 (1.1) | 1 (0.33) | 1 (0.26)
Steroids (5) | 279 | 0 | 1 (1.6) | 0
NSAIDs (1) | 20 | 0 | 0 | 0
Anesthetic (1) | 80 | 0 | 0 | 0
Placebo (4) | 163 | 4 (6.9) | 0 | 1 (1.4)

Note: Percentages for readmissions/revisits reflect the number of each instance of reencounter divided by the total number of patients in the studies reporting such data, and not in the total number of participants across all studies in a given row.

N = number; NSAID=nonsteroidal anti-inflammatory drug; PONV = postoperative nausea and vomiting

## Key Question 6 Effectiveness of Postoperative Medications To Reduce Pain-Related Outcomes After Tonsillectomy

### Key Points

- Few studies of postoperative medications addressed the same intervention and outcomes, limiting our ability to make conclusions about this body of literature.
- In studies of postoperative NSAIDs, we found a low frequency of PTH. Our confidence in this estimate is low (low strength of evidence).
- We could not make conclusions about the effects of postoperative analgesics on need for rescue medications; return to normal diet or activity; or PTH (insufficient strength of evidence).
- In studies of postoperative steroids, we found no difference in effects on return to normal diet or activity between steroids and placebo. Our confidence in this conclusion is low (low strength of evidence).
- In studies of postoperative steroids, we found no difference in effects on bleeding between steroids and placebo or no treatment. Our confidence in this conclusion is low (low strength of evidence).

### Overview of the Literature

Of 13 studies addressing postoperative medications for pain-related outcomes identified, 11 were RCTs,^38, 41, 49, 55, 60, 115, 137, 138, 155, 159, 190^ and two were nonrandomized trials^194, 202^ (Table 43). Study country of origin included New Zealand,^49, 60^ Canada,^38, 155^ Denmark,^137, 138, 190^ Serbia,^115^ Egypt,^159^ Pakistan,^202^ Jordan,^55^ and South Korea.^41^ Studies included a total of 2660 children ranging in age from 1 to 18 years.

Table 43 Overview of studies addressing postoperative medications for pain-related outcomes

Characteristic | RCTs | Nonrandomized Trials | Total Literature
Comparisons
Acetaminophen vs. Non-NSAID Analgesic or Acetaminophen | 4 | 0 | 4
Acetaminophen vs. NSAID | 2 | 1 | 3
Steroid vs. Placebo or No Steroid | 2 | 0 | 2
NSAID vs. Placebo | 1 | 0 | 1
Other^*^ | 2 | 1 | 3
Surgical Indication
Throat Infection | 1 | 0 | 1
OSDB + Throat Infection | 3 | 1 | 4
Unspecified | 7 | 1 | 8
Effectiveness Outcomes Frequently Reported
Rescue analgesic use | 5 | 1 | 6
Time to return to normal diet/activity | 5 | 1 | 6
Quality of life | 1 | 0 | 1
Risk of Bias
Low | 4 | 0 | 4
Moderate | 5 | 1 | 6
High | 2 | 1 | 3
Total N participants | 2200 | 440 | 2660

* Antibiotic vs. no antibiotic^55^ or antibiotic vs. antibiotic vs. placebo^202^ or benzydamine oral rise vs. other oral rinse^115^ N = Number; NSAID = Nonsteroidal Anti-Inflammatory Drug; OSDB = Obstructive Sleep-Disordered Breathing; RCT = Randomized Controlled Trial

Studies assessed three categories of postoperative medications: analgesics (n=9),^38, 49, 115, 137, 138, 155, 159, 190, 194^ steroids (n=2),^41, 60^ and antibiotics (n=2).^55, 202^ Specific analgesics considered included nonsteroidal anti-inflammatory drugs (NSAID),^38, 49, 138, 155, 159, 190, 194^ acetaminophen,^49, 138, 159, 190, 194^ morphine,^155^ benzydamine oral rinse plus ibuprofen,^115^ and metamizole.^194^ Two studies evaluated oral prednisolone^41, 60^ and two evaluated the effect of amoxicillin + clavulanic acid^55, 202^(one comparing it to cefaclor^202^) on postoperative outcomes.

Indication for tonsillectomy varied among studies. Most included a combination of patients with recurrent infection and OSDB (n=4).^41, 60, 155, 194^ One study enrolled children with recurrent tonsillitis,^55^ and several studies did not specify tonsillectomy indication(s) (n=8).^38, 49, 115, 137, 138, 159, 190, 202^ All but three trials^55, 137, 202^ had low^41, 49, 115, 155^ or moderate risk of bias,^38, 60, 138, 159, 190, 194^ and were included in further analyses. Major sources of bias in these studies included use of unblinded outcome assessors and unclear methods for concealment of study group allocation.

### Detailed Analysis

Only four studies evaluating postoperative analgesic medications provided effectiveness outcomes, which included need for rescue medication^38, 49, 159^ and return to normal diet.^155, 159^ Four studies reported postoperative PTH or harms outcomes, but no effectiveness data.^115, 138, 190, 194^

#### Analgesics

##### Pain-Related Outcomes

Studies investigating the need for postoperative rescue medication after tonsillectomy considered different treatment comparisons. One RCT (moderate risk of bias) randomized 282 children to celecoxib given preoperatively (6mg/kg) and twice daily (3mg/kg) postoperatively for 5 doses or placebo.^38^ Children who received celecoxib had lower mean consumption of acetaminophen on postoperative days (POD) 0-2 (celecoxib 78 vs. placebo 97 mg/kg, p=0.03), but no difference in mean morphine consumption (celecoxib 0.56 vs. placebo 0.70 mg/kg, p=NS).

Another low risk of bias trial randomized 152 children who underwent tonsillectomy to acetaminophen + ibuprofen, acetaminophen alone, or ibuprofen alone (60mg per 5 mL suspension) for postoperative pain control.^49^ Groups did not differ in the use of rescue analgesia in the recovery room, but after discharge from the recovery room during postoperative days 0-2, fewer patients required rescue analgesia (i.e., acetaminophen + ibuprofen) in the combination group than in the other arms (0% combined, 16% acetaminophen, 15% ibuprofen). A third study (moderate risk of bias) compared postoperative treatment with acetaminophen or diclofenac (dose NR) to be administered every 8 hours or as needed for pain.^159^ Mean analgesic use did not differ between groups in the first 24 hours.

All trials assessing analgesia outcomes had short-term followup ranging from 24 to 48 hours postoperatively and assessed a heterogeneous group of medications. Available data are conflicting as to whether postoperative use of NSAIDs (celecoxib, ibuprofen, diclofenac) decreases rescue pain medication requirement in the first 24-48 hours among children post-tonsillectomy. Longer-term effectiveness of these medications cannot be gleaned from currently available data (Table 44).

Table 44 Need for rescue medications reported in studies of postoperative medications

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Need for Rescue Medications
Merry 2013^49^ RCT Low ROB | G1: Acetaminophen 120 mg+ ibuprofen 60 mg/5mL suspension (52) G2: Acetaminophen 120 mg/5 mL suspension (49) G3: Ibuprofen 60 mg/5 mL suspension (51) | N requiring rescue analgesia, (%) In PACU G1: 1 (2) G2: 1 (2) G3: 1 (2) Post-PACU discharge G1: 0 G2: 8 (16) G3: 8 (15)
Monem 2005^159^ RCT Moderate ROB | G1: Acetaminophen (32) G2: Diclofenac (34) | N requiring additional analgesia, (%) G1: 3 (9) G2: 2 (6) No significant group differences in total analgesic use in first postoperative day or in at-home antiemetic use
Murto 2015^38^ RCT Moderate ROB | G1: Celecoxib (141) G2: Placebo (141) | Analgesic consumption; - No group differences in opioid consumption in PACU; - No group differences in cumulative co-analgesic consumption in postoperative days 0-7; - No group differences in N morphine-free patients; Postoperative day 0-2 acetaminophen consumption, mean G1: 78 mg/kg-^1^ (95% CI: 68 to 89) G2: 97 mg/kg-^1^ (95% CI: 85 to 109) G1 vs. G2: p=0.03 Postoperative day 0-2 morphine consumption G1: 0.56 mg/kg^-1^ (95% CI: 0.47 to 0.65) G2: 0.70 mg/kg^-1^ (95% CI: 0.59 to 0.81) G1 vs. G2: p=NS

CI=Confidence Interval; G=Group; kg = Kilogram; mg = Milligram; N=Number; NR=Not Reported; NS=Not Significant; PACU=Post-Anesthesia Care Unit; RCT=Randomized Controlled Trial; ROB=Risk of Bias

##### Return to Normal Diet

Return to normal diet was evaluated and defined differently in two studies (Table 45). In one RCT with low risk of bias, 91 children (1-10 years of age) with OSDB with or without recurrent tonsillitis undergoing tonsillectomy were randomized to postoperative acetaminophen + ibuprofen or acetaminophen + morphine.^155^ Both groups used pain medications for a mean of 4 postoperative days (ibuprofen 4.64 vs. morphine 4.04 days). No difference was observed in days to return to preoperative diet between arms (morphine 7.31 vs. ibuprofen 7.17 days, p=0.89). Another moderate risk of bias trial randomized children undergoing tonsillectomy to postoperative acetaminophen or diclofenac.^159^ Children in the acetaminophen group had faster return to normal oral intake compared with those getting diclofenac, and this reached significance on the first 5 postoperative days. Altogether, current data do not consistently indicate a differential return to preoperative/normal diet among children treated with NSAIDs (i.e., ibuprofen, diclofenac), morphine, or acetaminophen.

Table 45 Return to normal diet or activity in studies of postoperative medications

Author, Year Study Type Groups (N) Risk of Bias | Comparison Groups (N) | Time to Return to Normal Diet/Activity
Kelly 2015^155^ RCT Low ROB | G1: Acetaminophen + morphine (46) G2: Acetaminophen + ibuprofen (38) | N days to return to preoperative diet, mean±SD G1: 7.31±3.82 G2: 7.17±5.23 G1 vs. G2: p=NS
Monem 2005^159^ RCT Moderate ROB | G1: Acetaminophen (32) G2: Diclofenac (34) | Significantly greater percent of normal diet consumed in G1 vs. G2, p < 0.05

G = Group; NR = Not Reported; NS = Not Significant; RCT = Randomized Controlled Trial; ROB = Risk of Bias; SD = Standard Deviation

#### Steroids

##### Return to Normal Diet

Two RCTs evaluated the effectiveness of postoperative prednisolone in children undergoing tonsillectomy (Table 46).^41, 60^ In one trial (low risk of bias) 138 children (≥4 years of age) undergoing elective tonsillectomy for tonsillitis or hypertrophy were randomized to oral prednisolone (0.25 mg/kg/day) for seven postoperative days or no prednisolone.^41^ No difference in type of diet (i.e., none, fluid, soft, normal) was seen between arms on POD 1 (p=0.30); however, significantly more children had normal diet (46% vs. 25%, p < 0.001) and a higher activity level in the prednisolone arm on postoperative day 7 (p=0.004). No difference between groups in either diet or activity was present on postoperative day 14. Although not reported specifically for children, outcomes did differ based on tonsillectomy indication. In a stratified post hoc analysis, those undergoing tonsillectomy for OSDB were significantly more likely to have normal diet and improved activity by postoperative day 7 if treated postoperatively with prednisolone compared with controls. These associations were not observed in patients whose indication was recurrent tonsillitis.

Table 46 Time to return to normal diet or activity in studies addressing postoperative steroids

Author, Year Study Type Risk of Bias | Comparison Groups (N) | Time to Return to Normal Diet/Activity
Park 2015^41^ RCT Low ROB | G1: Prednisolone 0.25 mg/kg/day (69) G2: No prednisolone (69) | Normal diet at day 14 postoperative, N (%) G1: 64 (93) G2: 65 (94) G1 vs. G2: p=NS Normal activity at day 14, N (%) G1: 69 (100) G2: 66 (96) G1 vs. G2: p=NS
Macassey 2012^60^ RCT Moderate ROB | G1: Prednisolone (106) G2: Placebo (107) | Time to normal diet G1 vs. G2: p=NS Time to normal activity G1 vs. G2: p=NS

G=group; NR=not reported; NS=not significant; RCT=randomized controlled trial; ROB=risk of bias

A second trial (low risk of bias) randomized 215 children to a 5-day postoperative course of prednisolone (0.5 mg/kg up to 20 mg/day) or placebo.^60^ Time to return to preoperative diet or activity did not differ between groups (p values > 0.2). Overall, data from these studies provide inconsistent evidence that postoperative treatment with oral prednisolone decreases time to return to preoperative/normal diet or activity level.

#### Harms Associated With Postoperative Medications

##### PTH

Six studies of low or moderate risk of bias addressed postoperative medications for pain and reported PTH-related outcomes.^38, 41, 60, 115, 138, 194^ PTH occurred in less than 10 percent of children overall (Table 47). In steroid studies 8.1 percent of children had PTH overall, but numbers of PTH in steroid and placebo arms in the two studies addressing that comparison were similar (n^PTH in steroid arms^=13, n ^placebo/no treatment arms^=15).^41, 60^ Frequency of PTH in studies comparing NSAIDs (celecoxib, ibuprofen) to placebo or other medications were also similar (n^PTH in NSAID arms^=14, n^comparison arms^=16).^38, 194^ Frequency of PTH were similar among studies of non-NSAID analgesics (2%-4%).^115, 138, 194^ One NSAID study did not specify adverse effects assessed but noted that no events occurred in children receiving either diclofenac or placebo.^190^

Table 47 Unadjusted PTH-related outcomes in study arms evaluating postoperative medications for pain

Drug Class (n arms) | Total N | Total PTH (%) | Total Primary PTH (%) | Total Secondary PTH (%) | Total Other/Undefined PTH (%) | Total Nonoperative Readmission or Revisit for PTH (%) | Total Reoperation for PTH (%)
All arms (13) | 2063 | 97 (4.7) | 12 (1.4) | 15 (1.8) | 70 (5.7) | 18 (3.8) | 17 (1.2)
Non-NSAID analgesics (4) | 772 | 23 (3.0) | 7 (1.7) | 2 (0.49) | 14 (3.9) | NR | 3 (0.47)
NSAIDs (3) | 679 | 32 (4.7) | 5 (1.2) | 13 (3.1) | 14 (5.5) | 8 (5.7) | 12 (1.8)
No treatment/Placebo (3) | 312 | 23 (7.4) | NR | NR | 23 (7.4) | 9 (3.7) | 2 (1.4)
Steroids (2) | 160 | 13 (8.1) | NR | NR | 13 (8.1) | 1 (1.1) | NR
Other (1) | 140 | 6 (4.3) | NR | NR | 6 (4.3) | NR | NR

Note: Percentages for primary and secondary PTH, readmissions/revisits, and reoperations reflect the number of each instance of bleeding or reencounter divided by the total number of patients in the studies reporting such data, and not in the total number of participants across all studies in a given row.

N = Number; NR = Not Reported; NSAID = Nonsteroidal Anti-Inflammatory Drug; PTH = Post-Tonsillectomy Hemorrhage