# References

1 Boss EF, Marsteller JA, Simon AE. (2012). Outpatient tonsillectomy in children: demographic and geographic variation in the United States, 2006. J Pediatr.
2 Cullen KA, Hall MJ, Golosinskiy A. (2009). Ambulatory surgery in the United States, 2006. Natl Health Stat Report.
3 Parker NP, Walner DL. (2011). Trends in the indications for pediatric tonsillectomy or adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
4 Patel HH, Straight CE, Lehman EB, et al. (2014). Indications for tonsillectomy: a 10 year retrospective review. Int J Pediatr Otorhinolaryngol.
5 Wennberg J, Gittelsohn. (1973). Small area variations in health care delivery. Science.
6 Paradise JL, Bluestone CD, Bachman RZ, et al. (1984). Efficacy of tonsillectomy for recurrent throat infection in severely affected children. Results of parallel randomized and nonrandomized clinical trials. N Engl J Med.
7 Dooling KL, Shapiro DJ, Van Beneden C, et al. (2014). Overprescribing and inappropriate antibiotic selection for children with pharyngitis in the United States, 1997-2010. JAMA Pediatr.
8 Bathala S, Eccles R. (2013). A review on the mechanism of sore throat in tonsillitis. J Laryngol Otol.
9 Paradise JL, Bluestone CD, Colborn DK, et al. (2002). Tonsillectomy and adenotonsillectomy for recurrent throat infection in moderately affected children. Pediatrics.
10 Baugh RF, Archer SM, Mitchell RB, et al. (2011). Clinical practice guideline: tonsillectomy in children. Otolaryngol Head Neck Surg.
11 Paradise JL, Bluestone CD, Colborn DK, et al. (1999). Adenoidectomy and adenotonsillectomy for recurrent acute otitis media: parallel randomized clinical trials in children not previously treated with tympanostomy tubes. JAMA.
12 Park JG, Ramar K, Olson EJ. (2011). Updates on definition, consequences, and management of obstructive sleep apnea. Mayo Clin Proc.
13 Beebe DW. (2006). Neurobehavioral morbidity associated with disordered breathing during sleep in children: a comprehensive review. Sleep.
14 Teo DT, Mitchell RB. (2013). Systematic review of effects of adenotonsillectomy on cardiovascular parameters in children with obstructive sleep apnea. Otolaryngol Head Neck Surg.
15 Walz PC, Schroeder JW. (2013). Pediatric polysomnography for sleep-disordered breathing prior to tonsillectomy: a guideline review. Pediatr Ann.
16 Marcus CL, Rosen G, Ward SL, et al. (2006). Adherence to and effectiveness of positive airway pressure therapy in children with obstructive sleep apnea. Pediatrics.
17 Prashad PS, Marcus CL, Maggs J, et al. (2013). Investigating reasons for CPAP adherence in adolescents: a qualitative approach. J Clin Sleep Med.
18 Ramirez A, Khirani S, Aloui S, et al. (2013). Continuous positive airway pressure and noninvasive ventilation adherence in children. Sleep Med.
19 Jambhekar SK, Com G, Tang X, et al. (2013). Role of a respiratory therapist in improving adherence to positive airway pressure treatment in a pediatric sleep apnea clinic. Respir Care.
20 Beecroft J, Zanon S, Lukic D, et al. (2003). Oral continuous positive airway pressure for sleep apnea: effectiveness, patient preference, and adherence. Chest.
21 Edmonson MB, Eickhoff JC, Zhang C. (2015). A population-based study of acute care revisits following tonsillectomy. J Pediatr.
22 Gallagher TQ, Wilcox L, McGuire E, et al. (2010). Analyzing factors associated with major complications after adenotonsillectomy in 4776 patients: comparing three tonsillectomy techniques. Otolaryngol Head Neck Surg.
23 Dhiwakar M, Clement WA, Supriya M, et al. (2012). Antibiotics to reduce post-tonsillectomy morbidity. Cochrane Database Syst Rev.
24 Shargorodsky J, Hartnick CJ, Lee GS. (2012). Dexamethasone and postoperative bleeding after tonsillectomy and adenotonsillectomy in children: A meta-analysis of prospective studies. Laryngoscope.
25 Bellis JR, Pirmohamed M, Nunn AJ, et al. (2014). Dexamethasone and haemorrhage risk in paediatric tonsillectomy: a systematic review and meta-analysis. Br J Anaesth.
26 Geva A, Brigger MT. (2011). Dexamethasone and tonsillectomy bleeding: a meta-analysis. Otolaryngol Head Neck Surg.
27 Steward David L, Grisel J, Meinzen-Derr J. (2011). Steroids for improving recovery following tonsillectomy in children. Cochrane Database of Systematic Reviews.
28 Steward DL, Welge JA, Myer CM. (2001). Do steroids reduce morbidity of tonsillectomy? Meta-analysis of randomized trials. Laryngoscope.
29 Plante J, Turgeon AF, Zarychanski R, et al. (2012). Effect of systemic steroids on post-tonsillectomy bleeding and reinterventions: systematic review and meta-analysis of randomised controlled trials. Bmj.
30 Lewis Sharon R, Nicholson A, Cardwell Mary E, et al. (2013). Nonsteroidal anti-inflammatory drugs and perioperative bleeding in paediatric tonsillectomy. Cochrane Database of Systematic Reviews.
31 Riggin L, Ramakrishna J, Sommer DD, et al. (2013). A 2013 updated systematic review & meta-analysis of 36 randomized controlled trials; no apparent effects of non steroidal anti-inflammatory agents on the risk of bleeding after tonsillectomy. Clin Otolaryngol.
32 Chan DK, Parikh SR. (2014). Perioperative ketorolac increases post-tonsillectomy hemorrhage in adults but not children. Laryngoscope.
33 Agency for Healthcare Research and Quality. (2014). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
34 Treadwell JR, Singh S, Talati R, et al. (2012). A framework for best evidence approaches can improve the transparency of systematic reviews. J Clin Epidemiol.
35 Viswanathan M, Ansari MT, Berkman ND, et al. (2008). Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
36 McMaster Evidence Based Practice Centre. (2008). McMaster Quality Assessment Scale of Harms (McHarm) for primary studies.
37 Berkman ND, Lohr KN, Ansari MT, et al. (2014). Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol.
38 Murto K, Lamontagne C, McFaul C, et al. (2015). Celecoxib pharmacogenetics and pediatric adenotonsillectomy: a double-blinded randomized controlled study. Can J Anaesth.
39 Gao W, Zhang QR, Jiang L, et al. (2015). Comparison of local and intravenous dexamethasone for postoperative pain and recovery after tonsillectomy. Otolaryngol Head Neck Surg.
40 Abdel-Ghaffar HS, Abdel-Azeem HG, Roushdy MM. (2015). Safety and efficacy of pre-incisional peritonsillar lornoxicam in paediatric post-tonsillectomy pain: a prospective double-blind, placebo-controlled, split-body clinical study. Clin Otolaryngol.
41 Park SK, Kim J, Kim JM, et al. (2015). Effects of oral prednisolone on recovery after tonsillectomy. Laryngoscope.
42 Amin SM. (2014). Evaluation of gabapentin and dexamethasone alone or in combination for pain control after adenotonsillectomy in children. Saudi J Anaesth.
43 D'Eredita R. (2014). Molecular resonance tonsillectomy in children: comparative study over standard techniques in an 11-year study. Otolaryngol Head Neck Surg.
44 Sudarsan SS, Paramasivan VK, Arumugam SV, et al. (2014). Comparison of treatment modalities in syndromic children with obstructive sleep apnea--a randomized cohort study. Int J Pediatr Otorhinolaryngol.
45 Aysenur D, Mine C, Ozgur Y, et al. (2014). Pre-emptive peritonsillar dexamethasone vs. levobupivacaine infiltration for relief of post-adenotonsillectomy pain in children: a controlled clinical study. Int J Pediatr Otorhinolaryngol.
46 Faiz SH, Rahimzadeh P, Alebouyeh MR, et al. (2013). A Randomized Controlled Trial on Analgesic Effects of Intravenous Acetaminophen versus Dexamethasone after Pediatric Tonsillectomy. Iran Red Crescent Med J.
47 Moss JR, Watcha MF, Bendel LP, et al. (2014). A multicenter, randomized, double-blind placebo-controlled, single dose trial of the safety and efficacy of intravenous ibuprofen for treatment of pain in pediatric patients undergoing tonsillectomy. Paediatr Anaesth.
48 Aydin S, Taskin U, Altas B, et al. (2014). Post-tonsillectomy morbidities: randomised, prospective controlled clinical trial of cold dissection versus thermal welding tonsillectomy. J Laryngol Otol.
49 Merry AF, Edwards KE, Ahmad Z, et al. (2013). Randomized comparison between the combination of acetaminophen and ibuprofen and each constituent alone for analgesia following tonsillectomy in children. Can J Anaesth.
50 Ju NY, Cui GX, Gao W. (2013). Ropivacaine plus dexamethasone infiltration reduces postoperative pain after tonsillectomy and adenoidectomy. Int J Pediatr Otorhinolaryngol.
51 Basuni AS, Ezz HA, Albirmawy OA. (2013). Preoperative peritonsillar infiltration of dexamethasone and levobupivacaine reduces pediatric post-tonsillectomy pain: a double-blind prospective randomized clinical trial. J Anesth.
52 El-Fattah AM, Ramzy E. (2013). Pre-emptive triple analgesia protocol for tonsillectomy pain control in children: double-blind, randomised, controlled, clinical trial. J Laryngol Otol.
53 Chaidas KS, Kaditis AG, Papadakis CE, et al. (2013). Tonsilloplasty versus tonsillectomy in children with sleep-disordered breathing: short- and long-term outcomes. Laryngoscope.
54 Gallagher TQ, Hill C, Ojha S, et al. (2012). Perioperative dexamethasone administration and risk of bleeding following tonsillectomy in children: a randomized controlled trial. JAMA.
55 Al-Layla A, Mahafza TM. (2013). Antibiotics do not reduce post-tonsillectomy morbidity in children. Eur Arch Otorhinolaryngol.
56 Frampton SJ, Ward MJ, Sunkaraneni VS, et al. (2012). Guillotine versus dissection tonsillectomy: randomised, controlled trial. J Laryngol Otol.
57 Hermans V, De Pooter F, De Groote F, et al. (2012). Effect of dexamethasone on nausea, vomiting, and pain in paediatric tonsillectomy. Br J Anaesth.
58 Havel M, Sroka R, Englert E, et al. (2012). Intraindividual comparison of 1,470 nm diode laser versus carbon dioxide laser for tonsillotomy: a prospective, randomized, double blind, controlled feasibility trial. Lasers Surg Med.
59 Aouad MT, Nasr VG, Yazbeck-Karam VG, et al. (2012). A comparison between dexamethasone and methylprednisolone for vomiting prophylaxis after tonsillectomy in inpatient children: a randomized trial. Anesth Analg.
60 Macassey E, Dawes P, Taylor B, et al. (2012). The effect of a postoperative course of oral prednisone on postoperative morbidity following childhood tonsillectomy. Otolaryngol Head Neck Surg.
61 Yilmaz M, Duzlu M, Catli T, et al. (2012). Thermal welding versus cold knife tonsillectomy: a prospective randomized study. Kaohsiung J Med Sci.
62 Safavi M, Honarmand A, Habibabady MR, et al. (2012). Assessing intravenous ketamine and intravenous dexamethasone separately and in combination for early oral intake, vomiting and postoperative pain relief in children following tonsillectomy. Med Arh.
63 Paramasivan VK, Arumugam SV, Kameswaran M. (2012). Randomised comparative study of adenotonsillectomy by conventional and coblation method for children with obstructive sleep apnoea. Int J Pediatr Otorhinolaryngol.
64 Chang H, Hah JH. (2012). Comparison of post-tonsillectomy pain with two different types of bipolar forceps: low temperature quantum molecular resonance device versus high temperature conventional electrocautery. Acta Otolaryngol.
65 Kemal O. (2012). Harmonic scalpel versus bipolar tonsillectomy: a double-blind clinical trial. Eur Arch Otorhinolaryngol.
66 Parker NP, Walner DL. (2011). Post-operative pain following coblation or monopolar electrocautery tonsillectomy in children: a prospective, single-blinded, randomised comparison. Clin Otolaryngol.
67 Babademez MA, Yurekli MF, Acar B, et al. (2011). Comparison of radiofrequency ablation, laser and coblator techniques in reduction of tonsil size. Acta Otolaryngol.
68 Jones DT, Kenna MA, Guidi J, et al. (2011). Comparison of postoperative pain in pediatric patients undergoing coblation tonsillectomy versus cautery tonsillectomy. Otolaryngol Head Neck Surg.
69 D'Eredita R. (2010). Tonsillectomy in children: a five-factor analysis among three techniques--reporting upon clinical results, anesthesia time, surgery time, bleeding, and cost. Laryngoscope.
70 Ferreira RF, Serapiao CJ, Ferreira AP, et al. (2010). Cost and outcomes after cold and mixed adenotonsillectomy in children. Laryngoscope.
71 Pruegsanusak K, Wongsuwan K, Wongkittithawon J. (2010). A randomized controlled trial for perioperative morbidity in microdebrider versus cold instrument dissection tonsillectomy. J Med Assoc Thai.
72 Rhendra Hardy MZ, Zayuah MS, Baharudin A, et al. (2010). The effects of topical viscous lignocaine 2% versus per-rectal diclofenac in early post-tonsillectomy pain in children. Int J Pediatr Otorhinolaryngol.
73 Karaman M, Ilhan AE, Dereci G, et al. (2009). Determination of optimum dosage of intraoperative single dose dexamethasone in pediatric tonsillectomy and adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
74 D'Eredita R, Bozzola L. (2009). Molecular resonance vs. coblation tonsillectomy in children. Laryngoscope.
75 Parker D, Howe L, Unsworth V, et al. (2009). A randomised controlled trial to compare postoperative pain in children undergoing tonsillectomy using cold steel dissection with bipolar haemostasis versus coblation technique. Clin Otolaryngol.
76 Erdem AF, Yoruk O, Silbir F, et al. (2009). Tropisetron plus subhypnotic propofol infusion is more effective than tropisetron alone for the prevention of vomiting in children after tonsillectomy. Anaesth Intensive Care.
77 Wilson YL, Merer DM, Moscatello AL. (2009). Comparison of three common tonsillectomy techniques: a prospective randomized, double-blinded clinical study. Laryngoscope.
78 Czarnetzki C, Elia N, Lysakowski C, et al. (2008). Dexamethasone and risk of nausea and vomiting and postoperative bleeding after tonsillectomy in children: a randomized trial. JAMA.
79 Hesham A. (2009). Bipolar diathermy versus cold dissection in paediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
80 Sezen OS, Kaytanci H, Kubilay U, et al. (2008). Comparison between tonsillectomy with thermal welding and the conventional 'cold' tonsillectomy technique. ANZ J Surg.
81 Lee SW, Jeon SS, Lee JD, et al. (2008). A comparison of postoperative pain and complications in tonsillectomy using BiClamp forceps and electrocautery tonsillectomy. Otolaryngol Head Neck Surg.
82 Chimona T, Proimos E, Mamoulakis C, et al. (2008). Multiparametric comparison of cold knife tonsillectomy, radiofrequency excision and thermal welding tonsillectomy in children. Int J Pediatr Otorhinolaryngol.
83 D'Agostino R, Tarantino V, Calevo MG. (2008). Blunt dissection versus electronic molecular resonance bipolar dissection for tonsillectomy: operative time and intraoperative and postoperative bleeding and pain. Int J Pediatr Otorhinolaryngol.
84 Korkmaz O, Bektas D, Cobanoglu B, et al. (2008). Partial tonsillectomy with scalpel in children with obstructive tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
85 Chang KW. (2008). Intracapsular versus subcapsular coblation tonsillectomy. Otolaryngol Head Neck Surg.
86 Skoulakis CE, Papadakis CE, Manios AG, et al. (2007). Tonsilloplasty in children with obstructive symptoms. J Otolaryngol.
87 Bukhari MA, Al-Ammar AY. (2007). Monopolar electrodissection versus cold dissection tonsillectomy among children. Saudi Med J.
88 Bolton CM, Myles PS, Carlin JB, et al. (2007). Randomized, double-blind study comparing the efficacy of moderate-dose metoclopramide and ondansetron for the prophylactic control of postoperative vomiting in children after tonsillectomy. Br J Anaesth.
89 Mitic S, Tvinnereim M, Lie E, et al. (2007). A pilot randomized controlled trial of coblation tonsillectomy versus dissection tonsillectomy with bipolar diathermy haemostasis. Clin Otolaryngol.
90 Park A, Proctor MD, Alder S, et al. (2007). Subtotal bipolar tonsillectomy does not decrease postoperative pain compared to total monopolar tonsillectomy. Int J Pediatr Otorhinolaryngol.
91 Hegazy HM, Albirmawy OA, Kaka AH, et al. (2008). Pilot comparison between potassium titanyl phosphate laser and bipolar radiofrequency in paediatric tonsillectomy. J Laryngol Otol.
92 Kim MS, Cote CJ, Cristoloveanu C, et al. (2007). There is no dose-escalation response to dexamethasone (0.0625-1.0 mg/kg) in pediatric tonsillectomy or adenotonsillectomy patients for preventing vomiting, reducing pain, shortening time to first liquid intake, or the incidence of voice change. Anesth Analg.
93 Shapiro NL, Bhattacharyya N. (2007). Cold dissection versus coblation-assisted adenotonsillectomy in children. Laryngoscope.
94 Antila H, Manner T, Kuurila K, et al. (2006). Ketoprofen and tramadol for analgesia during early recovery after tonsillectomy in children. Paediatr Anaesth.
95 Coticchia JM, Yun RD, Nelson L, et al. (2006). Temperature-controlled radiofrequency treatment of tonsillar hypertrophy for reduction of upper airway obstruction in pediatric patients. Arch Otolaryngol Head Neck Surg.
96 Leaper M, Mahadevan M, Vokes D, et al. (2006). A prospective randomised single blinded study comparing harmonic scalpel tonsillectomy with bipolar tonsillectomy. Int J Pediatr Otorhinolaryngol.
97 Sobol SE, Wetmore RF, Marsh RR, et al. (2006). Postoperative recovery after microdebrider intracapsular or monopolar electrocautery tonsillectomy: a prospective, randomized, single-blinded study. Arch Otolaryngol Head Neck Surg.
98 Derkay CS, Darrow DH, Welch C, et al. (2006). Post-tonsillectomy morbidity and quality of life in pediatric patients with obstructive tonsils and adenoid: microdebrider vs electrocautery. Otolaryngol Head Neck Surg.
99 Parsons SP, Cordes SR, Comer B. (2006). Comparison of posttonsillectomy pain using the ultrasonic scalpel, coblator, and electrocautery. Otolaryngol Head Neck Surg.
100 Ragab SM. (2005). Bipolar radiofrequency dissection tonsillectomy: a prospective randomized trial. Otolaryngol Head Neck Surg.
101 Kutluhan A, Caksen H, Yurttas V, et al. (2005). The effectiveness of unilateral tonsillectomy in chronic adenotonsillar hypertrophy. Kulak Burun Bogaz Ihtis Derg.
102 Kamal SA, Basu S, Kapoor L, et al. (2006). Harmonic scalpel tonsillectomy: a prospective study. Eur Arch Otorhinolaryngol.
103 Oko MO, Ganly I, Loughran S, et al. (2005). A prospective randomized single-blind trial comparing ultrasonic scalpel tonsillectomy with tonsillectomy by blunt dissection in a pediatric age group. Otolaryngol Head Neck Surg.
104 Kirazli T, Bilgen C, Midilli R, et al. (2005). Bipolar electrodissection tonsillectomy in children. Eur Arch Otorhinolaryngol.
105 Kaan MN, Odabasi O, Gezer E, et al. (2006). The effect of preoperative dexamethasone on early oral intake, vomiting and pain after tonsillectomy. Int J Pediatr Otorhinolaryngol.
106 Kedek A, Derbent A, Uyar M, et al. (2005). Pre-emptive effects of ibuprofen syrup and lidocaine infiltration on post-operative analgesia in children undergoing adenotonsillectomy. J Int Med Res.
107 Chang KW. (2005). Randomized controlled trial of Coblation versus electrocautery tonsillectomy. Otolaryngol Head Neck Surg.
108 Collison PJ, Weiner R. (2004). Harmonic scalpel versus conventional tonsillectomy: a double-blind clinical trial. Ear Nose Throat J.
109 Samarkandi AH, Shaikh MA, Ahmad RA, et al. (2004). Use of dexamethasone to reduce postoperative vomiting and pain after pediatric tonsillectomy procedures. Saudi Med J.
110 Chan KH, Friedman NR, Allen GC, et al. (2004). Randomized, controlled, multisite study of intracapsular tonsillectomy using low-temperature plasma excision. Arch Otolaryngol Head Neck Surg.
111 D'Eredita R, Marsh RR. (2004). Contact diode laser tonsillectomy in children. Otolaryngol Head Neck Surg.
112 Hanasono MM, Lalakea ML, Mikulec AA, et al. (2004). Perioperative steroids in tonsillectomy using electrocautery and sharp dissection techniques. Arch Otolaryngol Head Neck Surg.
113 Celiker V, Celebi N, Canbay O, et al. (2004). Minimum effective dose of dexamethasone after tonsillectomy. Paediatr Anaesth.
114 Goldstein NA, Pugazhendhi V, Rao SM, et al. (2004). Clinical assessment of pediatric obstructive sleep apnea. Pediatrics.
115 Lalicevic S, Djordjevic I. (2004). Comparison of benzydamine hydrochloride and Salvia officinalis as an adjuvant local treatment to systemic nonsteroidal anti-inflammatory drug in controlling pain after tonsillectomy, adenoidectomy, or both: an open-label, single-blind, randomized clinical trial. Curr Ther Res Clin Exp.
116 Stoker KE, Don DM, Kang DR, et al. (2004). Pediatric total tonsillectomy using coblation compared to conventional electrosurgery: a prospective, controlled single-blind study. Otolaryngol Head Neck Surg.
117 Keidan I, Zaslansky R, Eviatar E, et al. (2004). Intraoperative ketorolac is an effective substitute for fentanyl in children undergoing outpatient adenotonsillectomy. Paediatr Anaesth.
118 Fujii Y, Tanaka H. (2003). Results of a prospective, randomized, double-blind, placebo-controlled, dose-ranging trial to determine the effective dose of ramosetron for the prevention of vomiting after tonsillectomy in children. Clin Ther.
119 Elhakim M, Ali NM, Rashed I, et al. (2003). Dexamethasone reduces postoperative vomiting and pain after pediatric tonsillectomy. Can J Anaesth.
120 Willging JP, Wiatrak BJ. (2003). Harmonic scalpel tonsillectomy in children: a randomized prospective study. Otolaryngol Head Neck Surg.
121 Oztekin S, Hepaguslar H, Kar AA, et al. (2002). Preemptive diclofenac reduces morphine use after remifentanil-based anaesthesia for tonsillectomy. Paediatr Anaesth.
122 Sukhani R, Pappas AL, Lurie J, et al. (2002). Ondansetron and dolasetron provide equivalent postoperative vomiting control after ambulatory tonsillectomy in dexamethasone-pretreated children. Anesth Analg.
123 Kothari P, Patel S, Brown P, et al. (2002). A prospective double-blind randomized controlled trial comparing the suitability of KTP laser tonsillectomy with conventional dissection tonsillectomy for day case surgery. Clin Otolaryngol Allied Sci.
124 Shah UK, Galinkin J, Chiavacci R, et al. (2002). Tonsillectomy by means of plasma-mediated ablation: prospective, randomized, blinded comparison with monopolar electrosurgery. Arch Otolaryngol Head Neck Surg.
125 Raut VV, Bhat N, Sinnathuray AR, et al. (2002). Bipolar scissors versus cold dissection for pediatric tonsillectomy--a prospective, randomized pilot study. Int J Pediatr Otorhinolaryngol.
126 Giannoni C, White S, Enneking FK. (2002). Does dexamethasone with preemptive analgesia improve pediatric tonsillectomy pain?. Otolaryngol Head Neck Surg.
127 Young C, MacRae J. (2001). Tonsillectomy. A comparative study of dissection/snare vs suction-cautery. Can Oper Room Nurs J.
128 Kokki H, Salonen A. (2002). Comparison of pre- and postoperative administration of ketoprofen for analgesia after tonsillectomy in children. Paediatr Anaesth.
129 Densert O, Desai H, Eliasson A, et al. (2001). Tonsillotomy in children with tonsillar hypertrophy. Acta Otolaryngol.
130 Walker RA, Syed ZA. (2001). Harmonic scalpel tonsillectomy versus electrocautery tonsillectomy: a comparative pilot study. Otolaryngol Head Neck Surg.
131 Temple RH, Timms MS. (2001). Paediatric coblation tonsillectomy. Int J Pediatr Otorhinolaryngol.
132 Fujii Y, Tanaka H. (2001). Comparison of granisetron, droperidol, and metoclopramide for prevention of postoperative vomiting in children with a history of motion sickness undergoing tonsillectomy. J Pediatr Surg.
133 Fujii Y, Saitoh Y, Kobayashi N. (2001). Prevention of vomiting after tonsillectomy in children: granisetron versus ramosetron. Laryngoscope.
134 Nunez DA, Provan J, Crawford M. (2000). Postoperative tonsillectomy pain in pediatric patients: electrocautery (hot) vs cold dissection and snare tonsillectomy--a randomized trial. Arch Otolaryngol Head Neck Surg.
135 Holt R, Rask P, Coulthard KP, et al. (2000). Tropisetron plus dexamethasone is more effective than tropisetron alone for the prevention of postoperative nausea and vomiting in children undergoing tonsillectomy. Paediatr Anaesth.
136 Jensen AB, Christiansen DB, Coulthard K, et al. (2000). Tropisetron reduces postoperative vomiting in children undergoing tonsillectomy. Paediatr Anaesth.
137 Romsing J, Hertel S, Harder A, et al. (1998). Examination of acetaminophen for outpatient management of postoperative pain in children. Paediatr Anaesth.
138 Stage J, Jensen JH, Bonding P. (1988). Post-tonsillectomy haemorrhage and analgesics. A comparative study of acetylsalicylic acid and paracetamol. Clin Otolaryngol Allied Sci.
139 Beriat GK, Ezerarslan H, Kocaturk S. (2013). Microdebrider tonsillotomy in children with obstructive tonsillar hypertrophy. Journal of Clinical and Analytical Medicine.
140 Hamza A, Hayat U, Khan Q, et al. (2012). To compare the efficacy of ketorolac and pethidine for postoperative pain relief in first 24 hours after tonsillectomy. Pakistan Journal of Medical and Health Sciences.
141 Al-Shehri AMS. (2012). Post-tonsillectomy pain and bleeding in children: A comparison of traditional tonsillectomy with electrodissection tonsillectomy. Current Pediatric Research.
142 Abdel-Ghaffar HS, Sayed JA, Fathy MA, et al. (2012). Preincisional peritonsillar vs. intravenous lornoxicam for posttonsillectomy analgesia: A clinical and platelet aggregometry comparative study. Egyptian Journal of Anaesthesia.
143 Beriat GK, Ezerarslan H, Ekmekci P, et al. (2012). The use of Bipolar electrocautery tonsillectomy in patients with pediatric respiratory tract obstruction. Journal of Clinical and Analytical Medicine.
144 Omrani M, Barati B, Omidifar N, et al. (2012). Coblation versus traditional tonsillectomy: A double blind randomized controlled trial. Journal of Research in Medical Sciences.
145 Haraldsson PO, Attner P, Fredelius L, et al. (2011). Intrapersonal randomized controlled trial comparing bipolar scissors and conventional cold tonsillectomy. Otorhinolaryngology Clinics.
146 Khani A, Jaafarpour M, Khajavikhan J, et al. (2009). The effect of dexamethasone on morbidity related to vomiting, pain and oral intake in children after tonsillectomy. Journal of Clinical and Diagnostic Research.
147 Bhattacharya D, Mazumdar S, Chowdhury S, et al. (2009). Single dose IV dexamethasone with preemptive transdermal diclofenac patch reduces opioid requirement and postoperative morbidity following tonsillectomy. Journal of Anaesthesiology Clinical Pharmacology.
148 Alajmi MA, Al Noumas HS, Al-Abdulhadi KA, et al. (2008). Steroids for reducing post-tonsillectomy morbidity. Kuwait Medical Journal.
149 Bhattacharya D, Mondol MC, Dasgupta S, et al. (2005). A comparison of rectal diclofenac with intravenous pethidine for pain relief following tonsillectomy and adenoidectomy in children. Journal of Anaesthesiology Clinical Pharmacology.
150 Lee IH, Sung CY, Han JI, et al. (2009). The preemptive analgesic effect of ketorolac and propacetamol for adenotonsillectomy in pediatric patients. Korean Journal of Anesthesiology.
151 Lister M. (2005). Microdebrider partial tonsillectomy vs. electrosurgical tonsillectomy: a randomized, double-blind, paired-control study of postoperative pain.
152 Salama MA. (2012). Harmonic scalpel tonsillectomy versus coblation tonsillectomy. Menoufiya Medical Journal.
153 Matin M, Chowdhury MA, Haque ME, et al. (2013). Coblation Tonsillectomy Versus Blunt Dissectomy Tonsillectomy in Children. Anwer khan modern medical college journal.
154 Matin M, Chowdhury MA. (2012). Diode laser versus blunt dissection tonsillectomy. Bangladesh Journal of Otorhinolaryngology.
155 Kelly LE, Sommer DD, Ramakrishna J, et al. (2015). Morphine or Ibuprofen for post-tonsillectomy analgesia: a randomized trial. Pediatrics.
156 Yegane Moghaddam A, Fazel MR. (2012). Comparison of analgesic effect between gabapentin and diclofenac on post-operative pain in patients undergoing tonsillectomy. Pain practice.
157 Hussain F, Hafiz A, Siddique M. (2006). Analgesia; for children undergoing tonsillectomy (a clinical trial of three analgesic regimens in a peripheral hospital). Professional Medical Journal.
158 Gabr S, Harhash K, Fouly M, et al. (2014). Microdebrider intracapsular tonsillotomy versus conventional extracapsular tonsillectomy. The Egyptian Journal of Otolaryngology.
159 Abdul Monem ETM, Adul Hady E, Abu Beih AA. (2005). Acetaminophen versus diclofenac sodium after pediatric tonsillectomy. New Egyptian journal of medicine.
160 Salomone R, Jordao Visioli A, Aquino MM, et al. (2007). Ultrasonic Curved Shears in Tonsillectomy: Comparative Clinical Trial Between this New Surgical Technique and the Technique with the Cold Blade Surgical Knife.
161 Solanki NS, Goswami M, Thaker N. (2012). Bupivacaine infiltration versus diclofenac suppository for post-tonsillectomy pain relief in paediatric patients. National Journal of Medical Research.
162 Muhammad R, Wadood F, Khan MR, et al. (2013). Comparison of Efficacy of Dexamethasone and Orogastric Suction in Reducing Post Tonsillectomy Vomiting in Children. Gomal journal of medical sciences.
163 Elbadawey MR, Hegazy HM, Eltahan AE, et al. (2015). A randomised controlled trial of coblation, diode laser and cold dissection in paediatric tonsillectomy. J Laryngol Otol.
164 van Staaij BK, van den Akker EH, Rovers MM, et al. (2004). Effectiveness of adenotonsillectomy in children with mild symptoms of throat infections or adenotonsillar hypertrophy: open, randomised controlled trial. Bmj.
165 Buskens E, van Staaij B, van den Akker J, et al. (2007). Adenotonsillectomy or watchful waiting in patients with mild to moderate symptoms of throat infections or adenotonsillar hypertrophy: a randomized comparison of costs and effects. Arch Otolaryngol Head Neck Surg.
166 Le TM, Rovers MM, van Staaij BK, et al. (2007). Alterations of the oropharyngeal microbial flora after adenotonsillectomy in children: a randomized controlled trial. Arch Otolaryngol Head Neck Surg.
167 Stelter K, Ihrler S, Siedek V, et al. (2012). 1-year follow-up after radiofrequency tonsillotomy and laser tonsillotomy in children: a prospective, double-blind, clinical study. Eur Arch Otorhinolaryngol.
168 Stelter K, de la Chaux R, Patscheider M, et al. (2010). Double-blind, randomised, controlled study of post-operative pain in children undergoing radiofrequency tonsillotomy versus laser tonsillotomy. J Laryngol Otol.
169 Roje Z, Racic G, Kardum G, et al. (2011). Is the systemic inflammatory reaction to surgery responsible for post-operative pain after tonsillectomy, and is it “technique-related”?. Wien Klin Wochenschr.
170 Roje Z, Racic G, Dogas Z, et al. (2009). Postoperative morbidity and histopathologic characteristics of tonsillar tissue following coblation tonsillectomy in children: a prospective randomized single-blind study. Coll Antropol.
171 Quante M, Wang R, Weng J, et al. (2014). The Effect of Adenotonsillectomy for Childhood Sleep Apnea on Cardiometabolic Measures. Sleep.
172 Marcus CL, Moore RH, Rosen CL, et al. (2013). A randomized trial of adenotonsillectomy for childhood sleep apnea. N Engl J Med.
173 Rosen CL, Wang R, Taylor HG, et al. (2015). Utility of symptoms to predict treatment outcomes in obstructive sleep apnea syndrome. Pediatrics.
174 Weinstock TG, Rosen CL, Marcus CL, et al. (2014). Predictors of obstructive sleep apnea severity in adenotonsillectomy candidates. Sleep.
175 Chervin RD, Ellenberg SS, Hou X, et al. (2015). Prognosis for Spontaneous Resolution of Obstructive Sleep Apnea in Children. Chest.
176 Garetz SL, Mitchell RB, Parker PD, et al. (2015). Quality of life and obstructive sleep apnea symptoms after pediatric adenotonsillectomy. Pediatrics.
177 Katz ES, Moore RH, Rosen CL, et al. (2014). Growth after adenotonsillectomy for obstructive sleep apnea: an RCT. Pediatrics.
178 Konstantinopoulou S, Gallagher P, Elden L, et al. (2015). Complications of adenotonsillectomy for obstructive sleep apnea in school-aged children. Int J Pediatr Otorhinolaryngol.
179 Lock C, Wilson J, Steen N, et al. (2010). North of England and Scotland Study of Tonsillectomy and Adeno-tonsillectomy in Children(NESSTAC): a pragmatic randomised controlled trial with a parallel non-randomised preference study. Health Technol Assess.
180 Wilson JA, Steen IN, Lock CA, et al. (2012). Tonsillectomy: a cost-effective option for childhood sore throat? Further analysis of a randomized controlled trial. Otolaryngol Head Neck Surg.
181 Lock C, Wilson J, Steen N, et al. (2010). Childhood tonsillectomy: who is referred and what treatment choices are made? Baseline findings from the North of England and Scotland Study of Tonsillectomy and Adenotonsillectomy in Children (NESSTAC). Arch Dis Child.
182 Ericsson E, Graf J, Hultcrantz E. (2006). Pediatric tonsillotomy with radiofrequency technique: long-term follow-up. Laryngoscope.
183 Ericsson E, Wadsby M, Hultcrantz E. (2006). Pre-surgical child behavior ratings and pain management after two different techniques of tonsil surgery. Int J Pediatr Otorhinolaryngol.
184 Hultcrantz E, Ericsson E. (2004). Pediatric tonsillotomy with the radiofrequency technique: less morbidity and pain. Laryngoscope.
185 Ericsson E, Graf J, Lundeborg-Hammarstrom I, et al. (2014). Tonsillotomy versus tonsillectomy on young children: 2 year post surgery follow-up. J Otolaryngol Head Neck Surg.
186 Ericsson E, Lundeborg I, Hultcrantz E. (2009). Child behavior and quality of life before and after tonsillotomy versus tonsillectomy. Int J Pediatr Otorhinolaryngol.
187 Bitar MA, Rameh C. (2008). Microdebrider-assisted partial tonsillectomy: short- and long-term outcomes. Eur Arch Otorhinolaryngol.
188 Mohammad L, Ahmad R, Ahmad ML, et al. (2006). Post-tonsilelectomy morbidity - do steroids help. Indian J Otolaryngol Head Neck Surg.
189 Kordeluk S, Goldbart A, Novack L, et al. (2016). Randomized study comparing inflammatory response after tonsillectomy versus tonsillotomy. Eur Arch Otorhinolaryngol.
190 Romsing J, Ostergaard D, Senderovitz T, et al. (2001). Pharmacokinetics of oral diclofenac and acetaminophen in children after surgery. Paediatr Anaesth.
191 Paruthi S, Rosen CL, Wang R, et al. (2015). End-Tidal Carbon Dioxide Measurement during Pediatric Polysomnography: Signal Quality, Association with Apnea Severity, and Prediction of Neurobehavioral Outcomes. Sleep.
192 Lorusso F, Gallina S, Modica DM, et al. (2015). Bipolar Quantum Molecular Resonance versus Blunt Dissection tonsillectomy. B-ent.
193 Moriniere S, Roux A, Bakhos D, et al. (2013). Radiofrequency tonsillotomy versus bipolar scissors tonsillectomy for the treatment of OSAS in children: a prospective study. Eur Ann Otorhinolaryngol Head Neck Dis.
194 Ozkiris M, Kapusuz Z, Yildirim YS, et al. (2012). The effect of paracetamol, metamizole sodium and ibuprofen on postoperative hemorrhage following pediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
195 Ozkiris M. (2012). Comparison of three techniques in pediatric tonsillectomy. Eur Arch Otorhinolaryngol.
196 Ragab MA, Atef A, Mosleh M, et al. (2011). Bipolar scissors tonsillectomy: what are the advantages?. J Otolaryngol Head Neck Surg.
197 Di Rienzo Businco L, Coen Tirelli G. (2008). Paediatric tonsillectomy: radiofrequency-based plasma dissection compared to cold dissection with sutures. Acta Otorhinolaryngol Ital.
198 Vlastos IM, Parpounas K, Economides J, et al. (2008). Tonsillectomy versus tonsillotomy performed with scissors in children with tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
199 Nawasreh O, Fraihat A, Maaita J. (2000). The effect of preoperative intravenous dexamethasone in pediatric adenotonsillectomy. Journal of the Bahrain Medical Society.
200 Chettri S, Bhandary S, Nepal A, et al. (2014). A single blind controlled study comparing bipolar elecrocautery tonsillectomy to cold dissection method in pediatric age groups. Health Renaissance.
201 Volsky PG, Woughter MA, Beydoun HA, et al. (2014). Adenotonsillectomy vs observation for management of mild obstructive sleep apnea in children. Otolaryngol Head Neck Surg.
202 Udaipurwala IH. (2002). Role of prophylactic antibiotic in reducing post-tonsillectomy morbidity. Pakistan Journal of Otolaryngology, Head and Neck Surgery.
203 Biggs SN, Vlahandonis A, Anderson V, et al. (2014). Long-term changes in neurocognition and behavior following treatment of sleep disordered breathing in school-aged children. Sleep.
204 Ben-Israel N, Zigel Y, Tal A, et al. (2011). Adenotonsillectomy improves slow-wave activity in children with obstructive sleep apnoea. Eur Respir J.
205 Fernandes AA, Alcantara TA, D'Avila DV, et al. (2008). Study of weight and height development in children after adenotonsillectomy. Braz J Otorhinolaryngol.
206 Tarasiuk A, Simon T, Tal A, et al. (2004). Adenotonsillectomy in children with obstructive sleep apnea syndrome reduces health care utilization. Pediatrics.
207 Silveira H, Soares JS, Lima HA. (2003). Tonsillectomy: cold dissection versus bipolar electrodissection. Int J Pediatr Otorhinolaryngol.
208 Dualibi AP, Pignatari SS, Weckx LL. (2002). Nutritional evaluation in surgical treatment of children with hypertrophic tonsils and or adenoids. Int J Pediatr Otorhinolaryngol.
209 Thong G, Davies K, Murphy E, et al. (2016). Significant improvements in quality of life following paediatric tonsillectomy: a prospective cohort study. Ir J Med Sci.
210 Koshy E, Watt H, Curcin V, et al. (2015). Tonsillectomy among children with low baseline acute throat infection consultation rates in UK general practices: a cohort study. BMJ Open.
211 Burstein DH, Jackson A, Weedon J, et al. (2013). Adenotonsillectomy for sleep-disordered breathing in a predominantly obese pediatric population. Int J Pediatr Otorhinolaryngol.
212 Brigance JS, Miyamoto RC, Schilt P, et al. (2009). Surgical management of obstructive sleep apnea in infants and young toddlers. Otolaryngol Head Neck Surg.
213 Orvidas LJ, St Sauver JL, Weaver AL. (2006). Efficacy of tonsillectomy in treatment of recurrent group A beta-hemolytic streptococcal pharyngitis. Laryngoscope.
214 Trosman SJ, Eleff DJ, Krishna J, et al. (2016). Polysomnography results in pediatric patients with mild obstructive sleep apnea: Adenotonsillectomy vs. watchful waiting. Int J Pediatr Otorhinolaryngol.
215 Chowdhury K, Tewfik TL, Schloss MD. (1988). Post-tonsillectomy and adenoidectomy hemorrhage. J Otolaryngol.
216 D'Agostino R, Tarantino V, Calevo MG. (2009). Post-tonsillectomy late haemorrhage: is it a preferably night-time event?. Int J Pediatr Otorhinolaryngol.
217 Lowe D, van der Meulen J, Cromwell D, et al. (2007). Key messages from the National Prospective Tonsillectomy Audit. Laryngoscope.
218 Lowe D, Cromwell DA, Lewsey JD, et al. (2009). Diathermy power settings as a risk factor for hemorrhage after tonsillectomy. Otolaryngol Head Neck Surg.
219 Lowe D, van der Meulen J. (2004). Tonsillectomy technique as a risk factor for postoperative haemorrhage. Lancet.
220 Hultcrantz E, Ericsson E, Hemlin C, et al. (2013). Paradigm shift in Sweden from tonsillectomy to tonsillotomy for children with upper airway obstructive symptoms due to tonsillar hypertrophy. Eur Arch Otorhinolaryngol.
221 Sunnergren O, Hemlin C, Ericsson E, et al. (2014). Radiofrequency tonsillotomy in Sweden 2009-2012. Eur Arch Otorhinolaryngol.
222 Elinder K, Soderman AH, Stalfors J, et al. (2016). Factors influencing morbidity after paediatric tonsillectomy: a study of 18,712 patients in the National Tonsil Surgery Register in Sweden. Eur Arch Otorhinolaryngol.
223 Carithers JS, Gebhart DE, Williams JA. (1987). Postoperative risks of pediatric tonsilloadenoidectomy. Laryngoscope.
224 Walner DL, Miller SP, Villines D, et al. (2012). Coblation tonsillectomy in children: incidence of bleeding. Laryngoscope.
225 Tomkinson A, Harrison W, Owens D, et al. (2012). Postoperative hemorrhage following adenoidectomy. Laryngoscope.
226 Tomkinson A, Harrison W, Owens D, et al. (2011). Risk factors for postoperative hemorrhage following tonsillectomy. Laryngoscope.
227 Colclasure JB, Graham SS. (1990). Complications of outpatient tonsillectomy and adenoidectomy: a review of 3,340 cases. Ear Nose Throat J.
228 Lavin JM, Shah RK. (2015). Postoperative complications in obese children undergoing adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
229 Kvaerner KJ. (2009). Benchmarking surgery: secondary post-tonsillectomy hemorrhage 1999-2005. Acta Otolaryngol.
230 Suzuki S, Yasunaga H, Matsui H, et al. (2014). Impact of systemic steroids on posttonsillectomy bleeding: analysis of 61 430 patients using a national inpatient database in Japan. JAMA Otolaryngol Head Neck Surg.
231 Tomkinson A, De Martin S, Gilchrist CR, et al. (2005). Instrumentation and patient characteristics that influence postoperative haemorrhage rates following tonsil and adenoid surgery. Clin Otolaryngol.
232 Bhattacharyya N. (2010). Ambulatory pediatric otolaryngologic procedures in the United States: characteristics and perioperative safety. Laryngoscope.
233 Duval M, Wilkes J, Korgenski K, et al. (2015). Causes, costs, and risk factors for unplanned return visits after adenotonsillectomy in children. Int J Pediatr Otorhinolaryngol.
234 Padia R, Olsen G, Henrichsen J, et al. (2015). Hospital and Surgeon Adherence to Pediatric Tonsillectomy Guidelines Regarding Perioperative Dexamethasone and Antibiotic Administration. Otolaryngol Head Neck Surg.
235 Mahant S, Keren R, Localio R, et al. (2014). Variation in quality of tonsillectomy perioperative care and revisit rates in children's hospitals. Pediatrics.
236 Mahant S, Keren R, Localio R, et al. (2014). Dexamethasone and risk of bleeding in children undergoing tonsillectomy. Otolaryngol Head Neck Surg.
237 Bangiyev JN, Thottam PJ, Christenson JR, et al. (2015). The association between pediatric general emergency department visits and post operative adenotonsillectomy hospital return. Int J Pediatr Otorhinolaryngol.
238 Tweedie DJ, Bajaj Y, Ifeacho SN, et al. (2012). Peri-operative complications after adenotonsillectomy in a UK pediatric tertiary referral centre. Int J Pediatr Otorhinolaryngol.
239 Abou-Jaoude PM, Manoukian JJ, Daniel SJ, et al. (2006). Complications of adenotonsillectomy revisited in a large pediatric case series. J Otolaryngol.
240 Zhao YC, Berkowitz RG. (2006). Prolonged hospitalization following tonsillectomy in healthy children. Int J Pediatr Otorhinolaryngol.
241 Clark MP, Waddell A. (2004). The surgical arrest of post-tonsillectomy haemorrhage: hospital episode statistics. Ann R Coll Surg Engl.
242 Mills N, Anderson BJ, Barber C, et al. (2004). Day stay pediatric tonsillectomy--a safe procedure. Int J Pediatr Otorhinolaryngol.
243 Capper JW, Randall C. (1984). Post-operative haemorrhage in tonsillectomy and adenoidectomy in children. J Laryngol Otol.
244 Yuan CC, Yu DY, Jun TS, et al. (1984). Guillotine tonsillectomy without anesthesia. Auris Nasus Larynx.
245 Carmody D, Vamadevan T, Cooper SM. (1982). Post tonsillectomy haemorrhage. J Laryngol Otol.
246 Gooda MR, Sheik I, Suleri A. (2010). Reducing post operative bleeding after tonsillectomies in children by modifying the monopolar diathermy technique: A study of 1500 patients. Pakistan Journal of Medical Sciences.
247 Shay S, Shapiro NL, Bhattacharyya N. (2015). Revisit rates and diagnoses following pediatric tonsillectomy in a large multistate population. Laryngoscope.
248 Bhattacharyya N, Shapiro NL. (2014). Associations between socioeconomic status and race with complications after tonsillectomy in children. Otolaryngol Head Neck Surg.
249 Kim DW, Koo JW, Ahn SH, et al. (2010). Difference of delayed post-tonsillectomy bleeding between children and adults. Auris Nasus Larynx.
250 Sarny S, Habermann W, Ossimitz G, et al. (2013). What lessons can be learned from the Austrian events?. ORL J Otorhinolaryngol Relat Spec.
251 Sarny S, Ossimitz G, Habermann W, et al. (2011). Hemorrhage following tonsil surgery: a multicenter prospective study. Laryngoscope.
252 Windfuhr JP, Chen YS. (2002). Incidence of post-tonsillectomy hemorrhage in children and adults: a study of 4,848 patients. Ear Nose Throat J.
253 Windfuhr JP, Chen YS. (2001). Hemorrhage following pediatric tonsillectomy before puberty. Int J Pediatr Otorhinolaryngol.
254 Windfuhr JP, Chen YS. (2003). Post-tonsillectomy and -adenoidectomy hemorrhage in nonselected patients. Ann Otol Rhinol Laryngol.
255 Granell J, Gete P, Villafruela M, et al. (2004). Safety of outpatient tonsillectomy in children: a review of 6 years in a tertiary hospital experience. Otolaryngol Head Neck Surg.
256 Perkins JN, Liang C, Gao D, et al. (2012). Risk of post-tonsillectomy hemorrhage by clinical diagnosis. Laryngoscope.
257 Crysdale WS, Russel D. (1986). Complications of tonsillectomy and adenoidectomy in 9409 children observed overnight. CMAJ.
258 Hessen Soderman AC, Ericsson E, Hemlin C, et al. (2011). Reduced risk of primary postoperative hemorrhage after tonsil surgery in Sweden: results from the National Tonsil Surgery Register in Sweden covering more than 10 years and 54,696 operations. Laryngoscope.
259 Lannigan FJ, Martin-Hirsch DP, Basey E. (1993). Clinical audit: is day-case adenotonsillectomy safe?. Br J Clin Pract.
260 Achar P, Sharma RK, De S, et al. (2015). Does primary indication for tonsillectomy influence post-tonsillectomy haemorrhage rates in children?. Int J Pediatr Otorhinolaryngol.
261 Liu JH, Anderson KE, Willging JP, et al. (2001). Posttonsillectomy hemorrhage: what is it and what should be recorded?. Arch Otolaryngol Head Neck Surg.
262 Herdman RC, Bates GJ. (1986). Childhood tonsillectomy and discharge after 24 hours. J Laryngol Otol.
263 Arnoldner C, Grasl M, Thurnher D, et al. (2008). Surgical revision of hemorrhage in 8388 patients after cold-steel adenotonsillectomies. Wien Klin Wochenschr.
264 Vlastos IM, Athanasopoulos I, Economides J, et al. (2010). Outpatient cold knife tonsillectomy in toddlers with sleep disordered breathing. B-ENT.
265 Abdullah B, Qazi IM, Al Harbi JM, et al. (2015). Post-tonsillectomy hemorrhage: An analysis of incidence and risk factors in Kuwait. Kuwait Medical Journal.
266 Spektor Z, Saint-Victor S, Kay DJ, et al. (2016). Risk factors for pediatric post-tonsillectomy hemorrhage. Int J Pediatr Otorhinolaryngol.
267 Kshirsagar R, Mahboubi H, Moriyama D, et al. (2016). Increased immediate postoperative hemorrhage in older and obese children after outpatient tonsillectomy. Int J Pediatr Otorhinolaryngol.
268 Harounian JA, Schaefer E, Schubart J, et al. (2016). Pediatric Posttonsillectomy Hemorrhage: Demographic and Geographic Variation in Health Care Costs in the United States. Otolaryngol Head Neck Surg.
269 Odhagen E, Sunnergren O, Hemlin C, et al. (2016). Risk of reoperation after tonsillotomy versus tonsillectomy: a population-based cohort study. Eur Arch Otorhinolaryngol.
270 Raol N, Zogg CK, Boss EF, et al. (2016). Inpatient Pediatric Tonsillectomy: Does Hospital Type Affect Cost and Outcomes of Care?. Otolaryngol Head Neck Surg.
271 Pfaff JA, Hsu K, Chennupati SK. (2016). The Use of Ibuprofen in Posttonsillectomy Analgesia and Its Effect on Posttonsillectomy Hemorrhage Rate. Otolaryngol Head Neck Surg.
272 Jones DT, Yoon MJ, Licameli G. (2007). Effectiveness of postoperative follow-up telephone interviews for patients who underwent adenotonsillectomy: a retrospective study. Arch Otolaryngol Head Neck Surg.
273 Kang J, Brodsky L, Danziger I, et al. (1994). Coagulation profile as a predictor for post-tonsillectomy and adenoidectomy (T + A) hemorrhage. Int J Pediatr Otorhinolaryngol.
274 Yardley MP. (1992). Tonsillectomy, adenoidectomy and adenotonsillectomy: are they safe day case procedures?. J Laryngol Otol.
275 Mahadevan M, van der Meer G, Gruber M, et al. (2016). The starship children's hospital tonsillectomy: A further 10 years of experience. Laryngoscope.
276 Peeters A, Van Rompaey D, Schmelzer B, et al. (1999). Tonsillectomy and adenotomy as a one day procedure?. Acta Otorhinolaryngol Belg.
277 Sckolnick JS, Mantle B, Li J, et al. (2008). Pediatric myringoplasty: factors that affect success-a retrospective study. Laryngoscope.
278 Koycu A, Aydin E, Tulgar Kinik S. (2016). Changes in body composition and growth pattern after adenotonsillectomy in prepubertal children. Int J Pediatr Otorhinolaryngol.
279 Sklar MC, Narang I, Ngan BY, et al. (2013). A solitary tonsil can cause severe obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
280 United Nations. (2016). World Economic Situation and Prospects.
281 Greiner O, Berger C, Day PJ, et al. (2002). Rates of detection of Neisseria meningitidis in tonsils differ in relation to local incidence of invasive disease. J Clin Microbiol.
282 Finkelstein Y, Wexler DB, Nachmani A, et al. (2002). Endoscopic partial adenoidectomy for children with submucous cleft palate. Cleft Palate Craniofac J.
283 Naraghi M, Adil S, Bastaninejad S, et al. (2015). Evaluation of pediatric voice handicap index and pediatric voice related quality of life before and after adenotonsillectomy in pediatric population. Int J Pediatr Otorhinolaryngol.
284 Fitzgerald C, Oosthuizen JC, Colreavy M. (2015). Paediatric tonsillotomy--an Irish perspective on potential evolving indications. Ir Med J.
285 Rijken BF, Lequin MH, de Rooi JJ, et al. (2013). Foramen magnum size and involvement of its intraoccipital synchondroses in Crouzon syndrome. Plast Reconstr Surg.
286 Perkins J, Dahiya R. (2003). Microdissection needle tonsillectomy and postoperative pain: a pilot study. Arch Otolaryngol Head Neck Surg.
287 Bitar MA, Birjawi G, Youssef M, et al. (2009). How frequent is adenoid obstruction? Impact on the diagnostic approach. Pediatr Int.
288 Arruda LK, Mimica IM, Sole D, et al. (1990). Abnormal maxillary sinus radiographs in children: do they represent bacterial infection?. Pediatrics.
289 Tait AR, Voepel-Lewis T, O'Brien LM. (2014). Postsurgical behaviors in children with and without symptoms of sleep-disordered breathing. Perioper Med (Lond).
290 Chazan B, Shaabi M, Bishara E, et al. (2003). Clinical predictors of streptococcal pharyngitis in adults. Isr Med Assoc J.
291 Oda M, Kito S, Tanaka T, et al. (2013). Prevalence and imaging characteristics of detectable tonsilloliths on 482 pairs of consecutive CT and panoramic radiographs. BMC Oral Health.
292 Tanpowpong K, Saisukul I, Kittimanont H, et al. (2007). Outcome of myringotomy with ventilation tube for otitis media with effusion in Thai children: Ramathibodi experiences. J Med Assoc Thai.
293 Mosges R, Hellmich M, Allekotte S, et al. (2011). Hemorrhage rate after coblation tonsillectomy: a meta-analysis of published trials. Eur Arch Otorhinolaryngol.
294 Alexiou VG, Salazar-Salvia MS, Jervis PN, et al. (2011). Modern technology-assisted vs conventional tonsillectomy: a meta-analysis of randomized controlled trials. Arch Otolaryngol Head Neck Surg.
295 Acevedo JL, Shah RK, Brietzke SE. (2012). Systematic review of complications of tonsillotomy versus tonsillectomy. Otolaryngol Head Neck Surg.
296 Walton J, Ebner Y, Stewart MG, et al. (2012). Systematic review of randomized controlled trials comparing intracapsular tonsillectomy with total tonsillectomy in a pediatric population. Arch Otolaryngol Head Neck Surg.
297 Venekamp RP, Hearne BJ, Chandrasekharan D, et al. (2015). Tonsillectomy or adenotonsillectomy versus non-surgical management for obstructive sleep-disordered breathing in children. Cochrane Database Syst Rev.
298 Song SA, Tolisano AM, Cable BB, et al. (2016). Neurocognitive outcomes after pediatric adenotonsillectomy for obstructive sleep apnea: A systematic review and meta-analysis. Int J Pediatr Otorhinolaryngol.
299 Wang H, Fu Y, Feng Y, et al. (2015). Tonsillectomy versus tonsillotomy for sleep-disordered breathing in children: a meta analysis. PLoS One.
300 Van M, Khan I, Hussain SS. (2015). Short-term weight gain after adenotonsillectomy in children with obstructive sleep apnoea: systematic review. J Laryngol Otol.
301 De Luca Canto G, Pacheco-Pereira C, Aydinoz S, et al. (2015). Adenotonsillectomy Complications: A Meta-analysis. Pediatrics.
302 Burton MJ, Glasziou PP, Chong LY, et al. (2014). Tonsillectomy or adenotonsillectomy versus non-surgical treatment for chronic/recurrent acute tonsillitis. Cochrane Database Syst Rev.
303 Georgalas CC, Tolley NS, Narula PA. (2014). Tonsillitis. BMJ Clin Evid.
304 Pinder DK, W H, Hilton MP. (2011). Dissection versus diathermy for tonsillectomy (Review). Cochrane Database of Systematic Reviews.
305 Jeyakumar A, Brickman TM, Williamson ME, et al. (2008). Nonsteroidal anti-inflammatory drugs and postoperative bleeding following adenotonsillectomy in pediatric patients. Arch Otolaryngol Head Neck Surg.
306 Lee CH, Hsu WC, Chang WH, et al. (2015). Polysomnographic Findings after Adenotonsillectomy for Obstructive Sleep Apnea in Obese and Non-Obese Children: A Systemic review and Meta-Analysis. Clin Otolaryngol.
307 O'Reilly BJ, Black S, Fernandes J, et al. (2003). Is the routine use of antibiotics justified in adult tonsillectomy?. J Laryngol Otol.
308 Mitchell RB. (2007). Adenotonsillectomy for obstructive sleep apnea in children: outcome evaluated by pre- and postoperative polysomnography. Laryngoscope.
309 Stewart MG, Glaze DG, Friedman EM, et al. (2005). Quality of life and sleep study findings after adenotonsillectomy in children with obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
310 McAteer JP, LaRiviere CA, Drugas GT, et al. (2013). Influence of surgeon experience, hospital volume, and specialty designation on outcomes in pediatric surgery: a systematic review. JAMA Pediatr.
311 Pieper D, Mathes T, Neugebauer E, et al. (2013). State of evidence on the relationship between high-volume hospitals and outcomes in surgery: a systematic review of systematic reviews. J Am Coll Surg.
312 Birkmeyer JD, Stukel TA, Siewers AE, et al. (2003). Surgeon volume and operative mortality in the United States. N Engl J Med.
313 Fox R, Temple M, Owens D, et al. (2008). Does tonsillectomy lead to improved outcomes over and above the effect of time? A longitudinal study. J Laryngol Otol.
314 Fox R, Tomkinson A, Myers P. (2006). Morbidity in patients waiting for tonsillectomy in Cardiff: a cross-sectional study. J Laryngol Otol.
315 Windfuhr JP, Schloendorff G, Baburi D, et al. (2008). Serious post-tonsillectomy hemorrhage with and without lethal outcome in children and adolescents. Int J Pediatr Otorhinolaryngol.
316 Windfuhr JP, Schloendorff G, Baburi D, et al. (2008). Life-threatening posttonsillectomy hemorrhage. Laryngoscope.
317 Attner P, Haraldsson PO, Hemlin C, et al. (2009). A 4-year consecutive study of post-tonsillectomy haemorrhage. ORL J Otorhinolaryngol Relat Spec.