# Methods

In this chapter, we document the procedures that we used to produce a comparative effectiveness review (CER) on tonsillectomy in children with obstructive sleep-disordered breathing (OSDB) or recurrent throat infections. These procedures follow the methods outlined in the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^33^

## Topic Refinement and Review Protocol

The topic for this report was nominated by the American Academy of Otolaryngology-Head and Neck Surgery (AAO-HNSF) in a public process using the Effective Health Care website. Working from the nomination, we drafted the initial key questions (KQ) and analytic frameworks and refined them with input from key informants representing the fields of pediatrics, otolaryngology, anesthesiology, and sleep medicine. We also spoke with a caregiver representative. All members of the research team were required to submit information about potential conflicts of interest before initiation of the work. No members of the review team had any conflicts.

After review from AHRQ, the questions and framework were posted online for public comment. No changes to the questions or frameworks were recommended. We also developed population, interventions, outcomes, timing, and settings (PICOTS) criteria for intervention KQ.

We identified technical experts on the topic to provide assistance during the project. The Technical Expert Panel (TEP), representing the fields of pediatrics, otolaryngology, anesthesiology, infectious disease, and sleep medicine, contributed to the AHRQ's broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included eight members serving as technical or clinical experts. To ensure robust, scientifically relevant work, TEP members participated in conference calls and discussions through e-mail to:

- Help to refine the analytic framework and KQ at the beginning of the project;
- Discuss inclusion/exclusion criteria; and
- Assist with determining key interventions and outcomes of interest.

The final protocol was posted to the AHRQ Effective Health Care web site and registered in the PROSPERO international register of systematic reviews (ID#: CRD42015025600).

## Literature Search Strategy

### Search Strategy

To ensure comprehensive retrieval of relevant studies of therapies for children undergoing tonsillectomy, we used three key databases: the MEDLINE^®^ medical literature database via the PubMed^®^ interface; EMBASE (Excerpta Medica Database), an international biomedical and pharmacological literature database via the Ovid^®^ interface; and the Cochrane Library. Search strategies for KQs applied a combination of controlled vocabulary (Medical Subject Headings [MeSH] and Emtree headings) to focus specifically on tonsillectomy and harms of interventions. We restricted literature searches for KQs to studies published from January 1980 to June 2016 to reflect current techniques for tonsillectomy and perioperative or postoperative medications. A second librarian reviewed the search strategies.

We included only studies published in English as a review of non-English citations retrieved by our MEDLINE search identified few studies of relevance. Appendix B lists our search terms and strategies and the yield from each database.

We carried out hand searches of the reference lists of recent systematic reviews or meta-analyses of studies addressing pediatric tonsillectomy. The investigative team also scanned the reference lists of studies included after the full-text review phase for additional studies that potentially could meet our inclusion criteria.

### Gray Literature

AHRQ's Scientific Resource Center notified companies that produce surgical instruments used for tonsillectomy or devices such as continuous positive airway pressure (CPAP) machines about the opportunity to provide Scientific Information Packets (SIPs) to inform the review. Because many manufacturers may produce medications used in the peri- or postoperative periods, a notice of the opportunity to submit scientific material to inform the review was posted in the Federal Register for 6 weeks.

We also searched ClinicalTrials.gov to assess reporting bias and to identify any study results that may not have been identified in our other database searches. We applied the inclusion criteria in Table 3 to studies identified via our gray literature searches.

Table 3 Inclusion criteria for studies of tonsillectomy

Category | Criteria
Population | - Children with OSDB age 3-18 years, inclusive (KQ1); - Children with neuromuscular or craniofacial abnormalities and OSDB age 3-18 years, inclusive (KQ1a); - Children under age 3 years with OSDB (KQ1b); - Children with Down syndrome OSDB age 3-18 years, inclusive (KQ1c ); - Children with obesity or overweight and OSDB age 3-18 years, inclusive (KQ1d ); - Children with recurrent throat infection age 3-18 years, inclusive (KQ2); - Children with OSDB or recurrent throat infection undergoing tonsillectomy age 3-18 years, inclusive (KQ 4-6)
Intervention | - Tonsillectomy, adenotonsillectomy, or tonsillotomy (partial removal of tonsil) using any surgical approach (e.g., coblation, laser, cold dissection) (KQ 1-6); - Perioperative (preoperative, intraoperative, and immediate postoperative [postanesthesia care] periods) NSAIDs, steroids, or antiemetics (KQ5); - Any postoperative (discharge from post-anesthesia care to up to 10 days postsurgery) agent for pain (KQ6)
Design | - Effectiveness outcomes: Comparative studies (RCTs, prospective or retrospective cohort studies with comparison groups, nonrandomized trials, case-control studies) (KQ1-6); - Harms: Comparative studies (RCTs, prospective or retrospective cohort studies with comparison groups, nonrandomized trials, case-control studies), database or registry studies (harms of tonsillectomy), case series with at least 1000 participants (harms of tonsillectomy)
Other | - Original research (KQ1-6); - Publication language: English (KQ1-6); - Publication year: January 1980-June 2016 (KQ1-2) or January 2000-June 2016 (KQ3-6); - Reports one or more of the outcomes described in Table 2; - Sufficiently detailed methods and results to enable data extraction (KQ1-6); - Reports outcome data by target population or intervention (KQ1-KQ6)

Abbreviations: KQ = Key Question; NSAID = Nonsteroidal Anti-Inflammatory Drug; OSDB = Obstructive Sleep-Disordered Breathing; RCT = Randomized Controlled Trial

### Inclusion and Exclusion Criteria

Table 3 lists the inclusion/exclusion criteria we used based on our understanding of the literature, key informant and public comment during the topic refinement phase, input from the TEP, and established principles of systematic review methods. We used a best evidence approach to determine final inclusion of studies. That is, if evidence from randomized studies was insufficient to address a KQ or specific outcomes, we considered evidence from observational literature as well as factors related to the relevance of studies to determine whether including additional studies was warranted).^34^ We also included studies considered to have high risk of bias (as described below) in meta-analyses after sensitivity analyses showed no systematic effects on findings.

We limited our searches for comparative effectiveness questions to studies published in English and from January 1980 to June 2016 for studies of the effectiveness of tonsillectomy in children with OSDB or recurrent throat infections (KQs1-2). In consultation with the review nominator, we limited inclusion of studies relevant to KQs3-6 to those published between January 2000 and June 2016 as we identified a large literature base, including many randomized controlled trials (RCTs), addressing these questions.

We also excluded studies including both children and adults if the mean plus standard deviation age of participants was greater than 18 years and data were not reported separately for children (3-18 years of age for most KQs). We included comparative studies (studies including an intervention and a comparison group) evaluating the benefits or harms of tonsillectomy (tonsillectomy, adenotonsillectomy, and partial tonsillectomy conducted using any surgical technique such as cautery or cold dissection) compared with an inactive control or alternate intervention. We also included case series or database studies including at least 1,000 children undergoing tonsillectomy to address harms but not effectiveness. We selected the bound of 1,000 as a conservative value based on a preliminary review in which we identified numerous case series or database studies with 1,000 or more participants.

### Study Selection

Once we identified articles through the electronic database searches and hand-searching, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated the abstracts of studies identified in our searches for KQs for inclusion or exclusion, using an Abstract Review Form (Appendix C). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it. Following abstract review, two reviewers independently assessed the full text of each included study using a standardized form (Appendix C) that included questions stemming from our inclusion and exclusion criteria. We adjudicated disagreements through discussion between reviews or final adjudication by a senior reviewer.

We conducted all abstract and full text reviews using the DistillerSR online screening application (Evidence Partners Incorporated, Ottawa, Ontario). Appendix D includes a list of excluded studies and the reasons for exclusion. Data extracted for each study are available via the Systematic Review Data Repository (srdr.ahrq.gov).

### Data Extraction

The staff members and clinical experts who conducted this review (including two otolaryngologists, one pediatrician, one pediatric pulmonology sleep medicine physician, one biostatistician, and three epidemiologists/systematic reviewers) jointly developed the data extraction forms for the KQs. We designed forms to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to the KQs. We used two templates to facilitate the extraction of data based on study type; one form was designed for case series or database studies that reported harms data and one was created to accommodate all types of comparative studies for effectiveness and harms data.

The team was trained to extract data by extracting several articles into the template and then reconvening as a group to discuss the utility of the template. We repeated this process through several iterations until we decided that the templates included the appropriate categories for gathering the information contained in the articles and for potential meta-analyses. Team data extractors shared the task of initially entering information into the evidence tables. A second team member also reviewed the articles and edited all initial entries for accuracy, completeness, and consistency. A senior reviewer reconciled disagreements concerning the information reported.

The full research team met regularly during the data extraction period and discussed issues related to the whole process. In addition to outcomes related to the effectiveness of tonsillectomy (e.g., changes in sleep parameters or quality of life), we extracted all data available on harms. Harms encompass the full range of specific negative effects, including the narrower definition of adverse events.

## Data Synthesis

We summarized data for KQs qualitatively using summary tables when meta-analyses were not possible. We used a best evidence approach and focused on lower risk of bias studies when they provided sufficient data to address a KQ.^34^

We identified sufficient data to address studies comparing tonsillectomy with watchful waiting in children with OSDB. Studies used in this fixed effects meta-analysis included children with polysomnography-proven OSDB and reported the Apnea Hypopnea Index (AHI) at baseline and followup. We modeled the difference between followup and baseline scores as a Gaussian random variable.

We also meta-analyzed studies comparing the risk of post-tonsillectomy hemorrhage (PTH) with perioperative steroids compared with placebo. We used a zero-inflated binomial model to account for the relatively high number of studies with no PTH-related outcomes in the available data. We included study random effects to account for correlation among arms in the same study. Finally, we addressed PTH and related readmissions or clinician visits using quantitative meta-analysis methods. We implemented a mixed-effects, arm-based meta-analysis to assess the influence of different surgical procedures and the effect of partial compared with total tonsillectomy on the occurrence of PTH-related outcomes following surgery. We also conducted analyses to estimate the effects of including high risk of bias studies in our analyses. These analyses suggested no systematic effects of these studies; thus, we retained them in all three meta-analyses. Appendix E contains a full description of the meta-analytic methods.

## Risk of Bias Assessment of Individual Studies

We used separate tools appropriate for specific study designs to assess the risk of bias of individual studies meeting eligibility criteria for our KQs. We used prespecified questions from Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions^35^ appropriate to each study design to assess risk of bias of randomized controlled trials (RCT) and observational studies and a tool adapted from questions outlined in the McMaster McHarms tool to assess reporting of harms.^36^

Questions assessing risk of bias evaluate domains including selection bias, performance bias, attrition bias, detection bias, and reporting bias as well as methods for recruiting cohorts and controlling for confounding. The harms assessment tool addresses questions related to pre-specification and reporting of harms.

Risk of bias assessment of each study was conducted independently by two team members using the forms presented in Appendix C. Any discrepancies were adjudicated by the two team members or a senior investigator. Investigators did not rely on the study design as described by authors of individual papers; rather, the methods section of each paper was reviewed to determine which rating tool to employ. The results of these tools were then translated to “low,” “moderate,” and “high” risk of bias ratings as described below. Appendix F reports risk of bias scoring for each study.

We required that RCTs receive a positive rating (i.e., low risk of bias) on 12 of 13 of the questions used to assess each study to be considered to have low risk of bias. RCTs had to receive nine to eleven positive ratings to have moderate risk of bias, and studies with ≤ eight positive ratings were considered to have high risk of bias. We considered a rating of “unclear” for a question as a negative rating. We assessed the risk of bias for each major outcome of relevance reported but report an overall assessment unless the risk of bias varied by outcome.

We required that cohort studies receive positive ratings on at least 13 of the 14 questions used to assess each study to have low risk of bias for cohort studies and on nine to 12 questions to be considered to have moderate risk of bias for cohort studies. We considered studies that received positive ratings on ≤ eight questions to have high risk of bias. We required that studies assessed for harms reporting receive positive ratings on all four of the four questions used to assess each study to be considered to have low risk of bias. We considered studies receiving three positive ratings as moderate risk of bias and those with two or fewer positive ratings as high risk of bias.

## Strength of the Body of Evidence

We applied explicit criteria for rating the overall strength of the evidence for each key intervention-outcome pair for which the overall risk of bias was not high. We rated the strength of the evidence for the outcomes of interest for our KQs (Table 2) and for clinically important harms. We used established concepts of the quantity of evidence (e.g., numbers of studies, aggregate ending-sample sizes), the quality of evidence (from the risk of bias ratings on individual articles), and the coherence or consistency of findings across similar and dissimilar studies and in relation to known or theoretically sound ideas of clinical knowledge.

The strength of evidence evaluation that we used is described in the Effective Health Care Program's Methods Guide for Effectiveness and Comparative Effectiveness Reviews^33^ and in the updated strength of evidence guide.^37^ The latter emphasizes five major domains: study limitations (low, medium, high level of limitation), consistency (inconsistency not present, inconsistency present, unknown or not applicable), directness (direct, indirect), precision (precise, imprecise), and reporting bias (suspected, undetected). Study limitations are derived from the risk of bias assessment of the individual studies that addressed the KQs and specific outcome under consideration (see Appendix C for more information on strength of evidence domains). Each key outcome for each comparison of interest is given an overall evidence grade based on the ratings for the individual domains.

We graded the overall strength of evidence as outlined in Table 4. Two senior staff members independently graded the body of evidence; disagreements were resolved as needed through discussion or third-party adjudication. We recorded strength of evidence assessments in tables, summarizing results for each outcome. We did not consider case series and database studies in the assessment of strength of the evidence for harms.

Table 4 Strength of evidence grades and definitions^*^

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

* Excerpted from Berkman et al., 2014^37^

## Applicability

We assessed the applicability of findings reported in the included literature addressing our KQs to the general population of children undergoing tonsillectomy; our approach involved determining the population, intervention, comparator, and setting in each study and developing an overview of these elements for each intervention category. We anticipated that areas in which applicability would be especially important to describe would include the indication for tonsillectomy, age at treatment, surgical technique, and population characteristics such as body mass index (BMI), Down syndrome, and craniofacial abnormalities. Applicability tables for each KQ are in Appendix G.

## Peer Review and Public Commentary

Researchers and clinicians with expertise in tonsillectomy and individuals representing stakeholder and user communities provided external peer review of this report. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revised the text as appropriate, and documented changes and revisions to the report in a disposition of comments report that will be made available 3 months after AHRQ posts the final review on the AHRQ Effective Health Care Web site.