# Introduction

## Background

Tonsillectomy or adenotonsillectomy (“tonsillectomy”) are commonly performed in the United States and represent more than 15 percent of all surgical procedures in children under the age of 15 years.^1, 2^ The primary indication for tonsillectomy has shifted over the last 20 years from recurrent throat infections to obstructive sleep-disordered breathing (OSDB) and obstructive sleep apnea (OSA).^3, 4^ Widely variable national and small area tonsillectomy rates are well documented. In their seminal study, Wennberg and Gittlesohn found that rates of tonsillectomy varied almost 12-fold across adjacent counties in rural Vermont with similar populations.^5^ Variation in rates continues despite improved evidence and dissemination about indications.^1^

### Surgical Techniques

Table 1 categorizes common surgical techniques used for tonsillectomy. Choice of technique depends on patient factors including the surgical indication (e.g., recurrent infection, OSDB) and clinician practice patterns. All procedures are performed under general anesthesia. Hereafter, we use the term tonsillectomy to refer to removal of the tonsils alone, removal of tonsils and adenoids (adenotonsillectomy), and partial removal of the tonsils (tonsillotomy, partial tonsillectomy) using any surgical technique or approach.

Table 1 Commonly used surgical techniques or tools for tonsillectomy

Surgical Technique or Tool | Description
Cold dissection | Palatine tonsils dissected and removed from oropharynx using a scalpel, scissors or other nonpowered means.
Electrocautery | Palatine tonsils dissected and removed from oropharynx using electrocautery (i.e., monopolar cautery, bipolar cautery).
Harmonic scalpel | Palatine tonsils dissected and removed from oropharynx using ultrasonic energized instrumentation.
Microdebridement | Palatine tonsils removed from oropharynx using a microdebrider, which suctions tonsillar tissue into a rotary blade, which morselizes and removes tissue. All or part of the tonsil can be removed with this technique.
Laser ablation | Palatine tonsils removed from oropharynx with handheld laser.
Coblation | Palatine tonsils dissected and removed from oropharynx using low-temperature irrigation radio frequency energy device.

### Indications for Tonsillectomy

Tonsillectomy has two primary indications: recurrent tonsillitis and obstructive sleep-disordered breathing (OSDB). Recurrent or severe tonsillitis has been defined as seven or more episodes of sore throat in the preceding year OR five or more episodes in the each of the preceding 2 years OR 3 or more episodes in each of the preceding 3 years.^6^ No gold standard diagnostic test exists to implicate etiologically or predictably attribute symptoms to tonsillitis. In fact, consensus is lacking on what symptoms attributable to tonsillitis are considered “disabling.” Surrogates often used for tonsillitis include sore throat and pharyngitis. However, the degree to which either of these terms reflects true tonsillitis is not known. Bacterial pharyngitis can be diagnosed via rapid testing or culture. It is not possible, however, to determine whether the tonsil represents the infectious nidus or if the suspected pathogen represents normal bacterial flora for a particular child's pharynx.

Despite evidence to the contrary, clinicians sometimes treat sore throat empirically with antibiotics without objective testing.^7^ Sore throat or pharyngitis may or may not have a tonsillar origin, and it is possible that many cases have alternative explanations. Nonetheless, many cases are termed “tonsillitis” without supportive documentation.^8^ Frequency of infections is a metric of severity used to determine eligibility for tonsillectomy.^6, 9, 10^ This criterion is fraught with complexity related to diagnostic variability and to incomplete and inconsistent medical documentation. Thus, heterogeneity in diagnostic accuracy, establishment of severity, and frequency of infections complicates treatment decisions regarding tonsillectomy and the performance of comparative effectiveness of its treatments.^6, 9-11^

Currently, the most common indication for tonsillectomy is OSDB (i.e., breathing difficulties during sleep including OSA, which has been defined as “a disorder in which a person frequently stops breathing during his or her sleep,” and may be diagnosed based on the frequency of cessation of airflow [apnea] or reduction in airflow with desaturation [hypopnea],^12^ and upper airway resistance syndrome [UARS]). OSDB results from obstruction from or dynamic collapse due to upper airway soft tissue during sleep resulting in snoring, hypopnea, apnea, and restless sleep. Adenotonsillar hypertrophy can cause oropharyngeal crowding, thereby increasing the likelihood of symptomatic airway collapse during sleep. OSDB includes disorders ranging from simple snoring to OSA and can result in significant declines in quality of life and negative health consequences. It has been associated with a five-point decrease in intelligence quotient (IQ), hypersomnolence, emotional lability, decreased attention, small stature, enuresis, cardiopulmonary morbidity, and missed school.^13^ Evidence of the relationship is reinforced by the effectiveness of OSDB treatment in improving behavior, attention, quality of life, neurocognitive functioning, enuresis, parasomnias, and restless sleep, and reversal of associated cardiovascular sequelae.^14, 15^ Moreover, OSDB occurs at especially high rates in subsets of children with developmental disorders and craniofacial syndromes, including Down syndrome.

As in adults, the gold standard diagnostic test for OSA in children is polysomnography (PSG), which physiologically tests sleep architecture and efficiency. Treatment involves alleviating the inciting upper airway soft tissue obstruction or collapse. One method of primary treatment is continuous positive airway pressure (CPAP), which is a device worn over a child's nose and/or mouth that delivers continuous high pressure flow to the lungs, acting as a pneumatic stent to maintain upper airway patency during sleep. CPAP compliance is highly variable in children.^16-20^ Therefore, other treatment approaches include weight loss in overweight children, orthodontic devices to expand the palate, and allergy or anti-inflammatory medications. However, since the most common culprit in children is tonsillar hypertrophy-related oropharyngeal obstruction, tonsillectomy is often used to establish an adequate airway.

Regardless of indication, age may affect tonsillectomy outcomes. In general, younger children tend to tolerate surgery better than older children and adults,^21, 22^ but risk is increased with surgery in very young children (< 2 years) compared with older children. Tonsillectomy is not commonly performed in this very young age group. To date, little guidance regarding the comparative effectiveness of treating recurrent infection or OSDB in children less than 2 years of age exists. Furthermore, obesity may differentially affect OSDB, which may alter expectations and treatment efficacy and outcomes.

Tonsillectomy is painful and is associated with odynophagia (painful swallowing) and dysphagia (difficulty swallowing) that can make it difficult to return to normal diet or stay hydrated, and can be associated with postoperative hemorrhage, nausea and vomiting. To help minimize these concerns, clinicians may use perioperative antibiotics, steroids, antiemetics, and pain medications (e.g., nonsteroidal anti-inflammatory drugs [NSAIDs] and other analgesics). A 2012 Cochrane review examining the effect of perioperative systemic antibiotics on post-tonsillectomy morbidity (pain, consumption of pain medications, secondary hemorrhage, fever, and return to normal diet) failed to find any clinically important impact of antibiotics in reducing pain, need for analgesia, or secondary post-tonsillectomy hemorrhage (PTH).^23^ However, this analysis combined adult and pediatric trials; thus, the applicability to children alone is not clear. Furthermore, this review included only randomized controlled trials (RCTs). The role of perioperative anti-inflammatory medications (e.g., NSAIDs) and systemic steroids have been addressed in prior meta-analyses and reviews, with consistent findings of low risk of PTH and reduced morbidity (pain, time to return to normal diet and activity) associated with perioperative dexamethasone in children,^24-29^ and less consistent findings regarding NSAIDs.^30, 31^ Two systematic reviews reported no significant risk of PTH with perioperative NSAID use^31, 32^ while one reported insufficient data to rule out risk.^30^ One review also noted an increased PTH risk with postoperative NSAIDs.^31^

Thus, clinicians and parents need to know three key things: 1) what is the likelihood that the surgery (compared with watchful waiting with supportive care) will improve clinical outcomes around recurrent throat infections and sleep disorders; 2) what is the risk that the child will experience a harm, primarily PTH, with the surgery; and 3) if surgery is indicated, what approach, in terms of both surgical technique and perioperative medical care, has been demonstrated to optimize effectiveness and minimize harms? We address these questions by reviewing the comparative (primarily RCT) data for effectiveness on a specific set of outcomes and also searching a broader set of studies for harms data in order to estimate the frequency of the most common and most severe harms, namely PTH, readmission, and reoperation. The results from this report will be widely applicable; however, lack of consistently reported modifier data (e.g., body mass index [BMI], surgical indications) may limit its generalizability to every child.

## Scope and Key Questions

### Scope of Review

The current review addresses the comparative effectiveness and harms of tonsillectomy in children with the most common indications for the procedure, namely, OSDB and recurrent throat infections. We targeted the review on these two key indications in order to maximize its utility for a broad population while maintaining a scope of work feasible for the systematic review. The review, nominated by the American Academy of Otolaryngology - Head & Neck Surgery Foundation (AAO-HNSF), addresses key decisional dilemmas identified by stakeholders and through our preliminary scan of the literature in a comprehensive manner. The review also includes Key Questions (KQ) to improve understanding of outcomes in subgroups such as very young children (1-2 years old), children with Down syndrome, and those who are overweight or obese.

### Key Questions

We developed KQs in consultation with Key Informants and the Task Order Officer. KQs were posted for review to the Agency for Healthcare Research and Quality Effective Health Care Web site. We note that OSDB includes breathing difficulties during sleep as operationalized in each study, including OSA and UARS. As noted, tonsillectomy includes tonsillectomy, partial tonsillectomy, and adenotonsillectomy. We also note that comparative effectiveness includes both the benefits and harms of interventions.

Questions were as follows:

KQ1. In children with obstructive sleep-disordered breathing (OSDB), what is the comparative effectiveness of tonsillectomy compared with continuous positive airway pressure (CPAP) or watchful waiting with supportive care (including pharmacologic treatment) to improve sleep outcomes, cognitive or behavioral outcomes, and health outcomes?

KQ1a. In children with OSDB and neuromuscular or craniofacial abnormalities, what is the comparative effectiveness of tonsillectomy compared with CPAP or watchful waiting with supportive care (including pharmacologic treatment) to improve sleep outcomes, cognitive or behavioral outcomes, and health outcomes?

KQ1b. In children with OSDB under age 3 years, what is the comparative effectiveness of tonsillectomy compared with watchful waiting with supportive care (including pharmacologic treatment) to improve sleep outcomes, cognitive or behavioral outcomes, and health outcomes?

KQ1c. In children with OSDB and Down syndrome, what is the comparative effectiveness of tonsillectomy compared with CPAP or watchful waiting with supportive care (including pharmacologic treatment) to improve sleep outcomes, cognitive or behavioral outcomes, and health outcomes?

KQ1d. In children with OSDB who are overweight or obese, what is the comparative effectiveness of tonsillectomy compared with CPAP, weight loss, or watchful waiting with supportive care (including pharmacologic treatment) to improve sleep outcomes, cognitive or behavioral outcomes, and health outcomes?

KQ2. Among children with recurrent throat infections, what is the comparative effectiveness, including harms, of tonsillectomy compared with watchful waiting with supportive care (including pharmacologic—antibiotic or nonantibiotic—treatments) on the number and severity of throat infections, quality of life, and health care utilization?

KQ3. Do benefits and harms differ between partial tonsillectomy and total tonsillectomy?

KQ4. Do benefits and harms differ by surgical technique (e.g., cautery, coblation)?

KQ5. What are the benefits and harms of adjunctive perioperative (i.e., preoperative, intraoperative, or in post-anesthesia care) pharmacologic agents intended to improve outcomes?

KQ6. What are the benefits and harms of postoperative (i.e., after discharge from post-anesthesia care and up to 10 days postsurgery) pharmacologic agents intended to reduce pain-related outcomes?

Table 2 outlines population, intervention, comparator, outcomes, timing, and setting (PICOTS) characteristics for each KQ.

Table 2 Population, intervention, comparator, outcome characteristics^*^

KQ | Population | Intervention^†^ | Comparators | Outcomes
1 | Children (3-18 years of age) with OSDB^**^ | Tonsillectomy | - Continuous positive airway pressure (CPAP); - Pharmacologic treatment including anti-inflammatory medications, decongestants, allergy medication, antihistamines, nasal steroids, leukotriene inhibitors | Sleep outcomes; - Apnea Hypopnea Index (AHI); - Sleep quality measures (Obstructive Sleep Apnea-18 [OSA-18], Clinical Assessment Score-15 [CAS-15]); - Pediatric Sleep Questionnaire (PSQ); - Modified Epworth Sleepiness Scale; - Desaturation nadir; - OSDB persistence; Cognitive or behavioral outcomes; - Validated measures of attention, irritability, and memory; Health outcomes; - Growth velocity (height, BMI for age); - Cardiopulmonary issues; - Self or caregiver-reported enuresis; - Health care utilization (number of clinician visits); Harms; - Re-admission or ER visit or ICU admission for postoperative pain, dehydration, PTH, or nausea and vomiting; - Reoperation for primary or secondary PTH; - Velopharyngeal insufficiency; - 30-day mortality; - Harms of comparator agents reported in studies with comparison groups
1a | Children (3-18 years of age) with OSDB and neuromuscular or craniofacial abnormalities | Tonsillectomy | See comparators above (KQ1) | See outcomes above (KQ1)
1b | Children under age 3 with OSDB | Tonsillectomy | See comparators above (KQ1) | See outcomes above (KQ1) Length of stay
1c | Children (3-18 years of age) with OSDB and Down syndrome | Tonsillectomy | See comparators above (KQ1) | See outcomes above (KQ1) Length of stay
1d | Children (3-18 years of age) with OSDB who are overweight or obese | Tonsillectomy | - CPAP; - Weight loss; - Pharmacologic treatment including anti-inflammatory medications, decongestants, allergy medication, antihistamines, nasal steroids, leukotriene inhibitors | See outcomes above (KQ1)
2 | Children (3-18 years) with recurrent throat infections | Tonsillectomy | - Antibiotics; - Nonantibiotic pharmacologic treatments (e.g., anti-inflammatory agents, decongestants, antihistamines, leukotriene inhibitors, nasal or systemic steroids) | Throat infections; - Number of throat infections/year; - Severity of throat infections; - Number of streptococcal infections/year; Quality of life; - Validated quality of life measures; - Missed school or work for child or caregiver; Other outcomes; - Health care utilization (number of clinician visits, number of courses of antibiotics); Harms; - ER visit or hospital or ICU admission for postoperative pain, PTH, dehydration, or nausea and vomiting; - Reoperation for primary or secondary PTH; - Velopharyngeal insufficiency; - 30-day mortality; - Harms of comparator agents reported in studies with comparison groups
3 | Children (3-18 years) undergoing tonsillectomy | Total tonsillectomy | - Partial tonsillectomy | See sleep, cognitive or behavioral, and health outcomes (KQ1) and quality of life outcomes (KQ2) Throat infections; - Number of throat infections/year; - Severity of throat infections; - Number of streptococcal infections/year; Other outcomes; - Symptomatic tonsillar regrowth; - Time to return to usual activity (diet, school); Harms See KQ1 Reoperation for complete tonsillectomy
4 | Children (3-18 years) undergoing tonsillectomy | Tonsillectomy | - Other technique for tonsillectomy | See sleep, cognitive or behavioral, and health outcomes (KQ1) and quality of life outcomes (KQ2) Throat infections; - Number of throat infections/year; - Severity of throat infections; - Number of streptococcal infections/year; Other outcomes; - Time to return to usual activity (diet, school); Harms See KQ1
5 | Children (3-18 years) undergoing tonsillectomy | Tonsillectomy plus adjunctive perioperative (i.e., preoperative, intraoperative, or immediate postoperative [post-anesthesia care] periods) pharmacologic agents | - Tonsillectomy without adjunctive perioperative pharmacologic agents (i.e., pharmacologic agents given to attempt to reduce postoperative morbidity including pain or nausea and vomiting ) | - Pain management (need for rescue medications); - Time to return to usual activities (diet, school); - Health care utilization (number of clinician visits, number of courses of antibiotics); Harms; - Harms of agent; - Re-admission to hospital or ICU or ER visit for postoperative pain, PTH, dehydration, or nausea and vomiting; - Reoperation for primary or secondary PTH; - 30-day mortality
6 | Children (3-18 years) undergoing tonsillectomy and receiving pharmacologic agents for pain postoperatively (i.e., up to 10 days after discharge from post-anesthesia care) | Tonsillectomy plus postoperative pharmacologic agents for pain (e.g., NSAID, ketorolac) | - Tonsillectomy with other postoperative pharmacologic agents for pain | See outcomes and harms for KQ5

* Studies of any length or followup and in any setting, except for KQ6, which includes pharmacologic agents for pain given up to 10 days postsurgery.

** Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

† Tonsillectomy includes tonsillectomy, adenotonsillectomy, partial tonsillectomy

Abbreviations: AHI = Apnea Hypopnea Index; BMI = Body Mass Index; CAS-15 = Clinical Assessment Score-15; CPAP = Continuous Positive Airway Pressure; ER = Emergency Room; KQ = Key Question; NSAID = Nonsteroidal Anti-Inflammatory Drug; OSA-18 = Obstructive Sleep Apnea-18; OSDB = Obstructive Sleep-Disordered Breathing; PTH = Post-Tonsillectomy Hemorrhage

## Analytic Framework

The analytic frameworks illustrate the population, interventions, and outcomes that guided the literature search and synthesis (Appendix A). The frameworks depict the key questions within the context of the population, intervention, comparator, outcomes, timing, and setting (PICOTS) parameters described in Table 2.

## Organization of This Report

The Methods section describes the review processes. The Results section presents findings for each key question organized by intervention and outcome area where possible. We discuss harms reported in studies of surgical techniques in a separate section following discussion of effectiveness outcomes in each KQ, including a meta-analysis that provides expected frequency of PTH by surgical approach and by partial versus total tonsillectomy. Summary tables for each key question outline key outcomes.

The Discussion section of the report outlines the current state of the literature and challenges for future research in the field. We also provide a list of abbreviations and acronyms at the end of the report.

## Uses of This Evidence Report

We anticipate this report will be of primary value to organizations that develop guidelines for tonsillectomy, to clinicians who provide care for children with indications for tonsillectomy, and for families making treatment decisions. Children who are candidates for tonsillectomy may be treated by clinicians including pediatricians, otolaryngologists, sleep medicine physicians, allergists, family physicians, anesthesiologists, infectious disease physicians, nurse practitioners, physician assistants, and nurses. This report supplies practitioners and researchers up-to-date information about the current state of evidence and assesses the quality of studies that aim to determine the outcomes and safety of tonsillectomy.