# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- James Barraclough, M.B.Ch.B.
  Royal Wolverhampton Hospitals NHS Trust
  Wolverhampton, England, UK
- David Gozal, M.D., M.B.A.
  The University of Chicago
  Chicago, IL
- Sanjay Mahant, M.D., M.Sc., FRCPC
  Hospital for Sick Children
  Institute of Health Policy, Management, and Evaluation
  University of Toronto
  Toronto, Ontario, CA
- Kalpana Manthiram, M.D., M.S.C.I.
  National Human Genome Research Institute
  National Institutes of Health
  Bethesda, MD