# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Reginald Baugh, M.D.
  The University of Toledo
  Toledo, OH
- Emily Boss, M.D., M.P.H.
  Johns Hopkins University School of Medicine
  Baltimore, MD
- Randall Flick, M.D., M.P.H.
  Mayo Clinic
  Rochester, MN
- Carole L. Marcus, M.B.B.Ch.
  Children's Hospital of Philadelphia
  University of Pennsylvania
  Philadelphia, PA
- Ron B. Mitchell, M.D.
  University of Texas Southwestern Medical Center
  Dallas, TX
- Richard Rosenfeld, M.D., M.P.H.
  SUNY Downstate Medical Center
  Brooklyn, NY