# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Ms. Jessica Kimber was an invaluable resource for assistance with data extraction and checking, and helped to locate studies and track data. Ms. Katie Worley assisted with data extraction and developing tables, and Ms. Sanura Latham helped with data entry and extraction. Drs. Mamata Raj and Jeff Andrews assisted with screening studies and risk of bias assessment. We sincerely appreciate their dedicated work and the input of our Task Order Officers and Associate Editor, Key Informants, and Technical Experts.