# Discussion

## State of the Literature

We identified 218 unique studies addressing the benefits and harms of tonsillectomy (which we consider to encompass tonsillectomy, adenotonsillectomy, partial tonsillectomy or tonsillotomy). These unique studies (reported in multiple publications) comprised 141 randomized controlled trials (RCTs), 12 nonrandomized trials, seven prospective and five retrospective cohort studies, and 53 database or registry studies or case series including at 1000 children. Key Questions (KQs) addressed in this review assessed the likelihood that tonsillectomy will improve clinical outcomes around throat infections and sleep disorders; the risk of harm associated with tonsillectomy, primarily post-tonsillectomy hemorrhage (PTH); and whether different approaches to tonsillectomy (e.g., partial vs. total tonsil removal, surgical technique such as coblation or laser) optimize effectiveness and minimize harms. We addressed these questions by reviewing the comparative (primarily RCT) data for effectiveness on a specific set of outcomes, then by searching a broader set of studies (case series and database or registry studies including at least 1000 children) for harms data in order to estimate the frequency of the most common and most severe harms (PTH, readmission, and reoperation). While we attempted to stratify on key covariates, including body mass index (BMI), documentation of throat infections, and surgical indication, such data were rarely available.

The literature on tonsillectomy in children for obstructive sleep-disordered breathing (OSDB) or recurrent throat infection is heterogeneous in terms of populations, interventions, comparators, and outcomes. Most studies included children with widely varying ages (e.g., 2 to 14 years), unspecified or mixed (both OSDB and throat infections) indications for surgery, and varying degrees of severity. Few studies stratified on potential confounding factors such as degree of tonsillar hypertrophy.

Anesthetic, analgesic, and anti-emetic regimens varied across studies, as did surgical techniques and perioperative and postoperative agents or combinations of agents assessed. Comparison groups included placebo, observation, historical control groups, and other active interventions. While studies typically addressed similar effectiveness outcomes including changes in respiratory or sleep parameters (e.g., Apnea Hypopnea Index [AHI], sleep-related quality of life), number and severity of throat infections, return to normal diet and activity, need for rescue analgesia or antiemetics postoperatively, and behavioral outcomes, measures used to evaluate the outcomes varied. Although a large number of studies reported PTH, definitions of “bleeding” varied and ranged from episodes of blood-tinged sputum to profuse bleeding requiring reoperation for hemostasis. Outcome measures were also frequently caregiver- or child-reported pain or bleeding diaries.

## Summary of Key Findings and Strength of the Evidence

### KQ1 Effectiveness of Tonsillectomy for OSDB

#### Key Findings

Relative to no intervention, most studies reported better sleep-related outcomes in children who had a tonsillectomy, but improvements were modest overall. In five studies that included children whose OSDB was confirmed with polysomnography (PSG), AHI scores improved more in children receiving tonsillectomy than in those with no surgery (significant group differences in 3 studies).^114, 172, 203, 204, 211^ ). Meta-analysis of three studies showed a 4.8-point decline (improvement) in AHI in children who underwent tonsillectomy compared with no surgery.^172, 204, 211^ Sleep-related quality of life and negative behaviors (e.g., anxiety, emotional lability) also improved more among children who had tonsillectomy, but the clinical significance of these changes is not clear.^114, 172, 211^ Children in the studies typically did not have behavioral scores indicative of clinical concern at baseline. Changes in executive function were not significantly different between groups.^172, 203^

We did not find tonsillectomy to be superior to continuous positive airway pressure (CPAP) in the one RCT addressing this comparison, which included children with significant comorbidities.

#### Strength of the Evidence

For tonsillectomy compared with no surgery, we found greater improvement in AHI and negative behaviors with tonsillectomy vs. watchful waiting. Our confidence in these conclusions is low (low strength of evidence). We also found consistently greater improvement in sleep-related quality of life with tonsillectomy vs. watchful waiting and have more confidence in this conclusion (moderate strength of evidence). We could not make conclusions about effects on executive function and other outcomes including cognitive changes (insufficient strength of evidence). Table 48 outlines strength of evidence findings for this KQ. We could not make conclusions about outcomes following tonsillectomy compared with CPAP and in studies assessing outcomes in sub-populations such as children with Down syndrome (KQ1a-d) given the few studies addressing CPAP or these populations (insufficient strength of evidence).

Table 48 Strength of evidence for effectiveness of tonsillectomy versus watchful waiting/no treatment for OSDB

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Finding
Tonsillectomy vs. No Tonsillectomy
AHI Meta-analysis RCT: 2 moderate^114, 172^ (N=456) Prospective Cohort: 1 moderate^203^ (N=38) Retrospective Cohort: 2 moderate^211,214^ (N=94) | Medium | Inconsistent | Indirect | Precise | Undetected | Low SOE for greater improvement of AHI with tonsillectomy compared with no surgery Significant improvement in tonsillectomy vs. no surgery groups in 1 RCT and 2 retrospective cohort studies; no significant group differences in 1 RCT and 1 prospective cohort. In 3 studies, children in control arms improved from baseline. 4.8-point improvement in AHI in tonsillectomy arms in meta-analysis.
Sleep-related Quality of Life RCT: 2 moderate^114, 172^ (N=456) Retrospective Cohort: 1 moderate^211^ (N=32) | Medium | Consistent | Direct | Precise | Undetected | Moderate SOE for improvement in sleep-related quality of life after tonsillectomy vs. no surgery Significant improvements in tonsillectomy vs. no tonsillectomy groups on measures of sleep-related quality of life in 2 RCTs and 1 cohort study in the short term
Behavioral Outcomes RCT: 1 moderate^172^ (N=397) Prospective Cohort: 1 moderate^203^ (N=38) Retrospective Cohort: 1 moderate^211^ (N=32) | Medium | Inconsistent | Direct | Imprecise | Not suspected | Low SOE for improvements in negative behaviors after tonsillectomy vs. no surgery Significant improvements in tonsillectomy vs. no surgery in 1 RCT and 1 retrospective cohort; no significant differences in 1 prospective cohort; differences in measurement time frames across studies (7 months-4 years) and unclear clinical significance of changes

AHI = apnea-hypopnea index; OSDB = obstructive-sleep disordered breathing; RCT = randomized controlled trial; SOE = strength of the evidence

### KQ1a-d Effectiveness of Tonsillectomy for Subpopulations of Children With OSDB

#### Key Findings

While studies may have included some children with craniofacial abnormalities, only a single, small RCT compared the efficacy of tonsillectomy to immediate initiation of CPAP in children with OSDB and concurrent Down syndrome or mucopolysaccharidoses.^44^ Both groups showed improvement in AHI at 6-month followup, with no significant group differences in AHI at 12 months. Another study reported no significant group differences in outcomes in analyses of children with syndromic comorbidities receiving tonsillectomy or watchful waiting.^214^

Several studies included children who were overweight or obese; however, only two retrospective cohorts specifically evaluated overweight/obese populations with OSDB. One reported a significant decrease in AHI in children who received tonsillectomy compared with those who did not.^211^ In another including children with mild OSA, analysis of subgroups of obese children showed no significant differences in outcomes between groups in these populations.^214^

While several studies included children less than 3 years of age, these data were not extractable from the aggregate study population data. We did not identify studies explicitly addressing this question.

#### Strength of the Evidence

Strength of the evidence is insufficient to assess effects on outcomes in subpopulations of children with OSDB (children with neuromuscular or craniofacial abnormalities, those under 3 years of age, those with Down syndrome, or those with obesity).

### KQ2 Effectiveness of Tonsillectomy for Recurrent Throat Infection

#### Key Findings

Although studies assessed frequency of infections and a number of utilization measures, such as missed school in the short term, longer-term results were rarely reported, and studies that did report longer-term results suffered from high attrition and incomplete data. In addition, “throat infection” was not defined consistently across studies and very rarely was bacterial infection confirmed.

Overall, children undergoing tonsillectomy to improve number of throat infections, associated health care utilization (clinician visits), and days of work/school missed had improvements in these outcomes in the first postsurgical year compared with children not receiving surgery.^9, 164, 179, 210, 213^ These benefits diminished over time, however, and data on the longer-term outcomes are limited.

#### Strength of the Evidence

Compared with no surgery, tonsillectomy reduced utilization (clinician contacts) and missed school/work in the short term. We have low confidence in this conclusion (low strength of evidence). We have moderate confidence that compared with no surgery, tonsillectomy reduced throat infections or streptococcal infections in the short term (<12 months) (moderate strength of evidence). In the longer term (>12 months) we found no difference between groups in reduction in streptococcal infections (low strength of evidence). We found no significant differences between groups in missed school/work or quality of life in the long term (>12 months) and have low confidence in these conclusions (low strength of evidence). Table 49 outlines strength of evidence ratings.

Table 49 Strength of evidence for effectiveness of tonsillectomy versus watchful waiting/no treatment for recurrent throat infections

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Findings
Tonsillectomy vs. No tonsillectomy in children with at least 3 episodes of sore throat in year prior to study
Throat Infection RCT: 4 moderate^9, 164, 179^ (N=761) Non-RCT: 1 moderate^179^ (N=303) Retrospective Cohort: 1 moderate^213^ (N=290) | Medium | Consistent | Direct | Precise | Undetected | Moderate SOE for reduction in throat infection after tonsillectomy vs. no treatment in short-term (12 months) Fewer throat infections in tonsillectomy arms in short-term
Streptococcal Infection (≤ 12 months post-tonsillectomy) RCT: 2 moderate^9^ (N=273) Retrospective Cohort: 1 moderate^213^ (N=290) | Medium | Consistent | Direct | Precise | Undetected | Moderate SOE for reduction in streptococcal infection after tonsillectomy vs. no tonsillectomy in short term (12 months) Fewer streptococcal infections in tonsillectomy arms in short-term
Streptococcal Infection (2-3 years post tonsillectomy) RCT: 2 moderate^9^ (N=203) Retrospective Cohort: 1 moderate^213^ (N=290) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low SOE for no difference in reduction in streptococcal infection after tonsillectomy vs.no surgery over longer term (2-3 years) Similar proportion of infections in retrospective cohort and significantly more infections in nonsurgical groups in 2 RCTs
Utilization (clinician contacts) RCT: 1 moderate^179^ (N=231) Non-RCT: 1 moderate^179^ (N=303) | Medium | Consistent | Direct | Precise | Undetected | Low SOE for reduction in clinician contacts after tonsillectomy vs. no surgery in short term ( <12 months) Fewer consultations in tonsillectomy arms vs. no surgery, but high loss to followup and differences in outcome assessment
Missed school/work (≤ 12 months post tonsillectomy) RCT: 3 moderate^9, 164^ (N=503) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low SOE for improvements in missed school after tonsillectomy vs. no surgery in short term ( < 12 months) Significantly fewer missed days in tonsillectomy arms vs. no surgery in 2 RCTs with medium study limitations at 12 month followup; no differences in third RCT
Missed school/work (> 12 months post tonsillectomy) RCT: 3 moderate^9, 164^ (N=245) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no difference in effects between in longer term (>12 months) No significant differences between groups in all studies at longer-term followup; SOE is low given medium study limitations and relatively low number of participants
Quality of Life (>12 months) RCT: 2 moderate^164, 179^ (N=373) Non-RCT: 1 moderate^179^ (N=123) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no difference in longer term (>12 months) quality of life Modest improvements in quality of life in both groups in all studies; SOE is low given high attrition in studies

Non-RCT = nonrandomized trial; RCT = randomized controlled trial; SOE = strength of the evidence

We could not make a conclusion about long term (>12 months) effects on throat infections (insufficient strength of evidence) as few studies reported longer-term data, and those that did had high attrition rates. Only one study included children with less than 3 episodes of throat infection in the year prior to surgery;^210^ we could not make conclusions about outcomes (utilization) reported in this single study (insufficient strength of evidence).

### KQ3 Effectiveness of Partial Versus Total Tonsillectomy

#### Key Findings

Few studies compared partial and total tonsillectomy using the same surgical technique.^53, 84-86, 90^ In studies comparing cold dissection or coblation for partial or total tonsillectomy, return to normal diet or activity were faster in children undergoing partial removal. ^53, 84-86^ Differences in time to return to normal activity were not significant in a study comparing partial and total electrocautery.^90^

In studies evaluating partial vs. total tonsillectomy using differing surgical techniques, differences between partial and total tonsillectomy were generally not significant for outcomes related to OSDB persistence, quality of life, or behavior (although it is not possible to be certain that effects are due to the surgical technique rather than the extent of surgery).^71, 95, 97, 98, 107, 110, 139, 151, 158, 182-186^

In six studies, children in the partial tonsillectomy arms had faster return to diet and normal activity compared with those in total tonsillectomy groups; however, these effects may be due to confounding by indication as surgical indication varied across studies. Across all studies, 10 out of an estimated 166 children (6%) had tonsillar regrowth after partial tonsillectomy, 5 of whom ultimately underwent revision surgery. Data from these studies do not allow firm conclusions about the benefits or harms of one technique over another or about the comparative benefit of partial vs. total removal; however, neither surgical technique or extent of surgery appear to have a marked effect on outcomes.

#### Strength of the Evidence

In studies comparing partial and total cold dissection tonsillectomy, return to normal diet was faster in children undergoing partial tonsillectomy. Our confidence in this conclusion is low (low strength of evidence). We could not assess effects on throat infections, OSDB persistence, or return to normal activity in these studies (insufficient SOE).

In studies comparing either partial and total coblation tonsillectomy or partial and total electrocautery tonsillectomy, we could not make conclusions about effects on return to normal diet or activity (insufficient strength of evidence).

In studies comparing mixed techniques for partial or total tonsillectomy, return to normal diet and activity was more favorable in children undergoing partial versus total tonsillectomy. Our confidence in this conclusion is low (low strength of evidence). These effects may be due to confounding by indication as indication varied across studies. In studies comparing mixed techniques for partial or total tonsillectomy, we found no difference in effects on long-term (>12 months) persistence of OSDB symptoms, quality of life, behavioral outcomes, or throat infections between partial and total tonsillectomy. Our confidence in these conclusions is low (low strength of evidence). Table 50 outlines strength of evidence findings.

Table 50 Strength of evidence for effectiveness of total tonsillectomy versus partial tonsillectomy

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Findings
Total vs.partial cold dissection tonsillectomy
Return to Normal Diet RCT: 1 low,^53^ 1 moderate^86^ (N=131) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for faster return to normal diet after partial vs. total tonsillectomy Children undergoing partial tonsillectomy returned to normal diet approximately 4 days sooner than children undergoing total tonsillectomy according to parent report
Total vs. Partial tonsillectomy (mixed techniques)
Return to Normal Diet or Activity RCT: 2 low,^97, 98^ 4 moderate,^95, 107, 110, 185, 186^ (N=620) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for more favorable return to normal diet and activity in children undergoing partial vs. total tonsillectomy Children undergoing partial vs. total tonsillectomy had consistently favorable outcomes but unit of measure varied across studies (e.g., mean days, N children)
OSDB Persistence (≥12 months post-tonsillectomy) RCT: 3 moderate^110, 182-186^ (N=214) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no difference in effects on long-term persistence of OSDB symptoms between partial and total tonsillectomy More children undergoing partial vs. total tonsillectomy had short-term snoring or obstructive symptoms in 2 studies but no group differences in longer term in any study
Quality of Life (≥12 months post-tonsillectomy) RCT: 2 moderate^182-186^ (N=159) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no long-term differences in quality of life after partial vs. total tonsillectomy Improvements from baseline in both groups in 2 small studies, but no significant group differences in quality of life in either study
Behavioral Outcomes (≥12 months post-tonsillectomy) RCT: 2 moderate^182-186^ (N=159) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no long-term differences in behavioral outcomes after partial vs. total tonsillectomy Improvements from baseline in both groups on the Child Behavior Checklist in 2 small studies, but no significant group differences in either study
Throat Infections (≥12 months post-tonsillectomy) RCT: 1 low,^185, 186^ 3 moderate^110, 139, 182-184^ (N=296) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low SOE for no effect on throat infections following partial vs. total tonsillectomy More throat infections or sore throats following partial vs. total tonsillectomy in 3 of 4 RCTs but no significant group differences

N = number; OSDB = obstructive sleep-disordered breathing; RCT = randomized controlled trial; SOE = strength of the evidence

### KQ4 Effectiveness of Surgical Techniques for Tonsillectomy

#### Key Findings

Few studies addressing this question reported effectiveness data. Nineteen studies reported resumption of normal activity and/or diet. Commonly used “hot” techniques were generally associated with faster return to normal diet or activity than was cold dissection (roughly 1 to 4 days). Few studies, typically addressing different measures and using different comparison techniques, addressed newer techniques such as thermal welding, laser, or harmonic scalpel, thus limiting our ability to draw conclusions about these approaches.

#### Strength of the Evidence

We found a faster return to diet with coblation or electrocautery tonsillectomy compared with cold dissection and have low confidence in these conclusions (low strength of evidence) (Table 51). We could not make conclusions about effects associated with other techniques including laser, thermal welding, and harmonic scalpel (insufficient strength of evidence) on these outcomes given that studies were typically small and evaluated different measures (e.g., dietary intake score, number of children consuming normal diet, parental return to work).

Table 51 Strength of evidence for return to normal diet or activity in studies of surgical techniques for tonsillectomy

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Findings
Coblation vs. Cold dissection tonsillectomy
Return to normal activity RCT: 3 low^89, 144, 169, 170^ 1 moderate^197^ (N=276) | Low | Consistent | Direct | Imprecise | Undetected | Low SOE for faster return with coblation Coblation, compared with cold dissection, associated with moderately faster return to normal activity in 4 small studies
Electrocautery vs. cold dissection tonsillectomy
Return to normal diet RCT: 1 low^134^ 2 moderate^79, 127^ (N=254) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low SOE for faster return with electrocautery Electrocautery associated with faster return to normal diet in 2 studies and not significantly faster in a third

N = number; RCT = randomized controlled trial; SOE = strength of the evidence

### Harms of Surgical Techniques

#### Key Findings

We included harms data reported in comparative studies and case series and database and registry studies to address this KQ; however, we considered only data from meta-analyses and comparative studies in our assessment of the strength of the evidence. Overall, estimates of PTH and utilization harms associated with tonsillectomy are less than 5 percent. In meta-analyses, the frequency of primary and secondary PTH associated with total and partial tonsillectomy was below 4 percent for any technique and with overlapping confidence bounds. Pooled frequencies (without adjustment) of PTH were also less than 5 percent overall (4.2% for total tonsillectomy; 1.5% for partial tonsillectomy) in comparative studies. Unadjusted frequencies of revisits for pain, dehydration, or postoperative nausea and vomiting (PONV) were less than 2 percent. Other harms were disparate and generally not clinically significant (e.g., thermal burn from a cautery apparatus). No comparative studies reported deaths. Frequency of PTH in case series and database or registry studies generally aligned with that in comparative studies. At least four deaths were reported across case series or database studies (low or moderate risk of bias) including 1,778,342 children.

#### Strength of the Evidence

We found a low frequency of PTH and PTH-related utilization across surgical techniques and have confidence in these findings (high strength of evidence). We found a low frequency of revisits or readmission for dehydration associated with partial tonsillectomy. Our confidence in this conclusion is low given the few studies reporting these outcomes (low strength of evidence). We have greater confidence in a low frequency of nonbleeding readmissions/revisits associated with total tonsillectomy (moderate strength of evidence). We could not draw conclusions about effects on admissions or revisits for pain or PONV associated with partial tonsillectomy given the few comparative studies addressing the outcome (insufficient strength of evidence). Table 52 outlines strength of evidence.

Table 52 Strength of evidence for harms associated with surgical techniques for tonsillectomy

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Findings
Partial tonsillectomy
PTH and PTH-associated utilization Meta-analysis RCT: 5 low,^53, 90, 98, 151, 167, 168^11 moderate^58, 71, 84-86, 95, 110, 139, 158, 182-186^ (N=1234) | Medium | Consistent | Direct | Precise | Undetected | High SOE for low frequency of PTH associated with partial tonsillectomy Frequency did not exceed 4% for total PTH; fewer data available to assess associated utilization, but frequency is likely low given the low frequency of PTH
Readmissions/revisits for dehydration RCT: 1 low,^98^ 2 moderate^85, 139^ (N=221) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for low frequency of dehydration revisits/readmissions associated with partial tonsillectomy 5 readmissions reported across 3 study arms
Total tonsillectomy
PTH and PTH-associated utilization Meta-analysis RCT: 18 low,^43, 53, 56, 69, 75, 89, 90, 93, 98, 120, 123, 125, 131, 134, 144, 151, 163, 169, 170^ 34 moderate^9, 44, 48, 63, 64, 66, 71, 74, 79, 80, 82, 84, 86, 87, 91, 95, 96, 103, 110, 111, 116, 124, 127, 130, 139, 141, 145, 152, 158, 160, 164, 178, 185, 186^ (N=6293) Non-RCT: 4 moderate^195-197, 200^ (N=478) Cohort studies: 2 moderate^213, 292^ (N=350) | Medium | Consistent | Direct | Precise | Undetected | High SOE for low frequency of PTH associated with total tonsillectomy Frequency of <5% of PTH and PTH-associated utilization in both meta-analysis and unadjusted analyses associated with commonly used techniques
Readmissions for pain, PONV, dehydration RCT: 9 low,^43, 66, 69, 93, 103, 114, 123, 125, 134^ 8 moderate^74, 110, 111, 116, 124, 130, 154, 164^ (N=2269) Prospective cohort: 1 moderate^207^ (N=29) Retrospective cohort: 1 moderate^213^ (N=145) | Medium | Consistent | Direct | Precise | Undetected | Moderate SOE for low frequency of non-PTH readmissions/revisits associated with total tonsillectomy In 37 study arms, overall frequency of nonbleeding revisits/readmissions was below 2%; SOE is moderate given smaller sample size

N = number; PTH = post-tonsillectomy hemorrhage; RCT = randomized controlled trial; SOE = strength of the evidence

### KQ5 Effectiveness of Adjunctive Perioperative Medications To Improve Outcomes After Tonsillectomy

#### Key Findings

A variety of medications have been the focus of research including different steroids (dexamethasone, prednisolone); nonsteroidal anti-inflammatory drugs (NSAIDs) including diclofenac, ibuprofen, ketoprofen, lornoxicam, and ketorolac; and antiemetics (ramosetron, granisetron, dolasetron, ondansetron Studies were heterogeneous, addressing multiple agents, combinations of agents, routes of administration and dosage, timing of agents, and rescue medications provided. This heterogeneity limits our ability to draw conclusions about perioperative medications.

NSAIDs. Studies comparing NSAIDs with placebo reported reduced need for analgesia (significant group differences in 4 of 5 studies).^47, 121, 142, 156^ Results in trials comparing NSAIDs vs. other agents were not consistent in terms of effects on need for additional analgesia. A single study found no effect of NSAIDS on reducing anti-emetic use.^161^ NSAIDs were not associated with a faster return to normal diet or activity.^72, 126^ Few studies reported PTH.

Steroids. Most placebo-controlled steroid trials (5/8) found that perioperative intravenous dexamethasone administration reduced the need for analgesics immediately after surgery (postanesthesia care unit [PACU] and up to 24 hours postoperatively), but no longer-term results were reported.^50, 119, 146-148^ Two studies reported that peritonsillar infiltration of dexamethasone also reduced immediate postoperative analgesic requirements (PACU, surgical day ward) compared with placebo.^39, 51^ Five RCTs found perioperative steroid administration decreased postoperative anti-emetic use in the immediate postoperative period (PACU and up to 24 hours postoperatively).^57, 62, 78, 119, 146^ While most studies reported reductions in analgesic or anti-emetic use associated with perioperative steroids, roughly half of studies addressing each outcome reported no group differences. Steroids had little effect on return to normal diet in two RCTs.^112, 135^

Antiemetics. Data were consistent in terms of antiemetic medications. All five trials of 5-hydroxytryptamine (5-HT) receptor antagonists found their administration to have no effect on postoperative analgesic requirements.^88, 118, 122, 132, 133^ Three trials consistently reported reduced postoperative antiemetic requirements in patients treated with intraoperative 5-HT receptor antagonists.^118, 122, 136^

#### Strength of the Evidence

We considered the strength of the evidence for studies with placebo comparison in most cases given the heterogeneity of agents and comparators (Table 53). We considered the drug class (instead of individual agent such as diclofenac) in assessing strength of evidence for NSAIDs and antiemetics. All steroid studies addressed dexamethasone.

NSAIDs. We found a reduced need for analgesia with NSAIDs compared with placebo. Our confidence in this conclusion is low (low strength of evidence). We found no difference in effects on return to normal diet or activity with perioperative NSAIDs compared with placebo. Our confidence in this conclusion is low (low strength of evidence). We found a low frequency of PTH (< 6%) and associated utilization with perioperative NSAIDs. Our confidence in this conclusion is low (low strength of evidence). We could not make conclusions about non-PTH related readmissions or revisits following NSAID use as few studies addressed these outcomes (insufficient strength of evidence).

Steroids. We found a reduced need for analgesics or antiemetics associated with steroids (IV or infiltrated dexamethasone) compared with placebo. Our confidence in this conclusion is low (low strength of evidence). Studies of steroids reported few cases of PTH and PTH-related utilization. We have moderate confidence that steroids are associated with a low frequency of PTH (moderate strength of evidence).

Meta-analysis of nine studies comparing steroids and placebo did not indicate a significantly increased risk of PTH with steroids vs. placebo; confidence bounds were wide for all estimates, and we have low confidence in this conclusion (low strength of evidence). We could not make conclusions about the effects of steroids on return to normal diet or activity, as the two small studies addressing the outcome reported inconsistent results, or on non-PTH-related readmissions or revisits as few studies reported these outcomes (insufficient strength of evidence).

Antiemetics. We found a reduced need for postoperative antiemetics in studies of perioperative antiemetics; our confidence in this conclusion is low (low strength of evidence). We found no effect of 5-HT perioperative antiemetics on postoperative analgesia requirements. We have moderate confidence in this conclusion (moderate strength of evidence). need for postoperative antiemetics given the small number of children evaluated in these studies.

Table 53 Strength of the evidence for studies addressing perioperative medications

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Findings
NSAID vs. Placebo
Need for rescue analgesic RCT: 3 low,^94, 128, 156^ 2 moderate^121, 142^ (N=345) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low SOE for reduced need for rescue analgesia with NSAIDs vs. placebo Significantly less need in 4 small studies, no group differences in a 5th study
Return to Normal diet and activity RCT: 2 moderate^72, 126^ (N=180) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no difference in return to normal diet or activity with NSAIDs vs. placebo No significant group differences in 2 small studies with medium study limitations
PTH and PTH-related revists/readmissions RCT: 1 low,^40^ 5 moderate^47, 106, 117, 150, 161^ (N=277) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for low frequency of PTH or PTH-related revisits/readmissions associated with perioperative dexamethasone Frequency of PTH or associated utilization <3% (unadjusted analyses) in 277 children receiving NSAIDs
Dexamethasone vs. Placebo
Need for rescue analgesic RCT: 4 low, ^50, 105, 119, 146^ 6 moderate^45, 78, 109, 126, 147, 148^ (N=979) | Medium | Inconsistent | Direct | Precise | Undetected | Low SOE for reduction in analgesic need with dexamethasone vs. placebo Significantly less need for analgesics after dexamethasone (IV or infiltration) vs. placebo in 7 small studies; no significant differences in 3 studies; inconsistency precludes higher SOE
Need for rescue anti-emetic RCT: 4 low,^57, 105, 119, 146^ 4 moderate^62, 78, 109, 126^ (N=812) | Medium | Inconsistent | Direct | Precise | Undetected | Low SOE for reduction in anti-emetic need with dexamethasone vs. placebo Significantly less need for antiemetics after dexamethasone vs. placebo in 5 small studies; no significant differences in 3 studies; inconsistency precludes higher SOE
PTH Meta analysis | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no increased risk of PTH with dexamethasone compared with placebo Odds ratios ≥1 with wide credible intervals. SOE is low given imprecision of estimates
Dexamethasone
PTH and PTH-related revists/readmissions RCT: 6 low,^54, 57, 59, 105, 112, 119^ 3 moderate^45, 78, 148^ (N=811) | Medium | Consistent | Direct | Precise | Undetected | Moderate SOE for low frequency of PTH or PTH-related revisits/readmissions associated with perioperative dexamethasone Frequency of PTH or associated utilization <6% (unadjusted analyses) in 811 children receiving steroids
5-HT Antiemetics vs. Placebo or Other Comparators
Need for rescue analgesic RCT: 4 low^88, 118, 132, 133^ 1 moderate^122^ (N=964) | Low | Consistent | Direct | Precise | Undetected | Moderate SOE for no effect of antiemetics (5-hydroxytryptamine [5-HT] receptor antagonists) No significant group differences in 5 RCTs comparing 5-HT antagonists with other antiemetics, other 5-HTantagonists, or placebo
Need for postoperative rescue antiemetic RCT: 2 low^118, 136^ 1 moderate^122^ (N=303) | Low | Consistent | Direct | Imprecise | Undetected | Low SOE for reduced need for postoperative antiemetics with perioperative 5-HT antiemetics vs. placebo Significantly less need for postoperative antiemetics in 3 small RCTs comparing 5-HT antagonists and placebo; imprecision precludes higher SOE

5-HT = 5-hydroxytryptamine; N = number; PTH = post-tonsillectomy hemorrhage; RCT = randomized controlled trial; SOE = strength of the evidence

### KQ6 Effectiveness of Postoperative Medications for Pain After Tonsillectomy

#### Key Findings

Drugs assessed in studies addressing this question included steroids (prednisolone), NSAIDs (diclofenac, ibuprofen, celecoxib, aspirin), non-NSAID analgesics (acetaminophen) and antibiotics (amoxicillin). Few studies addressed the same interventions and comparisons, and studies typically reported on need for rescue pain medication, PTH, and return to normal diet or activity as outcomes. Data on the effect of NSAIDS on rescue pain medication in the first 24 to 48 hours after surgery are conflicting, and no long-term data are available. Two studies compared prednisolone and placebo and found no effect on return to normal diet or activity.^41, 60^

PTH frequency overall was less than 10 percent. The frequency of PTH in steroid and placebo arms in the two studies addressing that comparison were similar.^41, 60^ In studies comparing NSAIDs (celecoxib, ibuprofen) and non-NSAID analgesics to placebo or other medications, occurrences of PTH were also similar.^38, 49, 137, 138, 155, 159, 194^

#### Strength of the Evidence

In studies of postoperative NSAIDs, we found a low frequency of PTH. Our confidence in this estimate is low (low strength of evidence). We could not make conclusions about the effects of postoperative analgesics on need for rescue medications; return to normal diet or activity; or PTH (insufficient strength of evidence).

In studies of postoperative steroids, we found no difference in effects on return to normal diet or activity between steroids and placebo. Our confidence in this conclusion is low (low strength of evidence). We also found no difference in effects on bleeding between postoperative steroids and placebo or no treatment. Our confidence in this conclusion is low (low strength of evidence). Table 54 outlines these findings.

Table 54 Strength of evidence for effectiveness of postoperative medications for pain-related outcomes

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Findings
Prednisolone vs. Placebo
Return to Normal Diet or activity in longer term (≥5 days) RCT: 1 low,^41^ 1 moderate^60^ (N=331) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no difference in effects of prednisolone vs. placebo on return to normal diet or activity Number of children consuming normal diet or engaging in normal activity did not differ at 14 days post-tonsillectomy in one study; time to return to normal diet or activity did not differ in second small RCT
PTH RCT: 1 low,^41^ 1 moderate^60^ (N=331) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no difference in PTH associated with steroids vs. placebo/no treatment Numbers of PTH in steroid and placebo arms were similar in 2 studies (13 PTH in steroid arms vs. 15 in placebo/no treatment)
NSAIDs
PTH RCT: 2 moderate^38, 138^ (N=564) Non-RCT: 1 moderate^194^ (N=115) | Medium | Consistent | Direct | Precise | Undetected | Low SOE for a low frequency of PTH Unadjusted frequency ranged from 0-6% across agents; higher frequency associated with celecoxib; SOE is low given small sample size

RCT = randomized controlled trial; SOE = strength of the evidence

## Findings in Relation to What Is Already Known

We identified 23 recent (2011-present) systematic reviews or meta-analyses assessing tonsillectomy.^23-27, 29-32, 293-306^ Most reviews or meta-analyses (n=9) addressed perioperative medications and PTH risk or other morbidity: three addressed NSAIDs^30-32^ five addressed dexamethasone;^24-27, 29^ and one addressed antibiotics.^23^ Two reviews addressed tonsillectomy for recurrent tonsillitis;^302, 303^ seven addressed tonsillectomy for OSDB (including one comparing partial and total tonsillectomy in children with OSDB and two comparing outcomes among children with or without OSA or with obesity)^296-301, 306^ and five addressed partial vs. total tonsillectomy or specific surgical techniques.^293-295, 304, 305^

Across reviews, investigators commented on methodologic limitations such as lack of blinding and limited allocation concealment; heterogeneity of techniques and indications for tonsillectomy; use of subjective outcome measures; short-term followup; small sample sizes; and generally low to moderate quality studies. Appendix I includes an overview of findings of all reviews. Findings in prior reviews and meta-analyses generally aligned with our findings in the current report. Reviews of tonsillectomy specifically in children with OSDB or tonsillitis reported modest benefits in obstructive symptoms or sore throat reduction, typically in the short-term, for tonsillectomy compared with no surgery. Reviews comparing partial and total tonsillectomy reported few differences between techniques: partial tonsillectomy was generally associated with faster return to normal diet and activity and less PTH, but changes in resolution of OSDB symptoms or recurrent throat infections were not significantly different between approaches. Reviews comparing surgical techniques (e.g., coblation, electrocautery) similarly reported few significant differences among techniques. Reviews of perioperative steroids consistently reported no significant association with PTH in children, though one review reported greater need for reintervention when PTH occurred. Reviews of perioperative NSAIDs and PTH risk were less consistent, with two reporting no increased risk in children and one noting insufficient data to rule out risk. One review of antibiotics reported no evidence for a consistent effect of antibiotics on pain, PTH, or need for pain medications. Finally, in one review assessing weight gain in a general population of normal and overweight children undergoing tonsillectomy, participants gained more weight than expected postoperatively.

## Applicability

Studies included in this review typically did not describe severity of indications of tonsillectomy and comorbidities for populations adequately, which makes applicability difficult to assess. As would be expected, studies addressing KQ1 (tonsillectomy in children with OSDB) and KQ2 (tonsillectomy in children with recurrent throat infection) specified surgical indication and generally provided greater characterization of study participants. Baseline severity of OSDB or throat infection varied across these studies as did definitions of “cure” or resolution of symptoms. Of note, the largest U.S.-based RCT addressing tonsillectomy vs. no surgery for children with OSDB included a majority African-American and majority overweight or obese population^171-178, 191^ as did two additional studies addressing this comparison.^114, 211^ Two other studies addressing this comparison included a majority of children with Down syndrome or mucopolysaccharidoses^44^ or children under 2 years of age.^212^ RCTs addressing tonsillectomy vs. no surgery for recurrent throat infection explicitly included children with mild to moderate baseline symptoms, and definitions of “throat infection” varied across studies.^164-166, 307^ Two larger studies addressing this comparison (2 studies reported in one paper) included majority white populations.^9^

Studies addressing surgical approaches and peri- or post-operative medications typically did not specify surgical indications or included both children with OSDB or recurrent throat infections without stratifying analyses. Roughly one-third of studies were conducted in less developed countries in which surgical techniques and procedures may differ from those used in the United States. Regardless of the country in which studies were performed, anesthetic approaches, analgesic agents and dosing, surgical expertise, and surgical and hemostatic techniques (including definitions of “partial tonsillectomy”) varied widely across studies. Studies reporting weight or BMI typically did not address whether children were under- or over- weight for age at baseline, and few studies reported baseline comorbidities such as asthma or Down syndrome; thus assessing applicability to these sub-populations is challenging. Most studies used subjective outcome measures or relied on caregiver- or child-completed diaries to assess longer-term outcomes. Objective measures such as the AHI or other PSG parameters may not accurately reflect effects on the totality of symptoms associated with OSDB (e.g., behavioral issues, sleepiness, overall quality of life).^173, 175, 308, 309^ We also included only studies addressing tonsillectomy for the two most common indications for the surgery: OSDB and recurrent throat infection; thus, individuals seeking information about tonsillectomy for Periodic Fever, Aphthous Stomatitis, Pharyngitis, Cervical Adenitis (PFAPA) or other indications will not find applicable studies in the current review.

Despite these limitations to generalizability, findings reported here are likely widely applicable given the heterogeneous population of children without comorbidities who undergo tonsillectomy for OSDB or recurrent throat infection. Applicability of findings to children with Down syndrome, craniofacial abnormalities, obesity, or under age 2 is limited. Although studies included some children with these comorbidities or in the younger age range, few provided explicit analyses of these subgroups. Appendix G includes applicability tables for each KQ.

## Implications for Clinical and Policy Decisionmaking

This review provides evidence for decisionmaking in the care of children who are potential candidates for tonsillectomy. Despite the large body of literature, most evidence addresses effects in the short term. The literature reports short-term improvements in obstructive symptoms and throat infections following tonsillectomy compared with no surgery. Evidence about long-term benefits of tonsillectomy for either OSDB or throat infection is limited. Thus, individual decisionmaking needs to balance needs for relief of illness-related outcomes (including missing school and work) with the risks associated with surgery. Caregivers and providers may wish to consider the potential benefits and drawbacks of attempting to manage children's illnesses for a period of time to see if they outgrow the propensity for infection and may be able to avoid surgery. That said, shared decisionmaking rests in the hands of families and their clinicians, and decisions should be made on an individual basis. Harms are rare and generally minor, and clinicians have information from this review with which to counsel their patients and families.

In cases where families are considering surgery or CPAP for OSDB, comparative evidence is currently inconclusive to inform decisionmaking. Families with children in special subgroups, including those with Down syndrome, similarly cannot rely solely on currently available scientific evidence for their decision as few studies address these populations explicitly. Data on specific approaches to tonsillectomy (either partial versus total or by surgical technique) offer little clear guidance for clinicians. Some evidence suggests that partial removal may speed time to return to normal diet or activity relative to total removal; however, we found a roughly 6 percent rate of regrowth with partial tonsillectomy. PTH typically occurred in less than 5 percent of children across all surgical techniques, and no clear evidence exists for a superior approach. Familiarity with a technique and surgical skill may both have a role in driving outcomes, as has been demonstrated in other fields.^310-312^

Decisional dilemmas still exist regarding the perioperative use of medications and whether they speed postoperative return to normal diet and activity and reduce the need for post-tonsillectomy analgesia and rescue antiemetic use. Clinical care would be improved by optimizing perioperative use of medication to improve outcomes. The literature base on this subject was insufficient to inform guidance on whether any perioperative medications affect time to normal diet or activity. Low strength of evidence suggested that a single dose of IV dexamethasone intraoperatively reduces analgesic requirement in the PACU and up to 24 hours postoperatively. Evidence is mixed as to whether dexamethasone reduces the need for postoperative rescue antiemetics. In contrast, clinicians can have some confidence that pre-emptive 5-HT receptor antagonists given intra-operatively do reduce the need for rescue antiemetics post-tonsillectomy.

## Limitations of the Comparative Effectiveness Review Process

We included studies published in English only. We scanned a random sample of 100 non-English abstracts retrieved by our MEDLINE search (25 selected from each decade 1980 to 2015). Most studies appeared to be case series, narrative reviews, imaging or basic science studies, or studies dealing with malignant lesions. Only two studies appeared to meet inclusion criteria; thus, given the high percentage of ineligible items in this scan (98%), we concluded that excluding non-English studies would not introduce significant bias into the review.

We also included only studies of perioperative NSAID, steroids, and antiemetics to address KQ5. Although this focus means that some medications are not included in this review, the drug classes addressed in the review comprise key agents frequently used in the perioperative period. We also did not include studies addressing adenoidectomy alone or studies comparing tonsillectomy with adenoidectomy as the choice of procedure is likely driven by the indication for surgery; thus, comparing these approaches would not be appropriate.

Given heterogeneity in anesthetic regimens, surgical techniques, postoperative analgesia and medications, and patient populations themselves, we were limited in our ability to stratify findings or identify potential subgroups that may respond more favorably to tonsillectomy or to supportive care.

## Limitations of the Evidence Base

A relatively large number of studies have been published on tonsillectomy, including for OSDB and throat infections, but risk of bias is mixed, with fewer studies (31%) having low risk of bias than moderate or high risk. Furthermore, most available studies provided little to no clinical outcome data, focusing instead on intermediate outcomes and harms. In addition, few studies addressed questions about the need for tonsillectomy compared with a nonsurgical treatment. Patient populations were generally poorly characterized, and little information was available on first-line treatment attempts before surgery. Very few studies focused on high risk or special populations at particular risk.

Particularly in studies intended to assess effects of tonsillectomy on throat infections, parents of severely affected children were noted to refuse randomization and cross over to surgery at high rates. Long-term effects are limited in the literature base, particularly regarding outcomes that include growth and development, sleep quality outcomes, and behavioral outcomes for children with OSDB. Exploration of demographics of patient populations more likely to be refractory to initial management strategies is also limited. It appears clear that throat infections decline in children over time regardless of treatment group, but with high loss to followup, the relative contribution of this decline on apparent effectiveness is unknown.

A particular problem in the literature is a lack of full characterization of the patient population, particularly about clinically documented severity of both sleep-disordered breathing and throat infections. Understanding of “obstructive sleep disordered breathing” varied from study to study as did degree of hypertrophy and number and severity of throat infections or sore throats. In the context of general lay expectations of the benefit of tonsillectomy, and common opinions that tonsillectomy is a “minor” surgery, patients undergoing tonsillectomy may vary widely in the severity of their clinical states. Among those studies focused on throat infection that did characterize patients, most had low numbers of reported infections, and few reported culture-confirmed bacterial infections.

Of particular importance for this surgical topic is a complete assessment of potential harms, particularly frequency of PTH, including PTH that leads to further intervention. However, the severity or degree, number of repeat episodes, and timing of PTH were rarely defined or measured; thus outcomes can be broadly defined only in terms of primary versus secondary PTH, readmissions, and reoperations, where reported. Our estimates include PTH as reported in eligible studies, which could have ranged from parent-reported bleeding that did not require a clinician visit to PTH requiring surgical hemostasis. Few studies of postoperative medications for pain met our inclusion criteria as we did not identify many comparative studies with low or moderate risk of bias; thus, evidence in the current review is inadequate to draw firm conclusions about PTH associated with postoperative NSAIDs.

In attempting to assess partial versus total tonsillectomy we note that partial tonsillectomy was rarely precisely specified. These studies also most often used different techniques for the partial and total tonsillectomy, thus introducing confounding that cannot be disentangled.

## Research Gaps and Areas for Future Research

Tonsillectomy is heavily researched, with far more data available to assess safety than efficacy. Despite substantial research, the literature is largely silent on the natural history of OSDB or throat infections that would provide a basis for the need for tonsillectomy in the long term. Many young patients may outgrow the need for intervention, but more data are needed to describe the potential to outgrow these indications to parents and to describe population factors that may predict resolution.^175, 313, 314^ Indeed, in many studies, outcomes for children in nonsurgical groups also improved, though improvements were generally greater in children receiving tonsillectomy. Long-term data are needed in order to enable caregivers to weigh the benefits of surgery versus the reality of managing their child's condition as they wait for it to resolve; obtaining longer-term data, however, is difficult, as evidenced by the high rate of attrition in most studies with more than 6 months followup included in this review.

Future studies should take more care to characterize patient populations completely—including severity of OSDB or throat infections—such that applicability can be much more specifically described and potential candidates for surgery or watchful waiting identified. Indeed the literature lacks a consistent, consensus definition of infection; defining infection consistently is critical for promoting synthesis of research in the area. Tonsillitis or “sore throat” may also include cases of entities such as PFAPA; clear characterization of children in studies is key for understanding effects on subpopulations.

Similarly, studies also typically did not clearly characterize severity of PTH, and many did not clearly specify timing or number of repeat episodes. Severity of bleeding or repeat episodes may be more predictive of serious morbidity than simple frequency; ^251, 315-317^ however, our ability to assess this association was limited. Improved characterization could allow analyses to inform our understanding of factors that may contribute to revisits or readmissions and outcomes such as mortality.

As new technologies for tonsillectomy emerge, as they continuously have over the past few decades, high quality research will continue to be needed to evaluate these technologies, in terms of both efficacy and safety. As we learn more about the deleterious effects of sleep apnea and detection rates increase, more refined and specific treatment algorithms will be in demand. Related to this issue, more data are needed on the use of CPAP in children as an initial modality; such data should address compliance and duration of use.

Future research should also address the current gaps in data surrounding treatment of special populations including very young children and children with comorbidities such as obesity and neuromuscular disease. Further, concerns about perioperative and postoperative management persist, including over-narcotization and potential respiratory suppression. Better data regarding optimal medication regimens are essential, both in terms of symptomatic relief and minimizing iatrogenic harm.

Measures commonly used to assess objective improvements in obstructed breathing, such as the AHI, are not patient-centered and may not reflect subjective reports of improvements or worsening of outcomes experienced by patients. Future research exploring the alignment of the AHI with patient-reported outcomes such as quality of life would help to gauge effects of tonsillectomy more precisely. Additionally, standardized measures of sleep outcomes are lacking.

Finally, relatively little data exist regarding predictable factors contributing to recurrence of symptoms of OSDB and throat infections following tonsillectomy for primary management. A better understanding of these factors would allow for more specific patient selection.

## Conclusions

Tonsillectomy can produce short-term improvement in sleep outcomes and reduction in throat infections compared with no surgery in children with OSDB or recurrent throat infections. Relative to no surgery, most studies reported better sleep-related outcomes in children with OSDB who had a tonsillectomy, but longer term data on durability of outcomes are limited. Children undergoing tonsillectomy to improve number of throat infections, associated health care utilization (clinician visits), and work/school absences had improvements in these outcomes in the first postsurgical year compared with children not receiving surgery. These benefits did not persist over time, and data on longer-term results are lacking. This short-term improvement must be weighed against a roughly 4 percent frequency of PTH. Surgical technique had little bearing on either return to normal diet or activity or PTH frequency. Perioperative dexamethasone improved pain and pre-emptive 5-HT receptor antagonist antiemetics reduced antiemetic use in the immediate postoperative period. Dexamethasone did not increase risk of PTH compared with placebo, but estimates had wide confidence bounds. Little evidence addressed the use of postoperative medications for pain-related outcomes.