# Appendix I Summary of Existing Systematic Reviews

Table I-1 Existing reviews of surgical interventions for OSDB/SDB (7 reviews)

Author, Year | Intervention Category | Inclusion Criteria | Outcome(s) | # Included Studies | Key Findings
Song et al. 2016^1^ | Tonsillectomy or Adenotonsillectomy (T&A); OSA in children | - Children <18 years; - Prospective studies; - Literature search database inception to 2015; - Included studies published 1996 to 2014 | - Neurocognitive function; - AHI | 19 studies with 898 children | - There was a reduction in AHI after T&A in children with SDB across studies; - Improvement in neurocognitive function and IQ after T&A; - Decreased effectiveness of T&A in older children suggests a threshold age when neurocognitive deficits become irreversible
De Luca Canto et al. 2015^2^ | Adenotonsillectomy (AT); OSA in children | - Children 0 to 18 years; - Clinical studies with postop evaluation within 3 weeks after AT; - Literature search up to 2015; - Included studies published 1987 to 2015 | - Postop complications that required intervention including respiratory, hemorrhage, pain, NV, refusal to drink, inadequate oral intake, dehydration, fever, dysphagia, cardiac | 23 studies with 13537 children | - Most frequent postop complication was respiratory compromise at 9.4% followed by secondary hemorrhage at 2.6% and primary hemorrhage at 2.4%; - Children with OSA have 5 times more respiratory complications after AT than children without OSA (across only 4 studies with 9394 children); - Bleeding is more likely to occur among children without OSA compared to children with OSA (across only 4 studies with 9394 children)
Lee et al. 2015^3^ | Adenotonsillectomy (T&A); OSA in obese and non-obese children | - Children <18 years; - Obese and non-obese children with OSA; - RCTs, retrospective observational case series, NRCTs; - Literature search published up to 2014; - Included studies 1994 to 2014 | - PSG parameters; - Residual OSA postop | 51 studies with 3413 children | - Residual OSA remained in ∼1/2 the children especially those with severe OSA and obesity after T&A; - Postop improvements in non-obese exceeded obese children; - Postop T&A saw increased sleep efficiency, slow wave sleep, oxygen saturation, spontaneous arousals; - Postop T&A saw decreased REM and non-REM AHI, number and severity of respiratory events, and total arousals; - T&A postop saw a prominent decrease in AHI by 12.4 events/hr
Van et al. 2015^4^ | Adenotonsillectomy (T&A); OSA in children | - Children 0 to 14 years; - Children with OSA; - RCTs, observational; - Literature search 1995 to 2014; - Included studies published | - BMI; - Weight percentiles | 6 studies with 729 children | - Evidence for significant weight gain in short term following T&A in children with OSA regardless of initial weight status
Venekamp et al. 2015^5^ | Tonsillectomy or adenoidectomy; OSDB in children | - Children 2 to 16 years with OSDB; - RCTs; - Literature search from database inception to 2015; - Included studies published 2004 to 2014 | Primary; - Disease-specific quality of life; - Adverse events, complications and morbidity; - Intraoperative and postoperative bleeding; - Postoperative infection, dehydration, and pain; Secondary; - Generic quality of life; - Respiratory events; - Cardiovascular complications; - Neurocognitive performance, attention, behavior, school performance, absence from school and weight changes | 3 studies with 562 children Study 1: 453 children with mild to moderate OSAS (adenotonsillectomy vs. no surgery) Study 2: 29 children with symptoms/signs of OSDB (adenotonsillectomy vs. no surgery) Study 3: 80 children with Down Syndrome or mucopolysaccharidosis and mild to moderate OSAS (adenotonsillectomy vs. CPAP) | - Only 3 included studies; - Disease-specific QoL mean scores were lower (better or fewer symptoms) at 7 months after adenotonsillectomy compared to watchful waiting in one study (CHAT Trial); - Mean OSAS QoL at 12 months did not differ significantly between adenotonsillectomy vs. CPAP(Sudarsan Trial); - Mean ESS score did not differ at 6 months, but was lower in adenotonsillectomy group at 12 months in one study (Sudarsan Trial); - 15 children (3%) had a serious adverse event (CHAT Trial)
Walton et al. 2015^6^ | Intracapsular tonsillectomy or Total tonsillectomy; SDB in children | - Children <16 years; - Children with SDB; - RCTs; - Included studies published 1999 to 2010 | - Postop pain; - Analgesic use; - Recovery time; - Diet; - Bleeding rate; - Infection; - Regrowth rate requiring further surgical intervention | 16 studies with 1312 participants (699 in the partial tonsillectomy group and 635 in the TT group) | - Secondary hemorrhage rate and number of days until pain free were superior in the IT group than the TT group; - Formal meta-analysis was not conducted due to lack of raw data reporting within individual studies
Wang et al. 2015^7^ | Tonsillectomy or Tonsillotomy; SDB in children | - Children birth to 18 years; - Sleep disordered breathing; - Studies compared tonsillotomy and tonsillectomy directly; - Prospective studies; - Literature search up to 2014; - Included studies published 1999 to 2014 | - Operation time, secondary postop bleeding, pain-free days, PSG outcomes, QoL, immune function, rate of SBD recurrence | 10 studies with 1029 children | - Tonsillotomy had lower hemorrhage rate, shorter operation time, and more pain-free days over tonsillectomy; - No significant difference in QoL, Postop immune function, and resolving obstructive symptoms

AHI= Apnea Hypopnea Index ; BMI=Body Mass Index; CPAP=Continuous Positive Airway Pressure; OSA=Obstructive Sleep Apnea; OSAS= Obstructive Sleep Apnea Syndrome ; PSG=Polysomnography; QoL=Quality of Life; RCT=Randomized Controlled Trials; SDB=Sleep Disordered Breathing; TT=Total Tonsillectomy

Table I-2 Existing reviews of surgical interventions for tonsillitis/throat infections (2 reviews)

Author, Year | Intervention Category | Inclusion Criteria | Outcome(s) | # Included Studies | Key Findings
Burton et al. 2014^8^ | Tonsillectomy or adenotonsillectomy; Chronic/recurrent acute tonsillitis | - Children and adults with diagnosed recurrent acute tonsillitis or chronic tonsillitis; - RCTs; - Literature search up to 2014; - Included studies with children published 1984 to 2010 | Primary; - Number/severity of episodes of tonsillitis/sore throat; - Number of days with sore throat; - Morbidity/mortality of surgery (include complications and no. days with postop pain from surgery); Secondary; - Consumption of antibiotics, analgesics; - Absence/time off work/school; - QoL | 5 studies with 987 children only; 3 studies with 196 adults only | - Demonstrated moderate reduction in number of episodes of sore throat during first year postop
Georgalas et al. 2014^9^ | Tonsillectomy; Acute recurrent or Chronic throat infections | - RCTs, Published systematic reviews of RCTs; - Literature search 1966 to 2014; - Included SRs published 2001 to 2010 | - Episodes of tonsillitis or sore throat; - Time off school or work; - Surgery: bleeding (intraoperative and postop); - Surgery: postop pain (includes analgesia use) | 15 studies/SRs | - Findings that tonsillectomy is more beneficial in children with severe symptoms, and only modestly beneficial for children with low incidence of tonsillitis; - Diathermy is associated with reduced rates of primary bleeding, but increased rates of secondary bleeding

RCT=Randomized Controlled Trials; SR=Systematic Review

Table I-3 Existing reviews of surgical approach or technique (5 reviews)

Author, Year | Intervention Category | Inclusion Criteria | Outcome(s) | # Included Studies | Key Findings
Acevedo et al. 2012^10^ | Tonsillotomy or Tonsillectomy | - Children and adults; - RCTs, Observational; - Literature search 2010 to 2011; - Included studies published 1999 to 2010 | Primary; - Postop bleeding rate; - Rate of dehydration requiring medical care; Secondary; - Days of analgesic use; - Days to return to normal diet; - Est. intraoperative blood loss | 39 studies with 14707 children and adults | - Tonsillotomy had lower postop bleeding rate, postop dehydration rate requiring medical care, reduced days of analgesic use, and reduced days to return to normal diet; - No clinically significant difference in intraoperative blood loss; - Subgroup analysis suggests that coblation technique confers more of an advantage than microdebrider for postop complications; - Data not sufficient to assess tonsil regrowth rates
Jeyakumar et al. 2011^11^ | Adenotonsillectomy (T&A) or Tonsillectomy | - Children 0 to 10 years; - Children of normal weight or overweight; - Prospective studies; - Literature search 1970 to 2009; - Included studies published 1988 to 2009 | - Postop BMI vs. control group BMI; - % of weight gain greater than expected postop; - Change in weight pre-op to postop | 9 studies with 795 children | - A large number of normal weight and overweight children gained a greater than expected amount of weight after T&A
Alexiou et al. 2011^12^ | Tonsillectomy (Vessel Sealing Systems (VSS) (e.g., LigaSure Vessel Sealing System,Thermal Welding System,BiClamp)) or Harmonic Scalpel or Coblation (e.g., Cold Steel (CS), Electrocautery Dissection (EC)) | - Children and Adults; - RCTs; - Literature search database inception to 2010; - Included studies published 2001 to 2011 | - Operative time; - Intraoperative and Postop bleeding (primary and secondary); - Postop pain | 33 studies with 3139 patients (11 studies with children only; 8 studies with adults only; 14 studies with mixed population) | - VSS group postop bleeding was significantly less than Conventional techniques in 792 patients; - Postop pain was significantly less on the 1^st^ and 7^th^ days in the VSS group in 740 patients; - No difference in outcomes between Coblation and CS/EC groups; - Included studies with weak evidence maintaining a lower threshold for inclusion in meta analysis
Mösges et al. 2011^13^ | Tonsillectomy (Coblation) | - Children and Adults; - RCTs, prospective studies; - Literature search dates NR; - Included studies published 2001 to 2009 | - Postop hemorrhage (primary and secondary) | 24 studies with 796 patients (461 children and 335 adults) | - Postop hemorrhage rate for children is 2.9%; - Primary hemorrhage rate for children was 1% and secondary hemorrhage rate was 6.2% postop
Pinder et al. 2011^14^ | Tonsillectomy (Dissection or Diathermy) | - Children and Adults; - RCTs; - Literature search from 1966 to 2010; - Included studies published 1997 to 2000 | Primary; - Intraoperative blood loss; - Primary and secondary hemorrhage; Secondary; - Pain control with need of analgesia and use of validated pain scores; - Time before resuming normal activities; - Operating time | 2 studies with 254 children and adults | - No difference in rate of secondary postop bleeding overall; - Studies demonstrated increased pain in diathermy group compared to dissection group

CS=Cold Steel, EC=Electrocautery Dissection, RCT=Randomized Controlled Trials; T&A= Adenotonsillectomy, VAS=Visual Analog Scale, VSS= Vessel Sealing Systems

Table I-4 Existing reviews of perioperative medications (9 reviews)

Author, Year | Intervention Category | Inclusion Criteria | Outcome(s) | # Included Studies | Key Findings
Bellis et al. 2014^15^ | Dexamethasone (Tonsillectomy) | - Children up to 18 years; - RCTs and quasi-RCTs; - During perioperative period (24 hrs prior, during procedure, or 24 hrs postop); - Included studies published 1991-2012 | - Hemorrhage rate | 61 studies with 13933 children | - No significant increase in risk of post-tonsillectomy hemorrhage; - Clinical heterogeneity was noted across studies; - Inadequate evidence due to majority of studies not designed to investigate post-tonsillectomy hemorrhage with use of dexamethasone; - Overall ROB was high or unclear for all RCTs
Plante et al. 2012^16^ | Dexamethasone or Prednisolone (Tonsillectomy) | - Adults and children; - RCTs; - Literature search 1947 to 2011; - Included studies published 1991 to 2011 | Primary; - Incidence of postop bleeding; Secondary; - Incidence of admission for bleeding episodes; - Operative interventions for bleeding episodes; - Red blood cell transfusion; - Mortality | 29 studies with 2674 patients (19 studies with children only, 6 studies with adults only, 4 studies included mixed population) | - Administration of steroids did not increase the incidence of bleeding postop; - The incidence of admission due to bleeding did not increase in steroid group compared to control group; - The incidence for operative re-intervention for bleeding was significantly increased in the steroid group compared to control group; with a significant increase of re-interventions in children (8 studies) but not in adults (4 studies); - No dose effect was observed; - Dexamethasone was used in 28 studies and Prednisolone used in 1 study
Shargorodsky et al. 2012^17^ | Dexamethasone (Tonsillectomy or Adenotonsillectomy) | - Children ≤18 years; - RCTs; - Dexamethasone administration preop or intraoperatively; - Literature search from 1990 to 2010; - Included studies published 1991 to 2009 | - Primary and secondary hemorrhage | 12 studies with 1180 children | - No significant association between dexamethasone at any dose and bleeding compared to placebo; - No significant association between increasing dosage and bleeding; - Doses on 0.4 to 0.6 mg/kg showed significantly increased odds of bleeding compared to placebo
Geva et al. 2011^18^ | Dexamethasone (Tonsillectomy) | - Children and Adults; - RCTs; - Literature search up to 2009; - Included studies published 1991 to 2008 | - Intraoperative and postop bleeding; - Bleeding requiring reoperation | 14 studies with 1429 children and adults (11 studies with 1166 children only, 3 studies with 263 adults only) | - No significant increase in postop bleeding between patients receiving dexamethasone and control patients across mixed population; - Younger patients receiving dexamethasone resulted in a statistically nonsignificant decrease in the risk of postoperative bleeding
Steward et al. 2011^19^ | Dexamethasone (Tonsillectomy) | - Children 9 months to 18 years; - RCTs; - Literature search up to 2010; - Included studies published 1991 to 2009 | - Number of children experiencing emesis during 24 hrs postop; - Number of children return to solf/solid diet by day 1 postop; - Pain at 24 hrs measured by VAS | 19 studies with 1756 children | - ROB in included studies was not formally assessed; - Statistically significant reduction in emesis during the 1^st^ 24 hrs postop compared to placebo group; - Statistically significant increase in the number of children return to soft/solid diet 1 day postop compared to placebo; - Statistically significant improvement in postop pain compared to placebo using VAS as measurement
Chan et al. 2014^20^ | Ketorolac (NSAID) (Tonsillectomy) | - Children and Adults; - RCTs, retrospective case-control studies; - Literature search from 1970 to 2013; - Included studies published 1995 to 2004 | - Postop hemorrhage | 10 studies with (7 studies with children only, 2 studies with mixed population, 1 study adults only) | - Children under 18 are not at statistically significantly increased risk for postop hemorrhage with ketorolac use
Lewis et al. 2013^21^ | NSAIDs (Tonsillectomy or Adenotonsillectomy) | - Children up to and including 16 years; - RCTs; - Literature search from database inception to 2012; - Included studies published 1995 to 2011 | - Bleeding; - Postop complications | 15 studies with 1101 children | - Use of NSAIDs was associated with a non-significant increase in the risk of bleeding requiring surgical intervention; - NSAIDs did not significantly alter the number of perioperative bleeds requiring non-surgical intervention; - NSAIDs benefit a reduction of vomiting; - Insufficient evidence to exclude an increased risk of bleeding when NSAIDs are used
Riggin et al. 2013^22^ | NSAIDs (Tonsillectomy) | - Children and adults who underwent tonsillectomy; - RCTs; - Literature search from database inception to 2012; - Included studies published 1984 to 2012 | - Postop hemorrhage; - Secondary hemorrhage; - Bleeding requiring readmission, reoperation, or tranexamic acid | 36 studies with 1747 children and 1446 adults | - No increased risk of bleeding in those using NSAIDs after tonsillectomy; - Use of NSAIDs in children was not associated with increased risk of general bleeding, most severe bleeding, secondary hemorrhage, readmission or need of reoperation due to bleeding; - In pediatrics population, overall odds ratio of bleeding was lower than general population (including adults) and not significant
Dhiwakar et al. 2012^23^ | Antibiotics (Tonsillectomy or Adenotonsillectomy) | - Children and adults undergoing tonsillectomy or adenotonsillectomy; - RCTs; - Antibiotic administration 48 hrs pre-op, intraoperatively, postop; - Literature search from database inception to 2012; - Included studies published 1986 to 2008 | - Pain; - Consumption of analgesia; - Secondary hemorrhage; - Fever; - Time to resume normal diet/activities; - Adverse events (e.g., rash, anaphylaxis, candidiasis, diarrhea) | 10 studies with 1035 children and adults | - No evidence to support clinically important impact of antibiotics in reducing pain , need for analgesia, and secondary hemorrhage rates; - No significant reduction in pain with antibiotics; - Mostly not shown to be effective in reducing need for analgesics; - Not associated with reduction in significant secondary hemorrhage rates; - Antibiotics reduced the proportion of patient with fever

AHI=Apnea-Hypopnea Index, AT=Adenotonsillectomy, CPAP= Continuous positive airway pressure, CS=Cold Steel, EC=Electrocautery Dissection, ESS=Epworth Sleepiness Scale, NSAIDs=Non-steroidal anti-inflammatory drugs, OSDB=Obstructive sleep-disordered breathing, QoL=Quality of life, RCTs=Randomized controlled trials, ROB=Risk of bias, RR=Pooled Relative Risk, SBD=Sleep disordered breathing, T&A= Adenotonsillectomy, VAS=Visual Analog Scale, VSS= Vessel Sealing Systems

## References

1 Song SA, Tolisano AM, Cable BB, et al. (2016). Neurocognitive outcomes after pediatric adenotonsillectomy for obstructive sleep apnea: A systematic review and meta-analysis. Int J Pediatr Otorhinolaryngol.
2 De Luca Canto G, Pacheco-Pereira C, Aydinoz S, et al. (2015). Adenotonsillectomy Complications: A Meta-analysis. Pediatrics.
3 Lee CH, Hsu WC, Chang WH, et al. (2015). Polysomnographic Findings after Adenotonsillectomy for Obstructive Sleep Apnea in Obese and Non-Obese Children: A Systemic review and Meta-Analysis. Clin Otolaryngol.
4 Van M, Khan I, Hussain SS. (2015). Short-term weight gain after adenotonsillectomy in children with obstructive sleep apnoea: systematic review. J Laryngol Otol.
5 Venekamp RP, Hearne BJ, Chandrasekharan D, et al. (2015). Tonsillectomy or adenotonsillectomy versus non-surgical management for obstructive sleep-disordered breathing in children. Cochrane Database Syst Rev.
6 Walton J, Ebner Y, Stewart MG, et al. (2012). Systematic review of randomized controlled trials comparing intracapsular tonsillectomy with total tonsillectomy in a pediatric population. Arch Otolaryngol Head Neck Surg.
7 Wang H, Fu Y, Feng Y, et al. (2015). Tonsillectomy versus tonsillotomy for sleep-disordered breathing in children: a meta analysis. PLoS One.
8 Burton MJ, Glasziou PP, Chong LY, et al. (2014). Tonsillectomy or adenotonsillectomy versus non-surgical treatment for chronic/recurrent acute tonsillitis. Cochrane Database Syst Rev.
9 Georgalas CC, Tolley NS, Narula PA. (2014). Tonsillitis BMJ Clin Evid.
10 Acevedo JL, Shah RK, Brietzke SE. (2012). Systematic review of complications of tonsillotomy versus tonsillectomy. Otolaryngol Head Neck Surg.
11 Jeyakumar A, Brickman TM, Williamson ME, et al. (2008). Nonsteroidal anti-inflammatory drugs and postoperative bleeding following adenotonsillectomy in pediatric patients. Arch Otolaryngol Head Neck Surg.
12 Alexiou VG, Salazar-Salvia MS, Jervis PN, et al. (2011). Modern technology-assisted vs conventional tonsillectomy: a meta-analysis of randomized controlled trials. Arch Otolaryngol Head Neck Surg.
13 Mosges R, Hellmich M, Allekotte S, et al. (2011). Hemorrhage rate after coblation tonsillectomy: a meta-analysis of published trials. Eur Arch Otorhinolaryngol.
14 Pinder DK, W H, Hilton MP. (2011). Dissection versus diathermy for tonsillectomy (Review). Cochrane Database of Systematic Reviews.
15 Bellis JR, Pirmohamed M, Nunn AJ, et al. (2014). Dexamethasone and haemorrhage risk in paediatric tonsillectomy: a systematic review and meta-analysis. Br J Anaesth.
16 Plante J, Turgeon AF, Zarychanski R, et al. (2012). Effect of systemic steroids on post-tonsillectomy bleeding and reinterventions: systematic review and meta-analysis of randomised controlled trials. Bmj.
17 Shargorodsky J, Hartnick CJ, Lee GS. (2012). Dexamethasone and postoperative bleeding after tonsillectomy and adenotonsillectomy in children: A meta-analysis of prospective studies. Laryngoscope.
18 Geva A, Brigger MT. (2011). Dexamethasone and tonsillectomy bleeding: a meta-analysis. Otolaryngol Head Neck Surg.
19 Steward David L, Grisel J, Meinzen-Derr J. (2011). Steroids for improving recovery following tonsillectomy in children. Cochrane Database of Systematic Reviews.
20 Chan DK, Parikh SR. (2014). Perioperative ketorolac increases post-tonsillectomy hemorrhage in adults but not children. Laryngoscope.
21 Lewis Sharon R, Nicholson A, Cardwell Mary E, et al. (2013). Nonsteroidal anti-inflammatory drugs and perioperative bleeding in paediatric tonsillectomy. Cochrane Database of Systematic Reviews.
22 Riggin L, Ramakrishna J, Sommer DD, et al. (2013). A 2013 updated systematic review & meta-analysis of 36 randomized controlled trials; no apparent effects of non steroidal anti-inflammatory agents on the risk of bleeding after tonsillectomy. Clin Otolaryngol.
23 Dhiwakar M, Clement WA, Supriya M, et al. (2012). Antibiotics to reduce post-tonsillectomy morbidity. Cochrane Database Syst Rev.