# Appendix H Detailed Tables of Findings

## Bleeding-Related Harms in Comparative Studies Addressing Tonsillectomy

Table H-1 Postoperative hemorrhage reported in comparative study arms addressing total tonsillectomy

Technique | Indication Author, Year | Total Arm N | Total PTH | Primary PTH n (%) | Secondary PTH n (%) | Other/Undefined PTH n (%) | Nonoperative Revisit or Readmission for PTH n (%) | Reoperation for PTH n (%)
Coblation | OSDB
Coblation | Sudarsan 2014^1^ | 37 | 2 | NR | 2 (5.4) | NR | NR | NR
Coblation | Paramasivan 2012^2^ | 50 | 1 | 1 (2) | 0 | NR | NR | NR
Coblation | Chang 2008^3^ | 35 | 1 | NR | NR | 1 (2.9) | NR | 1 (2.9)
Coblation | D'Eredita 2009^4^ | 74 | 1 | NR | NR | 1 (1) | 1 (1) | NR
Coblation | Throat Infection
Coblation | Salama 2012^5^ | 75 | 3 | NR | 3 (10) | NR | 0 | NR
Coblation | Elbadawey 2015^6^ | 40 | 1 | NR | 1 (2.5) | NR | NR | NR
Coblation | Hegazy 2008^7^ | 40 | 0 | NR | 0 | NR | NR | NR
Coblation | Temple 2001^8^ | 18 | 0 | NR | NR | 0 | NR | NR
Coblation | Di Renzo 2008^9^ | 21 | 0 | NR | NR | 0 | NR | NR
Coblation | Mixed
Coblation | Stoker 2004^10^ | 44 | 4 | 1 (2) | NR | 3 (7) | NR | 1 (2)
Coblation | Omrani 2012^11^ | 47 | 2 | 1 (2.12) | 1 (2.12) | NR | NR | NR
Coblation | Chimona 2008^12^ | 30 | 1 | NR | NR | 1 (3) | NR | NR
Coblation | Roje 2011^13, 14^ | 50 | 1 | NR | NR | 1 (2) | NR | NR
Coblation | D'Eredita 2010^15^ | 32 | 1 | NR | NR | 1 (3) | 1 (3) | NR
Coblation | Mitic 2007^16^ | 20 | 0 | NR | NR | 0 | NR | NR
Coblation | Unspecified
Coblation | Parker 2009^17^ | 35 | 2 | NR | NR | 2 (6) | NR | NR
Coblation | Shapiro 2007^18^ | 23 | 1 | NR | NR | 1 (4.3) | NR | 1 (4.3)
Coblation | Parker 2011^19^ | 40 | 1 | NR | NR | 1 (3) | NR | 1 (3)
Coblation | Shah 2002^20^ | 17 | 0 | NR | NR | 0 | NR | 0
Cold Dissection | OSDB
Cold Dissection | Salomone 2007^21^ | 50 | 7 | 0 | 7 (14) | NR | NR | NR
Cold Dissection | Ericsson 2009^22, 23^ | 32 | 0 | 0 | 0 | NR | 0 | 0
Cold Dissection | Paramasivan 2012^2^ | 50 | 1 | 1 (2) | 0 | NR | NR | NR
Cold Dissection | Korkmaz 2008^24^ | 41 | 1 | NR | NR | 1 (2) | NR | 1 (2)
Cold Dissection | Aydin 2014^25^ | 40 | 0 | 0 | 0 | NR | 0 | 0
Cold Dissection | Skoulakis 2007^26^ | 15 | 0 | NR | NR | 0 | NR | NR
Cold Dissection | Chaidas 2013,^27^ | 51 | 0 | 0 | 0 | NR | NR | 0
Cold Dissection | Beriat 2013^28^ | 45 | 0 | NR | NR | 0 | 0 | NR
Cold Dissection | Throat Infection
Cold Dissection | Paradise et al.(2002)^29^ | 203 | 7 | NR | NR | 7 (2) | 5 (1.6) | NR
Cold Dissection | Raut 2002^30^ | 32 | 5 | 1 (3) | 4 (12.5) | NR | NR | NR
Cold Dissection | Frampton 2012^31^ | 100 | 3 | 0 | 3 (3) | NR | NR | NR
Cold Dissection | Elbadawey 2015^6^ | 40 | 1 | NR | 1 (2.5) | NR | NR | NR
Cold Dissection | Sezen 2008^32^ | 25 | 0 | 0 | 0 | NR | NR | NR
Cold Dissection | Frampton 2012^31^ | 100 | 0 | 0 | 0 | NR | 0 | 0
Cold Dissection | Di Renzo 2008^9^ | 21 | 0 | NR | NR | 0 | NR | NR
Cold Dissection | Chettri 2014^33^ | 40 | 0 | NR | NR | 0 | NR | NR
Cold Dissection | Mixed
Cold Dissection | D'Eredita 2014^34^ | 285 | 15 | 0 | 15 (5.3) | NR | NR | 15 (5.3)
Cold Dissection | Omrani 2012^11^ | 47 | 7 | 2 (4.26) | 5 (10.64) | NR | NR | NR
Cold Dissection | Haraldsson 2007^35^ | 49 | 2 | 0 | 2 (4.1) | NR | NR | NR
Cold Dissection | Roje 2009^13, 14^ | 50 | 2 | NR | NR | 2 (4) | NR | NR
Cold Dissection | Ozkiris 2012^36^ | 99 | 2 | 0 | 2 (2) | NR | NR | NR
Cold Dissection | Chimona 2008^12^ | 30 | 1 | NR | NR | 1 (3) | NR | NR
Cold Dissection | Nunez 2000^37^ | 25 | 1 | NR | 1 (3.8) | NR | NR | NR
Cold Dissection | Hultcrantz 2004^38-40^ | 43 | 1 | 1 (2) | NR | NR | NR | NR
Cold Dissection | Gabr 2014^41^ | 20 | 0 | NR | NR | 0 | NR | NR
Cold Dissection | Lorusso 2015^42^ | 40 | 1 | 0 | 1 (2.5) | NR | 0 | 1 (2.5)
Cold Dissection | Unspecified
Cold Dissection | Oko 2005^43^ | 61 | 7 | 1 (2) | 6 (10) | NR | NR | 1 (2)
Cold Dissection | Kothari 2002^44^ | 72 | 4 | NR | NR | 4 (5.5) | 4 (5.5) | 0
Cold Dissection | Parker 2009^17^ | 35 | 2 | NR | NR | 2 (6) | NR | NR
Cold Dissection | Hesham 2009^45^ | 69 | 1 | NR | 1 (1.33) | NR | NR | 0
Cold Dissection | Silveira 2008^46^ | 28 | 1 | NR | 1 (3.6) | NR | NR | 1 (3.6)
Cold Dissection | Shapiro 2007^18^ | 23 | 0 | NR | NR | 0 | NR | 0
Cold Dissection | Young 2001^47^ | 23 | 0 | NR | NR | 0 | NR | NR
Cold Dissection | Pruegsanusak 2010^48^ | 20 | 0 | NR | NR | 0 | 0 | NR
Electrocautery | OSDB
Electrocautery | Coticchia 2006^49^ | 10 | 0 | NR | NR | 0 | 0 | NR
Electrocautery | Lister 2006^50^ | 25 | 0 | NR | NR | 0 | NR | NR
Electrocautery | Salomone 2007^21^ | 50 | 0 | 0 | 0 | NR | NR | NR
Electrocautery | Throat Infection
Electrocautery | Leaper 2006^51^ | 101 | 21 | NR | 21 (21) | NR | 11(11) | 2 (2)
Electrocautery | Raut 2002^30^ | 18 | 4 | 1 (5.5) | 3 (16.6) | NR | NR | NR
Electrocautery | Ragab 2011^52^ | 91 | 3 | 2 (2.2) | 1 (1.1) | NR | NR | NR
Electrocautery | Ragab 2011^52^ | 91 | 2 | 1 (1.1) | 1 (1.1) | NR | NR | NR
Electrocautery | Temple 2001^8^ | 20 | 0 | NR | NR | 0 | NR | NR
Electrocautery | Chettri 2014^33^ | 40 | 0 | NR | NR | 0 | NR | NR
Electrocautery | Mixed
Electrocautery | D'Eredita 2014^34^ | 285 | 12 | NR | 12 (4.2) | NR | 12 (4.2) | 12 (4.2)
Electrocautery | Ozkiris 2012^36^ | 102 | 6 | 0 | 6 (5.9) | NR | NR | 0
Electrocautery | Haraldsson 2007^35^ | 49 | 3 | 0 | 3 (6.1) | NR | NR | NR
Electrocautery | D'Eredita 2010^15^ | 32 | 2 | NR | NR | 2 (6) | 2 (6) | NR
Electrocautery | Stoker 2004^10^ | 45 | 2 | NR | NR | 2 (4.4) | 1 | 0
Electrocautery | Nunez 2000^37^ | 22 | 2 | NR | 2 (8.3) | NR | NR | NR
Electrocautery | D'Eredita 2004^53^ | 28 | 0 | NR | 0 | NR | NR | NR
Electrocautery | Mitic 2007^16^ | 20 | 0 | NR | NR | 0 | NR | NR
Electrocautery | Unspecified
Electrocautery | Walker 2001^54^ | 75 | 9 | 0 | 9 (12) | NR | 6 (8) | 3 (4)
Electrocautery | Hesham 2009^45^ | 71 | 4 | NR | 4 (5.33) | NR | NR | 1 (1.33)
Electrocautery | Willging 2003^55^ | 59 | 3 | NR | NR | 3 (5) | NR | 1 (2)
Electrocautery | Derkay 2006^56^ | 150 | 3 | NR | NR | 3 (2) | 3 (2) | NR
Electrocautery | Al-Shehri 2012^57^ | 93 | 2 | NR | NR | 2 (2.2) | NR | NR
Electrocautery | Shah 2002^20^ | 17 | 1 | NR | NR | 1 (6) | NR | 1 (6)
Electrocautery | Parker 2011^19^ | 40 | 1 | NR | NR | 1 (3) | NR | 1 (3)
Electrocautery | Silveira 2008^46^ | 29 | 1 | 1 (3.4) | NR | NR | NR | NR
Electrocautery | Chan 2004,^58^ | 28 | 1 | NR | NR | 1 (4) | 1 (4) | NR
Electrocautery | Young 2001^47^ | 23 | 0 | NR | NR | 0 | NR | NR
Electrocautery | Chang 2012^59^ | 33 | 0 | NR | NR | 0 | NR | NR
Electrocautery | Park 2007^60^ | 21 | 0 | NR | NR | 0 | NR | NR
Harmonic Scalpel | Throat Infection
Harmonic Scalpel | Leaper 2006^51^ | 103 | 24 | NR | 24 (23) | NR | 9 (9) | 4 (4)
Harmonic Scalpel | Salama 2012^5^ | 75 | 1 | NR | 1 (3.3) | NR | 1 (3.3) | NR
Harmonic Scalpel | Unspecified
Harmonic Scalpel | Oko 2005^43^ | 61 | 9 | 1 (2) | 8 (13) | NR | NR | 1 (2)
Harmonic Scalpel | Willging 2003^55^ | 61 | 6 | NR | NR | 6 (10) | NR | 3 (5)
Harmonic Scalpel | Walker 2001^54^ | 97 | 5 | 0 | 5 (5.2) | NR | 5 (5.2) | 1 (1)
Laser | Throat Infection
Laser | Hegazy 2008^7^ | 40 | 1 | NR | 1 (2.5) | NR | NR | NR
Laser | Elbadawey 2015^6^ | 40 | 0 | NR | 0 | NR | NR | NR
Laser | Mixed
Laser | D'Eredita 2004^53^ | 30 | 0 | NR | 0 | NR | NR | 0
Laser | Unspecified
Laser | Kothari 2002^44^ | 79 | 9 | 9 (11.3) | NR | NR | 9 (11.3) | 3 (3.7)
Molecular Resonance | OSDB
Molecular Resonance | D'Eredita 2009^4^ | 74 | 0 | NR | NR | 0 | 0 | NR
Molecular Resonance | Mixed
Molecular Resonance | D'Eredita 2014^34^ | 287 | 2 | NR | 2 (1) | NR | 0 | 0
Molecular Resonance | D'Eredita 2010^15^ | 32 | 0 | NR | NR | 0 | 0 | NR
Molecular Resonance | Lorusso 2015^42^ | 40 | 2 | 0 | 2 (5) | NR | 1 (2.5) | 1 (2.5)
Molecular Resonance | Unspecified
Molecular Resonance | Chang 2012^59^ | 33 | 0 | NR | NR | 0 | NR | NR
Thermal Welding | OSDB
Thermal Welding | Aydin 2014^25^ | 40 | 0 | 0 | 0 | NR | NR | NR
Thermal Welding | Throat Infection
Thermal Welding | Sezen 2008^32^ | 25 | 0 | 0 | 0 | NR | NR | NR
Thermal Welding | Mixed
Thermal Welding | Ozkiris 2012^36^ | 104 | 5 | 0 | 5 (4.8) | NR | NR | 1 (1)
Thermal Welding | Chimona 2008^12^ | 30 | 0 | NR | NR | 0 | NR | NR
Unspecified/Other Techniques | OSDB
Unspecified/Other Techniques | Marcus 2013^61-67^ Unspecified tonsillectomy | 212 | 5 | NR | NR | 5 (2.4) | 5 (2.4) | NR
Unspecified/Other Techniques | Throat Infection
Unspecified/Other Techniques | Orvidas et al.2006^68^ Unspecified tonsillectomy | 145 | 5 | NR | NR | 5 (3.4) | NR | 2 (1.4)
Unspecified/Other Techniques | Van Staaij 2004^69-71^ Unspecified tonsillectomy | 194 | 7 | 7 (4) | NR | NR | 3 (2) | 2 (1)
Unspecified/Other Techniques | Unspecified
Unspecified/Other Techniques | Al-Shehri 2012^57^ Unspecified tonsillectomy | 97 | 6 | NR | NR | 6 (6.2) | NR | 6 (6.2)
Unspecified/Other Techniques | Bukhari 2007^72^ Electrocautery and cold dissection (left or right tonsil) | 100 | 2 | 2 (2) | NR | NR | NR | NR
Totals | (N arms)
Totals | All arms (105) | 6299 | 265 (4.2) | 33 (1.3) | 166 (4.8) | 66 (2.7) | 80 (3.0) | 66 (2.2)
Totals | Electrocautery (29) | 1668 | 82 (4.9) | 5 (0.99) | 62 (6.3) | 15 (2.3) | 36 (5) | 21 (2.6)
Totals | Cold dissection (34) | 1904 | 72 (3.8) | 6 (0.54) | 49 (4) | 17 (2.7) | 9 (1.6) | 19 (2.3)
Totals | Harmonic scalpel (5) | 397 | 45 (11.3) | 1 (0.63) | 38 (11.3) | 6 (9.8) | 15 (5.5) | 9 (2.8)
Totals | Unspecified/other technique (5) | 748 | 25 (3.3) | 9 (3.1) | NR | 16 (3.5) | 8 (2.0) | 10 (2.3)
Totals | Coblation (19) | 748 | 25 (3.3) | 3 (2.1) | 7 (2.4) | 12 (2.7) | 2 (1.1) | 4 (2.5)
Totals | Laser (4) | 189 | 10 (5.3) | 9 (11.4) | 1 (0.91) | NR | 9 (11.4) | 3 (2.8)
Totals | Thermal welding (4) | 199 | 5 (2.5) | 0 (0) | 5 (2.96) | 0 (0) | NR | 1 (0.96)
Totals | Molecular resonance (5) | 466 | 4 (0.86) | 0 (0) | 4 (1.22) | 0 (0) | 1 (0.23) | 1 (0.31)

N=Number; NR=Not Reported; OSDB=Obstructive Sleep Disordered Breathing; PTH=Post-Tonsillectomy Hemorrhage

Table H-2 Postoperative hemorrhage reported in comparative study arms addressing partial tonsillectomy

Technique | Indication Author, Year | Total Arm N | Total PTH | Primary PTH n (%) | Secondary PTH n (%) | Other/Undefined PTH n (%) | Nonoperative Revisit or Readmission for PTH n (%) | Reoperation for PTH n (%)
Coblation | OSDB
Coblation | Ericsson 2009^22, 23^ | 32 | 2 | 0 | 2 (6) | NR | 2 (6) | 0 (0)
Coblation | Chang 2008^3^ | 34 | NR | NR | NR | NR | NR | 0
Coblation | Coticchia 2006 ^49^ | 13 | NR | NR | NR | NR | 0 | NR
Coblation | Throat infection
Coblation | Stelter 2012 ^73_1437^ | 14 | 0 | NR | NR | 0 | NR | NR
Coblation | Mixed
Coblation | Hultcrantz 2004^38-40^ | 49 | 2 | NR | NR | 2 (4) | NR | NR
Coblation | Chan 2004^58^ | 27 | NR | NR | NR | 0 | 0 | NR
Cold dissection | OSDB
Cold dissection | Skoulakis 2007^26^ | 15 | 0 | NR | NR | 0 | NR | NR
Cold dissection | Chaidas 2013 ^27^ | 50 | 0 | 0 | 0 | NR | NR | 0
Cold dissection | Korkmaz 2008^24^ | 40 | 1 | NR | NR | 1 (3) | NR | 1 (3)
Cold dissection | Unspecified
Cold dissection | Park 2007^60^ | 19 | 0 | NR | NR | 0 | NR | NR
Laser | OSDB
Laser | Havel 2012^74^ (diode laser) | 21 | 0 | 0 | 0 | NR | NR | NR
Laser | Havel 2012^74^ (CO_2_ laser) | 21 | 0 | 0 | 0 | NR | NR | NR
Laser | Throat infection
Laser | Stelter 2010^73, 75^ | 12 | 0 | NR | NR | 0 | NR | NR
Microdebrider | OSDB
Microdebrider | Lister 2006^50^ | 25 | 0 | NR | NR | 0 | NR | NR
Microdebrider | Beriat 2013 ^28^ | 37 | 0 | NR | NR | 0 | 0 | NR
Microdebrider | Mixed
Microdebrider | Gabr 2014^41^ | 20 | 0 | NR | NR | 0 | NR | NR
Microdebrider | Unspecified
Microdebrider | Pruegsanusak 2010 ^48^ | 20 | 1 | NR | NR | 1 (5) | 1 (5) | NR
Microdebrider | Derkay 2006 ^56^ | 150 | 2 | NR | NR | 2 (1.3) | 2 (1.3) | NR
Totals | (N arms)
Totals | All arms (18) | 599 | 8 (1.5) | 0 (0) | 2 (1.6) | 6 (1.4) | 5 (1.8) | 1 (0.64)
Totals | Coblation (6) | 169 | 4 (4.2) | 0 (0) | 2 (6.3) | 2 (2.2) | 2 (2.8) | 0 (0)
Totals | Microdebrider (5) | 252 | 3 (1.2) | NR | NR | 3 (1.2) | 3 (1.45) | NR
Totals | Cold dissection (4) | 124 | 1 (0.81) | 0 (0) | 0 (0) | 1 (1.4) | NR | 1 (1.1)
Totals | Laser (3) | 54 | 0 (0) | 0 (0) | 0 (0) | 0 (0) | NR | NR

N=Number; NR=Not Reported; OSDB=Obstructive Sleep Disordered Breathing; PTH=Post-Tonsillectomy Hemorrhage

## Non-Bleeding Harms

Table H-3 Revisits for pain or dehydration reported after partial tonsillectomy in arms of comparative studies

Technique for Partial Tonsillectomy | Author, Year Indication | Total Arm N | Pain Revisits/Readmissions, n (%) | Dehydration Revisits/Readmissions, n (%) | PONV Revisits/Readmissions, n (%)
Microdebrider | OSDB
Microdebrider | Derkay 2006^56^ | 150 | NR | 5 (3.3) | NR
Microdebrider | Beriat 2013^28^ | 37 | 0 | 0 (0) | NR
Coblation | Chang 2008^3^ | 34 | NR | 0 (0) | NR
Totals | (N arms)
| Microdebrider (2) | 187 | 0 | 5 (3.3) | NR
| Coblation (1) | 34 | NR | 0 | NR

N=Number; NR=Not Reported; PONV=Post-Operative Nausea Vomiting

Table H-4 Revisits for pain, dehydration, PONV reported after total tonsillectomy in arms of comparative studies

Technique for Total Tonsillectomy | Author, Year Indication | Total Arm N | Pain Revisits/Readmissions, n (%) | Dehydration Revisits/Readmissions, n (%) | PONV Revisits/Readmissions, n (%) | Other Revisits/Readmissions, n (%)
Laser | Not specified
Laser | Kothari 2002^44^ | 79 | 12 (15.1) | NR | 13 (16.4) | NR
Laser | Matin 2012^76^ | 50 | 1 (2) | NR | NR | NR
Laser | D'Eredita 2004^53^ | 30 | NR | 0 | NR | NR
Electrocautery | OSDB
Electrocautery | Derkay 2006^56^ | 150 | NR | 4 (2.6) | NR | NR
Electrocautery | Chang 2005^77^ | 49 | 0 (0) | 1 (2) | 0 | NR
Electrocautery | Throat Infection
Electrocautery | Walker 2001^54^ | 161 | NR | 4 (2.5) | NR | NR
Electrocautery | Raut 2002^30^ | 18 | 0 (0) | 0 | 0 | NR
Electrocautery | Mixed
Electrocautery | D'Eredita 2014^34^ | 279 | NR | 0 | NR | NR
Electrocautery | Stoker 2004^10^ | 45 | Post-op calls/visits to doctor 11 (24.4) | Post-op calls/visits to doctor 7 (15.5) | Post-op calls/visits to doctor 7 (15.5) | NR
Electrocautery | Parker 2011^19^ | 40 | NR | 1 (2.5) | NR | NR
Electrocautery | D'Eredita 2010^15^ | 32 | NR | 2 (6.2) | NR | NR
Electrocautery | Chan 2014^22^ | 28 | NR | 1 (3.7) | NR | NR
Electrocautery | D'Eredita 2004^53^ | 28 | NR | 0 | NR | NR
Electrocautery | Nunez 2000^37^ | 24 | 0 (0) | 0 | 0 | NR
Electrocautery | Not Specified
Electrocautery | Silveira 2003^46^ | 29 | Stayed extra day after surgery 1 (3.4) | NR | NR | NR
Cold dissection | OSDB
Cold dissection | Beriat 2013^28^ | 45 | 0 (0) | 0 | NR | NR
Cold dissection | Throat infection
Cold dissection | Raut 2002^30^ | 32 | 0 (0) | 0 | 0 | NR
Cold dissection | Mixed
Cold dissection | D'Eredita 2014^34^ | 279 | NR | 0 | NR | NR
Cold dissection | Kothari 2002^44^ | 72 | 13 (18) | NR | 16 (22.2) | NR
Cold dissection | Oko 2005^43^ | 61 | 1 (1.6) | NR | NR | NR
Cold dissection | Nunez 2000^37^ | 26 | 0 (0) | 0 | 0 | NR
Cold dissection | Shapiro 2007^18^ | 23 | 0 (0) | NR | 0 | NR
Cold dissection | Not Specified
Cold dissection | Oko 2005^43^ | 61 | NR | 1 (1.6) | NR | NR
Cold dissection | Shapiro 2007^18^ | 23 | NR | 0 | NR | NR
Coblation | OSDB
Coblation | Chang 2008^3^ | 35 | NR | 0 | NR | NR
Coblation | Shah 2002^20^ | 17 | NR | 1 (5.8) | Post-op calls/visits to doctor 4 (9) | NR
Coblation | Mixed
Coblation | D'Eredita 2009 ^4^ | 78 | NR | 0 | NR | NR
Coblation | Stoker 2004^10^ | 44 | Post-op calls/visits to doctor 6 (13.6) | Post-op calls/visits to doctor 6 (13.6) | NR | NR
Coblation | Not Specified
Coblation | Shapiro 2007^18^ | 24 | 0 | 0 | 0 | NR
Harmonic Scalpel | Mixed
Harmonic Scalpel | Walker 2001^54^ | 155 | NR | 2 (1.3) | NR | NR
Harmonic Scalpel | Oko 2005^43^ | 61 | NR | NR | NR | Readmit for dehydration and pain 3 (4.9)
Molecular resonance | Mixed
Molecular resonance | D'Eredita 2014^34^ | 283 | NR | 0 | NR | NR
Molecular resonance | D'Eredita 2009^4^ | 79 | NR | 0 | NR | NR
Unspecified tonsillectomy | OSDB
Unspecified tonsillectomy | Marcus 2013^61-67^ | 212 | NR | 7 (3.3) | NR | NR
Unspecified tonsillectomy | Van Staaij et al. 2004^69-71^ | 151 | NR | NR | 5 (3) | NR
Unspecified tonsillectomy | Orvidas 2006^68^ | 145 | NR | 2 (1.4) | NR | NR
Unspecified tonsillectomy | Goldstein 2004^78^ | 21 | NR | 0 (0) | 0 | NR
Totals | (N arms)
Totals | All arms (37) | 2969 | 45 (1.5) | 39 (1.6) | 45 (1.5) | 3 (0.09)
Totals | Electrocautery-total (12) | 883 | 12 (7.3) | 20 (2.3) | 7 (5.1) | NR
Totals | Cold dissection-total (9) | 622 | 14 (5.4) | 1 (0.21) | 16 (10.5) | NR
Totals | Unspecified tonsillectomy (4) | 529 | NR | 9 (2.4) | 5 (0.85) | NR
Totals | Molecular resonance-total (2) | 362 | NR | 0 | NR | NR
Totals | Harmonic scalpel-total (2) | 216 | NR | 2 (1.3) | NR | 3 (4.9)
Totals | Coblation-total (5) | 198 | 6 (8.8) | 7 (3.5) | 4 (9.8) | NR
Totals | Laser-total (3) | 159 | 13 (10.1) | 0 | 13 (16.5) | NR
Totals | Microdebrider-partial (2) | 187 | 0 | 5 (2.5) | NR | NR
Totals | Coblation-partial (1) | 34 | NR | 0 | NR | NR

N=Number; NR=Not Reported; PONV=Post-Operative Nausea Vomiting

## Bleeding-Related Harms in Case Series, Database, and Registry Studies

Table H-5 Post-tonsillectomy hemorrhage rates reported across all studies

Author, Year RoB | Age Range, Years Surgical Indication Data Source Description | Total N | Total PTH | Primary PTH, n (%) | Secondary PTH, n (%) | Unspecified PTH, n (%) | Nonoperative revisit or readmission for PTH, n (%) | Reoperation for PTH, n (%)
Database Studies
Edmonson 2015^79^ Low | 0-24 Mixed CA hospital discharge database-return visits within 30 days postop | 30092 | 1331 | NR | NR | 1331 (3.8) | 1331 (3.8) | NR
Bhattacharyya 2015^80, 81^ Low | <18 years (mean=7.5 years) Unspecified CA, IA, FL, NY ER and ambulatory surgery and ER databases-return visits within 14 days postop | 79520 | 1652 | NR | NR | 1652 (2.1) | 1652 (2.1) | NR
Duval 2015^82^ Low | 1-18 Unspecified Hospital system database-return visits within 21 days postop | 39906 | 935 | NR | NR | 935 (2.3) | NR | 463 (1.2)
Padia 2015^83^ Moderate | 1-18 Unspecified Hospital system database-return visits within 21 days post-same-day tonsillectomy | 15953 | 1187 | NR | NR | 1187 (7.4) | NR | 413 (2.6)
Mahant 2014^84, 85^ Low | 1-18 Mixed Pediatric Health Information System-return visits within 30 days post-same day tonsillectomy | 139715 | 4182 | NR | NR | 4182 (3) | 4182 (3) | NR
Suzuki 2014^86^ Moderate | ≤15 years OSDB Japanese national inpatient database-7 years | 31934 | 160 | NR | NR | 160 (0.50) | NR | 160 (0.50)
Tomkinson 2012^87, 88^ Low | <12 years Mixed Wales Surgical Instrument Surveillance Programme Database-5 years | 4225 | 63 | 24 (0.6) | 39 (0.9) | NR | NR | 38 (0.9)
^*^Tomkinson 2005^89^ Low | <12 years Unspecified Patient Episode Database for Wales-return visits within 28 days post-tonsillectomy | 6730 | 225 | 53 (0.79) | 172 (3) | NR | 153 (2.3) | 41 (0.61)
Clark 2004^90^ Low | 0-14 Unspecified Hospital Episode Statistics for England-4 years | 131577 | 500 | NR | NR | 500 (0.38) | NR | 500 (0.38)
Kshirsagar 2016^91^ Low | 1-17 years Mixed California Ambulatory Surgery Data records-6 years | 138998 | 156 | NR | NR | 156 (0.1) | NR | NR
Harounian 2016^92^ Low | 1-17 years Unspecified MarketScan database records-5 years | 305860 | 8518 | NR | NR | 8518 (2.8) | 500 (0.16) | 2480 (0.81)
Raol 2016^93^ Low | 0-18 Mixed Kids' Inpatient Database records -3 years | 38631 | 446 | NR | NR | 446 (1.2) | NR | NR
Case Series
Achar 2015^94^ Moderate | 0-17 Mixed Single institution ER chart review of 5 years | 3527 | 222 | NR | 222 (6.3) | NR | NR | NR
Walner 2012^95^ Moderate | 1-18 Mixed Single institution chart review of 7 years | 1918 | 87 | 5 (0.5) | 82 (4) | NR | NR | 31 (1.6)
Perkins 2012^96^ Moderate | 6.90±4.02 (mean yrs±SD) Mixed Single institution chart review of 7 years | 9023 | 212 | 48 (0.5) | 164 (2) | NR | 109 (1.2) | 103 (1.1)
Kim 2010^97^ Moderate | ≤15 years Mixed Single institution chart review of 3 years | 1109 | 33 | 0 | 33 (3) | NR | 3 (0.27) | 2 (0.18)
Gooda 2010^98^ Moderate | 5-15 Throat infection Chart review of 8 years | 1500 | 9 | NR | NR | 9 (0.6) | NR | 2 (0.13)
D'Agostino 2009^99^ Moderate | 2-13 Mixed Single institution chart review of 5 years | 3306 | 59 | 44 (1.3) | 15 (0.45) | NR | NR | 15 (0.45)
Arnolder 2008^100^ Moderate | 1-15 Mixed Single institution chart review for 13 years | 3657 | 54 | NR | NR | 54 (1.5) | NR | 54 (1.5)
Jones 2007^101^ Moderate | 0.5-34.8 Mixed Children's Hospital, Boston, MA patient records- 4 years | 2319 | 295 | NR | NR | 295 (12.7) | NR | 63 (2.7)
Mills 2004^102^ Moderate | 9 months-17 years Mixed Single institution chart review of admitted or re-admitted patients over 9 years | 4850 | 209 | 46 (0.9; 95% CI: 0.68% to 1.22%) | 163 (3; 95% CI: 2.8% to 3.9%) | 0 | 38 (0.78) | 18 (0.37)
Granell 2004^103^ Moderate | 0-14 Mixed Single institution chart review of 6 years | 1243 | 84 | 78 (6) | 6 (0.48) | NR | NR | 36 (2.9)
Windfuhr 2001^104-106^ Moderate | 6 months-14 years Mixed Single institution chart review of 12 years | 2567 | 41 | 27 (1) | 14 (0.54) | NR | NR | 41 (1.6)
Liu 2001^107^ Moderate | 2.5 months-20 years Unspecified Single institution chart review of 1 year | 1438 | 134 (evaluations for PTH in 112 children) | 9 (0.63) | 125 (9) | NR | 60 (4.2) | 20 (1.4)
Kang 1994^108^ Moderate | 1-19 Unspecified In-patient and out-patient clinic records from the Children's Hospital of Buffalo- 4 years | 1061 | 64 | 64 (6) | 0 (0) | NR | 44 (4.1) | 14 (1.3)
Lannigan 1993^109^ Moderate | 3-13 Unspecified Single institution chart review of 4 years | 4386 | 25 | 25 (0.6) | NR | NR | NR | 18 (0.41)
Yardley 1992^110^ Moderate | NR Unspecified Two South Yorkshire hospitals- 3 years | 2091 | 11 | NR | NR | 11 (0.52) | NR | 11 (0.52)
Colclasure 1990^111^ Moderate | 6 years (mean) Unspecified Single institution chart review of 8 years | 2011 | 36 | 7 (0.35) | 29 (1.4) | 0 (0) | 12 (0.60) | 7 (0.35)
Chowdhury 1988^112^ Moderate | “Pediatric” (under 4 -over 12) Mixed Single institution chart review of 13 years | 6842 | 171 | 90 (1.3) | 81 (1.2) | NR | 46 (0.67) | 29 (0.42)
Carithers 1987^113^ Moderate | 1-23 (mean=6.3) Mixed Single institution chart review of 1 year | 2563 | 78 | 30 (1.2) | 48 (1.9) | NR | NR | NR
Crysdale 1986^114^ Moderate | ≤2 -17 Unspecified Single institution chart review of 4 years | 7974 | 199 | 199 (2.5) | NR | NR | 0 | NR
Herdman 1986^115^ Moderate | ≤14 years Unspecified Single institution chart review of 7 years | 2400 | 13 | 13 (0.54) | 0 | NR | NR | 0
Carmody 1982^116^ Moderate | 0-19 Not specified Single institution chart review of 5 years | 3380 | 54 | 30 (0.8) | 24 (0.7) | NR | NR | NR
Mahadevan 2016^117^ Moderate | 1-15 Unspecified Starship Children's Hospital database records- 10 years | 5400 | 234 | 25 (0.5) | 209 (3.9) | NR | 9 (0.17) | 57 (1.1)
Spektor 2016^118^ Low | 1-19 Mixed Electronic medical records of the Center for Pediatric ENT – 5 years | 2237 | 91 | NR | NR | 91 (4.1) | NR | 21 (1)
Peeters 1999^119^ Moderate | 1-16 Unspecified ENT dept at children's hospital- 10 years | 1508 | 44 | 39 (2.6) | 5 (0.3) | NR | NR | NR
Pfaff 2016^120^ Low | 0-18 Unspecified Tertiary care children's hospital- 4 years | 2697 | 97 | NR | NR | 97 (3.6) | NR | 59 (2.2)
Registries
Hultcrantz 2014^121-123^ Low | 2-18 OSDB Swedish National Registry for Tonsil Surgery-data at 30 days and 6 months postop | 10826 | 304 | 149 (1.4) | 155 (1.4) | NR | NR | 54 (0.49)
Soderman 2011^124^ Low | 0-19 years Mixed Swedish National Tonsil Register-11 years | 40322 | 431 | NR | NR | 431 (1.1) | NR | NR
Sarny 2011^125, 126^ Low | 1-18 Mixed Nationwide data collection for 12 months | 3372 | 283 | NR | NR | 283 (8.4) | NR | 47 (1.4)
Kvarner 2009^127^ Low | ≤16 years Unspecified Norwegian Patient Registry-7 years | 34955 | 157 | NR | NR | 157 (0.45) | 157 (0.45) | NR
Lowe 2007^128-130^ Low | <5 to 15 years Mixed UK National Tonsillectomy Audit-1 year | 21063 | 575 | NR | NR | 575 (3) | NR | NR
Totals
All studies | NA | 1154686 | 23661 (2.1) | 1005 (1.2) | 1586 (2.1) | 21070 (1.97) | 8451 (1.3) | 4797 (0.78)
Database studies | NA | 963141 | 19355 (2.0) | 77 (0.70) | 211 (1.9) | 19067 (2.0) | 7818 (1.4) | 4095 (0.76)
Case series | NA | 81007 | 2556 (3.2) | 779 (1.2) | 1220 (2.3) | 557 (3.4) | 321 (0.81) | 601 (0.97)
Registry studies | NA | 110538 | 1750 (1.6) | 149 (1.4) | 155 (1.4) | 1446 (1.5) | 312 (0.68) | 101 (0.71)

Note: primary typically defined as within 24 hours postoperatively and secondary as greater than 24 hours.

* Defined primary as during the initial admission and secondary as PTH requiring admission up to 28 days postoperatively

CI=Confidence Interval; N=Number; NR=Not Reported; OSDB=Obstructive Sleep Disordered Breathing; PTH=Post-Tonsillectomy Hemorrhage

Table H-6 PTH rates reported by technique in case series, database, or registry studies

Surgical Technique | Author, Year RoB | Total N | Total PTH | Primary PTH, n (%) | Secondary PTH, n (%) | Unspecified PTH, n (%) | Non-operative revisit or readmission, n (%) | Reoperation, n (%)
Electrocautery (total tonsillectomy) | Gooda 2010^98^ Moderate | 1500 | 9 | NR | NR | 9 (0.6) | NR | 2 (0.13)
Electrocautery (total tonsillectomy) | Kim 2010^97^ Moderate | 1109 | 33 | 0 | 33 (3) | NR | 3 (0.27) | 2 (0.18)
Electrocautery (total tonsillectomy) | Lowe 2007^128-130^ Low | 6161 | 204 | NR | NR | 204 (3.3) | NR | NR
Electrocautery (total tonsillectomy) | Liu 2001^107^ Moderate | 1438 | 134 (evaluations for PTH in 112 children) | 9 (0.63) | 125 (9) | NR | 60 (4.2) | 20 (1.4)
Electrocautery (total tonsillectomy) | Tomkinson 2005^89^ | 6730 | 225 | 53 (0.79) | 172 (3) | NR | 153 (2.3) | 41 (0.61)
Cold dissection (total tonsillectomy) | Hultcrantz^*^ 2014^121-123^ Low | 3945 | 192 | 74 (1.9) | 118 (3) | NR | NR | 46 (1.5)
Cold dissection (total tonsillectomy) | Arnolder 2008^100^ Moderate | 3657 | 54 | NR | NR | 54 (1.5) | NR | 54 (1.5)
Cold dissection (total tonsillectomy) | Lowe 2007^128-130^ Low | 5176 | 106 | NR | NR | 106 (2.04) | NR | NR
Cold dissection (total tonsillectomy) | Windfuhr 2001^104-106^ Moderate | 2567 | 41 | 27 (1) | 14 (0.54) | NR | NR | 41 (1.6)
Cold dissection (total tonsillectomy) | Carmody 1982^116^ Moderate | 3380 | 54 | 30 (0.8) | 24 (0.7) | NR | NR | NR
Cold dissection (total tonsillectomy) | Peeters 1999^119^ Moderate | 1508 | 44 | 39 (2.6) | 5 (0.3) | NR | NR | NR
Cold dissection (total tonsillectomy) | Chowdhury 1988^112^ | 6842 | 171 | 90 (1.3) | 81 (1.2) | NR | 46 (0.67) | 29 (0.42)
Cold dissection (total tonsillectomy) | Crysdale 1986^114^ | 7974 | 199 | 199 (2.5) | NR | NR | 0 | NR
Cold dissection (total tonsillectomy) | D'Agostino 2009^99^ | 3306 | 59 | 44 (1.3) | 15 (0.45) | NR | NR | 15 (0.45)
Cold dissection (total tonsillectomy) | Kang 1994^108^ Moderate | 1061 | 64 | 64 (6) | 0 (0) | NR | 44 (4.1) | 14 (1.3)
Coblation (total tonsillectomy) | Walner 2012^95^ Moderate | 1918 | 87 | 5 (0.5) | 82 (4) | NR | NR | 31 (1.6)
Coblation (total tonsillectomy) | Pfaff 2016^120^ Low | 2697 | 97 | NR | NR | 97 (3.6) | NR | 59 (2.2)
Coblation (total tonsillectomy) | Spektor 2016^118^ Low | 2237 | 91 | NR | NR | 91 (4.1) | NR | 21 (1)
Other techniques | Hultcrantz^*^ 2014^121-123^ Coblation-partial Low | 6881 | 112 | 75 (1.1) | 37 (0.54) | NR | NR | 8 (0.07)
Other techniques | Sarny 2011^125, 126^ Total tonsillectomy-unspecified Low | 2080 | 255 | NR | NR | 255 (12.3) | NR | 36 (1.7)
Other techniques | Sarny 2011^125, 126^ Partial tonsillectomy-unspecified Low | 1292 | 28 | NR | NR | 28 (2.2) | NR | 11 (0.85)
Other techniques | Perkins 2012^96^ Total tonsillectomy-unspecified Moderate | 9023 | 212 | 48 (0.5) | 164 (1.8) | NR | 109 (1.2) | 103 (1.1)
Other techniques | Yardley 1992^110^ Tonsillectomy - unspecified Moderate | 2091 | 11 | NR | NR | 11 (0.52) | NR | 11 (0.52)
Other techniques | Jones 2007^101^ Tonsillectomy - unspecified Moderate | 2319 | 295 | NR | NR | 295 (12.7) | NR | 63 (2.7)
Other techniques | Raol 2016^93^ Tonsillectomy - unspecified Low | 38631 | 446 | NR | NR | 446 (1.2) | NR | NR
Other techniques | Harounian 2016^92^ Tonsillectomy - unspecified Low | 305860 | 8518 | NR | NR | 8518 (2.8) | 500 (0.16) | 2480 (0.81)
Other techniques | Kshirsagar 2016^91^ Tonsillectomy - unspecified Low | 138998 | 156 | NR | NR | 156 (0.1) | NR | NR
Other techniques | Mahadevan 2016^117^ Adenotonsillectomy–multiple techniques Moderate | 5400 | 234 | 25 (0.5) | 209 (3.9) | NR | 9 (0.17) | 57 (1.1)
| Bhattacharyya 2015^80, 81^ Tonsillectomy - unspecified Low | 79520 | 1652 | NR | NR | 1652 (2.1) | 1652 (2.1) | NR
| Clark 2004^90^ Tonsillectomy - unspecified Low | 131577 | 500 | NR | NR | 500 (0.38) | NR | 500 (0.38)
| Duval 2015^82^ Tonsillectomy - unspecified Low | 39906 | 935 | NR | NR | 935 (2.3) | NR | 463 (1.2)
| Edmonson 2015^79^ Tonsillectomy - unspecified Low | 30092 | 1331 | NR | NR | 1331 (3.8) | 1331 (3.8) | NR
| Kvarner 2009^127^ Tonsillectomy - unspecified Low | 34955 | 157 | NR | NR | 157 (0.45) | 157 (0.45) | NR
| Mahant 2014^84, 85^ Tonsillectomy – unspecified Low | 139715 | 4182 | NR | NR | 4182 (3) | 4182 (3) | NR
| Soderman 2011^124^ Tonsillectomy - unspecified Low | 40322 | 431 | NR | NR | 431 (1.1) | NR | NR
| Tomkinson 2012^87, 88^ Tonsillectomy - unspecified Low | 4225 | 63 | 24 (0.6) | 39 (0.9) | NR | NR | 38 (0.9)
| Achar 2015^94^ Tonsillectomy-multiple techinques Moderate | 3527 | 222 | NR | NR | 222 (6.3) | NR | NR
| Carithers 1987^113^ Tonsillectomy - unspecified Moderate | 2563 | 78 | 30 (1.2) | 48 (1.9) | NR | NR | NR
| Colclasure 1990^111^ Tonsillectomy - unspecified Moderate | 2011 | 36 | 7 (0.35) | 29 (1.4) | 0 (0) | 12 (0.60) | 7 (0.35)
| Herdman 1986^115^ Tonsillectomy - unspecified Moderate | 2400 | 13 | 13 (0.54) | 0 | NR | NR | 0
| Lannigan 1993^109^ Adenotonsillectomy - unspecified Moderate | 4386 | 25 | 25 (0.6) | NR | NR | NR | 18 (0.41)
| Padia 2015^83^ Tonsillectomy-unspecified Moderate | 15953 | 1187 | NR | NR | 1187 (7.4) | NR | 413 (2.6)
| Suzuki 2014^86^ Tonsillectomy-unspecified Moderate | 31934 | 160 | NR | NR | 160 (0.50) | NR | 160 (0.50)
| Mills 2004^102^ Tonsillectomy-unspecified Moderate | 4850 | 209 | 46 (0.95) | 163 (3.4) | NR | 38 (0.78) | 18 (0.37)
| Granell 2004^103^ Tonsillectomy-unspecified Moderate | 1243 | 84 | 78 (6) | 6 (0.48) | NR | NR | 36 (2.9)
Totals
All arms | NA | 23284 (2.03) | 23284 (2.04) | 1005 (0.87) | 1586 (0.14) | 20805 (1.8) | 8451 (0.74) | 4797 (0.42)
Electrocautery | NA | 16938 | 605 (3.6) | 62 (0.7) | 330 (3.6) | 213 (2.8) | 216 (2.3) | 65 (0.6)
Cold dissection | NA | 39416 | 984 (2.5) | 567 (2.5) | 257 (1.9) | 160 (1.8) | 208 (1.1) | 199 (0.9)
Coblation | NA | 6852 | 275 (4.01) | 5 (0.3) | 82 (4.3) | 188 (3.8) | NR | 111 (1.62)
Other Techniques | NA | 21532 (2.04) | 21420 (1.98) | 371 (0.9) | 917 (2.2) | 20244 (1.95) | 8027 (0.74) | 4422 (0.41)

* Study notes that most total tonsillectomies were performed using cold dissection. Non-operative revisits may have included reoperations.

N=Number; NR=Not Reported; PTH=Post-Tonsillectomy Hemorrhage

Table H-7 PTH by indication in case series, database, or registry studies

Indication | Author, Year | Total N | Total PTH | Primary PTH, n (%) | Secondary PTH, n (%) | Unspecified PTH, n (%) | Non-operative revisit or readmission, n (%) | Reoperation, n (%)
OSDB | Achar 2015^94^ | 417 | 65 | NR | NR | 65 (15.6) | NR | NR
OSDB | Suzuki 2014^86^ | 31934 | 160 | NR | NR | 160 (0.50) | NR | 160 (0.50)
OSDB | ^*^Hultcrantz 2014^121, 122^ | 10820 | 304 | 149 (1.4) | 155 (1.4) | NR | 155 (1.4) | 54 (0.50)
OSDB | Perkins 2012^96^ | 1141 | 105 | NR | NR | 105 (9.2) | NR | NR
Recurrent throat infection | Achar 2015^94^ | 2398 | 150 | NR | 150 (6.3) | NR | NR | NR
Recurrent throat infection | Gooda 2010^98^ | 1500 | 9 | NR | NR | 9 (0.6) | NR | 2 (0.13)
Recurrent throat infection | Perkins 2012^96^ | 158 | 28 | NR | NR | 28 (17.7) | NR | NR
Mixed | Achar 2015^94^ | 564 | 37 | NR | 37 (6.6) | NR | NR | NR
Mixed | Perkins 2012^96^ | 330 | 65 | NR | NR | 65 (19.7) | NR | NR
Mixed | Kshirsagar 2016^91^ | 138998 | 156 | NR | NR | 156 (0.1) | NR | NR
Mixed | Raol 2016^93^ | 38631 | 446 | NR | NR | 446 (1.2) | NR | NR
Mixed | Spektor 2016^118^ | 2237 | 91 | NR | NR | 91 (4.1) | NR | 21 (1)
Mixed | Edmonson 2015^79^ | 30092 | 1331 | NR | NR | 1331 (3.8) | 1331 (3.8) | NR
Mixed | Mahant 2014^84, 85^ | 139715 | 4182 | NR | NR | 4182 (3) | 4182 (3) | NR
Mixed | Soderman 2011^124^ | 40322 | 431 | NR | NR | 431 (1.1) | NR | NR
Mixed | Tomkinson 2012^87, 88^ | 4225 | 63 | 24 (0.6) | 39 (0.9) | NR | NR | 38 (0.9)
Mixed | Arnolder 2008^100^ | 3657 | 54 | NR | NR | 54 (1.5) | NR | 54 (1.5)
Mixed | Carithers 1987^113^ | 2563 | 78 | 30 (1.2) | 48 (1.9) | NR | NR | NR
Mixed | Chowdhury 1988^112^ | 6842 | 171 | 90 (1.3) | 81 (1.2) | NR | 46 (0.67) | 29 (0.42)
Mixed | D'Agostino 2009^99^ | 3306 | 59 | 44 (1.3) | 15 (0.45) | NR | NR | 15 (0.45)
Mixed | Kim 2010^97^ | 1109 | 33 | 0 | 33 (3) | NR | 3 (0.27) | 2 (0.18)
Mixed | Walner 2012^95^ | 1918 | 87 | 5 (0.5) | 82 (4) | NR | NR | 31 (1.6)
Mixed | Windfuhr 2001^104-106^ | 2567 | 41 | 27 (1) | 14 (0.54) | NR | NR | 41 (1.6)
Mixed | Granell 2004^103^ | 1243 | 84 | 78 (6) | 6 (0.48) | NR | NR | 36 (2.9)
Mixed | Mills 2004^102^ | 4850 | 209 | 46 (0.9; 95% CI: 0.68% to 1.22%) | 163 (3; 95% CI: 2.8% to 3.9%) | 0 | 38 (0.78) | 18 (0.37)
Mixed | Lowe 2007^128-130^ | 21063 | 575 | NR | NR | 575 (3) | NR | NR
Mixed | Sarny 20136^205, 206^ | 3372 | 283 | NR | NR | 283 (8.4) | NR | 47 (1.4)
Mixed | Jones 2007^101^ | 2319 | 295 | NR | NR | 295 (12.7) | NR | 63 (2.7)
Other (not specified) | Achar 2015^94^ | 106 | 7 | NR | 7 (0.20) | NR | NR | NR
Other (not specified) | Perkins 2012^96^ | 71 | 14 | NR | NR | 14 (19.7) | NR | NR
Other (not specified) | Harounian 2016^92^ | 305860 | 8518 | NR | NR | 8518 (2.8) | 500 (0.16) | 2480 (0.81)
Other (not specified) | Kang 1994^108^ | 1061 | 64 | 64 (6) | 0 (0) | NR | 44 (4.1) | 14 (1.3)
Other (not specified) | Yardley 1992^110^ | 2091 | 11 | NR | NR | 11 (0.52) | NR | 11 (0.52)
Other (not specified) | Mahadevan 2016^117^ | 5400 | 234 | 25 (0.5) | 209 (3.9) | NR | 9 (0.17) | 57 (1.1)
Other (not specified) | Carmody 1982^244^ | 3380 | 54 | 30 (0.8) | 24 (0.7) | NR | NR | NR
Other (not specified) | Tomkinson 2005^89^ | 6730 | 225 | 53 (0.79) | 172 (3) | NR | 153 (2.3) | 41 (0.61)
Other (not specified) | Peeters 1999^119^ | 1508 | 44 | 39 (2.6) | 5 (0.3) | NR | NR | NR
Other (not specified) | Pfaff 2016^120^ | 2697 | 97 | 97 (3.6) | NR | NR | NR | 59 (2.2)
Other (not specified) | Bhattacharyya 2015^80, 81^ | 79520 | 1652 | NR | NR | 1652 (2.1) | 1652 (2.1) | NR
Other (not specified) | Clark 2004^90^ | 131577 | 500 | NR | NR | 500 (0.38) | NR | 500 (0.38)
Other (not specified) | Duval 2015^82^ | 39906 | 935 | NR | NR | 935 (2.3) | NR | 463 (1.2)
Other (not specified) | Kvarner 2009^127^ | 34955 | 157 | NR | NR | 157 (0.45) | 157 (0.45) | NR
Other (not specified) | Colclasure 1990^111^ | 2011 | 36 | 7 (0.35) | 29 (1.4) | 0 (0) | 12 (0.60) | 7 (0.35)
Other (not specified) | Crysdale 1986^114^ | 7974 | 199 | 199 (2.5) | NR | NR | 0 | NR
Other (not specified) | Herdman 1986^115^ | 2400 | 13 | 13 (0.54) | 0 | NR | NR | 0
Other (not specified) | Lannigan 1993^109^ | 4386 | 25 | 25 (0.6) | NR | NR | NR | 18 (0.41)
Other (not specified) | Liu 2001^107^ | 1438 | 134 (evaluations for PTH in 112 children) | 9 (0.63) | 125 (9) | NR | 60 (4.2) | 20 (1.4)
Other (not specified) | Padia 2015^83^ | 15953 | 1187 | NR | NR | 1187 (7.4) | NR | 413 (2.6)
Totals
All arms | NA | 1147321 | 23661 (2.1) | 957 (0.08) | 1422 (0.12) | 21282 (1.9) | 8342 (0.73) | 4694 (0.41)
OSDB | NA | 44318 | 597 (1.4) | 149 (1.4) | 183 (1.6) | 265 (0.80) | 155 (1.4) | 214 (0.50)
Throat Infection | NA | 4056 | 187 (4.6) | NR | 150 (6.3) | 37 (2.2) | NR | 2 (0.13)
Mixed | NA | 449923 | 8771 (1.95) | 344 (1.2) | 518 (1.8) | 7909 1.9() | 5600 (3.1) | 395 (1.1)
Unspecified | NA | 649024 | 14106 (2.2) | 464 (1.3) | 571 (2.4) | 13071 (2.1) | 2587 (0.58) | 4083 (0.78)

* The authors of this study reported bleeding rates on children with recurrent throat infection and OSDB in further publications.

N=Number; NR=Not Reported; OSDB=Obstructive Sleep Disordered Breathing; PTH=Post-Tonsillectomy Hemorrhage

## Other Harms

Table H-8 Revisits for pain, nausea, or dehydration reported in case series, database, or registry studies

Technique | Indication Author, Year | Total Arm N | Pain Revisits/Readmissions, n (%) | Dehydration Revisits/Readmissions, n (%) | PONV Revisits/Readmissions, n (%) | Mixed/Other Revisits/Readmissions, n (%)
Coblation tonsillectomy | Mixed
Coblation tonsillectomy | Walner 2012^95^ | 1,918 | NR | 29 (1.5) | NR | NR
Unspecified Tonsillectomy | Mixed
Unspecified Tonsillectomy | Elinder 2016^121-123^ | 18,712 | NR | NR | NR | Unplanned contact of health care provider 2,180 (11.6)
Unspecified Tonsillectomy | Mahant 2014 ^84, 85^ | 139,715 | 1060 (0.8) | Revisit for dehydration and vomiting 3,011(2.2) | NR | NR
Unspecified Tonsillectomy | Edmonson 2015^79^ | 35,085 | Acute post-op pain 354 (6.9) Throat pain 224 (4.2) | 311 (7.6) | PONV 118 (0.37) Vomiting alone 106 (0.3) | NR
Unspecified Tonsillectomy | Mills 2004^102^ | 4,853 | NR | NR | Vomiting requiring admission overnight 107 (2.7) | Rehydration or analgesia 24 (0.5)
Unspecified Tonsillectomy | Achar 2015^94^ | 3,527 | NR | NR | NR | ER visit for pain relief, poor oral intake, fever, and NV 346 (9.8)
Unspecified Tonsillectomy | Not Specified
Unspecified Tonsillectomy | Mahadevan 2016^117^ | 5,400 | 74 (1.37) | 4 (0.07) | 32 (0.59) | Fever or Drug Reaction 2 (.03)
Unspecified Tonsillectomy | Bhattacharyya 2014^80^ | 79,520 | 1,180 (1.5) | NR | 7503 (1.4) | Fever/NV/Dehydration 1,765 (2.2)
Unspecified Tonsillectomy | Duval 2015^82^ | 39,906 | NR | 898 (2.3) | NR | NR
Unspecified Tonsillectomy
Unspecified Tonsillectomy | Colclasure 1990^111^ | 2,011 | NR | 2 (0.05) [Not specific to age group] | NR | NR
Unspecified Tonsillectomy | Granell 2004^103^ | 1,243 | NR | Poor oral intake 2 (0.2) | NR | NR
Totals | (N studies)
Totals | All (11) | 331890 | 2668 (0.11) | 4257 (1.9) | 7760 (6.2) | 4317 (3.8)
Totals | Coblation total tonsillectomy (1) | 1,918 | NR | 29 (1.5) | NR | NR
Totals | Unspecified tonsillectomy (10) | 329972 | 2668 (0.11) | 4228 (1.9) | 7760 (6.2) | 4317 (3.8)

ER=Emergency Room; N=Number; NR=Not Reported; NV= Nausea and Vomiting; PONV=Postoperative Nausea and Vomiting

Table H-9 Other harms reported in case series and database studies

Author Study Design RoB | Indication | Intervention | Total Arm N | Harms of Intervention N (%) | Mortality N (%) | VPI N (%)
Odhagen 2016^131^ Registry Low | OSDB, Throat Infection | Total or partial tonsillectomy (unspecified) | Total: 11741 Partial: 15794 | Total tonsillectomy Total reoperations 75 (0.6) Reoperation for airway obstruction 49 (66.2) Reoperation for Infection 11 (14.9) Reoperation for Other cause 14 (18.9) Partial tonsillectomy Total reoperation 609 (3.9) Reoperation for airway obstruction 501 (82.3) Reoperation for Infection 73 (12) Reoperation for Other cause 35 (5.7) | NR | NR
Mahadevan 2016^117^ Case Series Moderate | Not Specified | Tonsillectomy (unspecified) | 5,400 | NR | Died within 1 month of tonsillectomy due to ventricular fibrillation, not direct link to tonsillectomy surgery 1(.01) | NR
Raol 2016^93^ Database Low | Not Specified | Tonsillectomy (unspecified) | 40,591 | Respiratory failure 383 (0.94) | Children's Teaching Hospital (n=10,220) ≤10 (0.09) Non-Children's Teaching Hospital (n=20,176) ≤10 (0.04) Nonteaching Hospital (n=8,235) ≤10 (0.12) | NR
Lavin 2015^132^ Database Low | OSDB | Tonsillectomy (unspecified) | 21,434 (899 Obese, 20535 Non-obese) Weighted N | Obese T&A patients respiratory complications 146 (16.2) Obese T&A patients major respiratory complications (pulmonary insufficiency or respiratory failure) 45 (5.04) Non-obese T&A patients respiratory complications 1984 (9.7) Non-obese T&A major respiratory complications (pulmonary insufficiency or respiratory failure) 617(3.0) | No deaths in obese T&A patients 0 (0) | NR
Shay 2015^81^ Case Series Low | Not Specified | Tonsillectomy (unspecified) | 36,221 | NR | 2(0.005) | NR
Walner 2012^95^ Database/Registry Moderate | OSDB, Throat Infection | Coblation total tonsillectomy | 1,918 | NR | 0(0) | NR
Tweedie 2012^133^ Case Series Moderate | OSDB, Throat Infection | Tonsillectomy (unspecified) | 1,735 | Postoperative desaturation or pulmonary edema or lung collapse 13 (0.75) Postoperative aspiration 2 (0.12) Malignany hyperpyrexia 1 (0.06) | 0(0) | NR
Sarny 2011^125, 126^ Database/Registry Low | Not Specified | Tonsillectomy (unspecified) | 9,405 | NR | 0(0) | NR
Bhattacharyya 2010^134^ Database/Registry Moderate | Not Specified | Tonsillectomy (unspecified) | 535,949 | Airway obstruction NR (0.04) | NR | NR
Jones 2007^101^ Case Series Moderate | OSDB, Throat Infection | Tonsillectomy, (unspecified) | 2,554 | NR | NR | 61(2.7)
Granell 2004^103^ Case Series Moderate | OSDB, Throat Infection | Tonsillectomy (unspecified) | 1,243 | NR | 0(0) | NR
Windfuhr 2001^104-106^ Case Series Moderate | OSDB, Throat Infection | Tonsillectomy (unspecified) | 2,567 | NR | 1(0.04) | NR
Peters 1999^119^ Case Series Moderate | Not Specified | Tonsillectomy including Adenotonsillectomy (unspecified) | 1,508 | NR | 0(0) | NR
Herdman 1986^115^ Case Series Moderate | Not Specified | Tonsillectomy (unspecified) | 2,400 | NR | 0(0) | NR
Kristensen 1984^135^ Case Series Moderate | OSDB, Throat Infection | Tonsillectomy (unspecified) | 1,150 | 0(0) | 0(0) | NR
Carmody 1982^116^ Case Series Moderate | Not Specified | Tonsillectomy (unspecified) | 3,756 (1649 0-19 yrs) | NR | 0(0) | NR

## Studies of Perioperative or Postoperative Medications

### Bleeding-Related Harms

Table H-10 Bleeding-related outcomes in comparative study arms evaluating perioperative medications

Drug class | Indication Author, Year | Intervention | Total Arm N | Total PTH | Primary PTH n (%) | Secondary PTH n (%) | Undefined PTH n (%) | Nonoperative Readmission or Revisit for PTH n (%) | Reoperation for PTH n (%)
Steroid | Mixed
Steroid | Gallagher 2012^136^ | Dexamethasone, 0.5 mg/kg (injection) | 154 | 17 | 2 (1) | NR | 15 (9.7) | 3 (1.9) | 3 (1.9)
Steroid | Czarnetzki 2008^137^ | Dexamethasone, 0.5 mg/kg (IV) | 52 | 12 | NR | NR | 12 (24) | NR | 4 (8)
Steroid | Czarnetzki 2008^137^ | Dexamethasone, 0.05 mg/kg (IV) | 53 | 6 | NR | NR | 6 (11) | NR | 3 (6)
Steroid | Czarnetzki 2008^137^ | Dexamethasone, 0.15 mg/kg (IV) | 54 | 2 | 0 | 0 | 2 (4) | NR | 1 (2)
Steroid | Hanasono 2004^138^ | Cold tonsillectomy+ dexamethasone, 1 mg/kg (IV) | 44 | 1 | NR | NR | 1 (2.3) | 1 (2) | NR
Steroid | Aysenur 2014^139^ | Dexamethasone sodium phosphate, 1 mg/kg (infiltration) | 20 | 0 | 0 | 0 | 0 | 0 | 0
Steroid | Hermans 2012^140^ | Dexamethasone, 0.15 mg/kg (IV) | 46 | 0 | NR | NR | 0 | NR | 0
Steroid | Hermans 2012^140^ | Dexamethasone, 0.5 mg/kg (IV) | 44 | 0 | NR | NR | 0 | NR | 0
Steroid | Aouad 2012^141^ | Methylprednisolone, 2.5 mg/kg (IV) | 78 | 0 | 0 | 0 | 0 | 0 | 0
Steroid | Aouad 2012^141^ | Dexamethasone, 0.5 mg/kg (IV) | 75 | 0 | 0 | 0 | 0 | 0 | 0
Steroid | Hanasono 2004^138^ | Hot tonsillectomy+ dexamethasone, 1 mg/kg (IV) | 62 | 0 | NR | NR | 0 | 0 | NR
Steroid | Unspecified
Steroid | Elhakim 2003^142^ | Dexamethasone, 0.5 mg/kg (IV) | 55 | 0 | NR | 0 | NR | NR | NR
Steroid | Alajmi 2008^143^ | Dexamethasone, 1mg/kg (IV) | 42 | 0 | NR | 0 | NR | 0 | NR
Steroid | Kaan 2006^144^ | Dexamethasone | 32 | 0 | NR | NR | NR | NR | 0
NSAIDs | Throat infection
NSAIDs | Abdel-Ghaffar 2015^145^ | Lornoxicam in one tonsil , 8 mg (infiltration) | 34 | 0 | NR | NR | NR | 0 | 0
NSAIDs | Unspecified
NSAIDs | Solanki 2012^146^ | Diclofenac, 2 mg/kg (rectal) | 25 | 3 | NR | NR | 3 (12) | NR | NR
NSAIDs | Moss 2014^147^ | Ibuprofen, 10 mg/kg (IV) | 73 | 2 | NR | NR | 2 (3) | 0 | 1 (1.4)
NSAIDs | Lee 2009^148^ | Ketorolac, preoperative, 1 mg/kg (IV) | 24 | 1 | NR | NR | 1 (4) | NR | NR
NSAIDs | Keidan 2004^149^ | Ketoroloc, 1 mg/kg^-1^ (IV) | 25 | 0 | NR | NR | 0 | NR | NR
NSAIDs | Lee 2009^148^ | Ketorolac, perioperative, 1 mg/kg (IV) | 26 | 0 | NR | NR | 0 | NR | NR
NSAIDs | Kedek 2005^150^ | Ibuprofen, 10 mg/kg (oral) | 20 | 0 | NR | NR | 0 | NR | NR
Non-NSAID Analgesics | Unspecified
Non-NSAID Analgesics | Lee 2009^148^ | Propacetamol, perioperative, 30 mg/kg (IV) | 26 | 0 | NR | NR | 0 | NR | NR
Non-NSAID Analgesics | Keidan 2004^149^ | Fentanyl, 2 μg/kg^-1^(IV) | 32 | 0 | NR | NR | 0 | NR | NR
Non-NSAID Analgesics | Lee 2009^148^ | Propacetamol, preoperative, 30 mg/kg (IV) | 26 | 0 | NR | NR | 0 | NR | NR
Anesthetic | Mixed
Anesthetic | Aysenur 2014^139^ | Levobupivacaine with epinephrine, ND (infiltration) | 20 | 0 | 0 | 0 | 0 | 0 | 0
Anesthetic | Unspecified
Anesthetic | Safavi 2012^146^ | Bupivacaine (0.25%), 5 mL (infiltration) | 25 | 4 | NR | NR | 4 (16) | NR | NR
Placebo | Throat infection
Placebo | Abdel-Ghaffar 2015^145^ | peritonsillar saline in other tonsil (infiltration) | 34 | 0 | NR | NR | NR | 0 | 0
Placebo | Abdel-Ghaffar 2015^145^ | bilateral peritonsillar saline (infiltration) | 68 | 0 | NR | NR | NR | 0 | 0
Placebo | Mixed
Placebo | Gallagher 2012^136^ | placebo (saline), 0.5 mg/kg (injection) | 151 | 13 | 2 (1) | NR | 11 (7.3) | 5 (3.2) | 1 (0.6)
Placebo | Czarnetzki 2008^137^ | Placebo (saline), NR (IV) | 54 | 2 | NR | NR | 2 (4) | NR | 0
Placebo | Hermans 2012^140^ | Placebo (saline), 0.5 mL/kg (IV) | 44 | 1 | NR | NR | 1 (2) | NR | 1 (2)
Placebo | Hanasono 2004^138^ | Cold tonsillectomy+placebo, 1 mg/kg (IV) | 57 | 1 | NR | NR | 1 (1.8) | 1 (1.8) | NR
Placebo | Aysenur 2014^139^ | Saline, ND (infiltration) | 20 | 0 | 0 | 0 | NR | 0 | 0
Placebo | Hanasono 2004^138^ | Hot tonsillectomy+placebo, 1 mg/kg (IV) | 56 | 0 | NR | NR | 0 | 0 | NR
Placebo | Unspecified
Placebo | Alajmi 2008^143^ | Placebo, 5 mL (IV) | 38 | 3 | NR | 3 (7.9) | NR | 3 (7.9) | NR
Placebo | Moss 2014^147^ | Placebo (normal saline), 10 mg/kg (IV) | 65 | 1 | NR | NR | 1 (2) | NR | 0
Placebo | Elhakim 2003^142^ | Placebo (saline), 0.5 mg/kg (IV) | 55 | 0 | NR | 0 | NR | NR | NR
Placebo | Kaan 2006^144^ | Placebo (saline), 0.5 mg/kg (IV) | 30 | NR | NR | NR | NR | NR | 0
Totals | (N arms)
| All arms | NA | 1839 | 69 (3.8) | 4 (0.7) | 3 (0.66) | 51 (5.9) | 13 (1.4) | 14 (1.2)
| Steroids (14) | NA | 811 | 38 (4.7) | 2 (0.61) | 0 (0) | 36 (7.1) | 4 (0.84) | 11 (1.8)
| Placebo (12) | NA | 672 | 21 (3.3) | 2 (0.89) | 3 (1.8) | 16 (3.6) | 9 (2.1) | 2 (0.43)
| NSAIDs (7) | NA | 227 | 6 (2.6) | NR | NR | 5 (2.96) | 0 (0) | 1 (0.93)
| Anesthetics (2) | NA | 45 | 4 (8.9) | 0 (0) | 0 (0) | 4 (8.9) | 0 (0) | 0 (0)
| Non-NSAID Analgesics (3) | NA | 84 | 0 (0) | NR | 0 (0) | 0 (0) | NR | NR

N=Number; NR=Not Reported; NSAID=Nonsteroidal Anti-Inflammatory Drug; PTH=Post-Tonsillectomy Hemorrhage

Table H-11 Bleeding-related outcomes in comparative study arms evaluating postoperative medications for pain

Drug class | Indication Author, Year | Intervention | Total Arm N | Total PTH, n | Primary PTH n (%) | Secondary PTH n (%) | Other/Undefined PTH n (%) | Nonoperative Readmission or Revisit for PTH n (%) | Reoperation for PTH n (%)
NSAIDs | Throat infection
NSAIDs | Stage 1988^151^ | Acetylsalicylic acid (Oral, dose not specified) | 423 | 18 | 5 (1.2) | 13 (3.1) | NR | NR | 8 (2)
NSAIDs | Mixed
NSAIDs | Ozkiris 2012^152^ | Ibuprofen, 30 mg/kg/day (Oral) | 115 | 6 | NR | NR | 6 (5.21) | NR | 1 (1)
NSAIDs | Unspecified
NSAIDs | Murto 2015^153^ | Celecoxib, 6 mg/kg preoperative and 3 mg/kg post-op (Oral) | 141 | 8 | NR | NR | 8 (5.7) | 8 (5.7) | 3 (2.1)
Non-NSAID analgesics | Throat infection
Non-NSAID analgesics | Stage 1988^151^ | Acetaminophen (Oral) | 409 | 9 | 7 (1.7) | 2 (0.49) | NR | NR | 3 (1)
Non-NSAID analgesics | Mixed
Non-NSAID analgesics | Ozkiris 2012^152^ | Metamizole sodium, 0.4 mg/kg/day (Oral) | 115 | 4 | NR | NR | 4 (3.47) | NR | 0
Non-NSAID analgesics | Ozkiris 2012^152^ | Acetaminophen, 40 mg/kg/day (Oral) | 110 | 4 | NR | NR | 4 (3.63) | NR | 0
Non-NSAID analgesics | Unspecified
Non-NSAID analgesics | Lalicevic et al. 2004^154^ | Benzydamine hydrochloride oral rinse, 20 mg/kg (Oral) | 138 | 6 | NR | NR | 6 (4.3) | NR | NR
Steroids | Mixed
Steroids | Park 2015^155^ | Prednisolone, 0.25 mg/kg/day (Oral) | 69 | 2 | NR | NR | 2 (2.5) | NR | NR
Steroids | Macassey et al. (2012)^156^ | Prednisolone syrup, 0.5 mg/kg (Oral) | 91 | 11 | NR | NR | 11 (12) | 1 (1) | NR
Other | Unspecified
Other | Lalicevic 2004^154^ | Salvia officinalis oral rinse, 20 mg/kg (Oral) | 140 | 6 | NR | NR | 6 (4.3) | NR | NR
No treatment/Placebo | Throat infection
No treatment/Placebo | Macassey 2012^156^ | Placebo syrup, 0.5 mg/kg (Oral) | 102 | 13 | NR | NR | 13 (12) | 1 (1) | NR
No treatment/Placebo | Park 2015^155^ | No Prednisolone | 69 | 2 | NR | NR | 2 (2.5) | NR | NR
No treatment/Placebo | Unspecified
No treatment/Placebo | Murto 2015^153^ | Placebo | 141 | 8 | NR | NR | 8 (5.7) | 8 (5.7) | 2 (1.4)
Totals | (N arms)
Totals | All arms (13) | NA | 2063 | 97 (4.7) | 12 (1.4) | 15 (1.8) | 70 (5.7) | 18 (3.8) | 17 (1.2)
Totals | NSAIDs (3) | NA | 679 | 32 (4.7) | 5 (1.2) | 13 (3.1) | 14 (5.5) | 8 (5.7) | 12 (1.8)
Totals | Non-NSAID analgesics (4) | NA | 772 | 23 (3.0) | 7 (1.7) | 2 (0.49) | 14 (3.9) | NR | 3 (0.47)
Totals | Steroids (2) | NA | 160 | 13 (8.1) | NR | NR | 13 (8.1) | 1 (1.1) | NR
Totals | Other (1) | NA | 140 | 6 (4.3) | NR | NR | 6 (4.3) | NR | NR
Totals | No treatment/Placebo (3) | NA | 312 | 23 (7.4) | NR | NR | 23 (7.4) | 9 (3.7) | 2 (1.4)

N=Number; NR=Not Reported; NSAID=Nonsteroidal Anti-Inflammatory Drug; PTH=Post-Tonsillectomy Hemorrhage

### Other Harms

Table H-12 Revisits or readmissions for pain, dehydration, and PONV reported in comparative study arms addressing perioperative agents

Drug Class | Author | Perioperative Agent | Total Arm N | N Pain Revisits, (%) | N Dehydration Revisits, (%) | N PONV Revisits, (%)
Steroids | Gao^157^ | Dexamethasone (IV) | 78 | 0 (0) | NR | 0
Steroids | Gao^157^ | Dexamethasone (infiltration) | 78 | 0 (0) | NR | 0
Steroids | Hanasono^138^ | Dexamethasone | 61 | NR | 1 (1.6) | NR
Steroids | Alajmi^143^ | Dexamethasone | 42 | 0 (0) | 0 | 0
Steroids | Elhakim^142^ | Dexamethasone | 20 | 0 (0) | 0 | 0
NSAIDs | Oztekin^158^ | Diclofenac | 20 | 0 (0) | 0 | 0
Anesthetic | ^*^El-Fattah^159^ | Propofol | 80 | 0 (0) | 0 | 0
Placebo/no agent | Hanasono^138^ | Placebo | 56 | NR | 0 | NR
Placebo/no agent | Sukhani^160^ | Placebo | 49 | NR | NR | ER or hospital admit for vomiting and poor oral intake 1 (2)
Placebo/no agent | Alajmi^143^ | Placebo | 38 | Readmitted for throat pain/dysphagia 4 (10.5) | NR | NR
Placebo/no agent | Oztekin^158^ | No perioperative agent | 20 | 0 (0) | 0 | 0
Totals | (N arms)
Totals | All arms (11) | NA | 542 | 4 (1.1) | 1 (0.33) | 1 (0.26)
Totals | Steroids (5) | NA | 279 | 0 | 1 (1.6) | 0
Totals | NSAIDs (1) | NA | 20 | 0 | 0 | 0
Totals | Anesthetic (1) | NA | 80 | 0 | 0 | 0
Totals | Placebo (4) | NA | 163 | 4 (6.9) | 0 | 1 (1.4)

* Indication for surgery in these arms was throat infection; indication not specified in all other arms

N=Number; NR=Not Reported; NSAID=Nonsteroidal Anti-Inflammatory Drug

### Rescue Medications

Table H-13 Need for rescue analgesics and anti-emetics reported in studies addressing perioperative medications

Author, Year Study Design Age range | Intervention Groups (N) | Surgical Technique | Criteria for using rescue analgesia/rescue antiemetics | Assessment Timepoint | Rescue Analgesic Needed, N (%) or mean ± SD Rescue Antiemetic Needed, N (%) or mean ± SD | Group Differences
Steroids
Gao 2015^157^ RCT 5-10 low | G1: Intravenous dexamethasone, 0.5mg/kg (IV) (78) G2: Local infiltration dexamethasone, 0.5mg/kg (infiltration) (78) G3: Control (no dexamethasone)(79) | sharp dissection technique with cautery hemostasis | mCHEOPS score > 4 assessed by anesthesiologist Vomiting > 2 times in 2 minutes | From PACU to 24 hrs post-op | Doses of IV fentanyl needed, mean(μg) ± SD G1: 14.2 ± 12 G2: 9.4 ± 6.8 G3: 23.1 ± 17.5 | G1 vs. G3, p < 0.01 G2 vs. G3, p < 0.01 G1 vs. G2, p = 0.002
Gao 2015^157^ RCT 5-10 low | G1: Intravenous dexamethasone, 0.5mg/kg (IV) (78) G2: Local infiltration dexamethasone, 0.5mg/kg (infiltration) (78) G3: Control (no dexamethasone)(79) | sharp dissection technique with cautery hemostasis | mCHEOPS score > 4 assessed by anesthesiologist Vomiting > 2 times in 2 minutes | From PACU to 24 hrs post-op | Number of patients needing 2nd injection of fentanyl, G1: 9/44 (20.5) G2: 0/32 (0) G3: 17/60 (28.3) | G1 vs. G3, p = NR G2 vs. G3, p = NR G1 vs. G2, p = NR
Gao 2015^157^ RCT 5-10 low | G1: Intravenous dexamethasone, 0.5mg/kg (IV) (78) G2: Local infiltration dexamethasone, 0.5mg/kg (infiltration) (78) G3: Control (no dexamethasone)(79) | sharp dissection technique with cautery hemostasis | mCHEOPS score > 4 assessed by anesthesiologist Vomiting > 2 times in 2 minutes | From PACU to 24 hrs post-op | Doses of IV metoclopramide, mean ± SD G1: 1.9 ± 0.5 G2: 2.3 ± 0.9 G3: 4.1 ± 1.2 | G1 vs. G3, p < 0.001 G2 vs. G3, p < 0.001 G1 vs. G2, p < 0.001
Aysenur 2014^139^ RCT 3-14 moderate | G1: Dexamethasone sodium phosphate, 1 mg/kg (infiltration) (20) G2: Levobupivacaine with epinephrine (infiltration) (20) G3: Saline (infiltration) (20) | A standard dissection and snare technique | Upon Request NA | POD0 | Number of analgesic interventions needed (paracetamol suspension) – POD0, G1: 2.5±0.5 G2: 2.8±0.3 G3: 3.5±0.5 | G1 vs. G2, p<0.05 G1 vs. G3, p<0.05 G2 vs. G3, p <0.05
Aysenur 2014^139^ RCT 3-14 moderate | G1: Dexamethasone sodium phosphate, 1 mg/kg (infiltration) (20) G2: Levobupivacaine with epinephrine (infiltration) (20) G3: Saline (infiltration) (20) | A standard dissection and snare technique | Upon Request NA | POD1 | Number of analgesic interventions needed (paracetamol suspension) – POD1, G1: 2±0.3 G2: 2.6±0.5 G3: 3.3±0.4 | G1 vs. G2, p<0.05 G1 vs. G3, p<0.05 G2 vs G3, p = ns
Aysenur 2014^139^ RCT 3-14 moderate | G1: Dexamethasone sodium phosphate, 1 mg/kg (infiltration) (20) G2: Levobupivacaine with epinephrine (infiltration) (20) G3: Saline (infiltration) (20) | A standard dissection and snare technique | Upon Request NA | POD2 | Number of analgesic interventions needed (paracetamol suspension) – POD2, G1: 1.9±0.3 G2: 2.5±0.5 G3: 3.2±0.4 | G1 vs. G2, p<0.05 G1 vs. G3, p<0.05 G2 vs G3, p < 0.05
Aysenur 2014^139^ RCT 3-14 moderate | G1: Dexamethasone sodium phosphate, 1 mg/kg (infiltration) (20) G2: Levobupivacaine with epinephrine (infiltration) (20) G3: Saline (infiltration) (20) | A standard dissection and snare technique | Upon Request NA | POD3 | Number of analgesic interventions needed (paracetamol suspension) – POD3, G1: 1.9±0.3 G2: 2.4±0.6 G3: 3.1±0.3 | G1 vs. G2, p<0.05 G1 vs. G3, p<0.05 G2 vs G3, p < 0.05
Aysenur 2014^139^ RCT 3-14 moderate | G1: Dexamethasone sodium phosphate, 1 mg/kg (infiltration) (20) G2: Levobupivacaine with epinephrine (infiltration) (20) G3: Saline (infiltration) (20) | A standard dissection and snare technique | Upon Request NA | POD7 | Number of analgesic interventions needed (paracetamol suspension) – POD7, G1: 1.4±0.6 G2: 2.2±0.4 G3: 2.6±0.4 | G1 vs. G2, p<0.05 G1 vs. G3, p<0.05 G2 vs G3, p < 0.05
Faiz 2013^161^ RCT 4-13 moderate | G1: Dexamethasone, 0.1 mg/kg (IV) (42) G2: Acetaminophen, 15 mg/kg (IV) (42) | Unspecified tonsillectomy | Objective pain score ≥5 | post-op (Ward) | N needing IV meperidine (mg), (%) G1: 7 (17) G2: 5 (12) | G1 vs. G2, p = 0.533
Faiz 2013^161^ RCT 4-13 moderate | G1: Dexamethasone, 0.1 mg/kg (IV) (42) G2: Acetaminophen, 15 mg/kg (IV) (42) | Unspecified tonsillectomy | Appearance of vomiting | | N needing IV ondansetron (mg), (%) G1: 0 (0) G2: 1 (2) | G1 vs. G2, p = 0.314
Hermans 2012^140^ RCT 2-18 low | G1: Dexamethasone, 0.15 mg/kg (IV) (46) G2: Dexamethasone, 0.5 mg/kg (IV) (44) G3: Placebo (saline), 0.5 mL/kg (IV) (44) | Cold dissection | CHEOPS score >7 or VAS score ≥3 | From PACU until discharge from hospital | N needing IV morphine (μg), (%) G1: 20 (43.5) G2: 16 (36) G3: 23 (52) | G1 vs. G2 vs. G3, p = 0.321
Hermans 2012^140^ RCT 2-18 low | G1: Dexamethasone, 0.15 mg/kg (IV) (46) G2: Dexamethasone, 0.5 mg/kg (IV) (44) G3: Placebo (saline), 0.5 mL/kg (IV) (44) | Cold dissection | Vomiting and/or retching without expulsion of gastric content | | N needing IV tramadol (mg), (%) G1: 17 (37) G2: 18 (40) G3: 23 (52) | G1 vs. G2 vs. G3, p = 0.331
Hermans 2012^140^ RCT 2-18 low | G1: Dexamethasone, 0.15 mg/kg (IV) (46) G2: Dexamethasone, 0.5 mg/kg (IV) (44) G3: Placebo (saline), 0.5 mL/kg (IV) (44) | Cold dissection | Vomiting and/or retching without expulsion of gastric content | | N needing IV alizapride (mg), (%) G1: 5 (10.9) G2: 5 (11.4) G3: 22 (50) | G1 vs. G2 vs. G3, p = 0.005
Hermans 2012^140^ RCT 2-18 low | G1: Dexamethasone, 0.15 mg/kg (IV) (46) G2: Dexamethasone, 0.5 mg/kg (IV) (44) G3: Placebo (saline), 0.5 mL/kg (IV) (44) | Cold dissection | Vomiting and/or retching without expulsion of gastric content | | N needing IV tropisetron (mg), (%) G1: 1 (2.2) G2: 1 (2.3) G3: 3 (7) | G1 vs. G2 vs. G3, p = 0.578
Aouad 2012^141^ RCT 2-12 low | G1: Methylprednisolone, 2.5 mg/kg (IV) (78) G2: Dexamethasone, 0.5 mg/kg (IV) (75) | Electrocautery | Wong-Baker faces pain score >6 | From PACU to 24 hrs post-op | N needing single dose of IV morphine (mg), (%) G1: 3 (3.8) G2: 3 (4) | G1 vs. G2, p = NR
Aouad 2012^141^ RCT 2-12 low | G1: Methylprednisolone, 2.5 mg/kg (IV) (78) G2: Dexamethasone, 0.5 mg/kg (IV) (75) | Electrocautery | Upon request | From PACU to 24 hrs post-op | Doses of IV paracetamol (mg), median (range) G1: 2 (0-4) G2: 3 (1-4) | G1 vs. G2, p = 0.26
Aouad 2012^141^ RCT 2-12 low | G1: Methylprednisolone, 2.5 mg/kg (IV) (78) G2: Dexamethasone, 0.5 mg/kg (IV) (75) | Electrocautery | Recurrent vomiting >2 episodes less than 5 minutes apart | From PACU to 24 hrs post-op | N needing IV ondansetron (mg), (%) G1: 1 (1) G2: 2 (3) | G1 vs. G2, p = 0.62
Khani 2009^162^ RCT 4-12 low | G1: Dexamethasone, 0.5 mg/kg (IV) (33) G2: Placebo (saline), 0.5 mg/kg (IV) (33) | Unspecified tonsillectomy with or without adenoidectomy | “Faces” pain scale (unspecified) | 8 hrs post-op | Patients needing IV morphine (μg), G1: 5 (15.1) G2: 16 (48.4) | G1 vs. G2, p < 0.05
Khani 2009^162^ RCT 4-12 low | G1: Dexamethasone, 0.5 mg/kg (IV) (33) G2: Placebo (saline), 0.5 mg/kg (IV) (33) | Unspecified tonsillectomy with or without adenoidectomy | Vomiting > 2 times | PACU | Patients needing IV metoclopramide (mg), G1: 6 (18.1) G2: 17 (51.5) | G1 vs. G2, p <0.001
Alajmi 2008^143^ RCT 5-18 moderate | G1: Dexamethasone, 1mg/kg (IV) (42) G2: Placebo, 5 mL (IV) (38) | Cold dissection | When patient complained of pain | PACU to 24 hrs post-op | Patients needing oral Profinal (mg), G1: 6 (14) G2: 18 (47) | G1 vs. G2, p = 0.001
Alajmi 2008^143^ RCT 5-18 moderate | G1: Dexamethasone, 1mg/kg (IV) (42) G2: Placebo, 5 mL (IV) (38) | Cold dissection | Vomiting > 2 times | 6 hrs post-op | N needing oral metoclopramide (mL), (%) G1: 2 (4.8 ) G2: 25 (65.8 ) | G1 vs. G2, p<0.001
Czarnetzki 2008^137^ RCT 2-17 moderate | G1: Dexamethasone, 0.05 mg/kg (IV) (53) G2: Dexamethasone, 0.15 mg/kg (IV) (54) G3: Dexamethasone, 0.5 mg/kg (IV) (52) G4: Placebo (saline) (IV) (54) | Total tonsillectomy with dissection (cold dissection, hot dissection, or combination) | VAS pain score ≥ 3, CHEOPS pain score ≥8, revised Faces Pain Scale ≥3 | PACU | N needing IV morphine (mg) in PACU, (%) G1: 42 (78) G2: 36 (79) G3: 37 (67) G4: 42 (78) | G1 vs. G2 vs. G3 vs. G4, p = 0.42
Czarnetzki 2008^137^ RCT 2-17 moderate | G1: Dexamethasone, 0.05 mg/kg (IV) (53) G2: Dexamethasone, 0.15 mg/kg (IV) (54) G3: Dexamethasone, 0.5 mg/kg (IV) (52) G4: Placebo (saline) (IV) (54) | Total tonsillectomy with dissection (cold dissection, hot dissection, or combination) | Unspecified | Within 24 hrs post-op | N needing oral ibuprofen (mg), (%) G1: 20 (38) G2: 23 (43) G3: 20 (38) G4: 35 (65) | G1 vs. G2 vs. G3 vs. G4, p = 0.01
Czarnetzki 2008^137^ RCT 2-17 moderate | G1: Dexamethasone, 0.05 mg/kg (IV) (53) G2: Dexamethasone, 0.15 mg/kg (IV) (54) G3: Dexamethasone, 0.5 mg/kg (IV) (52) G4: Placebo (saline) (IV) (54) | Total tonsillectomy with dissection (cold dissection, hot dissection, or combination) | Unspecified | Within 24 hrs post-op | N needing IV ondansetron (μg), (%) G1: 4 (8) G2: 3 (5.6) G3: 2 (4) G4: 11 (20) | G1 vs. G2 vs. G3 vs. G4, p = 0.04
Kim 2007^163^ RCT 2-7 moderate | G1: Dexamethasone, 0.0625 mg/kg (IV) (24) G2: Dexamethasone, 0.125 mg/kg (IV) (25) G3: Dexamethasone, 0.25 mg/kg (IV) (23) G4: Dexamethasone, 0.5 mg/kg (IV) (25) G5: Dexamethasone, 1 mg/kg (IV) (24) | Electrocautery | Objective pain score ≥6 for 2 consecutive 5 minute intervals or if the patients articulated that their throat hurt NA | 0-24 hours post-op | Need for IV morphine (mg) (up to 24 hrs), G1: NR G2: NR G3: NR G4: NR G5: NR | G1 vs. G2 vs. G3 vs. G4 vs. G5, p > 0.05
Kaan 2006^144^ RCT 4-12 low | G1: Dexamethasone, 0.5 mg/kg (IV) (32) G2: Placebo (saline), 0.5 mg/kg (IV) (30) | Cold dissection | “Faces” scale pain score >3 | PACU | N needing IV meperidine (mg), (%) G1: 8 (25) G2: 12 (40) | G1 vs G2, p = NR
Kaan 2006^144^ RCT 4-12 low | G1: Dexamethasone, 0.5 mg/kg (IV) (32) G2: Placebo (saline), 0.5 mg/kg (IV) (30) | Cold dissection | Retching or vomiting more than once in 3 minutes If vomiting was not under control in 20 minutes, ondansetron was given | 2 hrs post-op | N needing oral paracetamol (mg, 2 hrs), (%) G1: 6 (19) G2: 4 (13) | G1 vs G2, p = NR
Kaan 2006^144^ RCT 4-12 low | G1: Dexamethasone, 0.5 mg/kg (IV) (32) G2: Placebo (saline), 0.5 mg/kg (IV) (30) | Cold dissection | Retching or vomiting more than once in 3 minutes If vomiting was not under control in 20 minutes, ondansetron was given | 3 hrs post-op | N needing oral paracetamol (mg, 3 hrs), (%) G1: 11 (34) G2: 17 (57) | G1 vs G2, p = NR
Kaan 2006^144^ RCT 4-12 low | G1: Dexamethasone, 0.5 mg/kg (IV) (32) G2: Placebo (saline), 0.5 mg/kg (IV) (30) | Cold dissection | Retching or vomiting more than once in 3 minutes If vomiting was not under control in 20 minutes, ondansetron was given | 4 hrs post-op | N needing oral paracetamol (mg, 4 hrs), (%) G1: 12 (38) G2: 7 (23) | G1 vs G2, p = NR
Kaan 2006^144^ RCT 4-12 low | G1: Dexamethasone, 0.5 mg/kg (IV) (32) G2: Placebo (saline), 0.5 mg/kg (IV) (30) | Cold dissection | Retching or vomiting more than once in 3 minutes If vomiting was not under control in 20 minutes, ondansetron was given | 5 hrs post-op | N needing oral paracetamol (mg, 5 hrs), (%) G1: 3 (9) G2: 2 (7) | G1 vs G2, p = NR
Kaan 2006^144^ RCT 4-12 low | G1: Dexamethasone, 0.5 mg/kg (IV) (32) G2: Placebo (saline), 0.5 mg/kg (IV) (30) | Cold dissection | Retching or vomiting more than once in 3 minutes If vomiting was not under control in 20 minutes, ondansetron was given | 1-8 hrs post-op | N needing IV ondansetron (mg), (%) G1: 0 (0) G2: 0 (0) | G1 vs G2, p = NR
Kaan 2006^144^ RCT 4-12 low | G1: Dexamethasone, 0.5 mg/kg (IV) (32) G2: Placebo (saline), 0.5 mg/kg (IV) (30) | Cold dissection | Retching or vomiting more than once in 3 minutes If vomiting was not under control in 20 minutes, ondansetron was given | 1-8 hrs post-op | N needing IV metoclopramide (mg), (%) G1: 6 (19) G2: 10 (33) | G1 vs G2, p = NR
Samarkandi 2004^164^ 2-12 moderate | G1: Dexamethasone, 0.5 mg/kg (IV) (29) G2: Placebo (normal saline), 0.5 mg/kg (IV) (31) | Electrocautery | Unspecified (Rectal acetaminophen given to all children) Vomiting occurring less than 5 minutes apart or with persistent distressing emetic symptoms (Early=PACU, Late=Ward) | PACU | N needing suppository acetaminophen (mg, immediate), (%) G1: 10 (37) G2: 17 (54.8) | Need for analgesia, G1 vs G2, p = 0.275
Samarkandi 2004^164^ 2-12 moderate | G1: Dexamethasone, 0.5 mg/kg (IV) (29) G2: Placebo (normal saline), 0.5 mg/kg (IV) (31) | Electrocautery | Unspecified (Rectal acetaminophen given to all children) Vomiting occurring less than 5 minutes apart or with persistent distressing emetic symptoms (Early=PACU, Late=Ward) | Ward | N needing suppository acetaminophen (mg, late), (%) G1: 17 (63) G2: 14 (45.1) | Need for analgesia, G1 vs G2, p = 0.275
Samarkandi 2004^164^ 2-12 moderate | G1: Dexamethasone, 0.5 mg/kg (IV) (29) G2: Placebo (normal saline), 0.5 mg/kg (IV) (31) | Electrocautery | Unspecified (Rectal acetaminophen given to all children) Vomiting occurring less than 5 minutes apart or with persistent distressing emetic symptoms (Early=PACU, Late=Ward) | PACU | N needing IV metoclopramide (mg), (%) G1: 7 (24.1) G2: 15 (48.4) | G1 vs G2, p =0.09
Elhakim 2003^142^ RCT 4-11 low | G1: Dexamethasone, 0.5 mg/kg (IV) (55) G2: Placebo (saline), 0.5 mg/kg (IV) (55) | Electrocautery | CHEOPS pain score >7 or children who were crying during two consecutive five-minute observation periods until the child was comfortable More than two episodes of vomiting (repeatedly one to two minute period) | PACU to 24 hrs post-op | Doses of IV pethidine needed, mean(mg) ± SD G1: 0 ± 0 G2: 0.6 ± 0.1 (n=9) Patients needing IV metoclopramide (mg, early), n (%) G1: 6 (11) G2: 2 (4) Patients needing IV metoclopramide (mg, late), n (%) G1: 6 (11) G2: 0 (0) | G1 vs G2, p = NR
Elhakim 2003^142^ RCT 4-11 low | G1: Dexamethasone, 0.5 mg/kg (IV) (55) G2: Placebo (saline), 0.5 mg/kg (IV) (55) | Electrocautery | | PACU to 24 hrs post-op | Total patients needing IV metoclopramide (mg), n (%) G1: 2 (4) G2: 12 (22) | G1 vs. G2, p < 0.001
NSAID
Moss 2014^147^ RCT 6-17 moderate | G1: Ibuprofen, 10 mg/kg (IV) (73) G2: Placebo (normal saline), 10 mg/kg (IV) (65) | Electrocautery | VAS pain score rating >30 mm NA | PACU | Doses of IV fentanyl needed, mean (μg doses) ± SD G1: 1.6±1.3 G2: 1.9±1.06 | G1 vs. G2, p = 0.021
Moss 2014^147^ RCT 6-17 moderate | G1: Ibuprofen, 10 mg/kg (IV) (73) G2: Placebo (normal saline), 10 mg/kg (IV) (65) | Electrocautery | VAS pain score rating >30 mm NA | PACU | N needing IV fentanyl (μg), (%) G1: 61 (84) G2: 61 (94) | G1 vs. G2, p = 0.068
Moss 2014^147^ RCT 6-17 moderate | G1: Ibuprofen, 10 mg/kg (IV) (73) G2: Placebo (normal saline), 10 mg/kg (IV) (65) | Electrocautery | VAS pain score rating >30 mm NA | 24-28 hrs post-op | N needing more than 1 dose of IV fentanyl (μg), (%): G1: 31 (42) G2: 40 (62) | G1 vs. G2, p=0.028
Abdel-Ghaffar 2012^165^ RCT 8-18 moderate | G1: IV lornoxicam, 8 mg (20) G2: Infiltration lornoxicam, 8 mg (20) G3: Placebo (saline), 12 mL (20) | Unspecified tonsillectomy | VRS pain score ≥2 NA | Within 24 hrs post-op | Doses of injection diclofenac needed, mean(mg) ± SD G1: 44.73 ± 9.31 G2: 69.8 ± 38.71 G3: 87.8 ± 24.4 N needing 3 rescue doses of injection diclofenac (%): G1: 0 (0) G2: 9 (45) G3: 12 (60) | G1 vs. G3, p < 0.000 G2 vs. G3, p = NS G1 vs. G2, p < 0.009 G1 vs. G3: p=0.000 G2 vs G3: NS G1 vs. G2: p=0.01
Solanki 2012^146^ RCT 1-15 moderate | G1: Diclofenac, 2mg/kg (rectal) (25) G2: Bupivacaine (0.25%), 5 mL (instillation) (25) | Unspecified tonsillectomy | NA Unspecified | PACU to 24 hrs post-op | Patients needing injection ondansetron (units), G1: 2 (8) G2: 2 (8) | G1 vs G2, p = NR
Yegane Moghaddam 2012^166^ RCT 10-25 low | G1: Diclofenac, 1.0 mg/kg (rectal) (30) G2: Gabapentin, 20 mg/kg (oral) (30) G3: Placebo (30) | Unspecified tonsillectomy | Pain felt in recovery room or ward and VAS pain score >4 NA | PACU and Ward | Doses of injection meperidine, mean(mg) ± SD G1: 16.66 ± 8.95 G2: 14.16 ± 6.97 G3: 33.4 ± 13.97 | G1 vs. G3, p = 0.004 G2 vs. G3, p = 0.001 G1 vs. G2, p=0.59
Rhendra 2010^167^ 5-12 moderate | G1: Sodium diclofenac, 1 mg/kg (rectal) (65) G2: Viscous lignocaine, 2%, 4 mg/kg (topical) (65) | Cold dissection | Patient complained of intolerable pain and VAS score (0-100 mm) assessment (unspecified) NA | 0.5 hrs post-op | Doses of IV pethidine needed 0.5 hrs post-op, mean(units) ± SD G1: 0.16 ± 0.13 G2: 0 ± 0 | G1 vs. G2, p = 0.301
Rhendra 2010^167^ 5-12 moderate | G1: Sodium diclofenac, 1 mg/kg (rectal) (65) G2: Viscous lignocaine, 2%, 4 mg/kg (topical) (65) | Cold dissection | Patient complained of intolerable pain and VAS score (0-100 mm) assessment (unspecified) NA | 2 hrs post-op | Doses of IV pethidine needed 2 hrs post-op, mean(units) ± SD G1: 0.11 ± 0.32 G2: 0.02 ± 0.12 | G1 vs. G2, p = 0.023
Rhendra 2010^167^ 5-12 moderate | G1: Sodium diclofenac, 1 mg/kg (rectal) (65) G2: Viscous lignocaine, 2%, 4 mg/kg (topical) (65) | Cold dissection | Patient complained of intolerable pain and VAS score (0-100 mm) assessment (unspecified) NA | 12 hrs post-op | Doses of IV pethidine needed 12 hrs post-op, mean(units) ± SD G1: 0.46 ± 0.59 G2: 0.65 ± 0.59 | G1 vs. G2, p = 0.061
Rhendra 2010^167^ 5-12 moderate | G1: Sodium diclofenac, 1 mg/kg (rectal) (65) G2: Viscous lignocaine, 2%, 4 mg/kg (topical) (65) | Cold dissection | Patient complained of intolerable pain and VAS score (0-100 mm) assessment (unspecified) NA | 24 hrs post-op | Doses of IV pethidine needed 24 hrs post-op, mean(units) ± SD G1: 0.11 ± 0.22 G2: 0.25 ± 0.53 | G1 vs. G2, p = 0.068
Antila 2006^168^ RCT | G1: ketoprofen, 2 mg/kg (IV) (15) G2: tramadol, 1 mg/kg (IV) (15) G3: placebo (saline), (IV) (15) | Standard adenotonsillectomy | On patient demand | 0 to 24 hrs post-op | N needing fentanyl mean ±SD, G1: 5.5 ± 5 G2: 7.6 ± 7.1 G3: 9.4 ± 10 | G1 vs. G2, p = 0.035 G1 vs G3, p = 0.049 G2 vs G3, p=NR
Bhattacharya 2005^169^ RCT 8-12 moderate | G1: Diclofenac, 2 mg/kg (rectal) (25) G2: Pethidine, 0.5 mg/kg (IV) (25) | Unspecified tonsillectomy or adenoidectomy | VAS score > 40 mm or on patient demand | Ward (1 hr post-op to following morning) | Doses of oral paracetamol needed, mean(mg) ± SD G1: 350 ± 0.2 G2: 500 ± 0.5 | G1 vs G2, p <0.05
Bhattacharya 2005^169^ RCT 8-12 moderate | G1: Diclofenac, 2 mg/kg (rectal) (25) G2: Pethidine, 0.5 mg/kg (IV) (25) | Unspecified tonsillectomy or adenoidectomy | NA | Ward (1 hr post-op to following morning) | N needing 2^nd^ dose of rescue oral paracetamol (mg) (%) G1: 5 (20) G2: 6 (24) | G1 vs. G2: p=NR
Kedek 2005^150^ 5-12 moderate | G1: Ibuprofen syrup, 10 mg/kg (20) G2: Lidocaine infiltration, 0.5%, 10 mg/kg (20) | Unspecified adenotonsillectomy | VAS score >4 NA | 1 hrs post-op – 6 hrs post-op | Doses of syrup paracetamol needed, mean(mg doses) ± SD G1: 4.1 ± 1.41 G2: 3.8 ± 1.15 | G1 vs G2, p = ns
Oztekin 2002^158^ RCT 5-14 moderate | G1: Diclofenac, 1 mg/kg (rectal) (20) G2: No Rx (20) | Unspecified tonsillectomy with or without adenoidectomy | Children had any throat pain (unspecified) | PACU | Doses of infusion morphine (μg) needed in PACU, mean (SD) G1: 130.33 ± 11.26 G2: 169.92 ± 9.22 | G1 vs. G2, p = 0.012
Oztekin 2002^158^ RCT 5-14 moderate | G1: Diclofenac, 1 mg/kg (rectal) (20) G2: No Rx (20) | Unspecified tonsillectomy with or without adenoidectomy | NA | WARD | Doses of infusion morphine (μg) needed in Ward, mean (SD) G1: 50.80 ± 11.38 G2: 87.77 ± 10.55 | G1 vs. G2, p = 0.021
Oztekin 2002^158^ RCT 5-14 moderate | G1: Diclofenac, 1 mg/kg (rectal) (20) G2: No Rx (20) | Unspecified tonsillectomy with or without adenoidectomy | NA | (PACU+WARD) | Total doses of infusion morphine (μg) needed, mean (SD) G1: 181.13 ± 19.15 G2: 257.68 ± 16.04 | G1 vs. G2, p = 0.009
Antiemetics
Bolton 2007^170^ 6 mos-12 years low | G1: Odansetron, 0.1 mg/kg (injection) (273) G2: Metoclopramide, 0.5 mg/kg (injection) (284) | Unspecified tonsillectomy with or without adenoidectomy | Post-op every four hours (P.R.N.) NA | post-op (unspecified) | Doses of oral codeine needed, mean(mg) SD G1: 1.4 ± 1.5 G2: 1.7 ± 1.7 | G1 vs G2, p = NR
Fujii 2003^171^ RCT 4-10 low | G1: Ramosetron, 3 μg/kg (IV) (20) G2: Ramosetron, 6 μg/kg (IV) (20) G3: Ramosetron, 12 μg/kg (IV) (20) G4: Placebo, NR (IV) (20) | Unspecified tonsillectomy with or without adenoidectomy | NA Retching and/or vomiting ≥2 episodes within 48 hours | PACU-48 hrs post-op | N needing IV metoclopramide (mg), (%) G1: 5 (25) G2: 0 (0) G3: 0 (0) G4: 5 (25) | G1 vs. G4, p = ns G2,G3 vs. G4, p=0.024
Holt 2000^172^ RCT 2-14 low | G1: Tropisetron, 0.2 mg/kg – 5 mg/kg (IV) (35) G2: Placebo (IV) (36) | Unspecified tonsillectomy or adenotonsillectomy | NA Vomiting >2 times and clinician discretion | PACU-24 hrs post-op | Patients needing IV metoclopramide (mg), G1: 1 (3) G2: 12 (33) | G1 vs G2, p <0.01

G = Group; hrs= Hours; IV = Intravenous; kg = Kilograms; mCHEOPS = modified Eastern Ontario Children's Hospital Pain Scale; mg = Milligrams; N= Number; NA = Not Applicable; NR = Not Reported; NS = Not Significant; PACU = Post-Anesthesia Care Unit; POD = Post-Op Day; PRN = As Needed (“pro re nata”); RCT = Randomized Controlled Trial; SD = Standard Deviation; μg = Micrograms; VAS = Visual Analog Scale; VRS = Visual Rating Scale

Table H-14 Time to return to normal activity associated with perioperative medications

Author, Year Age Study Design RoB | Drug Class | Intervention | Time to return to normal activity, n/N (%) or mean ± SD (n) | Outcome measure (e.g., mean days)
Giannoni et al. (2002)^173^ 3-15 RCT moderate | Perioperative steroid + analgesics | Dexamethasone and ropivacaine + clonidine, 1.0 mg/kg (IV) and 0.15 mL/kg + 1 ug/kg | Time to return to normal activity, 7.74 ± 2.49 (25) | Mean days
Giannoni et al. (2002)^173^ 3-15 RCT moderate | Placebo + analgesics | Placebo (saline) and ropivacaine + clonidine, 0.25 mL/kg (IV) and 0.15 mL/kg + 1 ug/kg | Time to return to normal activity, 6.38 ± 2.24 (25) | Mean days

IV = intravenous; RCT = Randomized Controlled Trial; μg = Micrograms

## References

1 Sudarsan SS, Paramasivan VK, Arumugam SV, et al. (2014). Comparison of treatment modalities in syndromic children with obstructive sleep apnea--a randomized cohort study. Int J Pediatr Otorhinolaryngol.
2 Paramasivan VK, Arumugam SV, Kameswaran M. (2012). Randomised comparative study of adenotonsillectomy by conventional and coblation method for children with obstructive sleep apnoea. Int J Pediatr Otorhinolaryngol.
3 Chang KW. (2008). Intracapsular versus subcapsular coblation tonsillectomy. Otolaryngol Head Neck Surg.
4 D'Eredita R, Bozzola L. (2009). Molecular resonance vs. coblation tonsillectomy in children. Laryngoscope.
5 Salama MA. (2012). Harmonic scalpel tonsillectomy versus coblation tonsillectomy. Menoufiya Medical Journal.
6 Elbadawey MR, Hegazy HM, Eltahan AE, et al. (2015). A randomised controlled trial of coblation, diode laser and cold dissection in paediatric tonsillectomy. J Laryngol Otol.
7 Hegazy HM, Albirmawy OA, Kaka AH, et al. (2008). Pilot comparison between potassium titanyl phosphate laser and bipolar radiofrequency in paediatric tonsillectomy. J Laryngol Otol.
8 Temple RH, Timms MS. (2001). Paediatric coblation tonsillectomy. Int J Pediatr Otorhinolaryngol.
9 Di Rienzo Businco L, Coen Tirelli G. (2008). Paediatric tonsillectomy: radiofrequency-based plasma dissection compared to cold dissection with sutures. Acta Otorhinolaryngol Ital.
10 Stoker KE, Don DM, Kang DR, et al. (2004). Pediatric total tonsillectomy using coblation compared to conventional electrosurgery: a prospective, controlled single-blind study. Otolaryngol Head Neck Surg.
11 Omrani M, Barati B, Omidifar N, et al. (2012). Coblation versus traditional tonsillectomy: A double blind randomized controlled trial. Journal of Research in Medical Sciences.
12 Chimona T, Proimos E, Mamoulakis C, et al. (2008). Multiparametric comparison of cold knife tonsillectomy, radiofrequency excision and thermal welding tonsillectomy in children. Int J Pediatr Otorhinolaryngol.
13 Roje Z, Racic G, Dogas Z, et al. (2009). Postoperative morbidity and histopathologic characteristics of tonsillar tissue following coblation tonsillectomy in children: a prospective randomized single-blind study. Coll Antropol.
14 Roje Z, Racic G, Kardum G, et al. (2011). Is the systemic inflammatory reaction to surgery responsible for post-operative pain after tonsillectomy, and is it “technique-related”?. Wien Klin Wochenschr.
15 D'Eredita R. (2010). Tonsillectomy in children: a five-factor analysis among three techniques--reporting upon clinical results, anesthesia time, surgery time, bleeding, and cost. Laryngoscope.
16 Mitic S, Tvinnereim M, Lie E, et al. (2007). A pilot randomized controlled trial of coblation tonsillectomy versus dissection tonsillectomy with bipolar diathermy haemostasis. Clin Otolaryngol.
17 Parker D, Howe L, Unsworth V, et al. (2009). A randomised controlled trial to compare postoperative pain in children undergoing tonsillectomy using cold steel dissection with bipolar haemostasis versus coblation technique. Clin Otolaryngol.
18 Shapiro NL, Bhattacharyya N. (2007). Cold dissection versus coblation-assisted adenotonsillectomy in children. Laryngoscope.
19 Parker NP, Walner DL. (2011). Post-operative pain following coblation or monopolar electrocautery tonsillectomy in children: a prospective, single-blinded, randomised comparison. Clin Otolaryngol.
20 Shah UK, Galinkin J, Chiavacci R, et al. (2002). Tonsillectomy by means of plasma-mediated ablation: prospective, randomized, blinded comparison with monopolar electrosurgery. Arch Otolaryngol Head Neck Surg.
21 Salomone R, Jordao Visioli A, Aquino MM, et al. (2007). Ultrasonic Curved Shears in Tonsillectomy: Comparative Clinical Trial Between this New Surgical Technique and the Technique with the Cold Blade Surgical Knife.
22 Ericsson E, Graf J, Lundeborg-Hammarstrom I, et al. (2014). Tonsillotomy versus tonsillectomy on young children: 2 year post surgery follow-up. J Otolaryngol Head Neck Surg.
23 Ericsson E, Lundeborg I, Hultcrantz E. (2009). Child behavior and quality of life before and after tonsillotomy versus tonsillectomy. Int J Pediatr Otorhinolaryngol.
24 Korkmaz O, Bektas D, Cobanoglu B, et al. (2008). Partial tonsillectomy with scalpel in children with obstructive tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
25 Aydin S, Taskin U, Altas B, et al. (2014). Post-tonsillectomy morbidities: randomised, prospective controlled clinical trial of cold dissection versus thermal welding tonsillectomy. J Laryngol Otol.
26 Skoulakis CE, Papadakis CE, Manios AG, et al. (2007). Tonsilloplasty in children with obstructive symptoms. J Otolaryngol.
27 Chaidas KS, Kaditis AG, Papadakis CE, et al. (2013). Tonsilloplasty versus tonsillectomy in children with sleep-disordered breathing: short- and long-term outcomes. Laryngoscope.
28 Beriat GK, Ezerarslan H, Kocaturk S. (2013). Microdebrider tonsillotomy in children with obstructive tonsillar hypertrophy. Journal of Clinical and Analytical Medicine.
29 Paradise JL, Bluestone CD, Colborn DK, et al. (2002). Tonsillectomy and adenotonsillectomy for recurrent throat infection in moderately affected children. Pediatrics.
30 Raut VV, Bhat N, Sinnathuray AR, et al. (2002). Bipolar scissors versus cold dissection for pediatric tonsillectomy--a prospective, randomized pilot study. Int J Pediatr Otorhinolaryngol.
31 Frampton SJ, Ward MJ, Sunkaraneni VS, et al. (2012). Guillotine versus dissection tonsillectomy: randomised, controlled trial. J Laryngol Otol.
32 Sezen OS, Kaytanci H, Kubilay U, et al. (2008). Comparison between tonsillectomy with thermal welding and the conventional ‘cold’ tonsillectomy technique. ANZ J Surg.
33 Chettri S, Bhandary S, Nepal A, et al. (2014). A single blind controlled study comparing bipolar elecrocautery tonsillectomy to cold dissection method in pediatric age groups. Health Renaissance.
34 D'Eredita R. (2014). Molecular resonance tonsillectomy in children: comparative study over standard techniques in an 11-year study. Otolaryngol Head Neck Surg.
35 Haraldsson PO, Attner P, Fredelius L, et al. (2011). Intrapersonal randomized controlled trial comparing bipolar scissors and conventional cold tonsillectomy. Otorhinolaryngology Clinics.
36 Ozkiris M. (2012). Comparison of three techniques in pediatric tonsillectomy. Eur Arch Otorhinolaryngol.
37 Nunez DA, Provan J, Crawford M. (2000). Postoperative tonsillectomy pain in pediatric patients: electrocautery (hot) vs cold dissection and snare tonsillectomy--a randomized trial. Arch Otolaryngol Head Neck Surg.
38 Ericsson E, Graf J, Hultcrantz E. (2006). Pediatric tonsillotomy with radiofrequency technique: long-term follow-up. Laryngoscope.
39 Ericsson E, Wadsby M, Hultcrantz E. (2006). Pre-surgical child behavior ratings and pain management after two different techniques of tonsil surgery. Int J Pediatr Otorhinolaryngol.
40 Hultcrantz E, Ericsson E. (2004). Pediatric tonsillotomy with the radiofrequency technique: less morbidity and pain. Laryngoscope.
41 Gabr S, Harhash K, Fouly M, et al. (2014). Microdebrider intracapsular tonsillotomy versus conventional extracapsular tonsillectomy. The Egyptian Journal of Otolaryngology.
42 Lorusso F, Gallina S, Modica DM, et al. (2015). Bipolar Quantum Molecular Resonance versus Blunt Dissection tonsillectomy. B-ent.
43 Oko MO, Ganly I, Loughran S, et al. (2005). A prospective randomized single-blind trial comparing ultrasonic scalpel tonsillectomy with tonsillectomy by blunt dissection in a pediatric age group. Otolaryngol Head Neck Surg.
44 Kothari P, Patel S, Brown P, et al. (2002). A prospective double-blind randomized controlled trial comparing the suitability of KTP laser tonsillectomy with conventional dissection tonsillectomy for day case surgery. Clin Otolaryngol Allied Sci.
45 Hesham A. (2009). Bipolar diathermy versus cold dissection in paediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
46 Silveira H, Soares JS, Lima HA. (2003). Tonsillectomy: cold dissection versus bipolar electrodissection. Int J Pediatr Otorhinolaryngol.
47 Young C, MacRae J. (2001). Tonsillectomy. A comparative study of dissection/snare vs suction-cautery. Can Oper Room Nurs J.
48 Pruegsanusak K, Wongsuwan K, Wongkittithawon J. (2010). A randomized controlled trial for perioperative morbidity in microdebrider versus cold instrument dissection tonsillectomy. J Med Assoc Thai.
49 Coticchia JM, Yun RD, Nelson L, et al. (2006). Temperature-controlled radiofrequency treatment of tonsillar hypertrophy for reduction of upper airway obstruction in pediatric patients. Arch Otolaryngol Head Neck Surg.
50 Lister M. (2005). Microdebrider partial tonsillectomy vs. electrosurgical tonsillectomy: a randomized, double-blind, paired-control study of postoperative pain.
51 Leaper M, Mahadevan M, Vokes D, et al. (2006). A prospective randomised single blinded study comparing harmonic scalpel tonsillectomy with bipolar tonsillectomy. Int J Pediatr Otorhinolaryngol.
52 Ragab MA, Atef A, Mosleh M, et al. (2011). Bipolar scissors tonsillectomy: what are the advantages?. J Otolaryngol Head Neck Surg.
53 D'Eredita R, Marsh RR. (2004). Contact diode laser tonsillectomy in children. Otolaryngol Head Neck Surg.
54 Walker RA, Syed ZA. (2001). Harmonic scalpel tonsillectomy versus electrocautery tonsillectomy: a comparative pilot study. Otolaryngol Head Neck Surg.
55 Willging JP, Wiatrak BJ. (2003). Harmonic scalpel tonsillectomy in children: a randomized prospective study. Otolaryngol Head Neck Surg.
56 Derkay CS, Darrow DH, Welch C, et al. (2006). Post-tonsillectomy morbidity and quality of life in pediatric patients with obstructive tonsils and adenoid: microdebrider vs electrocautery. Otolaryngol Head Neck Surg.
57 Al-Shehri AMS. (2012). Post-tonsillectomy pain and bleeding in children: A comparison of traditional tonsillectomy with electrodissection tonsillectomy. Current Pediatric Research.
58 Chan KH, Friedman NR, Allen GC, et al. (2004). Randomized, controlled, multisite study of intracapsular tonsillectomy using low-temperature plasma excision. Arch Otolaryngol Head Neck Surg.
59 Chang H, Hah JH. (2012). Comparison of post-tonsillectomy pain with two different types of bipolar forceps: low temperature quantum molecular resonance device versus high temperature conventional electrocautery. Acta Otolaryngol.
60 Park A, Proctor MD, Alder S, et al. (2007). Subtotal bipolar tonsillectomy does not decrease postoperative pain compared to total monopolar tonsillectomy. Int J Pediatr Otorhinolaryngol.
61 Marcus CL, Moore RH, Rosen CL, et al. (2013). A randomized trial of adenotonsillectomy for childhood sleep apnea. N Engl J Med.
62 Weinstock TG, Rosen CL, Marcus CL, et al. (2014). Predictors of obstructive sleep apnea severity in adenotonsillectomy candidates. Sleep.
63 Katz ES, Moore RH, Rosen CL, et al. (2014). Growth after adenotonsillectomy for obstructive sleep apnea: an RCT. Pediatrics.
64 Quante M, Wang R, Weng J, et al. (2014). The Effect of Adenotonsillectomy for Childhood Sleep Apnea on Cardiometabolic Measures. Sleep.
65 Garetz SL, Mitchell RB, Parker PD, et al. (2015). Quality of life and obstructive sleep apnea symptoms after pediatric adenotonsillectomy. Pediatrics.
66 Chervin RD, Ellenberg SS, Hou X, et al. (2015). Prognosis for Spontaneous Resolution of Obstructive Sleep Apnea in Children. Chest.
67 Konstantinopoulou S, Gallagher P, Elden L, et al. (2015). Complications of adenotonsillectomy for obstructive sleep apnea in school-aged children. Int J Pediatr Otorhinolaryngol.
68 Orvidas LJ, St Sauver JL, Weaver AL. (2006). Efficacy of tonsillectomy in treatment of recurrent group A beta-hemolytic streptococcal pharyngitis. Laryngoscope.
69 van Staaij BK, van den Akker EH, Rovers MM, et al. (2004). Effectiveness of adenotonsillectomy in children with mild symptoms of throat infections or adenotonsillar hypertrophy: open, randomised controlled trial. Bmj.
70 Buskens E, van Staaij B, van den Akker J, et al. (2007). Adenotonsillectomy or watchful waiting in patients with mild to moderate symptoms of throat infections or adenotonsillar hypertrophy: a randomized comparison of costs and effects. Arch Otolaryngol Head Neck Surg.
71 Le TM, Rovers MM, van Staaij BK, et al. (2007). Alterations of the oropharyngeal microbial flora after adenotonsillectomy in children: a randomized controlled trial. Arch Otolaryngol Head Neck Surg.
72 Bukhari MA, Al-Ammar AY. (2007). Monopolar electrodissection versus cold dissection tonsillectomy among children. Saudi Med J.
73 Stelter K, de la Chaux R, Patscheider M, et al. (2010). Double-blind, randomised, controlled study of post-operative pain in children undergoing radiofrequency tonsillotomy versus laser tonsillotomy. J Laryngol Otol.
74 Havel M, Sroka R, Englert E, et al. (2012). Intraindividual comparison of 1,470 nm diode laser versus carbon dioxide laser for tonsillotomy: a prospective, randomized, double blind, controlled feasibility trial. Lasers Surg Med.
75 Stelter K, Ihrler S, Siedek V, et al. (2012). 1-year follow-up after radiofrequency tonsillotomy and laser tonsillotomy in children: a prospective, double-blind, clinical study. Eur Arch Otorhinolaryngol.
76 Matin M, Chowdhury MA. (2012). Diode laser versus blunt dissection tonsillectomy. Bangladesh Journal of Otorhinolaryngology.
77 Chang KW. (2005). Randomized controlled trial of Coblation versus electrocautery tonsillectomy. Otolaryngol Head Neck Surg.
78 Goldstein NA, Pugazhendhi V, Rao SM, et al. (2004). Clinical assessment of pediatric obstructive sleep apnea. Pediatrics.
79 Edmonson MB, Eickhoff JC, Zhang C. (2015). A population-based study of acute care revisits following tonsillectomy. J Pediatr.
80 Bhattacharyya N, Shapiro NL. (2014). Associations between socioeconomic status and race with complications after tonsillectomy in children. Otolaryngol Head Neck Surg.
81 Shay S, Shapiro NL, Bhattacharyya N. (2015). Revisit rates and diagnoses following pediatric tonsillectomy in a large multistate population. Laryngoscope.
82 Duval M, Wilkes J, Korgenski K, et al. (2015). Causes, costs, and risk factors for unplanned return visits after adenotonsillectomy in children. Int J Pediatr Otorhinolaryngol.
83 Padia R, Olsen G, Henrichsen J, et al. (2015). Hospital and Surgeon Adherence to Pediatric Tonsillectomy Guidelines Regarding Perioperative Dexamethasone and Antibiotic Administration. Otolaryngol Head Neck Surg.
84 Mahant S, Keren R, Localio R, et al. (2014). Dexamethasone and risk of bleeding in children undergoing tonsillectomy. Otolaryngol Head Neck Surg.
85 Mahant S, Keren R, Localio R, et al. (2014). Variation in quality of tonsillectomy perioperative care and revisit rates in children's hospitals. Pediatrics.
86 Suzuki S, Yasunaga H, Matsui H, et al. (2014). Impact of systemic steroids on posttonsillectomy bleeding: analysis of 61 430 patients using a national inpatient database in Japan. JAMA Otolaryngol Head Neck Surg.
87 Tomkinson A, Harrison W, Owens D, et al. (2012). Postoperative hemorrhage following adenoidectomy. Laryngoscope.
88 Tomkinson A, Harrison W, Owens D, et al. (2011). Risk factors for postoperative hemorrhage following tonsillectomy. Laryngoscope.
89 Tomkinson A, De Martin S, Gilchrist CR, et al. (2005). Instrumentation and patient characteristics that influence postoperative haemorrhage rates following tonsil and adenoid surgery. Clin Otolaryngol.
90 Clark MP, Waddell A. (2004). The surgical arrest of post-tonsillectomy haemorrhage: hospital episode statistics. Ann R Coll Surg Engl.
91 Kshirsagar R, Mahboubi H, Moriyama D, et al. (2016). Increased immediate postoperative hemorrhage in older and obese children after outpatient tonsillectomy. Int J Pediatr Otorhinolaryngol.
92 Harounian JA, Schaefer E, Schubart J, et al. (2016). Pediatric Posttonsillectomy Hemorrhage: Demographic and Geographic Variation in Health Care Costs in the United States. Otolaryngol Head Neck Surg.
93 Raol N, Zogg CK, Boss EF, et al. (2016). Inpatient Pediatric Tonsillectomy: Does Hospital Type Affect Cost and Outcomes of Care?. Otolaryngol Head Neck Surg.
94 Achar P, Sharma RK, De S, et al. (2015). Does primary indication for tonsillectomy influence post-tonsillectomy haemorrhage rates in children?. Int J Pediatr Otorhinolaryngol.
95 Walner DL, Miller SP, Villines D, et al. (2012). Coblation tonsillectomy in children: incidence of bleeding. Laryngoscope.
96 Perkins JN, Liang C, Gao D, et al. (2012). Risk of post-tonsillectomy hemorrhage by clinical diagnosis. Laryngoscope.
97 Kim DW, Koo JW, Ahn SH, et al. (2010). Difference of delayed post-tonsillectomy bleeding between children and adults. Auris Nasus Larynx.
98 Gooda MR, Sheik I, Suleri A. (2010). Reducing post operative bleeding after tonsillectomies in children by modifying the monopolar diathermy technique: A study of 1500 patients. Pakistan Journal of Medical Sciences.
99 D'Agostino R, Tarantino V, Calevo MG. (2009). Post-tonsillectomy late haemorrhage: is it a preferably night-time event?. Int J Pediatr Otorhinolaryngol.
100 Arnoldner C, Grasl M, Thurnher D, et al. (2008). Surgical revision of hemorrhage in 8388 patients after cold-steel adenotonsillectomies. Wien Klin Wochenschr.
101 Jones DT, Yoon MJ, Licameli G. (2007). Effectiveness of postoperative follow-up telephone interviews for patients who underwent adenotonsillectomy: a retrospective study. Arch Otolaryngol Head Neck Surg.
102 Mills N, Anderson BJ, Barber C, et al. (2004). Day stay pediatric tonsillectomy--a safe procedure. Int J Pediatr Otorhinolaryngol.
103 Granell J, Gete P, Villafruela M, et al. (2004). Safety of outpatient tonsillectomy in children: a review of 6 years in a tertiary hospital experience. Otolaryngol Head Neck Surg.
104 Windfuhr JP, Chen YS. (2002). Incidence of post-tonsillectomy hemorrhage in children and adults: a study of 4,848 patients. Ear Nose Throat J.
105 Windfuhr JP, Chen YS. (2001). Hemorrhage following pediatric tonsillectomy before puberty. Int J Pediatr Otorhinolaryngol.
106 Windfuhr JP, Chen YS. (2003). Post-tonsillectomy and -adenoidectomy hemorrhage in nonselected patients. Ann Otol Rhinol Laryngol.
107 Liu JH, Anderson KE, Willging JP, et al. (2001). Posttonsillectomy hemorrhage: what is it and what should be recorded?. Arch Otolaryngol Head Neck Surg.
108 Kang J, Brodsky L, Danziger I, et al. (1994). Coagulation profile as a predictor for post-tonsillectomy and adenoidectomy (T + A) hemorrhage. Int J Pediatr Otorhinolaryngol.
109 Lannigan FJ, Martin-Hirsch DP, Basey E. (1993). Clinical audit: is day-case adenotonsillectomy safe?. Br J Clin Pract.
110 Yardley MP. (1992). Tonsillectomy, adenoidectomy and adenotonsillectomy: are they safe day case procedures?. J Laryngol Otol.
111 Colclasure JB, Graham SS. (1990). Complications of outpatient tonsillectomy and adenoidectomy: a review of 3,340 cases. Ear Nose Throat J.
112 Chowdhury K, Tewfik TL, Schloss MD. (1988). Post-tonsillectomy and adenoidectomy hemorrhage. J Otolaryngol.
113 Carithers JS, Gebhart DE, Williams JA. (1987). Postoperative risks of pediatric tonsilloadenoidectomy. Laryngoscope.
114 Crysdale WS, Russel D. (1986). Complications of tonsillectomy and adenoidectomy in 9409 children observed overnight. CMAJ.
115 Herdman RC, Bates GJ. (1986). Childhood tonsillectomy and discharge after 24 hours. J Laryngol Otol.
116 Carmody D, Vamadevan T, Cooper SM. (1982). Post tonsillectomy haemorrhage. J Laryngol Otol.
117 Mahadevan M, van der Meer G, Gruber M, et al. (2016). The starship children's hospital tonsillectomy: A further 10 years of experience. Laryngoscope.
118 Spektor Z, Saint-Victor S, Kay DJ, et al. (2016). Risk factors for pediatric post-tonsillectomy hemorrhage. Int J Pediatr Otorhinolaryngol.
119 Peeters A, Van Rompaey D, Schmelzer B, et al. (1999). Tonsillectomy and adenotomy as a one day procedure?. Acta Otorhinolaryngol Belg.
120 Pfaff JA, Hsu K, Chennupati SK. (2016). The Use of Ibuprofen in Posttonsillectomy Analgesia and Its Effect on Posttonsillectomy Hemorrhage Rate. Otolaryngol Head Neck Surg.
121 Sunnergren O, Hemlin C, Ericsson E, et al. (2014). Radiofrequency tonsillotomy in Sweden 2009-2012. Eur Arch Otorhinolaryngol.
122 Hultcrantz E, Ericsson E, Hemlin C, et al. (2013). Paradigm shift in Sweden from tonsillectomy to tonsillotomy for children with upper airway obstructive symptoms due to tonsillar hypertrophy. Eur Arch Otorhinolaryngol.
123 Elinder K, Soderman AH, Stalfors J, et al. (2016). Factors influencing morbidity after paediatric tonsillectomy: a study of 18,712 patients in the National Tonsil Surgery Register in Sweden. Eur Arch Otorhinolaryngol.
124 Hessen Soderman AC, Ericsson E, Hemlin C, et al. (2011). Reduced risk of primary postoperative hemorrhage after tonsil surgery in Sweden: results from the National Tonsil Surgery Register in Sweden covering more than 10 years and 54,696 operations. Laryngoscope.
125 Sarny S, Habermann W, Ossimitz G, et al. (2013). What lessons can be learned from the Austrian events?. ORL J Otorhinolaryngol Relat Spec.
126 Sarny S, Ossimitz G, Habermann W, et al. (2011). Hemorrhage following tonsil surgery: a multicenter prospective study. Laryngoscope.
127 Kvaerner KJ. (2009). Benchmarking surgery: secondary post-tonsillectomy hemorrhage 1999-2005. Acta Otolaryngol.
128 Lowe D, van der Meulen J, Cromwell D, et al. (2007). Key messages from the National Prospective Tonsillectomy Audit. Laryngoscope.
129 Lowe D, Cromwell DA, Lewsey JD, et al. (2009). Diathermy power settings as a risk factor for hemorrhage after tonsillectomy. Otolaryngol Head Neck Surg.
130 Lowe D, van der Meulen J. (2004). Tonsillectomy technique as a risk factor for postoperative haemorrhage. Lancet.
131 Odhagen E, Sunnergren O, Hemlin C, et al. (2016). Risk of reoperation after tonsillotomy versus tonsillectomy: a population-based cohort study. Eur Arch Otorhinolaryngol.
132 Lavin JM, Shah RK. (2015). Postoperative complications in obese children undergoing adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
133 Tweedie DJ, Bajaj Y, Ifeacho SN, et al. (2012). Peri-operative complications after adenotonsillectomy in a UK pediatric tertiary referral centre. Int J Pediatr Otorhinolaryngol.
134 Bhattacharyya N. (2010). Ambulatory pediatric otolaryngologic procedures in the United States: characteristics and perioperative safety. Laryngoscope.
135 Kristensen S, Tveteras K. (1984). Post-tonsillectomy haemorrhage. A retrospective study of 1150 operations. Clin Otolaryngol Allied Sci.
136 Gallagher TQ, Hill C, Ojha S, et al. (2012). Perioperative dexamethasone administration and risk of bleeding following tonsillectomy in children: a randomized controlled trial. JAMA.
137 Czarnetzki C, Elia N, Lysakowski C, et al. (2008). Dexamethasone and risk of nausea and vomiting and postoperative bleeding after tonsillectomy in children: a randomized trial. JAMA.
138 Hanasono MM, Lalakea ML, Mikulec AA, et al. (2004). Perioperative steroids in tonsillectomy using electrocautery and sharp dissection techniques. Arch Otolaryngol Head Neck Surg.
139 Aysenur D, Mine C, Ozgur Y, et al. (2014). Pre-emptive peritonsillar dexamethasone vs. levobupivacaine infiltration for relief of post-adenotonsillectomy pain in children: a controlled clinical study. Int J Pediatr Otorhinolaryngol.
140 Hermans V, De Pooter F, De Groote F, et al. (2012). Effect of dexamethasone on nausea, vomiting, and pain in paediatric tonsillectomy. Br J Anaesth.
141 Aouad MT, Nasr VG, Yazbeck-Karam VG, et al. (2012). A comparison between dexamethasone and methylprednisolone for vomiting prophylaxis after tonsillectomy in inpatient children: a randomized trial. Anesth Analg.
142 Elhakim M, Ali NM, Rashed I, et al. (2003). Dexamethasone reduces postoperative vomiting and pain after pediatric tonsillectomy. Can J Anaesth.
143 Alajmi MA, Al Noumas HS, Al-Abdulhadi KA, et al. (2008). Steroids for reducing post-tonsillectomy morbidity. Kuwait Medical Journal.
144 Kaan MN, Odabasi O, Gezer E, et al. (2006). The effect of preoperative dexamethasone on early oral intake, vomiting and pain after tonsillectomy. Int J Pediatr Otorhinolaryngol.
145 Abdel-Ghaffar HS, Abdel-Azeem HG, Roushdy MM. (2015). Safety and efficacy of pre-incisional peritonsillar lornoxicam in paediatric post-tonsillectomy pain: a prospective double-blind, placebo-controlled, split-body clinical study. Clin Otolaryngol.
146 Solanki NS, Goswami M, Thaker N. (2012). Bupivacaine infiltration versus diclofenac suppository for post-tonsillectomy pain relief in paediatric patients. National Journal of Medical Research.
147 Moss JR, Watcha MF, Bendel LP, et al. (2014). A multicenter, randomized, double-blind placebo-controlled, single dose trial of the safety and efficacy of intravenous ibuprofen for treatment of pain in pediatric patients undergoing tonsillectomy. Paediatr Anaesth.
148 Lee IH, Sung CY, Han JI, et al. (2009). The preemptive analgesic effect of ketorolac and propacetamol for adenotonsillectomy in pediatric patients. Korean Journal of Anesthesiology.
149 Keidan I, Zaslansky R, Eviatar E, et al. (2004). Intraoperative ketorolac is an effective substitute for fentanyl in children undergoing outpatient adenotonsillectomy. Paediatr Anaesth.
150 Kedek A, Derbent A, Uyar M, et al. (2005). Pre-emptive effects of ibuprofen syrup and lidocaine infiltration on post-operative analgesia in children undergoing adenotonsillectomy. J Int Med Res.
151 Stage J, Jensen JH, Bonding P. (1988). Post-tonsillectomy haemorrhage and analgesics. A comparative study of acetylsalicylic acid and paracetamol. Clin Otolaryngol Allied Sci.
152 Ozkiris M, Kapusuz Z, Yildirim YS, et al. (2012). The effect of paracetamol, metamizole sodium and ibuprofen on postoperative hemorrhage following pediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
153 Murto K, Lamontagne C, McFaul C, et al. (2015). Celecoxib pharmacogenetics and pediatric adenotonsillectomy: a double-blinded randomized controlled study. Can J Anaesth.
154 Lalicevic S, Djordjevic I. (2004). Comparison of benzydamine hydrochloride and Salvia officinalis as an adjuvant local treatment to systemic nonsteroidal anti-inflammatory drug in controlling pain after tonsillectomy, adenoidectomy, or both: an open-label, single-blind, randomized clinical trial. Curr Ther Res Clin Exp.
155 Park SK, Kim J, Kim JM, et al. (2015). Effects of oral prednisolone on recovery after tonsillectomy. Laryngoscope.
156 Macassey E, Dawes P, Taylor B, et al. (2012). The effect of a postoperative course of oral prednisone on postoperative morbidity following childhood tonsillectomy. Otolaryngol Head Neck Surg.
157 Gao W, Zhang QR, Jiang L, et al. (2015). Comparison of local and intravenous dexamethasone for postoperative pain and recovery after tonsillectomy. Otolaryngol Head Neck Surg.
158 Oztekin S, Hepaguslar H, Kar AA, et al. (2002). Preemptive diclofenac reduces morphine use after remifentanil-based anaesthesia for tonsillectomy. Paediatr Anaesth.
159 El-Fattah AM, Ramzy E. (2013). Pre-emptive triple analgesia protocol for tonsillectomy pain control in children: double-blind, randomised, controlled, clinical trial. J Laryngol Otol.
160 Sukhani R, Pappas AL, Lurie J, et al. (2002). Ondansetron and dolasetron provide equivalent postoperative vomiting control after ambulatory tonsillectomy in dexamethasone-pretreated children. Anesth Analg.
161 Faiz SH, Rahimzadeh P, Alebouyeh MR, et al. (2013). A Randomized Controlled Trial on Analgesic Effects of Intravenous Acetaminophen versus Dexamethasone after Pediatric Tonsillectomy. Iran Red Crescent Med J.
162 Khani A, Jaafarpour M, Khajavikhan J, et al. (2009). The effect of dexamethasone on morbidity related to vomiting, pain and oral intake in children after tonsillectomy. Journal of Clinical and Diagnostic Research.
163 Kim MS, Cote CJ, Cristoloveanu C, et al. (2007). There is no dose-escalation response to dexamethasone (0.0625-1.0 mg/kg) in pediatric tonsillectomy or adenotonsillectomy patients for preventing vomiting, reducing pain, shortening time to first liquid intake, or the incidence of voice change. Anesth Analg.
164 Samarkandi AH, Shaikh MA, Ahmad RA, et al. (2004). Use of dexamethasone to reduce postoperative vomiting and pain after pediatric tonsillectomy procedures. Saudi Med J.
165 Abdel-Ghaffar HS, Sayed JA, Fathy MA, et al. (2012). Preincisional peritonsillar vs. intravenous lornoxicam for posttonsillectomy analgesia: A clinical and platelet aggregometry comparative study. Egyptian Journal of Anaesthesia.
166 Yegane Moghaddam A, Fazel MR. (2012). Comparison of analgesic effect between gabapentin and diclofenac on post-operative pain in patients undergoing tonsillectomy. Pain practice.
167 Rhendra Hardy MZ, Zayuah MS, Baharudin A, et al. (2010). The effects of topical viscous lignocaine 2% versus per-rectal diclofenac in early post-tonsillectomy pain in children. Int J Pediatr Otorhinolaryngol.
168 Antila H, Manner T, Kuurila K, et al. (2006). Ketoprofen and tramadol for analgesia during early recovery after tonsillectomy in children. Paediatr Anaesth.
169 Bhattacharya D, Mondol MC, Dasgupta S, et al. (2005). A comparison of rectal diclofenac with intravenous pethidine for pain relief following tonsillectomy and adenoidectomy in children. Journal of Anaesthesiology Clinical Pharmacology.
170 Bolton CM, Myles PS, Carlin JB, et al. (2007). Randomized, double-blind study comparing the efficacy of moderate-dose metoclopramide and ondansetron for the prophylactic control of postoperative vomiting in children after tonsillectomy. Br J Anaesth.
171 Fujii Y, Tanaka H. (2003). Results of a prospective, randomized, double-blind, placebo-controlled, dose-ranging trial to determine the effective dose of ramosetron for the prevention of vomiting after tonsillectomy in children. Clin Ther.
172 Jensen AB, Christiansen DB, Coulthard K, et al. (2000). Tropisetron reduces postoperative vomiting in children undergoing tonsillectomy. Paediatr Anaesth.
173 Giannoni C, White S, Enneking FK. (2002). Does dexamethasone with preemptive analgesia improve pediatric tonsillectomy pain?. Otolaryngol Head Neck Surg.