# Appendix G Applicability of Findings

Table G-1 Tonsillectomy vs. no surgery/watchful waiting for children with OSDB

Domain | Description of applicability of evidence
Population | Studies included children ages less than 2 to 16 years. In most studies children had PSG-proven OSDB. Three studies—including the largest RCT—had majority African-American populations.^1-3^, and two studies also reported that more than 50% of participants were overweight or obese.^1, 2^ One study included children with Down Syndrome or mucopolysaccharidosis^4^ and another included children under 24 months.^5^
Intervention | Tonsillectomy or tonsillectomy with adenoidectomy
Comparators | Comparators included watchful waiting or medical management.
Outcomes | Studies outcomes included changes in AHI, sleep-related quality of life, and behavioral and cognitive outcomes. Data were collected from PSG, direct interviews/assessments, provider records, and quality of life surveys. Outcomes were collected at various time points with followup times ranging from 5 months to 4 years. Most studies reported outcomes at 5-7 months.
Setting | Studies were conducted in the United States (6), Brazil (2), Israel (2), Australia (1), Ireland (1), and India (1). Patients were typically selected from otolaryngology clinics or their information was collected from a database.

PSG = Polysomnography; OSDB = Obstructive Sleep Disordered Breathing; RCT = Randomized Controlled Trial

Table G-2 Tonsillectomy vs. no surgery/watchful waiting for children with recurrent throat infections

Domain | Description of applicability of evidence
Population | Studies included children ages 3-16 with differing requirements for inclusion based on number of sore throat episodes from mildly impacted children with a minimum of one sore throat episode in the previous year to more severely impacted children with more than 7 sore throat episodes in the previous year. One study based inclusion on three or more documented episodes of Group A Strep throat infections. Studies typically did not report race/ethnicity or BMI. Four RCTs or non-randomized trials included majority Caucasian populations.
Intervention | Tonsillectomy or tonsillectomy with adenoidectomy
Comparators | Comparators included watchful waiting or medical management.
Outcomes | Study outcomes included number of sore throat days, healthcare visits, missed school or work, quality of life. Data were collected from patient diaries, direct interviews, provider records and quality of life surveys. Outcomes were collected at various time points with most studies offering a time point of one year post procedure and at least one additional study year. One study reported data 6-years post-procedure and had the longest duration.
Setting | Studies were conducted in the United States, Netherlands, Ireland, and the United Kingdom and patients were selected from otolaryngology or primary care clinics or their information was collected from a database.

BMI = Body Mass Index; RCT = Randomized Controlled Trial

Table G-3 Partial vs. total tonsillectomy

Domain | Description of applicability of evidence
Population | Studies included children ages less than 2 to 17 years. Most studies (19) included children with OSDB (typically based on clinical diagnosis vs. PSG). Neither race/ethnicity nor BMI were typically reported.
Intervention | Partial or total tonsillectomy/adenotonsillectomy. “Partial” tonsillectomy was variously defined (ranging from 10-70% removal or removal of protruding tissue only or removal of all but a thin rim of tissue) or not described across studies.
Comparators | Comparators included surgical technique (e.g., coblation, electrocautery) and partial or total removal of tonsils.
Outcomes | Outcomes included persistence of OSDB, return to normal diet or activity, recurrent throat infection, tonsillar regrowth, quality of life, postoperative bleeding, and behavioral outcomes. Outcomes were reported in multiple ways (means, %, days, N, etc.). Studies collected data from patient diaries, direct interviews/assessments, provider records, and quality of life or other outcome surveys. Outcomes were collected at various time points with followup times ranging from 5-7 days post-procedure to 6 years.
Setting | Studies were conducted in the United States (8), Greece (3), Sweden (2), Turkey (2), Brazil (2), Lebanon (1), Israel (1), Egypt (1), France (1), and Thailand (1). Patients were typically selected from otolaryngology clinics.

BMI = Body Mass Index; N = Number; PSG = Polysomnography; OSDB = Obstructive Sleep Disordered Breathing

Table G-4 Techniques for tonsillectomy

Domain | Description of applicability of evidence
Population | Studies included individuals ages less than 2 to 41 years (mean age in all studies <18 years). Most studies (28) included children with OSDB (typically based on clinical diagnosis vs. PSG) and recurrent throat infection (typically not defined). Studies typically did not report race/ethnicity or BMI.
Intervention | Partial or total tonsillectomy/adenotonsillectomy using various surgical techniques.
Comparators | Comparators included other surgical techniques (e.g., coblation, electrocautery).
Outcomes | Outcomes included return to normal diet or activity and postoperative bleeding and were reported in multiple ways (days, %, n children, etc.). Studies collected data from patient diaries and direct interviews/assessments. Outcomes were collected at various time points with followup times ranging from 9 days post-procedure to 12 months. Most studies had short-term (< 6 months) followup.
Setting | Studies were conducted in the United States (8), Greece (3), Sweden (2), Turkey (2), Brazil (2), Egypt (1), France (1), and Thailand (1). Patients were typically selected from otolaryngology clinics.

BMI = Body Mass Index; N = Number; PSG = Polysomnography; OSDB = Obstructive Sleep Disordered Breathing

Table G-5 Perioperative medications

Domain | Description of applicability of evidence
Population | Studies included individuals from 1-18 years of age. Most studies (38) did not specify indications for tonsillectomy. Six studies included children with mixed indications, and five studies included children with recurrent throat infection (typically not defined). Studies typically did not report race/ethnicity and BMI.
Intervention | NSAIDs, anti-emetics, or steroids (different doses and/or routes or combinations of these agents or these agents plus a non-NSAID analgesic or anesthetic) given perioperatively during tonsillectomy. Doses and routes of administration of intervention and comparator agents and of rescue medications varied widely.
Comparators | Comparators included other agents or no agent/placebo.
Outcomes | Outcomes included return to normal diet or activity, need for rescue medications, and postoperative bleeding. Studies reported outcomes in multiple ways (days, %, n children, mean dose, etc.). Data were collected from patient diaries and direct interviews/assessments. Most studies had short-term followup (24 hours post-op to ≤ 5 months).
Setting | Most studies (32) were conducted in less developed countries; 17 were conducted in the US, European countries, Japan, South Korea, or Australia. Studies typically recruited patients from otolaryngology or pediatric clinics.

BMI = Body Mass Index; N = Number; NSAID = Nonsteroidal Anti-Inflammatory Drug

Table G-6 Postoperative medications

Domain | Description of applicability of evidence
Population | Studies included children between 1 and 18 years of age. Most studies did not specify the indication for tonsillectomy (8). Four studies included children who had either OSDB or recurrent throat infection as surgical indications, and one included only children with throat infection. Neither race/ethnicity nor BMI were typically reported. One study included primarily Asian children.^6^
Intervention | Postoperative medications for pain following tonsillectomy (typically via unspecified techniques). Agents included steroids, NSAIDs, non-NSAID analgesics, and antibiotics, individually or in combination.
Comparators | Other agents or no agent/placebo.
Outcomes | Studies reported primarily on need for rescue medications, bleeding, and time to return to normal diet or activity. Outcomes were primarily reported using diaries or questionnaires, and studies typically had short-term followup (3-16 days post-procedure. One study had 5-month followup.
Setting | Studies were conducted in Denmark (3), New Zealand (2), Canada (2) Jordan (1), Serbia (1), Korea (1), Egypt (1), Pakistan (1), and Turkey (1). Patients were recruited primarily from otolaryngology clinics or pediatric surgery units.

NSAID = Nonsteroidal Anti-Inflammatory Drug; OSDB = Obstructive Sleep Disordered Breathing

## References

1 Marcus CL, Moore RH, Rosen CL, et al. (2013). A randomized trial of adenotonsillectomy for childhood sleep apnea. N Engl J Med.
2 Burstein DH, Jackson A, Weedon J, et al. (2013). Adenotonsillectomy for sleep-disordered breathing in a predominantly obese pediatric population. Int J Pediatr Otorhinolaryngol.
3 Goldstein NA, Pugazhendhi V, Rao SM, et al. (2004). Clinical assessment of pediatric obstructive sleep apnea. Pediatrics.
4 Sudarsan SS, Paramasivan VK, Arumugam SV, et al. (2014). Comparison of treatment modalities in syndromic children with obstructive sleep apnea--a randomized cohort study. Int J Pediatr Otorhinolaryngol.
5 Brigance JS, Miyamoto RC, Schilt P, et al. (2009). Surgical management of obstructive sleep apnea in infants and young toddlers. Otolaryngol Head Neck Surg.
6 Merry AF, Edwards KE, Ahmad Z, et al. (2013). Randomized comparison between the combination of acetaminophen and ibuprofen and each constituent alone for analgesia following tonsillectomy in children. Can J Anaesth.