# Appendix F Risk of Bias Ratings

Table F-1 Risk of bias assessment for randomized controlled trials

Author Year | Allocation Sequence Generated Adequately | Allocation Treatment Adequately Concealed | Participants Analyzed In Groups Originally Assigned | Design Account for Confounding | Rule Out Impact from Concurrent Intervention or Unintended Exposure | Fidelity Maintained to Intervention Protocol | If Attrition, Were Missing Data Handled Appropriately | Difference in Length of Follow-up Between Groups | Outcome Assessors Blinded | Interventions/ Exposures Assessed Clearly | Outcomes Assessed Clearly | Potential Outcomes Prespecified | All Prespecified Outcomes Reported | Risk of Bias Rating
Kordeluk 2016^1^ | Unclear | Unclear | Yes | Yes | Unclear | No | Yes or NA | Yes | Yes | Yes | No | Yes | Yes | High
Murto 2015^2^ | Yes | Yes | Yes | No | Yes | Yes or no indication of lack of fidelity | No | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Gao 2015^3^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Abdel-Ghaffar 2015^4^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Park 2015^5^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Kelly 2015^6^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Low
Elbadawey 2015^7^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Larusso 2015^8^ | Unclear | Unclear | Yes | No | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Amin 2014^9^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
D'Eredita 2014^10^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Sudarsan 2014^11^ | No | No | Yes | Yes | No | Yes or no indication of lack of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Aysenur 2014^12^ | Unclear | Yes | Yes | Yes | Unclear | Yes or no indication of lack of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Moss 2014^13^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Aydin 2014^14^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of lack of fidelity | NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Gabr 2014^15^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Quante 2014^16-21^ | Yes | Yes | Yes | Yes | Unclear | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Ericsson 2014^22, 23^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Faiz 2013^24^ | Yes | Yes | Yes | Yes | No | Yes or no indication of lack of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Merry 2013^25^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Ju 2013^26^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Basuni 2013^27^ | Yes | Yes | Yes | Yes | Ye | Yes or no indication of lack of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
El-Fattah 2013^28^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Chaidas 2013^29^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of lack of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Al-Layla 2013^30^ | No | No | Yes | Unclear | Unclear | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | High
Beriat 2013^31^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Matin 2013^32^ | Unclear | Unclear | Yes | No | Yes | Unclear | Yes or NA | Yes | Unclear | Yes | Unclear | Yes | Yes | High
Muhammad 2013^33^ | Unclear | Unclear | Yes | Unclear | Unclear | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | High
Gallagher 2012^34^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Frampton 2012^35^ | No | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Hermans 2012^36^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Low
Havel 2012^37^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Aouad 2012^38^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Macassey 2012^39^ | Yes | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Yilmaz 2012^40^ | Unclear | Unclear | Yes | Unclear | Yes | Unclear | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | High
Safavi 2012^41^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Paramasivan 2012^42^ | Unclear | Unclear | Yes | Unclear | NA | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Chang 2012^43^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Kemal 2012^44^ | Unclear | Unclear | Yes | Unclear | Unclear | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | High
Hamza 2012^45^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | High
Al-Shehri 2012^46^ | Unclear | Unclear | Yes | Yes | Unclear | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Abdel-Ghaffar 2012^47^ | Yes | Unclear | Yes | Yes | No | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Beriat 2012^48^ | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | High
Omrani 2012^49^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Salama 2012^50^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Matin 2012^51^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Moghaddam 2012^52^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Solanki 2012^53^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Stelter 2012^54, 55^ | No | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Parker 2011^56^ | No | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Roje 2011^57,70^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Babademez 2011^58^ | Unclear | No | Yes | Unclear | Yes | Unclear | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | High
Jones 2011^59^ | Unclear | No | Yes | Unclear | Yes | Unclear | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | High
Ferri 2011^60^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Unclear | Yes | No | Yes | Yes | Yes | Yes | Moderate
Haraldsson 2011^61^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
D'Eredita 2010^62^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Ferreira 2010^63^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Pruegsanusak 2010^64^ | Unclear | Unclear | Yes | No | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Rhendra Hardy 2010^65^ | No | No | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Lock 2010^66-68^ | Yes | Unclear | Yes | Yes | Yes | Unclear | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Karaman 2009^69^ | No | No | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Unclear | No | Unclear | High
D'Eredita 2009^70^ | Yes | Yes | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Unclear | Unclear | Moderate
Parker 2009^71^ | Yes | Yes | Yes | Yes | Yes | Unclear | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Stephens 2009^72^ | Unclear | Yes | Yes | Yes | Unclear | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Erdem 2009^73^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Wilson 2009^74^ | Unclear | Unclear | Yes | No | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | No | Unclear | High
Hesham 2009^75^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Khani 2009^76^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Bhattacharya 2009^77^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Unclear | Yes | Yes | Moderate
Lee 2009^78^ | Unclear | Yes | Yes | Yes | Unclear | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Czarnetzki 2008^79^ | Unclear | Unclear | Yes | NA | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Sezen 2008^80^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Erdem 2008^81^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Lee 2008^82^ | Yes | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | No | Yes | No | Yes | Yes | Yes | No | High
Chimona 2008^83^ | Unclear | Unclear | Yes | NA | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
D'Agostino 2008^84^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Korkmaz 2008^85^ | Unclear | No | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Davis 2008^86^ | Yes | Yes | Yes | Yes | Unclear | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Chang 2008^87^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Bitar 2008^88^ | No | No | No | Unclear | Unclear | Unclear | Yes or NA | Yes | No | Unclear | Yes | Yes | Yes | High
Hegazy 2008^89^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Alajmi 2008^90^ | No | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Skoulakis 2007^91^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Bukhari 2007^92^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Bolton 2007^93^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Mitic 2007^94^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Park 2007^95^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Kim 2007^96^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Shapiro 2007^97^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Salomone 2007^98^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Antila 2006^99^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Coticchia 2006^100^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Leaper 2006^101^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Sobol 2006^102^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Derkay 2006^103^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Parsons 2006^104^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | High
Kamal 2006^105^ | Unclear | Unclear | Yes | Unclear | No | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | High
Kaan 2006^106^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Ericsson 2006^107^ | Yes | No | Yes | No | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | No | Yes | Yes | Yes | Moderate
Lister 2006^108^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Hussain 2006^109^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Ericsson 2006^107, 110, 111^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Mohammad 2006^112^ | Unclear | Unclear | Yes | Yes | Unclear | No | Yes or NA | Yes | Yes | Yes | No | Yes | Yes | High
Ragab 2005^113^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | High
Kutluhan 2005^114^ | Unclear | No | Unclear | No | Unclear | Yes or no indication of fidelity | Unclear | Yes | No | Unclear | Unclear | Unclear | Unclear | High
Oko 2005^115^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Kirazli 2005^116^ | Unclear | Unclear | Yes | Unclear | Unclear | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | High
Kedek 2005^117^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | Moderate
Chang 2005^118^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Unclear | Yes | Yes | Moderate
Bhattacharya 2005^119^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Lister 2005^108^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Abdul Monem 2005^120^ | Unclear | Unclear | Yes | Yes | Unclear | Yes or no indication | No | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Collison 2004^121^ | No | No | Yes | No | Unclear | Unclear | Yes or NA | NA | Yes | Yes | Yes | Yes | Yes | High
Samarkandi 2004^122^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Unclear | Yes | Yes | Moderate
Chan 2004^123^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | No | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
D'Eredita 2004^124^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Unclear | Moderate
Hanasono 2004^125^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Low
Celiker 2004^126^ | Yes | Yes | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Goldstein 2004^127^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | No | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Lalicevic 2004^128^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Stoker 2004^129^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Keidan 2004^130^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
van Staaij 2004^131-133^ | Yes | Unclear | Yes | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Yes | Yes | Moderate
Fujii 2003^134^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Perkins 2003^135^ | Unclear | No | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Elhakim 2003^136^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Low
Willging 2003^137^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Stoker 2003^138^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Oztekin 2002^139^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Sukhani 2002^140^ | Unclear | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Kothari 2002^141^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Shah 2002^142^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Raut 2002^143^ | Yes | Unclear | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Giannoni 2002^144^ | Yes | Yes | Yes | Yes | No | No | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Kokki 2002^145^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Paradise 2002^146_a^ | Yes | Unclear | Unclear | Yes | Yes | Unclear | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Paradise 2002^146_b^ | Yes | Unclear | Unclear | Yes | Yes | Unclear | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Young 2001^147^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Densert 2001^148^ | Unclear | Unclear | Yes | Unclear | Unclear | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | High
Walker 2001^149^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Temple 2001^150^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Bergler 2001^151^ | Unclear | Unclear | Yes | Unclear | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Romsing 2001^152^ | Yes | Yes | Yes | Yes | Unclear | Yes or no indication of fidelity | No | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Fujii 2001^153^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Fujii 2001^154^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Nunez 2000^155^ | Unclear | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Pizzuto 2000^156^ | Yes | Yes | Yes | Unclear | No | Yes or no indication of fidelity | Yes or NA | Yes | Unclear | Yes | Yes | Yes | Yes | Moderate
Holt 2000^157^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Jensen 2000^158^ | Yes | Yes | Yes | Yes | Yes | Yes or no indication of fidelity | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Romsing 1998^159^ | Unclear | Unclear | Yes | Yes | No | Unclear | Yes or NA | Yes | No | Yes | Yes | Yes | Yes | High
Stage 1988^160^ | No | Unclear | Yes | Unclear | Yes | Unclear | Yes or NA | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Paradise 1984^161_a^ | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | No | Yes | No | Yes | Yes | Yes | Yes | High

Table F-2 Risk of bias assessment for observational studies

Author, Year | Inclusion/Exclusion Criteria Same | Participant Recruiting Strategy Same | Comparison Group Selection Appropriate | Important Variations in Execution of Study | Outcome Assessor Blinded | Valid and Reliable Measures Used to Assess Inclusion Criteria | Valid and Reliable Measures Used to Assess Outcomes | Valid and Reliable Measures Used to Assess Confounding | Balance Allocation Between Groups | Confounding Variables In Design or Analysis | Primary Outcomes Reported | Length of Follow-up Same | High Loss to Follow-up Assessed | Risk of Bias Rating
Mukhatiyar, 2016^162^ | Yes | Yes | Cannot determine or no description of the derivation of the comparison group | Not applicable; no variations | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Yes, valid and reliable measure used | Yes or study accounts for imbalance between groups through a post hoc approach such as multivariate analysis | Yes, accounted for or none identified | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Thong, 2016 ^163^ | Partially: some, but not all criteria, applied to all groups or not clearly stated if some criteria are applied to all groups | No, differs | yes, appropriate | Not applicable; no variations | No, not blinded | Cannot determine or measurement approach not reported | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | Yes or study accounts for imbalance between groups through a post hoc approach such as multivariate analysis | Yes, accounted for or none identified | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | No, impact not assessed | High
Trosman, 2016^164^ | Yes | Yes | Yes, appropriate | Not applicable; no variations | No, not blinded | cannot determine or measurement approach not reported | Yes, valid and reliable measure used for all outcomes of interest | Yes, valid and reliable measure used | Yes or study accounts for imbalance between groups through a post hoc approach such as multivariate analysis | Yes, accounted for or none identified | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Koshy, 2015^165^ | Yes | Yes | Yes, appropriate | Not applicable, no variations | No, not blinded | Cannot Determine | Yes, valid and reliable measure used for all outcomes of interest | Yes, valid and reliable measure used | No or cannot determine | Yes, accounted for or none identified | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | NA | Moderate
Volsky, 2014^166^ | Yes | Cannot Determine | Yes, appropriate | Cannot determine | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Yes, valid and reliable measure used | Yes or study accounts for imbalance between groups through a post hoc approach such as multivariate analysis | Yes, accounted for or none identified | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | No, impact not assessed | Moderate
Chettri, 2014^167^ | Yes | Yes | Yes, appropriate | Yes, accounts for variations | Yes, blinded | Yes, valid and reliable measure used | Partially, valid and reliable measures used for some outcomes of interest | Cannot determine or measurement approach not reported | No or cannot determine | No, not taken into account | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Biggs, 2014^168^ | Yes | Yes | No, inappropriate | Cannot determine | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Yes, valid and reliable measure used | No or cannot determine | Yes, accounted for or none identified | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Burstein, 2013^169^ | Yes | Yes | Yes, appropriate | Cannot determine | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Yes, valid and reliable measure used | Yes or study accounts for imbalance between groups through a post hoc approach such as multivariate analysis | Partially: some variables taken into account or adjustment achieved to some extent | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Moriniere, 2013^170^ | Partially: some, but not all criteria, applied to all groups or not clearly stated if some criteria are applied to all groups | Yes | Yes, appropriate | Yes, accounts for variations | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | No, valid and reliable measure not used | No or cannot determine | No, not taken into account | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Cannot determine | High
Ozkiris, 2012^171^ | Yes | Yes | Yes, appropriate | Yes, accounts for variations | Yes, blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Yes, valid and reliable measure used | No or cannot determine | Cannot determine | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Ozkiris, 2012^172^ | Yes | Yes | Yes, appropriate | Yes, accounts for variations | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | No or cannot determine | Cannot determine | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Ragab, 2011^173^ | Yes | Yes | Not applicable | Yes, accounts for variations | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | Not applicable: study does not include a comparison group (case series or one study group) | Cannot determine | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Ben-Israel, 2011^174^ | Yes | No, differs | Yes, appropriate | Cannot determine | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | No or cannot determine | Cannot determine | Yes, all important outcome(s) reported | No, different length of follow-up | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | High
Lock, 2010^66-68^ | Yes | Yes | Yes, appropriate | Cannot determine | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | Yes or study accounts for imbalance between groups through a post hoc approach such as multivariate analysis | Cannot determine | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Yes | Moderate
Brigance, 2009^175^ | Yes | Yes | Yes, appropriate | Cannot determine | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | No, valid and reliable measure not used | No or cannot determine | Partially: some variables taken into account or adjustment achieved to some extent | Yes, all important outcome(s) reported | No, different length of follow-up | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | High
Di Rienzo, 2008^176^ | Yes | Yes | Yes, appropriate | Yes, accounts for variations | Unclear | Cannot determine or measurement approach not reported | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | No or cannot determine | Cannot determine | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Vlastos, 2008^177^ | Yes | Yes | Yes, appropriate | Yes, accounts for variations | No, not blinded | Yes, valid and reliable measure used | Partially, valid and reliable measures used for some outcomes of interest | No, valid and reliable measure not used | No or cannot determine | No, not taken into account | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Cannot determine | High
Fernandes, 2008^178^ | Yes | Cannot Determine | Cannot determine or no description of the derivation of the comparison group | Cannot determine | Unclear | No, valid and reliable measure not used | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | No or cannot determine | No, not taken into account | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | High
Orvidas, 2006^179^ | Yes | Yes | Yes, appropriate | Cannot determine | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | No or cannot determine | Partially: some variables taken into account or adjustment achieved to some extent | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Tarasiuk, 2004^180^ | Yes | Yes | Yes, appropriate | Not applicable; no variations | No, not blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | No, valid and reliable measure not used | No or cannot determine | Yes, accounted for or none identified | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | Moderate
Silveira, 2003^181^ | Yes | Yes | Yes, appropriate | Yes, accounts for variations | Yes, blinded | Yes, valid and reliable measure used | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | Yes or study accounts for imbalance between groups through a post hoc approach such as multivariate analysis | Yes, accounted for or none identified | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable | Moderate
Udaipurwala, 2002^182^ | Partially: some, but not all criteria, applied to all groups or not clearly stated if some criteria are applied to all groups | Cannot Determine | Cannot determine or no description of the derivation of the comparison group | Yes, accounts for variations | No, not blinded | Cannot determine or measurement approach not reported | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | No or cannot determine | Partially: some variables taken into account or adjustment achieved to some extent | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | High
Dualibi, 2002^183^ | Yes | Cannot Determine | Cannot determine or no description of the derivation of the comparison group | Cannot determine | No, not blinded | Cannot determine or measurement approach not reported | Yes, valid and reliable measure used for all outcomes of interest | Cannot determine or measurement approach not reported | No or cannot determine | Cannot determine | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Cannot determine | High
Nawasreh, 2000^184^ | Yes | Cannot Determine | Cannot determine or no description of the derivation of the comparison group | Cannot determine | No, not blinded | Cannot determine or measurement approach not reported | Cannot determine | No, valid and reliable measure not used | No or cannot determine | No, not taken into account | Yes, all important outcome(s) reported | Yes, same length of follow-up or remedied through analysis | Not applicable: no loss to follow-up or loss to follow-up was not considered to be high | High
Paradise, 1984^161_b^ | Partially: some, but not all criteria, applied to all groups or not clearly stated if some criteria are applied to all groups | Yes | Yes, appropriate | Yes, accounts for variations | No, not blinded | Yes, valid and reliable measure used | Cannot determine | Cannot determine or measurement approach not reported | No or cannot determine | No, not taken into account | Yes, all important outcome(s) reported | No, different length of follow-up | No | High

Table F-3 Risk of bias assessment for studies reporting harms

Author, Year | Were the harms predefined using standardized or precise definitions? | Were all pre-specified harms reported? | Did the author(s) use STANDARD scale(s) or checklist(s) for harms collection? | Were the statistical methods used to assess the main harm or adverse event outcomes adequate? | Rating
Mahadevan, 2016^185^ | Yes | Yes | No | Yes | Moderate
Spektor, 2016^186^ | Yes | Yes | Yes | Yes | Low
Kshirsagar, 2016^187^ | Yes | Yes | Yes | Yes | Low
Harounian, 2016^188^ | Yes | Yes | Yes | Yes | Low
Elinder, 2016^189^ | Yes | Yes | Yes | Yes | Low
Odhagen, 2016^190^ | Yes | Yes | Yes | Yes | Low
Raol, 2016^191^ | Yes | Yes | Yes | Yes | Low
Pfaff, 2016^192^ | Yes | Yes | Yes | Yes | Low
Padia, 2015^193^ | No | Yes | Yes | Yes | Moderate
Achar, 2015^194^ | Yes | Yes | Unclear | Yes | Moderate
Edmonson, 2015^195^ | Yes | Yes | Yes | Yes | Low
Bangiyev, 2015^196^ | Unclear | Unclear | Unclear | Yes | High
Lavin, 2015^197^ | Yes | Yes | Yes | Yes | Low
Duval, 2015^198^ | Yes | Yes | Yes | Yes | Low
Abdullah, 2015^199^ | No | Yes | Unclear | Yes | High
Suzuki, 2014^200^ | Yes | Yes | Unclear | Yes | Moderate
Mahant, 2014^201, 202^ | Yes | Yes | Yes | Yes | Low
Bhattacharyya, 2014^203, 204^ | Yes | Yes | Yes | Yes | Low
Sarny, 2013^205, 206^ | Yes | Yes | Yes | Yes | Low
Hultcrantz, 2013^207, 208^ | Yes | Yes | Yes | Yes | Low
Walner, 2012^209^ | Yes | Yes | Unclear | Yes | Moderate
Perkins, 2012^210^ | Yes | Yes | Unclear | Yes | Moderate
Tweedie, 2012^211^ | Yes | Yes | Unclear | Yes | Moderate
Tomkinson, 2012^212, 213^ | Yes | Yes | Yes | Yes | Low
Hessen, 2011^214^ | Yes | Yes | Yes | Yes | Low
Vlastos, 2010^215^ | No | Unclear | No | Unclear | High
Bhattacharyya, 2010^216^ | Yes | Yes | Unclear | Yes | Moderate
Kim, 2010^217^ | Yes | Yes | Unclear | Yes | Moderate
Gooda, 2010^218^ | Yes | Yes | Unclear | Yes | Moderate
D'Agostino, 2009^219^ | Yes | Yes | Unclear | Yes | Moderate
Kvaerner, 2009^220^ | Yes | Yes | Yes | Yes | Low
Arnoldner, 2008^221^ | Yes | Yes | Unclear | Yes | Moderate
Jones, 2007^222^Yes | Yes | Unclear | Yes | Yes | Moderate
Lowe, 2007^223^ | Yes | Yes | Yes | Yes | Low
Abou-Jaoude, 2006^224^ | Unclear | Unclear | Unclear | Yes | High
Zhao, 2006^225^ | Unclear | Unclear | Unclear | Yes | High
Tomkinson, 2005^226^ | Yes | Yes | Yes | Yes | Low
Clark, 2004^227^ | Yes | Yes | Yes | Yes | Low
Mills, 2004^228^ | Yes | Yes | Unclear | Yes | Moderate
Granell, 2004^229^ | Yes | Unclear | Yes | Yes | High
Windfuhr, 2002^230, 231^ | Yes | Yes | Unclear | Yes | Moderate
Liu, 2001^232^ | Yes | Yes | Unclear | Yes | Moderate
Peeters, 1999^233^ | Yes | Yes | Unclear | Yes | Moderate
Kang, 1994^234^ | Yes | Yes | Unclear | Yes | Moderate
Yardley, 1992 ^235^ | Yes | Yes | Unclear | Yes | Moderate
Lannigan, 1993^236^ | Yes | Yes | Unclear | Yes | Moderate
Colclasure, 1990^237^ | Yes | Yes | Unclear | Yes | Moderate
Chowdhury, 1988^238^ | Yes | Yes | Unclear | Yes | Moderate
Carithers, 1987^239^ | Yes | Yes | Unclear | Yes | Moderate
Crysdale, 1986^240^ | Yes | Yes | Unclear | Yes | Moderate
Herdman, 1986^241^ | Yes | Yes | Unclear | Yes | Moderate
Capper, 1984^242^ | Unclear | Yes | Unclear | Yes | High
Yuan, 1984^243^ | No | Yes | No | Yes | High
Carmody, 1982^244^ | Yes | Yes | Unclear | Yes | Moderate

## References

1 Murto K, Lamontagne C, McFaul C, et al. (2015). Celecoxib pharmacogenetics and pediatric adenotonsillectomy: a double-blinded randomized controlled study. Can J Anaesth.
2 Gao W, Zhang QR, Jiang L, et al. (2015). Comparison of local and intravenous dexamethasone for postoperative pain and recovery after tonsillectomy. Otolaryngol Head Neck Surg.
3 Abdel-Ghaffar HS, Abdel-Azeem HG, Roushdy MM. (2015). Safety and efficacy of pre-incisional peritonsillar lornoxicam in paediatric post-tonsillectomy pain: a prospective double-blind, placebo-controlled, split-body clinical study. Clin Otolaryngol.
4 Park SK, Kim J, Kim JM, et al. (2015). Effects of oral prednisolone on recovery after tonsillectomy. Laryngoscope.
5 Kelly LE, Sommer DD, Ramakrishna J, et al. (2015). Morphine or Ibuprofen for post-tonsillectomy analgesia: a randomized trial. Pediatrics.
6 Elbadawey MR, Hegazy HM, Eltahan AE, et al. (2015). A randomised controlled trial of coblation, diode laser and cold dissection in paediatric tonsillectomy. J Laryngol Otol.
7 Amin SM. (2014). Evaluation of gabapentin and dexamethasone alone or in combination for pain control after adenotonsillectomy in children. Saudi J Anaesth.
8 D'Eredita R. (2014). Molecular resonance tonsillectomy in children: comparative study over standard techniques in an 11-year study. Otolaryngol Head Neck Surg.
9 Sudarsan SS, Paramasivan VK, Arumugam SV, et al. (2014). Comparison of treatment modalities in syndromic children with obstructive sleep apnea--a randomized cohort study. Int J Pediatr Otorhinolaryngol.
10 Aysenur D, Mine C, Ozgur Y, et al. (2014). Pre-emptive peritonsillar dexamethasone vs. levobupivacaine infiltration for relief of post-adenotonsillectomy pain in children: a controlled clinical study. Int J Pediatr Otorhinolaryngol.
11 Moss JR, Watcha MF, Bendel LP, et al. (2014). A multicenter, randomized, double-blind placebo-controlled, single dose trial of the safety and efficacy of intravenous ibuprofen for treatment of pain in pediatric patients undergoing tonsillectomy. Paediatr Anaesth.
12 Aydin S, Taskin U, Altas B, et al. (2014). Post-tonsillectomy morbidities: randomised, prospective controlled clinical trial of cold dissection versus thermal welding tonsillectomy. J Laryngol Otol.
13 Gabr S, Harhash K, Fouly M, et al. (2014). Microdebrider intracapsular tonsillotomy versus conventional extracapsular tonsillectomy. The Egyptian Journal of Otolaryngology.
14 Quante M, Wang R, Weng J, et al. (2014). The Effect of Adenotonsillectomy for Childhood Sleep Apnea on Cardiometabolic Measures. Sleep.
15 Marcus CL, Moore RH, Rosen CL, et al. (2013). A randomized trial of adenotonsillectomy for childhood sleep apnea. N Engl J Med.
16 Weinstock TG, Rosen CL, Marcus CL, et al. (2014). Predictors of obstructive sleep apnea severity in adenotonsillectomy candidates. Sleep.
17 Chervin RD, Ellenberg SS, Hou X, et al. (2015). Prognosis for Spontaneous Resolution of Obstructive Sleep Apnea in Children. Chest.
18 Garetz SL, Mitchell RB, Parker PD, et al. (2015). Quality of life and obstructive sleep apnea symptoms after pediatric adenotonsillectomy. Pediatrics.
19 Katz ES, Moore RH, Rosen CL, et al. (2014). Growth after adenotonsillectomy for obstructive sleep apnea: an RCT. Pediatrics.
20 Ericsson E, Graf J, Lundeborg-Hammarstrom I, et al. (2014). Tonsillotomy versus tonsillectomy on young children: 2 year post surgery follow-up. J Otolaryngol Head Neck Surg.
21 Ericsson E, Lundeborg I, Hultcrantz E. (2009). Child behavior and quality of life before and after tonsillotomy versus tonsillectomy. Int J Pediatr Otorhinolaryngol.
22 Faiz SH, Rahimzadeh P, Alebouyeh MR, et al. (2013). A Randomized Controlled Trial on Analgesic Effects of Intravenous Acetaminophen versus Dexamethasone after Pediatric Tonsillectomy. Iran Red Crescent Med J.
23 Merry AF, Edwards KE, Ahmad Z, et al. (2013). Randomized comparison between the combination of acetaminophen and ibuprofen and each constituent alone for analgesia following tonsillectomy in children. Can J Anaesth.
24 Ju NY, Cui GX, Gao W. (2013). Ropivacaine plus dexamethasone infiltration reduces postoperative pain after tonsillectomy and adenoidectomy. Int J Pediatr Otorhinolaryngol.
25 Basuni AS, Ezz HA, Albirmawy OA. (2013). Preoperative peritonsillar infiltration of dexamethasone and levobupivacaine reduces pediatric post-tonsillectomy pain: a double-blind prospective randomized clinical trial. J Anesth.
26 El-Fattah AM, Ramzy E. (2013). Pre-emptive triple analgesia protocol for tonsillectomy pain control in children: double-blind, randomised, controlled, clinical trial. J Laryngol Otol.
27 Chaidas KS, Kaditis AG, Papadakis CE, et al. (2013). Tonsilloplasty versus tonsillectomy in children with sleep-disordered breathing: short- and long-term outcomes. Laryngoscope.
28 Al-Layla A, Mahafza TM. (2013). Antibiotics do not reduce post-tonsillectomy morbidity in children. Eur Arch Otorhinolaryngol.
29 Beriat GK, Ezerarslan H, Kocaturk S. (2013). Microdebrider tonsillotomy in children with obstructive tonsillar hypertrophy. Journal of Clinical and Analytical Medicine.
30 Matin M, Chowdhury MA, Haque ME, et al. (2013). Coblation Tonsillectomy Versus Blunt Dissectomy Tonsillectomy in Children. Anwer khan modern medical college journal.
31 Muhammad R, Wadood F, Khan MR, et al. (2013). Comparison of Efficacy of Dexamethasone and Orogastric Suction in Reducing Post Tonsillectomy Vomiting in Children. Gomal journal of medical sciences.
32 Gallagher TQ, Hill C, Ojha S, et al. (2012). Perioperative dexamethasone administration and risk of bleeding following tonsillectomy in children: a randomized controlled trial. JAMA.
33 Frampton SJ, Ward MJ, Sunkaraneni VS, et al. (2012). Guillotine versus dissection tonsillectomy: randomised, controlled trial. J Laryngol Otol.
34 Hermans V, De Pooter F, De Groote F, et al. (2012). Effect of dexamethasone on nausea, vomiting, and pain in paediatric tonsillectomy. Br J Anaesth.
35 Havel M, Sroka R, Englert E, et al. (2012). Intraindividual comparison of 1,470 nm diode laser versus carbon dioxide laser for tonsillotomy: a prospective, randomized, double blind, controlled feasibility trial. Lasers Surg Med.
36 Aouad MT, Nasr VG, Yazbeck-Karam VG, et al. (2012). A comparison between dexamethasone and methylprednisolone for vomiting prophylaxis after tonsillectomy in inpatient children: a randomized trial. Anesth Analg.
37 Macassey E, Dawes P, Taylor B, et al. (2012). The effect of a postoperative course of oral prednisone on postoperative morbidity following childhood tonsillectomy. Otolaryngol Head Neck Surg.
38 Yilmaz M, Duzlu M, Catli T, et al. (2012). Thermal welding versus cold knife tonsillectomy: a prospective randomized study. Kaohsiung J Med Sci.
39 Safavi M, Honarmand A, Habibabady MR, et al. (2012). Assessing intravenous ketamine and intravenous dexamethasone separately and in combination for early oral intake, vomiting and postoperative pain relief in children following tonsillectomy. Med Arh.
40 Paramasivan VK, Arumugam SV, Kameswaran M. (2012). Randomised comparative study of adenotonsillectomy by conventional and coblation method for children with obstructive sleep apnoea. Int J Pediatr Otorhinolaryngol.
41 Chang H, Hah JH. (2012). Comparison of post-tonsillectomy pain with two different types of bipolar forceps: low temperature quantum molecular resonance device versus high temperature conventional electrocautery. Acta Otolaryngol.
42 Kemal O. (2012). Harmonic scalpel versus bipolar tonsillectomy: a double-blind clinical trial. Eur Arch Otorhinolaryngol.
43 Hamza A, Hayat U, Khan Q, et al. (2012). To compare the efficacy of ketorolac and pethidine for postoperative pain relief in first 24 hours after tonsillectomy. Pakistan Journal of Medical and Health Sciences.
44 Al-Shehri AMS. (2012). Post-tonsillectomy pain and bleeding in children: A comparison of traditional tonsillectomy with electrodissection tonsillectomy. Current Pediatric Research.
45 Abdel-Ghaffar HS, Sayed JA, Fathy MA, et al. (2012). Preincisional peritonsillar vs. intravenous lornoxicam for posttonsillectomy analgesia: A clinical and platelet aggregometry comparative study. Egyptian Journal of Anaesthesia.
46 Beriat GK, Ezerarslan H, Ekmekci P, et al. (2012). The use of Bipolar electrocautery tonsillectomy in patients with pediatric respiratory tract obstruction. Journal of Clinical and Analytical Medicine.
47 Omrani M, Barati B, Omidifar N, et al. (2012). Coblation versus traditional tonsillectomy: A double blind randomized controlled trial. Journal of Research in Medical Sciences.
48 Salama MA. (2012). Harmonic scalpel tonsillectomy versus coblation tonsillectomy. Menoufiya Medical Journal.
49 Matin M, Chowdhury MA. (2012). Diode laser versus blunt dissection tonsillectomy. Bangladesh Journal of Otorhinolaryngology.
50 Yegane Moghaddam A, Fazel MR. (2012). Comparison of analgesic effect between gabapentin and diclofenac on post-operative pain in patients undergoing tonsillectomy. Pain practice.
51 Solanki NS, Goswami M, Thaker N. (2012). Bupivacaine infiltration versus diclofenac suppository for post-tonsillectomy pain relief in paediatric patients. National Journal of Medical Research.
52 Stelter K, Ihrler S, Siedek V, et al. (2012). 1-year follow-up after radiofrequency tonsillotomy and laser tonsillotomy in children: a prospective, double-blind, clinical study. Eur Arch Otorhinolaryngol.
53 Stelter K, de la Chaux R, Patscheider M, et al. (2010). Double-blind, randomised, controlled study of post-operative pain in children undergoing radiofrequency tonsillotomy versus laser tonsillotomy. J Laryngol Otol.
54 Parker NP, Walner DL. (2011). Post-operative pain following coblation or monopolar electrocautery tonsillectomy in children: a prospective, single-blinded, randomised comparison. Clin Otolaryngol.
55 Roje Z, Racic G, Kardum G, et al. (2011). Is the systemic inflammatory reaction to surgery responsible for post-operative pain after tonsillectomy, and is it “technique-related”?. Wien Klin Wochenschr.
56 Babademez MA, Yurekli MF, Acar B, et al. (2011). Comparison of radiofrequency ablation, laser and coblator techniques in reduction of tonsil size. Acta Otolaryngol.
57 Jones DT, Kenna MA, Guidi J, et al. (2011). Comparison of postoperative pain in pediatric patients undergoing coblation tonsillectomy versus cautery tonsillectomy. Otolaryngol Head Neck Surg.
58 Ferri E, Armato E. (2011). Argon plasma coagulation versus cold dissection in pediatric tonsillectomy. Am J Otolaryngol.
59 Haraldsson PO, Attner P, Fredelius L, et al. (2011). Intrapersonal randomized controlled trial comparing bipolar scissors and conventional cold tonsillectomy. Otorhinolaryngology Clinics.
60 D'Eredita R. (2010). Tonsillectomy in children: a five-factor analysis among three techniques--reporting upon clinical results, anesthesia time, surgery time, bleeding, and cost. Laryngoscope.
61 Ferreira RF, Serapiao CJ, Ferreira AP, et al. (2010). Cost and outcomes after cold and mixed adenotonsillectomy in children. Laryngoscope.
62 Pruegsanusak K, Wongsuwan K, Wongkittithawon J. (2010). A randomized controlled trial for perioperative morbidity in microdebrider versus cold instrument dissection tonsillectomy. J Med Assoc Thai.
63 Rhendra Hardy MZ, Zayuah MS, Baharudin A, et al. (2010). The effects of topical viscous lignocaine 2% versus per-rectal diclofenac in early post-tonsillectomy pain in children. Int J Pediatr Otorhinolaryngol.
64 Lock C, Wilson J, Steen N, et al. (2010). North of England and Scotland Study of Tonsillectomy and Adeno-tonsillectomy in Children(NESSTAC): a pragmatic randomised controlled trial with a parallel non-randomised preference study. Health Technol Assess.
65 Wilson JA, Steen IN, Lock CA, et al. (2012). Tonsillectomy: a cost-effective option for childhood sore throat? Further analysis of a randomized controlled trial. Otolaryngol Head Neck Surg.
66 Lock C, Wilson J, Steen N, et al. (2010). Childhood tonsillectomy: who is referred and what treatment choices are made? Baseline findings from the North of England and Scotland Study of Tonsillectomy and Adenotonsillectomy in Children (NESSTAC). Arch Dis Child.
67 Karaman M, Ilhan AE, Dereci G, et al. (2009). Determination of optimum dosage of intraoperative single dose dexamethasone in pediatric tonsillectomy and adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
68 D'Eredita R, Bozzola L. (2009). Molecular resonance vs. coblation tonsillectomy in children. Laryngoscope.
69 Parker D, Howe L, Unsworth V, et al. (2009). A randomised controlled trial to compare postoperative pain in children undergoing tonsillectomy using cold steel dissection with bipolar haemostasis versus coblation technique. Clin Otolaryngol.
70 Roje Z, Racic G, Dogas Z, et al. (2009). Postoperative morbidity and histopathologic characteristics of tonsillar tissue following coblation tonsillectomy in children: a prospective randomized single-blind study. Coll Antropol.
71 Stephens J, Singh A, Hughes J, et al. (2009). A prospective multi-centre randomised controlled trial comparing PlasmaKnife with bipolar dissection tonsillectomy: evaluating an emerging technology. Int J Pediatr Otorhinolaryngol.
72 Erdem AF, Yoruk O, Silbir F, et al. (2009). Tropisetron plus subhypnotic propofol infusion is more effective than tropisetron alone for the prevention of vomiting in children after tonsillectomy. Anaesth Intensive Care.
73 Wilson YL, Merer DM, Moscatello AL. (2009). Comparison of three common tonsillectomy techniques: a prospective randomized, double-blinded clinical study. Laryngoscope.
74 Hesham A. (2009). Bipolar diathermy versus cold dissection in paediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
75 Khani A, Jaafarpour M, Khajavikhan J, et al. (2009). The effect of dexamethasone on morbidity related to vomiting, pain and oral intake in children after tonsillectomy. Journal of Clinical and Diagnostic Research.
76 Bhattacharya D, Mazumdar S, Chowdhury S, et al. (2009). Single dose IV dexamethasone with preemptive transdermal diclofenac patch reduces opioid requirement and postoperative morbidity following tonsillectomy. Journal of Anaesthesiology Clinical Pharmacology.
77 Lee IH, Sung CY, Han JI, et al. (2009). The preemptive analgesic effect of ketorolac and propacetamol for adenotonsillectomy in pediatric patients. Korean Journal of Anesthesiology.
78 Czarnetzki C, Elia N, Lysakowski C, et al. (2008). Dexamethasone and risk of nausea and vomiting and postoperative bleeding after tonsillectomy in children: a randomized trial. JAMA.
79 Sezen OS, Kaytanci H, Kubilay U, et al. (2008). Comparison between tonsillectomy with thermal welding and the conventional ‘cold’ tonsillectomy technique. ANZ J Surg.
80 Erdem AF, Yoruk O, Alici HA, et al. (2008). Subhypnotic propofol infusion plus dexamethasone is more effective than dexamethasone alone for the prevention of vomiting in children after tonsillectomy. Paediatr Anaesth.
81 Lee SW, Jeon SS, Lee JD, et al. (2008). A comparison of postoperative pain and complications in tonsillectomy using BiClamp forceps and electrocautery tonsillectomy. Otolaryngol Head Neck Surg.
82 Chimona T, Proimos E, Mamoulakis C, et al. (2008). Multiparametric comparison of cold knife tonsillectomy, radiofrequency excision and thermal welding tonsillectomy in children. Int J Pediatr Otorhinolaryngol.
83 D'Agostino R, Tarantino V, Calevo MG. (2008). Blunt dissection versus electronic molecular resonance bipolar dissection for tonsillectomy: operative time and intraoperative and postoperative bleeding and pain. Int J Pediatr Otorhinolaryngol.
84 Korkmaz O, Bektas D, Cobanoglu B, et al. (2008). Partial tonsillectomy with scalpel in children with obstructive tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
85 Davis PJ, Fertal KM, Boretsky KR, et al. (2008). The effects of oral ondansetron disintegrating tablets for prevention of at-home emesis in pediatric patients after ear-nose-throat surgery. Anesth Analg.
86 Chang KW. (2008). Intracapsular versus subcapsular coblation tonsillectomy. Otolaryngol Head Neck Surg.
87 Hegazy HM, Albirmawy OA, Kaka AH, et al. (2008). Pilot comparison between potassium titanyl phosphate laser and bipolar radiofrequency in paediatric tonsillectomy. J Laryngol Otol.
88 Alajmi MA, Al Noumas HS, Al-Abdulhadi KA, et al. (2008). Steroids for reducing post-tonsillectomy morbidity. Kuwait Medical Journal.
89 Skoulakis CE, Papadakis CE, Manios AG, et al. (2007). Tonsilloplasty in children with obstructive symptoms. J Otolaryngol.
90 Bukhari MA, Al-Ammar AY. (2007). Monopolar electrodissection versus cold dissection tonsillectomy among children. Saudi Med J.
91 Bolton CM, Myles PS, Carlin JB, et al. (2007). Randomized, double-blind study comparing the efficacy of moderate-dose metoclopramide and ondansetron for the prophylactic control of postoperative vomiting in children after tonsillectomy. Br J Anaesth.
92 Mitic S, Tvinnereim M, Lie E, et al. (2007). A pilot randomized controlled trial of coblation tonsillectomy versus dissection tonsillectomy with bipolar diathermy haemostasis. Clin Otolaryngol.
93 Park A, Proctor MD, Alder S, et al. (2007). Subtotal bipolar tonsillectomy does not decrease postoperative pain compared to total monopolar tonsillectomy. Int J Pediatr Otorhinolaryngol.
94 Kim MS, Cote CJ, Cristoloveanu C, et al. (2007). There is no dose-escalation response to dexamethasone (0.0625-1.0 mg/kg) in pediatric tonsillectomy or adenotonsillectomy patients for preventing vomiting, reducing pain, shortening time to first liquid intake, or the incidence of voice change. Anesth Analg.
95 Shapiro NL, Bhattacharyya N. (2007). Cold dissection versus coblation-assisted adenotonsillectomy in children. Laryngoscope.
96 Salomone R, Jordao Visioli A, Aquino MM, et al. (2007). Ultrasonic Curved Shears in Tonsillectomy: Comparative Clinical Trial Between this New Surgical Technique and the Technique with the Cold Blade Surgical Knife.
97 Lister M. (2005). Microdebrider partial tonsillectomy vs. electrosurgical tonsillectomy: a randomized, double-blind, paired-control study of postoperative pain.
98 Antila H, Manner T, Kuurila K, et al. (2006). Ketoprofen and tramadol for analgesia during early recovery after tonsillectomy in children. Paediatr Anaesth.
99 Coticchia JM, Yun RD, Nelson L, et al. (2006). Temperature-controlled radiofrequency treatment of tonsillar hypertrophy for reduction of upper airway obstruction in pediatric patients. Arch Otolaryngol Head Neck Surg.
100 Leaper M, Mahadevan M, Vokes D, et al. (2006). A prospective randomised single blinded study comparing harmonic scalpel tonsillectomy with bipolar tonsillectomy. Int J Pediatr Otorhinolaryngol.
101 Sobol SE, Wetmore RF, Marsh RR, et al. (2006). Postoperative recovery after microdebrider intracapsular or monopolar electrocautery tonsillectomy: a prospective, randomized, single-blinded study. Arch Otolaryngol Head Neck Surg.
102 Derkay CS, Darrow DH, Welch C, et al. (2006). Post-tonsillectomy morbidity and quality of life in pediatric patients with obstructive tonsils and adenoid: microdebrider vs electrocautery. Otolaryngol Head Neck Surg.
103 Parsons SP, Cordes SR, Comer B. (2006). Comparison of posttonsillectomy pain using the ultrasonic scalpel, coblator, and electrocautery. Otolaryngol Head Neck Surg.
104 Kamal SA, Basu S, Kapoor L, et al. (2006). Harmonic scalpel tonsillectomy: a prospective study. Eur Arch Otorhinolaryngol.
105 Kaan MN, Odabasi O, Gezer E, et al. (2006). The effect of preoperative dexamethasone on early oral intake, vomiting and pain after tonsillectomy. Int J Pediatr Otorhinolaryngol.
106 Hultcrantz E, Ericsson E. (2004). Pediatric tonsillotomy with the radiofrequency technique: less morbidity and pain. Laryngoscope.
107 Hussain F, Hafiz A, Siddique M. (2006). Analgesia; for children undergoing tonsillectomy (a clinical trial of three analgesic regimens in a peripheral hospital). Professional Medical Journal.
108 Ericsson E, Graf J, Hultcrantz E. (2006). Pediatric tonsillotomy with radiofrequency technique: long-term follow-up. Laryngoscope.
109 Ericsson E, Wadsby M, Hultcrantz E. (2006). Pre-surgical child behavior ratings and pain management after two different techniques of tonsil surgery. Int J Pediatr Otorhinolaryngol.
110 Ragab SM. (2005). Bipolar radiofrequency dissection tonsillectomy: a prospective randomized trial. Otolaryngol Head Neck Surg.
111 Kutluhan A, Caksen H, Yurttas V, et al. (2005). The effectiveness of unilateral tonsillectomy in chronic adenotonsillar hypertrophy. Kulak Burun Bogaz Ihtis Derg.
112 Oko MO, Ganly I, Loughran S, et al. (2005). A prospective randomized single-blind trial comparing ultrasonic scalpel tonsillectomy with tonsillectomy by blunt dissection in a pediatric age group. Otolaryngol Head Neck Surg.
113 Kirazli T, Bilgen C, Midilli R, et al. (2005). Bipolar electrodissection tonsillectomy in children. Eur Arch Otorhinolaryngol.
114 Kedek A, Derbent A, Uyar M, et al. (2005). Pre-emptive effects of ibuprofen syrup and lidocaine infiltration on post-operative analgesia in children undergoing adenotonsillectomy. J Int Med Res.
115 Chang KW. (2005). Randomized controlled trial of Coblation versus electrocautery tonsillectomy. Otolaryngol Head Neck Surg.
116 Bhattacharya D, Mondol MC, Dasgupta S, et al. (2005). A comparison of rectal diclofenac with intravenous pethidine for pain relief following tonsillectomy and adenoidectomy in children. Journal of Anaesthesiology Clinical Pharmacology.
117 Abdul Monem ETM, Adul Hady E, Abu Beih AA. (2005). Acetaminophen versus diclofenac sodium after pediatric tonsillectomy. New Egyptian journal of medicine.
118 Collison PJ, Weiner R. (2004). Harmonic scalpel versus conventional tonsillectomy: a double-blind clinical trial. Ear Nose Throat J.
119 Samarkandi AH, Shaikh MA, Ahmad RA, et al. (2004). Use of dexamethasone to reduce postoperative vomiting and pain after pediatric tonsillectomy procedures. Saudi Med J.
120 Chan KH, Friedman NR, Allen GC, et al. (2004). Randomized, controlled, multisite study of intracapsular tonsillectomy using low-temperature plasma excision. Arch Otolaryngol Head Neck Surg.
121 D'Eredita R, Marsh RR. (2004). Contact diode laser tonsillectomy in children. Otolaryngol Head Neck Surg.
122 Hanasono MM, Lalakea ML, Mikulec AA, et al. (2004). Perioperative steroids in tonsillectomy using electrocautery and sharp dissection techniques. Arch Otolaryngol Head Neck Surg.
123 Celiker V, Celebi N, Canbay O, et al. (2004). Minimum effective dose of dexamethasone after tonsillectomy. Paediatr Anaesth.
124 Goldstein NA, Pugazhendhi V, Rao SM, et al. (2004). Clinical assessment of pediatric obstructive sleep apnea. Pediatrics.
125 Lalicevic S, Djordjevic I. (2004). Comparison of benzydamine hydrochloride and Salvia officinalis as an adjuvant local treatment to systemic nonsteroidal anti-inflammatory drug in controlling pain after tonsillectomy, adenoidectomy, or both: an open-label, single-blind, randomized clinical trial. Curr Ther Res Clin Exp.
126 Stoker KE, Don DM, Kang DR, et al. (2004). Pediatric total tonsillectomy using coblation compared to conventional electrosurgery: a prospective, controlled single-blind study. Otolaryngol Head Neck Surg.
127 Keidan I, Zaslansky R, Eviatar E, et al. (2004). Intraoperative ketorolac is an effective substitute for fentanyl in children undergoing outpatient adenotonsillectomy. Paediatr Anaesth.
128 van Staaij BK, van den Akker EH, Rovers MM, et al. (2004). Effectiveness of adenotonsillectomy in children with mild symptoms of throat infections or adenotonsillar hypertrophy: open, randomised controlled trial. Bmj.
129 Buskens E, van Staaij B, van den Akker J, et al. (2007). Adenotonsillectomy or watchful waiting in patients with mild to moderate symptoms of throat infections or adenotonsillar hypertrophy: a randomized comparison of costs and effects. Arch Otolaryngol Head Neck Surg.
130 Le TM, Rovers MM, van Staaij BK, et al. (2007). Alterations of the oropharyngeal microbial flora after adenotonsillectomy in children: a randomized controlled trial. Arch Otolaryngol Head Neck Surg.
131 Fujii Y, Tanaka H. (2003). Results of a prospective, randomized, double-blind, placebo-controlled, dose-ranging trial to determine the effective dose of ramosetron for the prevention of vomiting after tonsillectomy in children. Clin Ther.
132 Perkins J, Dahiya R. (2003). Microdissection needle tonsillectomy and postoperative pain: a pilot study. Arch Otolaryngol Head Neck Surg.
133 Elhakim M, Ali NM, Rashed I, et al. (2003). Dexamethasone reduces postoperative vomiting and pain after pediatric tonsillectomy. Can J Anaesth.
134 Willging JP, Wiatrak BJ. (2003). Harmonic scalpel tonsillectomy in children: a randomized prospective study. Otolaryngol Head Neck Surg.
135 Donnelly LF, Surdulescu V, Chini BA, et al. (2003). Upper airway motion depicted at cine MR imaging performed during sleep: comparison between young Patients with and those without obstructive sleep apnea. Radiology.
136 Oztekin S, Hepaguslar H, Kar AA, et al. (2002). Preemptive diclofenac reduces morphine use after remifentanil-based anaesthesia for tonsillectomy. Paediatr Anaesth.
137 Sukhani R, Pappas AL, Lurie J, et al. (2002). Ondansetron and dolasetron provide equivalent postoperative vomiting control after ambulatory tonsillectomy in dexamethasone-pretreated children. Anesth Analg.
138 Kothari P, Patel S, Brown P, et al. (2002). A prospective double-blind randomized controlled trial comparing the suitability of KTP laser tonsillectomy with conventional dissection tonsillectomy for day case surgery. Clin Otolaryngol Allied Sci.
139 Shah UK, Galinkin J, Chiavacci R, et al. (2002). Tonsillectomy by means of plasma-mediated ablation: prospective, randomized, blinded comparison with monopolar electrosurgery. Arch Otolaryngol Head Neck Surg.
140 Raut VV, Bhat N, Sinnathuray AR, et al. (2002). Bipolar scissors versus cold dissection for pediatric tonsillectomy--a prospective, randomized pilot study. Int J Pediatr Otorhinolaryngol.
141 Giannoni C, White S, Enneking FK. (2002). Does dexamethasone with preemptive analgesia improve pediatric tonsillectomy pain?. Otolaryngol Head Neck Surg.
142 Kokki H, Salonen A. (2002). Comparison of pre- and postoperative administration of ketoprofen for analgesia after tonsillectomy in children. Paediatr Anaesth.
143 Paradise JL, Bluestone CD, Colborn DK, et al. (2002). Tonsillectomy and adenotonsillectomy for recurrent throat infection in moderately affected children. Pediatrics.
144 Young C, MacRae J. (2001). Tonsillectomy. A comparative study of dissection/snare vs suction-cautery. Can Oper Room Nurs J.
145 Densert O, Desai H, Eliasson A, et al. (2001). Tonsillotomy in children with tonsillar hypertrophy. Acta Otolaryngol.
146 Walker RA, Syed ZA. (2001). Harmonic scalpel tonsillectomy versus electrocautery tonsillectomy: a comparative pilot study. Otolaryngol Head Neck Surg.
147 Temple RH, Timms MS. (2001). Paediatric coblation tonsillectomy. Int J Pediatr Otorhinolaryngol.
148 Bergler W, Huber K, Hammerschmitt N, et al. (2001). Tonsillectomy with argon plasma coagulation (APC): evaluation of pain and hemorrhage. Laryngoscope.
149 Fujii Y, Tanaka H. (2001). Comparison of granisetron, droperidol, and metoclopramide for prevention of postoperative vomiting in children with a history of motion sickness undergoing tonsillectomy. J Pediatr Surg.
150 Fujii Y, Saitoh Y, Kobayashi N. (2001). Prevention of vomiting after tonsillectomy in children: granisetron versus ramosetron. Laryngoscope.
151 Nunez DA, Provan J, Crawford M. (2000). Postoperative tonsillectomy pain in pediatric patients: electrocautery (hot) vs cold dissection and snare tonsillectomy--a randomized trial. Arch Otolaryngol Head Neck Surg.
152 Pizzuto MP, Brodsky L, Duffy L, et al. (2000). A comparison of microbipolar cautery dissection to hot knife and cold knife cautery tonsillectomy. Int J Pediatr Otorhinolaryngol.
153 Holt R, Rask P, Coulthard KP, et al. (2000). Tropisetron plus dexamethasone is more effective than tropisetron alone for the prevention of postoperative nausea and vomiting in children undergoing tonsillectomy. Paediatr Anaesth.
154 Jensen AB, Christiansen DB, Coulthard K, et al. (2000). Tropisetron reduces postoperative vomiting in children undergoing tonsillectomy. Paediatr Anaesth.
155 Romsing J, Hertel S, Harder A, et al. (1998). Examination of acetaminophen for outpatient management of postoperative pain in children. Paediatr Anaesth.
156 Stage J, Jensen JH, Bonding P. (1988). Post-tonsillectomy haemorrhage and analgesics. A comparative study of acetylsalicylic acid and paracetamol. Clin Otolaryngol Allied Sci.
157 Paradise JL, Bluestone CD, Bachman RZ, et al. (1984). Efficacy of tonsillectomy for recurrent throat infection in severely affected children. Results of parallel randomized and nonrandomized clinical trials. N Engl J Med.
158 Koshy E, Watt H, Curcin V, et al. (2015). Tonsillectomy among children with low baseline acute throat infection consultation rates in UK general practices: a cohort study. BMJ Open.
159 Chettri S, Bhandary S, Nepal A, et al. (2014). A single blind controlled study comparing bipolar elecrocautery tonsillectomy to cold dissection method in pediatric age groups. Health Renaissance.
160 Biggs SN, Vlahandonis A, Anderson V, et al. (2014). Long-term changes in neurocognition and behavior following treatment of sleep disordered breathing in school-aged children. Sleep.
161 Burstein DH, Jackson A, Weedon J, et al. (2013). Adenotonsillectomy for sleep-disordered breathing in a predominantly obese pediatric population. Int J Pediatr Otorhinolaryngol.
162 Moriniere S, Roux A, Bakhos D, et al. (2013). Radiofrequency tonsillotomy versus bipolar scissors tonsillectomy for the treatment of OSAS in children: a prospective study. Eur Ann Otorhinolaryngol Head Neck Dis.
163 Ozkiris M. (2012). Comparison of three techniques in pediatric tonsillectomy. Eur Arch Otorhinolaryngol.
164 Ozkiris M, Kapusuz Z, Yildirim YS, et al. (2012). The effect of paracetamol, metamizole sodium and ibuprofen on postoperative hemorrhage following pediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
165 Ragab MA, Atef A, Mosleh M, et al. (2011). Bipolar scissors tonsillectomy: what are the advantages?. J Otolaryngol Head Neck Surg.
166 Ben-Israel N, Zigel Y, Tal A, et al. (2011). Adenotonsillectomy improves slow-wave activity in children with obstructive sleep apnoea. Eur Respir J.
167 Brigance JS, Miyamoto RC, Schilt P, et al. (2009). Surgical management of obstructive sleep apnea in infants and young toddlers. Otolaryngol Head Neck Surg.
168 Di Rienzo Businco L, Coen Tirelli G. (2008). Paediatric tonsillectomy: radiofrequency-based plasma dissection compared to cold dissection with sutures. Acta Otorhinolaryngol Ital.
169 Vlastos IM, Parpounas K, Economides J, et al. (2008). Tonsillectomy versus tonsillotomy performed with scissors in children with tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
170 Fernandes AA, Alcantara TA, D'Avila DV, et al. (2008). Study of weight and height development in children after adenotonsillectomy. Braz J Otorhinolaryngol.
171 Orvidas LJ, St Sauver JL, Weaver AL. (2006). Efficacy of tonsillectomy in treatment of recurrent group A beta-hemolytic streptococcal pharyngitis. Laryngoscope.
172 Tarasiuk A, Simon T, Tal A, et al. (2004). Adenotonsillectomy in children with obstructive sleep apnea syndrome reduces health care utilization. Pediatrics.
173 Chau KW, Ng KK, Kwok KL, et al. (2004). Survey of children with obstructive sleep apnea syndrome in Hong Kong of China. Chin Med J (Engl).
174 Silveira H, Soares JS, Lima HA. (2003). Tonsillectomy: cold dissection versus bipolar electrodissection. Int J Pediatr Otorhinolaryngol.
175 Dualibi AP, Pignatari SS, Weckx LL. (2002). Nutritional evaluation in surgical treatment of children with hypertrophic tonsils and or adenoids. Int J Pediatr Otorhinolaryngol.
176 Nawasreh O, Fraihat A, Maaita J. (2000). The effect of preoperative intravenous dexamethasone in pediatric adenotonsillectomy. Journal of the Bahrain Medical Society.
177 Padia R, Olsen G, Henrichsen J, et al. (2015). Hospital and Surgeon Adherence to Pediatric Tonsillectomy Guidelines Regarding Perioperative Dexamethasone and Antibiotic Administration. Otolaryngol Head Neck Surg.
178 Achar P, Sharma RK, De S, et al. (2015). Does primary indication for tonsillectomy influence post-tonsillectomy haemorrhage rates in children?. Int J Pediatr Otorhinolaryngol.
179 Edmonson MB, Eickhoff JC, Zhang C. (2015). A population-based study of acute care revisits following tonsillectomy. J Pediatr.
180 Bangiyev JN, Thottam PJ, Christenson JR, et al. (2015). The association between pediatric general emergency department visits and post operative adenotonsillectomy hospital return. Int J Pediatr Otorhinolaryngol.
181 Lavin JM, Shah RK. (2015). Postoperative complications in obese children undergoing adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
182 Duval M, Wilkes J, Korgenski K, et al. (2015). Causes, costs, and risk factors for unplanned return visits after adenotonsillectomy in children. Int J Pediatr Otorhinolaryngol.
183 Suzuki S, Yasunaga H, Matsui H, et al. (2014). Impact of systemic steroids on posttonsillectomy bleeding: analysis of 61 430 patients using a national inpatient database in Japan. JAMA Otolaryngol Head Neck Surg.
184 Mahant S, Keren R, Localio R, et al. (2014). Dexamethasone and risk of bleeding in children undergoing tonsillectomy. Otolaryngol Head Neck Surg.
185 Mahant S, Keren R, Localio R, et al. (2014). Variation in quality of tonsillectomy perioperative care and revisit rates in children's hospitals. Pediatrics.
186 Bhattacharyya N, Shapiro NL. (2014). Associations between socioeconomic status and race with complications after tonsillectomy in children. Otolaryngol Head Neck Surg.
187 Shay S, Shapiro NL, Bhattacharyya N. (2015). Revisit rates and diagnoses following pediatric tonsillectomy in a large multistate population. Laryngoscope.
188 Sarny S, Habermann W, Ossimitz G, et al. (2013). What lessons can be learned from the Austrian events?. ORL J Otorhinolaryngol Relat Spec.
189 Sarny S, Ossimitz G, Habermann W, et al. (2011). Hemorrhage following tonsil surgery: a multicenter prospective study. Laryngoscope.
190 Hultcrantz E, Ericsson E, Hemlin C, et al. (2013). Paradigm shift in Sweden from tonsillectomy to tonsillotomy for children with upper airway obstructive symptoms due to tonsillar hypertrophy. Eur Arch Otorhinolaryngol.
191 Sunnergren O, Hemlin C, Ericsson E, et al. (2014). Radiofrequency tonsillotomy in Sweden 2009-2012. Eur Arch Otorhinolaryngol.
192 Walner DL, Miller SP, Villines D, et al. (2012). Coblation tonsillectomy in children: incidence of bleeding. Laryngoscope.
193 Perkins JN, Liang C, Gao D, et al. (2012). Risk of post-tonsillectomy hemorrhage by clinical diagnosis. Laryngoscope.
194 Tweedie DJ, Bajaj Y, Ifeacho SN, et al. (2012). Peri-operative complications after adenotonsillectomy in a UK pediatric tertiary referral centre. Int J Pediatr Otorhinolaryngol.
195 Tomkinson A, Harrison W, Owens D, et al. (2012). Postoperative hemorrhage following adenoidectomy. Laryngoscope.
196 Tomkinson A, Harrison W, Owens D, et al. (2011). Risk factors for postoperative hemorrhage following tonsillectomy. Laryngoscope.
197 Hessen Soderman AC, Ericsson E, Hemlin C, et al. (2011). Reduced risk of primary postoperative hemorrhage after tonsil surgery in Sweden: results from the National Tonsil Surgery Register in Sweden covering more than 10 years and 54,696 operations. Laryngoscope.
198 Bhattacharyya N. (2010). Ambulatory pediatric otolaryngologic procedures in the United States: characteristics and perioperative safety. Laryngoscope.
199 Kim DW, Koo JW, Ahn SH, et al. (2010). Difference of delayed post-tonsillectomy bleeding between children and adults. Auris Nasus Larynx.
200 Gooda MR, Sheik I, Suleri A. (2010). Reducing post operative bleeding after tonsillectomies in children by modifying the monopolar diathermy technique: A study of 1500 patients. Pakistan Journal of Medical Sciences.
201 D'Agostino R, Tarantino V, Calevo MG. (2009). Post-tonsillectomy late haemorrhage: is it a preferably night-time event?. Int J Pediatr Otorhinolaryngol.
202 Kvaerner KJ. (2009). Benchmarking surgery: secondary post-tonsillectomy hemorrhage 1999-2005. Acta Otolaryngol.
203 Arnoldner C, Grasl M, Thurnher D, et al. (2008). Surgical revision of hemorrhage in 8388 patients after cold-steel adenotonsillectomies. Wien Klin Wochenschr.
204 Lowe D, van der Meulen J, Cromwell D, et al. (2007). Key messages from the National Prospective Tonsillectomy Audit. Laryngoscope.
205 Abou-Jaoude PM, Manoukian JJ, Daniel SJ, et al. (2006). Complications of adenotonsillectomy revisited in a large pediatric case series. J Otolaryngol.
206 Zhao YC, Berkowitz RG. (2006). Prolonged hospitalization following tonsillectomy in healthy children. Int J Pediatr Otorhinolaryngol.
207 Tomkinson A, De Martin S, Gilchrist CR, et al. (2005). Instrumentation and patient characteristics that influence postoperative haemorrhage rates following tonsil and adenoid surgery. Clin Otolaryngol.
208 Clark MP, Waddell A. (2004). The surgical arrest of post-tonsillectomy haemorrhage: hospital episode statistics. Ann R Coll Surg Engl.
209 Mills N, Anderson BJ, Barber C, et al. (2004). Day stay pediatric tonsillectomy--a safe procedure. Int J Pediatr Otorhinolaryngol.
210 Granell J, Gete P, Villafruela M, et al. (2004). Safety of outpatient tonsillectomy in children: a review of 6 years in a tertiary hospital experience. Otolaryngol Head Neck Surg.
211 Windfuhr JP, Chen YS. (2002). Incidence of post-tonsillectomy hemorrhage in children and adults: a study of 4,848 patients. Ear Nose Throat J.
212 Windfuhr JP, Chen YS. (2001). Hemorrhage following pediatric tonsillectomy before puberty. Int J Pediatr Otorhinolaryngol.
213 Liu JH, Anderson KE, Willging JP, et al. (2001). Posttonsillectomy hemorrhage: what is it and what should be recorded?. Arch Otolaryngol Head Neck Surg.
214 Lannigan FJ, Martin-Hirsch DP, Basey E. (1993). Clinical audit: is day-case adenotonsillectomy safe?. Br J Clin Pract.
215 Colclasure JB, Graham SS. (1990). Complications of outpatient tonsillectomy and adenoidectomy: a review of 3,340 cases. Ear Nose Throat J.
216 Chowdhury K, Tewfik TL, Schloss MD. (1988). Post-tonsillectomy and adenoidectomy hemorrhage. J Otolaryngol.
217 Carithers JS, Gebhart DE, Williams JA. (1987). Postoperative risks of pediatric tonsilloadenoidectomy. Laryngoscope.
218 Crysdale WS, Russel D. (1986). Complications of tonsillectomy and adenoidectomy in 9409 children observed overnight. CMAJ.
219 Herdman RC, Bates GJ. (1986). Childhood tonsillectomy and discharge after 24 hours. J Laryngol Otol.
220 Kristensen S, Tveteras K. (1984). Post-tonsillectomy haemorrhage. A retrospective study of 1150 operations. Clin Otolaryngol Allied Sci.
221 Capper JW, Randall C. (1984). Post-operative haemorrhage in tonsillectomy and adenoidectomy in children. J Laryngol Otol.
222 Yuan CC, Yu DY, Jun TS, et al. (1984). Guillotine tonsillectomy without anesthesia. Auris Nasus Larynx.
223 Carmody D, Vamadevan T, Cooper SM. (1982). Post tonsillectomy haemorrhage. J Laryngol Otol.