# Appendix E Methods for Meta-Analyses

## Key Question 1

To assess whether treatment of children suffering from obstructive sleep-disordered breathing (OSDB) with tonsillectomy results in improved outcomes compared with continuous positive airway pressure (CPAP), or watchful waiting with supportive care (including pharmacologic treatment), we constructed a simple meta-analysis using the change in apnea hypopnea index (AHI) as a measure of treatment efficacy. Because there were only three studies included in the final dataset, we fit a fixed effects model for the treatment effect. The expected arm response was modeled as:

θ_i_ = μ + δ I ( t_i_ )

where I is the indicator function, t_i_ is a dummy variable that equals one for a treatment arm and zero for a control arm.

The response variable d_i_ is the difference between the outcome and baseline for arm i, and is hypothesized to have the sampling distribution:

d_i_ ∼ N ( θ_i_ , s_i_ )

where s_i_ is assumed to be the empirical standard error of the difference between the sample means of the outcome and baseline response variables:

s_i_ = sqrt((s_i_ ( o )^2^)/(n_i_ ( o )) + (s_i_ ( b )^2^)/(n_i_ ( b )))

The effectiveness of the treatment was assessed by examining the estimate of δ and its associated 95% credible interval.

## Key Questions 3 and 4 (Harms)

We implemented a mixed-effects, arm-based meta-analysis to assess the influence of different surgical procedures as well as the effect of partial vs. total removal procedures on the occurrence of bleeding outcomes following tonsillectomy. The occurrence of bleeding events in most studies are reported as counts, and can therefore be modeled as a binomial response, with inference derived from estimates of the probability of a bleeding event.

x_ki_ ∼ Binomial ( n_i_ , π_ki_ )

where π_ki_ is the probability of a bleeding event for intervention k for study i. This probability is modeled hierarchically as a logit-linear model with treatment effects and a study-specific random effect as follows:

logit ( p_ki_ ) = θ_k_ + β I ( partial_k_ ) + α I ( high RoB_i_ ) + ∈_i_

here, θ_k_ is a surgery-specific mean and β the effect of a partial removal when partial_k_ is true, while ∊_i_ and α_i_ are a study random effect and a high risk of bias effect, respectively, that correspond to study i.

Logit-linear model parameters were given zero-mean normal priors with σ = 5, which correspond to diffuse information when transformed to the inverse-logit scale. The study random effect was assumed normally distributed with an unknown standard deviation that was estimated from data, with a broad half-Cauchy prior distribution.

This model was fit to each of four bleeding outcome data: re-operation bleeding, re-admission bleeding, primary bleeding, and secondary bleeding.

## Key Question 5

To assess the effectiveness of perioperative steroids on post-operative bleeding rates associated with tonsillectomy, we employed a Bayesian mixed-effects binomial meta-analytic model. We assumed bleeding type-specific baseline rates of bleeding, as well as bleeding type-specific intervention effects, and a fixed effect for dose. Additionally, we included study random effects to account for correlation among arms in the same study.

logit ( p_ijk_ ) = θ_k_ + α x_i_^( dose )^ + δ_k_ x_i_^( treat )^ + ∈_i_

However, the model above showed substantial lack of fit due to the prevalence of zeros in the bleeding counts. There appeared to be a mixture of outcomes, one of which never results in bleeding, and the other which may (according to the binomial model). Thus, we expanded the model to account for the zero-inflated data. Hence the distribution of the observed bleeding cases becomes:

y_i_ ∼ { 0 , with probability ( 1 − ψ ) Binomial ( n_i_ , p_ijk_ ) , with probability ψ

In other words, some study arms had no chance of post-operative bleeding, with probability 1 − ψ, while the remainder experienced bleeding with probability p_ijk_.

Logit-linear model parameters were given zero-mean normal priors with σ = 5, which correspond to diffuse information when transformed to the inverse-logit scale. Random effects were assumed normally distributed with an unknown standard deviation that was estimated from data, with a broad half-Cauchy prior distribution.

## Model Fitting

All models were fit using the No U-turn Sampler (Hoffman and Gelman 2014), a self-tuning, gradient-based Markov chain Monte Carlo (MCMC) algorithm. Models were checked for convergence using the Gelman-Rubin statistic (Gelman and Rubin 1992) and for goodness of fit using posterior predictive checks (Gelman et al. 2013). None of the final models showed evidence for lack of convergence or fit using these criteria.

## References

Hoffman MD, Gelman A. (2014). The No-U-turn sampler: adaptively setting path lengths in Hamiltonian Monte Carlo. The Journal of Machine Learning Research.
Gelman A, Rubin DB. (1992). Inference from Iterative Simulation Using Multiple Sequences. Statistical Science.
Gelman A, Carlin JB, Stern HS. (2013). Bayesian Data Analysis.