# Appendix D Excluded Studies

Reasons for Exclusion

X-1 | Does not address interventions or outcomes of interest in study conducted in relevant timeframe
X-2 | Not original research
X-3 | Does not address population of interest
X-5 | Not an eligible study design
X-6 | Not in English or not obtainable

1 Al-Sheikhli AR. (1980). Secretory otitis media in children. (A retrospective study of 249 cases). J Laryngol Otol.
2 Bernstein JM, Myers D, Kosinski D, et al. (1980). Antibody coated bacteria in otitis media with effusions. Ann Otol Rhinol Laryngol Suppl.
3 Boliston TA, Upton JJ. (1980). Infiltration with lignocaine and adrenaline in adult tonsillectomy. J Laryngol Otol.
4 Bosch A, Brandenburg JH, Gilchrist KW. (1980). Lymph node metastases in adenoid cystic carcinoma of the submaxillary gland. Cancer.
5 Brook I, Calhoun L, Yocum P. (1980). Beta-lactamase-producing isolates of Bacteroides species from children. Antimicrob Agents Chemother.
6 Brook I, Yocum P, Shah K. (1980). Surface vs core-tonsillar aerobic and anaerobic flora in recurrent tonsillitis. JAMA.
7 Brooks DN, Dogra TS. (1980). Long term results of treatment of middle ear effusion. J Laryngol Otol.
8 Buchwach KA, Birck HG. (1980). Serous otitis media and type 1 tympanoplasties in children. A retrospective study. Ann Otol Rhinol Laryngol Suppl.
9 Colling A, Kerr I, Maxted WR, et al. (1980). Streptococcal infection in a Junior Detention Centre: a five-year study. J Hyg (Lond).
10 Davidson TM, Calloway CA. (1980). Tonsillectomy and adenoidectomy-- its indications and its problems. West J Med.
11 Diamond O. (1980). Tonsils and adenoids: why the dilemma?. Am J Orthod.
12 Eggenberger K, Christen JP, Delarue C, et al. (1980). Streptococcal pharyngitis-tonsillitis in Swiss children. Diagnosis and management. Paediatrician.
13 Eliaschar I, Lavie P, Halperin E, et al. (1980). Sleep apneic episodes as indications for adenotonsillectomy. Arch Otolaryngol.
14 Enomoto T, Enomoto T, Matsui K, et al. (1980). Papillary hypertrophy of the palatine tonsils. Ann Otol Rhinol Laryngol.
15 Erviti VF, Templeton B, Bunce JV, et al. (1980). The relationship of pediatric resident recording behavior across medical conditions. Med Care.
16 Fiellau-Nikolajsen M, Falbe-Hansen J, Knudstrup P. (1980). Adenoidectomy for middle ear disorders: a randomized controlled trial. Clin Otolaryngol Allied Sci.
17 Flint EF. (1980). The use of the bipolar microcoagulator for haemostasis in tonsillectomy. Clin Otolaryngol Allied Sci.
18 Flint EF. (1980). The use of the bipolar microcoagulator for hemostasis in tonsillectomy. Clinical otolaryngology and allied sciences.
19 Frenkiel S, Black MJ, Small P. (1980). Persistent adenoid presenting as a nasopharyngeal mass. J Otolaryngol.
20 Freyss GE, Narcy PP, Manac'h Y, et al. (1980). Acoustic reflex as a predictor of middle ear effusion. Ann Otol Rhinol Laryngol Suppl.
21 Ginsburg CM, McCracken GH, Crow SD, et al. (1980). A controlled comparative study of penicillin V and cefadroxil therapy of group A streptococcal tonsillopharyngitis. J Int Med Res.
22 Grote JJ, Kuijpers W. (1980). Middle ear effusion and sinusitis. J Laryngol Otol.
23 Hibbert J, Stell PM, Wright A. (1980). Value of physical signs in the diagnosis of enlarged adenoids. Clin Otolaryngol Allied Sci.
24 Hsu SM, Ree HJ. (1980). Self-sandwich method. An improved immunoperoxidase technic for the detection of small amounts of antigens. Am J Clin Pathol.
25 Jackson IT, McGlynn MJ, Huskie CF, et al. (1980). Velopharyngeal incompetence in the absence of cleft palate: results of treatment in 20 cases. Plast Reconstr Surg.
26 Jeschke R, Stroder J. (1980). Continual observation of clinical and immunological parameters, in particular of salivary IgA, in tonsillectomised children. Arch Otorhinolaryngol.
27 Kaplan EL, Huew BB. (1980). The sensitivity and specificity of an agglutination test for antibodies to streptococcal extracellular antigens: a quantitative analysis and comparison of the Streptozyme test with the anti-streptolysin O and anti-deoxyribonuclease B tests. J Pediatr.
28 Katznelson D, Gross S. (1980). Familial clustering of tonsillectomies and adenoidectomies. Clin Pediatr (Phila).
29 Kawakita S, Inoue J, Takeuchi T, et al. (1980). The movement of streptococcal infection in Otsu City. Jpn Circ J.
30 Kirchhoff LV, Evans AS, McClelland KE, et al. (1980). A case-control study of Hodgkin's disease in Brazil. I. Epidemiogic aspects. Am J Epidemiol.
31 Klam WP. (1980). Pediatric considerations of diseases and surgery of the tonsils and adenoids. Ear Nose Throat J.
32 Konno A, Hoshino T, Togawa K. (1980). Influence of upper airway obstruction by enlarged tonsils and adenoids upon recurrent infection of the lower airway in childhood. Laryngoscope.
33 Kornblut AD. (1980). Surgery of the tonsils and adenoids. Ear Nose Throat J.
34 Kroeber MJ, Gray LP, Coates H. (1980). Tonsillectomy - current concepts and nursing care. Aust Nurses J.
35 Latham RA, Long RE, Latham EA. (1980). Cleft palate velopharyngeal musculature in a five-month-old infant: a three dimensional histological reconstruction. Cleft Palate J.
36 Lee ST. (1980). Intra-oral minor salivary gland tumours--a study of 25 cases. Ann Acad Med Singapore.
37 Leek JH. (1980). Stat tonsillectomy for peritonsillar abscess. Minn Med.
38 Mair IW, Haugeto OK, Elverland HH, et al. (1980). Chronic secretory otitis media. Int J Pediatr Otorhinolaryngol.
39 Marshak G, Neriah ZB. (1980). Adenoidectomy versus tympanostomy in chronic secretory otitis media. Ann Otol Rhinol Laryngol Suppl.
40 Mason RM, Warren DW. (1980). Adenoid involution and developing hypernasality in cleft palate. J Speech Hear Disord.
41 Maurizi M, Paludetti G, Todisco T, et al. (1980). Pulmonary function studies in adenoid hypertrophy. Int J Pediatr Otorhinolaryngol.
42 McCurdy JA. (1980). Manometric measurement of Eustachian tube ventilatory function. Laryngoscope.
43 Meistrup-Larsen KI, Mogensen HH, Helweg-Larsen K, et al. (1980). Studies on lymphoid cells of adenoid tissue in relation to clinical findings. ORL J Otorhinolaryngol Relat Spec.
44 Mill WB, Lee FA, Franssila KO. (1980). Radiation therapy treatment of stage I and II extranodal non-Hodgkin's lymphoma of the head and neck. Cancer.
45 Miller RH, Calcaterra TC. (1980). Adenoid cystic carcinoma of the nose, paranasal sinuses, and palate. Arch Otolaryngol.
46 Muenker G. (1980). Results after treatment of otitis media with effusion. Ann Otol Rhinol Laryngol Suppl.
47 Palmer JA, Mustard RA, Simpson WJ. (1980). Irradiation as an etiologic factor in tumours of the thyroid, parathyroid and salivary glands. Can J Surg.
48 Paradise JL, Bluestone CD, Rogers KD, et al. (1980). Efficacy of adenoidectomy in recurrent otitis media. Historical overview and preliminary results from a randomized, controlled trial. Ann Otol Rhinol Laryngol Suppl.
49 Peerless SA, Noiman AH. (1980). Etiology of otitis media with effusion: antihistamines--decongestants. Laryngoscope.
50 Poole MN, Engel GA, Chaconas SJ. (1980). Nasopharyngeal cephalometrics. Oral Surg Oral Med Oral Pathol.
51 Richardson MA, Seid AB, Cotton RT, et al. (1980). Evaluation of tonsils and adenoids in Sleep Apnea syndrome. Laryngoscope.
52 Roos LL, Roos NP, Gilbert P, et al. (1980). Continuity of care: does it contribute to quality of care?. Med Care.
53 Rowe LD, Hansen TN, Nielson D, et al. (1980). Continuous measurements of skin surface oxygen and carbon dioxide tensions in obstructive sleep apnea. Laryngoscope.
54 Roydhouse N. (1980). Adenoidectomy for otitis media with mucoid effusion. Ann Otol Rhinol Laryngol Suppl.
55 Ryhanen P, Kangas T, Rantakyla S. (1980). Premedication for outpatient adenoidectomy: comparison between ketamine and pethidine. Laryngoscope.
56 Saad EF. (1980). The underdeveloped palate in ear, nose and throat practice. Laryngoscope.
57 Saarnivaara L, Metsa-Ketela T, Mannisto P, et al. (1980). Pain relief and sputum prostaglandins in adults treated with pethidine, tilidine and indomethacin after tonsillectomy. A double-blind study. Acta anaesthesiologica Scandinavica.
58 Salmi HA. (1980). Comparison of sulphadiazine-trimethoprim and sulphamethoxazole-trimethoprim in the treatment of acute respiratory tract infections. Randomized double-blind trial. Chemotherapy.
59 Simpson RK, Colton J. (1980). A cephalometric study of velar stretch in adolescent subjects. Cleft Palate J.
60 Snow JB. (1980). Role of tonsillectomy and adenoidectomy in the management of children with middle ear effusion. Ann Otol Rhinol Laryngol Suppl.
61 Sorensen H, Solow B, Greve E. (1980). Assessment of the nasopharyngeal airway. A rhinomanometric and radiographic study in children with adenoids. Acta Otolaryngol.
62 Vianna NJ, Lawrence CE, Davies JN, et al. (1980). Tonsillectomy and childhood Hodgkin's disease. Lancet.
63 West RJ, Williams B. (1980). Radiographic studies of the ventricles in syringomyelia. Neuroradiology.
64 Yoshida Y, Ozawa A, Yamauchi S, et al. (1980). Tonsillectomy and autoantibodies in patients with habitual tonsillitis. Auris Nasus Larynx.
65 Zubair NA, Versichelen L, Rolly G. (1980). Effects of enflurane (Ethrane) anesthesia on children during short surgical procedures. Acta Anaesthesiol Belg.
66 Andersen E, Isager H, Hyllested K. (1981). Risk factors in multiple sclerosis: tuberculin reactivity, age at measles infection, tonsillectomy and appendectomy. Acta Neurol Scand.
67 Bachman RZ, DiGaudio KM, Menninger MT. (1981). The role of pediatric nurse practitioners in the tonsil and adenoid study. Pediatr Clin North Am.
68 Bluestone CD. (1981). Recent advances in the pathogenesis, diagnosis, and management of otitis media. Pediatr Clin North Am.
69 Bonding P, Tos M. (1981). Middle ear pressure during brief pathological conditions of the nose and throat. Acta Otolaryngol.
70 Bramwell RG, Manford ML. (1981). Premedication of children with trimeprazine tartrate. Br J Anaesth.
71 Brook I. (1981). Aerobic and anaerobic bacteriology of peritonsillar abscess in children. Acta Paediatr Scand.
72 Brook I, Leyva F. (1981). The treatment of the carrier state of group A beta-hemolytic streptococci with clindamycin. Chemotherapy.
73 Centor RM, Witherspoon JM, Dalton HP, et al. (1981). The diagnosis of strep throat in adults in the emergency room. Med Decis Making.
74 Croft CB, Shprintzen RJ, Ruben RJ. (1981). Hypernasal speech following adenotonsillectomy. Otolaryngol Head Neck Surg.
75 Crymble C, Vayda E. (1981). Surgical rates in the Canadian Forces and the general Canadian population. Clin Invest Med.
76 D'Achille KM, Flickinger DB, Riethmiller MK, et al. (1981). Antimicrobial use review in a family practice setting. Am J Hosp Pharm.
77 Decreton SJ, Clement PA. (1981). Comparative study of standard X-ray of the maxillary sinus and sinuscopy in children. Rhinology.
78 Elverland HH, Mair IW, Haugeto OK, et al. (1981). Influence of adenoid hypertrophy on secretory otitis media. Ann Otol Rhinol Laryngol.
79 Fiellau-Nikolajsen M. (1981). Tympanometry in three-year-old children. The 3-year follow-up of a cohort study. ORL J Otorhinolaryngol Relat Spec.
80 Fried MP, Forrest JL. (1981). Peritonsillitis. Evaluation of current therapy. Arch Otolaryngol.
81 Galioto GB, Fazio S. (1981). A double-blind controlled study of the haemostatic effect of Bothrops Jararaca haemocoagulase in tonsillectomy. International journal of clinical pharmacology research.
82 Gammelgaard NP, Juul A, Larsen K, et al. (1981). Comparison of a new analgesic, Ro 11-4337, with acetylsalicylic acid and placebo in pain following tonsillectomy: A randomized clinical trial. Curr-Ther-Res,-Clin-Exp.
83 Ghaffar A, Feldman W, Dolovich J. (1981). Otitis media in children. Can Fam Physician.
84 Ginsburg CM, McCracken GH, Nelson JD. (1981). Pharmacology of oral antibiotics used for treatment of otitis media and tonsillopharyngitis in infants and children. Ann Otol Rhinol Laryngol Suppl.
85 Gobbi PG, Cavalli P, Franzini B, et al. (1981). Tonsillectomy: a prognostic factor in Hodgkin's disease?. Tumori.
86 Hall LJ. (1981). Chronic serous otitis media. J Ky Med Assoc.
87 Harris PJ. (1981). Children in hospital--3. ‘I fell awful--where's my mummy?’. Nurs Times.
88 Herbild O, Bonding P. (1981). Peritonsillar abscess. Arch Otolaryngol.
89 Hibbert J. (1981). The occurrence of adenoidal signs and symptoms in normal children. Clin Otolaryngol Allied Sci.
90 Holt GR, Tinsley PP. (1981). Peritonsillar abscesses in children. Laryngoscope.
91 Holt GR, Watkins TM, Yoder MG, et al. (1981). The effect of tonsillectomy on impedance audiometry. Otolaryngol Head Neck Surg.
92 Hug JE, Pfaltz CR. (1981). Temporal bone pneumatization. A planimetric study. Arch Otorhinolaryngol.
93 Isaacs JH, Cassisi NJ. (1981). Quinsy: peritonsillar abscess revisited. J Fla Med Assoc.
94 Katsuta K. (1981). Clinical evaluation of a new nonsteroid analgesic antiinflammatory agent, Y-9213 for pain and inflammation after tonsillectomy. (A Double blind method in comparison with indometacin.). Oto-Rhino-Laryngology Tokyo.
95 Keller JD. (1981). Radiologic evaluation of the normal adult nasopharynx. Head Neck Surg.
96 Komisar A, Ruben RJ. (1981). Use of carbon dioxide laser in pediatric otolaryngologic disease. N Y State J Med.
97 Korsrud FR, Brandtzaeg P. (1981). Immunohistochemical evaluation of J-chain expression by intra- and extra-follicular immunoglobulin-producing human tonsillar cells. Scand J Immunol.
98 Leung VF. (1981). Tonsils and adenoids--current thinking. J Nebr Dent Assoc.
99 Lindgren L. (1981). E.C.G changes during halothane and enflurane anaesthesia for E.N.T. surgery in children. Br J Anaesth.
100 Lindgren L. (1981). Comparison of halothane and enflurane anaesthesia for otolaryngological surgery in children. Br J Anaesth.
101 Ludman H. (1981). ABC of ENT. Throat infections. Br Med J (Clin Res Ed).
102 Maw AR, Jeans WD, Fernando DC. (1981). Inter-observer variability in the clinical and radiological assessment of adenoid size, and the correlation with adenoid volume. Clin Otolaryngol Allied Sci.
103 McMurray DN, Loomis SA, Casazza LJ, et al. (1981). Development of impaired cell-mediated immunity in mild and moderate malnutrition. Am J Clin Nutr.
104 Meistrup-Larsen KI, Andersen MS, Helweg J, et al. (1981). Variations in tympanograms in children attending group-care during a one-year period. ORL J Otorhinolaryngol Relat Spec.
105 Misra UC, Gill RS, Lal M. (1981). Tonsil transposition into posterior pharyngeal wall in palato-pharyngeal incompetence. J Laryngol Otol.
106 Moore FD, Pratt LW. (1981). Tonsillectomy in Maine: regulation versus education as modulators of medical care. Ann Surg.
107 Naunton RF. (1981). Tympanostomy tubes: the conservative approach. Ann Otol Rhinol Laryngol.
108 Nielsen VM, Greisen O. (1981). Peritonsillar abscess. II. Cases treated with tonsillectomy a chaud. J Laryngol Otol.
109 Nielsen VM, Greisen O. (1981). Peritonsillar abscess. I. Cases treated by incision and drainage: a follow-up investigation. J Laryngol Otol.
110 Orr WC, Martin RJ. (1981). Obstructive sleep apnea associated with tonsillar hypertrophy in adults. Arch Intern Med.
111 Paradise JL. (1981). Tonsillectomy and adenoidectomy. Pediatr Clin North Am.
112 Paul D. (1981). Sinus infection and adenotonsillitis in pediatric patients. Laryngoscope.
113 Pillsbury HC, Kveton JF, Sasaki CT, et al. (1981). Quantitative bacteriology in adenoid tissue. Otolaryngol Head Neck Surg.
114 Plotkin RP. (1981). Middle ear ventilation with the Castelli membrane tube. Laryngoscope.
115 Pratt LW. (1981). Nasopharyngeal irradiation treatment of hyperplastic adenoids. Otolaryngol Head Neck Surg.
116 Qvarnberg Y. (1981). Acute otitis media. A prospective clinical study of myringotomy and antimicrobial treatment. Acta Otolaryngol Suppl.
117 Reilly S, Timmis P, Beeden AG, et al. (1981). Possible role of the anaerobe in tonsillitis. J Clin Pathol.
118 Revonta M, Suonpaa J. (1981). Diagnosis of subacute maxillary sinusitis in children. J Laryngol Otol.
119 Richardson KA, Birck H. (1981). Peritonsillar abscess in the pediatric population. Otolaryngol Head Neck Surg.
120 Roydhouse N. (1981). Bromhexine for otitis media with effusion. N Z Med J.
121 Scanlon EF, Sener SF. (1981). Head and neck neoplasia following irradiation for benign conditions. Head Neck Surg.
122 Schmidtmayer EK, Meyer F. (1981). UBER DIE ANWENDUNG VON TANTUM(Reg.trademark) VERDE, EINER GURGELLOSUNG AUF BENZYDAMINBASIS, NACH TONSILLEKTOMIE. Die Therapiewoche.
123 Shwartz M, Martin SG, Cooper DD, et al. (1981). The effect of a thirty per cent reduction in physician fees on Medicaid surgery rates in Massachusetts. Am J Public Health.
124 Sundberg L, Eden T, Ernstson S, et al. (1981). Tissue penetration of erythromycin in Waldeyer's ring and bacteriology of secretory otitis media. Acta Otolaryngol Suppl.
125 Talmon Y, Podoshin L, Fradis M. (1981). The surgical treatment of drooling in healthy children. Int J Pediatr Otorhinolaryngol.
126 Valman HB. (1981). ABC of 1 to 7. Tonsillitis and otitis media. Br Med J (Clin Res Ed).
127 Walker AR, Walker BF, Duvenhage A, et al. (1981). Tonsillectomy prevalences in South African schoolchildren. Trop Geogr Med.
128 Williams B. (1981). Chronic herniation of the hindbrain. Ann R Coll Surg Engl.
129 Yamauchi S, Ikeda M, Ikeda M, et al. (1981). Immunological Considerations in patients with tonsillar lesions. Tokai J Exp Clin Med.
130 (1982). T's and A's in question. Drug Ther Bull.
131 Agrawal SR, Raghuwanshi RHS, Kathuria SK, et al. (1982). A clinical study of styplon in prevention of excessive bleeding in tonsillectomy. Indian medical journal.
132 Amendoeira MR, Coutinho SG. (1982). Isolation of Toxoplasma gondii from the saliva and tonsils of a three-year-old child. J Infect Dis.
133 Benjamin BN. (1982). Guidelines on tonsillectomy and adenoidectomy in children. Australas Nurses J.
134 Bottone E, Baldini G, Macchia P, et al. (1982). Evaluation of the clinical efficacy of erythromycin, amoxicillin and co-trimoxazole in the treatment of acute respiratory tract infections in paediatric patients. Curr Med Res Opin.
135 Brouillette RT, Fernbach SK, Hunt CE. (1982). Obstructive sleep apnea in infants and children. J Pediatr.
136 Coker NJ, Milner PF. (1982). Elective surgery in patients with sickle cell anemia. Arch Otolaryngol.
137 Crepeau J, Patriquin HB, Poliquin JF, et al. (1982). Radiographic evaluation of the symptom-producing adenoid. Otolaryngol Head Neck Surg.
138 Crocker J. (1982). The T lymphocyte content of the efferent lymphatics of the human palatine tonsil. Clin Otolaryngol Allied Sci.
139 D'Amelio R, Palmisano L, Le Moli S, et al. (1982). Serum and salivary IgA levels in normal subjects: comparison between tonsillectomized and non-tonsillectomized subjects. Int Arch Allergy Appl Immunol.
140 Feldman BA, Schwartz RH, Chandra R, et al. (1982). Heterotopic brain tissue simulating a neonatal tonsil. Clin Pediatr (Phila).
141 Freeman JL, Jekel JF, Freeman DH. (1982). Changes in age and sex specific tonsillectomy rates: United States, 1970-1977. Am J Public Health.
142 Goycoolea MV, Cubillos PM, Martinez GC. (1982). Tonsillectomy with a suction coagulator. Laryngoscope.
143 Grahne B, Tarkkanen A. (1982). Inferior dacryocystorhinostomy in severe congenital dacryostenosis. Int J Pediatr Otorhinolaryngol.
144 Guilleminault C, Winkle R, Korobkin R, et al. (1982). Children and nocturnal snoring: evaluation of the effects of sleep related respiratory resistive load and daytime functioning. Eur J Pediatr.
145 Gupta R, Gupta AS, Duggal N. (1982). Tubercular mastitis. Int Surg.
146 Harris JP, South MA. (1982). Immunodeficiency diseases: head and neck manifestations. Head Neck Surg.
147 Heffner DK, Hyams VJ, Hauck KW, et al. (1982). Low-grade adenocarcinoma of the nasal cavity and paranasal sinuses. Cancer.
148 Helin I, Andreasson L, Jannert M, et al. (1982). Acute sinusitis in children - results of different therapeutic regimens. Helv Paediatr Acta.
149 Hibbert J, Stell PM. (1982). The role of enlarged adenoids in the aetiology of serous otitis media. Clin Otolaryngol Allied Sci.
150 Holt GR. (1982). The management of peritonsillar abscesses in military medicine. Mil Med.
151 Hunt CE, Brouillette RT. (1982). Abnormalities of breathing control and airway maintenance in infants and children as a cause of cor pulmonale. Pediatr Cardiol.
152 Iida K, Mornaghi R, Nussenzweig V. (1982). Complement receptor (CR1) deficiency in erythrocytes from patients with systemic lupus erythematosus. J Exp Med.
153 Kveton JF, Pillsbury HC, Sasaki CT. (1982). Nasal obstruction. Adenoiditis vs adenoid hypertrophy. Arch Otolaryngol.
154 LaPenna R, Folger GM. (1982). Extreme upper airway obstruction with the Marshall syndrome. Clin Pediatr (Phila).
155 Levine PA, Goode RL. (1982). The lateral port control pharyngeal flap: a versatile approach to velopharyngeal insufficiency. Otolaryngol Head Neck Surg.
156 Lundberg C, Lonnroth J, Nord CE. (1982). Identification of attached bacteria in the nasopharynx of the child. Infection.
157 MacKay IS, Ananian V. (1982). Analgesia following adult tonsillectomy: a comparative study of solpadeine and a soluble form of dextropropoxyphene napsylate and paracetamol. Journal of international medical research.
158 Malik MK, Bhatia BP, Kumar A. (1982). Control of haemorrhage in tonsillectomy. J Indian Med Assoc.
159 Martin SG, Shwartz M, Whalen BJ, et al. (1982). Impact of a mandatory second-opinion program on medicaid surgery rates. Medical care.
160 Mattucci KF. (1982). Tonsillectomy and adenoidectomy: a reappraisal. Int Surg.
161 Mindell WR, Vayda E, Cardillo B. (1982). Ten-year trends in Canada for selected operations. Can Med Assoc J.
162 Morris HL, Krueger LJ, Bumsted RM. (1982). Indications of congenital palatal incompetence before diagnosis. Ann Otol Rhinol Laryngol.
163 Nakayama K. (1982). Analgesic effect of voltaren suppository following tonsillectomy in children. Practica Otologica.
164 Newman RK, Byers RM. (1982). Squamous carcinoma of the larynx in patients under the age of 35 years. Otolaryngol Head Neck Surg.
165 Olmedo G, Rosenberg M, Fonseca R. (1982). Primary tumors of the trachea. Clinicopathologic features and surgical results. Chest.
166 O'Ryan FS, Gallagher DM, LaBanc JP, et al. (1982). The relation between nasorespiratory function and dentofacial morphology: a review. Am J Orthod.
167 Pekkarinen H, Karja J. (1982). Results of long-term ECG monitoring in patients submitting to tonsillectomy under local anaesthesia. J Laryngol Otol.
168 Peterson L, Shigetomi C. (1982). One-year follow-up of elective surgery child patients receiving preoperative preparation. J Pediatr Psychol.
169 Raghuram TC, Krishnaswamy K, Rao KV. (1982). Influence of dietary restriction and protein deficiency on plasma half-life and tissue distribution of tetracycline in rats. Clin Exp Pharmacol Physiol.
170 Revonta M, Suonpaa J. (1982). Diagnosis and follow-up of ultrasonographical sinus changes in children. Int J Pediatr Otorhinolaryngol.
171 Sandler DP, Comstock GW, Matanoski GM. (1982). Neoplasms following childhood radium irradiation of the nasopharynx. J Natl Cancer Inst.
172 Schechter GL, Sly DE, Roper AL, et al. (1982). Changing face of treatment of peritonsillar abscess. Laryngoscope.
173 Schwartz RH. (1982). Prevention of otitis media: a multitude of yellow brick roads. Pediatr Infect Dis.
174 Shapiro RS. (1982). Partial adenoidectomy. Laryngoscope.
175 Shmookler BM, Enzinger FM, Brannon RB. (1982). Orofacial synovial sarcoma: a clinicopathologic study of 11 new cases and review of the literature. Cancer.
176 Sigurdsson G, Lindahl S, Norden N. (1982). Influence of premedication on plasma ACTH and cortisol concentrations in children during adenoidectomy. Br J Anaesth.
177 Silingardi V, Venezia L, Tampieri A, et al. (1982). Tonsillectomy, appendectomy and malignant lymphomas. Scand J Haematol.
178 Sorensen CH, Holm-Jensen S. (1982). Middle ear effusion and risk factors. J Otolaryngol.
179 Sugita R, Kawamura S, Icikawa G, et al. (1982). Microorganisms isolated from peritonsillar abscess and indicated chemotherapy. Arch Otolaryngol.
180 Sundberg L, Eden T, Ernstson S. (1982). The penetration of erythromycin into Waldeyer's ring--tonsil and adenoid tissue. Infection.
181 Tuner K, Nord CE. (1982). beta-Lactamase-producing anaerobic bacteria in recurrent tonsillitis. J Antimicrob Chemother.
182 Valentin N, Lomholt B, Thorup M. (1982). Halothane anaesthesia with spontaneous respiration for tonsillectomy in children. Acta Anaesthesiol Scand.
183 Valentin N, Lomholt B, Thorup M. (1982). Arterial to end-tidal carbon dioxide tension difference in children under halothane anaesthesia. Can Anaesth Soc J.
184 van de Donk HJ, Zuidema J, Merkus FW. (1982). Correlation between the sensitivity of the ciliary beat frequency of human adenoid tissue and chicken embryo tracheas for some drugs. Rhinology.
185 Vayda E, Mindell WR, Mueller CB, et al. (1982). Measuring surgical decision-making with hypothetical cases. Can Med Assoc J.
186 Verbi W, Greaves MF, Schneider C, et al. (1982). Monoclonal antibodies OKT 11 and OKT 11A have pan-T reactivity and block sheep erythrocyte “receptors”. Eur J Immunol.
187 Woosley RE, Whaley RA. (1982). Use of metrizamide in computerized tomography to diagnose the Chiari I malformation. J Neurosurg.
188 Yamaguchi T, Somekawa Y, Ara H, et al. (1982). Indications for the use of ventilating tubes for secretory otitis media. Int J Pediatr Otorhinolaryngol.
189 (1983). A proposed national tonsillectomy audit? Report from the Criteria Committee on Tonsillectomy Audit. Aust Clin Rev.
190 Basjrah R, Lubis HR, Tann G. (1983). A beta-blocker as anxiolytic and haemostatic in tonsillectomy. J Int Med Res.
191 Bluestone CD. (1983). Eustachian tube function: physiology, pathophysiology, and role of allergy in pathogenesis of otitis media. J Allergy Clin Immunol.
192 Bluestone CD. (1983). Management of chronic otitis media with effusion. Acta Otorhinolaryngol Belg.
193 Blum DJ, Neel IHB. (1983). Current thinking on tonsillectomy and adenoidectomy. Comprehensive Therapy.
194 Brook I, Yokum P. (1983). In vitro protection of group A beta-hemolytic streptococci from penicillin and cephalothin by Bacteroides fragilis. Chemotherapy.
195 Carrick DG. (1983). Salicylates and post-tonsillectomy haemorrhage. Oto-Rhino-Laryngological Research Society (ORS) - Abstracts of the meeting held at the Royal Infirmary Glasgow on 15 April 1983. Clinical Otolaryngology and Allied Sciences.
196 Chen PM, Kwan SH, Hwang TS, et al. (1983). Insulin receptors on leukemia and lymphoma cells. Blood.
197 Christensen PH, Schonsted-Madsen U. (1983). Unilateral immediate tonsillectomy as the treatment of peritonsillar abscess: results, with special attention to pharyngitis. J Laryngol Otol.
198 Collins MP, Church MK. (1983). The effect of an anti-allergic, nasal decongestant combination (‘Dimotapp’) and sodium cromoglycate nose drops on the histamine content of adenoids, middle ear fluid and nasopharyngeal secretions of children with secretory otitis media. Curr Med Res Opin.
199 D'Apuzzo V, Zambelli D. (1983). Clinical experience with fentiazac suspension in inflammatory process of childhood. Current Therapeutic Research - Clinical and Experimental.
200 Eden T, Anari M, Ernstson S, et al. (1983). Penetration of cefaclor to adenoid tissue and middle ear fluid in secretory otitis media. Scand J Infect Dis Suppl.
201 Evans RG, Robinson GC. (1983). An economic study of cost savings on a care-by-parent ward. Med Care.
202 Fernbach SK, Brouillette RT, Riggs TW, et al. (1983). Radiologic evaluation of adenoids and tonsils in children with obstructive sleep apnea: plain films and fluoroscopy. Pediatr Radiol.
203 Frank Y, Kravath RE, Pollak CP, et al. (1983). Obstructive sleep apnea and its therapy: clinical and polysomnographic manifestations. Pediatrics.
204 Franks ML. (1983). A child's miracle. Todays OR Nurse.
205 Gefke K, Andersen LW, Friesel E. (1983). Lidocaine given intravenously as a suppressant of cough and laryngospasm in connection with extubation after tonsillectomy. Acta Anaesthesiol Scand.
206 Ghorbanian SN, Paradise JL, Doty RL. (1983). Odor perception in children in relation to nasal obstruction. Pediatrics.
207 Gray LP. (1983). Unilateral tonsillectomy--indications and results. J Laryngol Otol.
208 Gray LP. (1983). The relationship of the ‘inferior constrictor swallow’ and ‘globus hystericus’ or the hypopharyngeal syndrome. J Laryngol Otol.
209 Greco B, Bielory L, Stephany D, et al. (1983). Antithymocyte globulin reacts with many normal human cell types. Blood.
210 Gullane PJ, Conley J. (1983). Carcinoma of the maxillary sinus. A correlation of the clinical course with orbital involvement, pterygoid erosion or pterygopalatine invasion and cervical metastases. J Otolaryngol.
211 Habeshaw JA, Bailey D, Stansfeld AG, et al. (1983). The cellular content of non Hodgkin lymphomas: a comprehensive analysis using monoclonal antibodies and other surface marker techniques. Br J Cancer.
212 Hirschberg J. (1983). Pediatric otolaryngological relations of velopharyngeal insufficiency. Int J Pediatr Otorhinolaryngol.
213 Holm SE, Grahn E. (1983). Bacterial interference in streptococcal tonsillitis. Scand J Infect Dis Suppl.
214 Kuruvilla A. (1983). Cancer of the tonsil--a review. J Laryngol Otol.
215 Larson DL, Lindberg RD, Lane E, et al. (1983). Major complications of radiotherapy in cancer of the oral cavity and oropharynx. A 10 year retrospective study. Am J Surg.
216 Lildholdt T. (1983). Ventilation tubes in secretory otitis media. A randomized, controlled study of the course, the complications, and the sequelae of ventilation tubes. Acta Otolaryngol Suppl.
217 Lima JA, Autin JL. (1983). Immediate unilateral tonsillectomy for severe peritonsillar infections in children. Int J Pediatr Otorhinolaryngol.
218 Mauer KW, Staats BA, Olsen KD. (1983). Upper airway obstruction and disordered nocturnal breathing in children. Mayo Clin Proc.
219 Maw AR. (1983). Chronic otitis media with effusion and adeno-tonsillectomy--a prospective randomized controlled study. Int J Pediatr Otorhinolaryngol.
220 Maw AR. (1983). Chronic otitis media with effusion (glue ear) and adenotonsillectomy: prospective randomised controlled study. Br Med J (Clin Res Ed).
221 Maw AR, Jeans WD, Cable HR. (1983). Adenoidectomy. A prospective study to show clinical and radiological changes two years after operation. J Laryngol Otol.
222 McCormick MS. (1983). The sleep apnoea syndrome in children--the role of tonsillectomy and adenoidectomy. S Afr Med J.
223 Mills RP, Hibbert J. (1983). The effects of recurrent tonsillitis on growth and cervical lymphadenopathy in children. Int J Pediatr Otorhinolaryngol.
224 Ogunyemi O. (1983). Clinical trial of bacampicillin in acute bacterial infections. Clin Ther.
225 Ohta K, Manzara T, Harbeck RJ, et al. (1983). Human tonsillar IgE biosynthesis in vitro. I. Enhancement of IgE and IgG synthesis in the presence of pokeweed mitogen by T-cell irradiation. J Allergy Clin Immunol.
226 Okafor BC. (1983). Tonsillectomy: an appraisal of indications in developing countries. Acta Otolaryngol.
227 Ono T, Jono M, Kito M, et al. (1983). Evaluation of tonsillectomy as a treatment for pustulosis palmaris et plantaris. Acta Otolaryngol Suppl.
228 Ostergaard PA. (1983). Oral bacterial flora and secretory IgA in small children after repeated courses of antibiotics. Scand J Infect Dis.
229 Patel SB, Eastmond CJ. (1983). Preceding tonsillectomy and appendicectomy in rheumatoid and degenerative arthritis. J Rheumatol.
230 Prusek W, Agopsowicz T, Podwysocka M. (1983). T and B lymphocytes in peripheral blood and tonsils of children after tonsillectomy. Arch Immunol Ther Exp (Warsz).
231 Razon Veronesi S. (1983). Antipolysaccharide group-specific antibodies of Streptococcus pyogenes in children. Boll Ist Sieroter Milan.
232 Reissland N. (1983). Cognitive maturity and the experience of fear and pain in hospital. Soc Sci Med.
233 Resta L, Ricco R, Santangelo A. (1983). Morphologic and classificatory considerations about 140 cases of carcinoma of the nasopharynx. Tumori.
234 Rosen C, Christensen P, Hovelius B, et al. (1983). Effect of pneumococcal vaccination on upper respiratory tract infections in children. Design of a follow-up study. Scand J Infect Dis Suppl.
235 Schreier A, Kaplan D. (1983). The effectiveness of a preoperation preparation program in reducing anxiety in children. Child Health Care.
236 Schuurman HJ, Brekelmans P, Daemen T, et al. (1983). T-cell maturation in the human thymus and tonsil: peanut agglutinin binding T lymphocytes in thymus and tonsil differ in maturation stage. Clin Immunol Immunopathol.
237 Sederberg-Olsen JF, Sederberg-Olsen AE, Jensen AM. (1983). The prognostic significance of the air volume in the middle ear for the tendency to recurrence of secretory middle ear condition. Int J Pediatr Otorhinolaryngol.
238 Segal C, Berger G, Basker M, et al. (1983). Adenotonsillectomies on a surgical day-clinic basis. Laryngoscope.
239 Shore-Freedman E, Abrahams C, Recant W, et al. (1983). Neurilemomas and salivary gland tumors of the head and neck following childhood irradiation. Cancer.
240 Siegel G. (1983). Theoretical and clinical aspects of the tonsillar function. Int J Pediatr Otorhinolaryngol.
241 Sigurdsson GH, Carlsson C, Lindahl S, et al. (1983). Cardiac arrhythmias in non-intubated children during adenoidectomy. A comparison between enflurane and halothane anaesthesia. Acta Anaesthesiol Scand.
242 Sigurdsson GH, Lindahl S. (1983). Cardiac arrhythmias in intubated children during adenoidectomy. A comparison between enflurane and halothane anaesthesia. Acta Anaesthesiol Scand.
243 Sigurdsson GH, Lindahl S, Norden N. (1983). Influence of premedication on the sympathetic and endocrine responses and cardiac arrhythmias during halothane anaesthesia in children undergoing adenoidectomy. Br J Anaesth.
244 Sigurdsson GH, Werner O, Fahraeus T. (1983). Ventricular arrhythmia or supraventricular arrhythmia with aberrant conduction? An electrocardiographic study in halothane-anaesthetized children undergoing adenoidectomy. Br J Anaesth.
245 Stearns M. (1983). The relationship of adenoid weight to tonsillar weight. J Laryngol Otol.
246 Suarez Nieto C, Malluguiza Calvo R, Barthe Garcia P. (1983). Aetiological factors in chronic secretory otitis in relation to age. Clin Otolaryngol Allied Sci.
247 Talaat AM, Nahhas MM. (1983). Cardiopulmonary changes secondary to chronic adenotonsillitis. Arch Otolaryngol.
248 Tos M, Bonding P, Poulsen G. (1983). Tympanosclerosis of the drum in secretory otitis after insertion of grommets. A prospective, comparative study. J Laryngol Otol.
249 Tuner K, Nord CE. (1983). The role of beta-lactamase-producing Bacteroides in recurrent tonsillitis. Acta Otolaryngol.
250 Tuner K, Nord CE. (1983). Betalactamase-producing microorganisms in recurrent tonsillitis. Scand J Infect Dis Suppl.
251 Weligodapola GS. (1983). Comparative study of tonsillectomy performed by guillotine and dissection methods. J Laryngol Otol.
252 Wolfe F, Young DY. (1983). Rheumatoid arthritis and antecedent tonsillectomy. J Rheumatol.
253 Xu LT, Sun ZF, Li ZJ, et al. (1983). Tracheobronchial tumors: an eighteen-year series from Capital Hospital, Peking, China. Ann Thorac Surg.
254 Yamanaka N, Sambe S, Kataura A. (1983). Conceptual understanding of pustulosis palmaris et plantaris as an immune complex disease due to focal tonsillar infections. Acta Otolaryngol Suppl.
255 Yamanaka T, Cumella J, Parker C, et al. (1983). Immunologic aspects of otitis media with effusion. II. Nature of cell-mediated immunosuppressive activity in middle ear fluid. J Infect Dis.
256 Barton JH, Osborne BM, Butler JJ, et al. (1984). Non-Hodgkin's lymphoma of the tonsil. A clinicopathologic study of 65 cases. Cancer.
257 Black N. (1984). Surgery for glue ear--a modern epidemic. Lancet.
258 Blijdorp P, Muller H. (1984). The influence of the age at which the palate is closed on speech in the adult cleft patient. J Maxillofac Surg.
259 Bogger-Goren S, Bernstein JM, Gershon AA, et al. (1984). Mucosal cell-mediated immunity to varicella zoster virus: role in protection against disease. J Pediatr.
260 Brook I. (1984). The presence of beta-lactamase-producing bacteria as a guideline in the management of children with recurrent tonsillitis. Am J Otolaryngol.
261 Brook I, Gober AE. (1984). Rapid method for detecting beta-lactamase producing bacteria in clinical specimens. J Clin Pathol.
262 Brouilette R, Hanson D, David R, et al. (1984). A diagnostic approach to suspected obstructive sleep apnea in children. J Pediatr.
263 Brzezinska H, Brozik H, Mikucki J, et al. (1984). Concentrations of cloxacillin and erythromycin in the tonsils of children after administration of therapeutic doses. Int J Pediatr Otorhinolaryngol.
264 Bulman CH, Brook SJ, Berry MG. (1984). A prospective randomized trial of adenoidectomy vs grommet insertion in the treatment of glue ear. Clin Otolaryngol Allied Sci.
265 Canter RJ, Rogers J. (1984). Post tonsillectomy haemorrhage in children: The value of routine monitoring of the pulse. J Laryngol Otol.
266 Currimbhoy Z. (1984). Transitory anticoagulants in healthy children. Am J Pediatr Hematol Oncol.
267 Daele JJ. (1984). Sinusitis in the child. Acta Otorhinolaryngol Belg.
268 D'Amelio R, Fattorossi A, Berti R, et al. (1984). Serum IgG, IgA, IgM, IgE, salivary IgA levels and lung function in a healthy male population from the Italian Air Force: a preliminary study. Ann Allergy.
269 Deggouj N, Remacle M, Bertrand B, et al. (1984). Study of lymphoid tissue in paediatric ENT practice. Acta Otorhinolaryngol Belg.
270 Demarest DS, Hooke JF, Erickson MT. (1984). Preoperative intervention for the reduction of anxiety in pediatric surgery patients. Child Health Care.
271 Dillon WP, Mills CM, Kjos B, et al. (1984). Magnetic resonance imaging of the nasopharynx. Radiology.
272 Dommerby H, Rasmussen OR. (1984). Diclofenac (Voltaren). Pain-relieving effect after tonsillectomy. Acta Otolaryngol.
273 Dommerby H, Rasmussen OR. (1984). Diclofenac (Voltaren(Reg.trademark)). Pain-relieving effect after tonsillectomy. Acta Oto-Laryngol.
274 Eiser C. (1984). Communicating with sick and hospitalised children. J Child Psychol Psychiatry.
275 Ellsbury KE. (1984). Therapeutic alternatives and clinical outcomes in peritonsillitis. J Fam Pract.
276 Ermens F, Van Geert G, Kahn A, et al. (1984). Obstructive sleep apnea syndrome in childhood. Acta Otorhinolaryngol Belg.
277 Ernstson S, Sundberg L. (1984). Erythromycin in the treatment of otitis media with effusion (OME). J Laryngol Otol.
278 Fairbanks DN. (1984). Snoring: surgical vs. nonsurgical management. Laryngoscope.
279 Fan LL. (1984). Transnasal fiberoptic endoscopy in children with obstructive apnea. Crit Care Med.
280 Fujitani T, Takahara T, Hattori H, et al. (1984). Radiochemotherapy for non-Hodgkin's lymphoma in palatine tonsil. Cancer.
281 Gross WL, Schlaak M. (1984). Modulation of human lymphocyte functions by group A streptococci. Clin Immunol Immunopathol.
282 Irwin BC, Acharya KB. (1984). A comparative study of benzydamine hydrochloride 0.15% w/v (‘Difflam’ Oral Rinse) and acetyl salicylic acid as analgesics following tonsillectomy. Journal of international medical research.
283 Johnsen T, Katholm M, Stangerup SE. (1984). Otolaryngological complications in infectious mononucleosis. J Laryngol Otol.
284 Juntunen K, Tarkkanen J, Makinen J. (1984). Caldwell-Luc operation in the treatment of childhood bronchial asthma. Laryngoscope.
285 Karchev T, Kabakchiev P. (1984). M-cells in the epithelium of the nasopharyngeal tonsil. Rhinology.
286 Kristiansen BE, Elverland H. (1984). Increased meningococcal carrier rate after tonsillectomy. Br Med J (Clin Res Ed).
287 Kuftinec MM, Parson CE, Delivanis HP, et al. (1984). Investigation of a circannual rhythm in nasopharyngeal airway patency in children. Chronobiologia.
288 Kumar R. (1984). Secondary haemorrhage following tonsillectomy/adenoidectomy. J Laryngol Otol.
289 Lal H, Sachdeva OP, Mehta HR. (1984). Serum immunoglobulins in patients with chronic tonsillitis. J Laryngol Otol.
290 Lundberg C. (1984). Bacterial infections of the upper respiratory airways and beta-lactam antibiotics. Scand J Infect Dis Suppl.
291 Mann DG, George C, Scheiner E, et al. (1984). Tonsillectomy--some like it hot. Laryngoscope.
292 Maw AR. (1984). Otitis media with effusion (glue ear). A prospective randomized study 1 year following adenoidectomy and tonsillectomy. Oto-Rhino-Laryngological Research Society (ORS) - Abstracts of the meeting held at The Royal National Institute of Laryngology and Oncology on 7 October 1983. Clinical Otolaryngology and Allied Sciences.
293 Mellis CM. (1984). Tonsillectomy. A controlled prospective trial. Medical journal of Australia.
294 Nouri ME. (1984). Nimesulide for treatment of acute inflammation of the upper respiratory tract. Clin Ther.
295 Ogawa H, Yamazaki Y, Takada A, et al. (1984). N-Acetyl-L-tyrosine ethyl ester (ATEe) hydrolytic activities of diseased human palatine tonsils. Possible pathogenesis of recurrent acute tonsillitis. Acta Otolaryngol Suppl.
296 Praud JP, Gaultier C, Buvry A, et al. (1984). Lung mechanics and breathing pattern during wakefulness and sleep in children with enlarged tonsils. Sleep.
297 Reader WJ, Doehring RO. (1984). Tonsillitis in the paediatric outpatient. S Afr Med J.
298 Roth Y, Ostfeld E. (1984). Ciliary beat frequency of human middle-ear mucosa measured in vitro. J Laryngol Otol.
299 Ruch CR, Beckwith DG. (1984). Pharyngitis-tonsillitis in a college population. J Am Coll Health.
300 Ruuskanen O, Sarkkinen H, Meurman O, et al. (1984). Rapid diagnosis of adenoviral tonsillitis: a prospective clinical study. J Pediatr.
301 Saarnivaara L. (1984). Comparison of paracetamol and pentazocine suppositories for pain relief after tonsillectomy in adults. Acta anaesthesiologica Scandinavica.
302 Sengupta DK, Zakzouk SM, Sayed YAH. (1984). Ligation versus electrocoagulation - a comparative study of haemostatic methods used in tonsillectomy. Saudi medical journal.
303 Sidell N, Famatiga E, Golub SH. (1984). Immunological aspects of retinoids in humans. II. Retinoic acid enhances induction of hemolytic plaque-forming cells. Cell Immunol.
304 Siegel G. (1984). The influence of tonsillectomy on cell-mediated immune response. Arch Otorhinolaryngol.
305 Sigurdsson GH, Lindahl SG, Norden NE. (1984). Catecholamine and endocrine response in children during halothane and enflurane anaesthesia for adenoidectomy. Acta Anaesthesiol Scand.
306 Soekrawinata T, Ibrahim T, Driyatno E. (1984). Spiramycin and erythromycin in the treatment of acute tonsillo-pharyngitis: a comparative study. Curr Med Res Opin.
307 Sundberg L. (1984). Antibiotic treatment of secretory otitis media. Acta Otolaryngol Suppl.
308 Suprihati, Noersinggih, Hoedijono R. (1984). Treatment of acute tonsillo-pharyngitis: a comparative study of spiramycin and erythromycin. Curr Med Res Opin.
309 Tax WJ, Tidman N, Janossy G, et al. (1984). Monoclonal antibody (WT 1) directed against a T cell surface glycoprotein: characteristics and immunosuppressive activity. Clin Exp Immunol.
310 To SS, Pahor AL, Robin PE. (1984). A prospective trial of unilateral grommets for bilateral secretory otitis media in children. Clin Otolaryngol Allied Sci.
311 Tombs A. (1984). Tonsils - in or out?. Nurs Mirror.
312 Twiggs JT, O'Connell EJ, Yunginger JW, et al. (1984). The development of asthma after tracheobronchial aspiration of a foreign body. Ann Allergy.
313 Vinther B, Brahe Pedersen C, Elbrond O. (1984). Otitis media in childhood. Sociomedical aspects with special reference to day-care conditions. Clin Otolaryngol Allied Sci.
314 Warford A, McLachlan SM, Malcolm AJ, et al. (1984). Characterization of lymphoid cells in the thyroid of patients with Graves' disease. Clin Exp Immunol.
315 Wind J. (1984). Tympanic effusions. A retrospective and prospective investigation into their aetiology and treatment. Acta Otorhinolaryngol Belg.
316 Zulkifli, Fachri H, Efiaty S, et al. (1984). A comparative study of spiramycin and erythromycin in acute tonsillo-pharyngitis. Curr Med Res Opin.
317 (1985). Regional variations in costs of tonsillectomy and adenoidectomy. Stat Bull Metrop Insur Co.
318 Anari M, Cederberg A, Ernstson S. (1985). The effect of cefaclor on the nasopharyngeal flora in children with chronic OME. Acta Otolaryngol Suppl.
319 Andersson J, Skoldenberg B, Ernberg I, et al. (1985). Acyclovir treatment in primary Epstein-Barr virus infection. A double-blind placebo-controlled study. Scand J Infect Dis Suppl.
320 Baker SR, Malone B. (1985). Salivary gland malignancies in children. Cancer.
321 Basrjah R, Ibrahim M, Tann G, et al. (1985). Role of beta-blockers as haemostatic in tonsillectomy. Oto Rhino Laryngologica Indonesiana.
322 Black N. (1985). Geographical variations in use of surgery for glue ear. J R Soc Med.
323 Black N. (1985). Glue ear: the new dyslexia?. Br Med J (Clin Res Ed).
324 Bonding P, Tos M. (1985). Grommets versus paracentesis in secretory otitis media. A prospective, controlled study. Am J Otol.
325 Bosley TM, Cohen DA, Schatz NJ, et al. (1985). Comparison of metrizamide computed tomography and magnetic resonance imaging in the evaluation of lesions at the cervicomedullary junction. Neurology.
326 Brook I. (1985). Role of beta-lactamase-producing bacteria in the failure of penicillin to eradicate group A streptococci. Pediatr Infect Dis.
327 Brook I, Hirokawa R. (1985). Treatment of patients with a history of recurrent tonsillitis due to group A beta-hemolytic streptococci. A prospective randomized study comparing penicillin, erythromycin, and clindamycin. Clin Pediatr (Phila).
328 Butt W, Robertson C, Phelan P. (1985). Snoring in children: is it pathological?. Med J Aust.
329 Canter RJ, Rogers J. (1985). Tonsillectomy: home after 24 hours?. J Laryngol Otol.
330 Christensen P, Hovelius B, Prellner K, et al. (1985). Effects of pneumococcal vaccination on tonsillo-pharyngitis and upper respiratory tract flora. Int Arch Allergy Appl Immunol.
331 Cohen D, Konak S. (1985). The evaluation of radiographs of the nasopharynx. Clin Otolaryngol Allied Sci.
332 Collins MP, Church MK, Bakhshi KN, et al. (1985). Adenoid histamine and its possible relationship to secretory otitis media. J Laryngol Otol.
333 Conti P, Allegretta M, Williams TW, et al. (1985). Enhanced thromboxane synthesis and vacuolization in human polymorphonuclear leucocytes induced by human lymphokine containing supernatants. Clin Rheumatol.
334 Coulter A, McPherson K. (1985). Socioeconomic variations in the use of common surgical operations. Br Med J (Clin Res Ed).
335 Crysdale WS, Cole P, Emery P. (1985). Cephalometric radiographs, nasal airway resistance, and the effect of adenoidectomy. J Otolaryngol.
336 Dalton RE, Abedi E, Sismanis A. (1985). Bilateral peritonsillar abscesses and quinsy tonsillectomy. J Natl Med Assoc.
337 Dosch HM, White D, Grant C. (1985). Reconstitution of nude mouse T cell function in vivo: IL 2-independent effect of human T cells. J Immunol.
338 Ernstson S, Anari M, Eden T, et al. (1985). Penetration of cefaclor to adenoid tissue and middle ear effusion in chronic OME. Acta Otolaryngol Suppl.
339 Falchi M, Teodori F, Carraro A, et al. (1985). Penetration of erythromycin into tonsillar tissue. Curr Med Res Opin.
340 Farnsworth S. (1985). Clinical revision series. 15. Susan's sore throat. Nurs Mirror.
341 Fell D, Gough MB, Northan AA, et al. (1985). Diazepam premedication in children. Plasma levels and clinical effects. Anaesthesia.
342 Fergusson DM, Horwood LJ. (1985). Private medical insurance and elective surgery during early childhood. N Z Med J.
343 Fielder CP. (1985). The effect of adenoidectomy on nasal resistance to airflow. Acta Otolaryngol.
344 Fujikawa S, Ito Y, Ohkuni M. (1985). A new scoring system for diagnosis of streptopharyngitis. Jpn Circ J.
345 Gates GA, Wachtendorf C, Hearne EM, et al. (1985). Treatment of chronic otitis media with effusion: results of tympanostomy tubes. Am J Otolaryngol.
346 Ghilardi PL, Casani A. (1985). Treatment of ear, nose and throat infections with clofoctol. Drugs Exp Clin Res.
347 Gold EB, Gordis L, Diener MD, et al. (1985). Diet and other risk factors for cancer of the pancreas. Cancer.
348 Gomperts ED, Feorino P, Evatt BL, et al. (1985). LAV/HTLV III presence in peripheral blood lymphocytes of seropositive young hemophiliacs. Blood.
349 Grabowski N, May JJ, Pratt DS, et al. (1985). The effect of split virus influenza vaccination on theophylline pharmacokinetics. Am Rev Respir Dis.
350 Gupta AD, Samoszuk MK, Papayannopoulou T, et al. (1985). SFL 23.6: a monoclonal antibody reactive with CFU-E, erythroblasts, and erythrocytes. Blood.
351 Handler SD. (1985). Upper airway obstruction in craniofacial anomalies: diagnosis and management. Birth Defects Orig Artic Ser.
352 Honjo I, Tashima K, Mitoma T, et al. (1985). Effect of adenoidectomy on eustachian tube function. Auris Nasus Larynx.
353 Hossain A, Zakzouk SM, Sengupta DK. (1985). Ear, nose and throat diseases in Saudi Arabia. Microbiology and clinical observations. Trop Geogr Med.
354 Ijaduola TG. (1985). Acute otalgia in Nigerian children. Trop Geogr Med.
355 Jacobs C, Hoppe RT. (1985). Non-Hodgkin's lymphomas of head and neck extranodal sites. Int J Radiat Oncol Biol Phys.
356 Jokinen K, Sipila P, Jokipii AM, et al. (1985). Peritonsillar abscess: bacteriological evaluation. Clin Otolaryngol Allied Sci.
357 Kim KS, Kaplan EL. (1985). Association of penicillin tolerance with failure to eradicate group A streptococci from patients with pharyngitis. J Pediatr.
358 Krishnan A, Tolhurst-Cleaver CL, Kay B. (1985). Controlled comparison of nalbuphine and morphine for post-tonsillectomy pain. Anaesthesia.
359 Kuharik MA, Edwards MK, Grossman CB. (1985). Magnetic resonance evaluation of pediatric spinal dysraphism. Pediatr Neurosci.
360 Lee IN. (1985). Outpatient management of T and A procedure in children. J Otolaryngol.
361 Leicht P, Wisborg T, Chraemmer-Jorgensen B. (1985). Does intravenous lidocaine prevent laryngospasm after extubation in children?. Anesth Analg.
362 Lindgren L, Saarnivaara L. (1985). Comparison of paracetamol and aminophenazone plus diazepam suppositories for anxiety and pain relief after tonsillectomy in children. Acta Anaesthesiol Scand.
363 Linna O. (1985). A 5-year prognosis of childhood asthma. Acta Paediatr Scand.
364 Long CG, Smith DH. (1985). Parental pressure for tonsillectomy: attitudes and knowledge of parents accompanying their children to an ear, nose and throat clinic. Psychol Med.
365 Mahboubi S, Marsh RR, Potsic WP, et al. (1985). The lateral neck radiograph in adenotonsillar hyperplasia. Int J Pediatr Otorhinolaryngol.
366 Manchikanti L, Hawkins JM, McCracken JH, et al. (1985). Effect of cimetidine, metoclopramide and oral premedication on gastric contents in pediatric outpatients. Anesthesiol. Rev.
367 Maurice M, Yousef R, Louis K. (1985). Organisms causing tonsillitis with a comparative study of the anti-streptolysin 0 titre and C-reactive protein before and after tonsillectomy. J Egypt Public Health Assoc.
368 Maurizi M, Pagliari J, Paludetti G, et al. (1985). Functional evaluation of velar insufficiency by means of the rhinomanometric method. Rhinology.
369 Maw AR. (1985). Factors affecting adenoidectomy for otitis media with effusion (glue ear). J R Soc Med.
370 Maw AR. (1985). Age and adenoid size in relation to adenoidectomy in otitis media with effusion. Am J Otolaryngol.
371 Maw AR. (1985). The long term effect of adenoidectomy on established otitis media with effusion in children. Auris Nasus Larynx.
372 Maw AR, Speller DC. (1985). Are the tonsils and adenoids a reservoir of infection in otitis media with effusion (glue ear)?. Clin Otolaryngol Allied Sci.
373 Mills RP, Uttley AH, McIntyre MF. (1985). A bacteriological study of the middle ear and upper respiratory tract in children with chronic secretory otitis media. Clin Otolaryngol Allied Sci.
374 Moran WB, Orr WC. (1985). Diagnosis and management of obstructive sleep apnea. Part II. Arch Otolaryngol.
375 Niho M. (1985). Treatment of otitis media with effusion. Auris Nasus Larynx.
376 Noik ES. (1985). The analgesic effects of Stopayne Syrup in tonsillectomised patients. Current Therapeutic Research - Clinical and Experimental.
377 Palva T, Tuohimaa P, Lehtinen T. (1985). Pneumococcal immune complexes and clinical course of secretory otitis media. Int J Pediatr Otorhinolaryngol.
378 Roos K, Holm SE, Ekedahl C. (1985). Treatment failure in acute streptococcal tonsillitis in children over the age of 10 and in adults. Scand J Infect Dis.
379 Ruuskanen O, Meurman O, Sarkkinen H. (1985). Adenoviral diseases in children: a study of 105 hospital cases. Pediatrics.
380 Saul SH, Kapadia SB. (1985). Primary lymphoma of Waldeyer's ring. Clinicopathologic study of 68 cases. Cancer.
381 Sharman W. (1985). Tonsillectomy through a child's eyes. Nurs Times.
382 Shprintzen RJ, Schwartz RH, Daniller A, et al. (1985). Morphologic significance of bifid uvula. Pediatrics.
383 Simm KJ. (1985). ZUR SCHMERZTHERAPIE NACH TONSILLEKTOMIE. Die Therapiewoche.
384 Siodlak MZ, Gleeson MJ, Wengraf CL. (1985). Post-tonsillectomy secondary haemorrhage. Ann R Coll Surg Engl.
385 Suzuki M, Kodera K. (1985). Long term follow-up of secretory otitis media in children: the effects of adenotonsillectomy with insertion of a ventilation tube. Auris Nasus Larynx.
386 Svane-Knudsen V, Lildholdt T. (1985). Sequelae of ventilation tubes following tonsillectomy. Arch Otorhinolaryngol.
387 Tedder TF, Clement LT, Cooper MD. (1985). Human lymphocyte differentiation antigens HB-10 and HB-11. I. Ontogeny of antigen expression. J Immunol.
388 Thompson HL. (1985). Report of the Criteria Committee on tonsillectomy audit March, 1985. Aust Clin Rev.
389 Tuner K, Nord CE. (1985). Impact of phenoxymethylpenicillin and clindamycin on microflora in recurrent tonsillitis. Ann Otol Rhinol Laryngol.
390 Tyrer LB. (1985). Health benefits of legal abortion: an analysis. Plan Parent Rev.
391 Watanabe H, Shin T, Fukaura J, et al. (1985). Total actual speaking time in infants and children with otitis media with effusion. Int J Pediatr Otorhinolaryngol.
392 Watanabe H, Shin T, Fukaura J, et al. (1985). Measurement of young children's total actual speaking time by a newly devised accumulator as an assessment of otitis media with effusion. Auris Nasus Larynx.
393 Widemar L, Svensson C, Rynnel-Dagoo B, et al. (1985). The effect of adenoidectomy on secretory otitis media: a 2-year controlled prospective study. Clin Otolaryngol Allied Sci.
394 Yamanaka N, Somekawa Y, Kataura A. (1985). Spontaneous DNA synthesis in adenoidal lymphocytes from healthy children and from children with otitis media with effusion. Acta Otolaryngol.
395 Young JR. (1985). A comparative study of benzydamine hydrochloride 0.15% w.v. (‘Difflam’ pump spray) and placebo as analgesics following tonsillectomy. J Int Med Res.
396 Almqvist U. (1986). Cryosurgical treatment of tonsillar hypertrophy in children. J Laryngol Otol.
397 Andersson J, Britton S, Ernberg I, et al. (1986). Effect of acyclovir on infectious mononucleosis: a double-blind, placebo-controlled study. J Infect Dis.
398 Black N, Crowther J, Freeland A. (1986). The effectiveness of adenoidectomy in the treatment of glue ear: a randomized controlled trial. Clin Otolaryngol Allied Sci.
399 Brook I, Foote PA. (1986). Comparison of the microbiology of recurrent tonsillitis between children and adults. Laryngoscope.
400 Cantani A, Bellioni P, Salvinelli F, et al. (1986). Serum immunoglobulins and secretory IgA deficiency in tonsillectomized children. Ann Allergy.
401 Cramer BC, Jequier S, O'Gorman AM. (1986). Sonography of the neonatal craniocervical junction. AJR Am J Roentgenol.
402 Dahl M, Hakansson L, Kreuger A, et al. (1986). Polymorphonuclear neutrophil function and infections following splenectomy in childhood. Scand J Haematol.
403 De Korte D, Haverkort WA, Roos D, et al. (1986). Imbalance in the ribonucleotide pools of lymphoid cells from acute lymphoblastic leukemia patients. Leuk Res.
404 Duncavage JA, Ossoff RH. (1986). Use of the CO2 laser for malignant disease of the oral cavity. Lasers Surg Med.
405 Eliasson I, Kamme C, Prellner K. (1986). Beta-lactamase production in the upper respiratory tract flora. Eur J Clin Microbiol.
406 Favre A, Paoli D, Poletti M, et al. (1986). The human palatine tonsil studied from surgical specimens at all ages and in various pathological conditions. 2. Histochemical analyses. Z Mikrosk Anat Forsch.
407 Favre A, Paoli D, Poletti M, et al. (1986). The human palatine tonsil studied from surgical specimens at all ages and in various pathological conditions. 1. Morphological and structural analyses. Z Mikrosk Anat Forsch.
408 Federspil P, Koch A, Schatzle W, et al. (1986). Timentin--clinical and pharmacokinetic evaluation in otorhinolaryngology. J Antimicrob Chemother.
409 Fraschini F, Braga PC, Falchi M, et al. (1986). Ceftriaxone therapy in otolaryngological and pulmonary infections. Chemotherapy.
410 Gates GA. (1986). Otologic referral: indications and expectations. Pediatr Infect Dis.
411 Gates GA, Avery C, Prihoda TJ, et al. (1986). Post-tympanostomy otorrhea. Laryngoscope.
412 Gates GA, Folbre TW. (1986). Indications for adenotonsillectomy. Arch Otolaryngol Head Neck Surg.
413 Ginsburg CM. (1986). Pharmacology of erythromycin in infants and children. Pediatr Infect Dis.
414 Goday A, Simmonds HA, Fairbanks LD, et al. (1986). B-lymphocytes, thymocytes and platelets accumulate high dATP levels in simulated ADA deficiency. Adv Exp Med Biol.
415 Handler SD, Miller L, Richmond KH, et al. (1986). Post-tonsillectomy hemorrhage: incidence, prevention and management. Laryngoscope.
416 Klein JC. (1986). Nasal respiratory function and craniofacial growth. Arch Otolaryngol Head Neck Surg.
417 Klein M, Reynolds LG. (1986). Relief of sleep-related oropharyngeal airway obstruction by continuous insufflation of the pharynx. Lancet.
418 Kohli-Dang N, Crysdale WS. (1986). Cephalometric radiographs and nasal resistance. J Otolaryngol.
419 Lesser TH, Clayton MI, Skinner D. (1986). Efficacy of medical treatment as an adjunct to surgery in the treatment of secretory otitis media. J Laryngol Otol.
420 Levy Y, Nitzan M, Beharab A, et al. (1986). Adenovirus type 3 infection with systemic manifestation in apparently normal children. Isr J Med Sci.
421 Linder-Aronson S, Woodside DG, Lundstrom A. (1986). Mandibular growth direction following adenoidectomy. Am J Orthod.
422 Maurizi M, Paludetti G, Ottaviani F, et al. (1986). Mucociliary function and nasal resistance evaluation before and after adenoidectomy. Int J Pediatr Otorhinolaryngol.
423 Maw AR. (1986). Adenoidectomy and Adenotonsillectomy for Otitis Media with Effusion in Children: A Prospective Randomized Controlled Study.
424 Maw AR, Herod F. (1986). Otoscopic, impedance, and audiometric findings in glue ear treated by adenoidectomy and tonsillectomy. A prospective randomised study. Lancet.
425 McClairen WC, Strauss M. (1986). Tonsillectomy: a clinical study comparing the effects of local versus general anesthesia. Laryngoscope.
426 McCombie SC. (1986). Tonsillectomy as a co-factor in the development of AIDS. Med Hypotheses.
427 Morinaga S, Nakajima T, Shimosato Y, et al. (1986). Histologic factors influencing prognosis of adenoid cystic carcinoma of the head and neck. Jpn J Clin Oncol.
428 Nascimento AG, Amaral AL, Prado LA, et al. (1986). Adenoid cystic carcinoma of salivary glands. A study of 61 cases with clinicopathologic correlation. Cancer.
429 Nuutinen J, Kunnas K, Seppa J, et al. (1986). The mycotic flora of adenoids and antibodies to Candida albicans in children. Arch Otorhinolaryngol.
430 O'Brien CJ, Soong SJ, Herrera GA, et al. (1986). Malignant salivary tumors--analysis of prognostic factors and survival. Head Neck Surg.
431 Palva T, Malmberg H, Lehtinen T. (1986). Effect of erythromycin on adenoid bacteria. Acta Otolaryngol.
432 Parker DA, Gibbin KP, Noyelle RM. (1986). Syrup formulations for post-tonsillectomy analgesia: a double-blind study comparing ibuprofen, aspirin and placebo. J Laryngol Otol.
433 Perrin JM, Valvona J, Sloan FA. (1986). Changing patterns of hospitalization for children requiring surgery. Pediatrics.
434 Petridou E, Valadian I, Trichopoulos D, et al. (1986). Social factors and professional attitudes as determinants of the frequency of small surgical procedures among children in Greece. Soz Praventivmed.
435 Plum J, Van Cauwenberge P, De Smedt M. (1986). Phenotyping of mononuclear cells from tonsils and corresponding biopsies using a cytofluorimeter. A comparative study. Acta Otolaryngol.
436 Potsic WP, Pasquariello PS, Baranak CC, et al. (1986). Relief of upper airway obstruction by adenotonsillectomy. Otolaryngol Head Neck Surg.
437 Putto A, Ruuskanen O, Meurman O, et al. (1986). C reactive protein in the evaluation of febrile illness. Arch Dis Child.
438 Raj TB, Wickham MH. (1986). The effect of benzydamine hydrochloride (difflam) spray on post-tonsillectomy symptoms: a double-blind study. J Laryngol Otol.
439 Rice D. (1986). Snoring. Otolaryngol Clin North Am.
440 Ridley SA, Matthews NC, Dixon J. (1986). Meptazinol versus pethidine for postoperative pain relief in children. Anaesthesia.
441 Rockley TJ, Rhys Evans PH. (1986). Secretory otitis media--evidence for an inherited aetiology. J Laryngol Otol.
442 Roos K, Grahn E, Ekedahl C, et al. (1986). Pharmacokinetics of phenoxymethylpenicillin in tonsils. Scand J Infect Dis.
443 Roos K, Grahn E, Holm SE. (1986). Evaluation of beta-lactamase activity and microbial interference in treatment failures of acute streptococcal tonsillitis. Scand J Infect Dis.
444 Rutkow IM. (1986). Ear, nose, and throat operations in the United States, 1979 to 1984. Arch Otolaryngol Head Neck Surg.
445 Shoemaker M, Lampe RM, Weir MR. (1986). Peritonsillitis: abscess or cellulitis?. Pediatr Infect Dis.
446 Siegel-Sadewitz VL, Shprintzen RJ. (1986). Changes in velopharyngeal valving with age. Int J Pediatr Otorhinolaryngol.
447 Sigurdsson GH. (1986). Respiratory depression during enflurane anaesthesia in children: influence of the nitrous oxide concentration. Eur J Anaesthesiol.
448 St Haxholdt O, Loft S, Clemmensen A, et al. (1986). Increased hepatic microsomal activity after halothane anaesthesia in children. Anaesthesia.
449 Stafford N, von Haacke N, Sene A, et al. (1986). The treatment of recurrent tonsillitis in adults. J Laryngol Otol.
450 Stangerup SE, Tos M. (1986). Treatment of secretory otitis and pneumatization. Laryngoscope.
451 Stegehuis HR, Schousboe M. (1986). Peritonsillar infection in Christchurch 1981-1984. N Z Med J.
452 Strome M. (1986). Obstructive sleep apnea in Down syndrome children: a surgical approach. Laryngoscope.
453 Tankel JW, Cheesman AD. (1986). Symptom relief by adenoidectomy and relationship to adenoid and post-nasal airway size. J Laryngol Otol.
454 Telian SA, Handler SD, Fleisher GR, et al. (1986). The effect of antibiotic therapy on recovery after tonsillectomy in children. A controlled study. Arch Otolaryngol Head Neck Surg.
455 Theriault C, Fitzpatrick PJ. (1986). Malignant parotid tumors. Prognostic factors and optimum treatment. Am J Clin Oncol.
456 Toner JG, Stewart TJ, Campbell JB, et al. (1986). Tonsil flora in the very young tonsillectomy patient. Clin Otolaryngol Allied Sci.
457 Tran L, Sadeghi A, Hanson D, et al. (1986). Major salivary gland tumors: treatment results and prognostic factors. Laryngoscope.
458 Tuner K, Nord CE. (1986). Impact on peritonsillar infections and microflora of phenoxymethylpenicillin alone versus phenoxymethylpenicillin in combination with metronidazole. Infection.
459 Van der Velden U, Van Winkelhoff AJ, Abbas F, et al. (1986). The habitat of periodontopathic micro-organisms. J Clin Periodontol.
460 Walser H, Emre M, Janzer R. (1986). Somatosensory evoked potentials in comatose patients: correlation with outcome and neuropathological findings. J Neurol.
461 Willatt DJ. (1986). Children's sore throats related to parental smoking. Clin Otolaryngol Allied Sci.
462 Witzel MA, Rich RH, Margar-Bacal F, et al. (1986). Velopharyngeal insufficiency after adenoidectomy: an 8-year review. Int J Pediatr Otorhinolaryngol.
463 Adekeye EO, Chau KK, Edwards MB, et al. (1987). Osteosarcoma of the jaws--a series from Kaduna, Nigeria. Int J Oral Maxillofac Surg.
464 Anderson HR, Bland JM, Peckham CS. (1987). Risk factors for asthma up to 16 years of age. Evidence from a national cohort study. Chest.
465 Astbury J, Orgill A, Bajuk B. (1987). Relationship between two-year behaviour and neurodevelopmental outcome at five years of very low-birthweight survivors. Dev Med Child Neurol.
466 Brada M, Henk JM. (1987). Radiotherapy for lacrimal gland tumours. Radiother Oncol.
467 Brodsky L, Moore L, Stanievich JF. (1987). A comparison of tonsillar size and oropharyngeal dimensions in children with obstructive adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
468 Bronstein G, Gesztes T, Puterman M. (1987). The possibility of using narrow tubes in anesthesia. Current Therapeutic Research - Clinical and Experimental.
469 Brook I. (1987). Microbiology of abscesses of the head and neck in children. Ann Otol Rhinol Laryngol.
470 Cozanitis DA, Erkola O, Klemola UM, et al. (1987). Precurarisation in infants and children less than three years of age. Can J Anaesth.
471 Drexler HG, Brenner MK, Wimperis JZ, et al. (1987). CD5-positive B cells after T cell depleted bone marrow transplantation. Clin Exp Immunol.
472 Elwany S. (1987). The adenoidal-nasopharyngeal ratio (AN ratio). Its validity in selecting children for adenoidectomy. J Laryngol Otol.
473 Esposito S, Galante D, Barba D, et al. (1987). Ciprofloxacin concentrations in human fluids and tissues following a single oral dose. Int J Clin Pharmacol Res.
474 Estrov Z, Lau AS, Williams BR, et al. (1987). Recombinant human interferon alpha-2 and juvenile chronic myelogenous leukemia: cell receptor binding, enzymatic induction, and growth suppression in vitro. Exp Hematol.
475 Freeland AP, Curley JW. (1987). The consequences of delay in tonsil surgery. Otolaryngol Clin North Am.
476 Galvis AG. (1987). Pulmonary edema complicating relief of upper airway obstruction. Am J Emerg Med.
477 Gates GA, Avery CA, Prihoda TJ, et al. (1987). Effectiveness of adenoidectomy and tympanostomy tubes in the treatment of chronic otitis media with effusion. N Engl J Med.
478 Gooch WM, Swenson E, Higbee MD, et al. (1987). Cefuroxime axetil and penicillin V compared in the treatment of group A beta-hemolytic streptococcal pharyngitis. Clin Ther.
479 Havas TE, Cole P, Gullane P, et al. (1987). Alterations in nasal physiology after laryngectomy: the nasal cycle. J Otolaryngol.
480 Hebblethwaite EM, Brown GW, Cox DM. (1987). A comparison of the efficacy and safety of cefuroxime axetil and augmentin in the treatment of upper respiratory tract infections. Drugs Exp Clin Res.
481 Horiuchi J, Shibuya H, Suzuki S, et al. (1987). The role of radiotherapy in the management of adenoid cystic carcinoma of the head and neck. Int J Radiat Oncol Biol Phys.
482 Hovi T, Svahn T, Valtonen V. (1987). Twice-a-day regimen of erythromycin base is effective in the treatment of acute streptococcal tonsillitis. Scand J Infect Dis.
483 Humberstone DA, Levestrom M, Shaw JH. (1987). Parotid cancer in Auckland 1970-1986--too little, too late. N Z Med J.
484 Ijaduola GT, Akinyanju OO. (1987). Chronic tonsillitis, tonsillectomy and sickle cell crises. J Laryngol Otol.
485 Johannesson GP, Lindahl SG, Sigurdsson GH, et al. (1987). Halothane, enflurane and isoflurane anaesthesia for adenoidectomy in children, using two different premedications. Acta Anaesthesiol Scand.
486 Judd BA, Haycock GB, Dalton N, et al. (1987). Hyponatraemia in premature babies and following surgery in older children. Acta Paediatr Scand.
487 Juliusson S, Bende M. (1987). Rhinomanometry at selection for adenoidectomy. Rhinology.
488 Karma P, Palva T, Kouvalainen K, et al. (1987). Finnish approach to the treatment of acute otitis media. Report of the Finnish Consensus Conference. Ann Otol Rhinol Laryngol Suppl.
489 Laurikainen E, Erkinjuntti M, Alihanka J, et al. (1987). Radiological parameters of the bony nasopharynx and the adenotonsillar size compared with sleep apnea episodes in children. Int J Pediatr Otorhinolaryngol.
490 Ma DQ, Yu GY. (1987). Tumours of the minor salivary glands. A clinicopathologic study of 243 cases. Acta Otolaryngol.
491 Manning SC, Beste D, McBride T, et al. (1987). An assessment of preoperative coagulation screening for tonsillectomy and adenoidectomy. Int J Pediatr Otorhinolaryngol.
492 Martinez SA, Akin DP. (1987). Laser tonsillectomy and adenoidectomy. Otolaryngol Clin North Am.
493 McDonald TJ. (1987). Nosebleed in children. Background and techniques to stop the flow. Postgrad Med.
494 Moser RJ, Rajagopal KR. (1987). Obstructive sleep apnea in adults with tonsillar hypertrophy. Arch Intern Med.
495 Mueller N, Swanson GM, Hsieh CC, et al. (1987). Tonsillectomy and Hodgkin's disease: results from companion population-based studies. J Natl Cancer Inst.
496 Murray WB, Yankelowitz SM, le Roux M, et al. (1987). Prevention of post-tonsillectomy pain with analgesic doses of ketamine. S Afr Med J.
497 Odetoyinbo O. (1987). Ketamine: parenteral anaesthesia for tonsillectomy. Trop Doct.
498 Ophir D, Porat M, Marshak G. (1987). Myringoplasty in the pediatric population. Arch Otolaryngol Head Neck Surg.
499 Osborne JE, Telford D, Barr G, et al. (1987). Adenoid infection: its relationship to otitis media, glue ear and tonsillitis. Clin Otolaryngol Allied Sci.
500 Osterback L, Qvarnberg Y. (1987). A prospective study of respiratory infections in 12-year-old children actively engaged in sports. Acta Paediatr Scand.
501 Palumbo FM. (1987). Pediatric considerations of infections and inflammations of Waldeyer's ring. Otolaryngol Clin North Am.
502 Provvedini DM, Rulot CM, Sobol RE, et al. (1987). 1 alpha,25-Dihydroxyvitamin D3 receptors in human thymic and tonsillar lymphocytes. J Bone Miner Res.
503 Putto A. (1987). Febrile exudative tonsillitis: viral or streptococcal?. Pediatrics.
504 Rasmussen N. (1987). Complications of tonsillectomy and adenoidectomy. Otolaryngol Clin North Am.
505 Reath DB, LaRossa D, Randall P. (1987). Simultaneous posterior pharyngeal flap and tonsillectomy. Cleft Palate J.
506 Richmond KH, Wetmore RF, Baranak CC. (1987). Postoperative complications following tonsillectomy and adenoidectomy--who is at risk?. Int J Pediatr Otorhinolaryngol.
507 Ron E, Kleinerman RA, Boice JD, et al. (1987). A population-based case-control study of thyroid cancer. J Natl Cancer Inst.
508 Saarnivaara L, Klemola UM. (1987). Alfentanil as an adjuvant of balanced anaesthesia for tonsillectomy in adults. Acta anaesthesiologica Scandinavica.
509 Sanderson J, Warner JO. (1987). Previous ear, nose and throat surgery in children presenting with allergic perennial rhinitis. Clin Allergy.
510 Sankowski A, Janik P, Jeziorska M, et al. (1987). The results of topical application of 13-cis-retinoic acid on basal cell carcinoma. A correlation of the clinical effect with histopathological examination and serum retinol level. Neoplasma.
511 Shepard DS, Cooper GS. (1987). Small-area variations in rates of hospitalization and surgery within Rhode Island. Am J Prev Med.
512 Shott SR, Myer CM, Cotton RT. (1987). Efficacy of tonsillectomy and adenoidectomy as an outpatient procedure: a preliminary report. Int J Pediatr Otorhinolaryngol.
513 Shprintzen RJ, Sher AE, Croft CB. (1987). Hypernasal speech caused by tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
514 Soebardja D, Dahlan D, Rahman O, et al. (1987). Spiramycin and erythromycin in the treatment of acute tonsillopharyngitis in children. Paediatr Indones.
515 Southall DP, Stebbens VA, Mirza R, et al. (1987). Upper airway obstruction with hypoxaemia and sleep disruption in Down syndrome. Dev Med Child Neurol.
516 Spires JR, Owens JJ, Woodson GE, et al. (1987). Treatment of peritonsillar abscess. A prospective study of aspiration vs incision and drainage. Arch Otolaryngol Head Neck Surg.
517 Stang H. (1987). Tonsillectomy referrals in an HMO-based population. Minn Med.
518 Stanwick RS, Horne JM, Peabody DM, et al. (1987). Day-care versus inpatient pediatric surgery: a comparison of costs incurred by parents. CMAJ.
519 Stow PJ, White JB. (1987). Anaesthesia for paediatric tonsillectomy. Comparison of spontaneous ventilation and intermittent positive pressure ventilation. Br J Anaesth.
520 Stromberg A, Friberg U, Cars O. (1987). Concentrations of phenoxymethylpenicillin and cefadroxil in tonsillar tissue and tonsillar surface fluid. Eur J Clin Microbiol.
521 Strome M. (1987). Childhood irradiation of pharyngeal lymphoid tissue: management considerations. Otolaryngol Clin North Am.
522 Tami TA, Parker GS, Taylor RE. (1987). Post-tonsillectomy bleeding: an evaluation of risk factors. Laryngoscope.
523 Tarvonen PL, Koski K. (1987). Craniofacial skeleton of 7-year-old children with enlarged adenoids. Am J Orthod Dentofacial Orthop.
524 Thomas DL, Vaughan RS, Vickers MD, et al. (1987). Comparison of temazepam elixir and trimeprazine syrup as oral premedication in children undergoing tonsillectomy and associated procedures. Br J Anaesth.
525 Tos M, Stangerup SE, Larsen P. (1987). Dynamics of eardrum changes following secretory otitis. A prospective study. Arch Otolaryngol Head Neck Surg.
526 Tran L, Sadeghi A, Hanson D, et al. (1987). Salivary gland tumors of the palate: the UCLA experience. Laryngoscope.
527 Trask GM, Shapiro GG, Shapiro PA. (1987). The effects of perennial allergic rhinitis on dental and skeletal development: a comparison of sibling pairs. Am J Orthod Dentofacial Orthop.
528 Tuohimaa P, Palva T. (1987). The effect of tonsillectomy and adenoidectomy on the intra-tympanic pressure. J Laryngol Otol.
529 Van der Walt JH, Nicholls B, Bentley M, et al. (1987). Oral premedication in children. Anaesth Intensive Care.
530 Vaquero J, Martinez R, Salazar J, et al. (1987). Syringosubarachnoid shunt for treatment of syringomyelia. Acta Neurochir (Wien).
531 Vellucci A, Marcucci L, Greco D, et al. (1987). Use of ceftazidime in the treatment of otorhinolaryngoiatric bacterial infections. Int J Clin Pharmacol Ther Toxicol.
532 Wales JK, Milner RD. (1987). Knemometry in assessment of linear growth. Arch Dis Child.
533 Weimert TA. (1987). Evaluation of the upper airway in children. Ear Nose Throat J.
534 Wight RG, Jones AS, Connell JA, et al. (1987). Three-year follow-up (1983-1986) of children undergoing bilateral grommet insertion in Sheffield. Clin Otolaryngol Allied Sci.
535 Xu LT, Sun ZF, Li ZJ, et al. (1987). Clinical and pathologic characteristics in patients with tracheobronchial tumor: report of 50 patients. Ann Thorac Surg.
536 Young JR. (1987). A comparative study of benzydamine hydrochloride (“Difflam” pump spray) and placebo as analgesics following tonsillectomy. Int J Tissue React.
537 Abbey K, Kawabata I. (1988). Computerized three-dimensional reconstruction of the crypt system of the palatine tonsil. Acta Otolaryngol Suppl.
538 Ahlqvist-Rastad J, Hultcrantz E, Svanholm H. (1988). Children with tonsillar obstruction: indications for and efficacy of tonsillectomy. Acta Paediatr Scand.
539 Barr GS, Osborne J. (1988). Weight gain in children following tonsillectomy. J Laryngol Otol.
540 Bone ME, Fell D. (1988). A comparison of rectal diclofenac with intramuscular papaveretum or placebo for pain relief following tonsillectomy. Anaesthesia.
541 Brandtzaeg P. (1988). Immunopathological alterations in tonsillar disease. Acta Otolaryngol Suppl.
542 Brodsky L, Moore L, Stanievich J. (1988). The role of Haemophilus influenzae in the pathogenesis of tonsillar hypertrophy in children. Laryngoscope.
543 Brodsky L, Sobie SR, Korwin D, et al. (1988). A clinical prospective study of peritonsillar abscess in children. Laryngoscope.
544 Brook I. (1988). Beta-lactamase-producing bacteria in head and neck infection. Laryngoscope.
545 Cheng CY, Tang SJ, Cheng RQ. (1988). Clinical observation on guillotine tonsillectomy without anesthesia. Acta Otolaryngol Suppl.
546 DeDio RM, Tom LW, McGowan KL, et al. (1988). Microbiology of the tonsils and adenoids in a pediatric population. Arch Otolaryngol Head Neck Surg.
547 Dempster JH. (1988). Post-tonsillectomy analgesia: the use of benzocaine lozenges. J Laryngol Otol.
548 Donaldson JD, Redmond WM. (1988). Surgical management of obstructive sleep apnea in children with Down syndrome. J Otolaryngol.
549 Eapen LJ, Gerig LH, Catton GE, et al. (1988). Impact of local radiation in the management of salivary gland carcinomas. Head Neck Surg.
550 Fradis M, Podoshin L, Wellisch G, et al. (1988). Mycosis in patients with acute recurrent purulent tonsillitis. Ear Nose Throat J.
551 Fraschini F, Scaglione F, Vago F, et al. (1988). Correlation between plasma and tonsillar levels of cefroxadine. Chemotherapy.
552 Fujikawa S, Hanawa Y, Ito H, et al. (1988). Streptococcal antibody: as an indicator of tonsillectomy. Acta Otolaryngol Suppl.
553 Fujita A, Takahashi H, Honjo I. (1988). Etiological role of adenoids upon otitis media with effusion. Acta Otolaryngol Suppl.
554 Furusaka T, Ishiyama E, Kida A, et al. (1988). Indication of cryosurgery on tonsillar diseases. Acta Otolaryngol Suppl.
555 Galioto GB, Ortisi G, Mevio E, et al. (1988). Roxithromycin disposition in tonsils after single and repeated administrations. Antimicrob Agents Chemother.
556 Gates GA, Avery CA, Prihoda TJ. (1988). Effect of adenoidectomy upon children with chronic otitis media with effusion. Laryngoscope.
557 Gaudreault P, Guay J, Nicol O, et al. (1988). Pharmacokinetics and clinical efficacy of intrarectal solution of acetaminophen. Can J Anaesth.
558 Gereau SA, Shprintzen RJ. (1988). The role of adenoids in the development of normal speech following palate repair. Laryngoscope.
559 Gordin A, Mannisto PT, Antikainen R, et al. (1988). Concentrations of erythromycin, 2'-acetyl erythromycin, and their anhydro forms in plasma and tonsillar tissue after repeated dosage of erythromycin stearate and erythromycin acistrate. Antimicrob Agents Chemother.
560 Harley EH. (1988). Quinsy tonsillectomy as the treatment of choice for peritonsillar abscess. Ear Nose Throat J.
561 Honda K, Tanke M, Kumazawa T. (1988). Otitis media with effusion and tubal tonsil (video). Acta Otolaryngol Suppl.
562 Ijaduola TG, Ademiluyi SA. (1988). Parotid fistula in children in the tropics. Ann Trop Paediatr.
563 Ishikawa M, Kikuchi H, Fujisawa I, et al. (1988). Tonsillar herniation on magnetic resonance imaging. Neurosurgery.
564 Kapuniai LE, Andrew DJ, Crowell DH, et al. (1988). Identifying sleep apnea from self-reports. Sleep.
565 Kavanagh KT, Beckford NS. (1988). Adenotonsillectomy in children: indications and contraindications. South Med J.
566 Kim JY, Lee CH. (1988). Clinical study on the efficacy of tonsilloadenoidectomy. Acta Otolaryngol Suppl.
567 Kristensen S, Tveteraas K, Hein P, et al. (1988). Relief of pain and trismus in patients treated with naproxen or acetylsalicylic acid after tonsillectomy. J Laryngol Otol.
568 Laurence AS. (1988). Serum myoglobin release following suxamethonium administration to children. Eur J Anaesthesiol.
569 Leiberman A, Tal A, Brama I, et al. (1988). Obstructive sleep apnea in young infants. Int J Pediatr Otorhinolaryngol.
570 MacDougall SL, Grinstein S, Gelfand EW. (1988). Activation of Ca2+-dependent K+ channels in human B lymphocytes by anti-immunoglobulin. J Clin Invest.
571 Masuda Y, Terazawa K, Kawakami S, et al. (1988). Clinical and immunological study of IgA nephropathy before and after tonsillectomy. Acta Otolaryngol Suppl.
572 Maw AR. (1988). Tonsils and adenoids. Their relation to secretory otitis media. Adv Otorhinolaryngol.
573 Maw AR, Parker A. (1988). Surgery of the tonsils and adenoids in relation to secretory otitis media in children. Acta Otolaryngol Suppl.
574 McIlwain JC, Toner JG, Stewart TJ, et al. (1988). The flora of the tonsil and post-operative fossa in adult tonsillectomy patients. J Laryngol Otol.
575 Mira E, Benazzo M, Asti L, et al. (1988). Iron status in children undergoing tonsillectomy and its short-term modification following surgery. Acta Otolaryngol Suppl.
576 Moloney JR, John DG, Jagger C. (1988). Age, sex, ethnic origin and tonsillectomy. J Laryngol Otol.
577 Moore D. (1988). Fentanyl-supplemented halothane anesthesia for pediatric outpatient adenotonsillectomies. AANA J.
578 Nishimura T, Yagisawa M, Suzuki A, et al. (1988). Laser tonsillectomy. Acta Otolaryngol Suppl.
579 Ogino S, Notake N, Harada T, et al. (1988). Long-term observation of postoperative course of habitual tonsillitis. Acta Otolaryngol Suppl.
580 Ohashi Y, Nakai Y, Koshimo H, et al. (1988). Reversibility of reduced ciliary activity on adenoids of patients with otitis media with effusion following culture. Clin Otolaryngol Allied Sci.
581 Ophir D, Bawnik J, Poria Y, et al. (1988). Peritonsillar abscess. A prospective evaluation of outpatient management by needle aspiration. Arch Otolaryngol Head Neck Surg.
582 Pavesio D, Pecco P, Peisino MG. (1988). Short-term treatment of streptococcal tonsillitis with ceftriaxone. Chemotherapy.
583 Praud JP, D'Allest AM, Delaperche MF, et al. (1988). Diaphragmatic and genioglossus electromyographic activity at the onset and at the end of obstructive apnea in children with obstructive sleep apnea syndrome. Pediatr Res.
584 Resler DR. (1988). Personal observations regarding adenoidectomy. J Okla State Med Assoc.
585 Robinson PM. (1988). Prognostic factors in otitis media with effusion. J Laryngol Otol.
586 Ruckley RW, Blair RL. (1988). Thermal myringotomy (an alternative to grommet insertion in childhood secretory otitis media?). J Laryngol Otol.
587 Rynnel-Dagoo B, Freijd A. (1988). Nasopharyngeal lymphoid tissue--a threat to the middle ear?. Acta Otolaryngol Suppl.
588 Salassa JR, Seaman SL, Ruff T, et al. (1988). Oral dantrolene sodium for tonsillectomy pain: a double-blind study. Otolaryngol Head Neck Surg.
589 Savolainen S, Mannisto PT, Gordin A, et al. (1988). Tonsillar penetration of erythromycin and its 2'-acetyl ester in patients with chronic tonsillitis. J Antimicrob Chemother.
590 Schumacher MJ. (1988). Fiberoptic nasopharyngolaryngoscopy: a procedure for allergists?. J Allergy Clin Immunol.
591 Skinner DW, Lesser TH, Richards SH. (1988). A 15 year follow-up of a controlled trial of the use of grommets in glue ear. Clin Otolaryngol Allied Sci.
592 Sofer S, Weinhouse E, Tal A, et al. (1988). Cor pulmonale due to adenoidal or tonsillar hypertrophy or both in children. Noninvasive diagnosis and follow-up. Chest.
593 Stjernquist-Desatnik A, Prellner K. (1988). Antibody response to pneumococcal vaccination as related to tonsillectomy. J Laryngol Otol.
594 Stringer SP, Schaefer SD, Close LG. (1988). A randomized trial for outpatient management of peritonsillar abscess. Arch Otolaryngol Head Neck Surg.
595 Swift AC. (1988). Upper airway obstruction, sleep disturbance and adenotonsillectomy in children. J Laryngol Otol.
596 Tal A, Leiberman A, Margulis G, et al. (1988). Ventricular dysfunction in children with obstructive sleep apnea: radionuclide assessment. Pediatr Pulmonol.
597 Thorisdottir H, Ratnoff OD, Maniglia AJ. (1988). Activation of Hageman factor (factor XII) by bismuth subgallate, a hemostatic agent. J Lab Clin Med.
598 Togawa K, Konno A, Miyazaki S, et al. (1988). Obstructive sleep dyspnea. Diagnosis and treatment. Acta Otolaryngol Suppl.
599 Wackym PA, Abdul-Rasool IH. (1988). Prospective management of malignant hyperthermia in the otolaryngological patient. J Laryngol Otol.
600 Wardas M, Drozdz M, Weglarz L, et al. (1988). Hyaluronic acid and other glycosaminoglycans of the human palatal tonsils. Connect Tissue Res.
601 Watson C, Mangat KS. (1988). A comparison of audiometric performance and complications of T tubes and Shepard grommets. J Laryngol Otol.
602 Watters CH, Patterson CC, Mathews HM, et al. (1988). Diclofenac sodium for post-tonsillectomy pain in children. Anaesthesia.
603 Wolf M, Kronenberg J, Kessler A, et al. (1988). Peritonsillar abscess in children and its indication for tonsillectomy. Int J Pediatr Otorhinolaryngol.
604 Wuolijoki E, Flygare U, Hilden M, et al. (1988). Treatment of respiratory tract infections with erythromycin acistrate and two formulations of erythromycin base. J Antimicrob Chemother.
605 Ying MD. (1988). Immunological basis of indications for tonsillectomy and adenoidectomy. Acta Otolaryngol Suppl.
606 Yoshida A, Okamoto K. (1988). Indication of tonsillectomy for recurrent tonsillitis. Acta Otolaryngol Suppl.
607 Agren K, Engquist S, Danneman A, et al. (1989). Local versus general anaesthesia in tonsillectomy. Clinical otolaryngology and allied sciences.
608 Aubert-Tulkens G, Hamoir M, Van den Eeckhaut J, et al. (1989). Failure of tonsil and nose surgery in adults with long-standing severe sleep apnea syndrome. Arch Intern Med.
609 Austin DF. (1989). Adenoidectomy for secretory otitis media. Arch Otolaryngol Head Neck Surg.
610 Ayiomamitis A, Parker L. (1989). The differential diagnosis of nasal mucosal swelling and adenoidal hyperplasia using two- and three-parameter discriminant functions. Arch Otorhinolaryngol.
611 Barr GS, Crombie IK. (1989). Comparison of size of tonsils in children with recurrent tonsillitis and in controls. BMJ.
612 Behlfelt K, Linder-Aronson S, McWilliam J, et al. (1989). Dentition in children with enlarged tonsils compared to control children. Eur J Orthod.
613 Behrens TW, Lum LG, Lianos EA, et al. (1989). Lipoxygenase inhibitors enhance the proliferation of human B cells. J Immunol.
614 Bieluch VM, Martin ET, Chasin WD, et al. (1989). Recurrent tonsillitis: histologic and bacteriologic evaluation. Ann Otol Rhinol Laryngol.
615 Broadman LM, Patel RI, Feldman BA, et al. (1989). The effects of peritonsillar infiltration on the reduction of intraoperative blood loss and post-tonsillectomy pain in children. Laryngoscope.
616 Brodsky L, Adler E, Stanievich JF. (1989). Naso- and oropharyngeal dimensions in children with obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
617 Brook I. (1989). Treatment of patients with acute recurrent tonsillitis due to group A beta-haemolytic streptococci: a prospective randomized study comparing penicillin and amoxycillin/clavulanate potassium. J Antimicrob Chemother.
618 Brook I. (1989). Medical treatment of non-streptococcal recurrent tonsillitis. Am J Otolaryngol.
619 Brundage SR, Moore WD. (1989). Submandibular gland resection and bilateral parotid duct ligation as a management for chronic drooling in cerebral palsy. Plast Reconstr Surg.
620 Cole P. (1989). Doctors and dentists: review of a symposium. J Otolaryngol.
621 Cooper C, Pippard EC, Sharp H, et al. (1989). Is Behcet's disease triggered by childhood infection?. Ann Rheum Dis.
622 Corbo GM, Fuciarelli F, Foresi A, et al. (1989). Snoring in children: association with respiratory symptoms and passive smoking. BMJ.
623 Dempster JH, Browning GG. (1989). Eustachian tube function following adenoidectomy: an evaluation by sniffing. Clin Otolaryngol Allied Sci.
624 Dunn P, Shih LY, Liaw SJ, et al. (1989). Non-Hodgkin's lymphoma of Waldeyer's ring: an appraisal of therapeutic effect. Taiwan Yi Xue Hui Za Zhi.
625 Dure LS, Percy AK, Cheek WR, et al. (1989). Chiari type I malformation in children. J Pediatr.
626 Durr DG, Shapiro RS. (1989). Otologic manifestations in congenital velopharyngeal insufficiency. Am J Dis Child.
627 Favre A, Baracchini P, Giampalmo A, et al. (1989). Immunohistochemical investigations of the human palatine tonsil from surgical specimens using polyclonal and monoclonal antikeratin antibodies. Z Mikrosk Anat Forsch.
628 Federspil P, Grunbacher G, Lejdeborn L, et al. (1989). Sultamicillin versus amoxicillin in the treatment of tonsillitis and pharyngitis: a European multicenter study. APMIS Suppl.
629 Flood J. (1989). Glue ear. Nurs Times.
630 Foote PA, Brook I. (1989). Penicillin and clindamycin therapy in recurrent tonsillitis. Effect of microbial flora. Arch Otolaryngol Head Neck Surg.
631 Friedman EH, Regan CM, St Leger AS. (1989). Analysis of secular trends in surgery for glue ear in the North Western Region (1975-1984). Community Med.
632 Gates GA, Avery CA, Cooper JC, et al. (1989). Chronic secretory otitis media: effects of surgical management. Ann Otol Rhinol Laryngol Suppl.
633 Gauderer MW, Lorig JL, Eastwood DW. (1989). Is there a place for parents in the operating room?. J Pediatr Surg.
634 Golding-Wood DG, Whittet HB. (1989). The lingual tonsil. A neglected symptomatic structure?. J Laryngol Otol.
635 Guilleminault C, Partinen M, Praud JP, et al. (1989). Morphometric facial changes and obstructive sleep apnea in adolescents. J Pediatr.
636 Hansson S, Jodal U, Lincoln K, et al. (1989). Untreated asymptomatic bacteriuria in girls: II--Effect of phenoxymethylpenicillin and erythromycin given for intercurrent infections. BMJ.
637 Jan A, Ahmad I. (1989). The T's and A's problem in N.W.F.P. J Pak Med Assoc.
638 Kerr WJ, McWilliam JS, Linder-Aronson S. (1989). Mandibular form and position related to changed mode of breathing--a five-year longitudinal study. Angle Orthod.
639 Krespi YP, Har-El G, Levine TM, et al. (1989). Laser lingual tonsillectomy. Laryngoscope.
640 Lee CY, Lin TY, Chu ML, et al. (1989). Intravenous sulbactam/ampicillin in the treatment of pediatric infections. Diagn Microbiol Infect Dis.
641 Lippi L, De Meester W, Norberti A, et al. (1989). Malignant parotid tumors. Diagnostic considerations and therapeutic suggestions. Tumori.
642 Lokman S, Said H, Hakim J, et al. (1989). Experience with malignant tumours of the maxillary sinus in the Department of Otolaryngology Universiti Kebangsaan Malaysia, Kuala Lumpur. Med J Malaysia.
643 Louis E, Philippet B, Cardos B, et al. (1989). Intercellular contacts between germinal center cells. Mechanisms of adhesion between lymphoid cells and follicular dendritic cells. Acta Otorhinolaryngol Belg.
644 Maddern BR, Reed HT, Ohene-Frempong K, et al. (1989). Obstructive sleep apnea syndrome in sickle cell disease. Ann Otol Rhinol Laryngol.
645 Maniglia AJ, Kushner H, Cozzi L. (1989). Adenotonsillectomy. A safe outpatient procedure. Arch Otolaryngol Head Neck Surg.
646 Marsh RR, Potsic WP, Pasquariello PS. (1989). Reliability of sleep sonography in detecting upper airway obstruction in children. Int J Pediatr Otorhinolaryngol.
647 McLeod R. (1989). Spotlight on children. Tonsillectomy and after. Nurs Times.
648 Milatovic D, Knauer J. (1989). Cefadroxil versus penicillin in the treatment of streptococcal tonsillopharyngitis. Eur J Clin Microbiol Infect Dis.
649 Miyazaki S, Itasaka Y, Yamakawa K, et al. (1989). Respiratory disturbance during sleep due to adenoid-tonsillar hypertrophy. Am J Otolaryngol.
650 Mourad W, Scholl P, Diaz A, et al. (1989). The staphylococcal toxic shock syndrome toxin 1 triggers B cell proliferation and differentiation via major histocompatibility complex-unrestricted cognate T/B cell interaction. J Exp Med.
651 Nishioka K, Masuda Y, Yanagi E, et al. (1989). Cytologic diagnosis of the maxillary sinus reevaluated. Laryngoscope.
652 Parker AJ, Maw AR. (1989). No peak-peak tympanometric conversion following surgery for otitis media with effusion in relation to airway size: a new treatment strategy?. Clin Otolaryngol Allied Sci.
653 Parker AJ, Maw AR. (1989). Treatment of glue ear in relation to radiographic palatal airway size: a predictor for outcome following adenoidectomy?. J Laryngol Otol.
654 Parker AJ, Maw AR, Powell JE. (1989). Rhinomanometry in the selection for adenoidectomy and its relation to preoperative radiology. Int J Pediatr Otorhinolaryngol.
655 Parker AJ, Maw AR, Szallasi F. (1989). An objective method of assessing nasality: a possible aid in the selection of patients for adenoidectomy. Clin Otolaryngol Allied Sci.
656 Phillipps JJ, Thornton AR. (1989). Tonsillectomy haemostasis: diathermy or ligation. Clin Otolaryngol Allied Sci.
657 Phillips DE, Bates GJ, Parker AJ, et al. (1989). Digital and mirror assessment of the adenoids at operation. Clin Otolaryngol Allied Sci.
658 Randhawa PS, Yousem SA, Paradis IL, et al. (1989). The clinical spectrum, pathology, and clonal analysis of Epstein-Barr virus-associated lymphoproliferative disorders in heart-lung transplant recipients. Am J Clin Pathol.
659 Rauen KK, Holman JB. (1989). Pain control in children following tonsillectomies: a retrospective study. J Nurs Qual Assur.
660 Rivron RP. (1989). Bifid uvula: prevalence and association in otitis media with effusion in children admitted for routine otolaryngological operations. J Laryngol Otol.
661 Scatliff JH, Kendall BE, Kingsley DP, et al. (1989). Closed spinal dysraphism: analysis of clinical, radiological, and surgical findings in 104 consecutive patients. AJR Am J Roentgenol.
662 Serra A, Grillo C, Saita V, et al. (1989). Group A streptococcal tonsillitis: comparative evaluation of kits for rapid diagnosis. J Chemother.
663 Smith BE, Fiala KJ, Guyette TW. (1989). Partitioning model nasal airway resistance into its nasal cavity and velopharyngeal components. Cleft Palate J.
664 Smith RM, Gonzalez C. (1989). The relationship between nasal obstruction and craniofacial growth. Pediatr Clin North Am.
665 Spicher CM, Yund C. (1989). Effects of preadmission preparation on compliance with home care instructions. J Pediatr Nurs.
666 Surow JB, Handler SD, Telian SA, et al. (1989). Bacteriology of tonsil surface and core in children. Laryngoscope.
667 Takahashi H, Fujita A, Honjo I. (1989). Effect of adenoidectomy on otitis media with effusion, tubal function, and sinusitis. Am J Otolaryngol.
668 Takimoto T, Tanaka S, Masuda K, et al. (1989). Spontaneous lymphoblastoid transformation of cells obtained from human tonsils. ORL J Otorhinolaryngol Relat Spec.
669 Talaat AM, Bahgat YS, el-Ghazzawy E, et al. (1989). Nasopharyngeal bacterial flora before and after adenoidectomy. J Laryngol Otol.
670 Tomonaga K, Kurono Y, Chaen T, et al. (1989). Adenoids and otitis media with effusion: nasopharyngeal flora. Am J Otolaryngol.
671 Tos M, Stangerup SE. (1989). Hearing loss in tympanosclerosis caused by grommets. Arch Otolaryngol Head Neck Surg.
672 Valijan A. (1989). Pain relief after tonsillectomy. Effect of benzydamine hydrochloride spray on postoperative pain relief after tonsillectomy. Anaesthesia.
673 van Someren VH, Hibbert J, Stothers JK, et al. (1989). Identifying hypoxaemia in children admitted for adenotonsillectomy. BMJ.
674 Violaris NS, Tuffin JR. (1989). Can post-tonsillectomy pain be reduced by topical bupivacaine? Double blind controlled trial. Journal of laryngology and otology.
675 Vokurka J, Jakoubkova S, Vit Z, et al. (1989). Adenotomy under general anesthesia. Sb Ved Pr Lek Fak Karlovy Univerzity Hradci Kralove.
676 Wake M, Glossop P. (1989). Guillotine and dissection tonsillectomy compared. J Laryngol Otol.
677 Witzel MA, Posnick JC. (1989). Patterns and location of velopharyngeal valving problems: atypical findings on video nasopharyngoscopy. Cleft Palate J.
678 Zong YS, Zheng WJ. (1989). A morphologic and follow-up study on the nasopharyngeal lymphoid hyperplasia and its relation to the cancer. Chin Med J (Engl).
679 (1990). Flurithromycin. Drugs of the Future.
680 Adachi K, Chole RA. (1990). Management of tracheal lesions in Hurler syndrome. Arch Otolaryngol Head Neck Surg.
681 Agren K, Lundberg C, Nord CE. (1990). Effect of amoxycillin/clavulanic acid on the aerobic and anaerobic tonsillar microflora in the treatment of recurrent tonsillitis. Scand J Infect Dis.
682 Al Zahrani HA, Zamzami A. (1990). Stroke after tonsillectomy in a young girl. Bahrain Medical Bulletin.
683 Alexander CA. (1990). A modified Intavent laryngeal mask for ENT and dental anaesthesia. Anaesthesia.
684 Anavi Y, Kaplinsky C, Calderon S, et al. (1990). Head, neck, and maxillofacial childhood Burkitt's lymphoma: a retrospective analysis of 31 patients. J Oral Maxillofac Surg.
685 Arruda LK, Mimica IM, Sole D, et al. (1990). Abnormal maxillary sinus radiographs in children: do they represent bacterial infection?. Pediatrics.
686 Bartels JP, Oas RE. (1990). Use of KTP-532 laser delays healing in tonsillectomy. Clin Laser Mon.
687 Behlfelt K. (1990). Enlarged tonsils and the effect of tonsillectomy. Characteristics of the dentition and facial skeleton. Posture of the head, hyoid bone and tongue. Mode of breathing. Swed Dent J Suppl.
688 Behlfelt K, Linder-Aronson S, McWilliam J, et al. (1990). Cranio-facial morphology in children with and without enlarged tonsils. Eur J Orthod.
689 Berkowitz RG, Zalzal GH. (1990). Tonsillectomy in children under 3 years of age. Arch Otolaryngol Head Neck Surg.
690 Black NA, Sanderson CF, Freeland AP, et al. (1990). A randomised controlled trial of surgery for glue ear. BMJ.
691 Blanshard JD, Robson AK, Smith I, et al. (1990). A long term view of myringoplasty in children. J Laryngol Otol.
692 Bolger WE, Parsons DS, Potempa L. (1990). Preoperative hemostatic assessment of the adenotonsillectomy patient. Otolaryngol Head Neck Surg.
693 Bonelli L, Vitale V, Bistolfi F, et al. (1990). Hodgkin's disease in adults: association with social factors and age at tonsillectomy. A case-control study. Int J Cancer.
694 Borovich B, Johnston E, Spagnuolo E. (1990). Infratentorial subdural empyema: clinical and computerized tomography findings. Report of three cases. J Neurosurg.
695 Bredenkamp JK, Abemayor E, Wackym PA, et al. (1990). Tonsillectomy under local anesthesia: a safe and effective alternative. Am J Otolaryngol.
696 Brook I, Foote PA. (1990). Microbiology of “normal” tonsils. Ann Otol Rhinol Laryngol.
697 CG TB. (1990). Management of peritonsillar abscess (quinsy) at Harare Central Hospital. Cent Afr J Med.
698 Cheong TH, Wang YT, Poh SC. (1990). Sleep apnoea syndrome--a report of 14 cases. Singapore Med J.
699 Chiu HF, Lee S, Ho KW, et al. (1990). Sleep apnoea syndrome--a study of 5 cases. Singapore Med J.
700 Cohen J, Gierlowski TC, Schneider AB. (1990). A prospective study of hyperparathyroidism in individuals exposed to radiation in childhood. JAMA.
701 Coid DR. (1990). Managing the Fife ENT (ear, nose and throat) waiting list: the 1989 review of problems. Health Serv Manage Res.
702 Croft CB, Brockbank MJ, Wright A, et al. (1990). Obstructive sleep apnoea in children undergoing routine tonsillectomy and adenoidectomy. Clin Otolaryngol Allied Sci.
703 Croft CB, Thomson HG, Samuels MP, et al. (1990). Endoscopic evaluation and treatment of sleep-associated upper airway obstruction in infants and young children. Clin Otolaryngol Allied Sci.
704 Crombie IK, Barr G. (1990). An investigation into factors that may influence tonsil morphology. J R Soc Med.
705 de Alwis MC, Wijewardana TG, Gomis AI, et al. (1990). Persistence of the carrier status in haemorrhagic septicaemia (Pasteurella multocida serotype 6:B infection) in buffaloes. Trop Anim Health Prod.
706 De Groot C, Braun J, Mevissen ML, et al. (1990). Contrasting effects of interleukin 4 (IL-4) on the in vitro proliferation of human B cells is due to the presence of B cell subsets in different activation states. Lymphokine Res.
707 Dudley JP, Reynolds R, Dubrow TJ. (1990). Malignant hyperthermia in the otolaryngologic patient: prospective anesthetic and surgical management of eight children. Ann Otol Rhinol Laryngol.
708 Epperly TD, Wood TC. (1990). New trends in the management of peritonsillar abscess. Am Fam Physician.
709 Farrow DC, Davis S. (1990). Risk of pancreatic cancer in relation to medical history and the use of tobacco, alcohol and coffee. Int J Cancer.
710 Faure GC, Bene MC, Simon C, et al. (1990). Increase in specific antibody-forming cells in human tonsils after oral stimulation with D-53, a ribosomal vaccine. Int J Immunopharmacol.
711 Foulds G, Shepard RM, Johnson RB. (1990). The pharmacokinetics of azithromycin in human serum and tissues. J Antimicrob Chemother.
712 Furukawa M, Sakashita H, Ohoka H, et al. (1990). Osteomyelitis of temporal bone associated with tonsillar focal infection. Auris Nasus Larynx.
713 Gehanno P, Andrews JM, Ichou F, et al. (1990). Concentrations of cefpodoxime in plasma and tonsillar tissue after a single oral dose of cefpodoxime proxetil. J Antimicrob Chemother.
714 Gerber MA, Facklam RR, Randolph MF, et al. (1990). New colorimetric test for rapid diagnosis of streptococcal pharyngitis: a warning. Pediatrics.
715 Gherini S. (1990). Smokeless electrocautery tonsillectomy. Ear Nose Throat J.
716 Ginzburg AS, Onal E, Aronson RM, et al. (1990). Successful use of nasal-CPAP for obstructive sleep apnea in Hunter syndrome with diffuse airway involvement. Chest.
717 Gluckman JL, Robbins KT, Fried MP. (1990). Cervical metastatic squamous carcinoma of unknown or occult primary source. Head Neck.
718 Grennan EM. (1990). The Somera case. NLN Publ.
719 Grillo HC, Mathisen DJ. (1990). Primary tracheal tumors: treatment and results. Ann Thorac Surg.
720 Grundfast K, Berkowitz R, Fox L. (1990). Outcome and complications following surgery for obstructive adenotonsillar hypertrophy in children with neuromuscular disorders. Ear Nose Throat J.
721 Guarisco JL, Littlewood SC, Butcher RB. (1990). Severe upper airway obstruction in children secondary to lingual tonsil hypertrophy. Ann Otol Rhinol Laryngol.
722 Guida RA, Mattucci KF. (1990). Tonsillectomy and adenoidectomy: an inpatient or outpatient procedure?. Laryngoscope.
723 Guida RA, Mattucci KF. (1990). Tonsil and adenoid surgery as an out-patient procedure: is it safe?. Int Surg.
724 Haberman RS, Shattuck TG, Dion NM. (1990). Is outpatient suction cautery tonsillectomy safe in a community hospital setting?. Laryngoscope.
725 Harrison LB, Armstrong JG, Spiro RH, et al. (1990). Postoperative radiation therapy for major salivary gland malignancies. J Surg Oncol.
726 Heimdahl A, Hall G, Hedberg M, et al. (1990). Detection and quantitation by lysis-filtration of bacteremia after different oral surgical procedures. J Clin Microbiol.
727 Helmus C, Grin M, Westfall R. (1990). Same-day-stay adenotonsillectomy. Laryngoscope.
728 Hendrix RA, Bacon CK, Hoffer ME. (1990). Localization of the carotid artery within the tonsillar fossa by Doppler flow mapping. Laryngoscope.
729 Horst E, Meijer CJ, Duijvestijn AM, et al. (1990). The ontogeny of human lymphocyte recirculation: high endothelial cell antigen (HECA-452) and CD44 homing receptor expression in the development of the immune system. Eur J Immunol.
730 Iskandar HN, Fachruddin D, Hermani HB. (1990). Effectiveness of benzydamine mouthwash on post-tonsillectomy and acute pharyngitis/tonsillitis/tonsillopharyngitis: a randomized double controlled clinical trial. Oto Rhino Laryngologica Indonesiana.
731 Jones J, Handler SD, Guttenplan M, et al. (1990). The efficacy of cefaclor vs amoxicillin on recovery after tonsillectomy in children. Arch Otolaryngol Head Neck Surg.
732 Jones RA, Drexler HG, Gignac SM, et al. (1990). In vitro beta 2-microglobulin (beta 2m) secretion by normal and leukaemic B-cells: effects of recombinant cytokines and evidence for a differential response to the combined stimulus of phorbol ester and calcium ionophore. Br J Cancer.
733 Judd BA, Haycock GB, Dalton RN, et al. (1990). Antidiuretic hormone following surgery in children. Acta Paediatr Scand.
734 Kamel RH, Ishak EA. (1990). Enlarged adenoid and adenoidectomy in adults: endoscopic approach and histopathological study. J Laryngol Otol.
735 Kennedy KS, Strom CG. (1990). A comparison of postoperative bleeding incidence between general and local anesthesia tonsillectomies. Otolaryngol Head Neck Surg.
736 Kimura T, Fujiwara K, Kuki K, et al. (1990). HLA-DR antigen expression in tonsillar epithelium. With special reference to focal infection. Acta Otolaryngol.
737 Kleinerman RA, Littlefield LG, Tarone RE, et al. (1990). Chromosome aberrations in relation to radiation dose following partial-body exposures in three populations. Radiat Res.
738 Kraus DH, Roberts JK, Medendorp SV, et al. (1990). Nonsquamous cell malignancies of the paranasal sinuses. Ann Otol Rhinol Laryngol.
739 Lamy ME, Favart AM, Cornu C, et al. (1990). Epstein-Barr virus infection in 59 orthotopic liver transplant patients. Med Microbiol Immunol.
740 Lapicque F, Jankowski R, Netter P, et al. (1990). Drug assay in ground tissues: example of ketoprofen diffusion into tonsillar tissue. J Pharm Sci.
741 Levy M, Wong E, Fried D. (1990). Diseases that mimic meningitis. Analysis of 650 lumbar punctures. Clin Pediatr (Phila).
742 Linden BE, Gross CW, Long TE, et al. (1990). Morbidity in pediatric tonsillectomy. Laryngoscope.
743 Lopez O, Mimica I, Mimica LJ, et al. (1990). Lincomycin serum and tissue (tonsillar) levels in tonsillectomy patients after a single intramuscular preoperative 1.2-gm dose. Current Therapeutic Research - Clinical and Experimental.
744 Maggi G, Ardissone F, Cavallo A, et al. (1990). Tracheal stenosis. A study of 100 cases. Int Surg.
745 Manach Y, Ditisheim A. (1990). Double-blind, placebo-controlled multicentre trial of the efficacy and tolerance of morniflumate suppositories in the treatment of tonsillitis in children. J Int Med Res.
746 McCord AS. (1990). Teaching for tonsillectomies: details mean better compliance. Todays OR Nurse.
747 Milford CA, Sudderick RM, Bleach NR, et al. (1990). The influence of calcium alginate haemostatic swabs upon operative blood loss in adenotonsillectomy. Clin Otolaryngol Allied Sci.
748 Modi P, Steinberg J. (1990). Modern concepts of tonsillectomy. Can Fam Physician.
749 Morris HL, Wroblewski SK, Brown CK, et al. (1990). Velar-pharyngeal status in cleft palate patients with expected adenoidal involution. Ann Otol Rhinol Laryngol.
750 Murthy PS, Hazarika P, Mathai M, et al. (1990). Elongated styloid process: an overview. Int J Oral Maxillofac Surg.
751 Murty GE, Watson MG. (1990). Diathermy haemostasis at tonsillectomy: current practice--a survey of U.K. otolaryngologists. J Laryngol Otol.
752 Neilly IJ, Dawson AA, Russell D, et al. (1990). Non-Hodgkins lymphoma of the head and neck: experience in the Grampian area. J Laryngol Otol.
753 Nigam A, Ahmed K, Drake-Lee AB. (1990). The value of preoperative estimation of haemoglobin in children undergoing tonsillectomy. Clin Otolaryngol Allied Sci.
754 Nofal F, Moran MM. (1990). Long distance travel by children for tonsillectomy: experience of the ORL department at Princess Alexandra Hospital (PAH), Royal Air Force, Wroughton, Swindon. J Laryngol Otol.
755 Oas RE, Bartels JP. (1990). KTP-532 laser tonsillectomy: a comparison with standard technique. Laryngoscope.
756 O'Connor G, Riding K, Laird B, et al. (1990). Day care tonsillectomy: a study. Can J Anaesth.
757 Pannbacker M. (1990). Speech defects as an unusual complication of adenotonsillectomy. Ear Nose Throat J.
758 Pannbacker M, Lass NJ, Stout BM. (1990). Speech-language pathologists' opinions on the management of velopharyngeal insufficiency. Cleft Palate J.
759 Paradise JL, Bluestone CD, Rogers KD, et al. (1990). Efficacy of adenoidectomy for recurrent otitis media in children previously treated with tympanostomy-tube placement. Results of parallel randomized and nonrandomized trials. JAMA.
760 Parikh SR, Ensing GJ, Hurwitz RA. (1990). Transient myocardial wall motion abnormalities in a child: the phenomenon of “stunning”. Am Heart J.
761 Petersen RJ. (1990). Sucralfate and nasal synechiae. Ear Nose Throat J.
762 Petruzzelli GJ, Johnson JT. (1990). Peritonsillar abscess. Why aggressive management is appropriate. Postgrad Med.
763 Pinto A, Hutchison RE, Grant LH, et al. (1990). Follicular lymphomas in pediatric patients. Mod Pathol.
764 Ponka A. (1990). Absenteeism and respiratory disease among children and adults in Helsinki in relation to low-level air pollution and temperature. Environ Res.
765 Qvarnberg Y, Kantola O, Valtonen H, et al. (1990). Bacterial findings in middle ear effusion in children. Otolaryngol Head Neck Surg.
766 Reiner SA, Sawyer WP, Clark KF, et al. (1990). Safety of outpatient tonsillectomy and adenoidectomy. Otolaryngol Head Neck Surg.
767 Roos K, Brorson JE. (1990). Concentration of phenoxymethylpenicillin in tonsillar tissue. Eur J Clin Pharmacol.
768 Roos K, Lind L. (1990). Peritonsillar abscess in spite of adequately performed tonsillectomy. Arch Otolaryngol Head Neck Surg.
769 Rosenfeld RM, Green RP. (1990). Tonsillectomy and adenoidectomy: changing trends. Ann Otol Rhinol Laryngol.
770 Sauvage JP, Ditisheim A, Bessede JP, et al. (1990). Double-blind, placebo-controlled, multi-centre trial of the efficacy and tolerance of niflumic acid (‘Nifluril’) capsules in the treatment of tonsillitis in adults. Curr Med Res Opin.
771 Scadding GK. (1990). Immunology of the tonsil: a review. J R Soc Med.
772 Scaglione F, Falchi M, Ferrara F, et al. (1990). Cefonicid distribution into tonsillar tissue. Int J Clin Pharmacol Res.
773 Scaglione F, Falchi M, Nebuloni R, et al. (1990). Miocamycin distribution in tonsillar and pulmonary tissues after repeated administration. J Chemother.
774 Schafer J, Pirsig W. (1990). Digital signal analysis of snoring sounds in children. Int J Pediatr Otorhinolaryngol.
775 Schmidt JL, Yaremchuk KL, Mickelson SA. (1990). Abnormal coagulation profiles in tonsillectomy and adenoidectomy patients. Henry Ford Hosp Med J.
776 Schwarz R, Hubener KH. (1990). Fast neutron radiotherapy for advanced malignant tumors of the paranasal sinuses. Strahlenther Onkol.
777 Sen AK, Gupta B. (1990). Herniation of RAE tube through split Boyle Davis gag. Anaesth Intensive Care.
778 Shepard JW, Olsen KD. (1990). Uvulopalatopharyngoplasty for treatment of obstructive sleep apnea. Mayo Clin Proc.
779 Sher AE. (1990). Surgery for obstructive sleep apnea. Prog Clin Biol Res.
780 Shima N, Kobashi Y, Tsutsui K, et al. (1990). Extranodal non-Hodgkin's lymphoma of the head and neck. A clinicopathologic study in the Kyoto-Nara area of Japan. Cancer.
781 Sirimanna KS, Madden GJ, Miles SM. (1990). The use of long-acting penicillin in the prophylaxis of recurrent tonsillitis. J Otolaryngol.
782 Smalley PJ. (1990). Lasers in otolaryngology. Nurs Clin North Am.
783 Smith PS, Orchard PJ, Lekas MD. (1990). Predicting bleeding in common ear, nose, and throat procedures: a prospective study. R I Med J.
784 Sorri M, Laitakari K, Vainio-Mattila J, et al. (1990). Immediate correction of congenital nasal deformities; follow-up of 8 years. Int J Pediatr Otorhinolaryngol.
785 Splinter WM, MacNeill HB, Menard EA, et al. (1990). The effect of general anaesthesia on post-tonsillectomy pain and respiratory status. Can J Anaesth.
786 Splinter WM, Rhine EJ, MacNeill HB, et al. (1990). The effect of general anaesthesia on post-tonsillectomy vomiting. Can J Anaesth.
787 Stenfors LE, Raisanen S. (1990). Occurrence of middle ear pathogens in the nasopharynx of young individuals. A quantitative study in four age groups. Acta Otolaryngol.
788 Stevens MH. (1990). Laser surgery of tonsils, adenoids, and pharynx. Otolaryngol Clin North Am.
789 Stevens MH. (1990). Effects of peritonsillar infiltration. Laryngoscope.
790 Stevenson EW, Turner GT, Sutton FD, et al. (1990). Prognostic significance of age and tonsillectomy in uvulopalatopharyngoplasty. Laryngoscope.
791 Stjernquist-Desatnik A, Prellner K, Schalen C. (1990). Colonization by Haemophilus influenzae and group A streptococci in recurrent acute tonsillitis and in tonsillar hypertrophy. Acta Otolaryngol.
792 Stradling JR, Thomas G, Warley AR, et al. (1990). Effect of adenotonsillectomy on nocturnal hypoxaemia, sleep disturbance, and symptoms in snoring children. Lancet.
793 Strunk CL, Nichols ML. (1990). A comparison of the KTP/532-laser tonsillectomy vs. traditional dissection/snare tonsillectomy. Otolaryngol Head Neck Surg.
794 Takagi T, Mikata A. (1990). Evolution and progression in malignant lymphoma of Waldeyer's ring: histopathological and immunohistochemical studies of three cases of total tonsillectomy. Jpn J Clin Oncol.
795 Timon CI, McAllister VA, Walsh M, et al. (1990). Changes in tonsillar bacteriology of recurrent acute tonsillitis: 1980 vs. 1989. Respir Med.
796 Tran L, Sidrys J, Sadeghi A, et al. (1990). Salivary gland tumors of the oral cavity. Int J Radiat Oncol Biol Phys.
797 van der Walt JH, Jacob R, Murrell D, et al. (1990). The perioperative effects of oral premedication in children. Anaesth Intensive Care.
798 Van Someren VH, Hibbert J, Stothers JK, et al. (1990). Identification of hypoxaemia in children having tonsillectomy and adenoidectomy. Clin Otolaryngol Allied Sci.
799 Vogt P, Frei U, Repp H, et al. (1990). Malignant tumours in renal transplant recipients receiving cyclosporin: survey of 598 first-kidney transplantations. Nephrol Dial Transplant.
800 Weber RS, Byers RM, Petit B, et al. (1990). Submandibular gland tumors. Adverse histologic factors and therapeutic implications. Arch Otolaryngol Head Neck Surg.
801 Weimert TA, Babyak JW, Richter HJ. (1990). Electrodissection tonsillectomy. Archives of otolaryngology--head & neck surgery.
802 Wilson PS, Snow DG, O'Connel J, et al. (1990). Role of routine fluid replacement in children undergoing tonsillectomy. J Laryngol Otol.
803 Wollner N, Mandell L, Filippa D, et al. (1990). Primary nasal-paranasal oropharyngeal lymphoma in the pediatric age group. Cancer.
804 Wood WE, Gibson W, Longo D. (1990). Moderation of morbidity following tonsillectomy and adenoidectomy: a study of awareness under anesthesia. International journal of pediatric otorhinolaryngology.
805 Wyatt HV. (1990). Incubation of poliomyelitis as calculated from the time of entry into the central nervous system via the peripheral nerve pathways. Rev Infect Dis.
806 (1991). Emergency adenotonsillectomy for acute airway obstruction. Anaesthesia.
807 Andersen LJ, Therkildsen MH, Ockelmann HH, et al. (1991). Malignant epithelial tumors in the minor salivary glands, the submandibular gland, and the sublingual gland. Prognostic factors and treatment results. Cancer.
808 Andreassen ML, Leeper HA, MacRae DL. (1991). Changes in vocal resonance and nasalization following adenoidectomy in normal children: preliminary findings. J Otolaryngol.
809 Anim JT, Dawlatly EE. (1991). Tuberculosis of the tonsil revisited. West Afr J Med.
810 Asano S, Akaike Y, Muramatsu T, et al. (1991). Necrotizing lymphadenitis: a clinicopathological and immunohistochemical study of four familial cases and five recurrent cases. Virchows Arch A Pathol Anat Histopathol.
811 Benjamin B, Harrison H, Overton J, et al. (1991). Routine fluid replacement in children undergoing tonsillectomy. J Laryngol Otol.
812 Benter SE. (1991). Perceived seriousness of children's surgery and family adaptability and cohesion. J Child Adolesc Psychiatr Ment Health Nurs.
813 Bertin L, Pons G, d'Athis P, et al. (1991). Randomized, double-blind, multicenter, controlled trial of ibuprofen versus acetaminophen (paracetamol) and placebo for treatment of symptoms of tonsillitis and pharyngitis in children. J Pediatr.
814 Blatt IM. (1991). Postoperative bleeding incidence after local anesthesia tonsillectomies. Otolaryngol Head Neck Surg.
815 Bodner EE, Browning GG, Chalmers FT, et al. (1991). Can meta-analysis help uncertainty in surgery for otitis media in children. J Laryngol Otol.
816 Bowen MB, Butch AW, Parvin CA, et al. (1991). Germinal center T cells are distinct helper-inducer T cells. Hum Immunol.
817 Brahams D. (1991). Negligence, extra blood transfusions, and risk of AIDS. Lancet.
818 Brodsky L, Nagy M, Volk M, et al. (1991). The relationship of tonsil bacterial concentration to surface and core cultures in chronic tonsillar disease in children. Int J Pediatr Otorhinolaryngol.
819 Brook I, Leyva F. (1991). Discrepancies in the recovery of group A beta-hemolytic streptococci from both tonsillar surfaces. Laryngoscope.
820 Brown TC. (1991). Lidocaine en aerosol apres l'amygdalectomie chez l'enfant. Can J Anaesth.
821 Buckley G, Hinton A. (1991). Otitis media with effusion in children shows a progressive resolution with time. Clin Otolaryngol Allied Sci.
822 Bussi M, Carlevato MT, Galeazzi E, et al. (1991). Immunological investigations on tonsillar and peripheral blood lymphocytes after adeno-tonsillectomy. Possible suggestions for phenotypical and functional differences. Acta Otolaryngol.
823 Butcher RD, Cushley W. (1991). Flow cytometric studies of IL-4-stimulated expression of the CD25 antigen by quiescent human B lymphocyte subpopulations. Immunology.
824 Carson DK, Council JR, Gravley JE. (1991). Temperament and family characteristics as predictors of children's reactions to hospitalization. J Dev Behav Pediatr.
825 Catlin FI, Grimes WJ. (1991). The effect of steroid therapy on recovery from tonsillectomy in children. Arch Otolaryngol Head Neck Surg.
826 Chang SE, Bhatia P, Johnson NW, et al. (1991). Ras mutations in United Kingdom examples of oral malignancies are infrequent. Int J Cancer.
827 Chevretton EB, Morrison GA. (1991). The hayfork: an aid to safer tonsillectomy. J Laryngol Otol.
828 Childs EW, Baugh RF, Diaz JA. (1991). Tonsillar abscess. J Natl Med Assoc.
829 Dean PW. (1991). Surgery of the tonsils. Probl Vet Med.
830 Derkay CS, Bray G, Milmoe GJ, et al. (1991). Adenotonsillectomy in children with sickle cell disease. South Med J.
831 Dixon-Wood VL, Williams WN, Seagle MB. (1991). Team acceptance of specific recommendations for the treatment of VPI as provided by speech pathologists. Cleft Palate Craniofac J.
832 Donn AS, Giles ML. (1991). Do children waiting for tonsillectomy grow out of their tonsillitis?. N Z Med J.
833 Duddy MJ, Williams B. (1991). Hindbrain migration after decompression for hindbrain hernia: a quantitative assessment using MRI. Br J Neurosurg.
834 Elbrond O, Hilberg O, Felding JU, et al. (1991). Acoustic rhinometry, used as a method to demonstrate changes in the volume of the nasopharynx after adenoidectomy. Clin Otolaryngol Allied Sci.
835 Ferguson JA, Goldacre MJ, Henderson J, et al. (1991). Workload trends in otolaryngology: some statistical observations from medical record linkage. Clin Otolaryngol Allied Sci.
836 Finkelstein Y, Talmi YP, Kravitz K, et al. (1991). Study of the normal and insufficient velopharyngeal valve by the “Forced Sucking Test”. Laryngoscope.
837 Foulds G, Chan KH, Johnson JT, et al. (1991). Concentrations of azithromycin in human tonsillar tissue. Eur J Clin Microbiol Infect Dis.
838 Fraschini F, Scaglione F, Pintucci G, et al. (1991). The diffusion of clarithromycin and roxithromycin into nasal mucosa, tonsil and lung in humans. J Antimicrob Chemother.
839 Freeman SB, Hamaker RC, Singer MI, et al. (1991). Intraoperative radiotherapy of skull base cancer. Laryngoscope.
840 Fritsch G, Emminger W, Buchinger P, et al. (1991). CD34-positive cell proportions in peripheral blood correlate with colony-forming capacity. Exp Hematol.
841 Froom J, Culpepper L. (1991). Otitis media in day-care children. A report from the International Primary Care Network. J Fam Pract.
842 Fyllingen G, Arnesen AR, Biermann C, et al. (1991). Phenoxymethylpenicillin two or three times daily for tonsillitis with beta-haemolytic streptococci group A: a blinded, randomized and controlled clinical study. Scand J Infect Dis.
843 Fyllingen G, Arnesen AR, Ronnevig J. (1991). Phenoxymethylpenicillin two or three times daily in bacterial upper respiratory tract infections: a blinded, randomized and controlled clinical study. Scand J Infect Dis.
844 Gaffney RJ, Freeman DJ, Walsh MA, et al. (1991). Differences in tonsil core bacteriology in adults and children: a prospective study of 262 patients. Respir Med.
845 Gallo O, De Carli M, Gallina E, et al. (1991). T lymphocytes from tonsil and peripheral blood show different cytolytic and helper activities. Acta Otolaryngol.
846 Gledovic Z, Radovanovic Z. (1991). History of tonsillectomy and appendectomy in Hodgkin's disease. Eur J Epidemiol.
847 Harris WE. (1991). Is a single quinsy an indication for tonsillectomy?. Clin Otolaryngol Allied Sci.
848 Henningsson G, Isberg A. (1991). Comparison between multiview videofluoroscopy and nasendoscopy of velopharyngeal movements. Cleft Palate Craniofac J.
849 Hodson AH. (1991). Immunology of the tonsils. J R Soc Med.
850 Hultcrantz E, Larson M, Hellquist R, et al. (1991). The influence of tonsillar obstruction and tonsillectomy on facial growth and dental arch morphology. Int J Pediatr Otorhinolaryngol.
851 Hultcrantz E, Svanholm H. (1991). Down syndrome and sleep apnea--a therapeutic challenge. Int J Pediatr Otorhinolaryngol.
852 Ikeda T, Daimaru N, Inutsuka S, et al. (1991). Adverse effect of chronic tonsillitis on clinical course of sarcoidosis. Sarcoidosis.
853 Jebeles JA, Reilly JS, Gutierrez JF, et al. (1991). The effect of pre-incisional infiltration of tonsils with bupivacaine on the pain following tonsillectomy under general anesthesia. Pain.
854 Jennings LK, Wang WC, Jackson CW, et al. (1991). Hemostasis in Glanzmann's thrombasthenia (GT): GT platelets interfere with the aggregation of normal platelets. Am J Pediatr Hematol Oncol.
855 Jensen JH, Larsen SB. (1991). Treatment of recurrent acute tonsillitis with clindamycin. An alternative to tonsillectomy?. Clin Otolaryngol Allied Sci.
856 Jetlund O, Thurmann-Nielsen E, Walstad RA. (1991). Comparison of the serum and tissue concentrations of cefuroxime from cefuroxime axetil and phenoxymethylpenicillin in patients undergoing tonsillectomy. Int J Clin Pharmacol Res.
857 Jung TT, Rhee CK. (1991). Otolaryngologic approach to the diagnosis and management of otitis media. Otolaryngol Clin North Am.
858 Kane WJ, McCaffrey TV, Olsen KD, et al. (1991). Primary parotid malignancies. A clinical and pathologic review. Arch Otolaryngol Head Neck Surg.
859 Kearns DB, Pransky SM, Seid AB. (1991). Current concepts in pediatric adenotonsillar disease. Ear Nose Throat J.
860 Khalifa MS, Kamel RH, Zikry MA, et al. (1991). Effect of enlarged adenoids on arterial blood gases in children. J Laryngol Otol.
861 Klein JO. (1991). Prevention of acute otitis media. Seminars in Hearing.
862 Kobrinsky NL, Israels ED, Bickis MG. (1991). Synergistic shortening of the bleeding time by desmopressin and ethamsylate in patients with various constitutional bleeding disorders. Am J Pediatr Hematol Oncol.
863 Kohno K, Sakaki S, Nakamura H, et al. (1991). Foramen magnum decompression for syringomyelia associated with basilar impression and Chiari I malformation--report of three cases. Neurol Med Chir (Tokyo).
864 Konarzewski W, Walker P, Donovan A. (1991). Upper airway obstruction by enlarged tonsils. Anaesthesia.
865 Kornblut A, Kornblut AD. (1991). Tonsillectomy and adenoidectomy. Otolaryngology.
866 Kotecha B, O'Leary G, Bradburn J, et al. (1991). Pain relief after tonsillectomy in adults: intramuscular diclofenac and papaveretum compared. Clin Otolaryngol Allied Sci.
867 Laing MR, McKerrow WS. (1991). Adult tonsillectomy. Clin Otolaryngol Allied Sci.
868 Levin PS, Dutton JJ. (1991). A 20-year series of orbital exenteration. Am J Ophthalmol.
869 Limpens J, de Jong D, van Krieken JH, et al. (1991). Bcl-2/JH rearrangements in benign lymphoid tissues with follicular hyperplasia. Oncogene.
870 Livesey JR, Solomons NB, Gillies EA. (1991). Emergency adenotonsillectomy for acute postoperative upper airway obstruction. Anaesthesia.
871 Lockhart R, Parker GS, Tami TA. (1991). Role of quinsy tonsillectomy in the management of peritonsillar abscess. Ann Otol Rhinol Laryngol.
872 Loftin LH. (1991). Current treatment of otitis media in children. Ala Med.
873 Lorenzen A, Okey AB. (1991). Detection and characterization of Ah receptor in tissue and cells from human tonsils. Toxicol Appl Pharmacol.
874 Maloney RW. (1991). Contact Nd:YAG tonsillectomy: effects on weight loss and recovery. Lasers Surg Med.
875 Marcus CL, Keens TG, Bautista DB, et al. (1991). Obstructive sleep apnea in children with Down syndrome. Pediatrics.
876 Martin NG, Kehren U, Battistutta D, et al. (1991). Iatrogenic influences on the heritability of childhood tonsillectomy: cohort differences in twin concordance. Acta Genet Med Gemellol (Roma).
877 Martins RH, Heshiki Z, Luchesi NR, et al. (1991). Actinomycosis and botryomycosis of the tonsil. Auris Nasus Larynx.
878 Mather CM. (1991). Paediatric blood pressure and anaesthesia. Anaesthesia.
879 Milatovic D. (1991). Evaluation of cefadroxil, penicillin and erythromycin in the treatment of streptococcal tonsillopharyngitis. Pediatr Infect Dis J.
880 Miura M, Nomoto Y, Sakai H. (1991). Renal manifestation of pustulosis palmaris et plantaris. Jpn J Med.
881 Nadal D, Albini B, Chen CY, et al. (1991). Distribution and engraftment patterns of human tonsillar mononuclear cells and immunoglobulin-secreting cells in mice with severe combined immunodeficiency: role of the Epstein-Barr virus. Int Arch Allergy Appl Immunol.
882 Nadal D, Albini B, Schlapfer E, et al. (1991). Tissue distribution of mucosal antibody-producing cells specific for respiratory syncytial virus in severe combined immune deficiency (SCID) mice engrafted with human tonsils. Clin Exp Immunol.
883 Nigam A, Robin PE. (1991). The role of bupivacaine in post-tonsillectomy pain. Clinical otolaryngology.
884 Nishimura M, Matsuda T, Hori Y. (1991). Mucha-Habermann disease resolves after tonsillectomy. Int J Dermatol.
885 Nordbladh I, Ohlander B, Bjorkman R. (1991). Analgesia in tonsillectomy: a double-blind study on pre and post-operative treatment with diclofenac. Clin Otolaryngol Allied Sci.
886 Nosek-Cenkowska B, Cheang MS, Pizzi NJ, et al. (1991). Bleeding/bruising symptomatology in children with and without bleeding disorders. Thromb Haemost.
887 Ogisi FO. (1991). Diathermy haemostasis at tonsillectomy. J Laryngol Otol.
888 Patel RI, Hannallah RS, Norden J, et al. (1991). Emergence airway complications in children: a comparison of tracheal extubation in awake and deeply anesthetized patients. Anesth Analg.
889 Perez CA, Carmichael T, Devineni VR, et al. (1991). Carcinoma of the tonsillar fossa: a nonrandomized comparison of irradiation alone or combined with surgery: long-term results. Head Neck.
890 Ponka A, Nurmi T, Salminen E, et al. (1991). Infections and other illnesses of children in day-care centers in Helsinki. I: Incidences and effects of home and day-care center variables. Infection.
891 Pransky SM, Feldman JI, Kearns DB, et al. (1991). Actinomycosis in obstructive tonsillar hypertrophy and recurrent tonsillitis. Arch Otolaryngol Head Neck Surg.
892 Prior AJ, Drake-Lee AB. (1991). Auditing the reliability of recall of patients for minor surgical procedures. Clin Otolaryngol Allied Sci.
893 Prusek W, Mohgoub MK, Podwysocka M, et al. (1991). Circulating immune complexes in Waldeyer's ring hypertrophy. Arch Immunol Ther Exp (Warsz).
894 Randell T, Saarnivaara L, Oikkonen M, et al. (1991). Oral atropine enhances the risk for acid aspiration in children. Acta Anaesthesiol Scand.
895 Rao VR, Joseph S, Mandalam KR, et al. (1991). Syringohydromyelia: radiological evaluation of 82 patients in a developing country. Clin Radiol.
896 Rasgon BM, Cruz RM, Hilsinger RL, et al. (1991). Infiltration of epinephrine in tonsillectomy: a randomized, prospective, double-blind study. Laryngoscope.
897 Riding K, Laird B, O'Connor G, et al. (1991). Daycare tonsillectomy and/or adenoidectomy at the British Columbia Children's Hospital. J Otolaryngol.
898 Riviere A, Becker J, Loning T. (1991). Comparative investigation of c-erbB2/neu expression in head and neck tumors and mammary cancer. Cancer.
899 Ruckenstein MJ, Macdonald RE, Clarke JT, et al. (1991). The management of otolaryngological problems in the mucopolysaccharidoses: a retrospective review. J Otolaryngol.
900 Sarker MH, Chowdhury RI, Rashid HU. (1991). Study of proteinuria in a community. Bangladesh Med Res Counc Bull.
901 Serraino D, Franceschi S, Talamini R, et al. (1991). Socio-economic indicators, infectious diseases and Hodgkin's disease. Int J Cancer.
902 Shapiro M. (1991). Prophylaxis in otolaryngologic surgery and neurosurgery: a critical review. Reviews of infectious diseases.
903 Sharma S, Rajani M, Mishra N, et al. (1991). Extracranial carotid artery aneurysms following accidental injury: ten years experience. Clin Radiol.
904 Sharp JF, Rogers MJ, Riad M, et al. (1991). Combined study to assess the role of calcium alginate swabs and ligation of the inferior tonsillar pole in the control of intra-operative blood loss during tonsillectomy. J Laryngol Otol.
905 Singh B. (1991). A safer transnasal technique for the management of bilateral choanal atresia. J Laryngol Otol.
906 Soderstrom M, Blomberg J, Christensen P, et al. (1991). Erythromycin and phenoxymethylpenicillin (penicillin V) in the treatment of respiratory tract infections as related to microbiological findings and serum C-reactive protein. Scand J Infect Dis.
907 Soderstrom M, Hovelius B, Prellner K. (1991). Respiratory tract infections in children with recurrent episodes as preschoolers. Acta Paediatr Scand.
908 Sorensen JA, Godballe C, Andersen NH, et al. (1991). Peritonsillar abscess: risk of disease in the remaining tonsil after unilateral tonsillectomy a chaud. J Laryngol Otol.
909 Spear RM, Yaster M, Berkowitz ID, et al. (1991). Preinduction of anesthesia in children with rectally administered midazolam. Anesthesiology.
910 Staffel JG, Weissler MC, Tyler EP, et al. (1991). The prevention of postoperative stridor and laryngospasm with topical lidocaine. Arch Otolaryngol Head Neck Surg.
911 Stanley RE. (1991). Parapharyngeal space tumours. Ann Acad Med Singapore.
912 Stenfors LE, Raisanen S. (1991). In vivo attachment of beta-haemolytic streptococci to tonsillar epithelial cells in health and disease. Acta Otolaryngol.
913 Stenfors LE, Raisanen S. (1991). Attachment of bacteria to tonsillar epithelium during acute tonsillitis. J Laryngol Otol.
914 Stenfors LE, Raisanen S, Rantala I. (1991). In vivo attachment of group A streptococci to tonsillar epithelium during acute tonsillitis. Scand J Infect Dis.
915 Stjernquist-Desatnik A, Prellner K, Schalen C. (1991). High recovery of Haemophilus influenzae and group A streptococci in recurrent tonsillar infection or hypertrophy as compared with normal tonsils. J Laryngol Otol.
916 Stovroff MC, Coran AG, Hutchinson RJ. (1991). The role of surgery in American Burkitt's lymphoma in children. J Pediatr Surg.
917 Theopold HM, Matthias C, Adam D. (1991). Cefpodoxime proxetil concentrations in head and neck tissues. Infection.
918 Thompson AC. (1991). Adult tonsillectomy--results and patient selection. J Laryngol Otol.
919 Timon CI, Cafferkey M, Walsh M. (1991). Infection of Waldeyer's ring: value of pernasal retropharyngeal swabs. J Otolaryngol.
920 Timon CI, Cafferkey MT, Walsh M. (1991). Fine-needle aspiration in recurrent tonsillitis. Arch Otolaryngol Head Neck Surg.
921 Vig PS, Spalding PM, Lints RR. (1991). Sensitivity and specificity of diagnostic tests for impaired nasal respiration. Am J Orthod Dentofacial Orthop.
922 Wagner GA. (1991). Ambulatory adult tonsillectomy. J Otolaryngol.
923 Walther-Larsen S, Sloth M, Valentin N. (1991). Arterial desaturation in healthy children during and after minor surgery. Acta Anaesthesiol Scand.
924 Waters DJ, Michehl J, Shumate DR, et al. (1991). Round atelectasis in a 20-year-old woman. Chest.
925 Waters VV, Cook L. (1991). Group C beta-hemolytic streptococci in college students with pharyngitis. Jama.
926 Watson C. (1991). Prolonged use of a surgical retractor causing neuropathy in an assistant. J R Coll Surg Edinb.
927 Weider DJ, Sateia MJ, West RP. (1991). Nocturnal enuresis in children with upper airway obstruction. Otolaryngol Head Neck Surg.
928 Wiatrak BJ, Myer CM, Andrews TM. (1991). Complications of adenotonsillectomy in children under 3 years of age. Am J Otolaryngol.
929 Williams EF, Woo P, Miller R, et al. (1991). The effects of adenotonsillectomy on growth in young children. Otolaryngol Head Neck Surg.
930 Woodside DG, Linder-Aronson S, Lundstrom A, et al. (1991). Mandibular and maxillary growth after changed mode of breathing. Am J Orthod Dentofacial Orthop.
931 Yentis SM, Bissonnette B. (1991). P6 acupuncture and postoperative vomiting after tonsillectomy in children. Br J Anaesth.
932 (1992). Snoring children, sleep apnoea, and tonsillectomy. Drug Ther Bull.
933 Agocs MM, Rudnai P, Etzel RA. (1992). Respiratory disease surveillance in Hungary. MMWR CDC Surveill Summ.
934 Ahlqvist-Rastad J, Hultcrantz E, Melander H, et al. (1992). Body growth in relation to tonsillar enlargement and tonsillectomy. Int J Pediatr Otorhinolaryngol.
935 Alsawaf MM, Garlapo DA. (1992). Influence of tooth contact on the path of condylar movements. J Prosthet Dent.
936 Andersen JS, Borrild NJ, Renneberg J. (1992). An evaluation of a commercial co-agglutination test for the diagnosis of group A streptococcal tonsillitis in a family practice. Scand J Prim Health Care.
937 Arguello A. (1992). An open non-comparative pilot study of the safety and efficacy of oral sultamicillin in the treatment of mild to moderate upper respiratory tract infections in children. J Int Med Res.
938 Aycock WL. (1992). Tonsillectomy and poliomyelitis. I. Epidemiologic considerations. 1942. Medicine (Baltimore).
939 Baer GA, Rorarius MG, Kolehmainen S, et al. (1992). The effect of paracetamol or diclofenac administered before operation on postoperative pain and behaviour after adenoidectomy in small children. Anaesthesia.
940 Bath AP, Murty GE, Bradley PJ. (1992). Branchial cyst--to endoscope or not?. J Laryngol Otol.
941 Battistini A, Pisi G, Ferri T. (1992). Alveolar hypoventilation due to adenoid and tonsillar hypertrophy. Adv Otorhinolaryngol.
942 Becker SP, Roberts N, Coglianese D. (1992). Endoscopic adenoidectomy for relief of serous otitis media. Laryngoscope.
943 Benjamin B. (1992). Guidelines on tonsillectomy and adenoidectomy. J Paediatr Child Health.
944 Bennett JD, Young JR. (1992). Draffin and his rods. J Laryngol Otol.
945 Bernstein JM, Sendor S, Wactawski-Wende J. (1992). Antigen-presenting cells in the nasopharyngeal tonsil. A quantitative immunohistochemical study. Adv Otorhinolaryngol.
946 Berry CB, Irwin MG, Best CJ, et al. (1992). Intravenous diclofenac for analgesia after adenotonsillectomy in children. The Journal of the Pain Society.
947 Bluestone CD. (1992). Current indications for tonsillectomy and adenoidectomy. Ann Otol Rhinol Laryngol Suppl.
948 Boesen T, Jensen F. (1992). Preoperative ultrasonographic verification of peritonsillar abscesses in patients with severe tonsillitis. Eur Arch Otorhinolaryngol.
949 Bradford R, Spinks P. (1992). Child distress during hospitalization: implications for practice. Clin Otolaryngol Allied Sci.
950 Brodie C, Domenico J, Mazer BD, et al. (1992). Ethanol inhibits ligand-activated Ca2+ channels in human B lymphocytes. J Cell Physiol.
951 Brodsky L, Koch RJ. (1992). Anatomic correlates of normal and diseased adenoids in children. Laryngoscope.
952 Brookstone MS, Huvos AG. (1992). Central salivary gland tumors of the maxilla and mandible: a clinicopathologic study of 11 cases with an analysis of the literature. J Oral Maxillofac Surg.
953 Bueno de Mesquita HB, Maisonneuve P, Moerman CJ, et al. (1992). Aspects of medical history and exocrine carcinoma of the pancreas: a population-based case-control study in The Netherlands. Int J Cancer.
954 Burk CD, Miller L, Handler SD, et al. (1992). Preoperative history and coagulation screening in children undergoing tonsillectomy. Pediatrics.
955 Candan S, Yuceturk AV, Muhtar H. (1992). The effect of peritonsillar infiltration on intra-operative blood loss in children. J Otolaryngol.
956 Cantani A. (1992). Arguments against routine adenotonsillectomy. Immunol Today.
957 Carabott JA, Javaheri Z, Keilty K, et al. (1992). Oral fluid intake in children following tonsillectomy and adenoidectomy. Pediatr Nurs.
958 Careddu P, Biolchini A, Alfano S, et al. (1992). Pidotimod in the prophylaxis of recurrent acute tonsillitis in childhood. Adv Otorhinolaryngol.
959 Carson DK, Gravley JE, Council JR. (1992). Children's prehospitalization conceptions of illness, cognitive development, and personal adjustment. Child Health Care.
960 Castillo M, Quencer RM, Dominguez R. (1992). Chiari III malformation: imaging features. AJNR Am J Neuroradiol.
961 Chambers FA, O'Leary E, Gormley PK, et al. (1992). Delayed profound respiratory depression after premedication with trimeprazine. Anaesthesia.
962 Chan MK, McGuire LJ, King W, et al. (1992). Cytodiagnosis of 112 salivary gland lesions. Correlation with histologic and frozen section diagnosis. Acta Cytol.
963 Charnock DR, Chapman GD, Taylor RE, et al. (1992). Recurrent tonsillitis. The role of Chlamydia and Mycoplasma. Arch Otolaryngol Head Neck Surg.
964 Chowdhury CR, Bricknell MC. (1992). The management of quinsy--a prospective study. J Laryngol Otol.
965 Choy AT, Su AP. (1992). Bipolar diathermy or ligation for haemostasis in tonsillectomy? A prospective study on post-operative pain. J Laryngol Otol.
966 Claesson BE, Svensson NG, Gotthardsson L, et al. (1992). A foodborne outbreak of group A streptococcal disease at a birthday party. Scand J Infect Dis.
967 Cohen LM, Koltai PJ, Scott JR. (1992). Lateral cervical radiographs and adenoid size: do they correlate?. Ear Nose Throat J.
968 Cohen SM, Laurito CE, Segil LJ. (1992). Examination of the hypopharynx predicts ease of laryngoscopic visualization and subsequent intubation: a prospective study of 665 patients. J Clin Anesth.
969 Cook JA, Murrant NJ, Evans KL, et al. (1992). A randomized comparison of three post-tonsillectomy diets. Clin Otolaryngol Allied Sci.
970 Cortesina G, Carlevato MT, Bussi M, et al. (1992). T-lymphocyte role in the immunological reactivity of palatine tonsil. Adv Otorhinolaryngol.
971 Cozzi LM, Megerian CA, Dugue C, et al. (1992). Pulmonary sequelae of intraparenchymal bismuth subgallate. Laryngoscope.
972 Dawes PJ, O'Keefe L, Adcock S. (1992). Informed consent: the assessment of two structured interview approaches compared to the current approach. J Laryngol Otol.
973 De Benedetto M, Cuda D, Leante M. (1992). Obstructive sleep apnea syndrome and A&T surgery. Adv Otorhinolaryngol.
974 De Cillis G, Inchingolo F, D'Urso M. (1992). Recurrent pharingotonsillitis: epidemiological observations at the Center of Preventive Medicine ORL USL BA/2. Clinical and anatomopathological situations. Adv Otorhinolaryngol.
975 Deeter RG, Kalman DL, Rogan MP, et al. (1992). Therapy for pharyngitis and tonsillitis caused by group A beta-hemolytic streptococci: a meta-analysis comparing the efficacy and safety of cefadroxil monohydrate versus oral penicillin V. Clin Ther.
976 Disney FA, Dillon H, Blumer JL, et al. (1992). Cephalexin and penicillin in the treatment of group A beta-hemolytic streptococcal throat infections. Am J Dis Child.
977 Disney FA, Hanfling MJ, Hausinger SA. (1992). Loracarbef (LY163892) vs. penicillin VK in the treatment of streptococcal pharyngitis and tonsillitis. Pediatr Infect Dis J.
978 Edstrom L, Larsson H, Larsson L. (1992). Neurogenic effects on the palatopharyngeal muscle in patients with obstructive sleep apnoea: a muscle biopsy study. J Neurol Neurosurg Psychiatry.
979 Ejlersen E, Andersen HB, Eliasen K, et al. (1992). A comparison between preincisional and postincisional lidocaine infiltration and postoperative pain. Anesth Analg.
980 El-Awad Mel H, Vijayakumar E, Malhotra RK. (1992). Native manual tonsillectomy: A dangerous practice in Asir. Ann Saudi Med.
981 el-Fakahany AF, Abdalla KF, Younis MS, et al. (1992). Tonsilar toxoplasmosis. J Egypt Soc Parasitol.
982 Elster AD, Chen MY. (1992). Chiari I malformations: clinical and radiologic reappraisal. Radiology.
983 Endo LH, Vassalo J, Leitao SR. (1992). Allergic tonsillitis. A histopathological study. Adv Otorhinolaryngol.
984 Feinmesser R, Miyazaki I, Cheung R, et al. (1992). Diagnosis of nasopharyngeal carcinoma by DNA amplification of tissue obtained by fine-needle aspiration. N Engl J Med.
985 Ferrari LR, Donlon JV. (1992). Metoclopramide reduces the incidence of vomiting after tonsillectomy in children. Anesth Analg.
986 Foong HB, Yassim M, Chia YC, et al. (1992). Streptococcal pharyngitis in a primary care clinic. Singapore Med J.
987 Francois M, Bingen E, Soussi T, et al. (1992). Bacteriology of tonsils in children: comparison between recurrent acute tonsillitis and tonsillar hypertrophy. Adv Otorhinolaryngol.
988 Freeman SB, Markwell JK. (1992). Sucralfate in alleviating post-tonsillectomy pain. Laryngoscope.
989 Friday GA, Paradise JL, Rabin BS, et al. (1992). Serum immunoglobulin changes in relation to tonsil and adenoid surgery. Ann Allergy.
990 Gaffney RJ, Walsh MA, McShane DP, et al. (1992). Post-tonsillectomy bacteraemia. Clin Otolaryngol Allied Sci.
991 Gates GA, Muntz HR, Gaylis B. (1992). Adenoidectomy and otitis media. Ann Otol Rhinol Laryngol Suppl.
992 Gerrard JM, Duta E, Nosek-Cenkowska B, et al. (1992). A role for prostacyclin in bruising symptomatology. Pediatrics.
993 Ghirardo R, Dus I. (1992). Adenotonsillectomy as correction of dentofacial growth and dysfunctions. Adv Otorhinolaryngol.
994 Graivier MH, Cohen SR, Kawamoto HK, et al. (1992). A new operation for velopharyngeal insufficiency: the palatoglossus myomucosal pharyngoplasty. Plast Reconstr Surg.
995 Grandis JR, Johnson JT, Vickers RM, et al. (1992). The efficacy of perioperative antibiotic therapy on recovery following tonsillectomy in adults: randomized double-blind placebo-controlled trial. Otolaryngol Head Neck Surg.
996 Grey P. (1992). Bupivacaine infiltration and post tonsillectomy pain. Aust J Otolaryngol.
997 Hashiguchi K, Ogawa H, Kazuyama Y. (1992). Seroprevalence of Chlamydia pneumoniae infections in otolaryngeal diseases. J Laryngol Otol.
998 Havaldar PV. (1992). Diphtheria in the eighties: experience in a south Indian district hospital. J Indian Med Assoc.
999 Henderson J, Goldacre MJ, Fairweather JM, et al. (1992). Conditions accounting for substantial time spent in hospital in children aged 1-14 years. Arch Dis Child.
1000 Higgins PM. (1992). Splenomegaly in acute infections due to group A streptococci and viruses. Epidemiol Infect.
1001 Hirota Y, Takeshita S, Ide S, et al. (1992). Various factors associated with the manifestation of influenza-like illness. Int J Epidemiol.
1002 Hirota Y, Takeshita S, Kataoka K, et al. (1992). Individual and environmental characteristics related to influenza-like illness among children: a school-based case-control study. Nihon Eiseigaku Zasshi.
1003 Hoffmann S. (1992). An algorithm for a selective use of throat swabs in the diagnosis of group A streptococcal pharyngo-tonsillitis in general practice. Scand J Prim Health Care.
1004 Honjo I, Fujita A, Kurata K, et al. (1992). Significance of adenoidectomy in the treatment of secretory otitis media. Adv Otorhinolaryngol.
1005 Hrabak A, Antoni F, Szabo MT, et al. (1992). Differences and similarities in the sensitivity of lymphocytic and macrophage plasma membrane to deoxycholate. Acta Microbiol Hung.
1006 Ikeda T, Hayashi S, Kamikawaji N, et al. (1992). Adverse effect of chronic tonsillitis on clinical course of sarcoidosis in relation to HLA distribution. Chest.
1007 Ingram DM, Roberts A, Nottage EM. (1992). Host factors and breast cancer growth characteristics. Eur J Cancer.
1008 Jolley J. (1992). Parent and child views of an ENT ward. Nurs Stand.
1009 Kaplan BA, Mascie-Taylor CG, Boldsen J. (1992). Birth order and health status in a British national sample. J Biosoc Sci.
1010 Karjalainen S, Rekola M, Stahlberg MR. (1992). Long-term effects of syrup medications for recurrent otitis media on the dental health of 6- to 8-year-old children. Caries Res.
1011 Keller C, Elliott W, Hubbell RN. (1992). Endotracheal tube safety during electrodissection tonsillectomy. Arch Otolaryngol Head Neck Surg.
1012 Kikuchi K. (1992). Effects of tonsillectomy. Adv Otorhinolaryngol.
1013 Kimata H, Yoshida A, Ishioka C, et al. (1992). Interleukin 8 (IL-8) selectively inhibits immunoglobulin E production induced by IL-4 in human B cells. J Exp Med.
1014 Koike Y, Takeichi K, Ishida T, et al. (1992). Measurement of mesopharyngeal pressure in patients with obstructive sleep apnea. Adv Otorhinolaryngol.
1015 Kuki K, Kimura T, Hayashi Y, et al. (1992). Focus tonsils and skin diseases with special reference to palmoplantar pustulosis. Adv Otorhinolaryngol.
1016 Kusakari C, Takasaka T, Nose M, et al. (1992). IgA1 localization in tonsillar follicular dendritic cells is characteristic of IgA nephropathy. Adv Otorhinolaryngol.
1017 Laurikainen E, Aitasalo K, Erkinjuntti M, et al. (1992). Sleep apnea syndrome in children--secondary to adenotonsillar hypertrophy?. Acta Otolaryngol Suppl.
1018 Leach J, Olson J, Hermann J, et al. (1992). Polysomnographic and clinical findings in children with obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
1019 Lenander-Lumikari M, Tenovuo J, Puhakka HJ, et al. (1992). Salivary antimicrobial proteins and mutans streptococci in tonsillectomized children. Pediatr Dent.
1020 Lusk RP. (1992). Surgical modalities other than ethmoidectomy. J Allergy Clin Immunol.
1021 Lusk RP. (1992). Endoscopic approach to sinus disease. J Allergy Clin Immunol.
1022 Macknin ML. (1992). Respiratory infections in children: What helps and what doesn't?. Postgrad Med.
1023 Mandel EM, Bluestone CD, Takahashi H, et al. (1992). Effect of adenoidectomy on eustachian tube function. Preliminary results of a randomized clinical trial. Adv Otorhinolaryngol.
1024 Marinoni A, Galioto GB, Mevio E, et al. (1992). The family physician and pathologies of the tonsils: therapeutic practices. Adv Otorhinolaryngol.
1025 Masuda Y, Tamura S, Sugiyama N. (1992). The effect of tonsillectomy and its postoperative clinical course in IgA nephropathy with chronic tonsillitis. Adv Otorhinolaryngol.
1026 Maw AR, Parker AJ, Lance GN, et al. (1992). The effect of parental smoking on outcome after treatment for glue ear in children. Clin Otolaryngol Allied Sci.
1027 McCarty J, Hernon Y, Linn L, et al. (1992). Loracarbef versus penicillin VK in the treatment of streptococcal pharyngitis and tonsillitis in adults. Clin Ther.
1028 McColley SA, April MM, Carroll JL, et al. (1992). Respiratory compromise after adenotonsillectomy in children with obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
1029 McGowan FX, Kenna MA, Fleming JA, et al. (1992). Adenotonsillectomy for upper airway obstruction carries increased risk in children with a history of prematurity. Pediatr Pulmonol.
1030 Mevio E, Giacobone E, Galioto P, et al. (1992). Evolution of the bacterial flora in recurrent adenotonsillitis. Therapeutic implications. Adv Otorhinolaryngol.
1031 Moller P, Dingsor G, Breck P, et al. (1992). Transtympanic ventilator tubes in the treatment of seromucous otitis. Indications and results. Rev Laryngol Otol Rhinol (Bord).
1032 Moreno PM, Sanchez M, Sainz M, et al. (1992). Changes in immunological response in tonsillectomized children. II. Decreased cellular response. Clin Otolaryngol Allied Sci.
1033 Moriyama I, Nobori T, Nishizano H, et al. (1992). A new instrument for use with Nd:YAG in tonsillectomy. J Clin Laser Med Surg.
1034 Muller O, Spirer Z, Wettich K. (1992). Loracarbef versus penicillin V in the treatment of streptococcal pharyngitis and tonsillitis. Infection.
1035 Nadal D, Albini B, Schlapfer E, et al. (1992). Role of Epstein-Barr virus and interleukin 6 in the development of lymphomas of human origin in SCID mice engrafted with human tonsillar mononuclear cells. J Gen Virol.
1036 Nadal D, Soh N, Schlapfer E, et al. (1992). Distribution characteristics of immunoglobulin-secreting cells in adenoids. Relationship to age and disease. Int J Pediatr Otorhinolaryngol.
1037 Nish M. (1992). The rate of tonsillectomies in Saskatchewan. Concern.
1038 Ohga S, Okada K, Mitsui K, et al. (1992). Outbreaks of group A beta-hemolytic streptococcal pharyngitis in children: correlation of serotype T4 with scarlet fever. Scand J Infect Dis.
1039 Okayama Y, Church MK. (1992). Comparison of the modulatory effect of ketotifen, sodium cromoglycate, procaterol and salbutamol in human skin, lung and tonsil mast cells. Int Arch Allergy Immunol.
1040 O'Sullivan DG, Sherman IW, Phillips DE. (1992). The role of calcium alginate swabs in adenotonsillectomy. Clin Otolaryngol Allied Sci.
1041 Oswal VH, Bingham BJ. (1992). A pilot study of the holmium YAG laser in nasal turbinate and tonsil surgery. J Clin Laser Med Surg.
1042 Oudjhane K, Bowen A, Oh KS, et al. (1992). Pulmonary edema complicating upper airway obstruction in infants and children. Can Assoc Radiol J.
1043 Pamaar CG, Ahmad I, Marsh NJ. (1992). Accidental burn during tonsillectomy. Anesthesiology.
1044 Paradise JL. (1992). Etiology and management of pharyngitis and pharyngotonsillitis in children: a current review. Ann Otol Rhinol Laryngol Suppl.
1045 Parker AJ, Powell JE, Maw AR. (1992). Nasal mucociliary clearance and resolution of otitis media with effusion in children following adenoidectomy. Rhinology.
1046 Parker GS, Tami TA. (1992). The management of peritonsillar abscess in the 90s: an update. Am J Otolaryngol.
1047 Pascual J, Oterino A, Berciano J. (1992). Headache in type I Chiari malformation. Neurology.
1048 Patel KS, Reynolds C, Oyarzabal MF. (1992). Influence of methods of haemostasis on the microbiology of the post-tonsillectomy fossa. Adv Otorhinolaryngol.
1049 Pedersen D, Overgaard J, Sogaard H, et al. (1992). Malignant parotid tumors in 110 consecutive patients: treatment results and prognosis. Laryngoscope.
1050 Pestalozza G, Tessitore E, Bellotto R, et al. (1992). Tonsil surgery in heavy snoring young children. Adv Otorhinolaryngol.
1051 Pichichero ME. (1992). Culture and antigen detection tests for streptococcal tonsillopharyngitis. Am Fam Physician.
1052 Pignatari S, Smith EM, Gray SD, et al. (1992). Detection of human papillomavirus infection in diseased and nondiseased sites of the respiratory tract in recurrent respiratory papillomatosis patients by DNA hybridization. Ann Otol Rhinol Laryngol.
1053 Potsic WP. (1992). Assessment and treatment of adenotonsillar hypertrophy in children. Am J Otolaryngol.
1054 Ramet J, Pierard D, Vandenberghe P, et al. (1992). Comparative study of cefetamet pivoxil and penicillin V in the treatment of group A beta-hemolytic streptococcal pharyngitis. Chemotherapy.
1055 Ribeiro RC, Pui CH, Murphy SB, et al. (1992). Childhood malignant non-Hodgkin lymphomas of uncommon histology. Leukemia.
1056 Rihkanen H, Soini I. (1992). Changes in voice characteristics after uvulopalatopharyngoplasty. Eur Arch Otorhinolaryngol.
1057 Roberts C, Jayaramachandran S, Raine CH. (1992). A prospective study of factors which may predispose to post-operative tonsillar fossa haemorrhage. Clin Otolaryngol Allied Sci.
1058 Roos K, Holm SE, Grahn E, et al. (1992). Interfering alpha-streptococci as a protection against recurrent streptococcal pharyngotonsillitis. Adv Otorhinolaryngol.
1059 Rowe-Jones JM, Brockbank MJ. (1992). Parental smoking and persistent otitis media with effusion in children. Int J Pediatr Otorhinolaryngol.
1060 Sainz M, Gutierrez F, Moreno PM, et al. (1992). Changes in immunologic response in tonsillectomized children. I. Immunosuppression in recurrent tonsillitis. Clin Otolaryngol Allied Sci.
1061 Salam MA, Cable HR. (1992). Post-tonsillectomy pain with diathermy and ligation techniques. A prospective randomized study in children and adults. Clin Otolaryngol Allied Sci.
1062 Sale GE, Anderson P, Browne M, et al. (1992). Evidence of cytotoxic T-cell destruction of epidermal cells in human graft-vs-host disease. Immunohistology with monoclonal antibody TIA-1. Arch Pathol Lab Med.
1063 Saleh EM. (1992). Complications of treatment of recurrent laryngeal papillomatosis with the carbon dioxide laser in children. J Laryngol Otol.
1064 Samuels MP, Stebbens VA, Davies SC, et al. (1992). Sleep related upper airway obstruction and hypoxaemia in sickle cell disease. Arch Dis Child.
1065 Savay L, Jori J, Czigner J. (1992). Laser lingual tonsillotomy. Acta Chir Hung.
1066 Schilder AG, Zielhuis GA, Straatman HS, et al. (1992). An epidemiological approach to the etiology of middle ear disease in The Netherlands. Eur Arch Otorhinolaryngol.
1067 Shechtman FG, Lin PT, Pincus RL. (1992). Urgent adenotonsillectomy for upper airway obstruction. Int J Pediatr Otorhinolaryngol.
1068 Shido F, Hamamoto M, Kukuminato Y, et al. (1992). On arthropathy with special reference to sternocostoclavicular hyperostosis. Adv Otorhinolaryngol.
1069 Sigal R, Monnet O, de Baere T, et al. (1992). Adenoid cystic carcinoma of the head and neck: evaluation with MR imaging and clinical-pathologic correlation in 27 patients. Radiology.
1070 Singer JI. (1992). Evaluation of the patient with neck complaints following tonsillectomy or adenoidectomy. Pediatr Emerg Care.
1071 Singh B, Reddy FS. (1992). A safer anaesthetic airway for paediatric adenotonsillectomy. S Afr Med J.
1072 Smahel Z, Mullerova I. (1992). Nasopharyngeal characteristics in children with cleft lip and palate. Cleft Palate Craniofac J.
1073 Smith TC, Proops DW, Pearman K, et al. (1992). Hypoxia in sleeping children: overnight studies can be reduced to 4 hours without loss of clinical significance. Clin Otolaryngol Allied Sci.
1074 Smyth GD. (1992). Toynbee Memorial Lecture 1992: facts and fantasies in modern otology: the ear doctor's dilemma. J Laryngol Otol.
1075 Staskowski PA, McCaffrey TV. (1992). Effect of substance P on ciliary beat frequency in human adenoid explants. Otolaryngol Head Neck Surg.
1076 Stevenson DS, Webster G, Stewart IA. (1992). Acute tonsillectomy in the management of infectious mononucleosis. J Laryngol Otol.
1077 Takematsu H, Rokugo M, Takahashi K, et al. (1992). Juvenile generalized pustular psoriasis in a pair of monozygotic twins presenting strikingly similar clinical courses. Acta Derm Venereol.
1078 Talaat M. (1992). Pull-through branchial fistulectomy: a technique for the otolaryngologist. Ann Otol Rhinol Laryngol.
1079 Tan D. (1992). Treatment of fever due to exopathic wind-cold by rapid acupuncture. J Tradit Chin Med.
1080 Teculescu DB, Caillier I, Perrin P, et al. (1992). Snoring in French preschool children. Pediatr Pulmonol.
1081 Tewodros W, Muhe L, Daniel E, et al. (1992). A one-year study of streptococcal infections and their complications among Ethiopian children. Epidemiol Infect.
1082 Tom LW, DeDio RM, Cohen DE, et al. (1992). Is outpatient tonsillectomy appropriate for young children?. Laryngoscope.
1083 Touw-Otten FW, Johansen KS. (1992). Diagnosis, antibiotic treatment and outcome of acute tonsillitis: report of a WHO Regional Office for Europe study in 17 European countries. Fam Pract.
1084 Unlu Y, Tekalan SA, Cemiloglu R, et al. (1992). Guillotine and dissection tonsillectomy in children. J Laryngol Otol.
1085 Van Cauwenberge PB. (1992). Tonsillar hypertrophy and middle ear diseases. Adv Otorhinolaryngol.
1086 Wang D, Clement P, Kaufman L, et al. (1992). Fiberoptic examination of the nasal cavity and nasopharynx in children. Int J Pediatr Otorhinolaryngol.
1087 Wang HW, Chen HL, Wang JY. (1992). A histofluorescent study of sympathetic innervation of human palatine tonsils. Eur Arch Otorhinolaryngol.
1088 Ware RE, Filston HC. (1992). Surgical management of children with hemoglobinopathies. Surg Clin North Am.
1089 Watanabe T, Fujiyoshi T, Tomonaga K, et al. (1992). Adenoids and otitis media with effusion in children. Adv Otorhinolaryngol.
1090 Watcha MF, White PF. (1992). Postoperative nausea and vomiting. Its etiology, treatment, and prevention. Anesthesiology.
1091 Weiss LS, Butcher RB, White JA. (1992). Eagle's syndrome: the Ochsner experience. J La State Med Soc.
1092 Wennmo C, Olsson P, Flisberg K, et al. (1992). Treatment of snoring--with and without carbon dioxide laser. Acta Otolaryngol Suppl.
1093 Wetmore RF. (1992). Importance of maintaining normal nasal function in the cleft palate patient. Cleft Palate Craniofac J.
1094 Williams RG, Preece M, Rhys R, et al. (1992). The effect of adenoid and tonsil surgery on nasalance. Clin Otolaryngol Allied Sci.
1095 Winther B, Kawana R, Saito H. (1992). Fireside conference 11. Common cold. Rhinol Suppl.
1096 Wormald PJ, Prescott CA. (1992). Adenoids: comparison of radiological assessment methods with clinical and endoscopic findings. J Laryngol Otol.
1097 Wright JE, Rose GE, Garner A. (1992). Primary malignant neoplasms of the lacrimal gland. Br J Ophthalmol.
1098 Yadav RS, Yadav SP, Lal H. (1992). Serum immunoglobulin E levels in children with chronic tonsillitis. Int J Pediatr Otorhinolaryngol.
1099 Yamamoto Y, Okato S, Nishiyama M, et al. (1992). Function and morphology of macrophages in palatine tonsils. Adv Otorhinolaryngol.
1100 Yamanaka N, Matsuyama H, Harabuchi Y, et al. (1992). Distribution of lymphoid cells in tonsillar compartments in relation to infection and age. A quantitative study using image analysis. Acta Otolaryngol.
1101 Yu VY, Manlapaz ML, Tobin J, et al. (1992). Improving health status in extremely low birthweight children between two and five years. Early Hum Dev.
1102 (1993). Tonsillectomy and adenoidectomy in-hospital charges, 1991. Stat Bull Metrop Insur Co.
1103 Abdullah MA. (1993). Traditional practices and other socio-cultural factors affecting the health of children in Saudi Arabia. Ann Trop Paediatr.
1104 Ahmed K, McCormick MS, Baruah AK. (1993). Day-case adenoidectomy--is it safe?. Clin Otolaryngol Allied Sci.
1105 Andrea M. (1993). Microsurgical bipolar cautery tonsillectomy. Laryngoscope.
1106 Arnold JE, Allphin AL. (1993). Sleep apnea in the neurologically-impaired child. Ear Nose Throat J.
1107 Atkins K. (1993). Care in theater of a patient undergoing tonsillectomy. Br J Nurs.
1108 Banerjee AR, Soames JV, Birchall JP, et al. (1993). Ectopic salivary gland tissue in the palatine and lingual tonsil. Int J Pediatr Otorhinolaryngol.
1109 Begovac J, Bobinac E, Benic B, et al. (1993). Asymptomatic pharyngeal carriage of beta-haemolytic streptococci and streptococcal pharyngitis among patients at an urban hospital in Croatia. Eur J Epidemiol.
1110 Ben-David J, Podoshin L, Fradis M, et al. (1993). Is the vestibular system affected by middle ear effusion?. Otolaryngol Head Neck Surg.
1111 Bene MC, Hurault de Ligny B, Kessler M, et al. (1993). Tonsils in IgA nephropathy. Contrib Nephrol.
1112 Bene MC, Kahl L, Perruchet AM, et al. (1993). Bacterial lysates and ribosomes as inducers of specific immune responses: a comparative study. Scand J Immunol.
1113 Benson-Mitchell R, Maw AR. (1993). Assessment of sequelae at home following adenotonsillectomy. A basis for day-case management?. Clin Otolaryngol Allied Sci.
1114 Benton NC, Wolgat RA. (1993). Sudden cardiac arrest during adenotonsillectomy in a patient with subclinical Duchenne's muscular dystrophy. Ear Nose Throat J.
1115 Bergogne-Berezin E. (1993). Tissue distribution of dirithromycin: comparison with erythromycin. J Antimicrob Chemother.
1116 Bernstein JM, Faden HF, Dryja DM, et al. (1993). Micro-ecology of the nasopharyngeal bacterial flora in otitis-prone and non-otitis-prone children. Acta Otolaryngol.
1117 Bernstein JM, Rich GA, Odziemiec C, et al. (1993). Are thymus-derived lymphocytes (T cells) defective in the nasopharyngeal and palatine tonsils of children?. Otolaryngol Head Neck Surg.
1118 Blais R. (1993). Variations in surgical rates in Quebec: does access to teaching hospitals make a difference?. Cmaj.
1119 Brodsky L, Koch RJ. (1993). Bacteriology and immunology of normal and diseased adenoids in children. Arch Otolaryngol Head Neck Surg.
1120 Brodsky L, Radomski K, Gendler J. (1993). The effect of post-operative instructions on recovery after tonsillectomy and adenoidectomy. Int J Pediatr Otorhinolaryngol.
1121 Brook I, Foote PA, Slots J, et al. (1993). Immune response to Prevotella intermedia in patients with recurrent nonstreptococcal tonsillitis. Ann Otol Rhinol Laryngol.
1122 Buchholz TA, Shimotakahara SG, Weymuller EA, et al. (1993). Neutron radiotherapy for adenoid cystic carcinoma of the head and neck. Arch Otolaryngol Head Neck Surg.
1123 Burke P. (1993). Sore throat. Practitioner.
1124 Cafferkey MT, Timon CI, O'Regan M, et al. (1993). Effect of pre-operative antibiotic treatment on the bacterial content of the tonsil. Clin Otolaryngol Allied Sci.
1125 Carskadon MA, Pueschel SM, Millman RP. (1993). Sleep-disordered breathing and behavior in three risk groups: preliminary findings from parental reports. Childs Nerv Syst.
1126 Cheung WY, Chan AC, Loke SL, et al. (1993). Latent sites of Epstein-Barr virus infection. Am J Clin Pathol.
1127 Chumas PD, Armstrong DC, Drake JM, et al. (1993). Tonsillar herniation: the rule rather than the exception after lumboperitoneal shunting in the pediatric population. J Neurosurg.
1128 Clarke LA, Heppner J. (1993). Mucopolysaccharidosis Type I. Pagon RA, Adam MP, Ardinger HH, Wallace SE, Amemiya A, Bean LJH, et al., editors. GeneReviews(R).
1129 Close GR, Rushworth RL, Rob MI, et al. (1993). Variation in selected childhood surgical procedures: the case of tonsillectomy and management of middle ear disease. J Paediatr Child Health.
1130 Culpepper L, Froom J, Bartelds AI, et al. (1993). Acute otitis media in adults: a report from the International Primary Care Network. J Am Board Fam Pract.
1131 Cunningham MJ, Anonsen CK, Kinane B. (1993). Acquired laryngomalacia secondary to obstructive adenotonsillar hypertrophy. Am J Otolaryngol.
1132 Dagnelie CF, Touw-Otten FW, Kuyvenhoven MM, et al. (1993). Bacterial flora in patients presenting with sore throat in Dutch general practice. Fam Pract.
1133 Dajani AS, Kessler SL, Mendelson R, et al. (1993). Cefpodoxime proxetil vs. penicillin V in pediatric streptococcal pharyngitis/tonsillitis. Pediatr Infect Dis J.
1134 Das DK, Gulati A, Bhatt NC, et al. (1993). Fine needle aspiration cytology of oral and pharyngeal lesions. A study of 45 cases. Acta Cytol.
1135 De Melker RA. (1993). Treating persistent glue ear in children. Bmj.
1136 Dempster JH, Browning GG, Gatehouse SG. (1993). A randomized study of the surgical management of children with persistent otitis media with effusion associated with a hearing impairment. J Laryngol Otol.
1137 Derkay CS. (1993). Pediatric otolaryngology procedures in the United States: 1977-1987. Int J Pediatr Otorhinolaryngol.
1138 Ehrlich TP, Schwartz RH, Wientzen R, et al. (1993). Comparison of an immunochromatographic method for rapid identification of group A streptococcal antigen with culture method. Arch Fam Med.
1139 el-Sharkawi AM, Williams GT. (1993). Branchial cyst and cervical cystic metastases. J Laryngol Otol.
1140 Finkelstein Y, Bar-Ziv J, Nachmani A, et al. (1993). Peritonsillar abscess as a cause of transient velopharyngeal insufficiency. Cleft Palate Craniofac J.
1141 Finkelstein Y, Zohar Y, Nachmani A, et al. (1993). The otolaryngologist and the patient with velocardiofacial syndrome. Arch Otolaryngol Head Neck Surg.
1142 Forsgren J, Samuelson A, Lindberg A, et al. (1993). Quantitative bacterial culture from adenoid lymphatic tissue with special reference to Haemophilus [corrected]. Acta Otolaryngol.
1143 Friis H, Bro F, Eriksen NR, et al. (1993). The effect of reimbursement on the use of antibiotics. Scand J Prim Health Care.
1144 Gaffney R, Harrison M, Walsh M, et al. (1993). The incidence and role of actinomyces in recurrent acute tonsillitis. Clin Otolaryngol Allied Sci.
1145 Gaffney RJ, Timon CI, Freeman DF, et al. (1993). Bacteriology of tonsil and adenoid and sampling techniques of adenoidal bacteriology. Respir Med.
1146 Galetti G, Dallari S. (1993). Efficacy and tolerability of brodimoprim in pharyngotonsillitis in children. J Chemother.
1147 Gordts F, Clement PA, Derde MP. (1993). Lens tube vs Donaldson tube: results of a prospective study comparing a new with a conventional ventilation tube. Clin Otolaryngol Allied Sci.
1148 Griffin TC, Buchanan GR. (1993). Elective surgery in children with sickle cell disease without preoperative blood transfusion. J Pediatr Surg.
1149 Gronning M, Riise T, Kvale G, et al. (1993). Infections in childhood and adolescence in multiple sclerosis. A case-control study. Neuroepidemiology.
1150 Grounds M. (1993). Spontaneously remitting disease. Med J Aust.
1151 Grunwald Z, Torjman M, Schieren H, et al. (1993). The pharmacokinetics of droperidol in anesthetized children. Anesth Analg.
1152 Haapanen ML, Veija M, Pettay M. (1993). Speech outcome in cleft palate patients with simultaneous primary palatal repair and adenoidectomy. Acta Otolaryngol.
1153 Haeggstrom A, Gustafsson O, Engquist S, et al. (1993). Intraoral ultrasonography in the diagnosis of peritonsillar abscess. Otolaryngol Head Neck Surg.
1154 Hamill J. (1993). Multicentre evaluation of azithromycin and penicillin V in the treatment of acute streptococcal pharyngitis and tonsillitis in children. J Antimicrob Chemother.
1155 Han MH, Chang KH, Kim IO, et al. (1993). Non-Hodgkin lymphoma of the central skull base: MR manifestations. J Comput Assist Tomogr.
1156 Harada T, Sakagami M, Sano M, et al. (1993). Measurement of anaphylatoxin activity during surgery. Acta Otolaryngol Suppl.
1157 Hardy AM, Fowler MG. (1993). Child care arrangements and repeated ear infections in young children. Am J Public Health.
1158 Hemlin C, Carenfelt C, Hallden G, et al. (1993). Adenoid tissue lymphocyte subpopulations--evaluation of a quantitative analysis with flow cytometry. APMIS.
1159 Henderson J, Goldacre M, Yeates D. (1993). Use of hospital inpatient care in adolescence. Arch Dis Child.
1160 Herz G. (1993). Respiratory infections in children: when is brodimoprim indicated?. J Chemother.
1161 Hiller A. (1993). Comparison of cardiovascular changes during anaesthesia and recovery from propofol-alfentanil-nitrous oxide and thiopentone-halothane-nitrous oxide anaesthesia in children undergoing otolaryngological surgery. Acta Anaesthesiol Scand.
1162 Hinton AE, Herdman RC, Martin-Hirsch D, et al. (1993). Parental cigarette smoking and tonsillectomy in children. Clin Otolaryngol Allied Sci.
1163 Hoefakker S, van't Erve EH, Deen C, et al. (1993). Immunohistochemical detection of co-localizing cytokine and antibody producing cells in the extrafollicular area of human palatine tonsils. Clin Exp Immunol.
1164 Hotta O, Taguma Y, Kurosawa K, et al. (1993). Early intensive therapy for clinical remission of active IgA nephropathy: a three-year follow-up study. Nihon Jinzo Gakkai Shi.
1165 Iino Y, Ambe K, Kato Y, et al. (1993). Chronic tonsillitis and IgA nephropathy. Clinical study of patients with and without tonsillectomy. Acta Otolaryngol Suppl.
1166 Irving GA. (1993). Safety of non-steroidal anti-inflammatories before adenotonsillectomy. S Afr Med J.
1167 Jebeles JA, Reilly JS, Gutierrez JF, et al. (1993). Tonsillectomy and adenoidectomy pain reduction by local bupivacaine infiltration in children. Int J Pediatr Otorhinolaryngol.
1168 Johnson I. (1993). Day-case tonsillectomy--a public demand?. J Laryngol Otol.
1169 Jousimies-Somer H, Savolainen S, Makitie A, et al. (1993). Bacteriologic findings in peritonsillar abscesses in young adults. Clin Infect Dis.
1170 Kajanti MJ, Holsti LR. (1993). Radical surgery and postoperative split-course radiotherapy in squamous cell carcinoma of the head and neck--factors influencing local control and survival. Acta Oncol.
1171 Kavukcu S, Coskun S, Cevik N, et al. (1993). The importance of pulmonary function tests in adenotonsillectomy indications. Indian J Pediatr.
1172 Kawaguchi M, Sakai T, Sakamaki A, et al. (1993). Expanded primary T nodules in the palatine tonsils from patients with IgA nephropathy. Acta Otolaryngol Suppl.
1173 Kendrick D, Gibbin K. (1993). An audit of the complications of paediatric tonsillectomy, adenoidectomy and adenotonsillectomy. Clin Otolaryngol Allied Sci.
1174 Kimura H, Ohashi N, Nakagawa H, et al. (1993). Large tonsillolith mimicking peritonsillar abscess: a case report. Auris Nasus Larynx.
1175 Klimek L, Mosges R, Wein B, et al. (1993). Surgical or medical treatment of questionable peritonsillar abscess? The use of B-mode ultrasonography. Acta Otorhinolaryngol Belg.
1176 Kljakovic M. (1993). Sore throat presentation and management in general practice. N Z Med J.
1177 Koch RJ, Brodsky L. (1993). Effect of specific bacteria on lymphocyte proliferation in diseased and nondiseased tonsils. Laryngoscope.
1178 Kummer AW, Billmire DA, Myer CM. (1993). Hypertrophic tonsils: the effect on resonance and velopharyngeal closure. Plast Reconstr Surg.
1179 Kummer AW, Myer CM, Smith ME, et al. (1993). Changes in nasal resonance secondary to adenotonsillectomy. Am J Otolaryngol.
1180 Kusakari C, Takasaka T. (1993). Reconstitution of immunological imbalance in SCID mice given tonsillar mononuclear cells from patients with IgA nephropathy. Acta Otolaryngol Suppl.
1181 Lange De, Klerk E. (1993). Effects of homoeopathic medicines on children with recurrent upper respiratory tract infections. Unpublished dissertation.
1182 Lange de Klerk ESM. (1993). Effects of homeopathic medicines on children with recurrent upper respiratory tract infections. HomInt R&D Newsletter.
1183 Leach J, Manning S, Schaefer S. (1993). Comparison of two methods of tonsillectomy. Laryngoscope.
1184 Leighton SE, Rowe-Jones JM, Knight JR, et al. (1993). Day case adenoidectomy. Clin Otolaryngol Allied Sci.
1185 Linder-Aronson S, Woodside DG, Hellsing E, et al. (1993). Normalization of incisor position after adenoidectomy. Am J Orthod Dentofacial Orthop.
1186 Livesey JR. (1993). Are haematological tests warranted prior to tonsillectomy?. J Laryngol Otol.
1187 Lodge ML, Moore MH, Hanieh A, et al. (1993). The cloverleaf skull anomaly: managing extreme cranio-orbitofaciostenosis. Plast Reconstr Surg.
1188 Logemann JA, Pauloski BR, Rademaker AW, et al. (1993). Speech and swallow function after tonsil/base of tongue resection with primary closure. J Speech Hear Res.
1189 Mahmood K, Monck L, Osborne J, et al. (1993). Can audit improve the quality of care for routine tonsillectomy?. Clin Otolaryngol Allied Sci.
1190 Maw AR, Parker AJ. (1993). A model to refine the selection of children with otitis media with effusion for adenoidectomy. Clin Otolaryngol Allied Sci.
1191 Maw R, Bawden R. (1993). Spontaneous resolution of severe chronic glue ear in children and the effect of adenoidectomy, tonsillectomy, and insertion of ventilation tubes (grommets). BMJ.
1192 Mebrahtu YB, Hendricks LD, Oster CN, et al. (1993). Leishmania donovani parasites in the nasal secretions, tonsillopharyngeal mucosa, and urine centrifugates of visceral leishmaniasis patients in Kenya. Am J Trop Med Hyg.
1193 Meland E, Digranes A, Skjaerven R. (1993). Assessment of clinical features predicting streptococcal pharyngitis. Scand J Infect Dis.
1194 Milatovic D, Adam D, Hamilton H, et al. (1993). Cefprozil versus penicillin V in treatment of streptococcal tonsillopharyngitis. Antimicrob Agents Chemother.
1195 Moore MH. (1993). Upper airway obstruction in the syndromal craniosynostoses. Br J Plast Surg.
1196 Morikawa K, Oseko F, Morikawa S. (1993). Immunomodulatory effect of fosfomycin on human B-lymphocyte function. Antimicrob Agents Chemother.
1197 Muller O. (1993). Comparison of azithromycin versus clarithromycin in the treatment of patients with upper respiratory tract infections. J Antimicrob Chemother.
1198 Muller O, Wettich K. (1993). Clinical efficacy of dirithromycin in pharyngitis and tonsillitis. J Antimicrob Chemother.
1199 Nakamura T, Oishi M, Johno M, et al. (1993). Serum levels of interleukin 6 in patients with pustulosis palmaris et plantaris. J Dermatol.
1200 Nakamura T, Ono T, Aoki Y. (1993). Medullasin levels in neutrophils of patients with pustulosis palmaris et plantaris. J Dermatol.
1201 Nakatani M. (1993). The treatment of recurrent tonsillitis with Broncasma Berna instead of tonsillectomy. Arch Otolaryngol Head Neck Surg.
1202 Nayak DR, Murthy PS, Gopalakrishna RK, et al. (1993). Fibroma of the tonsil. J Indian Med Assoc.
1203 Nissel H. (1993). Pain treatment by means of acupuncture. Acupunct Electrother Res.
1204 Nyffenegger R, Riebenfeld D, Bandau KH, et al. (1993). A multicenter comparative study of brodimoprim and amoxicillin therapy in the treatment of tonsillopharyngitis in adults. J Chemother.
1205 Ophir D, Gilboa S, Halperin D, et al. (1993). Obstructing adenoids in adolescents: changing trends?. J Otolaryngol.
1206 Osujih M. (1993). Exploration of the frontiers of tradomedical practices: basis for development of alternative medical healthcare services in developing countries. J R Soc Health.
1207 Ovesen T, Paaske PB, Elbrond O. (1993). Accuracy of an automatic impedance apparatus in a population with secretory otitis media: principles in the evaluation of tympanometrical findings. Am J Otolaryngol.
1208 Pasquale G, Scaricabarozzi I, D'Agostino R, et al. (1993). An assessment of the efficacy and tolerability of nimesulide vs paracetamol in children after adenotonsillectomy. Drugs.
1209 Pauli RM. (1993). Achondroplasia. Pagon RA, Adam MP, Ardinger HH, Wallace SE, Amemiya A, Bean LJH, et al., editors. GeneReviews(R).
1210 Phippen ML. (1993). The magic of surgery. Semin Perioper Nurs.
1211 Pichichero ME. (1993). Cephalosporins are superior to penicillin for treatment of streptococcal tonsillopharyngitis: is the difference worth it?. Pediatr Infect Dis J.
1212 Polito E, Leccisotti A. (1993). Epithelial malignancies of the lacrimal gland: survival rates after extensive and conservative therapy. Ann Ophthalmol.
1213 Price SD, Hawkins DB, Kahlstrom EJ. (1993). Tonsil and adenoid surgery for airway obstruction: perioperative respiratory morbidity. Ear Nose Throat J.
1214 Prinsley P, Wood M, Lee CA. (1993). Adenotonsillectomy in patients with inherited bleeding disorders. Clin Otolaryngol Allied Sci.
1215 Quiding M, Granstrom G, Nordstrom I, et al. (1993). High frequency of spontaneous interferon-gamma-producing cells in human tonsils: role of local accessory cells and soluble factors. Clin Exp Immunol.
1216 Quisling RG, Quisling SG, Mickle JP. (1993). Obex/nucleus gracilis position: its role as a marker for the cervicomedullary junction. Pediatr Neurosurg.
1217 Radkowski D, McGill TJ, Healy GB, et al. (1993). Penetrating trauma of the oropharynx in children. Laryngoscope.
1218 Ren H, Bai G, Li ZJ, et al. (1993). Apoxesis of primary tracheal tumor. A clinical analysis of 23 cases. Chin Med J (Engl).
1219 Ren YF, Isberg A, Henningsson G. (1993). Interactive influence of a pharyngeal flap and an adenoid on maxillofacial growth in cleft lip and palate patients. Cleft Palate Craniofac J.
1220 Roos K, Grahn E, Holm SE, et al. (1993). Interfering alpha-streptococci as a protection against recurrent streptococcal tonsillitis in children. Int J Pediatr Otorhinolaryngol.
1221 Roos K, Holm SE, Grahn E, et al. (1993). Alpha-streptococci as supplementary treatment of recurrent streptococcal tonsillitis: a randomized placebo-controlled study. Scand J Infect Dis.
1222 Rorarius MG, Baer GA, Siirtola M, et al. (1993). Effect of intravenous diclofenac or indomethacin on the emergence from anaesthesia for tonsillectomy. Acta Anaesthesiol Scand.
1223 Ruggiero G, Utili R, Adinolfi LE, et al. (1993). Clinical efficacy of dirithromycin versus miocamycin in tonsillopharyngitis. J Antimicrob Chemother.
1224 Sadeghi A, Tran LM, Mark R, et al. (1993). Minor salivary gland tumors of the head and neck: treatment strategies and prognosis. Am J Clin Oncol.
1225 Salzberg R. (1993). A randomized, open, comparative study of brodimoprim versus erythromycin in patients with acute tonsillitis or bronchitis. J Chemother.
1226 Sarker AB, Akagi T, Yoshino T, et al. (1993). Bauhinia purpurea lectin (BPA) binding spectra in hyperplastic human tonsil and in peripheral blood: immunohistochemical, immunoelectron microscopic, and flow cytometric analyses. J Histochem Cytochem.
1227 Savolainen S, Jousimies-Somer HR, Makitie AA, et al. (1993). Peritonsillar abscess. Clinical and microbiologic aspects and treatment regimens. Arch Otolaryngol Head Neck Surg.
1228 Scarpa M. (1993). Mucopolysaccharidosis Type II. Pagon RA, Adam MP, Ardinger HH, Wallace SE, Amemiya A, Bean LJH, editors. GeneReviews(R).
1229 Schoem SR, Watkins GL, Kuhn JJ, et al. (1993). Control of early postoperative pain with bupivacaine in adult local tonsillectomy. Arch Otolaryngol Head Neck Surg.
1230 Schoem SR, Watkins GL, Kuhn JJ, et al. (1993). Control of early postoperative pain with bupivacaine in pediatric tonsillectomy. Ear Nose Throat J.
1231 Sennaroglu L, Onerci M, Hascelik G. (1993). The effect of tonsillectomy and adenoidectomy on neutrophil chemotaxis. Laryngoscope.
1232 Sheldon T, Freemantle N. (1993). Persistent glue ear in children. Bmj.
1233 Shenoy P, David VC. (1993). A case of quinsy in a fifteen-month old child. J Laryngol Otol.
1234 Sheppard IJ, Moir AA, Thomas RS, et al. (1993). Organization of day-case adenoidectomy in the management of chronic otitis media with effusion--preliminary results. J R Soc Med.
1235 Shyu WC, Reilly J, Campbell DA, et al. (1993). Penetration of cefprozil into tonsillar and adenoidal tissues. Antimicrob Agents Chemother.
1236 Silvestri JM, Weese-Mayer DE, Bass MT, et al. (1993). Polysomnography in obese children with a history of sleep-associated breathing disorders. Pediatr Pulmonol.
1237 Slawinski EB, Dubanowicz-Kossowska E. (1993). The assessment of hypertrophy of nasopharyngeal tonsil by acoustical methods. Int J Pediatr Otorhinolaryngol.
1238 Smith AB. (1993). Fluid style. Am J Nurs.
1239 Stenfors LE, Raisanen S. (1993). The membranous tonsillitis during infectious mononucleosis is nevertheless of bacterial origin. Int J Pediatr Otorhinolaryngol.
1240 Stevens JM, Serva WA, Kendall BE, et al. (1993). Chiari malformation in adults: relation of morphological aspects to clinical features and operative outcome. J Neurol Neurosurg Psychiatry.
1241 Still JG, Hubbard WC, Poole JM, et al. (1993). Comparison of clarithromycin and penicillin VK suspensions in the treatment of children with streptococcal pharyngitis and review of currently available alternative antibiotic therapies. Pediatr Infect Dis J.
1242 Sugiyama N, Shimizu J, Nakamura M, et al. (1993). Clinicopathological study of the effectiveness of tonsillectomy in IgA nephropathy accompanied by chronic tonsillitis. Acta Otolaryngol Suppl.
1243 Sun KO. (1993). Prevention of bronchial intubation with RAE tube during adenotonsillectomy. Anaesthesia.
1244 Takahashi K, Atsumi M. (1993). Pityriasis lichenoides chronica resolving after tonsillectomy. Br J Dermatol.
1245 Tamura S, Masuda Y, Inokuchi I, et al. (1993). Effect of and indication for tonsillectomy in IgA nephropathy. Acta Otolaryngol Suppl.
1246 Tan AK, Rothstein J, Tewfik TL. (1993). Ambulatory tonsillectomy and adenoidectomy: complications and associated factors. J Otolaryngol.
1247 Tewary AK. (1993). Day-case tonsillectomy: a review of the literature. J Laryngol Otol.
1248 Tewary AK, Barr GS, Bickerton RC. (1993). Parental preferences for duration of hospital stay following tonsillectomy. J Laryngol Otol.
1249 Tewary AK, Cable HR. (1993). Speech changes following uvulopalatopharyngoplasty. Clin Otolaryngol Allied Sci.
1250 Tewary AK, Cable HR, Barr GS. (1993). Steroids and control of post-tonsillectomy pain. J Laryngol Otol.
1251 Tewary AK, Curry AR. (1993). Same-day tonsillectomy. J Laryngol Otol.
1252 Tewodros W, Kronvall G. (1993). Distribution of presumptive pathogenicity factors among beta-hemolytic streptococci isolated from Ethiopia. Apmis.
1253 Tewodros W, Nordstrand A, Kronvall G, et al. (1993). Streptokinase gene polymorphism in group A streptococci isolated from Ethiopian children with various disease manifestations. Microb Pathog.
1254 Thiagarajan J, Bates S, Hitchcock M, et al. (1993). Blood loss following tonsillectomy in children. A blind comparison of diclofenac and papaveretum. Anaesthesia.
1255 Thompson RH, Vernon DT. (1993). Research on children's behavior after hospitalization: a review and synthesis. J Dev Behav Pediatr.
1256 Trent CS. (1993). Electrocautery versus epinephrine-injection tonsillectomy. Ear Nose Throat J.
1257 Tsang KW, Rutman A, Kanthakumar K, et al. (1993). Haemophilus influenzae infection of human respiratory mucosa in low concentrations of antibiotics. Am Rev Respir Dis.
1258 Vernon DT, Thompson RH. (1993). Research on the effect of experimental interventions on children's behavior after hospitalization: a review and synthesis. J Dev Behav Pediatr.
1259 Villard-Mackintosh L, Vessey MP. (1993). Oral contraceptives and reproductive factors in multiple sclerosis incidence. Contraception.
1260 Volk MS, Martin P, Brodsky L, et al. (1993). The effects of preoperative steroids on tonsillectomy patients. Otolaryngol Head Neck Surg.
1261 Wall JE, Wilimas JA, Manco-Johnson MJ. (1993). Preoperative coagulation screening in children. Pediatrics.
1262 Watanabe S, Ogura H, Fukushima K, et al. (1993). Comparison of Virapap filter hybridization with polymerase chain reaction and Southern blot hybridization methods for detection of human papillomavirus in tonsillar and pharyngeal cancers. Eur Arch Otorhinolaryngol.
1263 Watson MG, Dawes PJ, Samuel PR, et al. (1993). A study of haemostasis following tonsillectomy comparing ligatures with diathermy. J Laryngol Otol.
1264 Webster AC, Morley-Forster PK, Dain S, et al. (1993). Anaesthesia for adenotonsillectomy: a comparison between tracheal intubation and the armoured laryngeal mask airway. Can J Anaesth.
1265 Weinberg E, Brodsky L, Stanievich J, et al. (1993). Needle aspiration of peritonsillar abscess in children. Arch Otolaryngol Head Neck Surg.
1266 Weippl G. (1993). Multicentre comparison of azithromycin versus erythromycin in the treatment of paediatric pharyngitis or tonsillitis caused by group A streptococci. J Antimicrob Chemother.
1267 Wells MP, Hanes NA. (1993). Tonsillectomy, adenoidectomy in the day surgery unit: a case study. Aorn j.
1268 Williams PJ, Bailey PM. (1993). Comparison of the reinforced laryngeal mask airway and tracheal intubation for adenotonsillectomy. Br J Anaesth.
1269 Wilson JU. (1993). A knotty problem. Anaesthesia.
1270 Woodson BT, Toohill RJ. (1993). Transpalatal advancement pharyngoplasty for obstructive sleep apnea. Laryngoscope.
1271 Ysunza A, Garcia-Velasco M, Garcia-Garcia M, et al. (1993). Obstructive sleep apnea secondary to surgery for velopharyngeal insufficiency. Cleft Palate Craniofac J.
1272 Zhou WG, Wang TF, Xue Y, et al. (1993). Chronic tonsillitis and IgA nephropathy. Chin Med J (Engl).
1273 Zohar Y, Finkelstein Y, Strauss M, et al. (1993). Surgical treatment of obstructive sleep apnea. Technical variations. Arch Otolaryngol Head Neck Surg.
1274 Zucconi M, Strambi LF, Pestalozza G, et al. (1993). Habitual snoring and obstructive sleep apnea syndrome in children: effects of early tonsil surgery. Int J Pediatr Otorhinolaryngol.
1275 (1994). Managing otitis media with effusion in young children. American Academy of Pediatrics The Otitis Media Guideline Panel. Pediatrics.
1276 (1994). Managing otitis media with effusion in young children. Agency for Health Care Policy and Research. Clin Pract Guidel Quick Ref Guide Clin.
1277 Ajulo SO. (1994). The significance of recurrent tonsillitis in sickle cell disease. Clin Otolaryngol Allied Sci.
1278 Alho OP, Koivu M, Sorri M, et al. (1994). Which children are being operated on for recurrent acute otitis media?. Arch Otolaryngol Head Neck Surg.
1279 Andersson J, Abrams J, Bjork L, et al. (1994). Concomitant in vivo production of 19 different cytokines in human tonsils. Immunology.
1280 Andreassen ML, Leeper HA, MacRae DL, et al. (1994). Aerodynamic, acoustic, and perceptual changes following adenoidectomy. Cleft Palate Craniofac J.
1281 Arber DA, Sheibani K, Weiss LM. (1994). UCL3D3 and UCL4D12 reactivity in small B-cell neoplasms with special emphasis on monocytoid B-cell lymphoma. Hum Pathol.
1282 Armonda RA, Citrin CM, Foley KT, et al. (1994). Quantitative cine-mode magnetic resonance imaging of Chiari I malformations: an analysis of cerebrospinal fluid dynamics. Neurosurgery.
1283 Austin DF. (1994). Adenotonsillectomy in the treatment of secretory otitis media. Ear Nose Throat J.
1284 Babosa M, Baki M, Bodrogi I, et al. (1994). A study of children, fathered by men treated for testicular cancer, conceived before, during, and after chemotherapy. Med Pediatr Oncol.
1285 Barbour PJ, Castaldo JE, Rae-Grant AD, et al. (1994). Internal carotid artery redundancy is significantly associated with dissection. Stroke.
1286 Bartley JR, Connew AM. (1994). Parental attitudes and postoperative problems related to paediatric day stay tonsillectomy. N Z Med J.
1287 Berger G, Ophir D. (1994). Possible role of adenoid mast cells in the pathogenesis of secretory otitis media. Ann Otol Rhinol Laryngol.
1288 Bernstein JM, Sagahtaheri-Altaie S, Dryja DM, et al. (1994). Bacterial interference in nasopharyngeal bacterial flora of otitis-prone and non-otitis-prone children. Acta Otorhinolaryngol Belg.
1289 Bicknell PG. (1994). Role of adenotonsillectomy in the management of pediatric ear, nose and throat infections. Pediatr Infect Dis J.
1290 Bisset AF, Russell D. (1994). Grommets, tonsillectomies, and deprivation in Scotland. BMJ.
1291 Blokmanis A. (1994). Ultrasound in the diagnosis and management of peritonsillar abscesses. J Otolaryngol.
1292 Bock A, Popp W, Herkner KR. (1994). Tonsillectomy and the immune system: a long-term follow up comparison between tonsillectomized and non-tonsillectomized children. Eur Arch Otorhinolaryngol.
1293 Brook I, de Leyva F. (1994). Microbiology of tonsillar surfaces in infectious mononucleosis. Arch Pediatr Adolesc Med.
1294 Bruin G. (1994). Glossopharyngeal nerve block for tonsillectomy or uvulopalatopharyngoplasty. Can J Anaesth.
1295 Callanan V, Capper R, Gurr P, et al. (1994). Day-case adenoidectomy, parental opinions and concerns. J Laryngol Otol.
1296 Carr NF, Wales SG, Young D. (1994). Reported management of patients with sore throat in Australian general practice. Br J Gen Pract.
1297 Caugant DA, Hoiby EA, Magnus P, et al. (1994). Asymptomatic carriage of Neisseria meningitidis in a randomly sampled population. J Clin Microbiol.
1298 Cherkin DC, Deyo RA, Loeser JD, et al. (1994). An international comparison of back surgery rates. Spine (Phila Pa 1976).
1299 Chidzonga MM, Lopez Perez VM, Portilla Alvarez AL. (1994). A clinicopathologic study of parotid gland tumors. J Oral Maxillofac Surg.
1300 Chisholm GD, Ng PE, Prescott S. (1994). Benign prostatic hyperplasia: the incidence of prostatectomy within and without Europe. Prog Clin Biol Res.
1301 Close HL, Kryzer TC, Nowlin JH, et al. (1994). Hemostatic assessment of patients before tonsillectomy: a prospective study. Otolaryngol Head Neck Surg.
1302 Connolly AA, Davis JP, Stafford ND. (1994). Oropharyngeal trauma during routine ear, nose and throat procedures. J Laryngol Otol.
1303 Corey JP, Adham RE, Abbass AH, et al. (1994). The role of IgE-mediated hypersensitivity in otitis media with effusion. Am J Otolaryngol.
1304 De Carpentier J, Timms M. (1994). Preliminary experiences with microscopic tonsillectomy. Clin Otolaryngol Allied Sci.
1305 de Lange de Klerk ES, Blommers J, Kuik DJ, et al. (1994). Effect of homoeopathic medicines on daily burden of symptoms in children with recurrent upper respiratory tract infections. BMJ.
1306 de Melker RA, Kuyvenhoven MM. (1994). Management of upper respiratory tract infections in Dutch family practice. J Fam Pract.
1307 de Soto H. (1994). The bleeding tonsil. Crna.
1308 Donnelly MJ. (1994). Hypernasality following adenoid removal. Ir J Med Sci.
1309 Donnelly MJ, Quraishi MS, McShane DP. (1994). Indications for paediatric tonsillectomy GP versus Consultant perspective. J Laryngol Otol.
1310 Drake-Lee A, Price J, Varley R. (1994). Mast cell ultrastructure in the adenoids of children with and without secretory otitis media. J Laryngol Otol.
1311 Ebenfelt A, Lundberg C. (1994). Bacterial invasion of the tonsillar tissues in acute pharyngotonsillitis and in the adenoid: a preliminary study. Clin Otolaryngol Allied Sci.
1312 Eid NS, Jones VF. (1994). Bacterial tracheitis as a complication of tonsillectomy and adenoidectomy. J Pediatr.
1313 Eufinger H, Eggeling V. (1994). Should velopharyngoplasty and tonsillectomy in the cleft palate child be performed simultaneously?. J Oral Maxillofac Surg.
1314 Eufinger H, Eggeling V, Immenkamp E. (1994). Velopharyngoplasty with or without tonsillectomy and/or adenotomy--a retrospective evaluation of speech characteristics in 143 patients. J Craniomaxillofac Surg.
1315 Evans KL, Keene MH, Bristow AS. (1994). High-frequency jet ventilation--a review of its role in laryngology. J Laryngol Otol.
1316 Fagan JJ, Wormald PJ. (1994). Quinsy tonsillectomy or interval tonsillectomy--a prospective randomised trial. S Afr Med J.
1317 Farwell JR, Blackner G, Sulzbacher S, et al. (1994). First febrile seizures. Characteristics of the child, the seizure, and the illness. Clin Pediatr (Phila).
1318 Fenton JE, O'Dwyer TP. (1994). Adult day case tonsillectomy: a safe and viable option. Clin Otolaryngol Allied Sci.
1319 Fields M, Cabraal D, Dawes P. (1994). The effect of Dexamethasone on post operative pain following tonsillectomy in adults. Aust J Otolaryngol.
1320 Finkelstein Y, Nachmani A, Ophir D. (1994). The functional role of the tonsils in speech. Arch Otolaryngol Head Neck Surg.
1321 Flanagan PM, Roland NJ, Jones AS. (1994). Cervical node metastases presenting with features of branchial cysts. J Laryngol Otol.
1322 Francois M, Consten L, Rezvani Y, et al. (1994). ETUDE COMPARATIVE DE L'EFFICACITE ET DE LA TOLERANCE DE L'ACIDE TIAPROFENIQUE ET DU PARACETAMOL DANS LES SUITES D'AMYGDALECTOMIE CHEZ L'ENFANT. J Fr Oto-Rhino-Laryngol.
1323 Furst SR, Rodarte A. (1994). Prophylactic antiemetic treatment with ondansetron in children undergoing tonsillectomy. Anesthesiology.
1324 Garden AS, Weber RS, Ang KK, et al. (1994). Postoperative radiation therapy for malignant tumors of minor salivary glands. Outcome and patterns of failure. Cancer.
1325 Gaskill JR. (1994). Importance of anesthetic technique in outpatient tonsillectomy. Otolaryngol Head Neck Surg.
1326 Gedaly-Duff V, Ziebarth D. (1994). Mothers' management of adenoid-tonsillectomy pain in 4- to 8-year-olds: a preliminary study. Pain.
1327 Girard N, Lasjaunias P, Taylor W. (1994). Reversible tonsillar prolapse in vein of Galen aneurysmal malformations: report of eight cases and pathophysiological hypothesis. Childs Nerv Syst.
1328 Going JA, Ervin DM. (1994). Otitis media: when are tubes and/or adenoidectomy needed?. J S C Med Assoc.
1329 Goldstein NA, Sculerati N, Walsleben JA, et al. (1994). Clinical diagnosis of pediatric obstructive sleep apnea validated by polysomnography. Otolaryngol Head Neck Surg.
1330 Griffin JL, Ramadan HH, Adham RE. (1994). Prevalence of IgE-mediated hypersensitivity in children with adenotonsillar disease. Arch Otolaryngol Head Neck Surg.
1331 Grunwald ZS, M, Parness J, Potsic WP, Templeton JJ. (1994). Droperidol decreases the incidence and the severity of vomiting after tonsillectomy and adenoidectomy in children. Pediatric Anesthesia.
1332 Haapanen ML, Ignatius J, Rihkanen H, et al. (1994). Velopharyngeal insufficiency following palatine tonsillectomy. Eur Arch Otorhinolaryngol.
1333 Hackmann T. (1994). Anaesthesia for adenotonsillectomy. Can J Anaesth.
1334 Hasan MA, Black AE. (1994). A new technique for fibreoptic intubation in children. Anaesthesia.
1335 Hassard AD. (1994). Tonsillectomy and today's otolaryngologist. Otolaryngol Head Neck Surg.
1336 Healy GB. (1994). Quick reference guide for clinicians. Managing otitis media with effusion in young children: a commentary. Arch Otolaryngol Head Neck Surg.
1337 Heath ML, Sinnathamby SW. (1994). The reinforced laryngeal mask airway for adenotonsillectomy. Br J Anaesth.
1338 Helfaer MA, Wilson MD. (1994). Obstructive sleep apnea, control of ventilation, and anesthesia in children. Pediatr Clin North Am.
1339 Hone SW, Moore J, Fenton J, et al. (1994). The role of Chlamydia pneumoniae in severe acute tonsillitis. J Laryngol Otol.
1340 Hornig CR, Rust DS, Busse O, et al. (1994). Space-occupying cerebellar infarction. Clinical course and prognosis. Stroke.
1341 Howard DJ, Haribhakti VV. (1994). Primary tumours of the trachea: analysis of clinical features and treatment results. J Laryngol Otol.
1342 Huminer D, Pitlik S, Levy R, et al. (1994). Mycoplasma and Chlamydia in adenoids and tonsils of children undergoing adenoidectomy or tonsillectomy. Ann Otol Rhinol Laryngol.
1343 Kaczorowski S, Kaczorowska M, Christensson B. (1994). Expression of EBV encoded latent membrane protein 1 (LMP-1) and bcl-2 protein in childhood and adult Hodgkin's disease: application of microwave irradiation for antigen retrieval. Leuk Lymphoma.
1344 Kanamoto Y, Shibata R, Ozono Y, et al. (1994). Effect of tonsillectomy on peripheral blood T cell surface markers and cytokine production in patients with IgA nephropathy accompanied by chronic tonsillitis. Nihon Jinzo Gakkai Shi.
1345 Kaneko K, Suzuki Y, Kiya K, et al. (1994). A case report suggesting a common pathogenesis for IgA nephropathy and Henoch-Schonlein purpura. Pediatr Nephrol.
1346 Kaplan B. (1994). Homoeopathy: 2. In pregnancy and for the under-fives. Prof Care Mother Child.
1347 Katic V, Klapan I, Katic M, et al. (1994). Acute upper respiratory tract infections and indications for tonsillectomy in children. I. Immunoglobulin synthesis in the palatine tonsil tissue. Int J Pediatr Otorhinolaryngol.
1348 Khan MZ, McCombe AW, Swift AC. (1994). Prophylactic antibiotics for tonsillectomy?. Pakistan Journal of Otolaryngology, Head and Neck Surgery.
1349 Kolnaar BG, van den Bosch WJ, van den Hoogen HJ, et al. (1994). The clustering of respiratory diseases in early childhood. Fam Med.
1350 Krespi YP, Ling EH. (1994). Laser-assisted serial tonsillectomy. J Otolaryngol.
1351 Kusakari C, Nose M, Takasaka T, et al. (1994). Immunopathological features of palatine tonsil characteristic of IgA nephropathy: IgA1 localization in follicular dendritic cells. Clin Exp Immunol.
1352 Lang SA, Chang PC, Laxdal VA, et al. (1994). Haemoglobin Hammersmith precludes monitoring with conventional pulse oximetry. Can J Anaesth.
1353 Levin BC, Becker GD. (1994). Uvulopalatopharyngoplasty for snoring: long-term results. Laryngoscope.
1354 Litman RS, Wu CL, Catanzaro FA. (1994). Ondansetron decreases emesis after tonsillectomy in children. Anesth Analg.
1355 Macdonald MR, Wong A, Walker P, et al. (1994). Electrocautery-induced ignition of tonsillar packing. J Otolaryngol.
1356 Mandel EM, Casselbrant ML, Kurs-Lasky M. (1994). Acute otorrhea: bacteriology of a common complication of tympanostomy tubes. Ann Otol Rhinol Laryngol.
1357 Mann EA, Sidman JD. (1994). Results of cleft palate repair with the double-reverse Z-plasty performed by residents. Otolaryngol Head Neck Surg.
1358 Manolis E, Tsakris A, Kandiloros D, et al. (1994). Alterations to the oropharyngeal and nasopharyngeal microbial flora of children after tonsillectomy and adenoidectomy. J Laryngol Otol.
1359 Marcus CL, Carroll JL, Koerner CB, et al. (1994). Determinants of growth in children with the obstructive sleep apnea syndrome. J Pediatr.
1360 Marcus CL, Gozal D, Arens R, et al. (1994). Ventilatory responses during wakefulness in children with obstructive sleep apnea. Am J Respir Crit Care Med.
1361 Marcus CL, McColley SA, Carroll JL, et al. (1994). Upper airway collapsibility in children with obstructive sleep apnea syndrome. J Appl Physiol (1985).
1362 Maves KK, Weiler JM. (1994). Tonsillectomy in a patient with hereditary angioedema after prophylaxis with C1 inhibitor concentrate. Ann Allergy.
1363 Maw AR, Bawden R. (1994). Does adenoidectomy have an adjuvant effect on ventilation tube insertion and thus reduce the need for re-treatment?. Clin Otolaryngol Allied Sci.
1364 Maw AR, Bawden R. (1994). Factors affecting resolution of otitis media with effusion in children. Clin Otolaryngol Allied Sci.
1365 Maw AR, Bawden R. (1994). The long term outcome of secretory otitis media in children and the effects of surgical treatment: a ten year study. Acta Otorhinolaryngol Belg.
1366 McCall TT. (1994). Postoperative respiratory dysfunction. Crna.
1367 McClurg FL, Evans DA. (1994). Laser laryngoplasty for laryngomalacia. Laryngoscope.
1368 McRae RG, Weissburg AJ, Chang KW. (1994). Iatrogenic hyponatremia: a cause of death following pediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
1369 Messmore HL, Godwin J. (1994). Medical assessment of bleeding in the surgical patient. Med Clin North Am.
1370 Mitchelmore IJ, Reilly PG, Hay AJ, et al. (1994). Tonsil surface and core cultures in recurrent tonsillitis: prevalence of anaerobes and beta-lactamase producing organisms. Eur J Clin Microbiol Infect Dis.
1371 Moens HB, Corstjens A, Boon C. (1994). Rheumatoid arthritis is not associated with prior tonsillectomy or appendectomy. Clin Rheumatol.
1372 Moralee SJ, Carney AS, Cash MP, et al. (1994). The effect of fibrin sealant haemostasis on post-operative pain in tonsillectomy. Clin Otolaryngol Allied Sci.
1373 Mort EA, Weissman JS, Epstein AM. (1994). Physician discretion and racial variation in the use of surgical procedures. Arch Intern Med.
1374 Motta G, De Campora E, De Vita C, et al. (1994). Immunoactivity of pidotimod against episodes of recurrent tonsillitis in childhood. Arzneimittelforschung.
1375 Muhe L, Kidane Y, Shamebo D, et al. (1994). The Butajira Rural Health Project in Ethiopia: mothers' perceptions and practices in the care of children with acute respiratory infections. Int J Health Sci.
1376 Nair I, Thompsett C. (1994). Laryngeal mask airway and late postoperative stridor. Anaesthesia.
1377 Nakjang Y, Kullavanijaya P. (1994). Basal cell carcinoma: seven years' experience at the Institute of Dermatology in Bangkok. J Dermatol.
1378 Negus BH, Street NE. (1994). Midazolam-opioid combination and postoperative upper airway obstruction in children. Anaesth Intensive Care.
1379 Newton JN, Seagroatt V, Goldacre M. (1994). Geographical variation in hospital admission rates: an analysis of workload in the Oxford region, England. J Epidemiol Community Health.
1380 Noel PE, Guarisco JL. (1994). Tonsillectomy and adenoidectomy in children: current indications. J La State Med Soc.
1381 Obi JO, Ejeheri NA, Alakija W. (1994). Childhood febrile seizures (Benin City experience). Ann Trop Paediatr.
1382 Ogata H, Ebihara S, Mukai K. (1994). Salivary gland neoplasms in children. Jpn J Clin Oncol.
1383 Ohta N, Fukase S, Aoyagi M, et al. (1994). Neutrophil activating activity of tonsillar cells from patients with tonsillitis. Acta Otolaryngol Suppl.
1384 Oldfield EH, Muraszko K, Shawker TH, et al. (1994). Pathophysiology of syringomyelia associated with Chiari I malformation of the cerebellar tonsils. Implications for diagnosis and treatment. J Neurosurg.
1385 Orntoft S, Longreen A, Moiniche S, et al. (1994). A comparison of pre- and postoperative tonsillar infiltration with bupivacaine on pain after tonsillectomy. A pre-emptive effect?. Anaesthesia.
1386 Orrling A, Stjernquist-Desatnik A, Schalen C, et al. (1994). Clindamycin in persisting streptococcal pharyngotonsillitis after penicillin treatment. Scand J Infect Dis.
1387 Oulis CJ, Vadiakas GP, Ekonomides J, et al. (1994). The effect of hypertrophic adenoids and tonsils on the development of posterior crossbite and oral habits. J Clin Pediatr Dent.
1388 Pang YT, el-Hakim H, Rothera MP. (1994). Bipolar diathermy tonsillectomy. Clin Otolaryngol Allied Sci.
1389 Pargetter J. (1994). Fear and loathing. Nurs Times.
1390 Passy V. (1994). Pathogenesis of peritonsillar abscess. Laryngoscope.
1391 Pearl AJ, Manoukian JJ. (1994). Adenoidectomy: indirect visualization of choanal adenoids. J Otolaryngol.
1392 Petri N, Suadicani P, Wildschiodtz G, et al. (1994). Predictive value of Muller maneuver, cephalometry and clinical features for the outcome of uvulopalatopharyngoplasty. Evaluation of predictive factors using discriminant analysis in 30 sleep apnea patients. Acta Otolaryngol.
1393 Piccirillo JF. (1994). Outcomes research and otolaryngology. Otolaryngol Head Neck Surg.
1394 Pichichero ME. (1994). Recurrent streptococcal pharyngitis: indications for tonsillectomy and penicillin prophylaxis. Pediatr Infect Dis J.
1395 Pichichero ME, Gooch WM, Rodriguez W, et al. (1994). Effective short-course treatment of acute group A beta-hemolytic streptococcal tonsillopharyngitis. Ten days of penicillin V vs 5 days or 10 days of cefpodoxime therapy in children. Arch Pediatr Adolesc Med.
1396 Portier H, Chavanet P, Waldner-Combernoux A, et al. (1994). Five versus ten days treatment of streptococcal pharyngotonsillitis: a randomized controlled trial comparing cefpodoxime proxetil and phenoxymethyl penicillin. Scand J Infect Dis.
1397 Poss J, Meeks BH. (1994). Meeting the health care needs of migrant farmworkers: the experience of the Niagara County Migrant Clinic. J Community Health Nurs.
1398 Pulec JL. (1994). Tonsillectomy for serous otitis media. Ear Nose Throat J.
1399 Rafuse J. (1994). Saskatchewan moves to cut tonsillectomy rate. CMAJ.
1400 Rau BK, Harikrishnan KM, Krishna S. (1994). Neodymium: YAG laser therapy for obstructing tracheobronchial tumours. Ann Acad Med Singapore.
1401 Raymond JR. (1994). Adenoidotonsillectomy. Ear Nose Throat J.
1402 Ren CL, Fu SM, Geha RS. (1994). Protein tyrosine kinase activation and protein kinase C translocation are functional components of CD40 signal transduction in resting human B cells. Immunol Invest.
1403 Robinson PM, Ahmed I. (1994). Diclofenac and post-tonsillectomy haemorrhage. Clin Otolaryngol Allied Sci.
1404 Rogers MA, Crockard HA, Moskovich R, et al. (1994). Nystagmus and joint position sensation: their importance in posterior occipitocervical fusion in rheumatoid arthritis. Spine (Phila Pa 1976).
1405 Rosen GM, Muckle RP, Mahowald MW, et al. (1994). Postoperative respiratory compromise in children with obstructive sleep apnea syndrome: can it be anticipated?. Pediatrics.
1406 Rothschild MA, Catalano P, Biller HF. (1994). Ambulatory pediatric tonsillectomy and the identification of high-risk subgroups. Otolaryngol Head Neck Surg.
1407 Sakai T, Kawaguchi M, Ishizawa S, et al. (1994). Histological features of palatine tonsils in pustulosis palmaris et plantaris: a morphometric study. Pathol Int.
1408 Sakata K, Aoki Y, Karasawa K, et al. (1994). Radiation therapy for patients of malignant salivary gland tumors with positive surgical margins. Strahlenther Onkol.
1409 Sassen ML, van Aarem A, Grote JJ. (1994). Validity of tympanometry in the diagnosis of middle ear effusion. Clin Otolaryngol Allied Sci.
1410 Scharrer I, Vigh T, Aygoren-Pursun E. (1994). Experience with Haemate P in von Willebrand's disease in adults. Haemostasis.
1411 Schloss MD, Tan AK, Schloss B, et al. (1994). Outpatient tonsillectomy and adenoidectomy: complications and recommendations. Int J Pediatr Otorhinolaryngol.
1412 Seay RE, Stene EN, LA YO, et al. (1994). A randomized, double-blind comparison of the antiemetic efficacy of prophylactic pre-induction ondansetron, metoclopramide, or placebo for pediatric tonsillectomy/adenoidectomy. Pharmacotherapy.
1413 Shissias CG, Golnik KC. (1994). Horner's syndrome after tonsillectomy. Am J Ophthalmol.
1414 Stenstrom C, Ingvarsson L. (1994). General illness and need of medical care in otitis prone children. Int J Pediatr Otorhinolaryngol.
1415 Steyn MP, Quinn AM, Gillespie JA, et al. (1994). Tracheal intubation without neuromuscular block in children. Br J Anaesth.
1416 Stuart JC, MacGregor FB, Cairns CS, et al. (1994). Peritonsillar infiltration with bupivacaine for paediatric tonsillectomy. Anaesth Intensive Care.
1417 Tay HL, Mills RP. (1994). Predictive factors for the resolution of childhood otitis media with effusion following initial surgical treatment. Clin Otolaryngol Allied Sci.
1418 Thompson ML. (1994). Information-seeking coping and anxiety in school-age children anticipating surgery. Child Health Care.
1419 Truy E, Merad F, Robin P, et al. (1994). Failures in outpatient tonsillectomy policy in children: a retrospective study in 311 children. Int J Pediatr Otorhinolaryngol.
1420 Tsuruta Y, Hata F, Yane K, et al. (1994). Tissue transmigration of CZON (Cosmosin) to middle ear mucosa, maxillary sinus mucosa, and palatine tonsils. Auris Nasus Larynx.
1421 Wang D, Clement P, Kaufman L, et al. (1994). Fiberoptic evaluation of the nasal and nasopharyngeal anatomy in children with snoring. J Otolaryngol.
1422 Wat PJ, Strickler JG, Myers JL, et al. (1994). Herpes simplex infection causing acute necrotizing tonsillitis. Mayo Clin Proc.
1423 Winther B, Innes DJ. (1994). The human adenoid. A morphologic study. Arch Otolaryngol Head Neck Surg.
1424 Wolf M, Even-Chen I, Kronenberg J. (1994). Peritonsillar abscess: repeated needle aspiration versus incision and drainage. Ann Otol Rhinol Laryngol.
1425 Wolpert SM, Bhadelia RA, Bogdan AR, et al. (1994). Chiari I malformations: assessment with phase-contrast velocity MR. AJNR Am J Neuroradiol.
1426 Wormald PJ, Sellars SL. (1994). Bismuth subgallate: a safe means to a faster adenotonsillectomy. J Laryngol Otol.
1427 Wurzelmann JI, Lyles CM, Sandler RS. (1994). Childhood infections and the risk of inflammatory bowel disease. Dig Dis Sci.
1428 Yanagisawa E, Yanagisawa K. (1994). Endoscopic view of adenoids. Ear Nose Throat J.
1429 Yardley MP, Fairley JW, Durham LH, et al. (1994). Day case tonsil and adenoid surgery: how many are eligible?. J R Coll Surg Edinb.
1430 Yoshioka K, Hirayama Y, Andachi H. (1994). T-cell lymphoma of the tonsil with Ki-1 antigen expression. Intern Med.
1431 Zalzal GH. (1994). Adenotonsillar disease. J Med Liban.
1432 Zanin C, Bene MC, Perruchet AM, et al. (1994). Bacterial crude extracts or ribosomes are recognized similarly by peripheral and mucosal B cells. FEMS Immunol Med Microbiol.
1433 Zanin C, Perrin P, Bene MC, et al. (1994). Antibody-producing cells in peripheral blood and tonsils after oral treatment of children with bacterial ribosomes. Int J Immunopharmacol.
1434 Zeitoun H, Ahmed I, Robinson P. (1994). Validity of a patient-administered questionnaire for routine otolaryngology admissions. Clin Otolaryngol Allied Sci.
1435 Zwar NA, Gordon JJ, Sanson-Fisher RW. (1994). Antibiotic and benzodiazepine prescribing by general practice trainees. Med J Aust.
1436 Adam D, Hostalek U, Troster K. (1995). 5-day cefixime therapy for bacterial pharyngitis and/or tonsillitis: comparison with 10-day penicillin V therapy. Cefixime Study Group. Infection.
1437 Agren K, Andersson U, Nordlander B, et al. (1995). Upregulated local cytokine production in recurrent tonsillitis compared with tonsillar hypertrophy. Acta Otolaryngol.
1438 Alusi GH, Grant WE, Lee CA, et al. (1995). Bleeding after tonsillectomy in severe von Willebrand's disease. J Laryngol Otol.
1439 Anagnostopoulos I, Hummel M, Kreschel C, et al. (1995). Morphology, immunophenotype, and distribution of latently and/or productively Epstein-Barr virus-infected cells in acute infectious mononucleosis: implications for the interindividual infection route of Epstein-Barr virus. Blood.
1440 Apostolopoulos NJ, Nikolopoulos TP, Bairamis TN. (1995). Peritonsillar abscess in children. Is incision and drainage an effective management?. Int J Pediatr Otorhinolaryngol.
1441 Arcioni R, Cannata F, Bandiera G, et al. (1995). Post-operative pain control through peritonsillar local anaesthetic infiltration in children undergoing tonsillectomy. Acta Anaesthesiologica Italica.
1442 Avery JK. (1995). Unanswered questions--somebody pays. J Tenn Med Assoc.
1443 Avrahami E, Englender M. (1995). Relation between CT axial cross-sectional area of the oropharynx and obstructive sleep apnea syndrome in adults. AJNR Am J Neuroradiol.
1444 Babad MS. (1995). Eagle's syndrome caused by traumatic fracture of a mineralized stylohyoid ligament--literature review and a case report. Cranio.
1445 Baraka A. (1995). Fentanyl-induced laryngospasm following tracheal extubation in a child. Anaesthesia.
1446 Barst SM, Markowitz A, Yossefy Y, et al. (1995). Propofol reduces the incidence of vomiting after tonsillectomy in children. Paediatr Anaesth.
1447 Beckhardt RN, Weber RS, Zane R, et al. (1995). Minor salivary gland tumors of the palate: clinical and pathologic correlates of outcome. Laryngoscope.
1448 Bene MC, Zanin C, Perrin P, et al. (1995). Specific antibody-producing cells in humans after oral immunization with a ribosomal vaccine Ribomunyl. Adv Exp Med Biol.
1449 Boisson-Bertrand D. (1995). AMYGDALECTOMIES ET MASQUE LARYNGE RENFORCE. Journal canadien d'anesthesie.
1450 Bolton-Maggs PH, Patterson DA, Wensley RT, et al. (1995). Definition of the bleeding tendency in factor XI-deficient kindreds--a clinical and laboratory study. Thromb Haemost.
1451 Boudewyns AN, Van de Heyning PH. (1995). Obstructive sleep apnea syndrome in children: an overview. Acta Otorhinolaryngol Belg.
1452 Bower CM, Richmond D. (1995). Tonsillectomy and adenoidectomy in patients with Down syndrome. Int J Pediatr Otorhinolaryngol.
1453 Brokstad KA, Cox RJ, Olofsson J, et al. (1995). Parenteral influenza vaccination induces a rapid systemic and local immune response. J Infect Dis.
1454 Brook I, Gober AE. (1995). Role of bacterial interference and beta-lactamase-producing bacteria in the failure of penicillin to eradicate group A streptococcal pharyngotonsillitis. Arch Otolaryngol Head Neck Surg.
1455 Brook I, Yocum P, Foote PA. (1995). Changes in the core tonsillar bacteriology of recurrent tonsillitis: 1977-1993. Clin Infect Dis.
1456 Browning G. (1995). Randomised control trial of antibiotic cover of adult tonsillectomy to reduce post-operative morbidity. National Research Register.
1457 Caldemeyer KS, Boaz JC, Wappner RS, et al. (1995). Chiari I malformation: association with hypophosphatemic rickets and MR imaging appearance. Radiology.
1458 Callanan V, Curran AJ, Smyth DA, et al. (1995). The influence of bismuth subgallate and adrenaline paste upon operating time and operative blood loss in tonsillectomy. J Laryngol Otol.
1459 Camilleri AE, MacKenzie K, Gatehouse S. (1995). The effect of recurrent tonsillitis and tonsillectomy on growth in childhood. Clin Otolaryngol Allied Sci.
1460 Carbon C, Chatelin A, Bingen E, et al. (1995). A double-blind randomized trial comparing the efficacy and safety of a 5-day course of cefotiam hexetil with that of a 10-day course of penicillin V in adult patients with pharyngitis caused by group A beta-haemolytic streptococci. J Antimicrob Chemother.
1461 Carney AS, Robinson PJ. (1995). Assessment and management of snoring: a surgical perspective. Br J Hosp Med.
1462 Celik O, Yalcin S, Hancer A, et al. (1995). Tuberculous tonsillitis. J Otolaryngol.
1463 Cherchi GB, Pacifico L, Cossellu S, et al. (1995). Prospective study of Yersinia enterocolitica infection in thalassemic patients. Pediatr Infect Dis J.
1464 Chernyshov AV, Melnikov OF. (1995). Tonsillar lymphocyte subsets in tonsillitis and hyperplasia. Adv Exp Med Biol.
1465 Cinalli G, Renier D, Sebag G, et al. (1995). Chronic tonsillar herniation in Crouzon's and Apert's syndromes: the role of premature synostosis of the lambdoid suture. J Neurosurg.
1466 Clayman GL, DeMonte F, Jaffe DM, et al. (1995). Outcome and complications of extended cranial-base resection requiring microvascular free-tissue transfer. Arch Otolaryngol Head Neck Surg.
1467 Constantopoulos A, Papadaki-Papandreou U, Papaconstantinou E. (1995). Increased beta-endorphin but not Leu-enkephalin in plasma due to preoperative stress. Experientia.
1468 Couriel JM. (1995). Glue ear: prescribe, operate, or wait?. Lancet.
1469 Cressman WR, Myer CM. (1995). Management of tonsillectomy hemorrhage: results of a survey of pediatric otolaryngology fellowship programs. Am J Otolaryngol.
1470 Cron R. (1995). Index of suspicion. Case 2. Diagnosis: peritonsillitis. Pediatr Rev.
1471 Cui LX, Ikenami M, Katano H, et al. (1995). Immunoglobulin idiotypic specificity of AIDS-associated lymphomas and their experimental model. Pathol Int.
1472 Dajani A, Taubert K, Ferrieri P, et al. (1995). Treatment of acute streptococcal pharyngitis and prevention of rheumatic fever: a statement for health professionals. Committee on Rheumatic Fever, Endocarditis, and Kawasaki Disease of the Council on Cardiovascular Disease in the Young, the American Heart Association. Pediatrics.
1473 Davis CJ, Mostofi FK, Sesterhenn IA. (1995). Renal medullary carcinoma. The seventh sickle cell nephropathy. Am J Surg Pathol.
1474 De PR, Mikhail T. (1995). A combined approach excision of branchial fistula. J Laryngol Otol.
1475 Dearlove O, Sharples A, O'Brien K, et al. (1995). Evidence based medicine. Many questions cannot be answered by evidence based medicine. Bmj.
1476 Del Rio-Navarro BE, Torres S, Barragan-Tame L, et al. (1995). Immunological effects of tonsillectomy/adenectomy in children. Adv Exp Med Biol.
1477 Demain JG, Goetz DW. (1995). Pediatric adenoidal hypertrophy and nasal airway obstruction: reduction with aqueous nasal beclomethasone. Pediatrics.
1478 Derkay CS, Darrow DH, LeFebvre SM. (1995). Pediatric tonsillectomy and adenoidectomy procedures. Aorn j.
1479 Deutsch ES, Isaacson GC. (1995). Tonsils and adenoids: an update. Pediatr Rev.
1480 Domenighetti G, Bisig BE. (1995). Tonsillectomy: a family-transmissible surgical procedure. Lancet.
1481 Elhakim M, Abdel Hay H. (1995). Comparison of preoperative with postoperative topical lidocaine spray on pain after tonsillectomy. Acta Anaesthesiol Scand.
1482 Epstein LJ, Strollo PJ, Donegan RB, et al. (1995). Obstructive sleep apnea in patients with human immunodeficiency virus (HIV) disease. Sleep.
1483 Eufinger H, Bremerich A, Eggeling V, et al. (1995). Speech results and velopharyngeal morphology following 151 cranially based velopharyngoplasties. Folia Phoniatr Logop.
1484 Fagan JJ, James MF. (1995). A prospective study of anaesthesia for quinsy tonsillectomy. Anaesthesia.
1485 Fenton JE, Blayney AW, O'Dwyer TP. (1995). Bismuth subgallate--its role in tonsillectomy. J Laryngol Otol.
1486 Fischer EG. (1995). Posterior fossa decompression for Chiari I deformity, including resection of the cerebellar tonsils. Childs Nerv Syst.
1487 Fisher EW, Palmer CR, Daly NJ, et al. (1995). Acoustic rhinometry in the pre-operative assessment of adenoidectomy candidates. Acta Otolaryngol.
1488 Freezer NJ, Bucens IK, Robertson CF. (1995). Obstructive sleep apnoea presenting as failure to thrive in infancy. J Paediatr Child Health.
1489 Fried D. (1995). On tonsillectomy: mom's personal experience. Lancet.
1490 Fujimori I, Goto R, Kikushima K, et al. (1995). Investigation of oral alpha-streptococcus showing inhibitory activity against pathogens in children with tonsillitis. Int J Pediatr Otorhinolaryngol.
1491 Galioto GB, Passali D, Catalano GB, et al. (1995). Oral therapy with flurithromycin in ear, nose and throat infections. Int J Clin Pharmacol Ther.
1492 Gallagher JE, Blauth J, Fornadley JA. (1995). Perioperative ketorolac tromethamine and postoperative hemorrhage in cases of tonsillectomy and adenoidectomy. Laryngoscope.
1493 Gallegos B, Rios A, Espidel A, et al. (1995). A double-blind, multicenter comparative study of two regimens of clindamycin hydrochloride in the treatment of patients with acute streptococcal tonsillitis/pharyngitis. Clin Ther.
1494 Garden AS, Weber RS, Morrison WH, et al. (1995). The influence of positive margins and nerve invasion in adenoid cystic carcinoma of the head and neck treated with surgery and radiation. Int J Radiat Oncol Biol Phys.
1495 Gervaix A, Brighi L, Halperin DS, et al. (1995). Cefetamet pivoxil in the treatment of pharyngotonsillitis due to group A beta-hemolytic streptococci: preliminary report. J Chemother.
1496 Gianoli GJ, Worley NK, Guarisco JL. (1995). Pediatric tympanoplasty: the role of adenoidectomy. Otolaryngol Head Neck Surg.
1497 Greenspun JC, Hannallah RS, Welborn LG, et al. (1995). Comparison of sevoflurane and halothane anesthesia in children undergoing outpatient ear, nose, and throat surgery. J Clin Anesth.
1498 Gryczynska D, Powajbo K, Zakrzewska A. (1995). The influence of tonsillectomy on obstructive sleep apnea children with malocclusion. Int J Pediatr Otorhinolaryngol.
1499 Guldbrand P, Mellstrom A. (1995). Rectal versus intramuscular morphine-scopolamine as premedication in children. Acta Anaesthesiol Scand.
1500 Gunter JB, Varughese AM, Harrington JF, et al. (1995). Recovery and complications after tonsillectomy in children: a comparison of ketorolac and morphine. Anesth Analg.
1501 Haapaniemi JJ. (1995). Adenoids in school-aged children. J Laryngol Otol.
1502 Haddad J, Inglesby TV, Addonizio L. (1995). Head and neck infections in pediatric cardiac transplant patients. Ear Nose Throat J.
1503 Hall MD, Brodsky L. (1995). The effect of post-operative diet on recovery in the first twelve hours after tonsillectomy and adenoidectomy. Int J Pediatr Otorhinolaryngol.
1504 Herzon FS. (1995). Harris P. Mosher Award thesis. Peritonsillar abscess: incidence, current management practices, and a proposal for treatment guidelines. Laryngoscope.
1505 Hester TO, Jones RO, Archer SM, et al. (1995). Prophylactic antibiotic drops after tympanostomy tube placement. Arch Otolaryngol Head Neck Surg.
1506 Holm S, Henning C, Grahn E, et al. (1995). Is penicillin the appropriate treatment for recurrent tonsillopharyngitis? Results from a comparative randomized blind study of cefuroxime axetil and phenoxymethylpenicillin in children. The Swedish Study Group. Scand J Infect Dis.
1507 Hultcrantz E, Lofstrand-Tidestrom B, Ahlquist-Rastad J. (1995). The epidemiology of sleep related breathing disorder in children. Int J Pediatr Otorhinolaryngol.
1508 Idoko JA, Anteyi EA, Ighogboja IS, et al. (1995). Open clinical trial of roxithromycin amongst patients of Jos University Teaching Hospital with lower and upper respiratory tract infections. West Afr J Med.
1509 Jacob SV, Morielli A, Mograss MA, et al. (1995). Home testing for pediatric obstructive sleep apnea syndrome secondary to adenotonsillar hypertrophy. Pediatr Pulmonol.
1510 Johannesson GP, Floren M, Lindahl SG. (1995). Sevoflurane for ENT-surgery in children. A comparison with halothane. Acta Anaesthesiol Scand.
1511 Juarbe C, Longo F, Riera I, et al. (1995). Changing trends in adenotonsillectomy at San Pablo Hospital 1983 vs. 1993. Bol Asoc Med P R.
1512 Kapadia SB, Roman LN, Kingma DW, et al. (1995). Hodgkin's disease of Waldeyer's ring. Clinical and histoimmunophenotypic findings and association with Epstein-Barr virus in 16 cases. Am J Surg Pathol.
1513 Karam R, Najm JC, Kattar M, et al. (1995). Respiratory complications in children emerging from halothane anesthesia--awake vs deep extubation. Middle East J Anaesthesiol.
1514 Kermode J, Walker S, Webb I. (1995). Postoperative vomiting in children. Anaesth Intensive Care.
1515 Khazin V, Ezra S, Cohen A. (1995). Comparison of rectal to intranasal administration of midazolam for premedication of children. Military medicine.
1516 Kini PG. (1995). Juvenile myasthenia gravis with predominant facial weakness in a 7-year-old boy. Int J Pediatr Otorhinolaryngol.
1517 Kinsella JB, O'Sullivan P, McShane DP. (1995). The role of the middle ear and tonsil in the etiology of febrile convulsions. Int J Pediatr Otorhinolaryngol.
1518 Klausner RD, Tom LW, Schindler PD, et al. (1995). Depression in children after tonsillectomy. Arch Otolaryngol Head Neck Surg.
1519 Kluemper GT, Vig PS, Vig KW. (1995). Nasorespiratory characteristics and craniofacial morphology. Eur J Orthod.
1520 Knudsen KE, Brofeldt S, Mikkelsen S, et al. (1995). Peritonsillar infiltration with low-dose tenoxicam after tonsillectomy. Br J Anaesth.
1521 Knudsen KE, Brofeldt S, Mikkelsen S, et al. (1995). Analgesic effect of peritonsillar infiltration with low-dose tenoxicam after tonsillectomy [abstract]. Br-J-Anaesth.
1522 Knudsen TD, Simko EJ. (1995). Eikenella corrodens: an unexpected pathogen causing a persistent peritonsillar abscess. Ear Nose Throat J.
1523 Koay CB, Norval C. (1995). An unusual presentation of an unusual complication of infectious mononucleosis: haematemesis and melaena. J Laryngol Otol.
1524 Koch RJ, Brodsky L. (1995). Qualitative and quantitative immunoglobulin production by specific bacteria in chronic tonsillar disease. Laryngoscope.
1525 Kosko JR, Derkay CS. (1995). Uvulopalatopharyngoplasty: treatment of obstructive sleep apnea in neurologically impaired pediatric patients. Int J Pediatr Otorhinolaryngol.
1526 Kuhn JJ, Brook I, Waters CL, et al. (1995). Quantitative bacteriology of tonsils removed from children with tonsillitis hypertrophy and recurrent tonsillitis with and without hypertrophy. Ann Otol Rhinol Laryngol.
1527 Kuo M, Hegarty D, Johnson A, et al. (1995). Early post-tonsillectomy morbidity following hospital discharge: do patients and GPs know what to expect?. Health Trends.
1528 Lake L. (1995). Tonsillitis on the tall ships. Nurs Stand.
1529 Llewellyn R. (1995). KTP/532 laser tonsillectomy--a potential day-case procedure. J Laryngol Otol.
1530 Lones MA, Mishalani S, Shintaku IP, et al. (1995). Changes in tonsils and adenoids in children with posttransplant lymphoproliferative disorder: report of three cases with early involvement of Waldeyer's ring. Hum Pathol.
1531 Loyola AM, de Araujo VC, de Sousa SO, et al. (1995). Minor salivary gland tumours. A retrospective study of 164 cases in a Brazilian population. Eur J Cancer B Oral Oncol.
1532 MacDougall G, Denholm SW. (1995). Audit of the treatment of tonsillar and peritonsillar sepsis in an ear, nose and throat unit. J Laryngol Otol.
1533 MacGregor FB, Albert DM, Bhattacharyya AK. (1995). Post-operative morbidity following paediatric tonsillectomy; a comparison of bipolar diathermy dissection and blunt dissection. Int J Pediatr Otorhinolaryngol.
1534 Manning SC. (1995). Re: Coagulation profile as a predictor for post-tonsillectomy and adenoidectomy (T + A) hemorrhage. Int J Pediatr Otorhinolaryngol.
1535 Marcus CL, Ward SL, Mallory GB, et al. (1995). Use of nasal continuous positive airway pressure as treatment of childhood obstructive sleep apnea. J Pediatr.
1536 Marshall JN, Sheppard I, Narula AA. (1995). A prospective study of day case adenoidectomy. Clin Otolaryngol Allied Sci.
1537 Masuda Y, Kondoh M, Namiki A. (1995). Usefulness of infiltration anesthesia in child tonsillectomy under general anesthesia. Anesthesia and Resuscitation.
1538 Mather SJ, Peutrell JM. (1995). Postoperative morphine requirements, nausea and vomiting following anaesthesia for tonsillectomy. Comparison of intravenous morphine and non-opioid analgesic techniques. Paediatr Anaesth.
1539 McDonald JP. (1995). Airway problems in children--can the orthodontist help?. Ann Acad Med Singapore.
1540 McGuirt WF, Johnson JT, Sanders MH. (1995). Previous tonsillectomy as prognostic indicator for success of uvulopalatopharyngoplasty. Laryngoscope.
1541 Messinger S. (1995). Former times. N Engl J Med.
1542 Millesimo M, Savoia D. (1995). Group A streptococci: evaluation of in vitro resistance to two macrolides. Microbios.
1543 Mills RP, Tay HL. (1995). Findings at initial surgery for childhood otitis media with effusion and subsequent outcome. Clin Otolaryngol Allied Sci.
1544 Min YG, Kang MK, Park HM, et al. (1995). Effects of adenotonsillar hypertrophy on snoring in children. ORL J Otorhinolaryngol Relat Spec.
1545 Moore CE. (1995). Above the law. J Fla Med Assoc.
1546 Moralee SJ, Murray JA. (1995). Would day-case adult tonsillectomy be safe?. J Laryngol Otol.
1547 Muir DC, Papesch ME, Allison RS. (1995). Peritonsillar infection in Christchurch 1990-2: microbiology and management. N Z Med J.
1548 Murthy P, Laing MR. (1995). Cigarette smoking and sore throats in adults. Postgrad Med J.
1549 Nandapalan V, McIlwain JC. (1995). Tonsillar fossa obliteration and post-operative pain. Clin Otolaryngol Allied Sci.
1550 Nicklaus PJ, Herzon FS, Steinle EWt. (1995). Short-stay outpatient tonsillectomy. Arch Otolaryngol Head Neck Surg.
1551 Nilsen OG. (1995). Pharmacokinetics of macrolides. Comparison of plasma, tissue and free concentrations with special reference to roxithromycin. Infection.
1552 Norinkavich KM, Howie G, Cariofiles P. (1995). Quality improvement study of day surgery for tonsillectomy and adenoidectomy patients. Pediatr Nurs.
1553 Ohlms LA, Wilder RT, Weston B. (1995). Use of intraoperative corticosteroids in pediatric tonsillectomy. Arch Otolaryngol Head Neck Surg.
1554 Okeke EN, Juryit Z, Ikeh EI. (1995). Open clinical trial of roxithromycin in patients of Plateau Hospitals, Jos in upper and lower respiratory tract infections. West Afr J Med.
1555 Oluwole M, Mills RP. (1995). Methods of selection for adenoidectomy in childhood otitis media with effusion. Int J Pediatr Otorhinolaryngol.
1556 Onerci M, Hasçelik G, Sener B, et al. (1995). The effect of tonsillectomy on neutrophil chemotaxis in adults with chronic tonsillitis. European archives of oto-rhino-laryngology.
1557 Pandit UA, Malviya S, Lewis IH. (1995). Vomiting after outpatient tonsillectomy and adenoidectomy in children: the role of nitrous oxide. Anesth Analg.
1558 Pang YT. (1995). Paediatric tonsillectomy: bipolar electrodissection and dissection/snare compared. J Laryngol Otol.
1559 Panizza B. (1995). Bacteraemia and tonsillectomy. Australian Journal of Otolaryngology.
1560 Parchman ML. (1995). Small area variation analysis: a tool for primary care research. Fam Med.
1561 Pawluk C. (1995). Memories of nursing. AARN News Lett.
1562 Pirsig W. (1995). Tonsil- and syndrome-related diseases and sleep apnea. Int J Pediatr Otorhinolaryngol.
1563 Poklis A, Edinboro LE, Wohler AS, et al. (1995). Fatal morphine poisoning in a child due to accidental oral ingestion. Forensic Sci Int.
1564 Quiding-Jarbrink M, Granstrom G, Nordstrom I, et al. (1995). Induction of compartmentalized B-cell responses in human tonsils. Infect Immun.
1565 Qvarnberg Y, Valtonen H. (1995). Bacteria in middle ear effusions in children treated with tympanostomy; a 10-year series. Acta Otolaryngol.
1566 Raine NM, Whittet HB, Marks NJ, et al. (1995). KTP-532 laser tonsillectomy--a potential day-case procedure?. J Laryngol Otol.
1567 Ranke MB, Savage MO, Chatelain PG, et al. (1995). Insulin-like growth factor I improves height in growth hormone insensitivity: two years' results. Horm Res.
1568 Ren YF, Isberg A, Henningsson G. (1995). Velopharyngeal incompetence and persistent hypernasality after adenoidectomy in children without palatal defect. Cleft Palate Craniofac J.
1569 Richardson HC, Prichard AJ. (1995). Microscopic tonsillectomy. Clin Otolaryngol Allied Sci.
1570 Righi PD, Sofferman RA. (1995). Screening unilateral tonsillectomy in the unknown primary. Laryngoscope.
1571 Rimell FL, Shapiro AM, Shoemaker DL, et al. (1995). Head and neck manifestations of Beckwith-Wiedemann syndrome. Otolaryngol Head Neck Surg.
1572 Robb PJ, Rollin AM, Saunders DA. (1995). Diclofenac and post-tonsillectomy haemorrhage. Clin Otolaryngol Allied Sci.
1573 Rolling C, Treton D, Beckmann P, et al. (1995). JAK3 associates with the human interleukin 4 receptor and is tyrosine phosphorylated following receptor triggering. Oncogene.
1574 Ron E, Lubin JH, Shore RE, et al. (1995). Thyroid cancer after exposure to external radiation: a pooled analysis of seven studies. Radiat Res.
1575 Roos K, Claesson R, Persson U, et al. (1995). The economic cost of a streptococcal tonsillitis episode. Scand J Prim Health Care.
1576 Rose JB, Martin TM. (1995). Ondansetron or metoclopramide in children undergoing tonsillectomy. Anesthesiology.
1577 Rose JB, McCloskey JJ. (1995). Rapid intravenous administration of ondansetron or metoclopramide is not associated with cardiovascular compromise in children. Paediatr Anaesth.
1578 Rosenfeld RM. (1995). Pilot study of outcomes in pediatric rhinosinusitis. Arch Otolaryngol Head Neck Surg.
1579 Ruby RR, Webster AC, Morley-Forster PK, et al. (1995). Laryngeal mask airway in paediatric otolaryngologic surgery. J Otolaryngol.
1580 Ruco LP, Uccini S, Stoppacciaro A, et al. (1995). The lymphoepithelial organization of the tonsil: an immunohistochemical study in chronic recurrent tonsillitis. J Pathol.
1581 Rusy LM, Houck CS, Sullivan LJ, et al. (1995). A double-blind evaluation of ketorolac tromethamine versus acetaminophen in pediatric tonsillectomy: analgesia and bleeding. Anesth Analg.
1582 Samuel D, Thomas DM, Tierney PA, et al. (1995). Atlanto-axial subluxation (Grisel's syndrome) following otolaryngological diseases and procedures. J Laryngol Otol.
1583 Sandooja D, Sachdeva OP, Gulati SP, et al. (1995). Effect of adeno-tonsillectomy on hearing threshold and middle ear pressure. Indian J Pediatr.
1584 Schroeder WA. (1995). Post tonsillectomy hemorrhage: a ten-year retrospective study. Mo Med.
1585 Selimoglu E, Sutbeyaz Y, Ciftcioglu MA, et al. (1995). Primary tonsillar tuberculosis: a case report. J Laryngol Otol.
1586 Shazly MK, Kamel NM, Hassanein MH, et al. (1995). Risk factors related to deaf-mutism among pupils attending the Alexandria governmental deaf-mute schools. J Egypt Public Health Assoc.
1587 Smithson JE, Radford-Smith G, Jewell GP. (1995). Appendectomy and tonsillectomy in patients with inflammatory bowel disease. J Clin Gastroenterol.
1588 Sokic SI, Adanja BJ, Marinkovic JP, et al. (1995). Risk factors for laryngeal cancer. Eur J Epidemiol.
1589 Sow O, Diallo AB, Haba F, et al. (1995). Acute respiratory infections in children: a community-based study comparing a primary health center and a pediatric unit, Republic of Guinea. Tuber Lung Dis.
1590 Spahr-Schopfer IA, Lerman J, Sikich N, et al. (1995). Pharmacokinetics of intravenous ondansetron in healthy children undergoing ear, nose, and throat surgery. Clin Pharmacol Ther.
1591 Splinter WM, Baxter MR, Gould HM, et al. (1995). Oral ondansetron decreases vomiting after tonsillectomy in children. Can J Anaesth.
1592 Splinter WM, MacNeill HB, Menard EA, et al. (1995). Midazolam reduces vomiting after tonsillectomy in children. Can J Anaesth.
1593 Splinter WM, Rhine EJ, Roberts DW, et al. (1995). Ondansetron is a better prophylactic antiemetic than droperidol for tonsillectomy in children. Can J Anaesth.
1594 Stankiewicz JA. (1995). Pediatric endoscopic nasal and sinus surgery. Otolaryngol Head Neck Surg.
1595 Steketee KG, Reisdorff EJ. (1995). Emergency care for posttonsillectomy and postadenoidectomy hemorrhage. Am J Emerg Med.
1596 Suen JS, Arnold JE, Brooks LJ. (1995). Adenotonsillectomy for treatment of obstructive sleep apnea in children. Arch Otolaryngol Head Neck Surg.
1597 Sutters KA, Levine JD, Dibble S, et al. (1995). Analgesic efficacy and safety of single-dose intramuscular ketorolac for postoperative pain management in children following tonsillectomy. Pain.
1598 Szucs E, Diependaele R, Clement PA. (1995). The accuracy of tympanometry assessed by its sensitivity and specificity. Acta Otorhinolaryngol Belg.
1599 Tachibana S, Harada K, Abe T, et al. (1995). Syringomyelia secondary to tonsillar herniation caused by posterior fossa tumors. Surg Neurol.
1600 Tay HL. (1995). Post-operative morbidity in electrodissection tonsillectomy. J Laryngol Otol.
1601 Teka T, Dagnew M. (1995). Health behaviour of rural mothers to acute respiratory infections in children in Gondar, Ethiopia. East Afr Med J.
1602 Teranishi Y, Mizutani H, Murata M, et al. (1995). Increased spontaneous production of IL-8 in peripheral blood monocytes from the psoriatic patient: relation to focal infection and response to treatments. J Dermatol Sci.
1603 Thomas PC, Moore P, Reilly JS. (1995). Child preferences for post-tonsillectomy diet. Int J Pediatr Otorhinolaryngol.
1604 Tirosh E, Tal Y, Jaffe M. (1995). CPAP treatment of obstructive sleep apnoea and neurodevelopmental deficits. Acta Paediatr.
1605 Toma AG, Blanshard J, Eynon-Lewis N, et al. (1995). Post-tonsillectomy pain: the first ten days. J Laryngol Otol.
1606 Uckunkaya N, Sahin S, Haci I. (1995). Comparison of midazolam and buprenorphine premedication in children. Turk Anesteziyoloji Ve Reanimasyon.
1607 van Cauwenberge PB, Bellussi L, Maw AR, et al. (1995). The adenoid as a key factor in upper airway infections. Int J Pediatr Otorhinolaryngol.
1608 Van den Berg AA, Savva D, Honjol NM, et al. (1995). Comparison of total intravenous, balanced inhalational and combined intravenous-inhalational anaesthesia for tympanoplasty, septorhinoplasty and adenotonsillectomy. Anaesth Intensive Care.
1609 Vavrina J. (1995). Computer assisted pulse oximetry for detecting children with obstructive sleep apnea syndrome. Int J Pediatr Otorhinolaryngol.
1610 Vedung S. (1995). Pharyngeal flaps after one- and two-stage repair of the cleft palate: a 25-year review of 520 patients. Cleft Palate Craniofac J.
1611 Vos GD, Marres EH, Heineman E, et al. (1995). Tension pneumoperitoneum as an early complication after adenotonsillectomy. J Laryngol Otol.
1612 Wang D, Clement P. (1995). Fiberscopic imaging of the pediatric nasopharynx. Diagn Ther Endosc.
1613 Wang DY, Clement PA, Kaufman L, et al. (1995). Chronic nasal obstruction in children. A fiberscopic study. Rhinology.
1614 Waters KA, Everett F, Bruderer J, et al. (1995). The use of nasal CPAP in children. Pediatr Pulmonol Suppl.
1615 Waters KA, Everett F, Sillence DO, et al. (1995). Treatment of obstructive sleep apnea in achondroplasia: evaluation of sleep, breathing, and somatosensory-evoked potentials. Am J Med Genet.
1616 Waters KA, Everett FM, Bruderer JW, et al. (1995). Obstructive sleep apnea: the use of nasal CPAP in 80 children. Am J Respir Crit Care Med.
1617 Weinstock DJ, Schwartz AD. (1995). Factor XI deficiency in an Ashkenazi Jewish child, causing severe postoperative hemorrhage. J Pediatr Surg.
1618 Weisglas-Kuperus N, Sas TC, Koopman-Esseboom C, et al. (1995). Immunologic effects of background prenatal and postnatal exposure to dioxins and polychlorinated biphenyls in Dutch infants. Pediatr Res.
1619 Wolf M, Even-Chen I, Talmi YP, et al. (1995). The indication for tonsillectomy in children following peritonsillar abscess. Int J Pediatr Otorhinolaryngol.
1620 Wong AK, Bissonnette B, Braude BM, et al. (1995). Post-tonsillectomy infiltration with bupivacaine reduces immediate postoperative pain in children. Can J Anaesth.
1621 Yamaguchi K, Ozono Y, Harada T, et al. (1995). Changes in circulating immune complex and charge distribution with upper respiratory tract inflammation in IgA nephropathy. Nephron.
1622 Yardley M. (1995). Is it appropriate to perform adenoidectomy tonsillectomy or adenotonsillectomy on a day case basis?. Clin Otolaryngol Allied Sci.
1623 Yellin SA, Weiss MH, Kraus DH, et al. (1995). Tonsil lymphoma presenting as tonsillitis after bone marrow transplantation. Otolaryngol Head Neck Surg.
1624 (1996). Electrosurgical airway fires still a hot topic. Health Devices.
1625 (1996). Tonsils: Recent Progress in Clinical and Basic Research. Acta Otolaryngol Suppl.
1626 Abe K, Hori Y, Ohtsu SY, et al. (1996). A case of non-Hodgkin's lymphoma with macroglobulinemia. Acta Otolaryngol Suppl.
1627 Acebo C, Millman RP, Rosenberg C, et al. (1996). Sleep, breathing, and cephalometrics in older children and young adults. Part I -- Normative values. Chest.
1628 Adam D, Scholz H. (1996). Five days of erythromycin estolate versus ten days of penicillin V in the treatment of group A streptococcal tonsillopharyngitis in children. Pharyngitis Study Group. Eur J Clin Microbiol Infect Dis.
1629 Agren K, Andersson U, Litton M, et al. (1996). The production of immunoregulatory cytokines is localized to the extrafollicular area of human tonsils. Acta Otolaryngol.
1630 Ali NJ, Pitson D, Stradling JR. (1996). Sleep disordered breathing: effects of adenotonsillectomy on behaviour and psychological functioning. Eur J Pediatr.
1631 Altemani A, Endo LH. (1996). Histopathology of the palatine tonsil in the newborn infant. Acta Otolaryngol Suppl.
1632 Altemani A, Endo LH, Chone C, et al. (1996). Histopathological concept of chronic tonsillitis in children. Acta Otolaryngol Suppl.
1633 Anderson B, Kanagasundarum S, Woollard G. (1996). Analgesic efficacy of paracetamol in children using tonsillectomy as a pain model. Anaesth Intensive Care.
1634 April MM, Callan ND, Nowak DM, et al. (1996). The effect of intravenous dexamethasone in pediatric adenotonsillectomy. Arch Otolaryngol Head Neck Surg.
1635 Armerding D, Hren A, Callard RE, et al. (1996). Induction of cognate and non-cognate T-cell help for B-cell IgE production in relation to CD40 ligand expression. Int Arch Allergy Immunol.
1636 Bairamis TN, Nikolopoulos TP, Kafetzis DA, et al. (1996). Concentrations of cefpodoxime in plasma, adenoid, and tonsillar tissue after repeated administrations of cefpodoxime proxetil in children. J Antimicrob Chemother.
1637 Baker LL, Bower CM, Glasier CM. (1996). Atlanto-axial subluxation and cervical osteomyelitis: two unusual complications of adenoidectomy. Ann Otol Rhinol Laryngol.
1638 Bean-Lijewski JD, Hunt RD. (1996). Effect of ketorolac on bleeding time and postoperative pain in children: a double-blind, placebo-controlled comparison with meperidine. J Clin Anesth.
1639 Benson JM, Arnold J, Manning SC, et al. (1996). Tonsillar tissue penetration of dirithromycin after multiple doses. J Clin Pharmacol.
1640 Bhargava D, Raman R, El Azzouni MZ, et al. (1996). Anisakiasis of the tonsils. J Laryngol Otol.
1641 Bhargava D, Raman R, Khalfan Al Abri R, et al. (1996). Heterotopia of the tonsil. J Laryngol Otol.
1642 Blair RL, McKerrow WS, Carter NW, et al. (1996). The Scottish tonsillectomy audit. Audit Sub-Committee of the Scottish Otolaryngological Society. J Laryngol Otol.
1643 Blair RL, McKerrow WS, Carter NW, et al. (1996). The Scottish tonsillectomy audit. The Audit Sub-Committee of the Scottish Otolaryngological Society. J Laryngol Otol Suppl.
1644 Bosseloir A, Bouzahzah F, Defrance TH, et al. (1996). The influence of follicular dendritic cells on B-cell proliferation depends on the activation of B cells and the mitogen used. Scand J Immunol.
1645 Brandtzaeg P. (1996). The B-cell development in tonsillar lymphoid follicles. Acta Otolaryngol Suppl.
1646 Brodsky L, Frankel S, Gorfien J, et al. (1996). The role of dendritic cells in the development of chronic tonsillar disease in children. Acta Otolaryngol Suppl.
1647 Brodsky L, Pizzuto M, Gendler J, et al. (1996). Microbipolar dissection vs. cold knife/suction cautery tonsillectomy in children: preliminary results of a prospective study. Acta Otolaryngol Suppl.
1648 Brook I, Deleyva F. (1996). Immune response to Fusobacterium nucleatum and Prevotella intermedia in patients with infectious mononucleosis. J Med Microbiol.
1649 Bugti AH. (1996). Quinsy following tonsillectomy. J Pak Med Assoc.
1650 Bulow K, Nielsen TG, Lund J. (1996). The effect of topical lignocaine on intubating conditions after propofol-alfentanil induction. Acta Anaesthesiol Scand.
1651 Bussi M, Carlevato MT, Panizzut B, et al. (1996). Expression of antigens associated with the individual stages of the inflammatory response in child and adult as a possible distinctive method for recurrent and chronic tonsillitis. Int J Pediatr Otorhinolaryngol.
1652 Bussi M, Carlevato MT, Panizzut B, et al. (1996). Are recurrent and chronic tonsillitis different entities? An immunological study with specific markers of inflammatory stages. Acta Otolaryngol Suppl.
1653 Cannon CR. (1996). The efficacy of a single dose antibiotic regimen in adults undergoing tonsillectomy. J Miss State Med Assoc.
1654 Cannon CR, Lampton LM. (1996). Peritonsillar abscess following tonsillectomy. J Miss State Med Assoc.
1655 Casiano RR, Sheth S. (1996). Efficacy of cold-steel uvulopalatoplasty. Otolaryngol Head Neck Surg.
1656 Castro A, Bono MR, Simon V, et al. (1996). Lymphocyte adhesion to endothelium derived from human lymphoid tissue. Eur J Cell Biol.
1657 Cepeda MS, Daza E, Angarita E, et al. (1996). Effect of pre-operative infiltration of local anaesthetic on post-operative pain after tonsillectomy. Revista Latinoamericana de Dolor.
1658 Cerfolio RJ, Deschamps C, Allen MS, et al. (1996). Mainstem bronchial sleeve resection with pulmonary preservation. Ann Thorac Surg.
1659 Chee NW, Chan KO. (1996). Clinical audit on tonsils and adenoid surgery. Is day surgery a reasonable option?. Ann Acad Med Singapore.
1660 Cohen R, Levy C, Doit C, et al. (1996). Six-day amoxicillin vs. ten-day penicillin V therapy for group A streptococcal tonsillopharyngitis. Pediatr Infect Dis J.
1661 Conley SF, Kodali S, Beecher RB, et al. (1996). Changes in deglutition following tonsillectomy in neurologically impaired children. Int J Pediatr Otorhinolaryngol.
1662 Conlon B, Daly N, Temperely I, et al. (1996). ENT surgery in children with inherited bleeding disorders. J Laryngol Otol.
1663 Cummins B. (1996). Tonsillectomy in 1913. Lancet.
1664 Daniele E, Tralongo V, Morello V, et al. (1996). Pleomorphic adenoma and adenoid-cystic carcinoma of salivary glands: immunohistochemical assessment of proliferative activity in comparison with flow-cytometric study. Cell Prolif.
1665 D'Antonio LL, Snyder LS, Samadani S. (1996). Tonsillectomy in children with or at risk for velopharyngeal insufficiency: effects on speech. Otolaryngol Head Neck Surg.
1666 Davidson A, Brown TC. (1996). Respiratory arrest in two children following postoperative flushing of suxamethonium from the deadspace of intravenous cannulae. Anaesth Intensive Care.
1667 Dean MG, Cunningham I, Dao LP, et al. (1996). Chronic lymphocytic leukaemia with upper airway obstruction. Leuk Lymphoma.
1668 Derkay CS, Werner E, Plotnick E. (1996). Management of children with von Willebrand disease undergoing adenotonsillectomy. Am J Otolaryngol.
1669 Deutsch ES. (1996). Tonsillectomy and adenoidectomy. Changing indications. Pediatr Clin North Am.
1670 DiFranza JR, Lew RA. (1996). Morbidity and mortality in children associated with the use of tobacco products by other people. Pediatrics.
1671 Dohar JE, Bonilla JA. (1996). Processing of adenoid and tonsil specimens in children: a national survey of standard practices and a five-year review of the experience at the Children's Hospital of Pittsburgh. Otolaryngol Head Neck Surg.
1672 Douglas JG, Laramore GE, Austin-Seymour M, et al. (1996). Neutron radiotherapy for adenoid cystic carcinoma of minor salivary glands. Int J Radiat Oncol Biol Phys.
1673 Dundar A, Ozunlu A, Sahan M, et al. (1996). Lingual tonsil hypertrophy producing obstructive sleep apnea. Laryngoscope.
1674 Dykhuizen RS, Golder D, Reid TM, et al. (1996). Phenoxymethyl penicillin versus co-amoxiclav in the treatment of acute streptococcal pharyngitis, and the role of beta-lactamase activity in saliva. J Antimicrob Chemother.
1675 Endo LH, Altemani A, Chone C, et al. (1996). Histopathological comparison between tonsil and adenoid responses to allergy. Acta Otolaryngol Suppl.
1676 Endo LH, Sakano E, Carvalho DS, et al. (1996). Comparative bacteriology of the surface of normal and pathological palatine tonsils in children. Acta Otolaryngol Suppl.
1677 Endo S, Kida A, Sawada U, et al. (1996). Clinical analysis of malignant lymphomas of tonsils. Acta Otolaryngol Suppl.
1678 Erincler T. (1996). The effect of tramadol on minimal alveolar enflurane concentrations in children. Cocuk Sagligi Ve Hastaliklari Dergisi.
1679 Fernandes DB, Grobbelaar AO, Hudson DA, et al. (1996). Velopharyngeal incompetence after adenotonsillectomy in non-cleft patients. Br J Oral Maxillofac Surg.
1680 Finley GA, McGrath PJ, Forward SP, et al. (1996). Parents' management of children's pain following ‘minor’ surgery. Pain.
1681 Fredriksen F, Myklebust R, Olsen R, et al. (1996). In situ localization of Streptococcus pyogenes during acute tonsillitis: an immunocytochemical study with gold markers. Acta Otolaryngol.
1682 Fredriksen F, Raisanen S, Myklebust R, et al. (1996). Bacterial adherence to the surface and isolated cell epithelium of the palatine tonsils. Acta Otolaryngol.
1683 Fujii Y, Tanaka H, Toyooka H. (1996). Granistron and dexamethasone provide more improved prevention of postoperative emesis than granisetron alone in children. Can J Anaesth.
1684 Fujii Y, Tanaka H, Toyooka H. (1996). Granisetron reduces vomiting after strabismus surgery and tonsillectomy in children. Can J Anaesth.
1685 Fujii Y, Tanaka H, Toyooka H. (1996). Granisetron and dexamethasone provide more improved prevention of postoperative emesis than granisetron alone in children. Canadian Journal of Anaesthesia.
1686 Fujii Y, Toyooka H, Tanaka H. (1996). Antiemetic efficacy of granisetron and metoclopramide in children undergoing ophthalmic or ENT surgery. Can J Anaesth.
1687 Fujii Y, Toyooka H, Tanaka H. (1996). Effective dose of granisetron for preventing postoperative emesis in children. Can J Anaesth.
1688 Fujii Y, Toyooka H, Tanaka H. (1996). Antiemetic efficacy of granisetron and metoclopramide in children undergoing ophthalmic or ENT usrgery. Canadian Journal of Anaesthesia.
1689 Fujimori I, Hisamatsu K, Kikushima K, et al. (1996). The nasopharyngeal bacterial flora in children with otitis media with effusion. Eur Arch Otorhinolaryngol.
1690 Fujimori I, Kikushima K, Goto R, et al. (1996). Investigation of the nasopharyngeal bacterial flora in children with otitis media with effusion. ORL J Otorhinolaryngol Relat Spec.
1691 Fujimori I, Kikushima K, Hisamatsu KI, et al. (1996). Analysis of defense mechanisms against bacterial infection by oral streptococcus in normal flora. Zentralbl Bakteriol.
1692 Fujimoto M, Aramaki H, Takano S, et al. (1996). Immediate tonsillectomy for peritonsillar abscess. Acta Otolaryngol Suppl.
1693 Fujisaka M, Ohtani O, Watanabe Y. (1996). Distribution of lymphatics in human palatine tonsils: a study by enzyme-histochemistry and scanning electron microscopy of lymphatic corrosion casts. Arch Histol Cytol.
1694 Gabalski EC, Mattucci KF, Setzen M, et al. (1996). Ambulatory tonsillectomy and adenoidectomy. Laryngoscope.
1695 Garnett JD, Ramadan HH. (1996). Swallowing dysfunction after tonsillectomy. Otolaryngol Head Neck Surg.
1696 Gates GA. (1996). Cost-effectiveness considerations in otitis media treatment. Otolaryngol Head Neck Surg.
1697 Gates GA. (1996). Sizing up the adenoid. Arch Otolaryngol Head Neck Surg.
1698 Gerber ME, O'Connor DM, Adler E, et al. (1996). Selected risk factors in pediatric adenotonsillectomy. Arch Otolaryngol Head Neck Surg.
1699 Goldsher M, Podoshin L, Fradis M, et al. (1996). Effects of peritonsillar infiltration on post-tonsillectomy pain. A double-blind study. Ann Otol Rhinol Laryngol.
1700 Goodman RS. (1996). Surgicel in the control of post-tonsillectomy bleeding. Laryngoscope.
1701 Gosa P. (1996). Clinical exemplar. Minim Invasive Surg Nurs.
1702 Graham D, Kaddour HS. (1996). RAE tube obstruction during tonsil dissection. Br J Anaesth.
1703 Guilleminault C, Pelayo R, Leger D, et al. (1996). Recognition of sleep-disordered breathing in children. Pediatrics.
1704 Gusev E, Boiko A, Lauer K, et al. (1996). Environmental risk factors in MS: a case-control study in Moscow. Acta Neurol Scand.
1705 Halfon N, Newacheck PW, Wood DL, et al. (1996). Routine emergency department use for sick care by children in the United States. Pediatrics.
1706 Hall SC. (1996). Tonsillectomies, ketorolac, and the march of progress. Can J Anaesth.
1707 Hamers JP, Abu-Saad HH, van den Hout MA, et al. (1996). The influence of children's vocal expressions, age, medical diagnosis and information obtained from parents on nurses' pain assessments and decisions regarding interventions. Pain.
1708 Hasegawa K, Nishimura T, Yagisawa M, et al. (1996). Diagnosis by dynamic MRI in sleep disordered breathing. Acta Otolaryngol Suppl.
1709 Hausmann R, Schmidt B, Schellmann B, et al. (1996). Differential diagnosis of postoperative liver failure in a 12-year-old child. Int J Legal Med.
1710 Hayashi Y, Kunimoto M, Kuki K, et al. (1996). Animal model of focal tonsillar infection: human tonsillar lymphocytes induce skin lesion in SCID mice. Acta Otolaryngol Suppl.
1711 Helfaer MA, McColley SA, Pyzik PL, et al. (1996). Polysomnography after adenotonsillectomy in mild pediatric obstructive sleep apnea. Crit Care Med.
1712 Herzon FS, Nicklaus P. (1996). Pediatric peritonsillar abscess: management guidelines. Curr Probl Pediatr.
1713 Hirao M, Harabuchi Y, Kataura A, et al. (1996). Immunological role of human palatine tonsil in Epstein-Barr virus persistence. Acta Otolaryngol Suppl.
1714 Hone SW, Donnelly MJ, Powell F, et al. (1996). Clearance of recalcitrant psoriasis after tonsillectomy. Clin Otolaryngol Allied Sci.
1715 Hori Y, Koike Y, Ohyama G, et al. (1996). Effects of tonsillectomy on articulation. Acta Otolaryngol Suppl.
1716 Hotta O, Taguma Y, Yoshizawa N, et al. (1996). Long-term effects of intensive therapy combined with tonsillectomy in patients with IgA nephropathy. Acta Otolaryngol Suppl.
1717 Howard-Griffin RM, Driver IK. (1996). Laryngeal mask airway in adeno-tonsillectomy in children. Anaesthesia.
1718 Husband AD, Davis A. (1996). Pain after tonsillectomy. Clin Otolaryngol Allied Sci.
1719 Ilic M, Vlajinac H, Marinkovic J. (1996). Case-control study of risk factors for prostate cancer. Br J Cancer.
1720 Ishizuka Y, Kakuta H. (1996). Treatment of sleep apnea and snoring in children. Acta Otolaryngol Suppl.
1721 Jacobs IN, Gray RF, Todd NW. (1996). Upper airway obstruction in children with Down syndrome. Arch Otolaryngol Head Neck Surg.
1722 Jamin C, Lydyard PM, Le Corre R, et al. (1996). CD5+B cells: differential capping and modulation of IgM and CD5. Scand J Immunol.
1723 Johansen M, Harbo G, Illum P. (1996). Preincisional infiltration with bupivacaine in tonsillectomy. Arch Otolaryngol Head Neck Surg.
1724 Jones RF, Ayer JG, Stening WA. (1996). Hydromyelia and Chiari malformation in children and adolescents. J Clin Neurosci.
1725 Judkins JH, Dray TG, Hubbell RN. (1996). Intraoperative ketorolac and posttonsillectomy bleeding. Arch Otolaryngol Head Neck Surg.
1726 Jung KY, Lim HH, Choi G, et al. (1996). Age-related changes of IgA immunocytes and serum and salivary IgA after tonsillectomy. Acta Otolaryngol Suppl.
1727 Kataura A, Tsubota H. (1996). Clinical analyses of focus tonsil and related diseases in Japan. Acta Otolaryngol Suppl.
1728 Kessell G, Barker I. (1996). Leg ischaemia in an infant following accidental intra-arterial administration of atracurium treated with caudal anaesthesia. Anaesthesia.
1729 Kirse DJ, Tryka AF, Seibert RW, et al. (1996). Mortality following adenotonsillectomy in a patient with Williams-Campbell syndrome. Arch Otolaryngol Head Neck Surg.
1730 Kirstila V, Tenovuo J, Ruuskanen O, et al. (1996). Longitudinal analysis of human salivary immunoglobulins, nonimmune antimicrobial agents, and microflora after tonsillectomy. Clin Immunol Immunopathol.
1731 Klijanienko J, Vielh P. (1996). Fine-needle sampling of salivary gland lesions. I. Cytology and histology correlation of 412 cases of pleomorphic adenoma. Diagn Cytopathol.
1732 Kobayashi S, Tamura N, Akimoto T, et al. (1996). Reactive arthritis induced by tonsillitis. Acta Otolaryngol Suppl.
1733 Koivunen P, Alho OP, Uhari M, et al. (1996). General anesthesia with and without nitrous oxide (N2O) and the weight of middle ear effusion in children undergoing adenoidectomy and tympanostomy. Laryngoscope.
1734 Kotiniemi LH, Ryhanen PT, Moilanen IK. (1996). Behavioural changes following routine ENT operations in two-to-ten-year-old children. Paediatr Anaesth.
1735 Kudoh F, Sanai A. (1996). Effect of tonsillectomy and adenoidectomy on obese children with sleep-associated breathing disorders. Acta Otolaryngol Suppl.
1736 Kurono Y, Shigemi H, Kodama S, et al. (1996). The role of adenoids in nasopharyngeal colonization with nontypeable Haemophilus influenzae. Acta Otolaryngol Suppl.
1737 Kvaerner KJ, Tambs K, Harris JR, et al. (1996). Otitis media: relationship to tonsillitis, sinusitis and atopic diseases. Int J Pediatr Otorhinolaryngol.
1738 Lawhorn CD, Bower C, Brown RE, et al. (1996). Ondansetron decreases postoperative vomiting in pediatric patients undergoing tonsillectomy and adenoidectomy. Int J Pediatr Otorhinolaryngol.
1739 Lee WC, Duignan MC, Walsh RM, et al. (1996). An audit of prophylactic antibiotic treatment following tonsillectomy in children. J Laryngol Otol.
1740 Lee WC, Pickles JM. (1996). ‘Hemostatic pause’ in pediatric tonsillectomy?. Int J Pediatr Otorhinolaryngol.
1741 Lee WC, Sharp JF. (1996). Complications of paediatric tonsillectomy post-discharge. J Laryngol Otol.
1742 Liu CM, Su CY. (1996). Post-operative pain control with topical steroid injection after hot dissection tonsillectomy. J Laryngol Otol.
1743 Lojander J, Maasilta P, Partinen M, et al. (1996). Nasal-CPAP, surgery, and conservative management for treatment of obstructive sleep apnea syndrome. A randomized study. Chest.
1744 Mainous AG, Zoorob RJ, Kohrs FP, et al. (1996). Streptococcal diagnostic testing and antibiotics prescribed for pediatric tonsillopharyngitis. Pediatr Infect Dis J.
1745 Malhes AK, Gordon RC, Malkovich DL, et al. (1996). An Old Disease Makes a Comeback. Adolesc Med.
1746 Marais J, Armstrong MW. (1996). Parental knowledge and experiences after surgery for chronic otitis media. Br J Clin Pract.
1747 Marcus CL, Curtis S, Koerner CB, et al. (1996). Evaluation of pulmonary function and polysomnography in obese children and adolescents. Pediatr Pulmonol.
1748 Mate-Jimenez J, Correa-Estan JA, Perez-Miranda M, et al. (1996). Tonsillectomy and inflammatory bowel disease location. Eur J Gastroenterol Hepatol.
1749 Mattila PS, Tarkkanen J. (1996). B- and T-lymphocyte subpopulations in the adenoids of children with otitis media. APMIS.
1750 Maziak DE, Todd TR, Keshavjee SH, et al. (1996). Adenoid cystic carcinoma of the airway: thirty-two-year experience. J Thorac Cardiovasc Surg.
1751 McCoy JP, Overton WR, Schroeder K, et al. (1996). Immunophenotypic analysis of the T cell receptor V beta repertoire in CD4+ and CD8+ lymphocytes from normal peripheral blood. Cytometry.
1752 McCutcheon IE, Blacklock JB, Weber RS, et al. (1996). Anterior transcranial (craniofacial) resection of tumors of the paranasal sinuses: surgical technique and results. Neurosurgery.
1753 Mendham JE, Mather SJ. (1996). Comparison of diclofenac and tenoxicam for postoperative analgesia with and without fentanyl in children undergoing adenotonsillectomy or tonsillectomy. Paediatr Anaesth.
1754 Mevio E, Perano D, De Amici M, et al. (1996). Chronic tonsillitis in children: activation of polymorphonuclear cells from peripheral blood and tonsillar tissue. In vitro production of MPO, ECP and EPX. Acta Otolaryngol Suppl.
1755 Mevio E, Perano D, Pagani L, et al. (1996). The role of tissue colonization and bacterial resistance in recurrent tonsillitis. Acta Otolaryngol Suppl.
1756 Millman RP, Acebo C, Rosenberg C, et al. (1996). Sleep, breathing, and cephalometrics in older children and young adults. Part II -- Response to nasal occlusion. Chest.
1757 Mitchell RB, Quinn SJ, Kenyon GS. (1996). Day-stay tonsillectomy: is hospital stay reduced at the expense of increased community care?. Ann R Coll Surg Engl.
1758 Molliex S, Haond P, Baylot D, et al. (1996). Effect of pre- vs postoperative tonsillar infiltration with local anesthetics on postoperative pain after tonsillectomy. Acta Anaesthesiol Scand.
1759 Moralee SJ, MacDougall G, Molony N, et al. (1996). Day case tonsillectomy in adults: how many are suitable?. J R Coll Surg Edinb.
1760 Muller O. (1996). An open comparative study of azithromycin and roxithromycin in the treatment of acute upper respiratory tract infections. J Antimicrob Chemother.
1761 Murakata H, Harabuchi Y, Kukuminato Y, et al. (1996). Cytokine production by tonsillar lymphocytes stimulated with alpha-streptococci in patients with pustulosis palmaris et plantaris. Acta Otolaryngol Suppl.
1762 Myssiorek D, Alvi A. (1996). Post-tonsillectomy hemorrhage: an assessment of risk factors. Int J Pediatr Otorhinolaryngol.
1763 Nagahara K, Miyajima K, Nakamura S, et al. (1996). Orthodontic treatment of an open bite patient with oral-facial-digital syndrome. Am J Orthod Dentofacial Orthop.
1764 Nagasawa R, Ishii K, Maruyama N, et al. (1996). Reconstitution of SCID mouse with tonsillar cells from patients with IgA nephropathy. Acta Otolaryngol Suppl.
1765 Neugebauer P, Bonnekoh B, Wevers A, et al. (1996). Human keratinocyte culture from the peritonsillar mucosa. Eur Arch Otorhinolaryngol.
1766 Nielsen EW, Gran JT, Straume B, et al. (1996). Hereditary angio-oedema: new clinical observations and autoimmune screening, complement and kallikrein-kinin analyses. J Intern Med.
1767 Nielsen TR, Clement F, Andreassen UK. (1996). Mediastinitis-a rare complication of a peritonsillar abscess. J Laryngol Otol.
1768 Nishimura T, Morishima N, Hasegawa S, et al. (1996). Effect of surgery on obstructive sleep apnea. Acta Otolaryngol Suppl.
1769 Noble B, Gorfien J, Frankel S, et al. (1996). Microanatomical distribution of dendritic cells in normal tonsils. Acta Otolaryngol Suppl.
1770 Nolan P. (1996). Chronic lymphatic leukaemia presenting as severe obstructive sleep apnoea. Respirology.
1771 O'Doherty B. (1996). Azithromycin versus penicillin V in the treatment of paediatric patients with acute streptococcal pharyngitis/tonsillitis. Paediatric Azithromycin Study Group. Eur J Clin Microbiol Infect Dis.
1772 O'Doherty B. (1996). An open comparative study of azithromycin versus cefaclor in the treatment of patients with upper respiratory tract infections. J Antimicrob Chemother.
1773 Ogata T, Yamakawa M, Imai Y, et al. (1996). Follicular dendritic cells adhere to fibronectin and laminin fibers via their respective receptors. Blood.
1774 O'Gorman P, Bennett D, Kavanagh E, et al. (1996). MALTectomy (appendectomy/tonsillectomy) does not influence the occurrence or mode of presentation of adult celiac disease. Am J Gastroenterol.
1775 Ohguro S, Tsubota H, Harabuchi Y. (1996). Interaction and immunological effect of very late antigen-4, 5, and fibronectin in tonsillar lymphocytes and their relation to age. Acta Otolaryngol.
1776 Olofsson K, Hellstrom S, Hammarstrom ML. (1996). Abundance of intraepithelial gamma delta T cells in hypertrophic obstructive but not in chronically infected adenoids. Clin Exp Immunol.
1777 Otsu SY, Koike Y, Hori Y, et al. (1996). Hypertrophy of the palatine tonsils and sleep respiratory disorders. Acta Otolaryngol Suppl.
1778 Owen G, Evans A, Canter R, et al. (1996). The reproducibility of urinary growth hormone measurement in children undergoing adenotonsillectomy: a pilot study. Clin Otolaryngol Allied Sci.
1779 Owen GO, Canter RJ. (1996). Overnight pulse oximetry in normal children and in children undergoing adenotonsillectomy. Clin Otolaryngol Allied Sci.
1780 Parsons JT, Mendenhall WM, Stringer SP, et al. (1996). Management of minor salivary gland carcinomas. Int J Radiat Oncol Biol Phys.
1781 Passali D, Bellussi L, De Lauretis A. (1996). Relapsing infective-phlogistic pathology of Waldeyer's ring and its relationship with secretory otitis media. Acta Otolaryngol Suppl.
1782 Peyramond D, Portier H, Geslin P, et al. (1996). 6-day amoxicillin versus 10-day penicillin V for group A beta-haemolytic streptococcal acute tonsillitis in adults: a French multicentre, open-label, randomized study. The French Study Group Clamorange. Scand J Infect Dis.
1783 Pignataro O, Pignataro LD, Gallus G, et al. (1996). Otitis media with effusion and S-carboxymethylcysteine and/or its lysine salt: a critical overview. Int J Pediatr Otorhinolaryngol.
1784 Pisacane A, Impagliazzo N, De Caprio C, et al. (1996). Breast feeding and tonsillectomy. BMJ.
1785 Pitkaranta A, Hovi T, Karma P. (1996). Interferon production by leukocytes in children with otitis media with effusion. Int J Pediatr Otorhinolaryngol.
1786 Pringle MB, Cosford E, Beasley P, et al. (1996). Day-case tonsillectomy--is it appropriate?. Clin Otolaryngol Allied Sci.
1787 Rafuse J. (1996). Education, practice reviews needed to reduce surgical intervention, Quebec report says. Cmaj.
1788 Rajasuo A, Jousimies-Somer H, Savolainen S, et al. (1996). Bacteriologic findings in tonsillitis and pericoronitis. Clin Infect Dis.
1789 Rakhmanova AG, Lumio J, Groundstroem K, et al. (1996). Diphtheria outbreak in St. Petersburg: clinical characteristics of 1860 adult patients. Scand J Infect Dis.
1790 Ramjettan S, Singh B. (1996). Are sutured faucial pillars really an advantage in tonsillectomy?. S Afr J Surg.
1791 Rathfoot CJ, Coleman JA. (1996). Laser utilization in the oral pharynx. Otolaryngol Clin North Am.
1792 Ravalia A, Arrowsmith JE. (1996). Anaesthesia for quinsy tonsillectomy. Anaesthesia.
1793 Renehan A, Gleave EN, Hancock BD, et al. (1996). Long-term follow-up of over 1000 patients with salivary gland tumours treated in a single centre. Br J Surg.
1794 Rieger A, Schroter G, Philippi W, et al. (1996). A comparison of sevoflurane with halothane in outpatient adenotomy in children with mild upper respiratory tract infections. J Clin Anesth.
1795 Robinson K, Gatehouse S, Browning GG. (1996). Measuring patient benefit from otorhinolaryngological surgery and therapy. Ann Otol Rhinol Laryngol.
1796 Romej M, Voepel-Lewis T, Merkel SI, et al. (1996). Effect of preemptive acetaminophen on postoperative pain scores and oral fluid intake in pediatric tonsillectomy patients. AANA J.
1797 Romsing J. (1996). Assessment of nurses' judgement for analgesic requirements of postoperative children. J Clin Pharm Ther.
1798 Romsing J, Hertel S, Moller-Sonnergaard J, et al. (1996). Postoperative pain in Danish children: self-report measures of pain intensity. J Pediatr Nurs.
1799 Romsing J, Moller-Sonnergaard J, Hertel S, et al. (1996). Postoperative pain in children: comparison between ratings of children and nurses. J Pain Symptom Manage.
1800 Rose JB, Brenn BR, Corddry DH, et al. (1996). Preoperative oral ondansetron for pediatric tonsillectomy. Anesth Analg.
1801 Rose JB, Martin TM. (1996). Posttonsillectomy vomiting. Ondansetron or metoclopramide during paediatric tonsillectomy: are two doses better than one?. Paediatr Anaesth.
1802 Rosen CL. (1996). Obstructive sleep apnea syndrome (OSAS) in children: diagnostic challenges. Sleep.
1803 Rossen BE, McKeever PD. (1996). The behavior of preschoolers during and after brief surgical hospitalizations. Issues Compr Pediatr Nurs.
1804 Ruboyianes JM, Cruz RM. (1996). Pediatric adenotonsillectomy for obstructive sleep apnea. Ear Nose Throat J.
1805 Saida H, Hirose H. (1996). Acoustic changes in voice after tonsillectomy. Acta Otolaryngol Suppl.
1806 Saito H, Asakura K, Hata M, et al. (1996). Does adenotonsillectomy affect the course of bronchial asthma and nasal allergy?. Acta Otolaryngol Suppl.
1807 Salata JA, Derkay CS. (1996). Water precautions in children with tympanostomy tubes. Arch Otolaryngol Head Neck Surg.
1808 Sampalis JS, Medsger TA, Fries JF, et al. (1996). Risk factors for adult Still's disease. J Rheumatol.
1809 Sanai A, Kudoh F. (1996). Effects of tonsillectomy in children with IgA nephropathy, purpura nephritis, or other chronic glomerulonephritides. Acta Otolaryngol Suppl.
1810 Sanchez-Armengol A, Capote-Gil F, Cano-Gomez S, et al. (1996). Polysomnographic studies in children with adenotonsillar hypertrophy and suspected obstructive sleep apnea. Pediatr Pulmonol.
1811 Sato Y, Hotta O, Taguma Y, et al. (1996). Reduced reticulization of palatine tonsils with IgA nephropathy. Acta Otolaryngol Suppl.
1812 Sato Y, Hotta O, Taguma Y, et al. (1996). IgA nephropathy with poorly developed lymphoepithelial symbiosis of the palatine tonsils. Nephron.
1813 Scaglione F, Pintucci JP, Demartini G, et al. (1996). Ceftibuten concentrations in human tonsillar tissue. Eur J Clin Microbiol Infect Dis.
1814 Schaad UB, Heynen G. (1996). Evaluation of the efficacy, safety and toleration of azithromycin vs. penicillin V in the treatment of acute streptococcal pharyngitis in children: results of a multicenter, open comparative study. The Swiss Tonsillopharyngitis Study Group. Pediatr Infect Dis J.
1815 Sdralis T, Berkowitz RG. (1996). Early adenotonsillectomy for relief of acute upper airway obstruction due to acute tonsillitis in children. Int J Pediatr Otorhinolaryngol.
1816 Shamoto H, Chugani DC, Chugani HT. (1996). Glucose metabolism in the human cerebellum: anatomical-functional correlations. J Child Neurol.
1817 Sher AE, Schechtman KB, Piccirillo JF. (1996). The efficacy of surgical modifications of the upper airway in adults with obstructive sleep apnea syndrome. Sleep.
1818 Shintani T, Asakura K, Kataura A. (1996). Adenotonsillar hypertrophy and skeletal morphology of children with obstructive sleep apnea syndrome. Acta Otolaryngol Suppl.
1819 Shiraishi S, Tomoda K, Matsumoto A, et al. (1996). Investigation of the local provocation test to PPP and IgA nephritis. Acta Otolaryngol Suppl.
1820 Shukla GK, Mahajan A, Pandey S, et al. (1996). A study of free radicals and scavenging enzyme in tonsillitis. Boll Chim Farm.
1821 Skatvedt O, Akre H, Godtlibsen OB. (1996). Continuous pressure measurements in the evaluation of patients for laser assisted uvulopalatoplasty. Eur Arch Otorhinolaryngol.
1822 Spence AG. (1996). Single injection field block of tonsillar fossa. Anaesth Intensive Care.
1823 Splinter WM, Rhine EJ, Roberts DW, et al. (1996). Preoperative ketorolac increases bleeding after tonsillectomy in children. Can J Anaesth.
1824 Splinter WM, Roberts DJ. (1996). Dexamethasone decreases vomiting by children after tonsillectomy. Anesth Analg.
1825 Staub M, Sasvari-Szekely M, Spasokukotskaja T, et al. (1996). Human tonsillar lymphocytes as targets for immunosuppressive and anticancer drugs. Acta Otolaryngol Suppl.
1826 Stene FN, Seay RE, Young LA, et al. (1996). Prospective, randomized, double-blind, placebo-controlled comparison of metoclopramide and ondansetron for prevention of posttonsillectomy or adenotonsillectomy emesis. J Clin Anesth.
1827 Stenfors LE, Raisanen S. (1996). Immunoglobulin-coated bacteria on the tonsillar surface during infectious mononucleosis. J Laryngol Otol.
1828 Suleman M. (1996). Patterns of health-care utilization and morbidity in a rural community near Lahore, Pakistan. Ann Trop Med Parasitol.
1829 Supiyaphun P, Siricharoensang S. (1996). Treatment of tonsillar crypt infection with CO2 laser: a preliminary report. J Med Assoc Thai.
1830 Suto Y, Matsuda E, Inoue Y. (1996). MRI of the pharynx in young patients with sleep disordered breathing. Br J Radiol.
1831 Suzuki K, Yamamoto S, Ito Y, et al. (1996). Sleep apnea associated with congenital diseases and moderate hypertrophy of tonsils. Acta Otolaryngol Suppl.
1832 Szeremeta W, Novelly NJ, Benninger M. (1996). Postoperative bleeding in tonsillectomy patients. Ear Nose Throat J.
1833 Szoke I, Pascu C, Nagy E, et al. (1996). Binding of extracellular matrix proteins to the surface of anaerobic bacteria. J Med Microbiol.
1834 Takahashi H, Honjo I, Fujita A. (1996). Endoscopic findings at the pharyngeal orifice of the eustachian tube in otitis media with effusion. Eur Arch Otorhinolaryngol.
1835 Takahashi K, Lappin D, Kinane DF. (1996). In situ localization of cell synthesis and proliferation in periodontitis gingiva and tonsillar tissue. Oral Dis.
1836 Takeuchi J, Yagisawa M, Nishimura T. (1996). Tonsillar focal infection: clinical observations of low grade fever. Acta Otolaryngol Suppl.
1837 Tanaka I, Suzuki K, Tanaka E, et al. (1996). Investigation of normal bacterial flora in the upper respiratory tract. Acta Otolaryngol Suppl.
1838 Tay HL. (1996). Post-tonsillectomy pain with selective diathermy haemostasis. J Laryngol Otol.
1839 Thomson C, Blake P. (1996). The increasing incidence of hospital admission for acute tonsillitis: a 5 year review of the Wellington experience. N Z Med J.
1840 Tokuda M, Shimizu J, Sugiyama N, et al. (1996). Direct evidence of the production of IgA by tonsillar lymphocytes and the binding of IgA to the glomerular mesangium of IgA nephropathy patients. Acta Otolaryngol Suppl.
1841 Tom LW, Templeton JJ, Thompson ME, et al. (1996). Dexamethasone in adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
1842 Tomioka S, Miyoshi K, Tabata K, et al. (1996). Clinical study of chronic tonsillitis with IgA nephropathy treated by tonsillectomy. Acta Otolaryngol Suppl.
1843 Tomkinson A, Roblin DG, Quine SM, et al. (1996). Tympanic thermometry and minor ear surgery. J Laryngol Otol.
1844 van Balen FA, de Melker RA, Touw-Otten FW. (1996). Double-blind randomised trial of co-amoxiclav versus placebo for persistent otitis media with effusion in general practice. Lancet.
1845 van den Berg AA. (1996). Comparison of ondansetron and prochlorperazine for the prevention of nausea and vomiting after adenotonsillectomy. Br J Anaesth.
1846 Vaudaux BP, Cherpillod J, Dayer P. (1996). Concentrations of azithromycin in tonsilar and/or adenoid tissue from paediatric patients. J Antimicrob Chemother.
1847 Vauzelle-Kervroedan F, Revzani Y, Pons G, et al. (1996). Antipyretic efficacy of tiaprofenic acid in febrile children. Fundam Clin Pharmacol.
1848 Ved SA, Walden TL, Montana J, et al. (1996). Vomiting and recovery after outpatient tonsillectomy and adenoidectomy in children. Comparison of four anesthetic techniques using nitrous oxide with halothane or propofol. Anesthesiology.
1849 Volk MS, Wang Z, Pankratov MM, et al. (1996). Mucosal intact laser tonsillar ablation. Arch Otolaryngol Head Neck Surg.
1850 Wang B, Li G, Fang J. (1996). Experimental study on spontaneous DNA synthesis of tonsillar lymphocytes in chronic recurrent tonsillitis and focal tonsillitis. Acta Otolaryngol Suppl.
1851 Wang WS, Chiou TJ, Pan CC, et al. (1996). Signet-ring cell carcinoma of the rectum with tonsillar metastasis: a case report. Zhonghua Yi Xue Za Zhi (Taipei).
1852 Ward SL, Marcus CL. (1996). Obstructive sleep apnea in infants and young children. J Clin Neurophysiol.
1853 Welborn LG, Hannallah RS, Norden JM, et al. (1996). Comparison of emergence and recovery characteristics of sevoflurane, desflurane, and halothane in pediatric ambulatory patients. Anesth Analg.
1854 Wexler DB. (1996). Recovery after tonsillectomy: electrodissection vs. sharp dissection techniques. Otolaryngol Head Neck Surg.
1855 Windak A, Tomasik T, Jacobs HM, et al. (1996). Are antibiotics over-prescribed in Poland? Management of upper respiratory tract infections in primary health care region of Warszawa, Wola. Fam Pract.
1856 Xavier R, Paiva A, Ribeiro da Silva P, et al. (1996). Primary malignant melanoma of the palatine tonsil: a case report. J Laryngol Otol.
1857 Yamabe H, Osawa H, Inuma H, et al. (1996). Deterioration of urinary findings after tonsil stimulation in patients with IgA nephropathy. Acta Otolaryngol Suppl.
1858 Yamanaka N, Yokoyama M, Kawaguchi T, et al. (1996). Role of gamma delta-T cells in the palatine tonsil. Acta Otolaryngol Suppl.
1859 Yeh HC, Matanoski GM, Comstock GW. (1996). A follow-up study of childhood nasopharyngeal radium irradiation in Washington County, Maryland. Otolaryngol Head Neck Surg.
1860 Yokoyama Y, Harabuchi Y, Kodama H, et al. (1996). Systemic immune response to Streptococcal and Staphylococcal lipoteichoic acids in children with recurrent tonsillitis. Acta Otolaryngol Suppl.
1861 Yundt KD, Park TS, Tantuwaya VS, et al. (1996). Posterior fossa decompression without duraplasty in infants and young children for treatment of Chiari malformation and achondroplasia. Pediatr Neurosurg.
1862 Zinder DJ, Parker GS. (1996). Electrocautery burns and operator ignorance. Otolaryngol Head Neck Surg.
1863 Akkielah A, Kalan A, Kenyon GS. (1997). Diathermy tonsillectomy: comparisons of morbidity following bipolar and monopolar microdissection needle excision. J Laryngol Otol.
1864 al Anazy FH, Zakzouk SM. (1997). The impact of social and environmental changes on allergic rhinitis among Saudi children. A clinical and allergological study. Int J Pediatr Otorhinolaryngol.
1865 Al-Ghamdi SA, Manoukian JJ, Morielli A, et al. (1997). Do systemic corticosteroids effectively treat obstructive sleep apnea secondary to adenotonsillar hypertrophy?. Laryngoscope.
1866 Anderhuber W, Stammberger H. (1997). Endoscopic surgery of uni- and bilateral choanal atresia. Auris Nasus Larynx.
1867 Anderson BJ, Holford NH. (1997). Rectal paracetamol dosing regimens: determination by computer simulation. Paediatr Anaesth.
1868 Auf I, Osborne JE, Sparkes C, et al. (1997). Is the KTP laser effective in tonsillectomy?. Clinical otolaryngology and allied sciences.
1869 Baba H, Uchida K, Wada M, et al. (1997). Vertebral lesions associated with palmoplantar pustulosis. Int Orthop.
1870 Bailey BJ. (1997). Tonsils and adenoids: snapshots from The Laryngoscope scrapbook. Laryngoscope.
1871 Bailey R, Sinha C, Burgess LP. (1997). Ketorolac tromethamine and hemorrhage in tonsillectomy: a prospective, randomized, double-blind study. Laryngoscope.
1872 Bean-Lijewski JD. (1997). Glossopharyngeal nerve block for pain relief after pediatric tonsillectomy: retrospective analysis and two cases of life-threatening upper airway obstruction from an interrupted trial. Anesthesia and analgesia.
1873 Beldman TF, Teunisse HA, Schouten TJ. (1997). Septic arthritis of the hip by Fusobacterium necrophorum after tonsillectomy: a form of Lemierre syndrome?. Eur J Pediatr.
1874 Bell KR, Cyna AM, Lawler KM, et al. (1997). The effect of glossopharyngeal nerve block on pain after elective adult tonsillectomy and uvulopalatoplasty. Anaesthesia.
1875 Bene MC, Faure GC. (1997). From Peyer's patches to tonsils. Specific stimulation with ribosomal immunotherapy. Drugs.
1876 Berrey MM, Shea T. (1997). Oral sex and HIV transmission. J Acquir Immune Defic Syndr Hum Retrovirol.
1877 Biavati MJ, Manning SC, Phillips DL. (1997). Predictive factors for respiratory complications after tonsillectomy and adenoidectomy in children. Arch Otolaryngol Head Neck Surg.
1878 Bisset F. (1997). Glue ear surgery in Scottish children 1990-1994: still plenty of ENT and public health challenges. Clin Otolaryngol Allied Sci.
1879 Blakeslee DB, Jafek BW, Birney JL. (1997). An optimal choice: home intravenous hydration after tonsillectomy. Laryngoscope.
1880 Braverman I, Rosenmann E, Elidan J. (1997). Closed rhinolalia as a symptom of pneumomediastinum after tonsillectomy: a case report and literature review. Otolaryngol Head Neck Surg.
1881 Breslin NP, McDonnell C, O'Morain C. (1997). Surgical and smoking history in inflammatory bowel disease: a case-control study. Inflamm Bowel Dis.
1882 Brook I, Foote PA. (1997). Effect of penicillin or cefprozil therapy on tonsillar flora. J Antimicrob Chemother.
1883 Brook I, Foote PA, Slots J. (1997). Immune response to Fusobacterium nucleatum, Prevotella intermedia and other anaerobes in children with acute tonsillitis. J Antimicrob Chemother.
1884 Browning S, Blanshard J, Baskerville R. (1997). Day case adenoidectomy: is it acceptable to parents?. J R Coll Surg Edinb.
1885 Bunting HE, Allen RW. (1997). Prolonged muscle weakness following emergency tonsillectomy in a patient with familial periodic paralysis and infectious mononucleosis. Paediatr Anaesth.
1886 Burstin PP, Hooper RE. (1997). Massive primary hemorrhage during tonsillectomy from a large venous varicosity. Otolaryngol Head Neck Surg.
1887 Byrns PJ, Bondy J, Glazner JE, et al. (1997). Utilization of services for otitis media by children enrolled in Medicaid. Arch Pediatr Adolesc Med.
1888 Cajulis RS, Gokaslan ST, Yu GH, et al. (1997). Fine needle aspiration biopsy of the salivary glands. A five-year experience with emphasis on diagnostic pitfalls. Acta Cytol.
1889 Candan S, Sapci T, Turkmen M, et al. (1997). Sucralfate in accelerating post-tonsillectomy wound healing. Marmara Medical Journal.
1890 Cannon CR. (1997). Transnasal butorphanol: pain relief in the head and neck patient. Otolaryngol Head Neck Surg.
1891 Carnahan D, Dato K, Hartsuff J. (1997). The safety and efficacy of granisetron in postoperative vomiting in pediatric patients undergoing tonsillectomy. AANA J.
1892 Carr MM, Kolenda J, Clarke KD. (1997). Tonsillectomy: indications for referral by family physicians versus indications for surgery by otolaryngologists. J Otolaryngol.
1893 Chevretton EB, Davis JP. (1997). Tonsillitis: its causes, management and possible complications. Int J Clin Pract.
1894 Chinn K, Brown OE, Manning SC, et al. (1997). Middle ear pressure variation: effect of nitrous oxide. Laryngoscope.
1895 Chomarat M, Panteix G, Guillaumond B, et al. (1997). Tonsillar diffusion kinetics of amoxycillin after oral administration of 1 g to adults. European journal of drug metabolism and pharmacokinetics.
1896 Coad NA, Jones TJ, Muir KR, et al. (1997). Analysis of ploidy and proliferative activity in childhood non-Hodgkin's lymphoma (NHL) and Hodgkin's disease (HD). Pediatr Pathol Lab Med.
1897 Cocuzza CE, Mattina R, Mazzariol A, et al. (1997). High incidence of erythromycin-resistant Streptococcus pyogenes in Monza (North Italy) in untreated children with symptoms of acute pharyngo-tonsillitis: an epidemiological and molecular study. Microb Drug Resist.
1898 Cohen SR, Lefaivre JF, Burstein FD, et al. (1997). Surgical treatment of obstructive sleep apnea in neurologically compromised patients. Plast Reconstr Surg.
1899 Conlon BJ, Donnelly MJ, McShane DP. (1997). Tonsillitis, tonsillectomy and weight disturbance. Int J Pediatr Otorhinolaryngol.
1900 Conlon BJ, Donnelly MJ, McShane DP. (1997). Improvements in health and behaviour following childhood tonsillectomy: a parental perspective at 1 year. Int J Pediatr Otorhinolaryngol.
1901 Cook SP, Borkowski WJ. (1997). Obstructive sleep apnea in Schwartz-Jampel syndrome. Arch Otolaryngol Head Neck Surg.
1902 Cyna AM, Bell KR, Flood LM. (1997). Cervical osteomyelitis following tonsillectomy. Anaesthesia.
1903 de Melker RA, Touw-Otten FW, Kuyvenhoven MM. (1997). Transcultural differences in illness behaviour and clinical outcome: an underestimated aspect of general practice?. Fam Pract.
1904 Delanghe G, Ghyselen J, Feenstra L, et al. (1997). Experiences of a Belgian multidisciplinary breath odour clinic. Acta Otorhinolaryngol Belg.
1905 Dibbets JM, Trotman CA, McNamara JA, et al. (1997). Multiple linear regression as an analytical tool in cephalometric studies. Br J Orthod.
1906 Donaldson C, Farrar S, Mapp T, et al. (1997). Assessing community values in health care: is the ‘willingness to pay’ method feasible?. Health Care Anal.
1907 Drake-Lee A, Weiner G. (1997). Suitability of children for ENT day case procedures. Clin Otolaryngol Allied Sci.
1908 Dundar A, Gerek M, Ozunlu A, et al. (1997). Patient selection and surgical results in obstructive sleep apnea. Eur Arch Otorhinolaryngol.
1909 Egeli E, Akkaya S. (1997). The effect of peritonsillar corticosteroid infiltration in tonsillectomy. Auris Nasus Larynx.
1910 Elhakim M, Abdul Salam AY, Eid A, et al. (1997). Inclusion of pethidine in lidocaine for infiltration improves analgesia following tonsillectomy in children. Acta Anaesthesiol Scand.
1911 Facer C, Khan G. (1997). Detection of EBV RNA (EBER-1 and EBER-2) in malaria lymph nodes by in situ hybridization. Microbiol Immunol.
1912 Fechner RE. (1997). Value-based surgical pathology: a valuable concept. Am J Clin Pathol.
1913 Ficnar B, Huzjak N, Oreskovic K, et al. (1997). Azithromycin: 3-day versus 5-day course in the treatment of respiratory tract infections in children. Croatian Azithromycin Study Group. J Chemother.
1914 Filiaci F, Zambetti G, Lovecchio A, et al. (1997). Nasal hypersensitivity and recurrent adenoids disease. Allergol Immunopathol (Madr).
1915 Fina DK. (1997). Is it only a tonsillectomy?. AORN J.
1916 Finkelstein Y, Malik Z, Kopolovic J, et al. (1997). Characterization of smoking-induced nasopharyngeal lymphoid hyperplasia. Laryngoscope.
1917 Finkelstein Y, Ophir D. (1997). One-stage laser-assisted uvulopalatoplasty. J Otolaryngol.
1918 Flomenberg P, Gutierrez E, Piaskowski V, et al. (1997). Detection of adenovirus DNA in peripheral blood mononuclear cells by polymerase chain reaction assay. J Med Virol.
1919 Foley PJ, Beste DJ, Farber NE. (1997). Massive blood loss during tonsillectomy in a child with congenital venous malformation. Paediatr Anaesth.
1920 Forrest JB, Heitlinger EL, Revell S. (1997). Ketorolac for postoperative pain management in children. Drug Saf.
1921 Friedman NR, Mitchell RB, Pereira KD, et al. (1997). Peritonsillar abscess in early childhood. Presentation and management. Arch Otolaryngol Head Neck Surg.
1922 Fujimori I, Kikushima K, Hisamatsu K, et al. (1997). Interaction between oral alpha-streptococci and group A streptococci in patients with tonsillitis. Ann Otol Rhinol Laryngol.
1923 Gangopadhyay K, Mahasin ZZ, Kfoury H, et al. (1997). Inflammatory myofibroblastic tumour of the tonsil. J Laryngol Otol.
1924 Gaskill JR. (1997). Overmedication in outpatient tonsillectomy. Arch Otolaryngol Head Neck Surg.
1925 Gerard JM, Garibaldi L, Myers SE, et al. (1997). Sleep apnea in patients receiving growth hormone. Clin Pediatr (Phila).
1926 Gillis JC, Brogden RN. (1997). Ketorolac. A reappraisal of its pharmacodynamic and pharmacokinetic properties and therapeutic use in pain management. Drugs.
1927 Glushakova S, Baibakov B, Zimmerberg J, et al. (1997). Experimental HIV infection of human lymphoid tissue: correlation of CD4+ T cell depletion and virus syncytium-inducing/non-syncytium-inducing phenotype in histocultures inoculated with laboratory strains and patient isolates of HIV type 1. AIDS Res Hum Retroviruses.
1928 Goode K, Laeder C. (1997). A comparison of the efficacy of intravenous granisetron and ondansetron in preventing postoperative vomiting in pediatric tonsillectomy and adenoidectomy procedures. Journal of the American Association of Nurse Anesthetists.
1929 Green KM, Pantelides E, de Carpentier JP. (1997). Tonsillar metastasis from a renal cell carcinoma presenting as a quinsy. J Laryngol Otol.
1930 Habre W, McLeod B. (1997). Analgesic and respiratory effect of nalbuphine and pethidine for adenotonsillectomy in children with obstructive sleep disorder. Anaesthesia.
1931 Hague K, Catalano P, Rothschild M, et al. (1997). Posttransplant lymphoproliferative disease presenting as sudden respiratory arrest in a three-year-old child. Ann Otol Rhinol Laryngol.
1932 Hall MJ, Kozak LJ, Gillum BS. (1997). National Survey of Ambulatory Surgery: 1994. Stat Bull Metrop Insur Co.
1933 Halvorson DJ, McKie V, McKie K, et al. (1997). Sickle cell disease and tonsillectomy. Preoperative management and postoperative complications. Arch Otolaryngol Head Neck Surg.
1934 Hampton SM, Cinnamond MJ. (1997). Subcutaneous emphysema as a complication of tonsillectomy. J Laryngol Otol.
1935 Hanna E, Wanamaker J, Adelstein D, et al. (1997). Extranodal lymphomas of the head and neck. A 20-year experience. Arch Otolaryngol Head Neck Surg.
1936 Hofer C, Binns HJ, Tanz RR. (1997). Strategies for managing group A streptococcal pharyngitis. A survey of board-certified pediatricians. Arch Pediatr Adolesc Med.
1937 Hone SW, Moodley S, Donnelly MJ, et al. (1997). The effect of tonsillectomy on eustachian tube function. Clin Otolaryngol Allied Sci.
1938 Houghton DJ, Camilleri AE, Stone P. (1997). Adult obstructive sleep apnoea syndrome and tonsillectomy. J Laryngol Otol.
1939 Howells RC, Wax MK, Ramadan HH. (1997). Value of preoperative prothrombin time/partial thromboplastin time as a predictor of postoperative hemorrhage in pediatric patients undergoing tonsillectomy. Otolaryngol Head Neck Surg.
1940 Hui S, Wing YW. (1997). Obstructive sleep apnoea syndrome in children. Hong Kong Med J.
1941 Irani DB, Berkowitz RG. (1997). Management of secondary hemorrhage following pediatric adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
1942 Ivarsson M, Ebenfelt A, Lundberg C. (1997). Do the leukocytes in the surface secretion on the adenoid have an immunological function?. Acta Otolaryngol.
1943 Jacobs IN, Teague WG, Bland JW. (1997). Pulmonary vascular complications of chronic airway obstruction in children. Arch Otolaryngol Head Neck Surg.
1944 Jero J, Karma P. (1997). Bacteriological findings and persistence of middle ear effusion in otitis media with effusion. Acta Otolaryngol Suppl.
1945 Jero J, Virolainen A, Virtanen M, et al. (1997). Prognosis of acute otitis media: factors associated with poor outcome. Acta Otolaryngol.
1946 Jones TM, Temple RH, Morar P, et al. (1997). General practitioner consultations after a paediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
1947 Kanegane H, Kanegane C, Yachie A, et al. (1997). Infectious mononucleosis as a disease of early childhood in Japan caused by primary Epstein-Barr virus infection. Acta Paediatr Jpn.
1948 Karajannis MA, Hummel M, Anagnostopoulos I, et al. (1997). Strict lymphotropism of Epstein-Barr virus during acute infectious mononucleosis in nonimmunocompromised individuals. Blood.
1949 Karas DE, Sawin RS, Sie KC. (1997). Pseudoaneursym of the external carotid artery after tonsillectomy. A rare complication. Arch Otolaryngol Head Neck Surg.
1950 Kearsley NL, Campbell A, Sanderson AA, et al. (1997). Comparison of clarithromycin suspension and amoxycillin syrup for the treatment of children with pharyngitis and/or tonsillitis. Br J Clin Pract.
1951 Kellogg JX, Piatt JH. (1997). Resection of fourth ventricle tumors without splitting the vermis: the cerebellomedullary fissure approach. Pediatr Neurosurg.
1952 Kerakawauchi H, Kurono Y, Mogi G. (1997). Immune responses against Streptococcus pyogenes in human palatine tonsils. Laryngoscope.
1953 Kiesewetter H. (1997). Use of desmopressin in younger patients. Research and Clinical Forums.
1954 Klijanienko J, Vielh P. (1997). Fine-needle sampling of salivary gland lesions. III. Cytologic and histologic correlation of 75 cases of adenoid cystic carcinoma: review and experience at the Institut Curie with emphasis on cytologic pitfalls. Diagn Cytopathol.
1955 Koivunen P, Alho OP, Uhari M, et al. (1997). Minitympanometry in detecting middle ear fluid. J Pediatr.
1956 Kokki H, Ahonen R. (1997). Pain and activity disturbance after paediatric day case adenoidectomy. Paediatr Anaesth.
1957 Koltai PJ, Kalathia AS, Stanislaw P, et al. (1997). Power-assisted adenoidectomy. Arch Otolaryngol Head Neck Surg.
1958 Kotiniemi LH, Ryhanen PT, Valanne J, et al. (1997). Postoperative symptoms at home following day-case surgery in children: a multicentre survey of 551 children. Anaesthesia.
1959 Koumantaki Y, Giziaki E, Kaklamani E. (1997). Do appendectomy and tonsillectomy reduce the risk of rheumatoid arthritis?. J Rheumatol.
1960 Kudoh A, Sakai T, Ishihara H, et al. (1997). Increase in serum creatine phosphokinase concentrations after suxamethonium during sevoflurane or isoflurane anaesthesia in children. Br J Anaesth.
1961 Kujawski O, Dulguerov P, Gysin C, et al. (1997). Microscopic tonsillectomy: a double-blind randomized trial. Otolaryngol Head Neck Surg.
1962 Lapeyre M, Malissard L, Peiffert D, et al. (1997). Cervical lymph node metastasis from an unknown primary: is a tonsillectomy necessary?. Int J Radiat Oncol Biol Phys.
1963 Lassaletta L, Martin G, Villafruela MA, et al. (1997). Pediatric tonsillectomy: post-operative morbidity comparing microsurgical bipolar dissection versus cold sharp dissection. Int J Pediatr Otorhinolaryngol.
1964 Lavy J, Rea P. (1997). The use of chewing gum in the first post-operative week following tonsillectomy. A prospective randomised controlled study.
1965 Lavy JA. (1997). Post-tonsillectomy pain: the difference between younger and older patients. Int J Pediatr Otorhinolaryngol.
1966 Lawhorn CD, Kymer PJ, Stewart FC, et al. (1997). Ondansetron dose response curve in high-risk pediatric patients. J Clin Anesth.
1967 Lawson MJ, Lapinski BJ, Velasco EC. (1997). Tonsillectomy and adenoidectomy pathway plan of care for the pediatric patient in day surgery. J Perianesth Nurs.
1968 Lee D, Rosenfeld RM. (1997). Adenoid bacteriology and sinonasal symptoms in children. Otolaryngol Head Neck Surg.
1969 Liaw KL, Adami J, Gridley G, et al. (1997). Risk of Hodgkin's disease subsequent to tonsillectomy: a population-based cohort study in Sweden. Int J Cancer.
1970 Linder TE, Marder HP, Munzinger J. (1997). Role of adenoids in the pathogenesis of otitis media: a bacteriologic and immunohistochemical analysis. Ann Otol Rhinol Laryngol.
1971 Little P, Gould C, Williamson I, et al. (1997). Reattendance and complications in a randomised trial of prescribing strategies for sore throat: the medicalising effect of prescribing antibiotics. BMJ.
1972 Little P, Williamson I, Warner G, et al. (1997). Open randomised trial of prescribing strategies in managing sore throat. BMJ.
1973 Lomat L, Galburt G, Quastel MR, et al. (1997). Incidence of childhood disease in Belarus associated with the Chernobyl accident. Environ Health Perspect.
1974 Maeda H, Iranami H, Hatano Y. (1997). Delayed recovery from muscle weakness due to malignant hyperthermia during sevoflurane anesthesia. Anesthesiology.
1975 Manni JJ. (1997). Re: General practitioner consultations after a paediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
1976 Mansoor A, Stevenson MS, Li RZ, et al. (1997). Prevalence of Epstein-Barr viral sequences and EBV LMP1 oncogene deletions in Burkitt's lymphoma from Pakistan: epidemiological correlations. Hum Pathol.
1977 Marcus CL. (1997). Management of obstructive sleep apnea in childhood. Curr Opin Pulm Med.
1978 Marcus CL. (1997). Clinical and pathophysiological aspects of obstructive sleep apnea in children. Pediatr Pulmonol Suppl.
1979 Marcus SM. (1997). Assessing non-consent bias with parallel randomized and nonrandomized clinical trials. J Clin Epidemiol.
1980 Maw J, Marsan J. (1997). Uvulopalatopharyngoplasty versus laser-assisted uvulopalatopharyngoplasty in the treatment of snoring. Journal of otolaryngology.
1981 McConnochie KM, Roghmann KJ, Liptak GS. (1997). Socioeconomic variation in discretionary and mandatory hospitalization of infants: an ecologic analysis. Pediatrics.
1982 McEwan JA, Dhingra J, Rowe-Jones J, et al. (1997). Parapharyngeal abscess: a rare complication of elective tonsillectomy. J Laryngol Otol.
1983 McLaughlin KE, Jacobs IN, Todd NW, et al. (1997). Management of nasopharyngeal and oropharyngeal stenosis in children. Laryngoscope.
1984 Messner AH, Barbita JA. (1997). Oral fluid intake following tonsillectomy. Int J Pediatr Otorhinolaryngol.
1985 Miller RC, Foote RL, Coffey RJ, et al. (1997). The role of stereotactic radiosurgery in the treatment of malignant skull base tumors. Int J Radiat Oncol Biol Phys.
1986 Minocha A, Raczkowski CA. (1997). Role of appendectomy and tonsillectomy in pathogenesis of ulcerative colitis. Dig Dis Sci.
1987 Minocha A, Raczkowski CA, Richards RJ. (1997). Is a history of tonsillectomy associated with a decreased risk of Helicobacter pylori infection?. J Clin Gastroenterol.
1988 Mitchell RB, Pereira KD, Friedman NR, et al. (1997). Outpatient adenotonsillectomy. Is it safe in children younger than 3 years?. Arch Otolaryngol Head Neck Surg.
1989 Mitchell RB, Pereira KD, Lazar RH, et al. (1997). Pseudoaneurysm of the right lingual artery: an unusual cause of severe hemorrhage during tonsillectomy. Ear Nose Throat J.
1990 Mitchell V, Grange C, Black A, et al. (1997). A comparison of midazolam with trimeprazine as an oral premedicant for children. Anaesthesia.
1991 Mizutani H, Ohmoto Y, Mizutani T, et al. (1997). Role of increased production of monocytes TNF-alpha, IL-1beta and IL-6 in psoriasis: relation to focal infection, disease activity and responses to treatments. J Dermatol Sci.
1992 Morrison JE, Lane G, Kelly S, et al. (1997). The Jehovah's Witness family, transfusions, and pediatric day surgery. Int J Pediatr Otorhinolaryngol.
1993 Morton NS, Camu F, Dorman T, et al. (1997). Ondansetron reduces nausea and vomiting after paediatric adenotonsillectomy. Paediatr Anaesth.
1994 Mostafa BE. (1997). Detection of adenoidal hypertrophy using acoustic rhinomanometry. Eur Arch Otorhinolaryngol.
1995 Nadal D, Guzman J, Frohlich S, et al. (1997). Human immunoglobulin preparations suppress the occurrence of Epstein-Barr virus-associated lymphoproliferation. Exp Hematol.
1996 Netser JC, Robinson RA, Smith RJ, et al. (1997). Value-based pathology: a cost-benefit analysis of the examination of routine and nonroutine tonsil and adenoid specimens. Am J Clin Pathol.
1997 Neumann AM, Wiatrak BJ. (1997). Erbe constant voltage electrocautery versus conventional variable voltage electrocautery for tonsillectomy in children. Int J Pediatr Otorhinolaryngol.
1998 Nicholson IC, Lenton KA, Little DJ, et al. (1997). Construction and characterisation of a functional CD19 specific single chain Fv fragment for immunotherapy of B lineage leukaemia and lymphoma. Mol Immunol.
1999 Nieminen P, Tolonen U, Lopponen H, et al. (1997). Snoring children: factors predicting sleep apnea. Acta Otolaryngol Suppl.
2000 Nikanne E, Kokki H, Tuovinen K. (1997). Comparison of perioperative ketoprofen 2.0 mg kg-1 with 0.5 mg kg-1 i.v. in small children during adenoidectomy. Br J Anaesth.
2001 Nikanne E, Kokki H, Tuovinen K. (1997). IV perioperative ketoprofen in small children during adenoidectomy. Br J Anaesth.
2002 O'Dwyer TP, Conlon BJ. (1997). The surgical management of drooling--a 15 year follow-up. Clin Otolaryngol Allied Sci.
2003 Onerci M, Kus S, Ogretmenoglu O. (1997). Trace elements in children with chronic and recurrent tonsillitis. Int J Pediatr Otorhinolaryngol.
2004 Onerci M, Ogretmenoglu O, Ozcan OE. (1997). Atlantoaxial subluxation after tonsillectomy and adenoidectomy. Otolaryngol Head Neck Surg.
2005 Orrling A, Stjernquist-Desatnik A, Schalen C. (1997). Clindamycin in recurrent group A streptococcal pharyngotonsillitis--an alternative to tonsillectomy?. Acta Otolaryngol.
2006 Osterlund A, Engstrand L. (1997). An intracellular sanctuary for Streptococcus pyogenes in human tonsillar epithelium--studies of asymptomatic carriers and in vitro cultured biopsies. Acta Otolaryngol.
2007 Osterlund A, Popa R, Nikkila T, et al. (1997). Intracellular reservoir of Streptococcus pyogenes in vivo: a possible explanation for recurrent pharyngotonsillitis. Laryngoscope.
2008 Padmore L, An S, Gunby RH, et al. (1997). CD40-triggered protein tyrosine phosphorylation on Vav and on phosphatidylinositol 3-kinase correlates with survival of the Ramos-Burkitt lymphoma B cell line. Cell Immunol.
2009 Park JK, Gleason PL, Madsen JR, et al. (1997). Presentation and management of Chiari I malformation in children. Pediatr Neurosurg.
2010 Parrello T, Pavia M, Angelillo IF, et al. (1997). Appendectomy is an independent protective factor for ulcerative colitis: results of a multicentre case control study. The Italian Group for the Study of the Colon and Rectum (GISC). Ital J Gastroenterol Hepatol.
2011 Patel RI, DeWitt L, Hannallah RS. (1997). Preoperative laboratory testing in children undergoing elective surgery: analysis of current practice. J Clin Anesth.
2012 Pearson CR, Wallace HC. (1997). The tonsil cup: a simple teaching aid for tonsillectomy. J Laryngol Otol.
2013 Pichichero ME. (1997). Sore throat after sore throat after sore throat. Are you asking the critical questions?. Postgrad Med.
2014 Postma DS, Poole MD, Wu SM, et al. (1997). The impact of day care on ventilation tube insertion. Int J Pediatr Otorhinolaryngol.
2015 Preutthipan A, Suwanjutha S, Chantarojanasiri T. (1997). Obstructive sleep apnea syndrome in Thai children diagnosed by polysomnography. Southeast Asian J Trop Med Public Health.
2016 Prince ME, Nasser JG, Pass BB. (1997). Effect of upper-airway passages on craniofacial growth in an animal model: a pilot study. J Otolaryngol.
2017 Rakover Y, Almog R, Rosen G. (1997). The risk of postoperative haemorrhage in tonsillectomy as an outpatient procedure in children. Int J Pediatr Otorhinolaryngol.
2018 Ramamoorthy C, Williams GD, Stevenson JG. (1997). Reversible pulmonary hypertension due to adenotonsillar hypertrophy in a patient for Fontan operation. Clin Pediatr (Phila).
2019 Ramamurthy L, Wyatt RA, Whitby D, et al. (1997). The evaluation of velopharyngeal function using flexible nasendoscopy. J Laryngol Otol.
2020 Ramirez MGI, Gonzalez AC, Gardea JA, et al. (1997). Pain control in tonsillectomized patients with bupivacaine infiltration in the postoperative period. Anestesia En Mexico.
2021 Ravi KV, Brooks JR. (1997). Peritonsillar abscess--an unusual presentation of Kawasaki disease. J Laryngol Otol.
2022 Robinson AC, Hanif J, Dumbreck LA, et al. (1997). Throat swabs in chronic tonsillitis: a time-honoured practice best forgotten. Br J Clin Pract.
2023 Rodrigo C. (1997). Prevention of acute otitis media. Clin Microbiol Infect.
2024 Rohrer JE, Vaughan M. (1997). Monitoring health care system performance in Iowa. Health Serv Manage Res.
2025 Rosa JC, Felix A, Fonseca I, et al. (1997). Immunoexpression of c-erbB-2 and p53 in benign and malignant salivary neoplasms with myoepithelial differentiation. J Clin Pathol.
2026 Schoem SR, Choi SS, Zalzal GH, et al. (1997). Management of oropharyngeal trauma in children. Arch Otolaryngol Head Neck Surg.
2027 Seid M, Sherman M, Seid AB. (1997). Perioperative psychosocial interventions for autistic children undergoing ENT surgery. Int J Pediatr Otorhinolaryngol.
2028 Shah C, Griffiths M, Moralee S. (1997). Direct listing for adult tonsillectomy. J R Coll Surg Edinb.
2029 Shehab ZP, Robin PE. (1997). Comparison of the effectiveness of uvulopalatopharyngoplasty and laser palatoplasty for snoring. Clin Otolaryngol Allied Sci.
2030 Shintani T, Asakura K, Kataura A. (1997). Evaluation of the role of adenotonsillar hypertrophy and facial morphology in children with obstructive sleep apnea. ORL J Otorhinolaryngol Relat Spec.
2031 Short JA, Melillo EP. (1997). Damage to a laryngeal mask during tonsillectomy. Anaesthesia.
2032 Shyr MH, Ho AC, Lin CC, et al. (1997). Propofol anesthesia in a patient with Isaacs syndrome--report of a case and literature review. Acta Anaesthesiol Sin.
2033 Siddiqui N, Yung MW. (1997). Day-case adenoidectomy: how popular and safe in a rural environment?. J Laryngol Otol.
2034 Sie KC, Perkins JA, Clarke WR. (1997). Acute right heart failure due to adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
2035 Smith JD. (1997). What you need to know: tonsillitis--medical and surgical therapy. Singapore Med J.
2036 Soto HM, Parra G, Rodriguez-Itrube B. (1997). Circulating levels of cytokines in poststreptococcal glomerulonephritis. Clin Nephrol.
2037 Spiegel JR, Sataloff RT, Emerich KA. (1997). The young adult voice. J Voice.
2038 Splinter W, Roberts DJ. (1997). Prophylaxis for vomiting by children after tonsillectomy: dexamethasone versus perphenazine. Anesth Analg.
2039 Splinter WM, Rhine EJ. (1997). Prophylactic antiemetics in children undergoing tonsillectomy: high-dose vs low-dose ondansetron. Paediatr Anaesth.
2040 Splinter WM, Roberts DJ. (1997). Perphenazine decreases vomiting by children after tonsillectomy. Can J Anaesth.
2041 St Charles CS, Matt BH, Hamilton MM, et al. (1997). A comparison of ibuprofen versus acetaminophen with codeine in the young tonsillectomy patient. Otolaryngol Head Neck Surg.
2042 Stenfors LE, Fredriksen F, Raisanen S, et al. (1997). Identification of Streptococcus pyogenes on tonsillar epithelium during infection. Acta Otolaryngol Suppl.
2043 Stewart MG, Harrill WC, Ohlms LA. (1997). The effects of an outpatient practice guideline at a teaching hospital: a prospective pilot study. Otolaryngol Head Neck Surg.
2044 Stjernquist-Desatnik A, Orrling A, Schalen C, et al. (1997). Clindamycin in recurrent group A streptococcal pharyngotonsillitis. An alternative to tonsillectomy?. Adv Exp Med Biol.
2045 Sutters KA, Miaskowski C. (1997). Inadequate pain management and associated morbidity in children at home after tonsillectomy. J Pediatr Nurs.
2046 Tajima K, Sato S, Miyabe M. (1997). A case of acute pulmonary edema and bulbar paralysis after local epinephrine infiltration. J Clin Anesth.
2047 Takahashi H, Honjo I, Fujita A, et al. (1997). Effects of adenoidectomy on sinusitis. Acta Otorhinolaryngol Belg.
2048 Talbott GA, Lynn AM, Levy FH, et al. (1997). Respiratory arrest precipitated by codeine in a child with chronic renal failure. Clin Pediatr (Phila).
2049 Tellado MV, McLean IW, Specht CS, et al. (1997). Adenoid cystic carcinomas of the lacrimal gland in childhood and adolescence. Ophthalmology.
2050 Thompson DN, Harkness W, Jones BM, et al. (1997). Aetiology of herniation of the hindbrain in craniosynostosis. An investigation incorporating intracranial pressure monitoring and magnetic resonance imaging. Pediatr Neurosurg.
2051 Thompson LD. (1997). Diagnostically challenging lesions in head and neck pathology. Eur Arch Otorhinolaryngol.
2052 Trotman CA, McNamara JA, Dibbets JM, et al. (1997). Association of lip posture and the dimensions of the tonsils and sagittal airway with facial morphology. Angle Orthod.
2053 Van Kruiningen HJ, Ganley LM, Freda BJ. (1997). The role of Peyer's patches in the age-related incidence of Crohn's disease. J Clin Gastroenterol.
2054 Vanaclocha V, Saiz-Sapena N, Garcia-Casasola MC. (1997). Surgical technique for cranio-cervical decompression in syringomyelia associated with Chiari type I malformation. Acta Neurochir (Wien).
2055 Vandenberg SJ, Heatley DG. (1997). Efficacy of adenoidectomy in relieving symptoms of chronic sinusitis in children. Arch Otolaryngol Head Neck Surg.
2056 Vartanian AJ, Alvi A. (1997). Lingual nerve palsy following tonsillectomy. J Otolaryngol.
2057 Vartiainen E, Vartiainen J. (1997). Tympanoplasty in young patients: the role of adenoidectomy. Otolaryngol Head Neck Surg.
2058 Vasilevsky CA, Abou-Khalil S, Rochon L, et al. (1997). Carcinoma of the colon presenting as tonsillar metastasis. J Otolaryngol.
2059 Viguer JM, Vicandi B, Jimenez-Heffernan JA, et al. (1997). Fine needle aspiration cytology of pleomorphic adenoma. An analysis of 212 cases. Acta Cytol.
2060 Vucicevic Z, Suskovic T. (1997). Acute respiratory distress syndrome after aprotinin infusion. Ann Pharmacother.
2061 Walsh RM, Kumar BN, Tse A, et al. (1997). Post-tonsillectomy bacteraemia in children. J Laryngol Otol.
2062 Wang DY, Bernheim N, Kaufman L, et al. (1997). Assessment of adenoid size in children by fibreoptic examination. Clin Otolaryngol Allied Sci.
2063 Weingarten C. (1997). Ultrasonic tonsillectomy: rationale and technique. Otolaryngol Head Neck Surg.
2064 Wengraf C. (1997). Management of enuresis. Lancet.
2065 Wiet GJ, Bower C, Seibert R, et al. (1997). Surgical correction of obstructive sleep apnea in the complicated pediatric patient documented by polysomnography. Int J Pediatr Otorhinolaryngol.
2066 Wimalasundera SS, Katz DR, Chain BM. (1997). Characterization of the T cell response to human rhinovirus in children: implications for understanding the immunopathology of the common cold. J Infect Dis.
2067 Wolfe F, Anderson J, Harkness D, et al. (1997). A prospective, longitudinal, multicenter study of service utilization and costs in fibromyalgia. Arthritis Rheum.
2068 Wright ED, Manoukian JJ, Shapiro RS. (1997). Ablative adenoidectomy: a new technique using simultaneous liquefaction/aspiration. J Otolaryngol.
2069 Zestos MM, Carr AS, McAuliffe G, et al. (1997). Subhypnotic propofol does not treat postoperative vomiting in children after adenotonsillectomy. Can J Anaesth.
2070 Zhu QR, White FH, Tipoe GL. (1997). p53 oncoprotein accumulation in adenoid cystic carcinoma of parotid and palatine salivary glands. Pathology.
2071 Zwack GC, Derkay CS. (1997). The utility of preoperative hemostatic assessment in adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
2072 (1998). Ignition of debris on active electrosurgical electrodes. Health Devices.
2073 Aarons L, Rowland M, Khan A, et al. (1998). Plasma and tonsillar tissue pharmacokinetics of teicoplanin following intramuscular administration to children. Eur J Pharm Sci.
2074 Abdel-Moula AM, Sherif AA, Sallam SA, et al. (1998). Prevalence of rheumatic heart disease among school children in Alexandria, Egypt: a prospective epidemiological study. J Egypt Public Health Assoc.
2075 Aboul Fotouh AM, el-Damaty SE, Abdel Megeid FY. (1998). Mother's knowledge about antibiotic and role of self prescription. J Egypt Public Health Assoc.
2076 Agren K, Brauner A, Andersson J. (1998). Haemophilus influenzae and Streptococcus pyogenes group A challenge induce a Th1 type of cytokine response in cells obtained from tonsillar hypertrophy and recurrent tonsillitis. ORL J Otorhinolaryngol Relat Spec.
2077 Agren K, Nordlander B, Linder-Aronsson S, et al. (1998). Children with nocturnal upper airway obstruction: postoperative orthodontic and respiratory improvement. Acta Otolaryngol.
2078 Alvi A, Vartanian AJ. (1998). Microscopic examination of routine tonsillectomy specimens: is it necessary?. Otolaryngol Head Neck Surg.
2079 Ang C, Habre W, Sims C. (1998). Tropisetron reduces vomiting after tonsillectomy in children. Br J Anaesth.
2080 Annila P, Rorarius M, Reinikainen P, et al. (1998). Effect of pre-treatment with intravenous atropine or glycopyrrolate on cardiac arrhythmias during halothane anaesthesia for adenoidectomy in children. Br J Anaesth.
2081 Arkkila E, Sipila J, Laurikainen E, et al. (1998). Peritonsillar abscess associated with infectious mononucleosis. ORL J Otorhinolaryngol Relat Spec.
2082 Arshad AR. (1998). Parotid swellings: report of 110 consecutive cases. Med J Malaysia.
2083 Aslam M, Mustafa G. (1998). Prophylactic antibiotics for tonsillectomy: Experience at Rawalpindi General Hospital. Journal of the College of Physicians and Surgeons--Pakistan : JCPSP.
2084 Atra A, Meller ST, Stevens RS, et al. (1998). Conservative management of follicular non-Hodgkin's lymphoma in childhood. Br J Haematol.
2085 Au WY, Chan AC, Kwong YL. (1998). Scrotal skin ulcer in a patient with a previous tonsillectomy because of natural killer cell lymphoma. Am J Dermatopathol.
2086 Avramovic V, Vlahovic P, Savic V, et al. (1998). Localisation of ecto-5'-nucleotidase and divalent cation-activated ecto-ATPase in chronic tonsillitis. ORL J Otorhinolaryngol Relat Spec.
2087 Avramovic V, Vlahovic P, Stankovic M, et al. (1998). Divalent cation-activated-ATPase and ecto 5'-nucleotidase activities in chronic tonsillitis. Arch Physiol Biochem.
2088 Beaty MM, Funk GF, Karnell LH, et al. (1998). Risk factors for malignancy in adult tonsils. Head Neck.
2089 Benning TL. (1998). Methods for cost-effectiveness study. Am J Clin Pathol.
2090 Berger MS. (1998). Throat disorders. Prim Care.
2091 Bevanger L, Bergh K, Gisnas G, et al. (1998). Identification of nasopharyngeal carriage of an outbreak strain of Neisseria meningitidis by pulsed-field gel electrophoresis versus phenotypic methods. J Med Microbiol.
2092 Bhaskar K. (1998). Diet following tonsillectomy. Paediatr Nurs.
2093 Bodey B, Bodey B, Siegel SE, et al. (1998). Upregulation of endoglin (CD105) expression during childhood brain tumor-related angiogenesis. Anti-angiogenic therapy. Anticancer Res.
2094 Brooks LJ, Stephens BM, Bacevice AM. (1998). Adenoid size is related to severity but not the number of episodes of obstructive apnea in children. J Pediatr.
2095 Brown PM, Fowler S, Ryan R, et al. (1998). ENT day surgery in England and Wales--an audit by the Royal College of Surgeons (Eng.) Comparative Audit Service. J Laryngol Otol.
2096 Burstin PP, Marshall CL. (1998). Infectious mononucleosis and bilateral peritonsillar abscesses resulting in airway obstruction. J Laryngol Otol.
2097 Camilleri IG, Malata CM, McLean NR, et al. (1998). Malignant tumours of the submandibular salivary gland: a 15-year review. Br J Plast Surg.
2098 Cannon CR. (1998). Safety protocol for laser-assisted tonsillectomy. Laryngoscope.
2099 Charakorn C. (1998). A comparison of the incidence of post operative bleeding between electric cauterization and suture ligation tonsillectomies. J Med Assoc Thai.
2100 Chen Y, Rennie DC, Lockinger LA, et al. (1998). Effect of environmental tobacco smoke on cough in children with a history of tonsillectomy or adenoidectomy. Eur Respir J.
2101 Chongkolwatana C, Nilsuwan A, Chongvisal S, et al. (1998). Nasopharyngeal tuberculosis. J Med Assoc Thai.
2102 Chow S. (1998). Specialty group differences over tonsillectomy: pediatricians versus otolaryngologists. Qual Health Res.
2103 Cinalli G, Sainte-Rose C, Kollar EM, et al. (1998). Hydrocephalus and craniosynostosis. J Neurosurg.
2104 Clemens J, McMurray JS, Willging JP. (1998). Electrocautery versus curette adenoidectomy: comparison of postoperative results. Int J Pediatr Otorhinolaryngol.
2105 Cook PR, Herr TM, Highfill G. (1998). Diagnosing and treating pediatric allergy. Otolaryngol Head Neck Surg.
2106 Costas-Gastiaburo LA, Rajah V, Rubin J. (1998). Tonsillectomy and the value of peritonsillar infiltrations. S Afr J Surg.
2107 Coulthard KP, Nielson HW, Schroder M, et al. (1998). Relative bioavailability and plasma paracetamol profiles of Panadol suppositories in children. J Paediatr Child Health.
2108 Cremer J, Wallrauch C, Milatovic D, et al. (1998). Azithromycin versus cefaclor in the treatment of pediatric patients with acute group A beta-hemolytic streptococcal tonsillopharyngitis. Eur J Clin Microbiol Infect Dis.
2109 Daftary S, Jagtap SR, Saksena S. (1998). Intravenous Ondansetron in prevention of PONV following tonsillectomy under ether anaesthesia. Journal of Anaesthesiology Clinical Pharmacology.
2110 Dagnelie CF, Bartelink ML, van der Graaf Y, et al. (1998). Towards a better diagnosis of throat infections (with group A beta-haemolytic streptococcus) in general practice. Br J Gen Pract.
2111 Dahlborg SA, Petrillo A, Crossen JR, et al. (1998). The potential for complete and durable response in nonglial primary brain tumors in children and young adults with enhanced chemotherapy delivery. Cancer J Sci Am.
2112 Dawlatly EE, Satti MB, Bohliga LA. (1998). Spontaneous tonsillar hemorrhage: an underdiagnosed condition. J Otolaryngol.
2113 de Silva KS, Gunatunga MW, Perera AJ, et al. (1998). Can group A beta haemolytic streptococcal sore throats be identified clinically?. Ceylon Med J.
2114 Del Mar CB. (1998). Tonsillectomy for sore throat?. Br J Gen Pract.
2115 Drake-Lee A, Stokes M. (1998). A prospective study of the length of stay of 150 children following tonsillectomy and/or adenoidectomy. Clin Otolaryngol Allied Sci.
2116 Dsida RM, Wheeler M, Birmingham PK, et al. (1998). Premedication of pediatric tonsillectomy patients with oral transmucosal fentanyl citrate. Anesth Analg.
2117 Duggan AE, Usmani I, Neal KR, et al. (1998). Appendicectomy, childhood hygiene, Helicobacter pylori status, and risk of inflammatory bowel disease: a case control study. Gut.
2118 Elhakim M, Magady M, Seuam A, et al. (1998). Alkalinisation of lidocaine for multiple level infiltration after tonsillectomy in children. Acta Anaesthesiologica Italica/Anaesthesia & Intensive Care in Italy.
2119 el-Madhun AS, Cox RJ, Soreide A, et al. (1998). Systemic and mucosal immune responses in young children and adults after parenteral influenza vaccination. J Infect Dis.
2120 Erincler T, Luleci N, Tutan A. (1998). Effects of different midazolam doses for rectal premedication in children. Turk Anesteziyoloji Ve Reanimasyon.
2121 Fava C, Ghidoni P, Broich G, et al. (1998). Cardiac malignant lymphoma: a case report. Anticancer Res.
2122 Figueroa JM, Mansilla E, Suburo AM. (1998). Innervation of nasal turbinate blood vessels in rhinitic and nonrhinitic children. Am J Respir Crit Care Med.
2123 Font RL, Smith SL, Bryan RG. (1998). Malignant epithelial tumors of the lacrimal gland: a clinicopathologic study of 21 cases. Arch Ophthalmol.
2124 Fradis M, Goldsher M, David JB, et al. (1998). Life-threatening deep cervical abscess after infiltration of the tonsillar bed for tonsillectomy. Ear Nose Throat J.
2125 Fujii Y, Saitoh Y, Tanaka H, et al. (1998). Comparison of granisetron and droperidol in the prevention of vomiting after strabismus surgery or tonsillectomy in children. Paediatr Anaesth.
2126 Fujii Y, Toyooka H, Tanaka H. (1998). Oral granisetron prevents postoperative vomiting in children. Br J Anaesth.
2127 Fujii Y, Toyooka H, Tanaka H. (1998). A granisetron-droperidol combination prevents postoperative vomiting in children. Anesth Analg.
2128 Gaffney RJ, Cafferkey MT. (1998). Bacteriology of normal and diseased tonsils assessed by fine-needle aspiration: Haemophilus influenzae and the pathogenesis of recurrent acute tonsillitis. Clin Otolaryngol Allied Sci.
2129 Gerson CR. (1998). Technicians or physicians. Otolaryngol Head Neck Surg.
2130 Giannoni C, Sulek M, Friedman EM, et al. (1998). Acquired nasopharyngeal stenosis: a warning and review. Arch Otolaryngol Head Neck Surg.
2131 Goldstein NA, Armfield DR, Kingsley LA, et al. (1998). Postoperative complications after tonsillectomy and adenoidectomy in children with Down syndrome. Arch Otolaryngol Head Neck Surg.
2132 Gozal D. (1998). Sleep-disordered breathing and school performance in children. Pediatrics.
2133 Grundmann U, Uth M, Eichner A, et al. (1998). Total intravenous anaesthesia with propofol and remifentanil in paediatric patients: a comparison with a desflurane-nitrous oxide inhalation anaesthesia. Acta Anaesthesiol Scand.
2134 Guyotat J, Bret P, Jouanneau E, et al. (1998). Syringomyelia associated with type I Chiari malformation. A 21-year retrospective study on 75 cases treated by foramen magnum decompression with a special emphasis on the value of tonsils resection. Acta Neurochir (Wien).
2135 Halpern LR, Chase DC, Gerard DA, et al. (1998). Temporomandibular disorders: clinical and laboratory analyses for risk assessment of criteria for surgical therapy, a pilot study. Cranio.
2136 Hamid SK, Selby IR, Sikich N, et al. (1998). Vomiting after adenotonsillectomy in children: a comparison of ondansetron, dimenhydrinate, and placebo. Anesth Analg.
2137 Han JI, Lee GY, Lee CH. (1998). Effect of Intravenous Ketorolac on Postoperative Pain after Tonsillectomy in Small Children. Korean Journal of Anesthesiology.
2138 Harley EH, Dattolo RA. (1998). Ibuprofen for tonsillectomy pain in children: efficacy and complications. Otolaryngol Head Neck Surg.
2139 Hartley BE, Papsin BC, Albert DM. (1998). Suction diathermy adenoidectomy. Clin Otolaryngol Allied Sci.
2140 Heras HA, Koltai PJ. (1998). Safety of powered instrumentation for adenoidectomy. Int J Pediatr Otorhinolaryngol.
2141 Hicks WL, Kuriakose MA, Loree TR, et al. (1998). Surgery versus radiation therapy as single-modality treatment of tonsillar fossa carcinoma: the Roswell Park Cancer Institute experience (1971-1991). Laryngoscope.
2142 Huang HM, Chao MC, Chen YL, et al. (1998). A combined method of conventional and endoscopic adenoidectomy. Laryngoscope.
2143 Hunter AG, Bankier A, Rogers JG, et al. (1998). Medical complications of achondroplasia: a multicentre patient review. J Med Genet.
2144 Ide C, Bodart E, Remacle M, et al. (1998). An early MR observation of carotid involvement by retropharyngeal abscess. AJNR Am J Neuroradiol.
2145 Ikeda K, Oshima T, Shimomura A, et al. (1998). Surgical criteria for obstructive sleep apnea syndrome based on localization of upper airway collapse during sleep: a preliminary study. Tohoku J Exp Med.
2146 Isaacson G, Szeremeta W. (1998). Pediatric tonsillectomy with bipolar electrosurgical scissors. Am J Otolaryngol.
2147 Isono S, Shimada A, Utsugi M, et al. (1998). Comparison of static mechanical properties of the passive pharynx between normal children and children with sleep-disordered breathing. Am J Respir Crit Care Med.
2148 Iwaki E, Saito T, Tsuda G, et al. (1998). Timing for removal of tympanic ventilation tube in children. Auris Nasus Larynx.
2149 Kaatsch P, Kaletsch U, Meinert R, et al. (1998). German case control study on childhood leukaemia--basic considerations, methodology and summary of the results. Klin Padiatr.
2150 Kamiyoshihara M, Hirai T, Kawashima O, et al. (1998). Low-grade malignant tumors of the lung: is lymph node dissection necessary?. Oncol Rep.
2151 Katsuura M, Shimizu Y, Akiba K, et al. (1998). CD48 expression on leukocytes in infectious diseases: flow cytometric analysis of surface antigen. Acta Paediatr Jpn.
2152 Kawamata T, Omote K, Kawamata M, et al. (1998). Premedication with oral dextromethorphan reduces postoperative pain after tonsillectomy. Anesth Analg.
2153 Kawamoto R, Asai Y, Nago N, et al. (1998). A study of clinical features and treatment of acute bronchitis by Japanese primary care physicians. Fam Pract.
2154 Kearney R, Mack C, Entwistle L. (1998). Withholding oral fluids from children undergoing day surgery reduces vomiting. Paediatr Anaesth.
2155 Kharb S, Yadav SP, Singh H, et al. (1998). Effect of adenotonsillectomy on arterial blood gases and acid-base balance. Int J Pediatr Otorhinolaryngol.
2156 Kiely JL, Deegan PC, McNicholas WT. (1998). Resolution of obstructive sleep apnoea with growth in the Robin sequence. Eur Respir J.
2157 Kim YK, Kang JH, Yoon KS. (1998). Acoustic rhinometric evaluation of nasal cavity and nasopharynx after adenoidectomy and tonsillectomy. Int J Pediatr Otorhinolaryngol.
2158 Kiroglu MM, Ozbilgin K, Aydogan B, et al. (1998). Adenoids and otitis media with effusion: a morphological study. Am J Otolaryngol.
2159 Klein JO. (1998). Clinical implications of antibiotic resistance for management of acute otitis media. Pediatr Infect Dis J.
2160 Koc C, Kocaman F, Aygenc E, et al. (1998). The use of preoperative lidocaine to prevent stridor and laryngospasm after tonsillectomy and adenoidectomy. Otolaryngol Head Neck Surg.
2161 Kocher M, Voges J, Staar S, et al. (1998). Linear accelerator radiosurgery for recurrent malignant tumors of the skull base. Am J Clin Oncol.
2162 Kokki H, Nikanne E, Tuovinen K. (1998). I.v. intraoperative ketoprofen in small children during adenoidectomy: a dose-finding study. Br J Anaesth.
2163 Korn AP, Judson PL, Zaloudek CJ. (1998). Importance of atypical glandular cells of uncertain significance in cervical cytologic smears. J Reprod Med.
2164 Kumar BN, Walsh RM, Courteney-Harris RG, et al. (1998). Direct listing' for tonsillectomy by general practitioners. Clin Otolaryngol Allied Sci.
2165 Kurol J, Modin H, Bjerkhoel A. (1998). Orthodontic maxillary expansion and its effect on nocturnal enuresis. Angle Orthod.
2166 Kutluhan A, Sakarya ME, Cankaya H, et al. (1998). Clinical value of preoperative intraoral ultrasonography in tonsillectomy. Auris Nasus Larynx.
2167 Lagging E, Papatziamos G, Hallden G, et al. (1998). T-cell subsets in adenoids and peripheral blood related to age, otitis media with effusion and allergy. APMIS.
2168 Lattyak BV, Rosenthal P, Mudge C, et al. (1998). Posttransplant lymphoproliferative disorder presenting in the head and neck. Laryngoscope.
2169 Lee SE, Johnson SP, Hale LP, et al. (1998). Analysis of DNA mismatch repair proteins in human medulloblastoma. Clin Cancer Res.
2170 Leiba H, Barash J, Pollack A. (1998). Poststreptococcal uveitis. Am J Ophthalmol.
2171 Levy P, Bettega G, Pepin JL. (1998). Surgical management options for snoring and sleep apnoea. European Respiratory Monograph.
2172 Liavaag PG, Cheung RK, Kerrebijn JD, et al. (1998). The physiologic reservoir of Epstein-Barr virus does not map to upper aerodigestive tissues. Laryngoscope.
2173 Licameli GR, Grillone GA. (1998). Inferior pole peritonsillar abscess. Otolaryngol Head Neck Surg.
2174 Lilja M, Raisanen S, Stenfors LE. (1998). Initial events in the pathogenesis of acute tonsillitis caused by Streptococcus pyogenes. Int J Pediatr Otorhinolaryngol.
2175 Linton K, Bath AP, Lee JA. (1998). Tonsillar metastasis from malignant pulmonary carcinoid tumour. J Laryngol Otol.
2176 Lisignoli G, Pozzi C, Toneguzzi S, et al. (1998). Different pattern of cytokine production and mRNA expression by lymphoid and non-lymphoid cells isolated from human palatine tonsil. Int J Clin Lab Res.
2177 Litman RS, Kottra JA, Berkowitz RJ, et al. (1998). Upper airway obstruction during midazolam/nitrous oxide sedation in children with enlarged tonsils. Pediatr Dent.
2178 Liutu M, Kalimo K, Uksila J, et al. (1998). Etiologic aspects of chronic urticaria. Int J Dermatol.
2179 Lopez-Gonzalez MA, Guerrero JM, Sanchez B, et al. (1998). Melatonin restores and enhances the human type B tonsillar lymphocyte subset in recurrent acute tonsillitis. Neurosci Lett.
2180 Lopez-Gonzalez MA, Lucas M, Sanchez B, et al. (1998). Adenoidal and tonsillar lymphocyte subsets in AIDS children. Int J Pediatr Otorhinolaryngol.
2181 Lopez-Gonzalez MA, Sanchez B, Mata F, et al. (1998). Tonsillar lymphocyte subsets in recurrent acute tonsillitis and tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
2182 Mak SK, Wong PN, Lo KY, et al. (1998). Successful treatment of IgA nephropathy in association with low-grade B-cell lymphoma of the mucosa-associated lymphoid tissue type. Am J Kidney Dis.
2183 Marchisio P, Principi N, Passali D, et al. (1998). Epidemiology and treatment of otitis media with effusion in children in the first year of primary school. Acta Otolaryngol.
2184 Marcus CL, Hamer A, Loughlin GM. (1998). Natural history of primary snoring in children. Pediatr Pulmonol.
2185 Marshall T. (1998). A review of tonsillectomy for recurrent throat infection. Hong Kong Practitioner.
2186 Maurelli AT, Routh PR, Dillman RC, et al. (1998). Shigella infection as observed in the experimentally inoculated domestic pig, Sus scrofa domestica. Microb Pathog.
2187 Mazzaglia G, Greco S, Lando C, et al. (1998). Adult acute upper respiratory tract infections in Sicily: pattern of antibiotic drug prescription in primary care. J Antimicrob Chemother.
2188 McQuone SJ, Eisele DW, Lee DJ, et al. (1998). Occult tonsillar carcinoma in the unknown primary. Laryngoscope.
2189 Mears J. (1998). The importance of sleep following ENT surgery. Paediatr Nurs.
2190 Mehra S, van Moerkerke M, Welck J, et al. (1998). Short course therapy with cefuroxime axetil for group A streptococcal tonsillopharyngitis in children. Pediatr Infect Dis J.
2191 Mgbor N. (1998). Bacterial agents of acute follicular tonsillitis in Gurayat, Saudi Arabia. J Commun Dis.
2192 Mickelson SA, Hakim I. (1998). Is postoperative intensive care monitoring necessary after uvulopalatopharyngoplasty?. Otolaryngol Head Neck Surg.
2193 Mihancea N. (1998). Frequency and distribution per species, biotypes, resistance to antibiotics and beta-lactamase production of the haemophils isolated from patients with respiratory diseases. Roum Arch Microbiol Immunol.
2194 Mitchell RB, Kenyon GS. (1998). Adult tonsillectomy: what proportion would accept same day discharge?. J R Coll Surg Edinb.
2195 Miyazaki S, Itasaka Y, Tada H, et al. (1998). Effectiveness of tonsillectomy in adult sleep apnea syndrome. Psychiatry Clin Neurosci.
2196 Mogayzel PJ, Carroll JL, Loughlin GM, et al. (1998). Sleep-disordered breathing in children with achondroplasia. J Pediatr.
2197 Mok TS, Steinberg J, Chan AT, et al. (1998). Application of the international prognostic index in a study of Chinese patients with non-Hodgkin's lymphoma and a high incidence of primary extranodal lymphoma. Cancer.
2198 Molony NC, Santana-Hernandez D, Wardrop PJ, et al. (1998). On which day is pain worst following adult tonsillectomy?. Int J Clin Pract.
2199 Moniot-Ville N, Chelly M, Consten L, et al. (1998). The acceptability, efficacy and safety of a new paediatric oral suspension of roxithromycin in respiratory tract infections. J Int Med Res.
2200 Montasser AM. (1998). A method for assessment of standards of care of anesthesia services in departments with different levels of resources. J Clin Monit Comput.
2201 Mozo L, Gayo A, Suarez A, et al. (1998). Glucocorticoids inhibit IL-4 and mitogen-induced IL-4R alpha chain expression by different posttranscriptional mechanisms. J Allergy Clin Immunol.
2202 Mui S, Rasgon BM, Hilsinger RL. (1998). Efficacy of tonsillectomy for recurrent throat infection in adults. Laryngoscope.
2203 Murthy P, Laing MR. (1998). Admission and discharge policy for paediatric adenoidectomy and tonsillectomy--a rural perspective. J Laryngol Otol.
2204 Murthy P, Laing MR. (1998). Dissection tonsillectomy: pattern of post-operative pain, medication and resumption of normal activity. J Laryngol Otol.
2205 Myatt HM. (1998). Direct listing for tonsillectomy. J R Coll Surg Edinb.
2206 Myatt HM, Myatt RA. (1998). The development of a paediatric quality of life questionnaire to measure post-operative pain following tonsillectomy. Int J Pediatr Otorhinolaryngol.
2207 Nakatani M. (1998). On the treatment of recurrent tonsillitis by vaccination. Curr Med Res Opin.
2208 Nichols PT, Ramadan HH, Wax MK, et al. (1998). Relationship between tympanic membrane perforations and retained ventilation tubes. Arch Otolaryngol Head Neck Surg.
2209 Niemela M, Uhari M, Luotonen M, et al. (1998). Changes in day care attendance rates and in the occurrence of adenoidectomies and tympanostomies. Acta Paediatr.
2210 O'Brien K, Kumar R, Morton NS. (1998). Sevoflurane compared with halothane for tracheal intubation in children. Br J Anaesth.
2211 Olofsson K, Hellstrom S, Hammarstrom ML. (1998). The surface epithelium of recurrent infected palatine tonsils is rich in gammadelta T cells. Clin Exp Immunol.
2212 Ong CC, Chorbachi R. (1998). The difficulties encountered in completing an audit cycle in a district general hospital. Int J Clin Pract.
2213 Ozbek MM, Miyamoto K, Lowe AA, et al. (1998). Natural head posture, upper airway morphology and obstructive sleep apnoea severity in adults. Eur J Orthod.
2214 Ozcan M, Altuntas A, Unal A, et al. (1998). Sucralfate for posttonsillectomy analgesia. Otolaryngol Head Neck Surg.
2215 Ozuer MZ. (1998). Local nerve blockade by bupivacaine reduced short- and long-term pain in children undergoing tonsillectomy and adenoidectomy. Ann Otol Rhinol Laryngol.
2216 Papadakis CE, Nikolidakis AA, Bizakis JG, et al. (1998). Meningitis as a complication of tonsillectomy. Int J Pediatr Otorhinolaryngol.
2217 Pappas AL, Sukhani R, Hotaling AJ, et al. (1998). The effect of preoperative dexamethasone on the immediate and delayed postoperative morbidity in children undergoing adenotonsillectomy. Anesth Analg.
2218 Paradise JL, Bernard BS, Colborn DK, et al. (1998). Assessment of adenoidal obstruction in children: clinical signs versus roentgenographic findings. Pediatrics.
2219 Perez CA, Patel MM, Chao KS, et al. (1998). Carcinoma of the tonsillar fossa: prognostic factors and long-term therapy outcome. Int J Radiat Oncol Biol Phys.
2220 Pestian JP, Derkay CS, Ritter C. (1998). Outpatient tonsillectomy and adenoidectomy clinical pathways: an evaluative study. Am J Otolaryngol.
2221 Pichichero ME, Green JL, Francis AB, et al. (1998). Recurrent group A streptococcal tonsillopharyngitis. Pediatr Infect Dis J.
2222 Pizzuto MP, Volk MS, Kingston LM. (1998). Common topics in pediatric otolaryngology. Pediatr Clin North Am.
2223 Postic WP, Shah UK. (1998). Nonsurgical and surgical management of infants and children with obstructive sleep apnea syndrome. Otolaryngol Clin North Am.
2224 Power C, Crowe C, Higgins P, et al. (1998). Anaesthetic depth at induction. An evaluation using clinical eye signs and EEG polysomnography. Anaesthesia.
2225 Prados M, Sanchez F, Olivencia M, et al. (1998). Serum immunoglobulin E levels in relation to adenoid surgery. Allergol Immunopathol (Madr).
2226 Pransky SM. (1998). Surgical strategies for otitis media. J Otolaryngol.
2227 Randall DA, Hoffer ME. (1998). Complications of tonsillectomy and adenoidectomy. Otolaryngol Head Neck Surg.
2228 Rechtweg JS, Wax MK. (1998). Eagle's syndrome: a review. Am J Otolaryngol.
2229 Reimer EJ, Dunn GS, Montgomery CJ, et al. (1998). The effectiveness of clonidine as an analgesic in paediatric adenotonsillectomy. Can J Anaesth.
2230 Rohlfing GK, Dilley DC, Lucas WJ, et al. (1998). The effect of supplemental oxygen on apnea and oxygen saturation during pediatric conscious sedation. Pediatr Dent.
2231 Romsing J, Ostergaard D, Walther-Larsen S, et al. (1998). Analgesic efficacy and safety of preoperative versus postoperative ketorolac in paediatric tonsillectomy. Acta Anaesthesiol Scand.
2232 Rosenmann E, Rabinowitz R, Schlesinger M. (1998). Lymphocyte subsets in human tonsils: the effect of age and infection. Pediatr Allergy Immunol.
2233 Rostoker G. (1998). Therapy of IgA nephropathy. BioDrugs.
2234 Ruiz I, Hernandez-Aguado I, Garrido P. (1998). Variation in surgical rates: a population study. Med Care.
2235 Schiff D, Suman VJ, Yang P, et al. (1998). Risk factors for primary central nervous system lymphoma: a case-control study. Cancer.
2236 Schneider AB, Lubin J, Ron E, et al. (1998). Salivary gland tumors after childhood radiation treatment for benign conditions of the head and neck: dose-response relationships. Radiat Res.
2237 Sclafani AP, Ginsburg J, Shah MK, et al. (1998). Treatment of symptomatic chronic adenotonsillar hypertrophy with amoxicillin/clavulanate potassium: short- and long-term results. Pediatrics.
2238 Sculerati N, Gottlieb MD, Zimbler MS, et al. (1998). Airway management in children with major craniofacial anomalies. Laryngoscope.
2239 Sepponen K, Ahonen R, Kokki H. (1998). The effects of a hospital staff training program on the treatment practices of postoperative pain in children under 8 years. Pharm World Sci.
2240 Seshul MJ, Wiatrak BJ, Galliani CA, et al. (1998). Pharyngeal fibrovascular polyp in a child. Ann Otol Rhinol Laryngol.
2241 Shah SB, Lalwani AK, Koerper MA. (1998). Perioperative management of von Willebrand's disease in otolaryngologic surgery. Laryngoscope.
2242 Sher MH, Laing DI, Brands E. (1998). Life-threatening upper airway obstruction after glossopharyngeal nerve block: possibly due to an inappropriately large dose of bupivacaine?. Anesth Analg.
2243 Shibl AM, Memish Z, Abdulla A, et al. (1998). Incidence of beta-lactamase production by oral aerobic/anaerobic flora from patients admitted for elective tonsillectomy. J Infect.
2244 Shintani T, Asakura K, Kataura A. (1998). The effect of adenotonsillectomy in children with OSA. Int J Pediatr Otorhinolaryngol.
2245 Short JA. (1998). Laryngeal mask and tonsillectomy. Br J Anaesth.
2246 Shukla GK, Sharma S, Shukla A, et al. (1998). Comparative status of oxidative damage and antioxidant enzymes in chronic tonsillitis patients. Boll Chim Farm.
2247 Sigman K, Ghibu F, Sommerville W, et al. (1998). Intravenous immunoglobulin inhibits IgE production in human B lymphocytes. J Allergy Clin Immunol.
2248 Soldado L, Esteban F, Delgado-Rodriguez M, et al. (1998). Bacteraemia during tonsillectomy: a study of the factors involved and clinical implications. Clin Otolaryngol Allied Sci.
2249 Splinter WM, Rhine EJ. (1998). Prophylaxis for vomiting by children after tonsillectomy: ondansetron compared with perphenazine. Br J Anaesth.
2250 Staub M, Csapo Z, Spasokukotskaja T, et al. (1998). Deoxycytidine kinase can be also potentiated by the G-protein activator NaF in cells. Adv Exp Med Biol.
2251 Steward DJ. (1998). Morbidity after day-case tonsillectomy in children. Br J Anaesth.
2252 Stoddart PA, Mather SJ. (1998). Onset of neuromuscular blockade and intubating conditions one minute after the administration of rocuronium in children. Paediatr Anaesth.
2253 Straand J, Rokstad K, Heggedal U. (1998). Drug prescribing for children in general practice. A report from the More & Romsdal Prescription Study. Acta Paediatr.
2254 Straand J, Rokstad KS, Sandvik H. (1998). Prescribing systemic antibiotics in general practice. A report from the More & Romsdal Prescription Study. Scand J Prim Health Care.
2255 Strachan DP, Cook DG. (1998). Health effects of passive smoking. 4. Parental smoking, middle ear disease and adenotonsillectomy in children. Thorax.
2256 Sudo K, Tashiro K, Miyasaka K. (1998). Features of spontaneous improvement in syringomyelia with low-situated cerebellar tonsils. Acta Neurol Belg.
2257 Sutherland CJ, Montgomery JE, Kestin IG. (1998). A comparison of intramuscular tenoxicam with intramuscular morphine for pain relief following tonsillectomy in children. Paediatr Anaesth.
2258 Sutherland M, Bruce B. (1998). Same-day pediatric surgery. Can Nurse.
2259 Szuhay G, Tewfik TL. (1998). Peritonsillar abscess or cellulitis? A clinical comparative paediatric study. J Otolaryngol.
2260 Tasker RC, Dundas I, Laverty A, et al. (1998). Distinct patterns of respiratory difficulty in young children with achondroplasia: a clinical, sleep, and lung function study. Arch Dis Child.
2261 Thellin O, Coumans B, Zorzi W, et al. (1998). Expression of growth hormone receptors by lymphocyte subpopulations in the human tonsil. Dev Immunol.
2262 Tzifa KT, Shehab ZP, Robin PE. (1998). The relation between tonsillectomy and snoring. Clin Otolaryngol Allied Sci.
2263 Venkatachalam VP. (1998). Snoring: Is it a humorous or a pathological condition!. JK Practitioner.
2264 Venn PJ. (1998). Use of laryngeal mask during tonsillectomy. Br J Anaesth.
2265 Viitanen H, Annila P, Rorarius M, et al. (1998). Recovery after halothane anaesthesia induced with thiopental, propofol-alfentanil or halothane for day-case adenoidectomy in small children. Br J Anaesth.
2266 Wang RC, Elkins TP, Keech D, et al. (1998). Accuracy of clinical evaluation in pediatric obstructive sleep apnea. Otolaryngol Head Neck Surg.
2267 Warnock FF, Lander J. (1998). The painful (and costly) facts about children's tonsillectomy day surgery. AARN News Lett.
2268 Warnock FF, Lander J. (1998). Pain progression, intensity and outcomes following tonsillectomy. Pain.
2269 Waters KA, Forbes P, Morielli A, et al. (1998). Sleep-disordered breathing in children with myelomeningocele. J Pediatr.
2270 Wedi B, Wagner S, Werfel T, et al. (1998). Prevalence of Helicobacter pylori-associated gastritis in chronic urticaria. Int Arch Allergy Immunol.
2271 Wiesenauer M. (1998). Comparison of solid and liquid forms of homeopathic remedies for tonsillitis. Adv Ther.
2272 Williams A, Nagy M, Wingate J, et al. (1998). Lemierre syndrome: a complication of acute pharyngitis. Int J Pediatr Otorhinolaryngol.
2273 Wright ED, Pearl AJ, Manoukian JJ. (1998). Laterally hypertrophic adenoids as a contributing factor in otitis media. Int J Pediatr Otorhinolaryngol.
2274 Wu CC, Tseng CS, Shen CH, et al. (1998). Succinylcholine-induced cardiac arrest in unsuspected becker muscular dystrophy--a case report. Acta Anaesthesiol Sin.
2275 Yamamoto T, Katayama I, Nishioka K. (1998). Restricted usage of the T-cell receptor V beta repertoire in tonsillitis in association with palmoplantar pustulosis. Acta Derm Venereol.
2276 Yamazaki Y, Tachibana S, Takano M, et al. (1998). Clinical and neuroimaging features of Chiari type I malformations with and without associated syringomyelia. Neurol Med Chir (Tokyo).
2277 (1999). Treatment strategy for IgA nephropathy depends on the risk of disease progression. Drugs and Therapy Perspectives.
2278 Agrawal A, Gerson CR, Seligman I, et al. (1999). Postoperative hemorrhage after tonsillectomy: use of ketorolac tromethamine. Otolaryngol Head Neck Surg.
2279 Agren K, Lindberg K, Samulesson A, et al. (1999). What is wrong in chronic adenoiditis/tonsillitis immunological factor. Int J Pediatr Otorhinolaryngol.
2280 Akagi H, Nishizaki K, Hattori K, et al. (1999). Prognosis of tonsillectomy in patients with IgA nephropathy. Acta Otolaryngol Suppl.
2281 Ali Hiari M. (1999). Histopathology of the tonsil, is it important?. Bahrain Medical Bulletin.
2282 Allen GC, Armfield DR, Bontempo FA, et al. (1999). Adenotonsillectomy in children with von Willebrand disease. Arch Otolaryngol Head Neck Surg.
2283 Ammash NM, Connolly HM, Abel MD, et al. (1999). Noncardiac surgery in Eisenmenger syndrome. J Am Coll Cardiol.
2284 Anand VT, Phillipps JJ, Allen D, et al. (1999). A study of postoperative fever following paediatric tonsillectomy. Clin Otolaryngol Allied Sci.
2285 Anderhuber W, Walch C, Nemeth E, et al. (1999). Plasma adrenaline concentrations during functional endoscopic sinus surgery. Laryngoscope.
2286 Anderson BJ, Holford NH, Woollard GA, et al. (1999). Perioperative pharmacodynamics of acetaminophen analgesia in children. Anesthesiology.
2287 Anderson BJ, Rees SG, Liley A, et al. (1999). Effect of preoperative paracetamol on gastric volumes and pH in children. Paediatr Anaesth.
2288 Annila P, Viitanen H, Reinikainen P, et al. (1999). Induction characteristics of thiopentone/suxamethonium, propofol/alfentanil or halothane alone in children aged 1-3 years. Eur J Anaesthesiol.
2289 Arican A, Dincol D, Akbulut H, et al. (1999). Clinicopathologic features and prognostic factors of primary extranodal non-Hodgkin's lymphomas in Turkey. Am J Clin Oncol.
2290 Armstrong M. (1999). Chisel tip suction cautery device for tonsillectomy. Otolaryngol Head Neck Surg.
2291 Asai T, Murao K, Yukawa H, et al. (1999). Re-evaluation of appropriate size of the laryngeal mask airway. British journal of anaesthesia.
2292 Asai T, Murao K, Yukawa H, et al. (1999). Re-evaluation of appropriate size of the laryngeal mask airway. see comment. British journal of anaesthesia.
2293 Aspinall RL, Mayor A. (1999). A prospective randomised controlled study of the efficacy of ketamine for post operative pain relief in children after adenotonsillectomy. Anesthesiology.
2294 Attia M, Zaoutis T, Eppes S, et al. (1999). Multivariate predictive models for group A beta-hemolytic streptococcal pharyngitis in children. Acad Emerg Med.
2295 Azcona C, Preece MA, Rose SJ, et al. (1999). Growth response to rhIGF-I 80 microg/kg twice daily in children with growth hormone insensitivity syndrome: relationship to severity of clinical phenotype. Clin Endocrinol (Oxf).
2296 Baba Y, Akagi H, Fukushima K, et al. (1999). Quantitative analysis of interleukin 6 (IL-6) in patients with IgA nephropathy after tonsillectomy. Auris Nasus Larynx.
2297 Bar A, Tarasiuk A, Segev Y, et al. (1999). The effect of adenotonsillectomy on serum insulin-like growth factor-I and growth in children with obstructive sleep apnea syndrome. J Pediatr.
2298 Barst SM, Leiderman JU, Markowitz A, et al. (1999). Ondansetron with propofol reduces the incidence of emesis in children following tonsillectomy. Can J Anaesth.
2299 Beck CS. (1999). Serving underserved communities. Mayo Clin Proc.
2300 Bedi HS, Angliss RD, Williams SA, et al. (1999). Torticollis following adenotonsillectomy. Aust N Z J Surg.
2301 Benito MB, Sampelayo TH, Gurbindo D, et al. (1999). Adenoidal tissue mass as a clinical guide of disease evolution in vertically HIV-1 infected children. Int J Pediatr Otorhinolaryngol.
2302 Bergler W, Adam S, Gross HJ, et al. (1999). Age-dependent altered proportions in subpopulations of tonsillar lymphocytes. Clin Exp Immunol.
2303 Berkowitz RG, Mahadevan M. (1999). Unilateral tonsillar enlargement and tonsillar lymphoma in children. Ann Otol Rhinol Laryngol.
2304 Berman S, Bondy J, Lezotte D, et al. (1999). The influence of having an assigned Medicaid primary care physician on utilization of otitis media-related services. Pediatrics.
2305 Black C, Peterson S, Mansfield J, et al. (1999). Using population-based data to enhance clinical practice guideline development. Med Care.
2306 Bodey B, Bodey B, Siegel SE, et al. (1999). Fas (APO-1, CD95) receptor expression and new options for immunotherapy in childhood medulloblastomas. Anticancer Res.
2307 Bodey B, Bodey B, Siegel SE, et al. (1999). Fas (Apo-1, CD95) receptor expression in childhood astrocytomas. Is it a marker of the major apoptotic pathway or a signaling receptor for immune escape of neoplastic cells?. In Vivo.
2308 Boelen-van der Loo WJ, Scheffer E, de Haan RJ, et al. (1999). Clinimetric evaluation of the pain observation scale for young children in children aged between 1 and 4 years after ear, nose, and throat surgery. J Dev Behav Pediatr.
2309 Bohliga LA, Dawlatly EE. (1999). Sutures and disasters in tonsillectomy revisited: a sharp pain in the neck. Otolaryngol Head Neck Surg.
2310 Bolte G, Mielck A, Meyer I, et al. (1999). Inverse social gradient of secondary immune response parameters in children. Rev Environ Health.
2311 Brady SP, Magro CM, Diaz-Cano SJ, et al. (1999). Analysis of clonality of atypical cutaneous lymphoid infiltrates associated with drug therapy by PCR/DGGE. Hum Pathol.
2312 Brook I, Gober AE. (1999). Interference by aerobic and anaerobic bacteria in children with recurrent group A beta-hemolytic streptococcal tonsillitis. Arch Otolaryngol Head Neck Surg.
2313 Brook I, Yocum P. (1999). Bacterial interference in the adenoids of otitis media-prone children. Pediatr Infect Dis J.
2314 Brook II. (1999). Therapy for Otitis Media, Sinusitis, and Tonsillitis. Curr Infect Dis Rep.
2315 Buchman CA, Yellon RF, Bluestone CD. (1999). Alternative to endoscopic sinus surgery in the management of pediatric chronic rhinosinusitis refractory to oral antimicrobial therapy. Otolaryngol Head Neck Surg.
2316 Cannon CR, Chambers A. (1999). Peritonsillar abscess (PTA) in children. J Miss State Med Assoc.
2317 Cannon CR, Replogle WH, Schenk MP. (1999). Endoscopic-assisted adenoidectomy. Otolaryngol Head Neck Surg.
2318 Carr MM, Williams JG, Carmichael L, et al. (1999). Effect of steroids on posttonsillectomy pain in adults. Arch Otolaryngol Head Neck Surg.
2319 Casselbrant ML. (1999). What is wrong in chronic adenoiditis/tonsillitis anatomical considerations. Int J Pediatr Otorhinolaryngol.
2320 Chan CH, Wu MC, Huang CT, et al. (1999). Genetic characterization of the hemagglutinin of two strains of influenza B virus co-circulated in Taiwan. J Med Virol.
2321 Cheng JC, Guo X, Sher AH, et al. (1999). Correlation between curve severity, somatosensory evoked potentials, and magnetic resonance imaging in adolescent idiopathic scoliosis. Spine (Phila Pa 1976).
2322 Chhibber AK, Lustik SJ, Thakur R, et al. (1999). Effects of anticholinergics on postoperative vomiting, recovery, and hospital stay in children undergoing tonsillectomy with or without adenoidectomy. Anesthesiology.
2323 Cho BS, Yoon SR, Jang JY, et al. (1999). Up-regulation of interleukin-4 and CD23/FcepsilonRII in minimal change nephrotic syndrome. Pediatr Nephrol.
2324 Cho JH, Lee DH, Lee NS, et al. (1999). Size assessment of adenoid and nasopharyngeal airway by acoustic rhinometry in children. J Laryngol Otol.
2325 Chopra H, Munjal M, Gupta SN. (1999). Deafness in paediatric age group. Indian J Otolaryngol Head Neck Surg.
2326 Chuma AV, Cacace AT, Rosen R, et al. (1999). Effects of tonsillectomy and/or adenoidectomy on vocal function: laryngeal, supralaryngeal and perceptual characteristics. Int J Pediatr Otorhinolaryngol.
2327 Church JJ. (1999). Day case tonsillectomy in children. Ambulatory Surgery.
2328 Coleman JA. (1999). The diagnosis of OSAS and UARS in children: trying to relieve the frustration. Arch Otolaryngol Head Neck Surg.
2329 Colleoni GW, Oliveira JS, Alves AC, et al. (1999). Clinical management of six cases of low-risk primary tonsillar non-Hodgkin's lymphoma. Sao Paulo Med J.
2330 Colreavy MP, Nanan D, Benamer M, et al. (1999). Antibiotic prophylaxis post-tonsillectomy: is it of benefit?. Int J Pediatr Otorhinolaryngol.
2331 Conley SF, Ellison MD. (1999). Avoidance of primary post-tonsillectomy hemorrhage in a teaching program. Arch Otolaryngol Head Neck Surg.
2332 Connors C, Millar WJ. (1999). Changes in children's hospital use. Health Rep.
2333 Constant I, Dubois MC, Piat V, et al. (1999). Changes in electroencephalogram and autonomic cardiovascular activity during induction of anesthesia with sevoflurane compared with halothane in children. Anesthesiology.
2334 Cooke RP. (1999). Colonic perforation due to Campylobacter colitis following tonsillectomy. Br J Biomed Sci.
2335 Coste J, Venot A. (1999). An epidemiologic approach to drug prescribing quality assessment: a study in primary care practice in France. Med Care.
2336 Courtman SP, Rawlings E, Carr AS. (1999). Masked bleeding posttonsillectomy with ondansetron. Paediatr Anaesth.
2337 Dasen KR. (1999). Atlantoaxial rotatory subluxation after a pediatric tonsillectomy. Anesth Analg.
2338 de Diego JI, Prim MP, Rodriguez E, et al. (1999). Von Willebrand disease as cause of unanticipated bleeding following adeno-tonsillectomy. Int J Pediatr Otorhinolaryngol.
2339 Dhooge I, Van Damme D, Vaneechoutte M, et al. (1999). Role of nasopharyngeal bacterial flora in the evaluation of recurrent middle ear infections in children. Clin Microbiol Infect.
2340 Dinis PB, Haider H, Gomes A. (1999). The effects of adenoid hypertrophy and subsequent adenoidectomy on pediatric nasal airway resistance. Am J Rhinol.
2341 Donaldson LJ, Hayes JH, Barton AG, et al. (1999). Impact of clinical practice guidelines on clinicians' behaviour: tonsillectomy in children. J Otolaryngol.
2342 Drake-Lee A, Harris S. (1999). Social conditions and paediatric day case tonsillectomy. J Health Serv Res Policy.
2343 Drake-Lee A, Harris S. (1999). Day case tonsillectomy: what is the risk and where is the economic benefit?. Clin Otolaryngol Allied Sci.
2344 Dubois MC, Piat V, Constant I, et al. (1999). Comparison of three techniques for induction of anaesthesia with sevoflurane in children. Paediatr Anaesth.
2345 Ellis D, Jaffe R, Green M, et al. (1999). Epstein-Barr virus-related disorders in children undergoing renal transplantation with tacrolimus-based immunosuppression. Transplantation.
2346 El-Madhun AS, Cox RJ, Haaheim LR. (1999). The effect of age and natural priming on the IgG and IgA subclass responses after parenteral influenza vaccination. J Infect Dis.
2347 Elsherif I, Kareemullah C. (1999). Tonsil and adenoid surgery for upper airway obstruction in children. Ear Nose Throat J.
2348 England RJ, Lau M, Ell SR. (1999). Angular cheilitis after tonsillectomy. Clin Otolaryngol Allied Sci.
2349 Falck G, Grahn-Hakansson E, Holm SE, et al. (1999). Tolerance and efficacy of interfering alpha-streptococci in recurrence of streptococcal pharyngotonsillitis: a placebo-controlled study. Acta Otolaryngol.
2350 Feinerman IL, Tan HK, Roberson DW, et al. (1999). Necrotizing fasciitis of the pharynx following adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
2351 Fordice J, Kershaw C, El-Naggar A, et al. (1999). Adenoid cystic carcinoma of the head and neck: predictors of morbidity and mortality. Arch Otolaryngol Head Neck Surg.
2352 Francis JD, Leary T, Niblett DJ. (1999). Convulsions and respiratory arrest in association with desmopressin administration for the treatment of a bleeding tonsil in a child with borderline haemophilia. Acta Anaesthesiol Scand.
2353 Friedman M, Tanyeri H, La Rosa M, et al. (1999). Clinical predictors of obstructive sleep apnea. Laryngoscope.
2354 Friedman O, Chidekel A, Lawless ST, et al. (1999). Postoperative bilevel positive airway pressure ventilation after tonsillectomy and adenoidectomy in children--a preliminary report. Int J Pediatr Otorhinolaryngol.
2355 Frosh A. (1999). Prions and the ENT surgeon. J Laryngol Otol.
2356 Fuchshuber S, Issing WJ. (1999). The patient is always right--a case of foreign-body ingestion. Eur Arch Otorhinolaryngol.
2357 Fujii Y, Saitoh Y, Tanaka H, et al. (1999). Preoperative oral antiemetics for reducing postoperative vomiting after tonsillectomy in children: granisetron versus perphenazine. Anesth Analg.
2358 Fujii Y, Saitoh Y, Tanaka H, et al. (1999). Prevention of postoperative vomiting with granisetron in paediatric patients with and without a history of motion sickness. Paediatr Anaesth.
2359 Fujii Y, Saitoh Y, Tanaka H, et al. (1999). Anti-emetic efficacy of prophylactic granisetron compared with perphenazine for the prevention of post-operative vomiting in children. Eur J Anaesthesiol.
2360 Garin P, Remacle M. (1999). Laser-assisted myringotomy combined with adenoidectomy in children: preliminary results. Acta Otorhinolaryngol Belg.
2361 Gates GA. (1999). Otitis media--the pharyngeal connection. Jama.
2362 Gilani SM, Nahi G, Ghazal S. (1999). Postoperative analgesia - effect of topical bupivacaine after tonsillectomy - a clinical study. Journal of Ayub Medical College.
2363 Girishkumar HT, Sivakumar M, Andaz S, et al. (1999). Pseudo-aneurysm of the carotid bifurcation secondary to radiation. J Cardiovasc Surg (Torino).
2364 Glassock RJ. (1999). The treatment of IgA nephropathy: status at the end of the millenium. J Nephrol.
2365 Goldenberg D, Golz A, Arie YB, et al. (1999). Adenocarcinoma of the rectum with metastasis to the palatine tonsil. Otolaryngol Head Neck Surg.
2366 Gonzales R, Barrett PH, Steiner JF. (1999). The relation between purulent manifestations and antibiotic treatment of upper respiratory tract infections. J Gen Intern Med.
2367 Gordts F, Abu Nasser I, Clement PA, et al. (1999). Bacteriology of the middle meatus in children. Int J Pediatr Otorhinolaryngol.
2368 Gordts F, Abu Nasser I, Pierard D, et al. (1999). Microbiology of the middle meatus in children requiring adenotonsillectomy. J Laryngol Otol.
2369 Gorfien JL, Hard R, Noble B, et al. (1999). Quantitative study of germinal center area in normal and diseased tonsils using image analysis. Ann Otol Rhinol Laryngol.
2370 Gosain AK, Conley SF, Santoro TD, et al. (1999). A prospective evaluation of the prevalence of submucous cleft palate in patients with isolated cleft lip versus controls. Plast Reconstr Surg.
2371 Grabb PA, Mapstone TB, Oakes WJ. (1999). Ventral brain stem compression in pediatric and young adult patients with Chiari I malformations. Neurosurgery.
2372 Gray SD, Pinborough-zimmerman J, Catten M. (1999). Posterior wall augmentation for treatment of velopharyngeal insufficiency. Otolaryngol Head Neck Surg.
2373 Greenlee J, Garell PC, Stence N, et al. (1999). Comprehensive approach to Chiari malformation in pediatric patients. Neurosurg Focus.
2374 Gryczynska D, Kobos J, Zakrzewska A. (1999). Relationship between passive smoking, recurrent respiratory tract infections and otitis media in children. Int J Pediatr Otorhinolaryngol.
2375 Gupta S, Kavan R, Mogera C. (1999). Matching appropriately sized reinforced laryngeal mask airways with Boyle-Davis gags for paediatric adenotonsillectomies. Acta Anaesthesiol Scand.
2376 Gwyn R, Elwyn G. (1999). When is a shared decision not (quite) a shared decision? Negotiating preferences in a general practice encounter. Soc Sci Med.
2377 Haight JS, Moulton R, Fong I, et al. (1999). Cervicovertebral osteitis: a complication of uvulopalatopharyngoplasty with tonsillectomy. J Otolaryngol.
2378 Hajioff D, Snow MH, Thaker H, et al. (1999). Primary tuberculosis of the posterior oropharyngeal wall. J Laryngol Otol.
2379 Haller JR, Gray SD. (1999). Severe pharyngeal stenosis treated with inferiorly based sternocleidomastoid myocutaneous flap. Ann Otol Rhinol Laryngol.
2380 Hamers JP, Huijer Abu-Saad H, Geisler FE, et al. (1999). The effect of paracetamol, fentanyl, and systematic assessments on children's pain after tonsillectomy and adenoidectomy. J Perianesth Nurs.
2381 Hanif J, Frosh A. (1999). Effect of chewing gum on recovery after tonsillectomy. Auris Nasus Larynx.
2382 Harvey JM, O'Callaghan MJ, Wales PD, et al. (1999). Six-month follow-up of children with obstructive sleep apnoea. J Paediatr Child Health.
2383 Hatcher IS, Stack CG. (1999). Postal survey of the anaesthetic techniques used for paediatric tonsillectomy surgery. Paediatr Anaesth.
2384 Heiss JD, Patronas N, DeVroom HL, et al. (1999). Elucidating the pathophysiology of syringomyelia. J Neurosurg.
2385 Hellier WP, Knight J, Hern J, et al. (1999). Day case paediatric tonsillectomy: a review of three years experience in a dedicated day case unit. Clin Otolaryngol Allied Sci.
2386 Hern JD, Jayaraj SM, Sidhu VS, et al. (1999). The laryngeal mask airway in tonsillectomy: the surgeon's perspective. Clin Otolaryngol Allied Sci.
2387 Hill AF, Butterworth RJ, Joiner S, et al. (1999). Investigation of variant Creutzfeldt-Jakob disease and other human prion diseases with tonsil biopsy samples. Lancet.
2388 Hoppe JE, Blumenstock G, Grotz W, et al. (1999). Compliance of German pediatric patients with oral antibiotic therapy: results of a nationwide survey. Pediatr Infect Dis J.
2389 Hoppe JE, Wahrenberger C. (1999). Compliance of pediatric patients with treatment involving antibiotic suspensions: a pilot study. Clin Ther.
2390 Howard DJ, Lund VJ. (1999). The role of midfacial degloving in modern rhinological practice. J Laryngol Otol.
2391 Hultcrantz E, Johansson K, Bengtson H. (1999). The effect of uvulopalatopharyngoplasty without tonsillectomy using local anaesthesia: a prospective long-term follow-up. J Laryngol Otol.
2392 Hultcrantz E, Linder A, Markstrom A. (1999). Tonsillectomy or tonsillotomy?--A randomized study comparing postoperative pain and long-term effects. Int J Pediatr Otorhinolaryngol.
2393 Hunt KD, Marks R. (1999). Tonsillectomy - an unusual complication. Anaesthesia.
2394 Ikushima I, Korogi Y, Makita O, et al. (1999). MR imaging of Tornwaldt's cysts. AJR Am J Roentgenol.
2395 Indudharan R, Quah BS, Shuaib IL. (1999). Internal jugular phlebectasia--an unusual cause of neck swelling. Ann Trop Paediatr.
2396 Ivarsson M, Quiding-Jarbrink M, Lundberg C. (1999). Immunoglobulin-secreting cells in the surface secretion on the pharyngeal tonsils. Acta Otolaryngol.
2397 Jones PH. (1999). Re: Surgical workshop: bipolar scissor tonsillectomy. Clin Otolaryngol Allied Sci.
2398 Juntti H, Tikkanen S, Kokkonen J, et al. (1999). Cow's milk allergy is associated with recurrent otitis media during childhood. Acta Otolaryngol.
2399 Kain ZN, Fasulo A, Rimar S. (1999). Establishment of a pediatric surgery center: increasing anesthetic efficiency. J Clin Anesth.
2400 Kaneko K, Nagaoka R, Ohtomo Y, et al. (1999). Tonsillectomy for asymptomatic isolated hematuria. Nephron.
2401 Kawabe J, Okamura T, Shakudo M, et al. (1999). Two cases of chronic tonsillitis studied by FDG-PET. Ann Nucl Med.
2402 Kemaloglu YK, Goksu N, Inal E, et al. (1999). Radiographic evaluation of children with nasopharyngeal obstruction due to the adenoid. Ann Otol Rhinol Laryngol.
2403 Kemppainen HO, Puhakka HJ, Laippala PJ, et al. (1999). Epidemiology and aetiology of middle ear cholesteatoma. Acta Otolaryngol.
2404 Kieff DA, Bhattacharyya N, Siegel NS, et al. (1999). Selection of antibiotics after incision and drainage of peritonsillar abscesses. Otolaryngol Head Neck Surg.
2405 Knoblauch SC, Wilson CJ. (1999). Clinical outcomes of educating nurses about pediatric pain management. Outcomes Manag Nurs Pract.
2406 Kodama H, Faden H, Harabuchi Y, et al. (1999). Cellular immune response of adenoidal and tonsillar lymphocytes to the P6 outer membrane protein of non-typeable Haemophilus influenzae and its relation to otitis media. Acta Otolaryngol.
2407 Koutroubakis IE, Vlachonikolis IG, Kapsoritakis A, et al. (1999). Appendectomy, tonsillectomy, and risk of inflammatory bowel disease: case-controlled study in Crete. Dis Colon Rectum.
2408 Krieger MD, McComb JG, Levy ML. (1999). Toward a simpler surgical management of Chiari I malformation in a pediatric population. Pediatr Neurosurg.
2409 Kubba H, Messersmith R. (1999). Is day case tonsillectomy suitable for children in Cumbria?. Clin Perform Qual Health Care.
2410 Kulapaditharom B, Boonkitticharoen V, Kunachak S. (1999). Fluorescence-guided biopsy in the diagnosis of an unknown primary cancer in patients with metastatic cervical lymph nodes. Ann Otol Rhinol Laryngol.
2411 Laffey JG, Neligan P, Ormonde G. (1999). Prolonged perioperative myocardial ischemia in a young male: due to topical intranasal cocaine?. J Clin Anesth.
2412 Lalakea ML, Marquez-Biggs I, Messner AH. (1999). Safety of pediatric short-stay tonsillectomy. Arch Otolaryngol Head Neck Surg.
2413 Lander J, Warnock F. (1999). Supporting the parents of children in day surgery. Can Nurse.
2414 Lee WI, Yang MH, Lee KF, et al. (1999). PFAPA syndrome (Periodic Fever, Aphthous stomatitis, Pharyngitis, Adenitis). Clin Rheumatol.
2415 Lembrechts D, Verschueren D, Heulens H, et al. (1999). Effect of a logopedic instruction program after adenoidectomy on open mouth posture: a single-blind study. Folia Phoniatr Logop.
2416 Lilja M, Silvola J, Bye HM, et al. (1999). SIgA- and IgG-coated Streptococcus pyogenes on the tonsillar surfaces during acute tonsillitis. Acta Otolaryngol.
2417 Lilja M, Silvola J, Raisanen S, et al. (1999). Where are the receptors for Streptococcus pyogenes located on the tonsillar surface epithelium?. Int J Pediatr Otorhinolaryngol.
2418 Lim LLY, Dear KBG, Heller RF. (1999). A systematic review of the antiemetic efficacy of prophylactic ondansetron compared with droperidol and with metoclopramide in children. Clinical Research and Regulatory Affairs.
2419 Lim PV, Curry AR. (1999). A new method for evaluating and reporting the severity of snoring. J Laryngol Otol.
2420 Linder A, Markstrom A, Hultcrantz E. (1999). Using the carbon dioxide laser for tonsillotomy in children. Int J Pediatr Otorhinolaryngol.
2421 Liu D, Labow DM, Dang N, et al. (1999). Pulmonary metastasectomy for head and neck cancers. Ann Surg Oncol.
2422 Lo LJ, Chen YR. (1999). Airway obstruction in severe syndromic craniosynostosis. Ann Plast Surg.
2423 Lopez-Gonzalez MA, Diaz P, Delgado F, et al. (1999). Lack of lymphoid cell apoptosis in the pathogenesis of tonsillar hypertrophy as compared to recurrent tonsillitis. Eur J Pediatr.
2424 Lopez-Gonzalez MA, Lucas M, Mata F, et al. (1999). Microalbuminuria as renal marker in recurrent acute tonsillitis and tonsillar hypertrophy in children. Int J Pediatr Otorhinolaryngol.
2425 Lowry VK, Tellez GI, Nisbet DJ, et al. (1999). Efficacy of Salmonella enteritidis-immune lymphokines on horizontal transmission of S. arizonae in turkeys and S. gallinarum in chickens. Int J Food Microbiol.
2426 Magardino TM, Tom LW. (1999). Surgical management of obstructive sleep apnea in children with cerebral palsy. Laryngoscope.
2427 Mann EA, Blair EA, Levy AJ, et al. (1999). Effect of topical antibiotic therapy on recovery after tonsillectomy in adults. Otolaryngology--head and neck surgery.
2428 Marshall T. (1999). How many tonsillectomies are based on evidence from randomized controlled trials?. Br J Gen Pract.
2429 Matsuda M, Shikata K, Wada J, et al. (1999). Increased urinary excretion of macrophage-colony-stimulating factor (M-CSF) in patients with IgA nephropathy: tonsil stimulation enhances urinary M-CSF excretion. Nephron.
2430 McKenna M. (1999). Postoperative tonsillectomy/adenoidectomy hemorrhage: a retrospective chart review. ORL Head Neck Nurs.
2431 McMillin BD, Maddern BR, Graham WR. (1999). A role for tonsillectomy in the treatment of psoriasis?. Ear Nose Throat J.
2432 Messner AH. (1999). Evaluation of obstructive sleep apnea by polysomnography prior to pediatric adenotonsillectomy. Arch Otolaryngol Head Neck Surg.
2433 Minocha A, Mesiya SA, Raczkowski CA, et al. (1999). Prevalence of previous appendectomy among patients needing gastrointestinal endoscopy. South Med J.
2434 Mohamed H. (1999). A comparative study between microbipolar dissection tonsillectomy VS. traditional knife dissection/snake with suture tonsillectomy and VS. knife/suction cautery tonsillectomy in children and adults. Scientific Journal of Al-Azhar Medical Faculty [Girls].
2435 Molloy ME, Orr I. (1999). Defect in the wiring of reinforced laryngeal mask leading to airway obstruction. Anaesthesia.
2436 Motamed M, Djazaeri B, Marks R. (1999). Acute pulmonary oedema complicating adenotonsillectomy for obstructive sleep apnoea. Int J Clin Pract.
2437 Murray JM. (1999). How I do it: a pediatric nurse practitioner--run postoperative otolaryngology clinic. ORL Head Neck Nurs.
2438 Nandapalan V, McCormick MS, Jones TM, et al. (1999). Does adenotonsillectomy cure hypoxaemia in children with sleep apnoea and congenital cardiac pathology?. Int J Pediatr Otorhinolaryngol.
2439 Niemela M, Uhari M, Mottonen M, et al. (1999). Costs arising from otitis media. Acta Paediatr.
2440 Nikanne E, Kokki H, Tuovinen K. (1999). Postoperative pain after adenoidectomy in children. Br J Anaesth.
2441 Nikolajev K, Heinonen K, Koskela H, et al. (1999). Determinants of bronchial responsiveness at school age in prematurely born children. Pediatr Pulmonol.
2442 Nolin L, Courteau M. (1999). Management of IgA nephropathy: evidence-based recommendations. Kidney Int Suppl.
2443 Nordahl SH, Albrektsen G, Guttormsen AB, et al. (1999). Effect of bupivacaine on pain after tonsillectomy: a randomized clinical trial. Acta Otolaryngol.
2444 Orendorz-Fraczkowska K, Bochnia M. (1999). Microbiological examination in children with chronic tonsillitis. New Medicine.
2445 Orenstein JM, Wahl SM. (1999). The macrophage origin of the HIV-expressing multinucleated giant cells in hyperplastic tonsils and adenoids. Ultrastruct Pathol.
2446 Ozawa A, Ohkido M, Haruki Y, et al. (1999). Treatments of generalized pustular psoriasis: a multicenter study in Japan. J Dermatol.
2447 Padeh S, Brezniak N, Zemer D, et al. (1999). Periodic fever, aphthous stomatitis, pharyngitis, and adenopathy syndrome: clinical characteristics and outcome. J Pediatr.
2448 Panarese A, Clarke RW, Yardley MP. (1999). Early post-operative morbidity following tonsillectomy in children: implications for day surgery. J Laryngol Otol.
2449 Paradise JL, Bluestone CD, Colborn DK, et al. (1999). Adenoidectomy and adenotonsillectomy for recurrent acute otitis media: parallel randomized clinical trials in children not previously treated with tympanostomy tubes. JAMA.
2450 Paulino AF, Huvos AG. (1999). Epithelial tumors of the lacrimal glands: a clinicopathologic study. Ann Diagn Pathol.
2451 Peterszegi G, Texier S, Robert L. (1999). Cell death by overload of the elastin-laminin receptor on human activated lymphocytes: protection by lactose and melibiose. Eur J Clin Invest.
2452 Pichichero ME, Hoeger W, Marsocci SM, et al. (1999). Variables influencing penicillin treatment outcome in streptococcal tonsillopharyngitis. Arch Pediatr Adolesc Med.
2453 Pichichero ME, Marsocci SM, Murphy ML, et al. (1999). Incidence of streptococcal carriers in private pediatric practice. Arch Pediatr Adolesc Med.
2454 Posey LA, Kerschner JE, Conley SF. (1999). Posttransplantation lymphoproliferative disease in children: otolaryngologic manifestations and management. South Med J.
2455 Putto-Laurila A, Mertsola J, Ruuskanen O. (1999). Viral causes of tonsillitis and fever unresponsive to antibiotic therapy. Pediatr Infect Dis J.
2456 Rak J, Pospiech L, Bochnia M, et al. (1999). Partial resection of tonsils - Tonsillotomy; analysis of indications and assessment of treatment results in children in the Otolaryngology Clinic of the Medical University of Wroclaw, 1989-1998. New Medicine.
2457 Ramadan HH. (1999). Adenoidectomy vs endoscopic sinus surgery for the treatment of pediatric sinusitis. Arch Otolaryngol Head Neck Surg.
2458 Ranjit S, Brett RH, Lu PK, et al. (1999). The incidence and management of post-tonsillectomy haemorrhage: a Singaporean experience. Singapore Med J.
2459 Rasche FM, Schwarz A, Keller F. (1999). Tonsillectomy does not prevent a progressive course in IgA nephropathy. Clin Nephrol.
2460 Rautakorpi UM, Lumio J, Huovinen P, et al. (1999). Indication-based use of antimicrobials in Finnish primary health care. Description of a method for data collection and results of its application. Scand J Prim Health Care.
2461 Reiter ER, Randolph GW, Pilch BZ. (1999). Microscopic detection of occult malignancy in the adult tonsil. Otolaryngol Head Neck Surg.
2462 Renehan AG, Gleave EN, Slevin NJ, et al. (1999). Clinico-pathological and treatment-related factors influencing survival in parotid cancer. Br J Cancer.
2463 Richardson MA. (1999). Sore throat, tonsillitis, and adenoiditis. Med Clin North Am.
2464 Riechelmann H, O'Connell JM, Rheinheimer MC, et al. (1999). The role of acoustic rhinometry in the diagnosis of adenoidal hypertrophy in pre-school children. Eur J Pediatr.
2465 Rivas Lacarte MP. (1999). Outpatient tonsillectomy: A prospective 7 years study - Complications and comparison with inpatients. Ambulatory Surgery.
2466 Roos K, Lind L, Holm SE, et al. (1999). Perianal streptococcal dermatitis. The possible protective role of alpha-streptococci against spread and recurrence of group A streptococcal throat infection. Scand J Prim Health Care.
2467 Rose JB, Cuy R, Cohen DE, et al. (1999). Preoperative oral dextromethorphan does not reduce pain or analgesic consumption in children after adenotonsillectomy. Anesth Analg.
2468 Rosen CL. (1999). Clinical features of obstructive sleep apnea hypoventilation syndrome in otherwise healthy children. Pediatr Pulmonol.
2469 Roux FX, Moussa R, Devaus B, et al. (1999). Subcranial fronto-orbito-nasal approach for ethmoidal cancers surgical techniques and results. Surg Neurol.
2470 Runer T, Lindberg S. (1999). Ciliostimulatory effects mediated by nitric oxide. Acta Otolaryngol.
2471 Rungby JA, Romeling F, Borum P. (1999). Tonsillectomy: assessment of quality by consultation rate after discharge. J Laryngol Otol.
2472 Sacchetti A, Warden T, Moakes ME, et al. (1999). Can sick children tell time?: emergency department presentation patterns of critically ill children. Acad Emerg Med.
2473 Saito T, Honda N, Saito H. (1999). Advantage and disadvantage of KTP-532 laser tonsillectomy compared with conventional method. Auris Nasus Larynx.
2474 Sakata N, Kawasome H, Terada N, et al. (1999). Differential activation and regulation of mitogen-activated protein kinases through the antigen receptor and CD40 in human B cells. Eur J Immunol.
2475 Saleh HA, Cain AJ, Mountain RE. (1999). Bipolar scissor tonsillectomy. Clin Otolaryngol Allied Sci.
2476 Salib RJ, Prior AJ, Howard DJ. (1999). Prevention before cure. Lancet.
2477 Salman M. (1999). Why does tonsillar herniation not occur in idiopathic intracranial hypertension?. Med Hypotheses.
2478 Schreiner C, Calhoun KH. (1999). Life-threatening infections of the head and neck: Part 1: Early clues to oral and otogenic involvement. Consultant.
2479 Schuz J, Kaletsch U, Meinert R, et al. (1999). Association of childhood leukaemia with factors related to the immune system. Br J Cancer.
2480 Sculerati N. (1999). Clinical opinion: preoperative sleep studies. Arch Otolaryngol Head Neck Surg.
2481 Seki H, Kasahara Y, Ohta K, et al. (1999). Antimicrobial activities of cefditoren against respiratory pathogens isolated from children in Japan. J Infect Chemother.
2482 Semple D, Russell S, Doyle E, et al. (1999). Comparison of morphine sulphate and codeine phosphate in children undergoing adenotonsillectomy. Paediatr Anaesth.
2483 Shabrawy AS. (1999). Does the pre-treatment with intravenous atropine or glycopyrrolate prevent, or ameliorate arrhythmias during halothane anaesthesia for adenotonsillectomy in children?. Scientific Journal of Al-Azhar Medical Faculty [Girls].
2484 Shanker S, Vig KW, Beck FM, et al. (1999). Dentofacial morphology and upper respiratory function in 8-10-year-old children. Clin Orthod Res.
2485 Shapiro NL, Seid AB, Pransky SM, et al. (1999). Adenotonsillectomy in the very young patient: cost analysis of two methods of postoperative care. Int J Pediatr Otorhinolaryngol.
2486 Shenkman Z, Holzman RS, Kim C, et al. (1999). Acupressure-acupuncture antiemetic prophylaxis in children undergoing tonsillectomy. Anesthesiology.
2487 Short JA, Cooper CM. (1999). Suspected recurrence of malignant hyperthermia after post-extubation shivering in the intensive care unit, 18 h after tonsillectomy. Br J Anaesth.
2488 Sisk EA, Heatley DG, Borowski BJ, et al. (1999). Obstructive sleep apnea in children with achondroplasia: surgical and anesthetic considerations. Otolaryngol Head Neck Surg.
2489 Smith I, Wilde A. (1999). Secondary tonsillectomy haemorrhage and non-steroidal anti-inflammatory drugs. J Laryngol Otol.
2490 Sood S, Strachan DR. (1999). Re: Bipolar scissor tonsillectomy. Clinical otolaryngology and allied sciences.
2491 Sood S, Strachan DR. (1999). Bipolar scissor tonsillectomy [Letter]. Clinical Otolaryngology and Allied Sciences.
2492 Sorensen WT, Henrichsen J, Bonding P. (1999). Does bismuth subgallate have haemostatic effects in tonsillectomy?. Clin Otolaryngol Allied Sci.
2493 Sorg RV, Kogler G, Wernet P. (1999). Identification of cord blood dendritic cells as an immature CD11c- population. Blood.
2494 Soultan Z, Wadowski S, Rao M, et al. (1999). Effect of treating obstructive sleep apnea by tonsillectomy and/or adenoidectomy on obesity in children. Arch Pediatr Adolesc Med.
2495 Spasokoukotskaja T, Sasvari-Szekely M, Keszler G, et al. (1999). Treatment of normal and malignant cells with nucleoside analogues and etoposide enhances deoxycytidine kinase activity. Eur J Cancer.
2496 Stewart IA. (1999). Evaluation of factors affecting outcome of surgery for otitis media with effusion in clinical practice. Int J Pediatr Otorhinolaryngol.
2497 Stjernquist-Desatnik A, Holst E. (1999). Tonsillar microbial flora: comparison of recurrent tonsillitis and normal tonsils. Acta Otolaryngol.
2498 Stoeckli SJ, Moe KS, Huber A, et al. (1999). A prospective randomized double-blind trial of fibrin glue for pain and bleeding after tonsillectomy. Laryngoscope.
2499 Strauss SG, Lynn AM, Bratton SL, et al. (1999). Ventilatory response to CO2 in children with obstructive sleep apnea from adenotonsillar hypertrophy. Anesth Analg.
2500 Suzuki M, Watanabe T, Mogi G. (1999). Clinical, bacteriological, and histological study of adenoids in children. Am J Otolaryngol.
2501 Swanepoel A, Semple P. (1999). Oral versus rectal diclofenac for postoperative tonsillectomy pain in children. Anaesthesia.
2502 Takenouchi N, Matsuoka E, Moritoyo T, et al. (1999). Molecular pathologic analysis of the tonsil in HTLV-I-infected individuals. J Acquir Immune Defic Syndr.
2503 Tan LK. (1999). Tonsillectomy--current practice and audit. Singapore Med J.
2504 Tano K, Olofsson C, Grahn-Hakansson E, et al. (1999). In vitro inhibition of S. pneumoniae, nontypable H. influenzae and M. catharralis by alpha-hemolytic streptococci from healthy children. Int J Pediatr Otorhinolaryngol.
2505 Tarkkila P, Saarnivaara L. (1999). Ketoprofen, diclofenac or ketorolac for pain after tonsillectomy in adults?. Br J Anaesth.
2506 Tetradis S, Kantor ML. (1999). Prevalence of skeletal and dental anomalies and normal variants seen in cephalometric and other radiographs of orthodontic patients. Am J Orthod Dentofacial Orthop.
2507 Thomas CL, Palmer TJ, Shipley P. (1999). Negative pressure pulmonary edema after a tonsillectomy and adenoidectomy in a pediatric patient: case report and review. Aana j.
2508 Thomas JO, Ogunsanwo BO, Ogunbiyi AO. (1999). Highlights of extranodal lymphomas in Ibadan, Nigeria. Cent Afr J Med.
2509 Thomas KT, Feder HM, Lawton AR, et al. (1999). Periodic fever syndrome in children. J Pediatr.
2510 Thwaites AJ, Edmends S, Tomlinson AA, et al. (1999). Double-blind comparison of sevofluran vs propofol and succinylcholine for tracheal intubation in children. Br J Anaesth.
2511 Thwaites AJ, Edmends S, Tomlinson AA, et al. (1999). Double-blind comparison of sevoflurane vs propofol and succinylcholine for tracheal intubation in children. British journal of anaesthesia.
2512 Tobias JD. (1999). End-tidal carbon dioxide monitoring during sedation with a combination of midazolam and ketamine for children undergoing painful, invasive procedures. Pediatr Emerg Care.
2513 Tomino Y. (1999). IgA nephropathy. From molecules to men. Contrib Nephrol.
2514 Torremorell M, Pijoan C, Dee S. (1999). Experimental exposure of young pigs using a pathogenic strain of Streptococcus suis serotype 2 and evaluation of this method for disease prevention. Can J Vet Res.
2515 Ulualp SO, Sahin D, Yilmaz N, et al. (1999). Increased adenoid mast cells in patients with otitis media with effusion. Int J Pediatr Otorhinolaryngol.
2516 Valtonen H, Qvarnberg Y, Nuutinen J. (1999). Tympanostomy in young children with recurrent otitis media. A long-term follow-up study. J Laryngol Otol.
2517 van den Berg AA, Montoya-Pelaez LF, Halliday EM, et al. (1999). Analgesia for adenotonsillectomy in children and young adults: a comparison of tramadol, pethidine and nalbuphine. Eur J Anaesthesiol.
2518 van der Westhuijzen AJ, van der Merwe J, Grotepass FW. (1999). Eagle's syndrome: lesser cornu amputation: an alternative surgical solution?. Int J Oral Maxillofac Surg.
2519 Viitanen H, Annila P, Viitanen M, et al. (1999). Premedication with midazolam delays recovery after ambulatory sevoflurane anesthesia in children. Anesth Analg.
2520 Viitanen H, Annila P, Viitanen M, et al. (1999). Midazolam premedication delays recovery from propofol-induced sevoflurane anesthesia in children 1-3 yr. Can J Anaesth.
2521 Viitanen H, Baer G, Koivu H, et al. (1999). The hemodynamic and Holter-electrocardiogram changes during halothane and sevoflurane anesthesia for adenoidectomy in children aged one to three years. Anesth Analg.
2522 Viitanen H, Tarkkila P, Mennander S, et al. (1999). Sevoflurane-maintained anesthesia induced with propofol or sevoflurane in small children: induction and recovery characteristics. Can J Anaesth.
2523 Virtaniemi J, Kokki H, Nikanne E, et al. (1999). Ketoprofen and fentanyl for pain after uvulopalatopharyngoplasty and tonsillectomy. Laryngoscope.
2524 Vories AA. (1999). Dysgeusia associated with tonsillectomy. Otolaryngol Head Neck Surg.
2525 Vosdoganis F, Baines DB. (1999). The effect of single dose intravenous dexamethasone in tonsillectomy in children. Anaesth Intensive Care.
2526 Vrabec JT, Deskin RW, Grady JJ. (1999). Meta-analysis of pediatric tympanoplasty. Arch Otolaryngol Head Neck Surg.
2527 Waldron P, Pegelow C, Neumayr L, et al. (1999). Tonsillectomy, adenoidectomy, and myringotomy in sickle cell disease: perioperative morbidity. Preoperative Transfusion in Sickle Cell Disease Study Group. J Pediatr Hematol Oncol.
2528 Waldron P, Pegelow C, Neumayr L, et al. (1999). Tonsillectomy, adenoidectomy, and myringotomy in sickle cell disease: Perioperative morbidity. Journal of Pediatric Hematology Oncology.
2529 Walker P, Temperley A, Bradshaw R. (1999). A 5 year prospective audit of the complications of paediatric diathermy tonsillectomy, adenoidectomy, and adeno-tonsillectomy. Australian Journal of Oto-Laryngology.
2530 Walker R, Dearlove OR, Aguilera I. (1999). Post tonsillectomy pain. Paediatr Anaesth.
2531 Wang EE, Einarson TR, Kellner JD, et al. (1999). Antibiotic prescribing for Canadian preschool children: evidence of overprescribing for viral respiratory infections. Clin Infect Dis.
2532 Wasik M, Chmielik M, Kowalska M, et al. (1999). Disturbances of lymphocyte subpopulations in children with tonsillar hypertrophy. New Medicine.
2533 Williams PM, Strome M, Eliachar I, et al. (1999). Impact of steroids on recovery after uvulopalatopharyngoplasty. Laryngoscope.
2534 Woods WA, Carter CT, Schlager TA. (1999). Detection of group A streptococci in children under 3 years of age with pharyngitis. Pediatr Emerg Care.
2535 Woolford TJ, Hanif J, Washband S, et al. (1999). The effect of previous antibiotic therapy on the bacteriology of the tonsils in children. Int J Clin Pract.
2536 Wu YW, Chin CT, Chan KM, et al. (1999). Pediatric Chiari I malformations: do clinical and radiologic features correlate?. Neurology.
2537 Zawadzka-Glos L, Chmielik M, Wasik M. (1999). Immunological response in hypertrophied palatine tonsils and blood pre- and postadenotonsillotomy. New Medicine.
2538 Abrahams JM, Arle JE, Hurst RW, et al. (2000). Extracranial aneurysms of the posterior inferior cerebellar artery. Cerebrovasc Dis.
2539 Adam D. (2000). Group A beta-haemolytic streptococcal (GABHS) tonsillopharyngitis is still a common problem. J Antimicrob Chemother.
2540 Adam D, Scholz H, Helmerking M. (2000). Short-course antibiotic treatment of 4782 culture-proven cases of group A streptococcal tonsillopharyngitis and incidence of poststreptococcal sequelae. J Infect Dis.
2541 Adam D, Scholz H, Helmerking M. (2000). Comparison of short-course (5 day) cefuroxime axetil with a standard 10 day oral penicillin V regimen in the treatment of tonsillopharyngitis. J Antimicrob Chemother.
2542 Aguilar A, Tinoco JC, Macias M, et al. (2000). Clinical and bacteriologic efficacy of amoxycillin b.d. (45 mg/kg/day) versus amoxycillin t.d.s (40 mg/kg/day) in children with group A beta-hemolytic streptococcal tonsillopharyngitis. J Chemother.
2543 Ahmed M, Khan AA, Siddiqi T, et al. (2000). A comparison of dissection-method and diathermy tonsillectomies. J Pak Med Assoc.
2544 Akker EH, Poels PJP, Staaij BK, et al. (2000). The NATAN project: A multicenter randomized trial of the effectiveness of adenotonsillectomy in children. Nederlands Tijdschrift voor Keel Neus Oorheelkunde.
2545 Al T, Al-Tamimi SF. (2000). Should antibiotics be mandatory in perioperative tonsillectomy and/or adenotonsillectomy?. Journal of the College of Physicians and Surgeons--Pakistan : JCPSP.
2546 Alsarraf R, Sie KC. (2000). Brain stem stroke associated with bupivacaine injection for adenotonsillectomy. Otolaryngol Head Neck Surg.
2547 Anderson BJ, Pearce S, McGann JE, et al. (2000). Investigations using logistic regression models on the effect of the LMA on morphine induced vomiting after tonsillectomy. Paediatr Anaesth.
2548 Anderson BJ, Ralph CJ, Stewart AW, et al. (2000). The dose-effect relationship for morphine and vomiting after day-stay tonsillectomy in children. Anaesth Intensive Care.
2549 Andus T, Gross V. (2000). Etiology and pathophysiology of inflammatory bowel disease--environmental factors. Hepatogastroenterology.
2550 Arena S. (2000). The use of the harmonic scalpel and post-operative pain following tonsillectomy - A prospective randomised clinical trial. Australian Journal of Otolaryngology.
2551 Astrom K, Magnusson CG, Papatziamos G, et al. (2000). Analysis of epsilon germline transcripts and IL-4 mRNA expression in the adenoids suggests local IgE switching. Allergy.
2552 Atallah N, Kumar M, Hilali A, et al. (2000). Post-operative pain in tonsillectomy: bipolar electrodissection technique vs dissection ligation technique. A double-blind randomized prospective trial. J Laryngol Otol.
2553 Ayshford CA, Kabbani M, Reddy TN. (2000). A new tongue plate for use in oropharyngeal KTP laser surgery. Rev Laryngol Otol Rhinol (Bord).
2554 Bafaqeeh SA. (2000). Eagle syndrome: classic and carotid artery types. J Otolaryngol.
2555 Bergstrom Y, Carlson T, Jonsson A. (2000). Nursing care for ambulatory day surgery: The concept and organization of nursing care. Ambulatory Surgery.
2556 Berman S, Bondy J, Byrns PJ, et al. (2000). Surgical management of uncomplicated otitis media in a pediatric Medicaid population. Ann Otol Rhinol Laryngol.
2557 Blotter JW, Yin L, Glynn M, et al. (2000). Otolaryngology consultation for peritonsillar abscess in the pediatric population. Laryngoscope.
2558 Boot H, van Wegen R, Poublon RM, et al. (2000). Long-term results of uvulopalatopharyngoplasty for obstructive sleep apnea syndrome. Laryngoscope.
2559 Brimacombe J, Keller C, Sartain J. (2000). Appropriate size of laryngeal mask. Br J Anaesth.
2560 Broadley SA, Deans J, Chataway SJ, et al. (2000). Multiple sclerosis and tonsillectomy: no evidence for an influence on the development of disease or clinical phenotype. Mult Scler.
2561 Brojerdian S, Bisschop P. (2000). Clinical advantage of abscess tonsillectomy in peritonsillar abscess. Acta Otorhinolaryngol Belg.
2562 Brook I, Shah K, Jackson W. (2000). Microbiology of healthy and diseased adenoids. Laryngoscope.
2563 Brosch S, Matthes C, Pirsig W, et al. (2000). Uvulopalatopharyngoplasty changes fundamental frequency of the voice--a prospective study. J Laryngol Otol.
2564 Broughton S, McClay JE, Murray A, et al. (2000). The effectiveness of tonsillectomy in diagnosing lymphoproliferative disease in pediatric patients after liver transplantation. Arch Otolaryngol Head Neck Surg.
2565 Brouillette RT, Morielli A, Leimanis A, et al. (2000). Nocturnal pulse oximetry as an abbreviated testing modality for pediatric obstructive sleep apnea. Pediatrics.
2566 Buchinsky FJ, Lowry MA, Isaacson G. (2000). Do adenoids regrow after excision?. Otolaryngol Head Neck Surg.
2567 Burton MJ, Towler B, Glasziou P. (2000). Tonsillectomy versus non-surgical treatment for chronic / recurrent acute tonsillitis. Cochrane Database Syst Rev.
2568 Bush A. (2000). Case 2: Assessment: cardiac enlargement. Paediatr Respir Rev.
2569 Byhahn C, Wilke HJ, Strouhal U, et al. (2000). Occupational exposure to nitrous oxide and desflurane during ear-nose-throat-surgery. Can J Anaesth.
2570 Cafferkey M. (2000). Oral cephalosporins in pharyngotonsillitis: is it necessary to use an antibiotic with activity against Haemophilus influenzae?. Clin Microbiol Infect.
2571 Cantekin EI. (2000). Adenoidectomy and adenotonsillectomy for recurrent otitis media. Jama.
2572 Cara DM, Armory P, Mahajan RP. (2000). Prolonged duration of neuromuscular block with rapacuronium in the presence of sevoflurane. Anesth Analg.
2573 Carr MM, Nguyen A, Poje C, et al. (2000). Correlation of findings on direct laryngoscopy and bronchoscopy with presence of extraesophageal reflux disease. Laryngoscope.
2574 Cataltepe S, Gornstein ER, Schick C, et al. (2000). Co-expression of the squamous cell carcinoma antigens 1 and 2 in normal adult human tissues and squamous cell carcinomas. J Histochem Cytochem.
2575 Charabi S, Balle V, Charabi B, et al. (2000). Surgical outcome in malignant parotid tumours. Acta Otolaryngol Suppl.
2576 Chay OM, Goh A, Abisheganaden J, et al. (2000). Obstructive sleep apnea syndrome in obese Singapore children. Pediatr Pulmonol.
2577 Chen SS, Shao KN, Chiang JH, et al. (2000). Aberrant cervical carotid artery. Zhonghua Yi Xue Za Zhi (Taipei).
2578 Clark MA, Wilson C, Sama A, et al. (2000). Differential cytokeratin and glycoconjugate expression by the surface and crypt epithelia of human palatine tonsils. Histochem Cell Biol.
2579 Coleman M, Kaufmann T, Nisce LZ, et al. (2000). Treatment of nonlaparotomized (clinical) stage I and II Hodgkin's disease patients by extended field and splenic irradiation. Int J Radiat Oncol Biol Phys.
2580 Collison PJ, Mettler B. (2000). Factors associated with post-tonsillectomy hemorrhage. Ear Nose Throat J.
2581 Collopy BT, Rodgers L, Woodruff P, et al. (2000). Early experience with clinical indicators in surgery. Aust N Z J Surg.
2582 Dahn KA, Glode MP, Chan KH. (2000). Periodic fever and pharyngitis in young children: a new disease for the otolaryngologist?. Arch Otolaryngol Head Neck Surg.
2583 Davis PJ, Finkel JC, Orr RJ, et al. (2000). A randomized, double-blinded study of remifentanil versus fentanyl for tonsillectomy and adenoidectomy surgery in pediatric ambulatory surgical patients. Anesth Analg.
2584 de Serres LM, Derkay C, Astley S, et al. (2000). Measuring quality of life in children with obstructive sleep disorders. Arch Otolaryngol Head Neck Surg.
2585 DeMonte F, Ginsberg LE, Clayman GL. (2000). Primary malignant tumors of the sphenoidal sinus. Neurosurgery.
2586 Depreitere B, Van Calenbergh F, van Loon J, et al. (2000). Posterior fossa decompression in syringomyelia associated with a Chiari malformation: a retrospective analysis of 22 patients. Clin Neurol Neurosurg.
2587 Derkay CS. (2000). A cost-effective approach for preoperative hemostatic assessment in children undergoing adenotonsillectomy. Arch Otolaryngol Head Neck Surg.
2588 Ebell MH, Smith MA, Barry HC, et al. (2000). The rational clinical examination. Does this patient have strep throat?. Jama.
2589 Elgun S, Guney K, Tuncer M, et al. (2000). A potential role for arginase in recurrent infections and hypertrophy of tonsillar and adenoidal tissue. Eur Arch Otorhinolaryngol.
2590 El-Hakim H, Nunez DA, Saleh HA, et al. (2000). A randomised controlled trial of the effect of regional nerve blocks on immediate post-tonsillectomy pain in adult patients. Clinical otolaryngology and allied sciences.
2591 El-Hakim H, Saleh H, Nunez DA, et al. (2000). The effect of regional nerve blocks on immediate post tonsillectomy pain in adult patients: a randomised controlled trial [abstract]. Clinical otolaryngology and allied sciences.
2592 Esuvaranathan VV, Mukherjee K, Streets C, et al. (2000). Intraoperative fentanyl reduces early vomiting after paediatric tonsillectomy compared with morphine. Paediatr Anaesth.
2593 Faulconbridge RV, Fowler S, Horrocks J, et al. (2000). Comparative audit of tonsillectomy. Clin Otolaryngol Allied Sci.
2594 Fenton RS, Long J. (2000). Ultrasonic tonsillectomy. J Otolaryngol.
2595 Filatov SM, Baer GA, Rorarius MG, et al. (2000). Efficacy and safety of premedication with oral ketamine for day-case adenoidectomy compared with rectal diazepam/diclofenac and EMLA. Acta Anaesthesiol Scand.
2596 Fini G, Gasparini G, Filippini F, et al. (2000). The long styloid process syndrome or Eagle's syndrome. J Craniomaxillofac Surg.
2597 Finkelstein Y, Wexler D, Berger G, et al. (2000). Anatomical basis of sleep-related breathing abnormalities in children with nasal obstruction. Arch Otolaryngol Head Neck Surg.
2598 Ford LC, Sulprizio SL, Rasgon BM. (2000). Otolaryngological manifestations of velocardiofacial syndrome: a retrospective review of 35 patients. Laryngoscope.
2599 Franco RA, Rosenfeld RM, Rao M. (2000). First place--resident clinical science award 1999. Quality of life for children with obstructive sleep apnea. Otolaryngol Head Neck Surg.
2600 Frisch M, Hjalgrim H, Jaeger AB, et al. (2000). Changing patterns of tonsillar squamous cell carcinoma in the United States. Cancer Causes Control.
2601 Fujieda S, Suzuki S, Sunaga H, et al. (2000). Production of interferon-gamma by tonsillar mononuclear cells in IgA nephropathy patients. Acta Otolaryngol.
2602 Fujieda S, Suzuki S, Sunaga H, et al. (2000). Induction of IgA against Haemophilus parainfluenzae antigens in tonsillar mononuclear cells from patients with IgA nephropathy. Clin Immunol.
2603 Furuhashi-Yonaha A, Dohi S, Oshima T, et al. (2000). Acute pulmonary edema caused by impaired switching from nasal to oral breathing in the emergence from anesthesia. Anesthesiology.
2604 Gabriel P, Mazoit X, Ecoffey C. (2000). Relationship between clinical history, coagulation tests, and perioperative bleeding during tonsillectomies in pediatrics. J Clin Anesth.
2605 Ghani AC, Donnelly CA, Ferguson NM, et al. (2000). Assessment of the prevalence of vCJD through testing tonsils and appendices for abnormal prion protein. Proc Biol Sci.
2606 Ghufoor K, Frosh A, Sandhu G, et al. (2000). Post-tonsillectomy patient care in the community. Int J Clin Pract.
2607 Gibberd R, Pathmeswaran A, Burtenshaw K. (2000). Using clinical indicators to identify areas for quality improvement. J Qual Clin Pract.
2608 Gnepp DR, Souther J. (2000). Skeletal muscle in routine tonsillectomy specimens: a common finding. Hum Pathol.
2609 Goldman AC, Govindaraj S, Rosenfeld RM. (2000). A meta-analysis of dexamethasone use with tonsillectomy. Otolaryngol Head Neck Surg.
2610 Goldstein NA, Post JC, Rosenfeld RM, et al. (2000). Impact of tonsillectomy and adenoidectomy on child behavior. Arch Otolaryngol Head Neck Surg.
2611 Gorlin RJ, Gelb B, Diaz GA, et al. (2000). WHIM syndrome, an autosomal dominant disorder: clinical, hematological, and molecular studies. Am J Med Genet.
2612 Gross CW, Harrison SE. (2000). Tonsils and adenoids. Pediatr Rev.
2613 Hack HA. (2000). Ondansetron - falsely accused?. Paediatr Anaesth.
2614 Hari CK, Raza SA, Clayton MI. (2000). Painrelieving effect of sucralfate in adult tonsillectomy. Laryngo-Rhino-Otologie.
2615 Haroun RI, Guarnieri M, Meadow JJ, et al. (2000). Current opinions for the treatment of syringomyelia and chiari malformations: survey of the Pediatric Section of the American Association of Neurological Surgeons. Pediatr Neurosurg.
2616 Hartnick CJ, Ruben RJ. (2000). Preoperative coagulation studies prior to tonsillectomy. Arch Otolaryngol Head Neck Surg.
2617 Hatton RC. (2000). Bismuth subgallate-epinephrine paste in adenotonsillectomies. Ann Pharmacother.
2618 Havkin N, Tatum SA, Shprintzen RJ. (2000). Velopharyngeal insufficiency and articulation impairment in velo-cardio-facial syndrome: the influence of adenoids on phonemic development. Int J Pediatr Otorhinolaryngol.
2619 Helvaci S, Gedikoglu S, Akalin H, et al. (2000). Tularemia in Bursa, Turkey: 205 cases in ten years. Eur J Epidemiol.
2620 Hennart D. (2000). The best approach for adenoidectomy and tonsillectomy. Acta Anaesthesiol Belg.
2621 Hilton DA. (2000). vCJD - predicting the future?. Neuropathol Appl Neurobiol.
2622 Hollis LJ, Burton MJ, Millar JM. (2000). Perioperative local anaesthesia for reducing pain following tonsillectomy. Cochrane Database Syst Rev.
2623 Holzmann D, Kaufmann T, Boesch M. (2000). On the decision of outpatient adenoidectomy and adenotonsillectomy in children. Int J Pediatr Otorhinolaryngol.
2624 Homer JJ, Williams BT, Semple P, et al. (2000). Tonsillectomy by guillotine is less painful than by dissection. Int J Pediatr Otorhinolaryngol.
2625 Howell TK. (2000). Oral transmucosal fentanyl citrate as a premedicant. British journal of anaesthesia.
2626 Huang RY, Shapiro NL. (2000). Adenotonsillar enlargement in pediatric patients following solid organ transplantation. Arch Otolaryngol Head Neck Surg.
2627 Hytonen M, Atula T, Pitkaranta A. (2000). Complications of acute sinusitis in children. Acta Otolaryngol Suppl.
2628 Ikram M, Khan MA, Ahmed M, et al. (2000). The histopathology of routine tonsillectomy specimens: results of a study and review of literature. Ear Nose Throat J.
2629 Ikushima I, Korogi Y, Hirai T, et al. (2000). Evaluation of dural sinus invasion and extension of extra-axial intracranial tumors. The advantages of a high-resolution postcontrast 3-D gradient-echo technique. Acta Radiol.
2630 Ivarsson M, Lundberg C. (2000). Nasopharyngeal tonsil's provision of the surface secretions with immunocytes, a property additional to antigen processing. Ann Otol Rhinol Laryngol.
2631 Joki-Erkkila VP, Pukander J, Laippala P. (2000). Alteration of clinical picture and treatment of pediatric acute otitis media over the past two decades. Int J Pediatr Otorhinolaryngol.
2632 Juarbe C. (2000). Efficacy of ceftibuten for pediatric patients undergoing adenotonsillectomy. Bol Asoc Med P R.
2633 Julian BA. (2000). Treatment of IgA nephropathy. Semin Nephrol.
2634 Kadirova R, Kartoglu HU, Strebel PM. (2000). Clinical characteristics and management of 676 hospitalized diphtheria cases, Kyrgyz Republic, 1995. J Infect Dis.
2635 Kakani RS, Callan ND, April MM. (2000). Superior adenoidectomy in children with palatal abnormalities. Ear Nose Throat J.
2636 Kardon DE, Thompson LD. (2000). A clinicopathologic series of 22 cases of tonsillar granulomas. Laryngoscope.
2637 Kardon DE, Wenig BM, Heffner DK, et al. (2000). Tonsillar lymphangiomatous polyps: a clinicopathologic series of 26 cases. Mod Pathol.
2638 Kawashima S, Niikuni N, Chia-hung L, et al. (2000). Cephalometric comparisons of craniofacial and upper airway structures in young children with obstructive sleep apnea syndrome. Ear Nose Throat J.
2639 Keller F, Rasche M. (2000). Reply to Satomura. Clin Nephrol.
2640 Kelly G, Gana P, Nielsen T, et al. (2000). The incidence of potential conjunctival contamination in tonsillectomy. J R Coll Surg Edinb.
2641 Kempf HG, Stover T, Lenarz T. (2000). Mastoiditis and acute otitis media in children with cochlear implants: recommendations for medical management. Ann Otol Rhinol Laryngol Suppl.
2642 Kirk VG, Morielli A, Gozal D, et al. (2000). Treatment of sleep-disordered breathing in children with myelomeningocele. Pediatr Pulmonol.
2643 Kokki H, Nikanne E, Ahonen R. (2000). The feasibility of pain treatment at home after adenoidectomy with ketoprofen tablets in small children. Paediatr Anaesth.
2644 Kokki H, Tuomilehto H, Tuovinen K. (2000). Pain management after adenoidectomy with ketoprofen: comparison of rectal and intravenous routes. Br J Anaesth.
2645 Kurien M, Stanis A, Job A, et al. (2000). Throat swab in the chronic tonsillitis: how reliable and valid is it?. Singapore Med J.
2646 Kvaerner KJ, Moen MC, Haugeto O, et al. (2000). Paediatric otolaryngology--disease profile and characteristics of children in outpatient surgery. Acta Otolaryngol Suppl.
2647 Kvaerner KJ, Nafstad P, Jaakkola JJ. (2000). Upper respiratory morbidity in preschool children: a cross-sectional study. Arch Otolaryngol Head Neck Surg.
2648 Lan AJ, Colford JM, Colford JM. (2000). The impact of dosing frequency on the efficacy of 10-day penicillin or amoxicillin therapy for streptococcal tonsillopharyngitis: A meta-analysis. Pediatrics.
2649 Lascaratos J, Assimakopoulos D. (2000). Surgery on the larynx and pharynx in Byzantium (AD 324-1453): early scientific descriptions of these operations. Otolaryngol Head Neck Surg.
2650 Lee LH, Ayoub E, Pichichero ME. (2000). Fewer symptoms occur in same-serotype recurrent streptococcal tonsillopharyngitis. Arch Otolaryngol Head Neck Surg.
2651 Lee SC, Wong JE, Kueh YK. (2000). Clinical characteristics and treatment outcome of 218 patients with non-Hodgkin's lymphoma in a Singaporean institution. Singapore Med J.
2652 Leelarasamee A, Leowattana W, Tobunluepop P, et al. (2000). Amoxicillin for fever and sore throat due to non-exudative pharyngotonsillitis: beneficial or harmful?. Int J Infect Dis.
2653 Levänen J. (2000). Ketamine and oxycodone in the management of postoperative pain. Military medicine.
2654 Lewis M, McClay JE, Schochet P. (2000). Lingual tonsillectomy for refractory paroxysmal cough. Int J Pediatr Otorhinolaryngol.
2655 Li KK, Riley RW, Powell NB, et al. (2000). Fiberoptic nasopharyngolaryngoscopy for airway monitoring after obstructive sleep apnea surgery. J Oral Maxillofac Surg.
2656 Lim NL. (2000). The use of the laryngeal mask airway in post-tonsillectomy haemorrhage--a case report. Ann Acad Med Singapore.
2657 Limb R, Walkley I. (2000). Adult day case tonsillectomy. Anaesth Intensive Care.
2658 Lurie JI, Sukhani R, Hotaling AJ, et al. (2000). Postoperative vomiting following ambulatory tonsillectomy in children: a comparison of ondansetron, dolasetron, and placebo.
2659 Lysakowski C, Fuchs-Buder T, Tassonyi E. (2000). Mivacurium or vecuronium for paediatric ENT surgery. Clinical experience and cost analysis. Anaesthesist.
2660 Marcus CL. (2000). Obstructive sleep apnea syndrome: differences between children and adults. Sleep.
2661 Marcus RJ, Victoria BA, Rushman SC, et al. (2000). Comparison of ketamine and morphine for analgesia after tonsillectomy in children. Br J Anaesth.
2662 Mattila PS, Nykanen A, Eloranta M, et al. (2000). Adenoids provide a microenvironment for the generation of CD4(+), CD45RO(+), L-selectin(-), CXCR4(+), CCR5(+) T lymphocytes, a lymphocyte phenotype found in the middle ear effusion. Int Immunol.
2663 Maw R. (2000). Re-evaluating the ENT procedures. Practitioner.
2664 McClay JE. (2000). Resistant bacteria in the adenoids: a preliminary report. Arch Otolaryngol Head Neck Surg.
2665 McEwen DR. (2000). Introduction. ENT surgery. Semin Perioper Nurs.
2666 McIsaac WJ, Coyte PC, Croxford R, et al. (2000). Otolaryngologists' perceptions of the indications for tympanostomy tube insertion in children. CMAJ.
2667 McNamara F, Sullivan CE. (2000). Treatment of obstructive sleep apnea syndrome in children. Sleep.
2668 Meadows J, Kraut M, Guarnieri M, et al. (2000). Asymptomatic Chiari Type I malformations identified on magnetic resonance imaging. J Neurosurg.
2669 Medina F, Segundo C, Brieva JA. (2000). Purification of human tonsil plasma cells: pre-enrichment step by immunomagnetic selection of CD31(+) cells. Cytometry.
2670 Melchior J, Spasov AA, Ostrovskij OV, et al. (2000). Double-blind, placebo-controlled pilot and phase III study of activity of standardized Andrographis paniculata Herba Nees extract fixed combination (Kan jang) in the treatment of uncomplicated upper-respiratory tract infection. Phytomedicine.
2671 Millman RP, Carlisle CC, Rosenberg C, et al. (2000). Simple predictors of uvulopalatopharyngoplasty outcome in the treatment of obstructive sleep apnea. Chest.
2672 Miman MC, Kirazli T, Ozyurek R. (2000). Doppler echocardiography in adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
2673 Moir MS, Bair E, Shinnick P, et al. (2000). Acetaminophen versus acetaminophen with codeine after pediatric tonsillectomy. Laryngoscope.
2674 Moore EW, Davies MW. (2000). Inhalational versus intravenous induction. A survey of emergency anaesthetic practice in the United Kingdom. Eur J Anaesthesiol.
2675 Murphy DB, Kavanagh P, O'Connor P, et al. (2000). Pharmacokinetic profile of rectally administered diclofenac sodium in children undergoing adenotonsillectomy. Paediatr Anaesth.
2676 Murray AD, Gibbs SR, Billings KR, et al. (2000). Respiratory difficulty following bismuth subgallate aspiration. Arch Otolaryngol Head Neck Surg.
2677 Myatt HM, Beckenham EJ. (2000). The use of diagnostic sleep nasendoscopy in the management of children with complex upper airway obstruction. Clin Otolaryngol Allied Sci.
2678 Nawaz H, Smith DS, Mazhari R, et al. (2000). Concordance of clinical findings and clinical judgment in the diagnosis of streptococcal pharyngitis. Acad Emerg Med.
2679 Nelson LM. (2000). Radiofrequency treatment for obstructive tonsillar hypertrophy. Arch Otolaryngol Head Neck Surg.
2680 Ng DKK, Cheung JMY. (2000). Childhood snoring - What's the problem?. Hong Kong Practitioner.
2681 Nieminen P, Lopponen H, Vayrynen M, et al. (2000). Nasalance scores in snoring children with obstructive symptoms. Int J Pediatr Otorhinolaryngol.
2682 Nieminen P, Tolonen U, Lopponen H. (2000). Snoring and obstructive sleep apnea in children: a 6-month follow-up study. Arch Otolaryngol Head Neck Surg.
2683 Nowlin JH. (2000). Coagulation studies prior to tonsillectomy: an unsettled and unsettling issue. Arch Otolaryngol Head Neck Surg.
2684 Ochi K, Ohashi T, Sugiura N, et al. (2000). Tonsillectomy using an ultrasonically activated scalpel. Laryngoscope.
2685 Orntoft I, Bonding P. (2000). Choanal adenoid syndrome--a preliminary report. Acta Otolaryngol Suppl.
2686 Orvidas LJ, Kasperbauer JL, Lewis JE, et al. (2000). Pediatric parotid masses. Arch Otolaryngol Head Neck Surg.
2687 Owen CM, Chalmers RJ, O'Sullivan T, et al. (2000). Antistreptococcal interventions for guttate and chronic plaque psoriasis. Cochrane Database Syst Rev.
2688 Owens J, Spirito A, Marcotte A, et al. (2000). Neuropsychological and Behavioral Correlates of Obstructive Sleep Apnea Syndrome in Children: A Preliminary Study. Sleep Breath.
2689 Ozkose Z, Akcabay M, Kemaloglu YK, et al. (2000). Relief of posttonsillectomy pain with low-dose tramadol given at induction of anesthesia in children. Int J Pediatr Otorhinolaryngol.
2690 Palme CE, Tomasevic P, Pohl DV. (2000). Evaluating the effects of oral prednisolone on recovery after tonsillectomy: a prospective, double-blind, randomized trial. Laryngoscope.
2691 Paulussen C, Claes J, Claes G, et al. (2000). Adenoids and tonsils, indications for surgery and immunological consequences of surgery. Acta Otorhinolaryngol Belg.
2692 Pearson J, Drake-Lee A. (2000). Day-case surgery and family response. Nurs Times.
2693 Pendeville PE, Von Montigny S, Dort JP, et al. (2000). Double-blind randomized study of tramadol vs. paracetamol in analgesia after day-case tonsillectomy in children. Eur J Anaesthesiol.
2694 Perkins JA, Sie K, Gray S. (2000). Presence of 22q11 deletion in postadenoidectomy velopharyngeal insufficiency. Arch Otolaryngol Head Neck Surg.
2695 Picard V, Dumont L, Pellegrini M. (2000). Quality of recovery in children: sevoflurane versus propofol. Acta Anaesthesiol Scand.
2696 Pichichero ME, Gooch WM. (2000). Comparison of cefdinir and penicillin V in the treatment of pediatric streptococcal tonsillopharyngitis. Pediatr Infect Dis J.
2697 Pichichero ME, Green JL, Francis AB, et al. (2000). Outcomes after judicious antibiotic use for respiratory tract infections seen in a private pediatric practice. Pediatrics.
2698 Pirsig W, Verse T. (2000). Long-term results in the treatment of obstructive sleep apnea. Eur Arch Otorhinolaryngol.
2699 Pizzuto MP, Brodsky L, Duffy L, et al. (2000). A comparison of microbipolar cautery dissection to hot knife and cold knife cautery tonsillectomy. Int J Pediatr Otorhinolaryngol.
2700 Podder S, Wig J, Malhotra SK, et al. (2000). Effect of pre-emptive analgesia on self-reported and biological measures of pain after tonsillectomy. Eur J Anaesthesiol.
2701 Pogranichnyy RM, Yoon KJ, Harms PA, et al. (2000). Characterization of immune response of young pigs to porcine circovirus type 2 infection. Viral Immunol.
2702 Prott FJ, Micke O, Haverkamp U, et al. (2000). Results of fast neutron therapy of adenoid cystic carcinoma of the salivary glands. Anticancer Res.
2703 Purser S, Royse CF, Velkov HA, et al. (2000). Topical application of ethanol to the tonsillar bed immediately following tonsillectomy does not improve post-operative analgesia. J Laryngol Otol.
2704 Quick ML, Sutter RW, Kobaidze K, et al. (2000). Risk factors for diphtheria: a prospective case-control study in the Republic of Georgia, 1995-1996. J Infect Dis.
2705 Randall DA, Johnstone PA, Foss RD, et al. (2000). Tonsillectomy in diagnosis of the unknown primary tumor of the head and neck. Otolaryngol Head Neck Surg.
2706 Ranga RK, Singh J, Gera A, et al. (2000). Nasal mucociliary clearance in adenotonsillar hypertrophy. Indian J Pediatr.
2707 Rau E. (2000). Treatment of acute tonsillitis with a fixed-combination herbal preparation. Adv Ther.
2708 Raut VV. (2000). Management of peritonsillitis/peritonsillar. Rev Laryngol Otol Rhinol (Bord).
2709 Raut VV, Yung MW. (2000). Peritonsillar abscess: the rationale for interval tonsillectomy. Ear Nose Throat J.
2710 Richards W, Ferdman RM. (2000). Prolonged morbidity due to delays in the diagnosis and treatment of obstructive sleep apnea in children. Clin Pediatr (Phila).
2711 Robinson SR, Purdie GL. (2000). Reducing post-tonsillectomy pain with cryoanalgesia: a randomized controlled trial. Laryngoscope.
2712 Rollins N, Booth T, Shapiro K. (2000). The use of gated cine phase contrast and MR venography in achondroplasia. Childs Nerv Syst.
2713 Rollins N, Booth T, Shapiro K. (2000). MR venography in children with complex craniosynostosis. Pediatr Neurosurg.
2714 Romsing J, Ostergaard D, Drozdziewicz D, et al. (2000). Diclofenac or acetaminophen for analgesia in paediatric tonsillectomy outpatients. Acta Anaesthesiol Scand.
2715 Rosbe KW, Jones D, Jalisi S, et al. (2000). Efficacy of postoperative follow-up telephone calls for patients who underwent adenotonsillectomy. Arch Otolaryngol Head Neck Surg.
2716 Rosen C. (2000). Diagnostic Approaches to Childhood Obstructive Sleep Apnea Hypopnea Syndrome. Sleep Breath.
2717 Rosenfeld RM. (2000). Surgical prevention of otitis media. Vaccine.
2718 Rovers MM, Straatman H, Ingels K, et al. (2000). The effect of ventilation tubes on language development in infants with otitis media with effusion: A randomized trial. Pediatrics.
2719 Rungby JA, Romeling F, Borum P. (2000). Methods of haemostasis in tonsillectomy assessed by pain scores and consultation rates. The Roskilde County Tonsillectomy Study. Acta Otolaryngol Suppl.
2720 Sakai J, Hebert F. (2000). Secondary enuresis associated with obstructive sleep apnea. J Am Acad Child Adolesc Psychiatry.
2721 Satko I, Stanko P, Longauerova I. (2000). Salivary gland tumours treated in the stomatological clinics in Bratislava. J Craniomaxillofac Surg.
2722 Sato M, Suzuki M, Oshima T, et al. (2000). Long-term follow-up of obstructive sleep apnea syndrome following surgery in children and adults. Tohoku J Exp Med.
2723 Senior BA, Rosenthal L, Lumley A, et al. (2000). Efficacy of uvulopalatopharyngoplasty in unselected patients with mild obstructive sleep apnea. Otolaryngol Head Neck Surg.
2724 Seno A, Arata J, Matsuura Y, et al. (2000). Palmoplantar pustulosis with pustulotic arthroosteitis involving temporal osteomyelitis and meningitis. J Dermatol.
2725 Shah RK, Nemati B, Wang LV, et al. (2000). Optical-thermal simulation of human tonsillar tissue irradiation: clinical implications. Lasers Surg Med.
2726 Shukla GK, Garg A, Bhatia N, et al. (2000). Significance of free radicals in chronic tonsillitis. Boll Chim Farm.
2727 Sim RJ, Harrison MM, Moxon ER, et al. (2000). Underestimation of meningococci in tonsillar tissue by nasopharyngeal swabbing. Lancet.
2728 Souza BB, Hennemann GV, Anselmo-Lima WT. (2000). Importance of nasal fiberoptic examination in the presence of a normal X-ray of the cavum. Int J Pediatr Otorhinolaryngol.
2729 Stanislaw P, Koltai PJ, Feustel PJ. (2000). Comparison of power-assisted adenoidectomy vs adenoid curette adenoidectomy. Arch Otolaryngol Head Neck Surg.
2730 Stenfors LE, Bye HM, Raisanen S, et al. (2000). Bacterial penetration into tonsillar surface epithelium during infectious mononucleosis. J Laryngol Otol.
2731 Stewart MG. (2000). Pediatric outcomes research: development of an outcomes instrument for tonsil and adenoid disease. Laryngoscope.
2732 Stewart MG, Friedman EM, Sulek M, et al. (2000). Quality of life and health status in pediatric tonsil and adenoid disease. Arch Otolaryngol Head Neck Surg.
2733 Suzuki S, Fujieda S, Sunaga H, et al. (2000). Immune response of tonsillar lymphocytes to Haemophilus parainfluenzae in patients with IgA nephropathy. Clin Exp Immunol.
2734 Suzuki S, Fujieda S, Sunaga H, et al. (2000). Synthesis of immunoglobulins against Haemophilus parainfluenzae by tonsillar lymphocytes from patients with IgA nephropathy. Nephrol Dial Transplant.
2735 Swallow J, Briggs M, Semple P. (2000). Pain at home: children's experience of tonsillectomy. J Child Health Care.
2736 Syms MJ, Birkmire-Peters DP, Holtel MR. (2000). Incidence of carcinoma in incidental tonsil asymmetry. Laryngoscope.
2737 Szeremeta W, Parameswaran MS, Isaacson G. (2000). Adenoidectomy with laser or incisional myringotomy for otitis media with effusion. Laryngoscope.
2738 Temmel AF, Herbst T, Popovic R, et al. (2000). Upper airway findings in patients with nocturnal breathing disorders. Wien Klin Wochenschr.
2739 Thorneman G, Akervall J. (2000). Pain treatment after tonsillectomy: advantages of analgesics regularly given compared with analgesics on demand. Acta Otolaryngol.
2740 Thorp MA, Isaacs S, Sellars SL. (2000). Tonsillectomy and tonsillitis in Cape Town--age and sex of patients. S Afr J Surg.
2741 Tripathi M, Pandey M. (2000). Atypical “tails-up” capnograph due to breach in the sampling tube of side-stream capnometer. J Clin Monit Comput.
2742 Tuomilehto H, Kokki H, Tuovinen K. (2000). Comparison of intravenous and oral ketoprofen for postoperative pain after adenoidectomy in children. Br J Anaesth.
2743 Uysal S, Sancak R, Sunbul M. (2000). A comparison of the efficacy of cefuroxime axetil and intramuscular benzathine penicillin for treating streptococcal tonsillopharyngitis. Ann Trop Paediatr.
2744 Valtonen HJ, Blomgren KE, Qvarnberg YH. (2000). Consequences of adenoidectomy in conjunction with tonsillectomy in children. Int J Pediatr Otorhinolaryngol.
2745 van Balen FA, de Melker RA. (2000). Persistent otitis media with effusion: can it be predicted? A family practice follow-up study in children aged 6 months to 6 years. J Fam Pract.
2746 Vasku V, Vasku A, Izakovicova Holla L, et al. (2000). Polymorphisms in inflammation genes (angiotensinogen, TAP1 and TNF-beta) in psoriasis. Arch Dermatol Res.
2747 Verbeke CS, Wenthe U, Bergler WF, et al. (2000). Characterization of the expanded T cell population in infectious mononucleosis: apoptosis, expression of apoptosis-related genes, and Epstein-Barr virus (EBV) status. Clin Exp Immunol.
2748 Verse T, Kroker BA, Pirsig W, et al. (2000). Tonsillectomy as a treatment of obstructive sleep apnea in adults with tonsillar hypertrophy. Laryngoscope.
2749 Viitanen H, Baer G, Annila P. (2000). Recovery characteristics of sevoflurane or halothane for day-case anaesthesia in children aged 1-3 years. Acta Anaesthesiol Scand.
2750 Vineis P, Crosignani P, Sacerdote C, et al. (2000). Haematopoietic cancer and medical history: a multicentre case control study. J Epidemiol Community Health.
2751 Viswanathan N, Nair SS, Thulseedharan S. (2000). Effect of tonsillectomy on aso-titre. Indian J Otolaryngol Head Neck Surg.
2752 Vogler RC, Ii FJ, Pilgram TK. (2000). Age-specific size of the normal adenoid pad on magnetic resonance imaging. Clin Otolaryngol Allied Sci.
2753 Vowles R, Loney E, Williams H, et al. (2000). Is paediatric day case tonsillectomy desirable? The parents' perspective. Int J Clin Pract.
2754 Wachtel JM, Kuehn DP, Weiss KS. (2000). Hypernasality after tonsillectomy without adenoidectomy in an adult. Otolaryngol Head Neck Surg.
2755 Wang JJ, Ho ST, Tzeng JI, et al. (2000). The effect of timing of dexamethasone administration on its efficacy as a prophylactic antiemetic for postoperative nausea and vomiting. Anesth Analg.
2756 Wardle EN. (2000). Ways of treating IgA nephropathies. Saudi J Kidney Dis Transpl.
2757 Wardle EN. (2000). Rationales for treating IgA nephropathies. Ren Fail.
2758 Wasowicz DK, Schmitz RF, Borghans HJ, et al. (2000). Growth potential of ambulatory surgery in The Netherlands. Ambulatory Surgery.
2759 Wei JL, Beatty CW, Gustafson RO. (2000). Evaluation of posttonsillectomy hemorrhage and risk factors. Otolaryngol Head Neck Surg.
2760 Weir N. (2000). Otorhinolaryngology. Postgrad Med J.
2761 Wilson KL, Lakheeram II, Morielli A, et al. (2000). Is polysomnography predictive of respiratory complications post adenotonsillectomy in children?. Paediatr Anaesth.
2762 Wolfensberger M, Haury JA, Linder T. (2000). Parent satisfaction 1 year after adenotonsillectomy of their children. Int J Pediatr Otorhinolaryngol.
2763 Woolford TJ, Ahmed A, Willatt DJ, et al. (2000). Spontaneous resolution of tonsillitis in children on the waiting list for tonsillectomy. Clin Otolaryngol Allied Sci.
2764 Yoskovitch A, Samaha M, Sweet R. (2000). Suction cautery use in lingual tonsillectomy. J Otolaryngol.
2765 Zamarron C, Gude F, Alvarez JM, et al. (2000). Airway disorders and pulmonary function in snorers. A population-based study. Respir Med.
2766 Zhuang Q, Bastien Y, Mazer BD. (2000). Activation via multiple signaling pathways induces down-regulation of platelet-activating factor receptors on human B lymphocytes. J Immunol.
2767 Zia MR, Malik KI, Haider Z, et al. (2000). Bupivacaine infiltration for the control of post-tonsillectomy pain. Pakistan Postgraduate Medical Journal.
2768 Zwart S, Sachs AP, Ruijs GJ, et al. (2000). Penicillin for acute sore throat: randomised double blind trial of seven days versus three days treatment or placebo in adults. BMJ.
2769 (2001). Steroid therapy of acute ENT infections: rarely indicated. Prescrire Int.
2770 (2001). Surgery for persistent otitis media with effusion: generalizability of results from the UK trial (TARGET). Trial of Alternative Regimens in Glue Ear Treatment. Clin Otolaryngol Allied Sci.
2771 (2001). “Hear this” about ear infections. Health News.
2772 (2001). Harmonic scalpel tonsillectomy. Clin Privil White Pap.
2773 Abdul-Baqi KJ, Shakhatreh FM, Khader QA. (2001). Use of adenoidectomy and adenotonsillectomy in children with otitis media with effusion. Ear Nose Throat J.
2774 Acuna C, Rabasseda X. (2001). Amoxicillin-sulbactam: A clinical and therapeutic review. Drugs Today (Barc).
2775 Akural EI, Koivunen PT, Teppo H, et al. (2001). Post-tonsillectomy pain: a prospective, randomised and double-blinded study to compare an ultrasonically activated scalpel technique with the blunt dissection technique. Anaesthesia.
2776 Alzate JC, Kothbauer KF, Jallo GI, et al. (2001). Treatment of Chiari I malformation in patients with and without syringomyelia: a consecutive series of 66 cases. Neurosurg Focus.
2777 Ananthanarayan C, Blight K. (2001). Dystonic reaction after anesthesia. Can J Anaesth.
2778 Anderson BJ, Woollard GA, Holford NH. (2001). Acetaminophen analgesia in children: placebo effect and pain resolution after tonsillectomy. Eur J Clin Pharmacol.
2779 Anuntaseree W, Rookkapan K, Kuasirikul S, et al. (2001). Snoring and obstructive sleep apnea in Thai school-age children: prevalence and predisposing factors. Pediatr Pulmonol.
2780 Aouad MT, Siddik SS, Rizk LB, et al. (2001). The effect of dexamethasone on postoperative vomiting after tonsillectomy. Anesth Analg.
2781 Aragon SB. (2001). Surgical management for snoring and sleep apnea. Dent Clin North Am.
2782 Arens R, McDonough JM, Costarino AT, et al. (2001). Magnetic resonance imaging of the upper airway structure of children with obstructive sleep apnea syndrome. Am J Respir Crit Care Med.
2783 Arnstein F. (2001). New variant Creutzfeldt-Jakob disease--is our practice safe?. Anaesthesia.
2784 Asaf T, Reuveni H, Yermiahu T, et al. (2001). The need for routine pre-operative coagulation screening tests (prothrombin time PT/partial thromboplastin time PTT) for healthy children undergoing elective tonsillectomy and/or adenoidectomy. Int J Pediatr Otorhinolaryngol.
2785 Aspinall RL, Mayor A. (2001). A prospective randomized controlled study of the efficacy of ketamine for postoperative pain relief in children after adenotonsillectomy. Paediatr Anaesth.
2786 Attia MW, Zaoutis T, Klein JD, et al. (2001). Performance of a predictive model for streptococcal pharyngitis in children. Arch Pediatr Adolesc Med.
2787 Back L, Paloheimo M, Ylikoski J. (2001). Traditional tonsillectomy compared with bipolar radiofrequency thermal ablation tonsillectomy in adults: a pilot study. Arch Otolaryngol Head Neck Surg.
2788 Bailey CR. (2001). Management of outpatient ear, nose and throat surgery. Curr Opin Anaesthesiol.
2789 Bannister CF, Brosius KK, Sigl JC, et al. (2001). The effect of bispectral index monitoring on anesthetic use and recovery in children anesthetized with sevoflurane in nitrous oxide. Anesth Analg.
2790 Barzilai A, Miron D, Sela S. (2001). Etiology and Management of Acute and Recurrent Group A Streptococcal Tonsillitis. Curr Infect Dis Rep.
2791 Bergler W, Huber K, Hammerschmitt N, et al. (2001). Tonsillectomy with argon plasma coagulation (APC): evaluation of pain and hemorrhage. Laryngoscope.
2792 Bernstein JM, Ballow M, Rich G. (2001). Detection of intracytoplasmic cytokines by flow cytometry in adenoids and peripheral blood lymphocytes of children. Ann Otol Rhinol Laryngol.
2793 Bernstein JM, Dryja D, Murphy TF. (2001). Molecular typing of paired bacterial isolates from the adenoid and lateral wall of the nose in children undergoing adenoidectomy: implications in acute rhinosinusitis. Otolaryngol Head Neck Surg.
2794 Bhargava D, Bhusnurmath B, Sundaram KR, et al. (2001). Tonsillar actinomycosis: a clinicopathological study. Acta Trop.
2795 Bhattacharyya N. (2001). Evaluation of post-tonsillectomy bleeding in the adult population. Ear Nose Throat J.
2796 Bhattacharyya N, Kepnes LJ, Shapiro J. (2001). Efficacy and quality-of-life impact of adult tonsillectomy. Arch Otolaryngol Head Neck Surg.
2797 Bland RM, Bulgarelli S, Ventham JC, et al. (2001). Total energy expenditure in children with obstructive sleep apnoea syndrome. Eur Respir J.
2798 Blomgren K, Qvarnberg YH, Valtonen HJ. (2001). A prospective study on pros and cons of electrodissection tonsillectomy. Laryngoscope.
2799 Bockelmann R, Neugebauer P, Paseban ND, et al. (2001). Suprabasal overexpression of the hsRPB7 gene in psoriatic epidermis as identified by a reverse transcriptase-polymerase chain reaction differential display model comparing psoriasis plaque tissue with peritonsillar mucosa. Am J Pathol.
2800 Brokstad KA, Cox RJ, Eriksson JC, et al. (2001). High prevalence of influenza specific antibody secreting cells in nasal mucosa. Scand J Immunol.
2801 Brook I. (2001). Failure of penicillin to eradicate group A beta-hemolytic streptococci tonsillitis: causes and management. J Otolaryngol.
2802 Brook I, Aronovitz GH, Pichichero ME. (2001). Open-Label, parallel-group, multicenter, randomized study of cefprozil versus erythromycin in children with group A streptococcal pharyngitis/tonsillitis. Clin Ther.
2803 Brook I, Shah K. (2001). Effect of amoxycillin with or without clavulanate on adenoid bacterial flora. J Antimicrob Chemother.
2804 Brook I, Shah K. (2001). Bacteriology of adenoids and tonsils in children with recurrent adenotonsillitis. Ann Otol Rhinol Laryngol.
2805 Brouillette RT, Manoukian JJ, Ducharme FM, et al. (2001). Efficacy of fluticasone nasal spray for pediatric obstructive sleep apnea. J Pediatr.
2806 Brunetti L, Rana S, Lospalluti ML, et al. (2001). Prevalence of obstructive sleep apnea syndrome in a cohort of 1,207 children of southern Italy. Chest.
2807 Cameron PU, Stent G. (2001). Isolation of human tonsillar dendritic cells. Methods Mol Med.
2808 Campo JV, Di Lorenzo C, Chiappetta L, et al. (2001). Adult outcomes of pediatric recurrent abdominal pain: do they just grow out of it?. Pediatrics.
2809 Capper R, Canter RJ. (2001). Is the incidence of tonsillectomy influenced by the family medical or social history?. Clin Otolaryngol Allied Sci.
2810 Capper R, Canter RJ. (2001). How well do parents recognize the difference between tonsillitis and other sore throats?. Clin Otolaryngol Allied Sci.
2811 Capper R, Canter RJ. (2001). Is there agreement among general practitioners, paediatricians and otolaryngologists about the management of children with recurrent tonsillitis?. Clin Otolaryngol Allied Sci.
2812 Capper R, Canter RJ. (2001). A comparison of sleep quality in normal children and children awaiting (adeno)tonsillectomy for recurrent tonsillitis. Clin Otolaryngol Allied Sci.
2813 Carr MM, Muecke CJ, Sohmer B, et al. (2001). Comparison of postoperative pain: tonsillectomy by blunt dissection or electrocautery dissection. J Otolaryngol.
2814 Carr MM, Nagy ML, Pizzuto MP, et al. (2001). Correlation of findings at direct laryngoscopy and bronchoscopy with gastroesophageal reflux disease in children: a prospective study. Arch Otolaryngol Head Neck Surg.
2815 Carr MM, Poje CP, Ehrig D, et al. (2001). Incidence of reflux in young children undergoing adenoidectomy. Laryngoscope.
2816 Chae SW, Lee SH, Cho JH, et al. (2001). Expression of human beta-defensin 1 mRNA in human palatine tonsil. Acta Otolaryngol.
2817 Chan SC, Dawes PJ. (2001). The management of severe infectious mononucleosis tonsillitis and upper airway obstruction. J Laryngol Otol.
2818 Chicken DW, Sivaji N, Kanegaonkar RG. (2001). A warning to users of disposable tonsillectomy instruments. J Laryngol Otol.
2819 Chidambaram A, Nigam A, Cardozo AA. (2001). Anticipated absence from work ('sick leave') following routine ENT surgery: are we giving the correct advice? A postal questionnaire survey. Clin Otolaryngol Allied Sci.
2820 Chikungwa MT, Bandason C. (2001). Sinister unilateral tonsillar enlargement. Cent Afr J Med.
2821 Childers NK, Powell WD, Tong G, et al. (2001). Human salivary immunoglobulin and antigen-specific antibody activity after tonsillectomy. Oral Microbiol Immunol.
2822 Ciacci C, Cavallaro R, Romano R, et al. (2001). Increased risk of surgery in undiagnosed celiac disease. Dig Dis Sci.
2823 Cinar U, Vural C, Cakir B, et al. (2001). Nocturnal enuresis and upper airway obstruction. Int J Pediatr Otorhinolaryngol.
2824 Cohen D, Shechter Y, Slatkine M, et al. (2001). Laser myringotomy in different age groups. Arch Otolaryngol Head Neck Surg.
2825 Cohen IT, Hannallah RS, Hummer KA. (2001). The incidence of emergence agitation associated with desflurane anesthesia in children is reduced by fentanyl. Anesth Analg.
2826 Cook SP. (2001). Bupivacaine injection to control tonsillectomy pain. Arch Otolaryngol Head Neck Surg.
2827 Cook SP, Brodsky L, Reilly JS, et al. (2001). Effectiveness of adenoidectomy and laser tympanic membrane fenestration. Laryngoscope.
2828 Corbo GM, Forastiere F, Agabiti N, et al. (2001). Snoring in 9- to 15-year-old children: risk factors and clinical relevance. Pediatrics.
2829 Courtney MJ, Cabraal D. (2001). Tramadol vs. diclofenac for posttonsillectomy analgesia. Arch Otolaryngol Head Neck Surg.
2830 Coyte PC, Croxford R, McIsaac W, et al. (2001). The role of adjuvant adenoidectomy and tonsillectomy in the outcome of the insertion of tympanostomy tubes. N Engl J Med.
2831 Culy CR, Bhana N, Plosker GL. (2001). Ondansetron: a review of its use as an antiemetic in children. Paediatr Drugs.
2832 Danielides V, Patrikakos G, Milionis HJ, et al. (2001). An unusual case of recurrent tonsillitis due to Pseudomonas aeruginosa. Acta Otorhinolaryngol Belg.
2833 Dawson GS, Seidman P, Ramadan HH. (2001). Improved postoperative pain control in pediatric adenotonsillectomy with dextromethorphan. Laryngoscope.
2834 De Diego JI, Prim MP, Hardisson D, et al. (2001). Post-transplant lymphoproliferative disease in tonsils of children with liver transplantation. Int J Pediatr Otorhinolaryngol.
2835 Dejonckere PH, van Wijngaarden HA. (2001). Retropharyngeal autologous fat transplantation for congenital short palate: a nasometric assessment of functional results. Ann Otol Rhinol Laryngol.
2836 Dimond B. (2001). Legal aspects of consent 9: when parents are overruled. Br J Nurs.
2837 Don DM, Yellon RF, Casselbrant ML, et al. (2001). Efficacy of a stepwise protocol that s intravenous antibiotic therapy for the management of chronic sinusitis in children and adolescents. Arch Otolaryngol Head Neck Surg.
2838 Ebenfelt A, Ivarsson M. (2001). Neutrophil migration in tonsils. J Anat.
2839 Endo LH, Ferreira D, Montenegro MC, et al. (2001). Detection of Epstein-Barr virus in tonsillar tissue of children and the relationship with recurrent tonsillitis. Int J Pediatr Otorhinolaryngol.
2840 Engelhardt T, Crawford M. (2001). Sublingual morphine may be a suitable alternative for pain control in children in the postoperative period. Paediatr Anaesth.
2841 Engstrand I, Augustsson I, Bergemalm PO, et al. (2001). Demonstration of Chlamydia pneumoniae in the adenoid from children with and without secretory otitis media using immunohistochemistry and PCR. Scand J Infect Dis.
2842 Erdamar B, Suoglu Y, Cuhadaroglu C, et al. (2001). Evaluation of clinical parameters in patients with obstructive sleep apnea and possible correlation with the severity of the disease. Eur Arch Otorhinolaryngol.
2843 Ezzat AA, Ibrahim EM, El Weshi AN, et al. (2001). Localized non-Hodgkin's lymphoma of Waldeyer's ring: clinical features, management, and prognosis of 130 adult patients. Head Neck.
2844 Fazi L, Jantzen EC, Rose JB, et al. (2001). A comparison of oral clonidine and oral midazolam as preanesthetic medications in the pediatric tonsillectomy patient. Anesth Analg.
2845 Fearon JA, Swift DM, Bruce DA. (2001). New methods for the evaluation and treatment of craniofacial dysostosis-associated cerebellar tonsillar herniation. Plast Reconstr Surg.
2846 Friese KH, Feuchter U, Ludtke R, et al. (2001). Results of a randomised prospective double-blind clinical trial on the homeopathic treatment of adenoid vegetations. European journal of general practice.
2847 Froom J, Culpepper L, Green LA, et al. (2001). A cross-national study of acute otitis media: risk factors, severity, and treatment at initial visit. Report from the International Primary Care Network (IPCN) and the Ambulatory Sentinel Practice Network (ASPN). J Am Board Fam Pract.
2848 Frosh A, Joyce R, Johnson A. (2001). Iatrogenic vCJD from surgical instruments. Bmj.
2849 Furuta T, Hotta O, Horigome I, et al. (2001). Steroid pulse therapy combined with tonsillectomy in IgA nephropathy associated with diabetes mellitus. Nephron.
2850 Giannoni C, White S, Enneking FK, et al. (2001). Ropivacaine with or without clonidine improves pediatric tonsillectomy pain. Arch Otolaryngol Head Neck Surg.
2851 Gibson WS. (2001). Concerns with bupivacaine injection. Arch Otolaryngol Head Neck Surg.
2852 Goldenberg D, Golz A, Netzer A, et al. (2001). Synergistic necrotizing cellulitis as a complication of peritonsillar abscess. Am J Otolaryngol.
2853 Gorfien JL, Noble B, Brodsky L. (2001). Comparison of the microanatomical distributions of macrophages and dendritic cells in normal and diseased tonsils. Ann Otol Rhinol Laryngol.
2854 Gorur K, Doven O, Unal M, et al. (2001). Preoperative and postoperative cardiac and clinical findings of patients with adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
2855 Gosain AK, Remmler D. (2001). Furlow palatoplasty to restore velopharyngeal competence following tonsillectomy avulsion of a pharyngeal flap. Cleft Palate Craniofac J.
2856 Gozal D, Pope DW. (2001). Snoring during early childhood and academic performance at ages thirteen to fourteen years. Pediatrics.
2857 Gross CW, Gallagher R, Schlosser RJ, et al. (2001). Autologous fibrin sealant reduces pain after tonsillectomy. Laryngoscope.
2858 Gross G, Gundlach K, Reichart PA. (2001). Virus infections and tumors of the oral mucosae. Eur J Med Res.
2859 Guirguis M, Berkowitz RG. (2001). Meningococcal septicemia post adenotonsillectomy in a child: case report. Int J Pediatr Otorhinolaryngol.
2860 Haczynski J, Bardadin J, Gryczynska D, et al. (2001). A comparative study of cefaclor vs. amoxicillin/clavulanate in tonsillopharyngitis. Med Sci Monit.
2861 Heatley DG. (2001). Perioperative intravenous steroid treatment and tonsillectomy. Arch Otolaryngol Head Neck Surg.
2862 Hengerer AS. (2001). Do intravenous steroids play a role for tonsillectomy patients?. Arch Otolaryngol Head Neck Surg.
2863 Herreen PG, Wiese MC. (2001). Concealed post-tonsillectomy haemorrhage associated with the use of the antiemetic tropisetron. Anaesth Intensive Care.
2864 Hirunwiwatkul P. (2001). Pain-relieving effect of local steroid injection in vulopalatopharyngoplasty. J Med Assoc Thai.
2865 Hirunwiwatkul P. (2001). Pain-relieving effect of local steroid injection in uvulopalatopharyngoplasty. Chotmaihet thangphaet.
2866 Hocwald E, Korkmaz H, Yoo GH, et al. (2001). Prognostic factors in major salivary gland cancer. Laryngoscope.
2867 Hohn DJ, Deschler DG, Tucker JA. (2001). Central incisor width as a predictor of appropriate curette size in adenoidectomy. Ann Otol Rhinol Laryngol.
2868 Homer JJ, Swallow J, Semple P. (2001). Audit of pain management at home following tonsillectomy in children. J Laryngol Otol.
2869 Hotta O, Miyazaki M, Furuta T, et al. (2001). Tonsillectomy and steroid pulse therapy significantly impact on clinical remission in patients with IgA nephropathy. Am J Kidney Dis.
2870 Huang SW, Giannoni C. (2001). The risk of adenoid hypertrophy in children with allergic rhinitis. Ann Allergy Asthma Immunol.
2871 Hui HNT, Ng DKK, Yau H, et al. (2001). Obstructive sleep apnoea syndrome presented as failure to thrive in a Down's syndrome child. Hong Kong Practitioner.
2872 Hurlstone DP, Sanders DS, Smith A, et al. (2001). Tonsillar metastasis: A rare presentation of gastric carcinoma. Eur J Surg Oncol.
2873 Ip-Yam PC, Goh MH, Chan YH, et al. (2001). Clinical evaluation of the Mapleson theoretical ideal fresh gas flow sequence at the start of low-flow anaesthesia with isoflurane, sevoflurane and desflurane. Anaesthesia.
2874 Ivarsson M, Lundberg C. (2001). Phagocytosis in the nasopharyngeal secretion by cells from the adenoid. Acta Otolaryngol.
2875 Jarboe JK, Zeitels SM, Elias B. (2001). Tonsillectomy and adenoidectomy in singers. J Voice.
2876 Jeffrey M, Martin S, Thomson JR, et al. (2001). Onset and distribution of tissue prp accumulation in scrapie-affected suffolk sheep as demonstrated by sequential necropsies and tonsillar biopsies. J Comp Pathol.
2877 Jones JE, Tabaee A, Glasgold R, et al. (2001). Efficacy of gastric aspiration in reducing posttonsillectomy vomiting. Arch Otolaryngol Head Neck Surg.
2878 Kawamura T, Morioka T, Nishio S, et al. (2001). Cerebral abnormalities in lumbosacral neural tube closure defect: MR imaging evaluation. Childs Nerv Syst.
2879 Kaygusuz I, Gok U, Yalcin S, et al. (2001). Bacteremia during tonsillectomy. Int J Pediatr Otorhinolaryngol.
2880 Kenny C. (2001). Infection control. CJD fears prompt cash for tonsil ops. Nurs Times.
2881 Keogh IJ, Hone SW, Colreavey M, et al. (2001). Blood splash and tonsillectomy: an underestimated hazard to the otolaryngologist. J Laryngol Otol.
2882 Kerbl R, Zotter H, Schenkeli R, et al. (2001). Persistent hypercapnia in children after treatment of obstructive sleep apnea syndrome by adenotonsillectomy. Wien Klin Wochenschr.
2883 Kerekhanjanarong V, Tang-On N, Supiyaphun P, et al. (2001). Tonsillar fossa steroid injection for reduction of the post-tonsillectomy pain. J Med Assoc Thai.
2884 Kerr TP, Duward A, Hodgson SV, et al. (2001). Hyperkalaemic cardiac arrest in a manifesting carrier of Duchenne muscular dystrophy following general anaesthesia. Eur J Pediatr.
2885 Khabie N, Savva A, Kasperbauer JL, et al. (2001). Epstein-Barr virus DNA is not increased in tonsillar carcinoma. Laryngoscope.
2886 Khan FA, Memon GA. (2001). Comparison of spontaneous with controlled mode of ventilation in tonsillectomy. Paediatr Anaesth.
2887 Kindo AJ, Somu L, Srikanth P, et al. (2001). Role of surface swab, core swab and fine needle aspiration in isolating the core bacteria in inflammed tonsils. Indian J Pathol Microbiol.
2888 Kirkham FJ, Hewes DK, Prengler M, et al. (2001). Nocturnal hypoxaemia and central-nervous-system events in sickle-cell disease. Lancet.
2889 Kishore A, Haider-Ali AM, Geddes NK. (2001). Patient eligibility for day case paediatric adenotonsillectomy. Clin Otolaryngol Allied Sci.
2890 Kitajiri S, Tabuchi K, Hiraumi H, et al. (2001). Relief of post-tonsillectomy pain by release of lidocaine from fibrin glue. Laryngoscope.
2891 Koch WM, Bhatti N, Williams MF, et al. (2001). Oncologic rationale for bilateral tonsillectomy in head and neck squamous cell carcinoma of unknown primary source. Otolaryngol Head Neck Surg.
2892 Kojima M, Nakamura S, Shuimizu K, et al. (2001). Marginal zone B cell lymphomas of Waldeyer's ring--a report of two tonsillectomy cases resembling histomorphological features of inflammatory lesions. Pathol Res Pract.
2893 Kokki H, Salonen A, Nikanne E. (2001). Perioperative intravenous ketoprofen neither prolongs operation time nor delays discharge after adenoidectomy in children. Paediatr Anaesth.
2894 Kolude B, Lawoyin JO, Akang EE. (2001). Salivary gland neoplasms: a 21year review of cases seen at University College Hospital, Ibadan. Afr J Med Med Sci.
2895 Kraitrakul S, Sirithunyaporn S, Yimtae K. (2001). Distribution of minor salivary glands in the peritonsillar space. J Med Assoc Thai.
2896 Krishna P, Lee D. (2001). Post-tonsillectomy bleeding: a meta-analysis. Laryngoscope.
2897 Kubba H, Bingham BJ. (2001). Endoscopy in the assessment of children with nasal obstruction. J Laryngol Otol.
2898 Kubba H, Bingham BJ. (2001). Can nasal endoscopy be used to predict residual symptoms after adenoidectomy for nasal obstruction?. Int J Pediatr Otorhinolaryngol.
2899 Leonard IE, Lacy PD, Moriarty DC, et al. (2001). Pulmonary embolism following tonsillectomy. J Laryngol Otol.
2900 Lesperance MM, Schneider B, Garetz SL, et al. (2001). Substituting a telephone call for pediatric adenotonsillectomy postoperative visits. Arch Otolaryngol Head Neck Surg.
2901 Letts M, Davidson D, Splinter W, et al. (2001). Analysis of the efficacy of pediatric day surgery. Can J Surg.
2902 Levy EI, Horowitz MB, Cahill AM. (2001). Lingual artery embolization for severe and uncontrollable postoperative tonsillar bleeding. Ear Nose Throat J.
2903 Li AM, Hui S, Wong E, et al. (2001). Obstructive sleep apnoea in children with adenotonsillar hypertrophy: prospective study. Hong Kong Med J.
2904 Litalien C, Jacqz-Aigrain E. (2001). Risks and benefits of nonsteroidal anti-inflammatory drugs in children: a comparison with paracetamol. Paediatr Drugs.
2905 Lopez Ramos D, Gabriel R, Cantero Perona J, et al. (2001). Association of MALTectomy (appendectomy and tonsillectomy) and inflammatory bowel disease: a familial case-control study. Rev Esp Enferm Dig.
2906 MacCallum PL, MacRae DL, Sukerman S, et al. (2001). Ambulatory adenotonsillectomy in children less than 5 years of age. J Otolaryngol.
2907 Macharia IM. (2001). Adenotonsillectomy. East Afr Med J.
2908 Mahendran S, Kumar M, Preece M. (2001). Post-tonsillectomy bleed: a delayed diagnosis of duodenal ulceration. J Laryngol Otol.
2909 Maheshwar AA, Jones MB, Evans RA. (2001). Efficacy and safety of 'hot' tonsillectomy. Int J Clin Pract.
2910 Mandell DL. (2001). Jazz and otolaryngology: the death of guitarist Eddie Lang. Laryngoscope.
2911 Mandell DL, Pearl AW, Rothschild MA. (2001). Influence of minor ear surgery on infrared tympanic thermometry. Arch Otolaryngol Head Neck Surg.
2912 Marcus CL. (2001). Nasal steroids as treatment for obstructive sleep apnea: Don't throw away the scalpel yet. J Pediatr.
2913 Martin F, Wilde A. (2001). Tonsillectomy--anaesthetic technique and the new disposable surgical equipment. Anaesthesia.
2914 Matar GM, Chahwan R, Fuleihan N, et al. (2001). PCR-based detection, restriction endonuclease analysis, and transcription of tonB in Haemophilus influenzae and Haemophilus parainfluenzae isolates obtained from children undergoing tonsillectomy and adenoidectomy. Clin Diagn Lab Immunol.
2915 Matsushima T, Inoue T, Inamura T, et al. (2001). Transcerebellomedullary fissure approach with special reference to methods of dissecting the fissure. J Neurosurg.
2916 Mattila PS, Tahkokallio O, Tarkkanen J, et al. (2001). Causes of tonsillar disease and frequency of tonsillectomy operations. Arch Otolaryngol Head Neck Surg.
2917 Matzdorff AC, White JG, Malzahn K, et al. (2001). Perioperative management of a patient with Fechtner syndrome. Ann Hematol.
2918 Meru N, Davison S, Whitehead L, et al. (2001). Epstein-Barr virus infection in paediatric liver transplant recipients: detection of the virus in post-transplant tonsillectomy specimens. Mol Pathol.
2919 Miman MC, Ozturan O, Durmus M, et al. (2001). Cervical subcutaneous emphysema: an unusual complication of adenotonsillectomy. Paediatr Anaesth.
2920 Misago N, Mochizuki Y, Sekiyama-Kodera H, et al. (2001). Cutaneous polyarteritis nodosa: therapy and clinical course in four cases. J Dermatol.
2921 Miziara ID, Koishi HU, Zonato AI, et al. (2001). The use of ultrasound evaluation in the diagnosis of peritonsillar abscess. Rev Laryngol Otol Rhinol (Bord).
2922 Morton S, Rosen C, Larkin E, et al. (2001). Predictors of sleep-disordered breathing in children with a history of tonsillectomy and/or adenoidectomy. Sleep.
2923 Mukherjee K, Esuvaranathan V, Streets C, et al. (2001). Adenotonsillectomy in children: a comparison of morphine and fentanyl for peri-operative analgesia. Anaesthesia.
2924 Munch EC, Bauhuf C, Horn P, et al. (2001). Therapy of malignant intracranial hypertension by controlled lumbar cerebrospinal fluid drainage. Crit Care Med.
2925 Murtagh RD, Caracciolo JT, Fernandez G. (2001). CT findings associated with Eagle syndrome. AJNR Am J Neuroradiol.
2926 Musiatowicz M, Wysocka J, Kasprzycka E, et al. (2001). Lymphocyte subpopulations in hypertrophied adenoid in children. Int J Pediatr Otorhinolaryngol.
2927 Naganuma M, Iizuka B, Torii A, et al. (2001). Appendectomy protects against the development of ulcerative colitis and reduces its recurrence: results of a multicenter case-controlled study in Japan. Am J Gastroenterol.
2928 Nalesnik MA. (2001). Posttransplant lymphoproliferative disorder and tonsillectomy in a pediatric liver transplant population. Liver Transpl.
2929 Nave H, Gebert A, Pabst R. (2001). Morphology and immunology of the human palatine tonsil. Anat Embryol (Berl).
2930 Ng DK, Chau KW, Kwok KL. (2001). Nocturnal enuresis and obstructive sleep apnoea in two children. Singapore Med J.
2931 Nieder C, Gregoire V, Ang KK. (2001). Cervical lymph node metastases from occult squamous cell carcinoma: cut down a tree to get an apple?. Int J Radiat Oncol Biol Phys.
2932 Nishizawa S, Yokoyama T, Yokota N, et al. (2001). Incidentally identified syringomyelia associated with Chiari I malformations: is early interventional surgery necessary?. Neurosurgery.
2933 Nix PA. (2001). Jugular thrombosis following tonsillectomy. J Laryngol Otol.
2934 Normann E, Gnarpe J, Naas J, et al. (2001). Chlamydia pneumoniae in children undergoing adenoidectomy. Acta Paediatr.
2935 Noronha BE, Panda NK, Mann SB, et al. (2001). Incidence of pharyngeal hypophysis in neonates a histologic study. Ann Otol Rhinol Laryngol.
2936 Norrby SR, Rabie WJ, Bacart P, et al. (2001). Efficacy of short-course therapy with the ketolide telithromycin compared with 10 days of penicillin V for the treatment of pharyngitis/tonsillitis. Scand J Infect Dis.
2937 Oburra HO, Idenya M. (2001). Frequency of adenotonsillectomy in some Nairobi hospitals. East Afr Med J.
2938 Ohlms LA. (2001). Injection of local anesthetic in tonsillectomy. Arch Otolaryngol Head Neck Surg.
2939 Olarinde O, Choa DI. (2001). Cannula aspiration of peritonsillar abscesses. Otolaryngol Head Neck Surg.
2940 O'Mara W, Butler NN, Nemechek AJ. (2001). Carcinomas of unknown primary in the head and neck. J La State Med Soc.
2941 Opatowsky MJ, Browne JD, McGuirt Jr WF, et al. (2001). Endovascular treatment of hemorrhage after tonsillectomy in children. AJNR Am J Neuroradiol.
2942 Orntoft I, Bonding P. (2001). Ectopic adenoid tissue in the choanae. J Laryngol Otol.
2943 Orvidas LJ, Slattery MJ. (2001). Pediatric autoimmune neuropsychiatric disorders and streptococcal infections: role of otolaryngologist. Laryngoscope.
2944 Owen CM, Chalmers RJ, O'Sullivan T, et al. (2001). A systematic review of antistreptococcal interventions for guttate and chronic plaque psoriasis. Br J Dermatol.
2945 Ozer Kocak Z, Altunkan AA, Atici S, et al. (2001). Comparison of remifentanil-propofol and sevoflurane for preventing cardiovascular response and quality of recovery in paediatric otolaryngologic surgery. Turkish Journal of Medical Sciences.
2946 Pandey A, Robinson S, Cohen AR. (2001). Cerebellar fits in children with Chiari I malformation. Neurosurg Focus.
2947 Parikh-Patel A, Gold EB, Worman H, et al. (2001). Risk factors for primary biliary cirrhosis in a cohort of patients from the united states. Hepatology.
2948 Peeters A, Claes J, Saldien V. (2001). Lethal complications after tonsillectomy. Acta Otorhinolaryngol Belg.
2949 Perrin JM. (2001). Should we operate on children with fluid in the middle ear?. N Engl J Med.
2950 Pignataro L, Grillo Della Berta L, Capaccio P, et al. (2001). Myringoplasty in children: anatomical and functional results. J Laryngol Otol.
2951 Pizzi NJ. (2001). Bleeding predisposition assessments in tonsillectomy/adenoidectomy patients using fuzzy interquartile encoded neural networks. Artif Intell Med.
2952 Pless-Mulloli T, Howel D, Prince H. (2001). Prevalence of asthma and other respiratory symptoms in children living near and away from opencast coal mining sites. Int J Epidemiol.
2953 Rajkumar S, Krishnamurthy R. (2001). Isolation of group A beta-hemolytic streptococci in the tonsillopharynx of school children in Madras City and correlation with their clinical features. Jpn J Infect Dis.
2954 Ralph WM, Huh SK, Kim H. (2001). Phenytoin-induced lingual tonsil hyperplasia causing laryngeal obstruction. Ann Otol Rhinol Laryngol.
2955 Rangheard AS, Vanel D, Viala J, et al. (2001). Synovial sarcomas of the head and neck: CT and MR imaging findings of eight patients. AJNR Am J Neuroradiol.
2956 Raut V, Bhat N, Kinsella J, et al. (2001). Bipolar scissors versus cold dissection tonsillectomy: a prospective, randomized, multi-unit study. Laryngoscope.
2957 Reber A, Bobbia SA, Hammer J, et al. (2001). Effect of airway opening manoeuvres on thoraco-abdominal asynchrony in anaesthetized children. Eur Respir J.
2958 Reber A, Paganoni R, Frei FJ. (2001). Effect of common airway manoeuvres on upper airway dimensions and clinical signs in anaesthetized, spontaneously breathing children. Br J Anaesth.
2959 Reif S, Lavy A, Keter D, et al. (2001). Appendectomy is more frequent but not a risk factor in Crohn's disease while being protective in ulcerative colitis: a comparison of surgical procedures in inflammatory bowel disease. Am J Gastroenterol.
2960 Reis-Filho JS, Milanezi F, Silva P, et al. (2001). Maspin expression in myoepithelial tumors of the breast. Pathol Res Pract.
2961 Safak MA, Haberal I, Kilic D, et al. (2001). Necrotizing fasciitis secondary to peritonsillar abscess: a new case and review of eight earlier cases. Ear Nose Throat J.
2962 Saikia B, Dey P, Saikia UN, et al. (2001). Fine needle aspiration cytology of metastatic scalp nodules. Acta Cytol.
2963 Salonen A, Kokki H, Tuovinen K. (2001). I.v. ketoprofen for analgesia after tonsillectomy: comparison of pre- and post-operative administration. Br J Anaesth.
2964 Satoh M, Yokoya S, Hachiya Y, et al. (2001). Two hyperandrogenic adolescent girls with congenital portosystemic shunt. Eur J Pediatr.
2965 Schmidt A, Björkman S, Akeson J. (2001). Preoperative rectal diclofenac versus paracetamol for tonsillectomy: effects on pain and blood loss. Acta anaesthesiologica Scandinavica.
2966 Schraff S, McGinn JD, Derkay CS. (2001). Peritonsillar abscess in children: a 10-year review of diagnosis and management. Int J Pediatr Otorhinolaryngol.
2967 Schramm VL, Imola MJ. (2001). Management of nasopharyngeal salivary gland malignancy. Laryngoscope.
2968 Sclafani AP, Jacono AA, Dolitsky JN. (2001). Grafting of the peritonsillar fossa with an acellular dermal graft to reduce posttonsillectomy pain. Am J Otolaryngol.
2969 Shah C, Shahab R, Robb P, et al. (2001). Role of a home care team in paediatric day-case tonsillectomy. J Laryngol Otol.
2970 Shamboul K, Yousif YM. (2001). Tonsillectomy and adenotonsillectomy in Sudanese patients. East Afr Med J.
2971 Shapiro NL, Strocker AM. (2001). Adenotonsillar hypertrophy and Epstein-Barr virus in pediatric organ transplant recipients. Laryngoscope.
2972 Sharif M, Zaman J, Yousaf N, et al. (2001). Diathermy tonsillectomy versus conventional dissection tonsillectomy. Journal of Postgraduate Medical Institute.
2973 Sharma M, Naqvi A, Maollod L, et al. (2001). Meningococcemia following tonsillectomy. Scand J Infect Dis.
2974 Shott SR. (2001). Tonsillectomy and postoperative vomiting: Do steroids really work?. Arch Otolaryngol Head Neck Surg.
2975 Simoni P, Bello JA, Kent B. (2001). Pseudoaneurysm of the lingual artery secondary to tonsillectomy treated with selective embolization. Int J Pediatr Otorhinolaryngol.
2976 Skadiang K. (2001). Researching post-tonsillectomy bleeding. Nurs N Z.
2977 Skinner LJ, Winter DC, Curran AJ, et al. (2001). Helicobacter pylori and tonsillectomy. Clin Otolaryngol Allied Sci.
2978 Sonne JE, Kim SB, Frank DK. (2001). Cervical necrotizing fasciitis as a complication of tonsillectomy. Otolaryngol Head Neck Surg.
2979 Sood S, Corbridge R, Powles J, et al. (2001). Effectiveness of the ultrasonic harmonic scalpel for tonsillectomy. Ear Nose Throat J.
2980 Splinter WM. (2001). Prevention of vomiting after strabismus surgery in children: dexamethasone alone versus dexamethasone plus low-dose ondansetron. Paediatr Anaesth.
2981 Stenfors LE, Bye HM, Raisanen S. (2001). Bacterial coating with immunoglobulins on the palatine tonsils during infectious mononucleosis: immunocytochemical study with gold markers. J Laryngol Otol.
2982 Stenfors LE, Bye HM, Vorland LH. (2001). Remarkable attachment of lactoferrin to Streptococcus pyogenes during acute pharyngotonsillitis. Acta Otolaryngol.
2983 Steward DL, Welge JA, Myer CM. (2001). Do steroids reduce morbidity of tonsillectomy? Meta-analysis of randomized trials. Laryngoscope.
2984 Stewart MG, Friedman EM, Sulek M, et al. (2001). Validation of an outcomes instrument for tonsil and adenoid disease. Arch Otolaryngol Head Neck Surg.
2985 Strong EB, Rubinstein B, Senders CW. (2001). Pathologic analysis of routine tonsillectomy and adenoidectomy specimens. Otolaryngol Head Neck Surg.
2986 Tawalbeh MI, Nawasreh OO, Husban AM. (2001). Comparative study of diclofenac sodium and paracetamol for treatment of pain after adenotonsillectomy in children. Saudi Med J.
2987 Tosca MA, Riccio AM, Marseglia GL, et al. (2001). Nasal endoscopy in asthmatic children: assessment of rhinosinusitis and adenoiditis incidence, correlations with cytology and microbiology. Clin Exp Allergy.
2988 Unver S, Kubilay U, Sezen OS, et al. (2001). Investigation of Helicobacter pylori colonization in adenotonsillectomy specimens by means of the CLO test. Laryngoscope.
2989 Uong EC, McDonough JM, Tayag-Kier CE, et al. (2001). Magnetic resonance imaging of the upper airway in children with Down syndrome. Am J Respir Crit Care Med.
2990 Uygur-Bayramicli O, Kilic D, Yavuzer D, et al. (2001). Helicobacter pylori colonization and immunological disease. Eur J Gastroenterol Hepatol.
2991 Verghese ST, Hannallah RS. (2001). Pediatric otolaryngologic emergencies. Anesthesiol Clin North America.
2992 Vickers G, Anders N, Flanagan P. (2001). Boyle-Davis gags for tonsillectomy. Paediatr Anaesth.
2993 Viitanen H, Annila P. (2001). Analgesic efficacy of tramadol 2 mg kg(-1) for paediatric day-case adenoidectomy. Br J Anaesth.
2994 Wald ER. (2001). Antibiotic treatment of pharyngitis. Pediatr Rev.
2995 Walker P. (2001). Pediatric adenoidectomy under vision using suction-diathermy ablation. Laryngoscope.
2996 Weber A, Schmoz S, Bootz F. (2001). CUP (carcinoma of unknown primary) syndrome in head and neck: clinic, diagnostic, and therapy. Onkologie.
2997 Weber P, Filipecki J, Bingen E, et al. (2001). Genetic and phenotypic characterization of macrolide resistance in group A streptococci isolated from adults with pharyngo-tonsillitis in France. J Antimicrob Chemother.
2998 Weber R, Hegenbarth V, Kaftan H, et al. (2001). Nasopharyngeal endoscopy adds to reliability of clinical diagnosis of infectious mononucleosis. J Laryngol Otol.
2999 Weksler N, Nash M, Rozentsveig V, et al. (2001). Vocal cord paralysis as a consequence of peritonsillar infiltration with bupivacaine. Acta Anaesthesiol Scand.
3000 Williams NP, Boyd DL, Choy L, et al. (2001). Salivary gland lesions: a Jamaican perspective. West Indian Med J.
3001 Williamson RA, Huang RY, Shapiro NL. (2001). Adenotonsillar histopathology after organ transplantation. Otolaryngol Head Neck Surg.
3002 Wilson JT, Murray A, MacKenzie K. (2001). Prospective study of morbidity after tonsillectomy in children. Int J Pediatr Otorhinolaryngol.
3003 Windfuhr J, Seehafer M. (2001). Classification of haemorrhage following tonsillectomy. J Laryngol Otol.
3004 Windfuhr JP, Chen YS. (2001). Immediate abscess tonsillectomy--a safe procedure?. Auris Nasus Larynx.
3005 Windfuhr JP, Ulbrich T. (2001). Post-tonsillectomy hemorrhage: results of a 3-month follow-up. Ear Nose Throat J.
3006 Wyatt RJ, Hogg RJ. (2001). Evidence-based assessment of treatment options for children with IgA nephropathies. Pediatr Nephrol.
3007 Yamanaka N, Yamamoto Y, Kuki K. (2001). Engraftment of tonsillar mononuclear cells in human skin/SCID mouse chimera--validation of a novel xenogeneic transplantation model for autoimmune diseases. Microbiol Immunol.
3008 Yasui Y, Potter JD, Stanford JL, et al. (2001). Breast cancer risk and “delayed” primary Epstein-Barr virus infection. Cancer Epidemiol Biomarkers Prev.
3009 Yata R, Motegi E, Ueda K, et al. (2001). A lip seal study of Japanese children with malocclusion. Bull Tokyo Dent Coll.
3010 Yeh H, Matanoski GM, Wang N, et al. (2001). Cancer incidence after childhood nasopharyngeal radium irradiation: a follow-up study in Washington County, Maryland. Am J Epidemiol.
3011 Younis RT, Hesse SV, Anand VK. (2001). Evaluation of the utility and cost-effectiveness of obtaining histopathologic diagnosis on all routine tonsillectomy specimens. Laryngoscope.
3012 Zakirullah. (2001). Post-tonsillectomy and adenotonsillectomy morbidity & complications at District Headquarter Hospital Daggar. J Ayub Med Coll Abbottabad.
3013 Zatman TF, Hall JE, Harmer M. (2001). Gastric residual volume in children: a study comparing efficiency of erythromycin and metoclopramide as prokinetic agents. Br J Anaesth.
3014 Zinder DJ. (2001). The tumble of medical advancement: a call for knowledge management. Arch Otolaryngol Head Neck Surg.
3015 (2002). Clinical practice guideline: diagnosis and management of childhood obstructive sleep apnea syndrome. Pediatrics.
3016 Abdul-Baqi KJ, Shakhatreh FM. (2002). Effectiveness of treatment of tonsillopharyngitis: comparative study. J Laryngol Otol.
3017 Ajello M, Greco R, Giansanti F, et al. (2002). Anti-invasive activity of bovine lactoferrin towards group A streptococci. Biochem Cell Biol.
3018 Al-Kindy SA. (2002). Do antibiotics decrease post-tonsillectomy morbidity?. Saudi Med J.
3019 Anand S, Gupta M, Singh B. (2002). An unusual cause of acute airway obstruction. Journal of Anaesthesiology Clinical Pharmacology.
3020 Andre M, Odenholt I, Schwan A, et al. (2002). Upper respiratory tract infections in general practice: diagnosis, antibiotic prescribing, duration of symptoms and use of diagnostic tests. Scand J Infect Dis.
3021 Arens R, McDonough JM, Corbin AM, et al. (2002). Linear dimensions of the upper airway structure during development: assessment by magnetic resonance imaging. Am J Respir Crit Care Med.
3022 Barkhudaryan N, Gambarov S, Gyulbayazyan T, et al. (2002). LVV-hemorphin-4 modulates Ca2+/calmodulin-dependent pathways in the immune system by the same mechanism as in the brain. J Mol Neurosci.
3023 Baschiera F, Fornai M, Lazzeri G, et al. (2002). Improved tonsillar disposition of azithromycin following a 3-day oral treatment with 20 mg kg(-1) in paediatric patients. Pharmacol Res.
3024 Bassili A, Barakat S, Sawaf GE, et al. (2002). Identification of clinical criteria for group A-beta hemolytic streptococcal pharyngitis in children living in a rheumatic fever endemic area. J Trop Pediatr.
3025 Behrman A, Shikowitz MJ, Dailey S. (2002). The effect of upper airway surgery on voice. Otolaryngol Head Neck Surg.
3026 Berkovitch M, Bulkowstein M, Zhovtis D, et al. (2002). Colonization rate of bacteria in the throat of healthy infants. Int J Pediatr Otorhinolaryngol.
3027 Berlucchi M, Tomenzoli D, Nicolai P, et al. (2002). Adenotonsillectomy in children with von Willebrand's disease: how and when. A case report with review of the literature. Int J Pediatr Otorhinolaryngol.
3028 Bernstein JM, Faden HS, Scannapieco F, et al. (2002). Interference of nontypeable Haemophilus influenzae and Moraxella catarrhalis by Streptococcus oralis in adenoid organ culture: a possible strategy for the treatment of the otitis-prone child. Ann Otol Rhinol Laryngol.
3029 Bhattacharyya N, Kepnes LJ. (2002). Economic benefit of tonsillectomy in adults with chronic tonsillitis. Ann Otol Rhinol Laryngol.
3030 Bildirici K, Cakli H, Kecik C, et al. (2002). Schwannoma (neurilemmoma) of the palatine tonsil. Otolaryngol Head Neck Surg.
3031 Bingham B. (2002). New variant CJD-BSE (mad cow disease). The need for disposable ENT instruments. Int J Pediatr Otorhinolaryngol.
3032 Black N, Hutchings A. (2002). Effectiveness of guidelines on persistent glue ear in children. Authors' estimates of size of impact are probably excessive. Bmj.
3033 Blandizzi C, Malizia T, Batoni G, et al. (2002). Distribution of azithromycin in plasma and tonsil tissue after repeated oral administration of 10 or 20 milligrams per kilogram in pediatric patients. Antimicrob Agents Chemother.
3034 Boccazzi A, Noviello S, Tonelli P, et al. (2002). The decision-making process in antibacterial treatment of pediatric upper respiratory infections: a national prospective office-based observational study. Int J Infect Dis.
3035 Bolton P, Bridge HS, Montgomery CJ, et al. (2002). The analgesic efficacy of preoperative high dose (40 mg x kg(-1)) oral acetaminophen after bilateral myringotomy and tube insertion in children. Paediatr Anaesth.
3036 Bowling DM. (2002). Argon beam coagulation for post-tonsillectomy hemostasis. Otolaryngol Head Neck Surg.
3037 Brokstad KA, Eriksson JC, Cox RJ, et al. (2002). Parenteral vaccination against influenza does not induce a local antigen-specific immune response in the nasal mucosa. J Infect Dis.
3038 Brownell M. (2002). Tonsillectomy rates for Manitoba children: temporal and spatial variations. Healthc Manage Forum.
3039 Cantor WL. (2002). Radiofrequency tonsil reduction. Arch Otolaryngol Head Neck Surg.
3040 Carlander D, Kollberg H, Larsson A. (2002). Retention of specific yolk IgY in the human oral cavity. BioDrugs.
3041 Chan LC, Lam TH, Li CK, et al. (2002). Is the timing of exposure to infection a major determinant of acute lymphoblastic leukaemia in Hong Kong?. Paediatr Perinat Epidemiol.
3042 Chiang S, Vu MC, Nguyen M, et al. (2002). Adenotonsillar enlargement in pediatric organ transplant recipients: a cross-sectional analysis. Otolaryngol Head Neck Surg.
3043 Childers NK, Tong G, Li F, et al. (2002). Humans immunized with Streptococcus mutans antigens by mucosal routes. J Dent Res.
3044 Chmielik M, Bielicka A, Brozek E. (2002). Tonsil operations in children - Indications and contradictions. New Medicine.
3045 Church JJ. (2002). Is postoperative nausea and vomiting following tonsillectomy really a problem?. Anaesthesia.
3046 Ciftci E, Dogru U, Guriz H, et al. (2002). Investigation of risk factors for tonsillopharyngitis with macrolide resistant Streptococcus pyogenes in Turkish children. Pediatr Int.
3047 Cohen IT, Drewsen S, Hannallah RS. (2002). Propofol or midazolam do not reduce the incidence of emergence agitation associated with desflurane anaesthesia in children undergoing adenotonsillectomy. Paediatr Anaesth.
3048 Cohen IT, Finkel JC, Hannallah RS, et al. (2002). The effect of fentanyl on the emergence characteristics after desflurane or sevoflurane anesthesia in children. Anesth Analg.
3049 Cohen R, Reinert P, De La Rocque F, et al. (2002). Comparison of two dosages of azithromycin for three days versus penicillin V for ten days in acute group A streptococcal tonsillopharyngitis. Pediatr Infect Dis J.
3050 Cohn AI. (2002). Acupuncture for postoperative nausea and vomiting prophylaxis: where's the point?. Anesthesiology.
3051 Conache ID, Meikle D, O'Brien C. (2002). Tracheostomy, lingular tonsillectomy and sleep-related breathing disorders. Br J Anaesth.
3052 Conley ME, Howard V. (2002). Clinical findings leading to the diagnosis of X-linked agammaglobulinemia. J Pediatr.
3053 Cook TM, McCormick B, Twigg S. (2002). Re-useable and sheathed laryngoscope blades. Anaesthesia.
3054 Cultrara A, Bennett GH, Lazar C, et al. (2002). Preoperative sedation in pediatric patients with sleep-disordered breathing. Int J Pediatr Otorhinolaryngol.
3055 Daghistani KJ. (2002). Tonsillectomy in Saudi Arabia. Bahrain Medical Bulletin.
3056 Darrow DH, Siemens C. (2002). Indications for tonsillectomy and adenoidectomy. Laryngoscope.
3057 De Serres LM, Derkay C, Sie K, et al. (2002). Impact of adenotonsillectomy on quality of life in children with obstructive sleep disorders. Arch Otolaryngol Head Neck Surg.
3058 Debska M, Bielicka A, Chmielik M. (2002). Ventilating tube insertion in the treatment of otitis media with effusion in children. New Medicine.
3059 Derkay CS, Maddern BR. (2002). Innovative techniques for adenotonsillar surgery in children: introduction and commentary. Laryngoscope.
3060 DeRosa J, Grundfast KM. (2002). Surgical management of otitis media. Pediatr Ann.
3061 Dhooge IJ, van Kempen MJ, Sanders LA, et al. (2002). Deficient IgA and IgG2 anti-pneumococcal antibody levels and response to vaccination in otitis prone children. Int J Pediatr Otorhinolaryngol.
3062 Donnelly LF, Casper KA, Chen B. (2002). Correlation on cine MR imaging of size of adenoid and palatine tonsils with degree of upper airway motion in asymptomatic sedated children. AJR Am J Roentgenol.
3063 Donner-Banzhoff N, Beck C, Meyer F, et al. (2002). Clinical findings in patients presenting with sore throat. A study on inter-observer reliability. Fam Pract.
3064 Dutta NN, Bordoloi BM. (2002). Tonsillectomy using harmonic scalpel. Indian J Otolaryngol Head Neck Surg.
3065 Ebenfelt A. (2002). Neutrophils are hyperactive in recurrent tonsillitis. Acta Otolaryngol.
3066 Elluru RG, Johnson L, Myer CM. (2002). Electrocautery adenoidectomy compared with curettage and power-assisted methods. Laryngoscope.
3067 Endo LH, Vassallo J, Sakano E, et al. (2002). Detection of Epstein-Barr virus and subsets of lymphoid cells in adenoid tissue of children under 2 years of age. Int J Pediatr Otorhinolaryngol.
3068 Enosawa S, Suzuki S, Amemiya H, et al. (2002). Establishment of public human tissue resource bank for research purposes with surgically removed tonsil tissue: potential scientific value and ethical problem. Transplant Proc.
3069 Erkilic S, Aydin A, Kocer NE. (2002). Histological features in routine tonsillectomy specimens: the presence and the proportion of mesenchymal tissues and seromucinous glands. J Laryngol Otol.
3070 Farstad IN, Malavasi F, Haraldsen G, et al. (2002). CD38 is a marker of human lacteals. Virchows Arch.
3071 Finkelstein Y, Wexler DB, Nachmani A, et al. (2002). Endoscopic partial adenoidectomy for children with submucous cleft palate. Cleft Palate Craniofac J.
3072 Ford-Jones EL, Friedberg J, McGeer A, et al. (2002). Microbiologic findings and risk factors for antimicrobial resistance at myringotomy for tympanostomy tube placement--a prospective study of 601 children in Toronto. Int J Pediatr Otorhinolaryngol.
3073 Freeman KO, Connelly NR, Schwartz D, et al. (2002). Analgesia for paediatric tonsillectomy and adenoidectomy with intramuscular clonidine. Paediatr Anaesth.
3074 Galanakis E, Papadakis CE, Giannoussi E, et al. (2002). PFAPA syndrome in children evaluated for tonsillectomy. Arch Dis Child.
3075 Garnett CT, Erdman D, Xu W, et al. (2002). Prevalence and quantitation of species C adenovirus DNA in human mucosal lymphocytes. J Virol.
3076 Georgalas C, Kanagalingam J, Zainal A, et al. (2002). The association between periodontal disease and peritonsillar infection: a prospective study. Otolaryngol Head Neck Surg.
3077 Geraghty JA. (2002). Post-tonsillectomy hemorrhage. Ear Nose Throat J.
3078 Gerber N, Apseloff G. (2002). Fatality after an injection of Bicillin into the tonsillar fossa during an adenotonsillectomy. Otolaryngol Head Neck Surg.
3079 Goldstein NA, Fatima M, Campbell TF, et al. (2002). Child behavior and quality of life before and after tonsillectomy and adenoidectomy. Arch Otolaryngol Head Neck Surg.
3080 Greiner O, Berger C, Day PJ, et al. (2002). Rates of detection of Neisseria meningitidis in tonsils differ in relation to local incidence of invasive disease. J Clin Microbiol.
3081 Gupta AK, Gupta S, Meena DS, et al. (2002). Post - Tonsillectomy pain: Different modes of pain relief. Indian Journal of Otolaryngology and Head and Neck Surgery.
3082 Haas I, Hoffmann TK, Engers R, et al. (2002). Diagnostic strategies in cervical carcinoma of an unknown primary (CUP). Eur Arch Otorhinolaryngol.
3083 Hamers JP, Abu-Saad HH. (2002). Children's pain at home following (adeno) tonsillectomy. Eur J Pain.
3084 Han W, Zao HL, Wang F. (2002). Propofol used for tonsillectomy and adnoid rectomy in comparison with (gamma)-hydroxybutyrate sodium. Journal of Jilin University (Medical Science).
3085 Harbo G, Bundgaard T, Pedersen D, et al. (2002). Prognostic indicators for malignant tumours of the parotid gland. Clin Otolaryngol Allied Sci.
3086 Harley EH. (2002). Asymmetric tonsil size in children. Arch Otolaryngol Head Neck Surg.
3087 Harris C. (2002). Childhood ENT disorders. When to refer to specialists. Aust Fam Physician.
3088 Hartrick CT, Kovan JP. (2002). Pain assessment following general anesthesia using the Toddler Preschooler Postoperative Pain Scale: a comparative study. J Clin Anesth.
3089 Havas T, Lowinger D. (2002). Obstructive adenoid tissue: an indication for powered-shaver adenoidectomy. Arch Otolaryngol Head Neck Surg.
3090 Helling K, Scherer H. (2002). Laser-tonsillotomy in infantile tonsillar hyperplasia. Medical Laser Application.
3091 Hidaka H, Nakamura N, Asano S, et al. (2002). A case of lymphoepithelioma-like carcinoma arising from the palatine tonsil. Tohoku J Exp Med.
3092 Homer JJ, Frewer JD, Swallow J, et al. (2002). An audit of post-operative analgesia in children following tonsillectomy. J Laryngol Otol.
3093 Hotta O, Furuta T, Chiba S, et al. (2002). Regression of IgA nephropathy: a repeat biopsy study. Am J Kidney Dis.
3094 Howel D, Webster S, Hayes J, et al. (2002). The impact of recurrent throat infection on children and their families. Fam Pract.
3095 Howell TK, Smith S, Rushman SC, et al. (2002). A comparison of oral transmucosal fentanyl and oral midazolam for premedication in children. Anaesthesia.
3096 Hung T, Moore-Gillon V, Hern J, et al. (2002). Topical bupivacaine in paediatric day-case tonsillectomy: a prospective randomized controlled trial. J Laryngol Otol.
3097 Huth MM. (2002). Imagery to reduce children's postoperative pain. Case Western Reserve University (Health Sciences).
3098 Ikinciogullari A, Dogu F, ikinciogullari A, et al. (2002). Is immune system influenced by adenotonsillectomy in children?. Int J Pediatr Otorhinolaryngol.
3099 Ilk HG, Erogul O, Satar B, et al. (2002). Effects of tonsillectomy on speech spectrum. J Voice.
3100 Indrasingh I, Chandi G, Vettivel S. (2002). Route of lymphocyte migration through the high endothelial venule (HEV) in human palatine tonsil. Ann Anat.
3101 Irving JA, Cameron BR, Ludemann JP, et al. (2002). Florid infectious mononucleosis: clinicopathological correlation in acute tonsillectomy. Int J Pediatr Otorhinolaryngol.
3102 Issioui T, Klein KW, White PF, et al. (2002). The efficacy of premedication with celecoxib and acetaminophen in preventing pain after otolaryngologic surgery. Anesth Analg.
3103 Ivarsson M, Lundin BS, Lundberg C. (2002). Activated T cells in the surface secretion on the adenoid--a flow cytometric study. Scand J Immunol.
3104 Jain A, Sahni JK. (2002). Polysomnographic studies in children undergoing adenoidectomy and/or tonsillectomy. J Laryngol Otol.
3105 James HE, Brant A. (2002). Treatment of the Chiari malformation with bone decompression without durotomy in children and young adults. Childs Nerv Syst.
3106 Jimenez-Yuste V, Prim MP, De Diego JI, et al. (2002). Otolaryngologic surgery in children with von Willebrand disease. Arch Otolaryngol Head Neck Surg.
3107 Johnson A. (2002). Tonsillectomy and variant Creutzfeldt-Jakob disease. Hosp Med.
3108 Johnson LB, Elluru RG, Myer CM. (2002). Complications of adenotonsillectomy. Laryngoscope.
3109 Johnson PA, Chavanu KE, Newman KD. (2002). Guiding practice improvements in pediatric surgery using multidisciplinary clinical pathways. Semin Pediatr Surg.
3110 Kara CO, Ergin H, Kocak G, et al. (2002). Prevalence of tonsillar hypertrophy and associated oropharyngeal symptoms in primary school children in Denizli, Turkey. Int J Pediatr Otorhinolaryngol.
3111 Karlidag T, Demirdag K, Kaygusuz I, et al. (2002). Resistant bacteria in the adenoid tissues of children with otitis media with effusion. Int J Pediatr Otorhinolaryngol.
3112 Katz TS, Mendenhall WM, Morris CG, et al. (2002). Malignant tumors of the nasal cavity and paranasal sinuses. Head Neck.
3113 Kawashima S. (2002). Sex-dependent differences in the craniofacial morphology of children with a sleep-related breathing disorder. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
3114 Kawashima S, Peltomaki T, Sakata H, et al. (2002). Craniofacial morphology in preschool children with sleep-related breathing disorder and hypertrophy of tonsils. Acta Paediatr.
3115 Kerschner JE, Lynch JB, Kleiner H, et al. (2002). Uvulopalatopharyngoplasty with tonsillectomy and adenoidectomy as a treatment for obstructive sleep apnea in neurologically impaired children. Int J Pediatr Otorhinolaryngol.
3116 Khan MF, Iqbal J, Raza N, Amjad M. (2002). Diode laser tonsillectomy a comparison with conventional technique. Pakistan Journal of Otolaryngology, Head and Neck Surgery.
3117 Kikuchi M, Higurashi N, Miyazaki S, et al. (2002). Facial pattern categories of sleep breathing-disordered children using Ricketts analysis. Psychiatry Clin Neurosci.
3118 Knipping S, Passmann M, Schrom T, et al. (2002). Abscess tonsillectomy for acute peritonsillar abscess. Rev Laryngol Otol Rhinol (Bord).
3119 Koempel JA. (2002). On the origin of tonsillectomy and the dissection method. Laryngoscope.
3120 Kohyama J, Hasegawa T. (2002). Subcortical arousal response in child patients with obstructive sleep apnea. Sleep Med.
3121 Koltai PJ, Chan J, Younes A. (2002). Power-assisted adenoidectomy: total and partial resection. Laryngoscope.
3122 Koltai PJ, Solares CA, Mascha EJ, et al. (2002). Intracapsular partial tonsillectomy for tonsillar hypertrophy in children. Laryngoscope.
3123 Kountakis SE. (2002). Effectiveness of perioperative bupivacaine infiltration in tonsillectomy patients. Am J Otolaryngol.
3124 Kurina LM, Goldacre MJ, Yeates D, et al. (2002). Appendicectomy, tonsillectomy, and inflammatory bowel disease: a case-control record linkage study. J Epidemiol Community Health.
3125 Kvaerner KJ, Nafstad P, Jaakkola JJ. (2002). Otolaryngological surgery and upper respiratory tract infections in children: an epidemiological study. Ann Otol Rhinol Laryngol.
3126 Lajtman Z, Surina B, Bartolek D, et al. (2002). “Warning card” as a prevention of prolonged apnea in children. Coll Antropol.
3127 Lalwani K. (2002). Is it safe to artificially ventilate a paralysed patient through a laryngeal mask?. Br J Anaesth.
3128 Lazareff JA, Galarza M, Gravori T, et al. (2002). Tonsillectomy without craniectomy for the management of infantile Chiari I malformation. J Neurosurg.
3129 Lee KC, Altenau MM, Barnes DR, et al. (2002). Incidence of complications for subtotal ionized field ablation of the tonsils. Otolaryngol Head Neck Surg.
3130 Lepcha A, Kurien M, Job A, et al. (2002). Chronic adenoid hypertrophy in children - is steroid nasal spray beneficial?. Indian J Otolaryngol Head Neck Surg.
3131 Li AM, Wong E, Kew J, et al. (2002). Use of tonsil size in the evaluation of obstructive sleep apnoea. Arch Dis Child.
3132 Li CS, Taylor JM. (2002). A semi-parametric accelerated failure time cure model. Stat Med.
3133 Liew L, Daudia A, Narula AA. (2002). Synchronous fat plug myringoplasty and tympanostomy tube removal in the management of refractory otorrhoea in younger patients. Int J Pediatr Otorhinolaryngol.
3134 Little P, Watson L, Morgan S, et al. (2002). Antibiotic prescribing and admissions with major suppurative complications of respiratory tract infections: a data linkage study. Br J Gen Pract.
3135 Lowe D, Hoare T. (2002). Dangerous Doughty--a quantitative study of disproportion between the size of endotracheal tubes and splits in tonsillectomy gag blades. J Laryngol Otol.
3136 Maciejewski A, Szymczyk C, Wierzgon J. (2002). Outcome of surgery for adenoid cystic carcinoma of head and neck region. J Craniomaxillofac Surg.
3137 Maddern BR. (2002). Electrosurgery for tonsillectomy. Laryngoscope.
3138 Maini S, Osborne JE, Fadl HM, et al. (2002). Temporomandibular joint dysfunction following tonsillectomy. Clin Otolaryngol Allied Sci.
3139 Maini S, Waine E, Evans K. (2002). Increased post-tonsillectomy secondary haemorrhage with disposable instruments: an audit cycle. Clin Otolaryngol Allied Sci.
3140 Malik V, Tyagi I, Varma A, et al. (2002). Use of the direct puncture technique in management of capillaro-venousmalformations: Case report. BMC Ear, Nose and Throat Disorders.
3141 Marshall T. (2002). Effectiveness of tonsillectomy? A reply to Howel et al. Fam Pract.
3142 Mason PS, Adam E, Prior M, et al. (2002). Effect of bacterial endotoxin and middle ear effusion on ciliary activity: implications for otitis media. Laryngoscope.
3143 Massa F, Gonsalez S, Laverty A, et al. (2002). The use of nasal continuous positive airway pressure to treat obstructive sleep apnoea. Arch Dis Child.
3144 Matar GM, Chahwan R, Fuleihan N, et al. (2002). DNA-based subtypes and antimicrobial susceptibility profiles of Haemophilus influenzae and Haemophilus parainfluenzae isolated from different tonsillar sites of children undergoing tonsillectomy and/or adenoidectomy. J Med Liban.
3145 Mathews J, Lancaster J, Sherman I, et al. (2002). Guillotine tonsillectomy: a glimpse into its history and current status in the United Kingdom. J Laryngol Otol.
3146 McCann ME, Bacsik J, Davidson A, et al. (2002). The correlation of bispectral index with endtidal sevoflurane concentration and haemodynamic parameters in preschoolers. Paediatr Anaesth.
3147 McKerrow WS. (2002). Recurrent tonsillitis. Am Fam Physician.
3148 Mehta AK. (2002). Universal tongue blade for tonsillectomy [4]. Medical Journal Armed Forces India.
3149 Mehta AK. (2002). Mehtas ligature forceps for tonsillectomy [3]. Medical Journal Armed Forces India.
3150 Mertens AC, Yasui Y, Liu Y, et al. (2002). Pulmonary complications in survivors of childhood and adolescent cancer. A report from the Childhood Cancer Survivor Study. Cancer.
3151 Mitchell SA, Thyssen M, Orchard TR, et al. (2002). Cigarette smoking, appendectomy, and tonsillectomy as risk factors for the development of primary sclerosing cholangitis: a case control study. Gut.
3152 Mocella S, Mozzo N. (2002). Streptococcal tonsillitis and kidney impact. Pediatr Med Chir.
3153 Moonka PK. (2002). Ligation vs. bipolar diathermy for haemostasis in tonsillectomy - A comparative study. Indian journal of otolaryngology.
3154 Morgenstein SA, Jacobs HK, Brusca PA, et al. (2002). A comparison of tonsillectomy with the harmonic scalpel versus electrocautery. Otolaryngol Head Neck Surg.
3155 Murray N, Fitzpatrick P, Guarisco JL. (2002). Powered partial adenoidectomy. Arch Otolaryngol Head Neck Surg.
3156 Myers LL, Nussenbaum B, Bradford CR, et al. (2002). Paranasal sinus malignancies: an 18-year single institution experience. Laryngoscope.
3157 Nandi S, Kumar R, Ray P, et al. (2002). Clinical score card for diagnosis of group A streptococcal sore throat. Indian J Pediatr.
3158 Nangia IP. (2002). Stitchless Tonsillo-styloidectomy. Indian J Otolaryngol Head Neck Surg.
3159 Nawasreh O, Momani O, Tawalbeh M. (2002). Pre-operative versus post-operative peritonsillar infiltration with local anesthetic on post-tonsillectomy pain. Qatar Medical Journal.
3160 Neff SP, Stapelberg F, Warmington A. (2002). Excruciating perineal pain after intravenous dexamethasone. Anaesth Intensive Care.
3161 Neill RA, Scoville C. (2002). Clinical inquiries. What are the indications for tonsillectomy in children?. J Fam Pract.
3162 Nelson R. (2002). Obstructive sleep apnoea in children might impair cognition and behaviour. Lancet.
3163 Niedzielska G, Katska E. (2002). TEOAE after treatment of otitis media with effusion. Ann Univ Mariae Curie Sklodowska Med.
3164 Nieminen P, Lopponen T, Tolonen U, et al. (2002). Growth and biochemical markers of growth in children with snoring and obstructive sleep apnea. Pediatrics.
3165 Nikolajev K, Korppi M, Remes K, et al. (2002). Determinants of bronchial responsiveness to methacholine at school age in twin pairs. Pediatr Pulmonol.
3166 Nixon GM, Brouillette RT. (2002). Case presentation of a boy referred because of concerns about breathing during sleep. Paediatr Respir Rev.
3167 Nouwen J, Smets F, Rombaux P, et al. (2002). Acute tonsillitis as the first manifestation of post-transplant lymphoproliferative disorder. Ann Otol Rhinol Laryngol.
3168 Odenholt I, Bylander-Groth A, Frimodt-Moller N, et al. (2002). Differences in antibiotic prescribing patterns between general practitioners in Scandinavia: a questionnaire study. Scand J Infect Dis.
3169 Ohtsuka K, Tomita H, Murakami G. (2002). Anatomy of the tonsillar bed: topographical relationship between the palatine tonsil and the lingual branch of the glossopharyngeal nerve. Acta Otolaryngol Suppl.
3170 Okur E, Aral M, Yildirim I, et al. (2002). Bacteremia during adenoidectomy. Int J Pediatr Otorhinolaryngol.
3171 Ono A, Ueyama K, Okada A, et al. (2002). Adult scoliosis in syringomyelia associated with Chiari I malformation. Spine (Phila Pa 1976).
3172 Ovchinsky A, Schulman S, Rosenfeld RM. (2002). Adenotonsillectomy as a treatment option for poststreptococcal uveitis. Laryngoscope.
3173 Ovetchkine P, Levy C, de la Rocque F, et al. (2002). Variables influencing bacteriological outcome in patients with streptococcal tonsillopharyngitis treated with penicillin V. Eur J Pediatr.
3174 Ozgenel GY, Ozcan M. (2002). Bilateral parotid-duct diversion using autologous vein grafts for the management of chronic drooling in cerebral palsy. Br J Plast Surg.
3175 Ozmen S, Tuz M, Eroglu F, et al. (2002). The efficacy of peritonsillar lidocaine infiltration for postoperative pain relief in the immediate postoperative period after pediatric adenotonsillectomy. Pain Clinic.
3176 Palumbo R. (2002). More palatable options for treating obstructive sleep apnea. Clinical Pulmonary Medicine.
3177 Pancharoen C, Mekmullica J, Thisyakorn U, et al. (2002). Clinical features of diphtheria in thai children: a historic perspective. Southeast Asian J Trop Med Public Health.
3178 Pang KP, Goh CH, Tan HM. (2002). Parapharyngeal space tumours: an 18 year review. J Laryngol Otol.
3179 Park AH, Kim H. (2002). Intravenous home hydration in pediatric patients following adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
3180 Patel N, Kirkland P, Tandon P, et al. (2002). Comparison of bipolar scissors and bipolar forceps in tonsillectomy. Ear Nose Throat J.
3181 Pickering AE, Bridge HS, Nolan J, et al. (2002). Double-blind, placebo-controlled analgesic study of ibuprofen or rofecoxib in combination with paracetamol for tonsillectomy in children. Br J Anaesth.
3182 Pitkaranta A, Rihkanen H, Carpen O, et al. (2002). Rhinovirus RNA in children with longstanding otitis media with effusion. Int J Pediatr Otorhinolaryngol.
3183 Plant RL. (2002). Radiofrequency treatment of tonsillar hypertrophy. Laryngoscope.
3184 Postma DS, Folsom F. (2002). The case for an outpatient “approach” for all pediatric tonsillectomies and/or adenoidectomies: a 4-year review of 1419 cases at a community hospital. Otolaryngol Head Neck Surg.
3185 Prasad KC, Kamath MP, Reddy KJ, et al. (2002). Elongated styloid process (Eagle's syndrome): a clinical study. J Oral Maxillofac Surg.
3186 Prim MP, de Diego JI, Larrauri M, et al. (2002). Spontaneous resolution of recurrent tonsillitis in pediatric patients on the surgical waiting list. Int J Pediatr Otorhinolaryngol.
3187 Prokopakis EP, Hajiioannou JK, Velegrakis GA, et al. (2002). The role of laser assisted tympanostomy (LAT) in treating allergic children with chronic serous otitis media. Int J Pediatr Otorhinolaryngol.
3188 Pulkkinen J, Ranta R, Heliovaara A, et al. (2002). Craniofacial characteristics and velopharyngeal function in cleft lip/palate children with and without adenoidectomy. Eur Arch Otorhinolaryngol.
3189 Raffin CN, Montovani JC, Neto JM, et al. (2002). Internal carotid artery pseudoaneurysm after tonsillectomy treated by endovascular approach. A case report. Interv Neuroradiol.
3190 Reber A, Geiduschek JM, Bobbia SA, et al. (2002). Effect of continuous positive airway pressure on the measurement of thoracoabdominal asynchrony and minute ventilation in children anesthetized with sevoflurane and nitrous oxide. Chest.
3191 Reddy MP, Moorchung N, Chaudhary A. (2002). Clinico-pathological profile of pediatric lymphadenopathy. Indian J Pediatr.
3192 Richards M, Giannoni C. (2002). Quality-of-life outcomes after surgical intervention for otitis media. Arch Otolaryngol Head Neck Surg.
3193 Richardson S. (2002). Alberta's provincial Travelling Clinic, 1924-42. Can Bull Med Hist.
3194 Roberts RG, Jones RM. (2002). Paediatric tonsillectomy and PONV -- big little problem remains big!. Anaesthesia.
3195 Rodriguez K, Murray N, Guarisco JL. (2002). Power-assisted partial adenoidectomy. Laryngoscope.
3196 Rowlands RG, Hicklin L, Hinton AE. (2002). Novel use of nebulised adrenaline in the treatment of secondary oropharyngeal haemorrhage. J Laryngol Otol.
3197 Rusy LM, Hoffman GM, Weisman SJ. (2002). Electroacupuncture prophylaxis of postoperative nausea and vomiting following pediatric tonsillectomy with or without adenoidectomy. Anesthesiology.
3198 Salonen A, Kokki H, Nuutinen J. (2002). Recovery after tonsillectomy in adults: a three-week follow-up study. Laryngoscope.
3199 Salonen A, Kokki H, Nuutinen J. (2002). The effect of ketoprofen on recovery after tonsillectomy in children: a 3-week follow-up study. Int J Pediatr Otorhinolaryngol.
3200 Satomaa T, Renkonen O, Helin J, et al. (2002). O-glycans on human high endothelial CD34 putatively participating in L-selectin recognition. Blood.
3201 Schechter MS. (2002). Technical report: diagnosis and management of childhood obstructive sleep apnea syndrome. Pediatrics.
3202 Sedlmaier B, Jivanjee A, Gutzler R, et al. (2002). Ventilation time of the middle ear in otitis media with effusion (OME) after CO2 laser myringotomy. Laryngoscope.
3203 Sedlmaier B, Jivanjee A, Jovanovic S. (2002). Transtympanic middle ear ventilation in otitis media with effusion (OME) after myringotomy with a CO2 laserotoscope. Medical Laser Application.
3204 Sharp CM, Borg HK, Kishore A, et al. (2002). Hypoglossal nerve paralysis following tonsillectomy. J Laryngol Otol.
3205 Simark-Mattsson C, Dahlgren U, Roos K. (2002). CD4+CD25+ T lymphocytes in human tonsils suppress the proliferation of CD4+CD25- tonsil cells. Scand J Immunol.
3206 Spinou E, Kubba H, Konstantinidis I, et al. (2002). Tonsillectomy for biopsy in children with unilateral tonsillar enlargement. Int J Pediatr Otorhinolaryngol.
3207 Stenfors LE, Bye HM, Raisanen S. (2002). Immunocytochemical localization of lysozyme and lactoferrin attached to surface bacteria of the palatine tonsils during infectious mononucleosis. J Laryngol Otol.
3208 Stewart KJ, Ahmad T, Razzell RE, et al. (2002). Altered speech following adenoidectomy: a 20 year experience. Br J Plast Surg.
3209 Stewart PC, Baines DB, Dalton C. (2002). Paediatric day stay tonsillectomy service: development and audit. Anaesth Intensive Care.
3210 Stewart R, Bill R, Ullah R, et al. (2002). Dexamethasone reduces pain after tonsillectomy in adults. Clinical otolaryngology and allied sciences.
3211 Steyer TE. (2002). Peritonsillar abscess: diagnosis and treatment. Am Fam Physician.
3212 Stickler GB. (2002). Indications and results of tonsillectomy and surgery for otitis media in children. Pediatr Case Rev.
3213 Sugiura N, Ochi K, Komatsuzaki Y, et al. (2002). Postoperative pain in tonsillectomy: comparison of ultrasonic tonsillectomy versus blunt dissection tonsillectomy. ORL; journal for oto-rhino-laryngology and its related specialties.
3214 Sun J, Keh-Gong W, Hwang B. (2002). Evaluation of the etiologic agents for acute suppurative tonsillitis in children. Zhonghua Yi Xue Za Zhi (Taipei).
3215 Tai YT, Podar K, Kraeft SK, et al. (2002). Translocation of Ku86/Ku70 to the multiple myeloma cell membrane: functional implications. Exp Hematol.
3216 Talukder MS, Huq MH, Haque A, et al. (2002). Extrapulmonary tuberculosis in surgical specimens. Mymensingh Med J.
3217 Taneja C, Allen H, Koness RJ, et al. (2002). Changing patterns of failure of head and neck cancer. Arch Otolaryngol Head Neck Surg.
3218 Tano K, Hellstrom S. (2002). Bacterial adherence to pharyngeal cells: in vitro studies with alpha-haemolytic streptococci and Haemophilus influenzae. Acta Otolaryngol.
3219 Tasker C, Crosby JH, Stradling JR. (2002). Evidence for persistence of upper airway narrowing during sleep, 12 years after adenotonsillectomy. Arch Dis Child.
3220 Telmesani AM, Ghazi HO. (2002). A study of group a streptococcal bacteria isolation from children less than 12 years with acute tonsillitis, pharyngitis and healthy primary school children. J Family Community Med.
3221 Thomsen J, Gower V. (2002). Adjuvant therapies in children undergoing adenotonsillectomy. Laryngoscope.
3222 Timms MS, Temple RH. (2002). Coblation tonsillectomy: a double blind randomized controlled study. J Laryngol Otol.
3223 Tomita H, Ohtuka K. (2002). Taste disturbance after tonsillectomy. Acta Otolaryngol Suppl.
3224 Tschopp K. (2002). Monopolar electrocautery in adenoidectomy as a possible risk factor for Grisel's syndrome. Laryngoscope.
3225 Tubbs RS, Wellons JC, Oakes WJ. (2002). Asymmetry of tonsillar ectopia in Chiari I malformation. Pediatr Neurosurg.
3226 Tuomilehto H, Kokki H. (2002). Parenteral ketoprofen for pain management after adenoidectomy: comparison of intravenous and intramuscular routes of administration. Acta Anaesthesiol Scand.
3227 Tuomilehto H, Kokki H, Ahonen R, et al. (2002). Postoperative behavioral changes in children after adenoidectomy. Arch Otolaryngol Head Neck Surg.
3228 Unal M, Ozturk C, Gorur K. (2002). Effect of tonsillectomy on serum concentrations of interleukins and TNF-alpha in patients with chronic tonsillitis. ORL J Otorhinolaryngol Relat Spec.
3229 Vasan NR, Stevenson S, Ward M. (2002). Preincisional bupivacaine in posttonsillectomy pain relief: a randomized prospective study. Arch Otolaryngol Head Neck Surg.
3230 Verlaet M, Adamantidis A, Coumans B, et al. (2002). Human immune cells express ppMCH mRNA and functional MCHR1 receptor. FEBS Lett.
3231 Voyles C. (2002). Bipolar Electrosurgery. Problems in General Surgery.
3232 Wang HW, Su WF, Lin YS, et al. (2002). Immunolocalization of inducible nitric oxide synthase and 3-nitrotyrosine in recurrently inflamed, human palatine tonsils. Eur Arch Otorhinolaryngol.
3233 Ward HJ, Everington D, Croes EA, et al. (2002). Sporadic Creutzfeldt-Jakob disease and surgery: a case-control study using community controls. Neurology.
3234 Watson S, Calam R, Jimmieson P. (2002). Can computers help in assessing children's postoperative pain? Initial validation of a computer-assisted interview. Eur J Anaesthesiol.
3235 Wiatrak BJ, Willging JP. (2002). Harmonic scalpel for tonsillectomy. Laryngoscope.
3236 Williams A, Lee P, Kerr A. (2002). Scottish Intercollegiate Guidelines Network (SIGN) guidelines on tonsillectomy: a three cycle audit of clinical record keeping and adherence to national guidelines. J Laryngol Otol.
3237 Williams DG, Patel A, Howard RF. (2002). Pharmacogenetics of codeine metabolism in an urban population of children and its implications for analgesic reliability. Br J Anaesth.
3238 Wilson K, Lakheeram I, Morielli A, et al. (2002). Can assessment for obstructive sleep apnea help predict postadenotonsillectomy respiratory complications?. Anesthesiology.
3239 Windfuhr J. (2002). Malignant neoplasia at different ages presenting as peritonsillar abscess. Otolaryngol Head Neck Surg.
3240 Windfuhr JP. (2002). Excessive post-tonsillectomy hemorrhage requiring ligature of the external carotid artery. Auris Nasus Larynx.
3241 Windfuhr JP. (2002). An aberrant artery as a cause of massive bleeding following adenoidectomy. J Laryngol Otol.
3242 Windfuhr JP. (2002). Indications for interventional arteriography in post-tonsillectomy hemorrhage. J Otolaryngol.
3243 Wynne DM, Marshall JN. (2002). Risk of accidental extubation with disposable tonsillectomy instruments. Br J Anaesth.
3244 Wysocka J, Hassmann E, Kasprzycka E, et al. (2002). Lymphocyte subpopulations in hypertrophied adenoid in children with otitis media with effusion. Rocz Akad Med Bialymst.
3245 Yamamoto K, Iwata F, Nakamura A, et al. (2002). Tonsillar tuberculosis associated with pulmonary and laryngeal foci. Intern Med.
3246 Yilmaz MD, Hosal AS, Oguz H, et al. (2002). The effects of tonsillectomy and adenoidectomy on serum IGF-I and IGFBP3 levels in children. Laryngoscope.
3247 Yokoyama Y, Harabuchi Y. (2002). Intranasal immunization with lipoteichoic acid and cholera toxin evokes specific pharyngeal IgA and systemic IgG responses and inhibits streptococcal adherence to pharyngeal epithelial cells in mice. Int J Pediatr Otorhinolaryngol.
3248 Yokoyama Y, Harabuchi Y. (2002). Decreased serum and pharyngeal antibody levels specific to streptococcal lipoteichoic acid in children with recurrent tonsillitis. Int J Pediatr Otorhinolaryngol.
3249 Younis RT, Lazar RH. (2002). History and current practice of tonsillectomy. Laryngoscope.
3250 Zahraa JN, Al-Boukai AA. (2002). Acute retropharyngeal and parapharyngeal abscesses in children. Saudi Med J.
3251 Zhuang Q, Bisotto S, Fixman ED, et al. (2002). Suppression of IL-4- and CD40-induced B-lymphocyte activation by intravenous immunoglobulin is not mediated through the inhibitory IgG receptor FcgammaRIIb. J Allergy Clin Immunol.
3252 Zielnik-Jurkiewicz B, Jurkiewicz D. (2002). Implication of immunological abnormalities after adenotonsillotomy. Int J Pediatr Otorhinolaryngol.
3253 Zuckerman JM, Kaye D. (2002). Ten questions on prophylaxis of endocarditis and prosthetic joint infection with oropharyngeal procedures. Infectious Diseases in Clinical Practice.
3254 (2003). The role of ventilation tube status in the hearing levels in children managed for bilateral persistent otitis media with effusion. Clin Otolaryngol Allied Sci.
3255 Ahmed J, Zaman MM, Keramat Ali SM. (2003). Identification of serogroups of beta hemolytic streptococci in children with tonsillo-pharyngitis. Bangladesh Med Res Counc Bull.
3256 Aho M, Kokki H, Nikanne E. (2003). Nimesulide versus Ibuprofen for Postoperative Tonsillectomy Pain: A Double-Blind, Randomised, Active Comparator-Controlled Clinical Trial. Clinical drug investigation.
3257 Al-Ammar AY. (2003). Otolaryngologic manifestation of gastroesophageal reflux in children. Saudi Med J.
3258 Al-Barrak H. (2003). Post tonsillectomy quinsy. Saudi Med J.
3259 Al-Bekaa S. (2003). Harmonic scalpel tonsillectomy vs diathermy tonsillectomy: A comparative study. Australian Journal of Otolaryngology.
3260 Al-Kindy SA, Ibekwe AO, Al Hiemy M, et al. (2003). Tonsillectomy blood splash. Saudi Med J.
3261 Al-Kindy SA, Obaideen AO. (2003). The value of radiological examination in the management of adenoidal hypertrophy in a pediatric population. Saudi Med J.
3262 Anderson RC, Dowling KC, Feldstein NA, et al. (2003). Chiari I malformation: potential role for intraoperative electrophysiologic monitoring. J Clin Neurophysiol.
3263 Andreu-Ballester JC, Colomer RE, Millan Scheiding M, et al. (2003). Tonsillectomy and risk of acute appendicitis. Am J Gastroenterol.
3264 Andrews PJ, Giddings CE, Su AP. (2003). Management of lateral cystic swellings of the neck, in the over 40s' age group. J Laryngol Otol.
3265 Anjaneyulu C, Sharan CJ. (2003). Complete Branchial Fistula. Bahrain Medical Bulletin.
3266 Apostolopoulos K, Labropoulou E, Samaan R, et al. (2003). Ropivacaine compared to lidocaine for tonsillectomy under local anaesthesia. Eur Arch Otorhinolaryngol.
3267 Arens R, McDonough JM, Corbin AM, et al. (2003). Upper airway size analysis by magnetic resonance imaging of children with obstructive sleep apnea syndrome. Am J Respir Crit Care Med.
3268 Arita M, Kodama S, Suzuki M, et al. (2003). Single cell analysis of adenoid CD5+ B cells and their protective contributions to nasopharyngeal immunity. Laryngoscope.
3269 Aronsohn MS, Brown HM, Hauptman G, et al. (2003). Expression of focal adhesion kinase and phosphorylated focal adhesion kinase in squamous cell carcinoma of the larynx. Laryngoscope.
3270 Arun T, Isik F, Sayinsu K. (2003). Vertical growth changes after adenoidectomy. Angle Orthod.
3271 Arya A, Donne AJ, Nigam A. (2003). Double-blind randomized controlled study of coblation tonsillotomy versus coblation tonsillectomy on postoperative pain. Clin Otolaryngol Allied Sci.
3272 Asada H, Miyagawa S, Tamura M, et al. (2003). Evaluation of provocation test monitoring palmoplantar temperature with the use of thermography for diagnosis of focal tonsillar infection in palmoplantar pustulosis. J Dermatol Sci.
3273 Banjar H, Al-Hamed M. (2003). Cystic fibrosis and sickle cell disease: The first case report in Saudi Arabia and review of the literature. Current Pediatric Research.
3274 Banwell ME, Robinson DS, Lloyd CM. (2003). Adenoid-derived TH2 cells reactive to allergen and recall antigen express CC chemokine receptor 4. J Allergy Clin Immunol.
3275 Belloso A, Chidambaram A, Morar P, et al. (2003). Coblation tonsillectomy versus dissection tonsillectomy: postoperative hemorrhage. Laryngoscope.
3276 Bennhoff DF. (2003). Partial tonsillectomy revisited and role for mini-tracheotomy revisited. Arch Otolaryngol Head Neck Surg.
3277 Bereznoy VV, Riley DS, Wassmer G, et al. (2003). Efficacy of extract of Pelargonium sidoides in children with acute non-group A beta-hemolytic streptococcus tonsillopharyngitis: a randomized, double-blind, placebo-controlled trial. Altern Ther Health Med.
3278 Bergler WF. (2003). Argon plasma coagulation (APC) surgery in otorhinolaryngology. Surg Technol Int.
3279 Berlucchi M, Meini A, Plebani A, et al. (2003). Update on treatment of Marshall's syndrome (PFAPA syndrome): report of five cases with review of the literature. Ann Otol Rhinol Laryngol.
3280 Bhattacharyya N. (2003). When does an adult need a tonsillectomy?. Cleve Clin J Med.
3281 Bishop P, Patel A. (2003). Laryngeal mask or tube for tonsillectomy?. Hosp Med.
3282 Boston M, McCook J, Burke B, et al. (2003). Incidence of and risk factors for additional tympanostomy tube insertion in children. Arch Otolaryngol Head Neck Surg.
3283 Bouchard S, Davey MG, Rintoul NE, et al. (2003). Correction of hindbrain herniation and anatomy of the vermis after in utero repair of myelomeningocele in sheep. J Pediatr Surg.
3284 Brandtzaeg P. (2003). Immunology of tonsils and adenoids: everything the ENT surgeon needs to know. Int J Pediatr Otorhinolaryngol.
3285 Brenn BR, Reilly JS, Deutsch ES, et al. (2003). Analysis of efficiency of common otolaryngology operations: comparison of operating room vs short procedure room in a pediatric tertiary hospital. Arch Otolaryngol Head Neck Surg.
3286 Brook I, Shah K. (2003). Effect of amoxicillin or clindamycin on the adenoids bacterial flora. Otolaryngol Head Neck Surg.
3287 Brown KA, Morin I, Hickey C, et al. (2003). Urgent adenotonsillectomy: an analysis of risk factors associated with postoperative respiratory morbidity. Anesthesiology.
3288 Bruppacher H, Reber A, Keller JP, et al. (2003). The effects of common airway maneuvers on airway pressure and flow in children undergoing adenoidectomies. Anesth Analg.
3289 Burton M. (2003). Tonsillectomy. Arch Dis Child.
3290 Butler CC, Williams RG. (2003). The etiology, pathophysiology, and management of otitis media with effusion. Current Infectious Disease Reports.
3291 Carbon C. (2003). A pooled analysis of telithromycin in the treatment of community-acquired respiratory tract infections in adults. Infection.
3292 Carlstedt K, Henningsson G, Dahllof G. (2003). A four-year longitudinal study of palatal plate therapy in children with Down syndrome: effects on oral motor function, articulation and communication preferences. Acta Odontol Scand.
3293 Cassano P, Gelardi M, Cassano M, et al. (2003). Adenoid tissue rhinopharyngeal obstruction grading based on fiberendoscopic findings: a novel approach to therapeutic management. Int J Pediatr Otorhinolaryngol.
3294 Castellano P, Lopez-Escamez JA. (2003). American Society of Anesthesiology classification may predict severe post-tonsillectomy haemorrhage in children. J Otolaryngol.
3295 Caulfield H. (2003). Investigations in paediatric obstructive sleep apnoea: do we need them?. Int J Pediatr Otorhinolaryngol.
3296 Chadha NK, Pratap R, Narula AA. (2003). Consent processes in common nose and throat procedures. J Laryngol Otol.
3297 Chazan B, Shaabi M, Bishara E, et al. (2003). Clinical predictors of streptococcal pharyngitis in adults. Isr Med Assoc J.
3298 Chervin RD, Ruzicka DL, Wiebelhaus JL, et al. (2003). Tolerance of esophageal pressure monitoring during polysomnography in children. Sleep.
3299 Chew ST, Ip-Yam PC, Kong CF. (2003). Recovery following tonsillectomy a comparison between tramadol and morphine for analgesia. Singapore Med J.
3300 Chole RA, Faddis BT. (2003). Anatomical evidence of microbial biofilms in tonsillar tissues: a possible mechanism to explain chronicity. Arch Otolaryngol Head Neck Surg.
3301 Cirak MY, Ozdek A, Yilmaz D, et al. (2003). Detection of Helicobacter pylori and its CagA gene in tonsil and adenoid tissues by PCR. Arch Otolaryngol Head Neck Surg.
3302 Claeys S, de Belder T, Holtappels G, et al. (2003). Human beta-defensins and toll-like receptors in the upper airway. Allergy.
3303 Clary RA. (2003). Is there a future for pediatric sinus surgery? An American perspective. Int J Pediatr Otorhinolaryngol.
3304 Compadretti GC, Nannini R, Tasca I. (2003). Isolated tonsillar sarcoidosis manifested as asymmetric palantine tonsils. Am J Otolaryngol.
3305 Contencin P, Guilleminault C, Manach Y. (2003). Long-term follow-up and mechanisms of obstructive sleep apnea (OSA) and related syndromes through infancy and childhood. Int J Pediatr Otorhinolaryngol.
3306 Criscuoli G, D'Amora S, Ripa G, et al. (2003). Frequency of surgery among children who have adenotonsillar hypertrophy and improve after treatment with nasal beclomethasone. Pediatrics.
3307 Cultrara A, Goldstein NA, Ovchinsky A, et al. (2003). The role of Chlamydia pneumoniae infection in children with chronic sinusitis. Arch Otolaryngol Head Neck Surg.
3308 Cupero TM, Kim SY, Silva AB. (2003). The effects of a preoperative steroid/anesthetic injection on post-tonsillectomy pain. Ear, nose, & throat journal.
3309 Curtin CD, Casey JR, Murray PC, et al. (2003). Efficacy of cephalexin two vs. three times daily vs. cefadroxil once daily for streptococcal tonsillopharyngitis. Clin Pediatr (Phila).
3310 da Silva JA, Holanda MM. (2003). Basilar impression, Chiari malformation and syringomyelia: a retrospective study of 53 surgically treated patients. Arq Neuropsiquiatr.
3311 Dahanukar S, Ogale S, Thatte U. (2003). ProImmu in the prevention of recurrent tonsillitis: a clinical study. Antiseptic.
3312 Dahlqvist A, Rask E, Rosenqvist CJ, et al. (2003). Sleep apnea and Down's syndrome. Acta Otolaryngol.
3313 de Baey A, Mende I, Baretton G, et al. (2003). A subset of human dendritic cells in the T cell area of mucosa-associated lymphoid tissue with a high potential to produce TNF-alpha. J Immunol.
3314 de Miguel-Diez J, Villa-Asensi JR, Alvarez-Sala JL. (2003). Prevalence of sleep-disordered breathing in children with Down syndrome: polygraphic findings in 108 children. Sleep.
3315 Del Carmen Trojavchich M, Crisci CD, Shafa M, et al. (2003). Relationship between group A beta-hemolytic streptococcal tonsillopharyngitis and asthma. Pediatr Allergy Immunol.
3316 Deutsch ES, Cook SP, Shaha S, et al. (2003). Duration of patency of laser-assisted tympanic membrane fenestration. Arch Otolaryngol Head Neck Surg.
3317 Dias EP, Alfaro SE, De Piro SC. (2003). Lymphoid papillary hyperplasia: report of a case. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
3318 Discolo CM, Darrow DH, Koltai PJ. (2003). Infectious indications for tonsillectomy. Pediatr Clin North Am.
3319 Dones J, De Jesus O, Colen CB, et al. (2003). Clinical outcomes in patients with Chiari I malformation: a review of 27 cases. Surg Neurol.
3320 Donnelly LF, Surdulescu V, Chini BA, et al. (2003). Upper airway motion depicted at cine MR imaging performed during sleep: comparison between young Patients with and those without obstructive sleep apnea. Radiology.
3321 Dunne AA, Granger O, Folz BJ, et al. (2003). Peritonsillar abscess--critical analysis of abscess tonsillectomy. Clin Otolaryngol Allied Sci.
3322 Dyken ME, Lin-Dyken DC, Poulton S, et al. (2003). Prospective polysomnographic analysis of obstructive sleep apnea in down syndrome. Arch Pediatr Adolesc Med.
3323 Ebenfelt A. (2003). Bacterial adherence to mucosal epithelium in the upper airways has less significance than believed. J Negat Results Biomed.
3324 Ecoffey C, Auroy Y, Pequignot F, et al. (2003). A French survey of paediatric airway management use in tonsillectomy and appendicectomy. Paediatr Anaesth.
3325 Elhakim M, Khalafallah Z, El-Fattah HA, et al. (2003). Ketamine reduces swallowing-evoked pain after paediatric tonsillectomy. Acta Anaesthesiol Scand.
3326 Engelhardt T, Steel E, Johnston G, et al. (2003). Tramadol for pain relief in children undergoing tonsillectomy: a comparison with morphine. Paediatr Anaesth.
3327 Eriksson JC, Davidsson A, Garberg H, et al. (2003). Lymphocyte distribution in the tonsils prior to and after influenza vaccination. Vaccine.
3328 Evans AS, El-Hawrani A, Lodhi A, et al. (2003). Lip injury prevention during tonsillectomy. J Laryngol Otol.
3329 Evans AS, Khan AM, Young D, et al. (2003). Assessment of secondary haemorrhage rates following adult tonsillectomy--a telephone survey and literature review. Clin Otolaryngol Allied Sci.
3330 Fagnani F, German-Fattal M. (2003). Antibiotic prescribing patterns of French GPs for upper respiratory tract infections: impact of fusafungine on rates of prescription of systemic antibiotics. Am J Respir Med.
3331 Fechner FP, Kieff D. (2003). Cervical emphysema complicating tonsillectomy with argon beam coagulation. Laryngoscope.
3332 Felder-Puig R, Maksys A, Noestlinger C, et al. (2003). Using a children's book to prepare children and parents for elective ENT surgery: results of a randomized clinical trial. Int J Pediatr Otorhinolaryngol.
3333 Fink W, Zimpfer A, Ugurel S. (2003). Mucosal metastases in malignant melanoma. Onkologie.
3334 Flanary VA. (2003). Long-term effect of adenotonsillectomy on quality of life in pediatric patients. Laryngoscope.
3335 Flickinger JC, Kondziolka D, Maitz AH, et al. (2003). Gamma knife radiosurgery of imaging-diagnosed intracranial meningioma. Int J Radiat Oncol Biol Phys.
3336 Fregosi RF, Quan SF, Kaemingk KL, et al. (2003). Sleep-disordered breathing, pharyngeal size and soft tissue anatomy in children. J Appl Physiol (1985).
3337 Friedman BC, Hendeles-Amitai A, Kozminsky E, et al. (2003). Adenotonsillectomy improves neurocognitive function in children with obstructive sleep apnea syndrome. Sleep.
3338 Friedman M, LoSavio P, Ibrahim H, et al. (2003). Radiofrequency tonsil reduction: safety, morbidity, and efficacy. Laryngoscope.
3339 Gehanno P, Sultan E, Passot V, et al. (2003). Telithromycin (HMR 3647) achieves high and sustained concentrations in tonsils of patients undergoing tonsillectomy. Int J Antimicrob Agents.
3340 Gessler EM, Bondy PC. (2003). Respiratory complications following tonsillectomy/UPPP: is step-down monitoring necessary?. Ear Nose Throat J.
3341 Gillespie MB, Scarlett M, Ingram F, et al. (2003). Value-based approach to power-assisted adenoidectomy. Ann Otol Rhinol Laryngol.
3342 Gnanalingham KK, Lafuente J, Thompson D, et al. (2003). The natural history of ventriculomegaly and tonsillar herniation in children with posterior fossa tumours--an MRI study. Pediatr Neurosurg.
3343 Graham SM, Nerad JA. (2003). Orbital complications in endoscopic sinus surgery using powered instrumentation. Laryngoscope.
3344 Greenfeld M, Tauman R, DeRowe A, et al. (2003). Obstructive sleep apnea syndrome due to adenotonsillar hypertrophy in infants. Int J Pediatr Otorhinolaryngol.
3345 Grivel JC, Biancotto A, Ito Y, et al. (2003). Bystander CD4+ T lymphocytes survive in HIV-infected human lymphoid tissue. AIDS Res Hum Retroviruses.
3346 Gudjonsson JE, Thorarinsson AM, Sigurgeirsson B, et al. (2003). Streptococcal throat infections and exacerbation of chronic plaque psoriasis: a prospective study. Br J Dermatol.
3347 Guilleminault C, Palombini L, Pelayo R, et al. (2003). Sleepwalking and sleep terrors in prepubertal children: what triggers them?. Pediatrics.
3348 Gulhas N, Durmus M, Demirbilek S, et al. (2003). The use of magnesium to prevent laryngospasm after tonsillectomy and adenoidectomy: a preliminary study. Paediatr Anaesth.
3349 Gupta M, Filler G, Kovesi T, et al. (2003). Quantitative tissue polymerase chain reaction for Epstein-Barr virus in pediatric solid organ recipients. Am J Kidney Dis.
3350 Gurunluoglu R, Gurunluoglu A. (2003). Paul of Aegina: landmark in surgical progress. World J Surg.
3351 Hackner C, Detsch O, Schneider G, et al. (2003). Early recovery after remifentanil-pronounced compared with propofol-pronounced total intravenous anaesthesia for short painful procedures. Br J Anaesth.
3352 Hanif J, Tasca RA, Frosh A, et al. (2003). Silver nitrate: histological effects of cautery on epithelial surfaces with varying contact times. Clin Otolaryngol Allied Sci.
3353 Harsha WJ, Goco PE, Crawford JV. (2003). Remission of chronic inflammatory demyelinating polyneuropathy following adenotonsillectomy. Ear Nose Throat J.
3354 Hartnick CJ, Volk M, Cunningham M. (2003). Establishing normative voice-related quality of life scores within the pediatric otolaryngology population. Arch Otolaryngol Head Neck Surg.
3355 Hatzakis GE, Karsan N, Cook J, et al. (2003). Acoustic reflectance of pharyngeal structures in children. Int J Pediatr Otorhinolaryngol.
3356 Hauben EI, Arends J, Vandenbroucke JP, et al. (2003). Multiple primary malignancies in osteosarcoma patients. Incidence and predictive value of osteosarcoma subtype for cancer syndromes related with osteosarcoma. Eur J Hum Genet.
3357 Heubi C, Shott SR. (2003). PANDAS: pediatric autoimmune neuropsychiatric disorders associated with streptococcal infections--an uncommon, but important indication for tonsillectomy. Int J Pediatr Otorhinolaryngol.
3358 Hiroshima K, Iyoda A, Isobe K, et al. (2003). Fatal infectious mononucleosis with evidence suggestive of the development of B cell lymphoma. Pathol Int.
3359 Hoare S. (2003). HIV infection in children--impact upon ENT doctors. Int J Pediatr Otorhinolaryngol.
3360 Hoeve LJ, Pijpers M, Joosten KF. (2003). OSAS in craniofacial syndromes: an unsolved problem. Int J Pediatr Otorhinolaryngol.
3361 Hofmann T, Lackner A, Berghold A, et al. (2003). Influence of sensitization to inhalative allergens on adenotonsillar disease. Otolaryngol Head Neck Surg.
3362 Hopkins C, Geyer M, Topham J. (2003). Post-tonsillectomy haemorrhage: a 7-year retrospective study. Eur Arch Otorhinolaryngol.
3363 Horie A, Hiki Y, Odani H, et al. (2003). IgA1 molecules produced by tonsillar lymphocytes are under-O-glycosylated in IgA nephropathy. Am J Kidney Dis.
3364 Inci E, Karakullukcu B, Aygun G, et al. (2003). Fine-needle aspiration as a diagnostic tool for recurrent tonsillitis. J Int Med Res.
3365 Issing WJ, Taleban B, Tauber S. (2003). Diagnosis and management of carcinoma of unknown primary in the head and neck. Eur Arch Otorhinolaryngol.
3366 Itoh A, Iwase H, Takatani T, et al. (2003). Tonsillar IgA1 as a possible source of hypoglycosylated IgA1 in the serum of IgA nephropathy patients. Nephrol Dial Transplant.
3367 Jalessi M, Shahram F, Safavi A, et al. (2003). Tonsillectomy and Behcet's disease. Adv Exp Med Biol.
3368 James AL, Runciman M, Burton MJ, et al. (2003). Investigation of cardiac function in children with suspected obstructive sleep apnea. J Otolaryngol.
3369 Jana U, Mukherjee S. (2003). Tuberculosis of tonsil - a rare site involvement. Indian J Otolaryngol Head Neck Surg.
3370 Jeon E, Park Y, Lee S, et al. (2003). Effect of Muscle Relaxant on Post-Tonsillectomy Pain. Korean Journal of Otolaryngology - Head & Neck Surgery.
3371 Jimenez C, Marques E, Loinaz C, et al. (2003). Upper aerodigestive tract and lung tumors after liver transplantation. Transplant Proc.
3372 Jinquan T, Jacobi HH, Jing C, et al. (2003). CCR3 expression induced by IL-2 and IL-4 functioning as a death receptor for B cells. J Immunol.
3373 Johansson E, Hultcrantz E. (2003). Tonsillectomy--clinical consequences twenty years after surgery?. Int J Pediatr Otorhinolaryngol.
3374 Johansson L, Mansson NO. (2003). Rapid test, throat culture and clinical assessment in the diagnosis of tonsillitis. Fam Pract.
3375 Johnson BC, Alvi A. (2003). Cost-effective workup for tonsillitis. Testing, treatment, and potential complications. Postgrad Med.
3376 Johnson RF, Stewart MG, Wright CC. (2003). An evidence-based review of the treatment of peritonsillar abscess. Otolaryngol Head Neck Surg.
3377 Joshi W, Connelly NR, Reuben SS, et al. (2003). An evaluation of the safety and efficacy of administering rofecoxib for postoperative pain management. Anesth Analg.
3378 Kadar AA, Obaid MA. (2003). Effect on postoperative pain after local application of bupivacaine in the tonsillar fossa; a prospective single blind controlled trial. J Pak Med Assoc.
3379 Kanerva M, Tarkkila P, Pitkaranta A. (2003). Day-case tonsillectomy in children: parental attitudes and consultation rates. Int J Pediatr Otorhinolaryngol.
3380 Karamanlioglu B, Turan A, Memis D, et al. (2003). Comparison of oral dolasetron and ondansetron in the prophylaxis of postoperative nausea and vomiting in children. European journal of anaesthesiology.
3381 Katcher K, Bothwell M, Tobias JD. (2003). Anaesthetic implications of Costello syndrome. Paediatr Anaesth.
3382 Kawano M, Okada K, Muramoto H, et al. (2003). Simultaneous, clonally identical T cell expansion in tonsil and synovium in a patient with rheumatoid arthritis and chronic tonsillitis. Arthritis Rheum.
3383 Kay DJ, Mehta V, Goldsmith AJ. (2003). Perioperative adenotonsillectomy management in children: current practices. Laryngoscope.
3384 Kaygusuz I, Godekmerdan A, Karlidag T, et al. (2003). Early stage impacts of tonsillectomy on immune functions of children. Int J Pediatr Otorhinolaryngol.
3385 Kaygusuz I, Ilhan N, Karlidag T, et al. (2003). Free radicals and scavenging enzymes in chronic tonsillitis. Otolaryngol Head Neck Surg.
3386 Kaygusuz I, Susaman N. (2003). The effects of dexamethasone, bupivacaine and topical lidocaine spray on pain after tonsillectomy. Int J Pediatr Otorhinolaryngol.
3387 Kazak I, Haisch A, Jovanovic S. (2003). Bilateral synchronous tonsillar carcinoma in cervical cancer of unknown primary site (CUPS). Eur Arch Otorhinolaryngol.
3388 Kern RC, Kutler DI, Reid KJ, et al. (2003). Laser-assisted uvulopalatoplasty and tonsillectomy for the management of obstructive sleep apnea syndrome. Laryngoscope.
3389 Kessler A, Lapinsky J, Segal S, et al. (2003). Bilateral peritonsillar abscesses: relief of upper airway obstruction by quinsy tonsillectomy. Isr Med Assoc J.
3390 Kihara S, Komatsuzaki T, Brimacombe JR, et al. (2003). A silicone-based wire-reinforced tracheal tube with a hemispherical bevel reduces nasal morbidity for nasotracheal intubation. Anesthesia and analgesia.
3391 Kim HJ, Choi HS, Seo YS, et al. (2003). Effect of Patient-Controlled Analgesia after Tonsillectomy with Laser Resection of Palatopharynx (LRPP). Journal of Rhinology.
3392 Klussmann JP, Gultekin E, Weissenborn SJ, et al. (2003). Expression of p16 protein identifies a distinct entity of tonsillar carcinomas associated with human papillomavirus. Am J Pathol.
3393 Knight R. (2003). Variant CJD: the present position and future possibilities. Int J Pediatr Otorhinolaryngol.
3394 Kojima M, Nakamura S, Motoori T, et al. (2003). Progressive transformation of germinal centers: a clinicopathological study of 42 Japanese patients. Int J Surg Pathol.
3395 Kokka F, Vorgias G, Tserkezoglou A, et al. (2003). Preoperative work-up of early cervical cancer (stages Ib-IIa). Eur J Gynaecol Oncol.
3396 Kokki H. (2003). Nonsteroidal anti-inflammatory drugs for postoperative pain: a focus on children. Paediatr Drugs.
3397 Kokki H, Nikanne E, Aho M, et al. (2003). Pain intensity after laseruvulopalatoplasty and tonsillectomy. Otolaryngol Head Neck Surg.
3398 Koltai PJ. (2003). Capsule sparing in tonsil surgery: the value of intracapsular tonsillectomy. Arch Otolaryngol Head Neck Surg.
3399 Koltai PJ, Solares CA, Koempel JA, et al. (2003). Intracapsular tonsillar reduction (partial tonsillectomy): reviving a historical procedure for obstructive sleep disordered breathing in children. Otolaryngol Head Neck Surg.
3400 Kowalska M, Kowalska H, Zawadzka-Glos L, et al. (2003). Dysfunction of peripheral blood granulocyte oxidative metabolism in children with recurrent upper respiratory tract infections. Int J Pediatr Otorhinolaryngol.
3401 Krishna S, Hughes LF, Lin SY. (2003). Postoperative hemorrhage with nonsteroidal anti-inflammatory drug use after tonsillectomy: a meta-analysis. Arch Otolaryngol Head Neck Surg.
3402 Krishnan BS, Eipe N, Korula G. (2003). Anaesthetic management of a patient with achondroplasia. Paediatr Anaesth.
3403 Krugmann J, Tzankov A, Gschwendtner A, et al. (2003). Longer failure-free survival interval of Epstein-Barr virus-associated classical Hodgkin's lymphoma: a single-institution study. Mod Pathol.
3404 Kurien M, Sheelan S, Jeyaseelan L, et al. (2003). Fine needle aspiration in chronic tonsillitis: reliable and valid diagnostic test. J Laryngol Otol.
3405 Kyrmizakis DE, Chimona TS, Papadakis CE, et al. (2003). Laser-assisted uvulopalatoplasty for the treatment of snoring and mild obstructive sleep apnea syndrome. J Otolaryngol.
3406 Lampton L. (2003). Looking back: Sluder method of tonsillectomy. J Miss State Med Assoc.
3407 Lee MS, Montague ML, Hussain SS. (2003). The admission of patients with peri-tonsillar abscess to a general ENT ward and its influence on secondary post-tonsillectomy haemorrhage. Clin Otolaryngol Allied Sci.
3408 Leinbach RF, Markwell SJ, Colliver JA, et al. (2003). Hot versus cold tonsillectomy: a systematic review of the literature. Otolaryngol Head Neck Surg.
3409 Lewis KE, Watterson T. (2003). Comparison of nasalance scores obtained from the Nasometer and the NasalView. Cleft Palate Craniofac J.
3410 Li HY, Li KK, Chen NH, et al. (2003). Modified uvulopalatopharyngoplasty: The extended uvulopalatal flap. Am J Otolaryngol.
3411 Lildholdt T, Doessing H, Lyster M, et al. (2003). The natural history of recurrent acute tonsillitis and a clinical trial of azithromycin for antibiotic prophylaxis. Clin Otolaryngol Allied Sci.
3412 Lin MH, Chang PF, Fong WK, et al. (2003). Epidemiological and clinical features of group A Streptococcus pharyngitis in children. Acta Paediatr Taiwan.
3413 Lin MH, Fong WK, Chang PF, et al. (2003). Predictive value of clinical features in differentiating group A beta-hemolytic streptococcal pharyngitis in children. J Microbiol Immunol Infect.
3414 Linder JA, Singer DE, Stafford RS. (2003). Association between antibiotic prescribing and visit duration in adults with upper respiratory tract infections. Clin Ther.
3415 Lipton AJ, Gozal D. (2003). Treatment of obstructive sleep apnea in children: do we really know how?. Sleep Med Rev.
3416 Liu J, Udupa JK, Odhnera D, et al. (2003). System for upper airway segmentation and measurement with MR imaging and fuzzy connectedness. Acad Radiol.
3417 Lo TP, Thaller SR. (2003). Velopharyngoplasty and tonsillectomy: whether to perform them simultaneously. J Craniofac Surg.
3418 Lombardi AM, Sartori MT, Cabrio L, et al. (2003). Severe prekallikrein (Fletcher factor) deficiency due to a compound heterozygosis (383Trp stop codon and Cys529Tyr). Thromb Haemost.
3419 Loughran S, Alves CB, Geddes NK. (2003). The perceived risk of variant Creutzfeld-Jakob disease and the effect of additional delay in tonsillectomy: a questionnaire based parents perspective. Int J Pediatr Otorhinolaryngol.
3420 Maheshwar A, De M, Browning ST. (2003). Reusable versus disposable instruments in tonsillectomy: a comparative study of outcomes. Int J Clin Pract.
3421 Makokha EP, Ogolla M, Orago AS, et al. (2003). CD4T lymphocyte subsets and disease manifestation in children with and without HIV born to HIV-1 infected mothers. East Afr Med J.
3422 Marioni G, De Filippis C, Tregnaghi A, et al. (2003). Cervical emphysema and pneumomediastinum after tonsillectomy: it can happen. Otolaryngol Head Neck Surg.
3423 Marret E, Flahault A, Samama CM, et al. (2003). Effects of postoperative, nonsteroidal, antiinflammatory drugs on bleeding risk after tonsillectomy: meta-analysis of randomized, controlled trials. Anesthesiology.
3424 Masanja MI, Kalyanyama BM, Simon EN. (2003). Salivary gland tumours in Tanzania. East Afr Med J.
3425 Mattila PS, Hammaren-Malmi S, Tarkkanen J, et al. (2003). Adenoidectomy during early life and the risk of asthma. Pediatr Allergy Immunol.
3426 Mattila PS, Joki-Erkkila VP, Kilpi T, et al. (2003). Prevention of otitis media by adenoidectomy in children younger than 2 years. Arch Otolaryngol Head Neck Surg.
3427 Mattucci KF, Militana CJ. (2003). The prevention of fire during oropharyngeal electrosurgery. Ear Nose Throat J.
3428 McGinn TG, Deluca J, Ahlawat SK, et al. (2003). Validation and modification of streptococcal pharyngitis clinical prediction rules. Mayo Clin Proc.
3429 McLaughlin PJ, Stack BC, Levin RJ, et al. (2003). Defects in the opioid growth factor receptor in human squamous cell carcinoma of the head and neck. Cancer.
3430 Mendenhall WM, Morris CG, Amdur RJ, et al. (2003). Parameters that predict local control after definitive radiotherapy for squamous cell carcinoma of the head and neck. Head Neck.
3431 Mert A, Ozaras R, Tabak F, et al. (2003). Fever of unknown origin: a review of 20 patients with adult-onset Still's disease. Clin Rheumatol.
3432 Messner AH. (2003). Treating pediatric patients with obstructive sleep disorders: an update. Otolaryngol Clin North Am.
3433 Milhorat TH, Bolognese PA. (2003). Tailored operative technique for Chiari type I malformation using intraoperative color Doppler ultrasonography. Neurosurgery.
3434 Mino M, Pilch BZ, Faquin WC. (2003). Expression of KIT (CD117) in neoplasms of the head and neck: an ancillary marker for adenoid cystic carcinoma. Mod Pathol.
3435 Moiniche S, Romsing J, Dahl JB, et al. (2003). Nonsteroidal antiinflammatory drugs and the risk of operative site bleeding after tonsillectomy: a quantitative systematic review. Anesth Analg.
3436 Montague ML, Lee MS, Hussain SS. (2003). Effect of disposable instruments on paediatric post-tonsillectomy haemorrhage rates. Int J Pediatr Otorhinolaryngol.
3437 Moorthy SS, Radpour S. (2003). Tracheal stomal recurrence of tonsillar cancer. Otolaryngol Head Neck Surg.
3438 Mora R, Salami A, Passali FM, et al. (2003). OSAS in children. Int J Pediatr Otorhinolaryngol.
3439 Mossad SB. (2003). Tonsillectomy in adults: a paucity of data. Cleve Clin J Med.
3440 Muller G, Groters S, Siebert U, et al. (2003). Parapoxvirus infection in harbor seals (Phoca vitulina) from the German North Sea. Vet Pathol.
3441 Muller R, Bottger C, Wichmann G. (2003). Suitability of cefotiam and cefuroxime axetil for the perioperative short-term prophylaxis in tonsillectomy patients. Arzneimittelforschung.
3442 Murray DP, El-Hakim H, Ahsan F, et al. (2003). Does synchronous nasal surgery increase the risk of post-operative haemorrhage in adult patients undergoing tonsillectomy?. J Laryngol Otol.
3443 Musiatowicz M, Hassmann-Poznanska E, Musiatowicz B, et al. (2003). The Bcl-2 protein expression in germinal centers of hypertrophied adenoids in children. Int J Pediatr Otorhinolaryngol.
3444 Nakazawa K, Ikeda D, Ishikawa S, et al. (2003). A case of difficult airway due to lingual tonsillar hypertrophy in a patient with Down's syndrome. Anesth Analg.
3445 Nandi R, De M, Browning S, et al. (2003). Diphtheria: the patch remains. J Laryngol Otol.
3446 Nelson LM. (2003). Temperature-controlled radiofrequency tonsil reduction in children. Arch Otolaryngol Head Neck Surg.
3447 Nikanne E, Virtaniemi J, Aho M, et al. (2003). Ketoprofen for postoperative pain after uvulopalatopharyngoplasty and tonsillectomy: two-week follow-up study. Otolaryngol Head Neck Surg.
3448 Nishimura T, Suzuki K. (2003). Anatomy of oral respiration: morphology of the oral cavity and pharynx. Acta Otolaryngol Suppl.
3449 Nishino H, Kenmochi M, Kasugai S, et al. (2003). Subcutaneous emphysema secondary to tonsillectomy: a case report. Auris Nasus Larynx.
3450 Nix P. (2003). Prions and disposable surgical instruments. Int J Clin Pract.
3451 Noon AP, Hargreaves S. (2003). Increased post-operative haemorrhage seen in adult coblation tonsillectomy. J Laryngol Otol.
3452 Nuhoglu Y, Nuhoglu C, Sirlioglu E, et al. (2003). Does recurrent sinusitis lead to a sinusitis remodeling of the upper airways in asthmatic children with chronic rhinitis?. J Investig Allergol Clin Immunol.
3453 O'Flaherty JE, Lin CX. (2003). Does ketamine or magnesium affect posttonsillectomy pain in children?. Paediatr Anaesth.
3454 Ohta Y, Ohya Y, Fujii K, et al. (2003). Inflammatory diseases associated with Takayasu's arteritis. Angiology.
3455 Okada K, Miyako M, Honma S, et al. (2003). Discharge diagnoses in infants with apparent life-threatening event. Pediatr Int.
3456 Oluwasanmi AF. (2003). Post tonsillectomy morbidity: following the introduction of single-use-instruments. Auris Nasus Larynx.
3457 Onakoya PA, Adeyi OA, Nwaorgu OG, et al. (2003). Primary extranodal non-Hodgkin's lymphoma of the upper aerodigestive tract--a descriptive analysis of the pattern seen in the University College Hospital, Ibadan. Afr J Med Med Sci.
3458 O'Reilly BJ, Black S, Fernandes J, et al. (2003). Is the routine use of antibiotics justified in adult tonsillectomy?. J Laryngol Otol.
3459 Ozer Z, Gorur K, Altunkan AA, et al. (2003). Efficacy of tramadol versus meperidine for pain relief and safe recovery after adenotonsillectomy. Eur J Anaesthesiol.
3460 Papakostas K, Moraitis D, Lancaster J, et al. (2003). Depressive symptoms in children after tonsillectomy. Int J Pediatr Otorhinolaryngol.
3461 Parikh SR, Reiter ER, Kenna MA, et al. (2003). Utility of tonsillectomy in 2 patients with the syndrome of periodic fever, aphthous stomatitis, pharyngitis, and cervical adenitis. Arch Otolaryngol Head Neck Surg.
3462 Park SN, Yeo SW, Park KH, et al. (2003). Superoxide dismutase in pediatric palatine tonsils and adenoids and its related clinical parameters. Am J Otolaryngol.
3463 Pellegrini M, Lysakowski C, Dumont L, et al. (2003). Propofol 1% versus propofol 2% in children undergoing minor ENT surgery. Br J Anaesth.
3464 Peloso UC, De Souza JC, Botino MA, et al. (2003). Penicillin concentrations in sera and tonsils after intramuscular administration of benzathine penicillin G to children. Pediatr Infect Dis J.
3465 Perez-Flores E, Medina-Santillan R, Reyes-Garcia G, et al. (2003). Combination of diclofenac plus B vitamins in acute pain after tonsillectomy: a pilot study. Proceedings of the Western Pharmacology Society.
3466 Perkins J, Dahiya R. (2003). Microdissection needle tonsillectomy and postoperative pain: a pilot study. Arch Otolaryngol Head Neck Surg.
3467 Pivalizza EG. (2003). Perioperative use of the Thrombelastograph in patients with inherited bleeding disorders. J Clin Anesth.
3468 Poels PJ, Schilder AG, van den Berg S, et al. (2003). Evaluation of a new device for home cardiorespiratory recording in children. Arch Otolaryngol Head Neck Surg.
3469 Prim MP, De Diego JI, Jimenez-Yuste V, et al. (2003). Analysis of the causes of immediate unanticipated bleeding after pediatric adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
3470 Quinn J, Ruoff GE, Ziter PS. (2003). Efficacy and tolerability of 5-day, once-daily telithromycin compared with 10-day, twice-daily clarithromycin for the treatment of group A beta-hemolytic streptococcal tonsillitis/pharyngitis: a multicenter, randomized, double-blind, parallel-group study. Clin Ther.
3471 Raghavan U, Bradley PJ. (2003). Management of cystic cervical metastasis. Curr Opin Otolaryngol Head Neck Surg.
3472 Raz R, Hassin D, Kitzes-Cohen R, et al. (2003). Antibiotic prescribing for adults and children in Israeli emergency rooms. Int J Antimicrob Agents.
3473 Ree HJ, Ohsima K, Aozasa K, et al. (2003). Detection of germinal center B-cell lymphoma in archival specimens: critical evaluation of Bcl-6 protein expression in diffuse large B-cell lymphoma of the tonsil. Hum Pathol.
3474 Rees LE, Ayoub O, Haverson K, et al. (2003). Differential major histocompatibility complex class II locus expression on human laryngeal epithelium. Clin Exp Immunol.
3475 Remacle M, Keghian J, Lawson G, et al. (2003). Carbon-dioxide laser-assisted tonsil ablation for adults with chronic tonsillitis: a 6-month follow-up study. Eur Arch Otorhinolaryngol.
3476 Ricci G, Patrizi A, Neri I, et al. (2003). Gianotti-Crosti syndrome and allergic background. Acta Derm Venereol.
3477 Rodriguez V, Nichols WL, Charlesworth JE, et al. (2003). Sebastian platelet syndrome: a hereditary macrothrombocytopenia. Mayo Clin Proc.
3478 Roodman S, Bothwell M, Tobias JD. (2003). Bradycardia with sevoflurane induction in patients with trisomy 21. Paediatr Anaesth.
3479 Rosefsky JB. (2003). Tonsillectomies and adenotonsillectomies--will the debate never be over?. Pediatrics.
3480 Rosen G. (2003). Identification and evaluation of obstructive sleep apnea prior to adenotonsillectomy in children: is there a problem?. Sleep Med.
3481 Ross AT, Kazahaya K, Tom LW. (2003). Revisiting outpatient tonsillectomy in young children. Otolaryngol Head Neck Surg.
3482 Rush MC, Simon MW. (2003). Occurrence of Epstein-Barr virus illness in children diagnosed with group A streptococcal pharyngitis. Clin Pediatr (Phila).
3483 Sader HS, Fritsche TR, Mutnick AH, et al. (2003). Contemporary evaluation of the in vitro activity and spectrum of cefdinir compared with other orally administered antimicrobials tested against common respiratory tract pathogens (2000-2002). Diagn Microbiol Infect Dis.
3484 Samman N, Mohammadi H, Xia J. (2003). Cephalometric norms for the upper airway in a healthy Hong Kong Chinese population. Hong Kong Med J.
3485 Sato M, Hotta O, Tomioka S, et al. (2003). Cohort study of advanced IgA nephropathy: efficacy and limitations of corticosteroids with tonsillectomy. Nephron Clin Pract.
3486 Sauermann R, Gattringer R, Graninger W, et al. (2003). Phenotypes of macrolide resistance of group A streptococci isolated from outpatients in Bavaria and susceptibility to 16 antibiotics. J Antimicrob Chemother.
3487 Schindler C, Krappweis J, Morgenstern I, et al. (2003). Prescriptions of systemic antibiotics for children in Germany aged between 0 and 6 years. Pharmacoepidemiol Drug Saf.
3488 Scholle S, Scholle HC, Kemper A, et al. (2003). First night effect in children and adolescents undergoing polysomnography for sleep-disordered breathing. Clin Neurophysiol.
3489 Selimoglu E, Selimoglu MA, Orbak Z. (2003). Does adenotonsillectomy improve growth in children with obstructive adenotonsillar hypertrophy?. J Int Med Res.
3490 Shaalan HF. (2003). What is the right size of the adenoid curette?. J Laryngol Otol.
3491 Shah RV, Racz GB. (2003). Pulsed mode radiofrequency lesioning to treat chronic post-tonsillectomy pain (secondary glossopharyngeal neuralgia). Pain Pract.
3492 Shapiro NL, Strocker AM, Bhattacharyya N. (2003). Risk factors for adenotonsillar hypertrophy in children following solid organ transplantation. Int J Pediatr Otorhinolaryngol.
3493 Shields JA, Shields CL, Freire JE, et al. (2003). Plaque radiotherapy for selected orbital malignancies: preliminary observations: the 2002 Montgomery Lecture, part 2. Ophthal Plast Reconstr Surg.
3494 Skinner LJ, Colreavy MP, Lang E, et al. (2003). Randomized controlled trial comparing argon plasma coagulation tonsillectomy with conventional techniques. J Laryngol Otol.
3495 Slovik Y, Tal A, Shapira Y, et al. (2003). Complications of adenotonsillectomy in children with OSAS younger than 2 years of age. Int J Pediatr Otorhinolaryngol.
3496 Sohn H, Rosenfeld RM. (2003). Evaluation of sleep-disordered breathing in children. Otolaryngol Head Neck Surg.
3497 Sørensen WT, Wagner N, Aarup AT, et al. (2003). Beneficial effect of low-dose peritonsillar injection of lidocaine-adrenaline before tonsillectomy. A placebo-controlled clinical trial. Auris, nasus, larynx.
3498 South M, Royle J, Starr M. (2003). A simple intervention to improve hospital antibiotic prescribing. Med J Aust.
3499 Spector A, Scheid S, Hassink S, et al. (2003). Adenotonsillectomy in the morbidly obese child. Int J Pediatr Otorhinolaryngol.
3500 Stenfors LE, Bye HM, Raisanen S. (2003). Noticeable differences in bacterial defence on tonsillar surfaces between bacteria-induced and virus-induced acute tonsillitis. Int J Pediatr Otorhinolaryngol.
3501 Strauchen JA, Miller LK. (2003). Lymphoid progenitor cells in human tonsils. Int J Surg Pathol.
3502 Suzuki K, Kawakatsu K, Hattori C, et al. (2003). Application of lingual tonsillectomy to sleep apnea syndrome involving lingual tonsils. Acta Otolaryngol Suppl.
3503 Suzuki K, Nishimura T, Baba S. (2003). Current status of bacterial resistance in the otolaryngology field: results from the Second Nationwide Survey in Japan. J Infect Chemother.
3504 Swarts JD, Bluestone CD. (2003). Eustachian tube function in older children and adults with persistent otitis media. Int J Pediatr Otorhinolaryngol.
3505 Takker U, Dzyublyk O, Busman T, et al. (2003). Comparison of 5 days of extended-release clarithromycin versus 10 days of penicillin V for the treatment of streptococcal pharyngitis/tonsillitis: results of a multicenter, double-blind, randomized study in adolescent and adult patients. Curr Med Res Opin.
3506 Tal A, Bar A, Leiberman A, et al. (2003). Sleep characteristics following adenotonsillectomy in children with obstructive sleep apnea syndrome. Chest.
3507 Tarasiuk A, Simon T, Regev U, et al. (2003). Willingness to pay for polysomnography in children with obstructive sleep apnea syndrome: a cost-benefit analysis. Sleep.
3508 Tarkkila P, Viitanen H, Mennander S, et al. (2003). Comparison of remifentanil versus ketamine for paediatric day case adenoidectomy. Acta Anaesthesiol Belg.
3509 Teng CL, Nurjahan MI, Hashim NA, et al. (2003). Upper respiratory tract infections: to what extent is the management evidence-based?. Med J Malaysia.
3510 Thompson JW, Ryan KW, Pinidiya SD, et al. (2003). Quality of care for children in commercial and Medicaid managed care. JAMA.
3511 Timmers-Raaijmaakers BC, Wolfs TF, Jansen NJ, et al. (2003). Invasive group A streptococcal infection after tonsillectomy. Pediatr Infect Dis J.
3512 Tisch M, Hengstermann F, Kraft K, et al. (2003). Follicular dendritic cell sarcoma of the tonsil: report of a rare case. Ear Nose Throat J.
3513 Tokumine J, Sugahara K, Ura M, et al. (2003). Lingual tonsil hypertrophy with difficult airway and uncontrollable bleeding. Anaesthesia.
3514 Tsang NM, Chang KP, Lin SY, et al. (2003). Detection of Epstein-Barr virus-derived latent membrane protein-1 gene in various head and neck cancers: is it specific for nasopharyngeal carcinoma?. Laryngoscope.
3515 Tsang WS, Marshall JN, van Hasselt CA. (2003). Peritonsillar abscess in a tonsillectomized patient. J Otolaryngol.
3516 Tubbs RS, Wellons JC, Blount JP, et al. (2003). Inclination of the odontoid process in the pediatric Chiari I malformation. J Neurosurg.
3517 Tyler DC, Pasquariello CA, Chen CH. (2003). Determining optimum operating room utilization. Anesth Analg.
3518 Tysnes OB. (2003). Risk of variant Creutzfeldt-Jakob disease and tonsillectomy. Eur Arch Otorhinolaryngol.
3519 Uruma Y, Suzuki K, Hattori H, et al. (2003). Obstructive sleep apnea syndrome in children. Acta Otolaryngol Suppl.
3520 Vaiman M, Eviatar E, Shlamkovich N, et al. (2003). Effect of modern fibrin glue on bleeding after tonsillectomy and adenoidectomy. Ann Otol Rhinol Laryngol.
3521 Valera FC, Travitzki LV, Mattar SE, et al. (2003). Muscular, functional and orthodontic changes in pre school children with enlarged adenoids and tonsils. Int J Pediatr Otorhinolaryngol.
3522 Van Den Akker EH, Rovers MM, Van Staaij BK, et al. (2003). Representativeness of trial populations: an example from a trial of adenotonsillectomy in children. Acta Otolaryngol.
3523 van den Akker EH, Schilder AG, Kemps YJ, et al. (2003). Current indications for (adeno)tonsillectomy in children: a survey in The Netherlands. Int J Pediatr Otorhinolaryngol.
3524 Van Staaij BK, Van Den Akker EH, De Haas Van Dorsser EH, et al. (2003). Does the tonsillar surface flora differ in children with and without tonsillar disease?. Acta Otolaryngol.
3525 Veivers D. (2003). Draining a peritonsillar abscess. Medicine Today.
3526 Ventureyra EC, Aziz HA, Vassilyadi M. (2003). The role of cine flow MRI in children with Chiari I malformation. Childs Nerv Syst.
3527 Verse T, Pirsig W, Stuck BA, et al. (2003). Recent developments in the treatment of obstructive sleep apnea. Am J Respir Med.
3528 Viitanen H, Tuominen N, Vaaraniemi H, et al. (2003). Analgesic efficacy of rectal acetaminophen and ibuprofen alone or in combination for paediatric day-case adenoidectomy. Br J Anaesth.
3529 Vineis P, Miligi L, Crosignani P, et al. (2003). Delayed infection, late tonsillectomy or adenoidectomy and adult leukaemia: a case-control study. Br J Cancer.
3530 Wali YA, al Okbi H, al Abri R. (2003). A comparison of two transfusion regimens in the perioperative management of children with sickle cell disease undergoing adenotonsillectomy. Pediatr Hematol Oncol.
3531 Weatherly RA, Mai EF, Ruzicka DL, et al. (2003). Identification and evaluation of obstructive sleep apnea prior to adenotonsillectomy in children: a survey of practice patterns. Sleep Med.
3532 Weider DJ, Baker GL, Salvatoriello FW. (2003). Dental malocclusion and upper airway obstruction, an otolaryngologist's perspective. Int J Pediatr Otorhinolaryngol.
3533 Werle AH, Nicklaus PJ, Kirse DJ, et al. (2003). A retrospective study of tonsillectomy in the under 2-year-old child: indications, perioperative management, and complications. Int J Pediatr Otorhinolaryngol.
3534 Westert GP, Smits JP, Polder JJ, et al. (2003). Community income and surgical rates in the Netherlands. J Epidemiol Community Health.
3535 Wilder-Smith A, Paton NI, Barkham TM, et al. (2003). Meningococcal carriage in Umra pilgrims returning from Saudi Arabia. J Travel Med.
3536 Williams MD, Brown HM. (2003). The adequacy of gross pathological examination of routine tonsils and adenoids in patients 21 years old and younger. Hum Pathol.
3537 Wilson JK, Al-Suwaidan SN, Krowchuk D, et al. (2003). Treatment of psoriasis in children: is there a role for antibiotic therapy and tonsillectomy?. Pediatr Dermatol.
3538 Windfuhr JP. (2003). Lethal post-tonsillectomy hemorrhage. Auris Nasus Larynx.
3539 Wing YK, Hui SH, Pak WM, et al. (2003). A controlled study of sleep related disordered breathing in obese children. Arch Dis Child.
3540 Wraige E, Ganesan V, Pohl KR. (2003). Arterial dissection complicating tonsillectomy. Dev Med Child Neurol.
3541 Wynn R, Rosenfeld RM. (2003). Outcomes in suction coagulator adenoidectomy. Arch Otolaryngol Head Neck Surg.
3542 Wysocka J, Hassmann E, Lipska A, et al. (2003). Naive and memory T cells in hypertrophied adenoids in children according to age. Int J Pediatr Otorhinolaryngol.
3543 Xie Y, Nishi S, Ueno M, et al. (2003). The efficacy of tonsillectomy on long-term renal survival in patients with IgA nephropathy. Kidney Int.
3544 Yadav SP, Dodeja OP, Gupta KB, et al. (2003). Pulmonary function tests in children with adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
3545 Yaremchuk K. (2003). Tonsillectomy by plasma-mediated ablation. Arch Otolaryngol Head Neck Surg.
3546 Yasan H, Dogru H, Tuz M, et al. (2003). Otitis media with effusion and histopathologic properties of adenoid tissue. Int J Pediatr Otorhinolaryngol.
3547 Yildirim I, Okur E, Ciragil P, et al. (2003). Bacteraemia during tonsillectomy. J Laryngol Otol.
3548 Yonekura A, Kawakatsu K, Suzuki K, et al. (2003). Laser midline glossectomy and lingual tonsillectomy as treatments for sleep apnea syndrome. Acta Otolaryngol Suppl.
3549 Yoshikai T, Ishimaru J, Satoh T, et al. (2003). The limitations of gallium scintigraphy in the differentiation between benign and malignant salivary gland mass lesions. Nucl Med Commun.
3550 Yu KK, White DR, Weissler MC, et al. (2003). Nontraumatic atlantoaxial subluxation (Grisel syndrome): a rare complication of otolaryngological procedures. Laryngoscope.
3551 Zakrzewska A, Kobos J, Gryczynska D. (2003). Evaluation of CD25, CD152, Fas-ligand expression in the adenoids of allergic and non-allergic children: a pilot study. Int J Pediatr Otorhinolaryngol.
3552 Zhang PC, Pang YT, Loh KS, et al. (2003). Comparison of histology between recurrent tonsillitis and tonsillar hypertrophy. Clin Otolaryngol Allied Sci.
3553 Zonato AI, Bittencourt LR, Martinho FL, et al. (2003). Association of systematic head and neck physical examination with severity of obstructive sleep apnea-hypopnea syndrome. Laryngoscope.
3554 Zuckerman RA, Whittington WL, Celum CL, et al. (2003). Factors associated with oropharyngeal human immunodeficiency virus shedding. J Infect Dis.
3555 Zwart S, Rovers MM, de Melker RA, et al. (2003). Penicillin for acute sore throat in children: randomised, double blind trial. BMJ.
3556 (2004). Preclinical vCJD: Prevalence higher than expected. Pharmaceutical Journal.
3557 Abe K, Miyazaki M, Shioshita K, et al. (2004). Clinical and immunohistochemical study of immunoglobulin A nephropathy (IgAN) before and after tonsillectomy. Acta Otolaryngol Suppl.
3558 Akagi H, Kosaka M, Hattori K, et al. (2004). Long-term results of tonsillectomy as a treatment for IgA nephropathy. Acta Otolaryngol Suppl.
3559 Akbas Y, Pata YS, Unal M, et al. (2004). The effect of fusafungine on post-operative pain and wound healing after pediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
3560 Akker EH, Sanders EAM, Rijkers GT, et al. (2004). Long-term effects of pediatric adenotonsillectomy on serum immunoglobulin levels. International journal of pediatric otorhinolaryngology.
3561 Alexander RJ, Kukreja R, Ford GR. (2004). Secondary post-tonsillectomy haemorrhage and informed consent. J Laryngol Otol.
3562 Ali S, El-Rayes BF, Heilbrun LK, et al. (2004). Cytochrome p450 and glutathione transferase expression in squamous cell cancer. Clin Cancer Res.
3563 Al-Shehri AM. (2004). Steroid therapy for post-tonsillectomy symptoms in adults: a randomized, placebo-controlled study. Ann Saudi Med.
3564 Altman JS, Senior B, Ransom E. (2004). The effect of electrocautery versus cold scalpel technique on the incidence of early postoperative tonsillar pillar dehiscence after uvulopalatopharyngoplasty with tonsillectomy. Laryngoscope.
3565 Ameli F, Castelnuovo P, Pagella F, et al. (2004). Nasal endoscopy in asthmatic children: clinical role in the diagnosis of rhinosinusitis. Rhinology.
3566 Andrews PJ, Latif A. (2004). Outpatient laser tonsillar ablation under local anaesthetic. Eur Arch Otorhinolaryngol.
3567 Arai YC, Fukunaga K, Hirota S, et al. (2004). The effects of chin lift and jaw thrust while in the lateral position on stridor score in anesthetized children with adenotonsillar hypertrophy. Anesth Analg.
3568 Archbold KH, Giordani B, Ruzicka DL, et al. (2004). Cognitive executive dysfunction in children with mild sleep-disordered breathing. Biol Res Nurs.
3569 Arruda JA, Costa CM, Tella Jr OI. (2004). Results of the treatment of syringomyelia associated with Chiari malformation: analysis of 60 cases. Arq Neuropsiquiatr.
3570 Atiq M, Masood F, Ikram M, et al. (2004). Reversible obstructive sleep apnea and right heart failure due to massive tonsillar hypertrophy. J Ayub Med Coll Abbottabad.
3571 Attygalle AD, Liu H, Shirali S, et al. (2004). Atypical marginal zone hyperplasia of mucosa-associated lymphoid tissue: a reactive condition of childhood showing immunoglobulin lambda light-chain restriction. Blood.
3572 Avior G, Fishman G, Leor A, et al. (2004). The effect of tonsillectomy and adenoidectomy on inattention and impulsivity as measured by the Test of Variables of Attention (TOVA) in children with obstructive sleep apnea syndrome. Otolaryngol Head Neck Surg.
3573 Azmy IA, Hurlstone DP, Butt TF, et al. (2004). Does surgical removal of mucosal associated lymphoid tissue protect against adult coeliac disease? A case controlled study. Dig Liver Dis.
3574 Bajracharya S, Pandey S, Shakya YL. (2004). Drug prescribing pattern and disease pattern in KMC Duwakot Health Center. Kathmandu Univ Med J (KUMJ).
3575 Batra K, Safaya A, Nair D, et al. (2004). Sore throat - a review of presentation and etiology. Indian J Otolaryngol Head Neck Surg.
3576 Batra YK, Al Qattan AR, Ali SS, et al. (2004). Assessment of tracheal intubating conditions in children using remifentanil and propofol without muscle relaxant. Paediatr Anaesth.
3577 Battiata AP, Pazos G. (2004). Grisel's syndrome: the two-hit hypothesis--a case report and literature review. Ear Nose Throat J.
3578 Bene MC, Faure GC, Hurault de Ligny B, et al. (2004). Clinical involvement of the tonsillar immune system in IgA nephropathy. Acta Otolaryngol Suppl.
3579 Bent JP, April MM, Ward RF, et al. (2004). Ambulatory powered intracapsular tonsillectomy and adenoidectomy in children younger than 3 years. Arch Otolaryngol Head Neck Surg.
3580 Bergendahl HT, Lonnqvist PA, Eksborg S, et al. (2004). Clonidine vs. midazolam as premedication in children undergoing adeno-tonsillectomy: a prospective, randomized, controlled clinical trial. Acta Anaesthesiol Scand.
3581 Billal DS, Hotomi M, Yamauchi K, et al. (2004). Macrolide-resistant genes of Streptococcus pyogenes isolated from the upper respiratory tract by polymerase chain reaction. J Infect Chemother.
3582 Birring SS, Passant C, Patel RB, et al. (2004). Chronic tonsillar enlargement and cough: preliminary evidence of a novel and treatable cause of chronic cough. Eur Respir J.
3583 Bjerrum L, Boada A, Cots JM, et al. (2004). Respiratory tract infections in general practice: considerable differences in prescribing habits between general practitioners in Denmark and Spain. Eur J Clin Pharmacol.
3584 Bozkurt MK, Calguner M. (2004). The efficacy of CO2 laser myringotomy in serous otitis media. Kulak Burun Bogaz Ihtis Derg.
3585 Brink AJ, Cotton MF, Feldman C, et al. (2004). Guideline for the management of upper respiratory tract infections. S Afr Med J.
3586 Brook I, Foote PA. (2004). Effect of antimicrobial therapy with amoxicillin and cefprozil on bacterial interference and beta-lactamase production in the adenoids. Ann Otol Rhinol Laryngol.
3587 Brown KA, Laferriere A, Moss IR. (2004). Recurrent hypoxemia in young children with obstructive sleep apnea is associated with reduced opioid requirement for analgesia. Anesthesiology.
3588 Buccheri A, Dilella G, Stella R. (2004). Rapid palatal expansion and pharyngeal space. Cephalometric evaluation. Prog Orthod.
3589 Buskens E, Staaij B, Akker E, et al. (2004). Costeffectiveness of childhood adenotonsillectomy: a randomised comparison with watchful waiting.
3590 Buttura da Prato E, Albanese M, Trevisiol L, et al. (2004). Eagle's syndrome secondary surgical treatment. Report of a case. Minerva Stomatol.
3591 Casey JR, Pichichero ME. (2004). Meta-analysis of cephalosporins versus penicillin for treatment of group A streptococcal tonsillopharyngitis in adults. Clin Infect Dis.
3592 Casey JR, Pichichero ME. (2004). Meta-analysis of cephalosporin versus penicillin treatment of group A streptococcal tonsillopharyngitis in children. Pediatrics.
3593 Castellarin A, Lipskey S, Sternberg P. (2004). Iatrogenic open globe eye injury following sinus surgery. Am J Ophthalmol.
3594 Cemek M, Caksen H, Cemek F, et al. (2004). Investigation of antioxidant status in children with acute otitis media and tonsillitis. Int J Pediatr Otorhinolaryngol.
3595 Ceran O, Aka S, Oztemel D, et al. (2004). The relationship of tonsillar hyperplasia and asthma in a group of asthmatic children. Int J Pediatr Otorhinolaryngol.
3596 Chan J, Akst LM, Eliachar I. (2004). The roles of the anterior tonsillar pillar and previous tonsillectomy on sleep-disordered breathing. Ear Nose Throat J.
3597 Charles J, Pan Y, Britt H. (2004). Trends in childhood illness and treatment in Australian general practice, 1971-2001. Med J Aust.
3598 Chau KW, Ng KK, Kwok KL, et al. (2004). Survey of children with obstructive sleep apnea syndrome in Hong Kong of China. Chin Med J (Engl).
3599 Chen HL, Chiou SS, Hsiao HP, et al. (2004). Respiratory adenoviral infections in children: a study of hospitalized cases in southern Taiwan in 2001--2002. J Trop Pediatr.
3600 Chervin RD, Burns JW, Subotic NS, et al. (2004). Correlates of respiratory cycle-related EEG changes in children with sleep-disordered breathing. Sleep.
3601 Chervin RD, Burns JW, Subotic NS, et al. (2004). Method for detection of respiratory cycle-related EEG changes in sleep-disordered breathing. Sleep.
3602 Chiang KH, Chang PY, Chou ASB, et al. (2004). Eagle's syndrome with 3-D reconstructed CT: Two cases report. Chinese Journal of Radiology.
3603 Choi MS, Ray R, Zhang Z, et al. (2004). IFN-gamma stimulates the expression of a novel secretoglobin that regulates chemotactic cell migration and invasion. J Immunol.
3604 Cinar F. (2004). Significance of asymptomatic tonsil asymmetry. Otolaryngol Head Neck Surg.
3605 Clement WA, Dempster JH. (2004). Implementation by Scottish otolaryngologists of the Scottish Intercollegiate Guidelines Network document Management of Sore Throats and the Indications for Tonsillectomy: four years on. J Laryngol Otol.
3606 Clement WA, Wales Y. (2004). Readability and content of postoperative tonsillectomy instructions given to patients in Scotland. Clin Otolaryngol Allied Sci.
3607 Constant I, Leport Y, Richard P, et al. (2004). Agitation and changes of Bispectral Index and electroencephalographic-derived variables during sevoflurane induction in children: clonidine premedication reduces agitation compared with midazolam. Br J Anaesth.
3608 Cote CJ, Sheldon SH. (2004). Obstructive sleep apnea and tonsillectomy: do we have a new indication for extended postoperative observation?. Can J Anaesth.
3609 Croxford R, Friedberg J, Coyte PC. (2004). Socio-economic status and surgery in children: myringotomies and tonsillectomies in Ontario, Canada, 1996-2000. Acta Paediatr.
3610 da Lilly-Tariah OB. (2004). Day-case adenotonsillectomy: suitable in the tropics?. Trop Doct.
3611 Demirbilek S, Togal T, Cicek M, et al. (2004). Effects of fentanyl on the incidence of emergence agitation in children receiving desflurane or sevoflurane anaesthesia. Eur J Anaesthesiol.
3612 Desikan SR, Meena NG. (2004). Do non-steroidal anti-inflammatory drugs increase the risk of bleeding after tonsillectomy?. Arch Dis Child.
3613 DiFrancesco RC, Junqueira PA, Trezza PM, et al. (2004). Improvement of bruxism after T & A surgery. Int J Pediatr Otorhinolaryngol.
3614 Dogruer ZN, Unal M, Eskandari G, et al. (2004). Malondialdehyde and antioxidant enzymes in children with obstructive adenotonsillar hypertrophy. Clin Biochem.
3615 Doner F, Yariktas M, Demirci M. (2004). The role of allergy in recurrent otitis media with effusion. J Investig Allergol Clin Immunol.
3616 Donnelly LF, Shott SR, LaRose CR, et al. (2004). Causes of persistent obstructive sleep apnea despite previous tonsillectomy and adenoidectomy in children with down syndrome as depicted on static and dynamic cine MRI. AJR Am J Roentgenol.
3617 Dsida R, Cote CJ. (2004). Nonsteroidal antiinflammatory drugs and hemorrhage following tonsillectomy: do we have the data?. Anesthesiology.
3618 Dundon B. (2004). The effect of dairy products on post-tonsillectomy recovery. Proquest Digital Dissertations (Source: MAI 43/03, p. 821, Jun 2005).
3619 Durr DG. (2004). Endoscopic electrosurgical adenoidectomy: technique and outcomes. J Otolaryngol.
3620 Economou S, Georgakis T, Roubos P, et al. (2004). Comparison of nasotracheal versus orotracheal intubation in tonsillectomy.
3621 Edmonds JL. (2004). Surgical and anesthetic management of patients with mitochondrial dysfunction. Mitochondrion.
3622 Egeli E, Harputluoglu U, Ozturk O, et al. (2004). Can post-adenotonsillectomy morbidity be reduced by intravenous 24 h hydration in pediatric patients following adenotonsillectomy?. Int J Pediatr Otorhinolaryngol.
3623 El-Naggar M, El-Baily S, Joseph KJ, et al. (2004). A comparative bacteriological study of surface versus core tonsil cultures in patients with chronic tonsillitis: Reliability and validity of throat swabs. Emirates Medical Journal.
3624 Elstraete AC, Lebrun T, Sandefo I, et al. (2004). Ketamine does not decrease postoperative pain after remifentanil-based anaesthesia for tonsillectomy in adults. Acta anaesthesiologica Scandinavica.
3625 Elverland HH, Aasand G, Miljeteig H, et al. (2004). Effects of tonsillectomy and adenoidectomy on hemoglobin and iron metabolism. Int J Pediatr Otorhinolaryngol.
3626 Engstrom S, Molstad S, Lindstrom K, et al. (2004). Excessive use of rapid tests in respiratory tract infections in Swedish primary health care. Scand J Infect Dis.
3627 Engstrom S, Molstad S, Nilsson G, et al. (2004). Data from electronic patient records are suitable for surveillance of antibiotic prescriptions for respiratory tract infections in primary health care. Scand J Infect Dis.
3628 Erler T, Paditz E. (2004). Obstructive sleep apnea syndrome in children: a state-of-the-art review. Treat Respir Med.
3629 Esmaeli B, Ahmadi MA, Youssef A, et al. (2004). Outcomes in patients with adenoid cystic carcinoma of the lacrimal gland. Ophthal Plast Reconstr Surg.
3630 Finkelstein Y, Talmi YP, Ophir D, et al. (2004). Laser cryptolysis for the treatment of halitosis. Otolaryngol Head Neck Surg.
3631 Ford JB, Henry RL, Sullivan EA. (2004). Comparison of selected reasons for hospitalization of children among children's/tertiary hospitals, Australia, 1996-97 and 1997-98. J Paediatr Child Health.
3632 Ford LC, Cruz RM. (2004). Bilateral glossopharyngeal nerve paralysis after tonsillectomy: case report and anatomic study. Laryngoscope.
3633 Friedman M, Ibrahim H, Lowenthal S, et al. (2004). Uvulopalatoplasty (UP2): a modified technique for selected patients. Laryngoscope.
3634 Friedman M, Ibrahim HZ, Vidyasagar R, et al. (2004). Z-palatoplasty (ZPP): a technique for patients without tonsils. Otolaryngol Head Neck Surg.
3635 Frosh A, Smith LC, Jackson CJ, et al. (2004). Analysis of 2000 consecutive UK tonsillectomy specimens for disease-related prion protein. Lancet.
3636 Fujimoto T, Okafuji T, Okafuji T, et al. (2004). Evaluation of a bedside immunochromatographic test for detection of adenovirus in respiratory samples, by comparison to virus isolation, PCR, and real-time PCR. J Clin Microbiol.
3637 Gaball CW, Bondy PC, Goufman DB, et al. (2004). Vioxx for adult post-tonsillectomy and UPPP pain: a randomized prospective controlled trial. Otolaryngology - Head and Neck Surgery.
3638 Garavello W, Romagnoli M, Sordo L, et al. (2004). Incidence of unexpected malignancies in routine tonsillectomy specimens in children. Laryngoscope.
3639 Garden AS, Asper JA, Morrison WH, et al. (2004). Is concurrent chemoradiation the treatment of choice for all patients with Stage III or IV head and neck carcinoma?. Cancer.
3640 Generali J, Cada DJ. (2004). Rofecoxib: Children, Postoperative Pain Management. Hospital Pharmacy.
3641 Georgalas C, Tolley N, Kanagalingam J. (2004). Measuring quality of life in children with adenotonsillar disease with the Child Health Questionnaire: a first U.K. study. Laryngoscope.
3642 Giger B, Bonanomi A, Odermatt B, et al. (2004). Human tonsillar tissue block cultures differ from autologous tonsillar cell suspension cultures in lymphocyte subset activation and cytokine gene expression. J Immunol Methods.
3643 Girolami A, Ruzzon E, Lombardi AM, et al. (2004). Thrombosis-free surgical procedures in severe (Homozygote) factor XII deficiency: report of four additional cases and literature review. Clin Appl Thromb Hemost.
3644 Go M, Kojima T, Takano K, et al. (2004). Expression and function of tight junctions in the crypt epithelium of human palatine tonsils. J Histochem Cytochem.
3645 Goins MR, Pitovski DZ. (2004). Posttonsillectomy taste distortion: a significant complication. Laryngoscope.
3646 Goldbart AD, Goldman JL, Li RC, et al. (2004). Differential expression of cysteinyl leukotriene receptors 1 and 2 in tonsils of children with obstructive sleep apnea syndrome or recurrent infection. Chest.
3647 Gozal D, O'Brien L, Row BW. (2004). Consequences of snoring and sleep disordered breathing in children. Pediatr Pulmonol Suppl.
3648 Guilleminault C, Abad VC. (2004). Obstructive Sleep Apnea. Curr Treat Options Neurol.
3649 Guilleminault C, Li K, Khramtsov A, et al. (2004). Breathing patterns in prepubertal children with sleep-related breathing disorders. Arch Pediatr Adolesc Med.
3650 Guilleminault C, Li K, Quo S, et al. (2004). A prospective study on the surgical outcomes of children with sleep-disordered breathing. Sleep.
3651 Guilleminault C, Li KK, Khramtsov A, et al. (2004). Sleep disordered breathing: surgical outcomes in prepubertal children. Laryngoscope.
3652 Gunduz K, Celenk P, Kayipmaz S. (2004). An unusual foreign body (suturing needle) in the tonsillar region. J Contemp Dent Pract.
3653 Gupta N, Mukherjee A, Moharana AK. (2004). Pediatric tonsillopharyngitis--an evaluation of cefprozil in Indian patients. Indian J Pediatr.
3654 Guthrie T, Hobbs CG, Davenport V, et al. (2004). Parenteral influenza vaccination influences mucosal and systemic T cell-mediated immunity in healthy adults. J Infect Dis.
3655 Hajoui O, Janani R, Tulic M, et al. (2004). Synthesis of IL-13 by human B lymphocytes: regulation and role in IgE production. J Allergy Clin Immunol.
3656 Hall DJ, Littlefield PD, Birkmire-Peters DP, et al. (2004). Radiofrequency ablation versus electrocautery in tonsillectomy. Otolaryngology--head and neck surgery.
3657 Hanafy MA, El-Zahaby HM, Swellam AM. (2004). The effect of dexmedetomidine on the emergence agitation associated with desflurane anaesthesia in children. Egyptian Journal of Anaesthesia.
3658 Haque SN, Malik S, Hamirani M. (2004). Comparison of ketamine and butorphanol for analgesia after tonsillectomy in children. Annals of Abbasi Shaheed Hospital and Karachi Medical and Dental College.
3659 Hart S, Horsman JM, Radstone CR, et al. (2004). Localised extranodal lymphoma of the head and neck: the Sheffield Lymphoma Group experience (1971-2000). Clin Oncol (R Coll Radiol).
3660 Hassmann E, Skotnicka B, Baczek M, et al. (2004). Laser myringotomy in otitis media with effusion: long-term follow-up. Eur Arch Otorhinolaryngol.
3661 Helgadottir HL, Wilson ME. (2004). Temperament and pain in 3 to 7-year-old children undergoing tonsillectomy. J Pediatr Nurs.
3662 Heshmati F, Hasani Afshar A, Mahoori A, et al. (2004). High intravenous fluid therapy prevents post-tonsillectomy nausea and vomiting. Iranian Journal of Medical Sciences.
3663 Hessel NS, Vries N. (2004). Increase of the apnoea-hypopnoea index after uvulopalatopharyngoplasty: analysis of failure. Clin Otolaryngol Allied Sci.
3664 Hiller A, Silvanto M, Savolainen S, et al. (2004). Propacetamol and diclofenac alone and in combination for analgesia after elective tonsillectomy. Acta Anaesthesiol Scand.
3665 Hilton DA, Ghani AC, Conyers L, et al. (2004). Prevalence of lymphoreticular prion protein accumulation in UK tissue samples. J Pathol.
3666 Hilton M. (2004). Tonsillectomy technique--tradition versus technology. Lancet.
3667 Hotta O. (2004). Tonsillectomy combined with steroid pulse therapy: a curative therapy for IgA nephropathy. Acta Otolaryngol Suppl.
3668 Hotta O. (2004). Use of corticosteroids, other immunosuppressive therapies, and tonsillectomy in the treatment of IgA nephropathy. Semin Nephrol.
3669 Hultcrantz E, Ericsson E, Graf J. (2004). Intracapsular tonsillectomy with RF-surgery versus regular tonsillectomy. One year results. International journal of pediatric otorhinolaryngology.
3670 Huth MM, Broome ME, Good M. (2004). Imagery reduces children's post-operative pain. Pain.
3671 Isaacson G. (2004). Pediatric intracapsular tonsillectomy with bipolar electrosurgical scissors. Ear Nose Throat J.
3672 Ivarsson M, Lundberg C, Quiding-Jarbrink M. (2004). Antibody production directed against pneumococci by immunocytes in the adenoid surface secretion. Int J Pediatr Otorhinolaryngol.
3673 Jereczek-Fossa BA, Jassem J, Orecchia R. (2004). Cervical lymph node metastases of squamous cell carcinoma from an unknown primary. Cancer Treat Rev.
3674 Kaditis AG, Finder J, Alexopoulos EI, et al. (2004). Sleep-disordered breathing in 3,680 Greek children. Pediatr Pulmonol.
3675 Kafetzis DA, Liapi G, Tsolia M, et al. (2004). Failure to eradicate Group A beta-haemolytic streptococci (GABHS) from the upper respiratory tract after antibiotic treatment. Int J Antimicrob Agents.
3676 Kararmaz A, Kaya S, Turhanoglu S, et al. (2004). Oral ketamine premedication can prevent emergence agitation in children after desflurane anaesthesia. Paediatr Anaesth.
3677 Kasenomm P, Mesila I, Piirsoo A, et al. (2004). Macroscopic oropharyngeal signs indicating impaired defensive function of palatine tonsils in adults suffering from recurrent tonsillitis. APMIS.
3678 Kataoka T, Enomoto F, Kim R, et al. (2004). The effect of surgical treatment of obstructive sleep apnea syndrome on the plasma TNF-alpha levels. Tohoku J Exp Med.
3679 Keles E, Gok U, Aral M, et al. (2004). The relationship between preoperative serum immunoglobulin levels and the development of bacteremia after tonsillectomy. Kulak Burun Bogaz Ihtis Derg.
3680 Kennedy JD, Blunden S, Hirte C, et al. (2004). Reduced neurocognition in children who snore. Pediatr Pulmonol.
3681 Koivunen P, Uhari M, Luotonen J, et al. (2004). Adenoidectomy versus chemoprophylaxis and placebo for recurrent acute otitis media in children aged under 2 years: randomised controlled trial. BMJ.
3682 Kokemueller H, Swennen G, Brueggemann N, et al. (2004). Epithelial malignancies of the salivary glands: clinical experience of a single institution-a review. Int J Oral Maxillofac Surg.
3683 Koomson A, Morin I, Brouillette R, et al. (2004). Children with severe OSAS who have adenotonsillectomy in the morning are less likely to have postoperative desaturation than those operated in the afternoon. Can J Anaesth.
3684 Kreimer AR, Alberg AJ, Viscidi R, et al. (2004). Gender differences in sexual biomarkers and behaviors associated with human papillomavirus-16, -18, and -33 seroprevalence. Sex Transm Dis.
3685 Krishna P, LaPage MJ, Hughes LF, et al. (2004). Current practice patterns in tonsillectomy and perioperative care. Int J Pediatr Otorhinolaryngol.
3686 Ku CC, Zerboni L, Ito H, et al. (2004). Varicella-zoster virus transfer to skin by T Cells and modulation of viral replication by epidermal cell interferon-alpha. J Exp Med.
3687 Kubba H, Swan IR, Gatehouse S. (2004). The Glasgow Children's Benefit Inventory: a new instrument for assessing health-related benefit after an intervention. Ann Otol Rhinol Laryngol.
3688 Kumar TV, Kuriakose S. (2004). Ultrasonographic evaluation of effectiveness of circumoral muscle exercises in adenotonsillectomized children. J Clin Pediatr Dent.
3689 Kumar VV, Kumar NV, Isaacson G. (2004). Superstition and post-tonsillectomy hemorrhage. Laryngoscope.
3690 Kussick SJ, Kalnoski M, Braziel RM, et al. (2004). Prominent clonal B-cell populations identified by flow cytometry in histologically reactive lymphoid proliferations. Am J Clin Pathol.
3691 Lake AP, Khater M. (2004). Effects of postoperative nonsteroidal antiinflammatory drugs on bleeding risk after tonsillectomy. Anesthesiology.
3692 Langton Hewer SC, Langton Hewer CD, Pamula Y, et al. (2004). Adenotonsillectomy in children with mild symptoms: watchful waiting may deny children opportunity for development. Bmj.
3693 Lee KC, Bent JP, Dolitsky JN, et al. (2004). Surgical advances in tonsillectomy: report of a roundtable discussion. Ear Nose Throat J.
3694 Lee MS, Montague ML, Hussain SS. (2004). Post-tonsillectomy hemorrhage: cold versus hot dissection. Otolaryngol Head Neck Surg.
3695 Leighton S, Drake AF. (2004). Airway considerations in craniofacial patients. Oral Maxillofac Surg Clin North Am.
3696 Lemos P. (2004). Ambulatory surgery in Portugal: The 2003 APCA report. Ambulatory Surgery.
3697 Leontidou A, Papadopoulou K, Vlachtsis K, et al. (2004). Child's cardiac tumour unmasked during tonsillectomy. Eur J Anaesthesiol.
3698 Li AM, Chan DF, Fok TF, et al. (2004). Childhood obstructive sleep apnoea: an update. Hong Kong Med J.
3699 Li HY, Wang PC, Hsu CY, et al. (2004). Same-stage palatopharyngeal and hypopharyngeal surgery for severe obstructive sleep apnea. Acta Otolaryngol.
3700 Li Y, Chiaravalloti ND, Hillary FG, et al. (2004). Differential cerebellar activation on functional magnetic resonance imaging during working memory performance in persons with multiple sclerosis. Arch Phys Med Rehabil.
3701 Lichtenberger G. (2004). Development of a new method and device for securing haemostasis during transoral surgery: in vitro and cadaver experiments. Eur Arch Otorhinolaryngol.
3702 Lim WK, Sdralis T. (2004). Regression of a sphenochoanal polyp in a child. Laryngoscope.
3703 Limonadi FM, Selden NR. (2004). Dura-splitting decompression of the craniocervical junction: reduced operative time, hospital stay, and cost with equivalent early outcome. J Neurosurg.
3704 Lindbaek M, Hoiby EA, Lermark G, et al. (2004). Predictors for spread of clinical group A streptococcal tonsillitis within the household. Scand J Prim Health Care.
3705 Listorti N, Gammarota FV, Del Pezzo C, et al. (2004). Nonobstetric surgical abdominal emergencies in pregnancy: Inflammatory bowel disease: A case report. Italian Journal of Gynaecology and Obstetrics.
3706 Liu CH, Lin CD, Cheng YK, et al. (2004). Deep neck infection in children. Acta Paediatr Taiwan.
3707 Low DE, Brown S, Felmingham D. (2004). Clinical and bacteriological efficacy of the ketolide telithromycin against isolates of key respiratory pathogens: a pooled analysis of phase III studies. Clin Microbiol Infect.
3708 Luna-Ortiz K, Guemes-Meza A, Villavicencio-Valencia V, et al. (2004). Lip cancer experience in Mexico. An 11-year retrospective study. Oral Oncol.
3709 Luntz M, Teszler CB, Shpak T. (2004). Cochlear implantation in children with otitis media: second stage of a long-term prospective study. Int J Pediatr Otorhinolaryngol.
3710 Macchi V, Porzionato A, Parenti A, et al. (2004). The course of the posterior inferior cerebellar artery may be related to its level of origin. Surg Radiol Anat.
3711 Mahony D, Karsten A, Linder-Aronson S. (2004). Effects of adenoidectomy and changed mode of breathing on incisor and molar dentoalveolar heights and anterior face heights. Aust Orthod J.
3712 Malmgren W, Akeson J. (2004). Similar excitation after sevoflurane anaesthesia in young children given rectal morphine or midazolam as premedication. Acta Anaesthesiol Scand.
3713 Marques VC, Anselmo-Lima WT. (2004). Pre- and postoperative evaluation by acoustic rhinometry of children submitted to adenoidectomy or adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
3714 Marrone O, Insalaco G, Salvaggio A. (2004). Adenotonsillectomy and sleep apnea in children. Chest.
3715 Martinet W, Abbeloos V, Van Acker N, et al. (2004). Western blot analysis of a limited number of cells: a valuable adjunct to proteome analysis of paraffin wax-embedded, alcohol-fixed tissue after laser capture microdissection. J Pathol.
3716 Maryn Y, Van Lierde K, De Bodt M, et al. (2004). The effects of adenoidectomy and tonsillectomy on speech and nasal resonance. Folia Phoniatr Logop.
3717 Mathiasen RA, Cruz RM. (2004). Prospective, randomized, controlled clinical trial of a novel matrix hemostatic sealant in children undergoing adenoidectomy. Otolaryngol Head Neck Surg.
3718 Matutani S, Honma R, Adachi M, et al. (2004). Clinical observation of palatine tonsils with IgA nephropathy. Acta Otolaryngol Suppl.
3719 Mehanna H, Rejali D, Murray A. (2004). Suspending tonsillectomy: the effects on primary and secondary acute care in Scotland. Scott Med J.
3720 Mehta D, Wild DC, Philpott CM, et al. (2004). Coblation versus dissection tonsillectomy. Clinical otolaryngology and allied sciences.
3721 Mendenhall WM, Morris CG, Amdur RJ, et al. (2004). Radiotherapy alone or combined with surgery for adenoid cystic carcinoma of the head and neck. Head Neck.
3722 Mesolella M, Cimmino M, Di Martino M, et al. (2004). Tonsillolith. Case report and review of the literature. Acta Otorhinolaryngol Ital.
3723 Meyer JE, Jeckstrom W, Ross DA, et al. (2004). Incidence and clinical background of posttonsillectomy bleeding related blood transfusion over 12 years. Otolaryngol Pol.
3724 Mistry D, Kelly G. (2004). Consent for tonsillectomy. Clin Otolaryngol Allied Sci.
3725 Mitchell RB, Kelly J. (2004). Outcome of adenotonsillectomy for severe obstructive sleep apnea in children. Int J Pediatr Otorhinolaryngol.
3726 Mitchell RB, Kelly J. (2004). Adenotonsillectomy for obstructive sleep apnea in obese children. Otolaryngol Head Neck Surg.
3727 Mitchell RB, Kelly J, Call E, et al. (2004). Long-term changes in quality of life after surgery for pediatric obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
3728 Mitchell RB, Kelly J, Call E, et al. (2004). Quality of life after adenotonsillectomy for obstructive sleep apnea in children. Arch Otolaryngol Head Neck Surg.
3729 Mlynarek A, Tewfik MA, Hagr A, et al. (2004). Lateral neck radiography versus direct video rhinoscopy in assessing adenoid size. J Otolaryngol.
3730 Modrzynski M, Mierzwinski J, Zawisza E, et al. (2004). Acoustic rhinometry in the assessment of adenoid hypertrophy in allergic children. Med Sci Monit.
3731 Mohan S, Dharamraj K, Dindial R, et al. (2004). Physician behaviour for antimicrobial prescribing for paediatric upper respiratory tract infections: a survey in general practice in Trinidad, West Indies. Ann Clin Microbiol Antimicrob.
3732 Montague ML, Lee MS, Hussain SS. (2004). Post-tonsillectomy haemorrhage: reusable and disposable instruments compared. Eur Arch Otorhinolaryngol.
3733 Moorthy R, Khan H. (2004). Adenotonsillectomy in children with mild symptoms: watchful waiting is appropriate. Bmj.
3734 Nadig SK, Back GW, Uppal S, et al. (2004). A blinded in vitro comparison of five sets of bipolar diathermy forceps. Clin Otolaryngol Allied Sci.
3735 Navarro R, Olavarria G, Seshadri R, et al. (2004). Surgical results of posterior fossa decompression for patients with Chiari I malformation. Childs Nerv Syst.
3736 Neri G, Mennucci E, Ortore R, et al. (2004). Rhinopharynx endoscopy in the diagnosis of chronic otitis media with effusion in infancy. Acta Otorhinolaryngol Ital.
3737 Nguyen LH, Manoukian JJ, Sobol SE, et al. (2004). Similar allergic inflammation in the middle ear and the upper airway: evidence linking otitis media with effusion to the united airways concept. J Allergy Clin Immunol.
3738 Nguyen LH, Manoukian JJ, Tewfik TL, et al. (2004). Evidence of allergic inflammation in the middle ear and nasopharynx in atopic children with otitis media with effusion. J Otolaryngol.
3739 Nguyen LH, Manoukian JJ, Yoskovitch A, et al. (2004). Adenoidectomy: selection criteria for surgical cases of otitis media. Laryngoscope.
3740 Nishi S, Xie Y, Ueno M, et al. (2004). A clinicopathological study on the long-term efficacy of tonsillectomy in patients with IgA nephropathy. Acta Otolaryngol Suppl.
3741 Nixon GM, Kermack AS, Davis GM, et al. (2004). Planning adenotonsillectomy in children with obstructive sleep apnea: the role of overnight oximetry. Pediatrics.
3742 Norrby SR, Quinn J, Rangaraju M, et al. (2004). Evaluation of 5-day therapy with telithromycin, a novel ketolide antibacterial, for the treatment of tonsillopharyngitis. Clin Microbiol Infect.
3743 Obaid MA, Yusuf A. (2004). Surgical management of epithelial parotid tumours. J Coll Physicians Surg Pak.
3744 Ohira H, Rai T, Takiguchi J, et al. (2004). Six cases of primary biliary cirrhosis complicated by psoriasis. Hepatology Research.
3745 Oluwasanmi AF. (2004). Unusual complication of tonsillectomy: taste disturbance and the lingual branch of the glossopharyngeal nerve. J Laryngol Otol.
3746 Ong YK, Goh YH, Lee YL. (2004). Peritonsillar infections: local experience. Singapore Med J.
3747 Otters HB, van der Wouden JC, Schellevis FG, et al. (2004). Trends in prescribing antibiotics for children in Dutch general practice. J Antimicrob Chemother.
3748 Ozdemir H, Altin R, Sogut A, et al. (2004). Craniofacial differences according to AHI scores of children with obstructive sleep apnoea syndrome: cephalometric study in 39 patients. Pediatr Radiol.
3749 Pagel JF, Snyder S, Dawson D. (2004). Obstructive sleep apnea in sleepy pediatric psychiatry clinic patients: polysomnographic and clinical correlates. Sleep Breath.
3750 Pai PC, Tsang NM, Tseng CK, et al. (2004). Prevalence of LMP-1 gene in tonsils and non-neoplastic nasopharynxes by nest-polymerase chain reaction in Taiwan. Head Neck.
3751 Pang KP, Balakrishnan A. (2004). Paediatric obstructive sleep apnoea: is a polysomnogram always necessary?. J Laryngol Otol.
3752 Park AH, Pappas AL, Fluder E, et al. (2004). Effect of perioperative administration of ropivacaine with epinephrine on postoperative pediatric adenotonsillectomy recovery. Arch Otolaryngol Head Neck Surg.
3753 Park HS, Costalonga M, Reinhardt RL, et al. (2004). Primary induction of CD4 T cell responses in nasal associated lymphoid tissue during group A streptococcal infection. Eur J Immunol.
3754 Passali D, Damiani V, Passali GC, et al. (2004). Structural and immunological characteristics of chronically inflamed adenotonsillar tissue in childhood. Clin Diagn Lab Immunol.
3755 Passos CA, Altemani A, Nicola JH, et al. (2004). Histopathological evaluation in biopsies of palatine tonsils submitted to cryptolysis by coagulation with CO2 laser for treatment of chronic caseous tonsillitis. Photomed Laser Surg.
3756 Patel NJ, Hansen A, Merati AL, et al. (2004). STAT3 activation in recurrent respiratory papillomatosis. Arch Otolaryngol Head Neck Surg.
3757 Peterson J, Losek JD. (2004). Post-tonsillectomy hemorrhage and pediatric emergency care. Clin Pediatr (Phila).
3758 Pirelli P, Saponara M, Guilleminault C. (2004). Rapid maxillary expansion in children with obstructive sleep apnea syndrome. Sleep.
3759 Price DL, Orvidas LJ, Weaver AL, et al. (2004). Efficacy of adenoidectomy in the treatment of nasal and middle ear symptoms in children with Down syndrome. Int J Pediatr Otorhinolaryngol.
3760 Przewozny T, Stankiewicz C. (2004). Neoplasms of the parotid gland in northern Poland, 1991-2000: an epidemiologic study. Eur Arch Otorhinolaryngol.
3761 Rabinovitch N, Gelfand EW. (2004). Expression of functional activating and inhibitory Fcgamma receptors on human B cells. Int Arch Allergy Immunol.
3762 Ramadan HH. (2004). Surgical management of chronic sinusitis in children. Laryngoscope.
3763 Ranin L, Opavski N, Djukic S, et al. (2004). Epidemiology of diseases caused by Streptococcus pyogenes in Serbia during a nine-year period (1991-1999). Indian J Med Res.
3764 Rasche FM, Sailer LC, Czock D, et al. (2004). Tonsillectomy, high dose immunoglobulins, and cyclophosphamide in progressive IgA-nephropathy. Acta Otolaryngol Suppl.
3765 Rassin M, Gutman Y, Silner D. (2004). Developing a computer game to prepare children for surgery. AORN J.
3766 Rembold CM, Suratt PM. (2004). Children with obstructive sleep-disordered breathing generate high-frequency inspiratory sounds during sleep. Sleep.
3767 Reuben SS, Connelly NR. (2004). The perioperative use of cyclooxygenase-2 selective nonsteroidal antiinflammatory drugs may offer a safer alternative. Anesthesiology.
3768 Rideout B, Shaw GY. (2004). Tonsillectomy using the Colorado microdissection needle: a prospective series and comparative technique review. South Med J.
3769 Rihkanen H, Carpen O, Roivainen M, et al. (2004). Rhinovirus in adenoid tissue. Int J Pediatr Otorhinolaryngol.
3770 Rob MI, Westbrook JI, Taylor R, et al. (2004). Increased rates of ENT surgery among young children: have clinical guidelines made a difference?. J Paediatr Child Health.
3771 Robb PJ. (2004). Re: Increased post-operative haemorrhage seen in adult coblation tonsillectomy. J Laryngol Otol.
3772 Robbins KT, Samant S, Vieira F, et al. (2004). Presurgical cytoreduction of oral cancer using intra-arterial cisplatin and limited concomitant radiation therapy (Neo-RADPLAT). Arch Otolaryngol Head Neck Surg.
3773 Rosenfeld RM, Culpepper L, Doyle KJ, et al. (2004). Clinical practice guideline: Otitis media with effusion. Otolaryngol Head Neck Surg.
3774 Rudack C, Jorg S, Sachse F. (2004). Biologically active neutrophil chemokine pattern in tonsillitis. Clin Exp Immunol.
3775 Sabiee SA. (2004). Dexamethasone-low dose ketamine combination versus droperidol low dose ketamine. A comparative study for their effect on postoperative nausea and vomiting and swallowing evoked pain after paediatric adenotonsillectomy. Scientific Journal of Al-Azhar Medical Faculty [Girls].
3776 Sakuragi T, Yasumoto M, Higa K, et al. (2004). Inadvertent intravenous administration of a high dose of ephedrine. J Cardiothorac Vasc Anesth.
3777 Sampaio ALL, Oliveira CA. (2004). Evaluation of postoperative morbidity in pediatric tonsillectomy with sucralfate. Otolaryngology and head and neck surgery.
3778 Sanz E, Hernandez MA, Ratchina S, et al. (2004). Drug utilisation in outpatient children. A comparison among Tenerife, Valencia, and Barcelona (Spain), Toulouse (France), Sofia (Bulgaria), Bratislava (Slovakia) and Smolensk (Russia). Eur J Clin Pharmacol.
3779 Satoh K, Nagata J, Shomura K, et al. (2004). Morphological evaluation of changes in velopharyngeal function following maxillary distraction in patients with repaired cleft palate during mixed dentition. Cleft Palate Craniofac J.
3780 Saunders NC, Hartley BE, Sell D, et al. (2004). Velopharyngeal insufficiency following adenoidectomy. Clin Otolaryngol Allied Sci.
3781 Schechter MS. (2004). Snoring: investigations guidelines. Pediatr Pulmonol Suppl.
3782 Scholz H. (2004). Streptococcal-A tonsillopharyngitis: a 5-day course of cefuroxime axetil versus a 10-day course of penicillin V. results depending on the children's age. Chemotherapy.
3783 Schrey A, Pulkkinen J, Fremling C, et al. (2004). Ultrasonically activated scalpel compared with electrocautery in tonsillectomy. ORL J Otorhinolaryngol Relat Spec.
3784 Schulz-Ertner D, Nikoghosyan A, Thilmann C, et al. (2004). Results of carbon ion radiotherapy in 152 patients. Int J Radiat Oncol Biol Phys.
3785 Shah SA, Ghani R. (2004). Frequency of post-tonsillectomy haemorrhage following tonsillectomy with bipolar diathermy--an experience at Ayub Teaching Hospital, Abbottabad. J Ayub Med Coll Abbottabad.
3786 Shahzad A. (2004). Diathermy and tonsillectomy: criticism of NICE. J R Soc Med.
3787 Shapiro J. (2004). Doctoring the ear, nose, and throat. Harv Health Lett.
3788 Shatz A. (2004). Indications and outcomes of adenoidectomy in infancy. Ann Otol Rhinol Laryngol.
3789 Sheahan P, Miller I, Colreavy M, et al. (2004). The ultrasonically activated scalpel versus bipolar diathermy for tonsillectomy: a prospective, randomized trial. Clin Otolaryngol Allied Sci.
3790 Sheeran PW, Rose JB, Fazi LM, et al. (2004). Rofecoxib administration to paediatric patients undergoing adenotonsillectomy. Paediatr Anaesth.
3791 Shimizu T, Niizeki H, Takeuchi O, et al. (2004). Induction of macrophage migration inhibitory factor precedes the onset of acute tonsillitis. Mediators Inflamm.
3792 Shinhar S, Scotch BM, Belenky W, et al. (2004). Harmonic scalpel tonsillectomy versus hot electrocautery and cold dissection: an objective comparison. Ear Nose Throat J.
3793 Shott SR, Donnelly LF. (2004). Cine magnetic resonance imaging: evaluation of persistent airway obstruction after tonsil and adenoidectomy in children with Down syndrome. Laryngoscope.
3794 Siddiqui RU, Rasheed K, Rafique M. (2004). Tonsillectomy-control of hemorrhage silk ligation v/s bipolar diathermy. Pakistan Journal of Otolaryngology, Head and Neck Surgery.
3795 Silverman DA, Carlson TP, Khuntia D, et al. (2004). Role for postoperative radiation therapy in adenoid cystic carcinoma of the head and neck. Laryngoscope.
3796 Singh B. (2004). Bilateral occipital neuropathy, not so rare. Acta Anaesthesiol Scand.
3797 Skinner LJ, Colreavy MP, Timon CI. (2004). Argon plasma coagulation in the treatment of tonsil remnants. Rev Laryngol Otol Rhinol (Bord).
3798 Somdas MA, Senturk M, Ketenci I, et al. (2004). Efficacy of bupivacaine for post-tonsillectomy pain: a study with the intra-individual design. Int J Pediatr Otorhinolaryngol.
3799 Sorin A, Bent JP, April MM, et al. (2004). Complications of microdebrider-assisted powered intracapsular tonsillectomy and adenoidectomy. Laryngoscope.
3800 Sritippayawan S, Desudchit T, Prapphal N, et al. (2004). Validity of tidal breathing flow volume loops in diagnosing obstructive sleep apnea in young children with adenotonsillar hypertrophy: a preliminary study. J Med Assoc Thai.
3801 Stevens MH, Stevens DC. (2004). Intracapsular adult tonsillectomy with a microdebrider.
3802 Stewart AE, Brewster DF, Bernstein PE. (2004). Subcutaneous emphysema and pneumomediastinum complicating tonsillectomy. Arch Otolaryngol Head Neck Surg.
3803 Sunaga H, Oh M, Takahashi N, et al. (2004). Infection of Haemophilus parainfluenzae in tonsils is associated with IgA nephropathy. Acta Otolaryngol Suppl.
3804 Sutters KA, Miaskowski C, Holdridge-Zeuner D, et al. (2004). A randomized clinical trial of the effectiveness of a scheduled oral analgesic dosing regimen for the management of postoperative pain in children following tonsillectomy. Pain.
3805 Suzuki M, Ogawa H, Okabe S, et al. (2004). The effect of upper airway structural changes on central chemosensitivity in obstructive sleep apnea-hypopnea. Sleep Breath.
3806 Syrogiannopoulos GA, Bozdogan B, Grivea IN, et al. (2004). Two dosages of clarithromycin for five days, amoxicillin/clavulanate for five days or penicillin V for ten days in acute group A streptococcal tonsillopharyngitis. Pediatr Infect Dis J.
3807 Takahara M, Kishibe K, Nozawa H, et al. (2004). T-cell repertoire in the tonsils of patients with IgA nephropathy. Acta Otolaryngol Suppl.
3808 Taneja MK. (2004). Blunt dissection to bipolar forcep tonsillectomy- a comparision. Indian J Otolaryngol Head Neck Surg.
3809 Tarantino V, D'Agostino R, Melagrana A, et al. (2004). Safety of electronic molecular resonance adenoidectomy. Int J Pediatr Otorhinolaryngol.
3810 Teng CL, Achike FI, Phua KL, et al. (2004). General and URTI-specific antibiotic prescription rates in a Malaysian primary care setting. Int J Antimicrob Agents.
3811 Terk AR, Levine SB. (2004). Radiofrequency volume tissue reduction of the tonsils: case report and histopathologic findings. Ear Nose Throat J.
3812 TJ OL, Rowe M. (2004). Electrocautery versus cold knife technique adenotonsillectomy: a cost analysis. Otolaryngol Head Neck Surg.
3813 Toftgaard C. (2004). Danish association of day surgery. Ambulatory Surgery.
3814 Toker A, Shvarts S, Perry ZH, et al. (2004). Clinical guidelines, defensive medicine, and the physician between the two. Am J Otolaryngol.
3815 Tran KD, Koprowska IA, Rao S, et al. (2004). Myringotomy and tympanostomy tube placement in children with sickle cell disease. Int J Pediatr Otorhinolaryngol.
3816 Triantaphyllidou IE, Mastronikolis NS, Papadas TA, et al. (2004). HPLC identification of oversulphated chondroitin as the major glycosaminoglycan of human tonsils. Biomed Chromatogr.
3817 Tsui BC, Wagner A, Cave D, et al. (2004). The incidence of laryngospasm with a “no touch” extubation technique after tonsillectomy and adenoidectomy. Anesth Analg.
3818 Tubbs RS, Iskandar BJ, Bartolucci AA, et al. (2004). A critical analysis of the Chiari 1.5 malformation. J Neurosurg.
3819 Tubbs RS, Rutledge SL, Kosentka A, et al. (2004). Chiari I malformation and neurofibromatosis type 1. Pediatr Neurol.
3820 Tubbs RS, Webb DB, Oakes WJ. (2004). Persistent syringomyelia following pediatric Chiari I decompression: radiological and surgical findings. J Neurosurg.
3821 Tuncer U, Aydogan B, Soylu L, et al. (2004). Chronic rhinosinusitis and adenoid hypertrophy in children. Am J Otolaryngol.
3822 Tzifa KT, Skinner DW. (2004). A survey on the management of reactionary haemorrhage following adenoidectomy in the UK and our practice. Clin Otolaryngol Allied Sci.
3823 Umuroglu T, Eti Z, Ciftci H, et al. (2004). Analgesia for adenotonsillectomy in children: a comparison of morphine, ketamine and tramadol. Paediatr Anaesth.
3824 Ungkanont K, Damrongsak S. (2004). Effect of adenoidectomy in children with complex problems of rhinosinusitis and associated diseases. Int J Pediatr Otorhinolaryngol.
3825 Valtonen H, Qvarnberg Y, Blomgren K. (2004). Patient contact with healthcare professionals after elective tonsillectomy. Acta Otolaryngol.
3826 Van Den Akker EH, Hoes AW, Burton MJ, et al. (2004). Large international differences in (adeno)tonsillectomy rates. Clin Otolaryngol Allied Sci.
3827 van der Marel CD, Anderson BJ, Romsing J, et al. (2004). Diclofenac and metabolite pharmacokinetics in children. Paediatr Anaesth.
3828 van Toorn R, Weyers HH, Schoeman JF. (2004). Distinguishing PANDAS from Sydenham's chorea: case report and review of the literature. Eur J Paediatr Neurol.
3829 Vazquez JC, Montes FM, Rivera CA, et al. (2004). Clinical predictors of sleep disordered breathing in children at moderate altitude. Arch Med Res.
3830 Walker P, Whitehead B, Rowley M. (2004). Criteria for elective admission to the paediatric intensive care unit following adenotonsillectomy for severe obstructive sleep apnoea. Anaesth Intensive Care.
3831 Walner DL. (2004). Pediatric tonsillectomy: coblation vs electrocautery. Otolaryngology and head and neck surgery.
3832 Wang EC, Choe MC, Meara JG, et al. (2004). Inequality of access to surgical specialty health care: why children with government-funded insurance have less access than those with private insurance in Southern California. Pediatrics.
3833 Watanabe K, Kunitomo M, Yamauchi Y, et al. (2004). Subcutaneous emphysema after tonsillectomy: a case report. J Nippon Med Sch.
3834 Weatherly RA, Ruzicka DL, Marriott DJ, et al. (2004). Polysomnography in children scheduled for adenotonsillectomy. Otolaryngol Head Neck Surg.
3835 Webb CJ, Osman E, Ghosh SK, et al. (2004). Tonsillar size is an important indicator of recurrent acute tonsillitis. Clin Otolaryngol Allied Sci.
3836 Wennberg J. (2004). Wrestling with variation: an interview with Jack Wennberg [interviewed by Fitzhugh Mullan]. Health Aff (Millwood).
3837 Wenzel S, Sagowski C, Laux G, et al. (2004). Course and therapy of intoxication with imidazoline derivate naphazoline. Int J Pediatr Otorhinolaryngol.
3838 Wild DC, Mehta D, Philpott CM, et al. (2004). Postoperative pain profile following coblator tonsillectomy versus cold steel dissection tonsillectomy. Joint ENT UK, RSM & Action on ENT Summer Meeting.
3839 Windfuhr JP, Chen YS, Remmert S. (2004). Unidentified coagulation disorders in post-tonsillectomy hemorrhage. Ear Nose Throat J.
3840 Wong L, Moxham JP, Ludemann JP. (2004). Electrosurgical adenoid ablation. J Otolaryngol.
3841 Wu CS, Wang SM, Ko WC, et al. (2004). Group B streptococcal infections in children in a tertiary care hospital in southern Taiwan. J Microbiol Immunol Infect.
3842 Xie Y, Chen X, Nishi S, et al. (2004). Relationship between tonsils and IgA nephropathy as well as indications of tonsillectomy. Kidney Int.
3843 Yamabe H, Sugawara T, Nakamura M, et al. (2004). Involvement of tonsils in IgA nephropathy. Acta Otolaryngol Suppl.
3844 Yammine NV, Alherabi A, Gerin-Lajoie J. (2004). Post-tonsillectomy subcutaneous emphysema and pneumomediastinum. J Otolaryngol.
3845 Yariktas M, Doner F, Dogru H, et al. (2004). The role of free oxygen radicals on the development of otitis media with effusion. Int J Pediatr Otorhinolaryngol.
3846 Yilmaz I, Cakmak O, Ozgirgin N, et al. (2004). Complete fistula of the second branchial cleft: case report of catheter-aided total excision. Int J Pediatr Otorhinolaryngol.
3847 Yilmaz M, Kara CO, Kaleli I, et al. (2004). Are tonsils a reservoir for Helicobacter pylori infection in children?. Int J Pediatr Otorhinolaryngol.
3848 Yilmaz M, Ugur MB, Uzun L, et al. (2004). Traditional tonsillectomy versus radiofrequency dissection tonsillectomy in adults. Gazi Medical Journal.
3849 Yilmaz T, Kocan EG, Besler HT. (2004). The role of oxidants and antioxidants in chronic tonsillitis and adenoid hypertrophy in children. Int J Pediatr Otorhinolaryngol.
3850 Yilmaz T, Kocan EG, Besler HT, et al. (2004). The role of oxidants and antioxidants in otitis media with effusion in children. Otolaryngol Head Neck Surg.
3851 Yokoyama M, Hashigucci K, Yamasaki Y. (2004). Effect of tonsillectomy in patients with pustulosis palmaris et plantaris. Acta Otolaryngol.
3852 Ziv O, Ragni MV. (2004). Bleeding manifestations in males with von Willebrand disease. Haemophilia.
3853 (2005). Snoring and the evidence behind the various treatments available. Pharmaceutical Journal.
3854 Adhikary B, Bora H, Bandyopadhyay SN, et al. (2005). Deaf child--a general practitioner's responsibility. J Indian Med Assoc.
3855 Agarwal, Jain AK, Marathe, et al. (2005). The effect of bismuth subgallete as heemostatic agent in tonsillectomy. Indian Journal of Otolaryngology and Head and Neck Surgery.
3856 Agrawal SR, Jain AK, Marathe D, et al. (2005). The effect of bismuth subgallate as haemostatic agent in tonsillectomy. Indian Journal of Otolaryngology and Head and Neck Surgery.
3857 Alperin N, Sivaramakrishnan A, Lichtor T. (2005). Magnetic resonance imaging-based measurements of cerebrospinal fluid and blood flow as indicators of intracranial compliance in patients with Chiari malformation. J Neurosurg.
3858 Al-Qahtani AS, Messahel FM. (2005). Quality improvement in anesthetic practice--incidence of sore throat after using small tracheal tube. Middle East J Anaesthesiol.
3859 Anand A, Vilela RJ, Guarisco JL. (2005). Intracapsular versus standard tonsillectomy: review of literature. J La State Med Soc.
3860 Anderson BJ, Pons G, Autret-Leca E, et al. (2005). Pediatric intravenous paracetamol (propacetamol) pharmacokinetics: a population analysis. Paediatr Anaesth.
3861 Andre M, Eriksson M, Molstad S, et al. (2005). The management of infections in children in general practice in Sweden: a repeated 1-week diagnosis-prescribing study in 5 counties in 2000 and 2002. Scand J Infect Dis.
3862 Andreu Ballester JC, Ballester F, Colomer Rubio E, et al. (2005). Association between tonsillectomy, adenoidectomy, and appendicitis. Rev Esp Enferm Dig.
3863 Annear B. (2005). Show and tell: patient involvement helps prevent medical errors. Tex Med.
3864 Apostolopoulos K, Psychogios G, Lampropoulou A, et al. (2005). Pre-emptive analgesia with levobupivacaine in adult tonsillectomy. European archives of oto-rhino-laryngology.
3865 Arai YC, Fukunaga K, Hirota S. (2005). Comparison of a combination of midazolam and diazepam and midazolam alone as oral premedication on preanesthetic and emergence condition in children. Acta Anaesthesiol Scand.
3866 Arai YC, Fukunaga K, Ueda W, et al. (2005). The endoscopically measured effects of airway maneuvers and the lateral position on airway patency in anesthetized children with adenotonsillar hypertrophy. Anesth Analg.
3867 Ark N, Kurtaran H, Yilmaz T, et al. (2005). Estimating the volume of blood loss and using diathermy in the cold dissection tonsillectomy group. Laryngoscope.
3868 Arya AK, Donne A, Nigam A. (2005). Double-blind randomized controlled study of coblation tonsillotomy versus coblation tonsillectomy on postoperative pain in children. Clin Otolaryngol.
3869 Aydin A, Erkilic S, Bayazit YA, et al. (2005). Relation between actinomycosis and histopathological and clinical features of the palatine tonsils: a comparative study between adult and pediatric patients. Rev Laryngol Otol Rhinol (Bord).
3870 Ball DR, Jefferson P. (2005). Childhood obstructive sleep apnoea: anaesthetic implications for adenotonsillectomy are important. Bmj.
3871 Bandyopadhyay A, Das TK, Raha K, et al. (2005). A study of fine needle aspiration cytology of salivary gland lesions with histopathological corroboration. J Indian Med Assoc.
3872 Bank MI, Gudbrand C, Rengtved P, et al. (2005). Immunohistochemical detection of the apoptosis-related proteins FADD, FLICE, and FLIP in Langerhans cell histiocytosis. J Pediatr Hematol Oncol.
3873 Barcelona SL, Thompson AA, Cote CJ. (2005). Intraoperative pediatric blood transfusion therapy: a review of common issues. Part II: transfusion therapy, special considerations, and reduction of allogenic blood transfusions. Paediatr Anaesth.
3874 Basha S, Bialowas C, Ende K, et al. (2005). Effectiveness of adenotonsillectomy in the resolution of nocturnal enuresis secondary to obstructive sleep apnea. Laryngoscope.
3875 Batas D, Park C, Hermon-Taylor AC. (2005). A serious case of failed extubation: difficulty removing a laser resistant tracheal tube in a 7-year-old child. Anaesthesia.
3876 Batra YK, Ivanova M, Ali SS, et al. (2005). The efficacy of a subhypnotic dose of propofol in preventing laryngospasm following tonsillectomy and adenoidectomy in children. Paediatr Anaesth.
3877 Batty A, Wren MW. (2005). Prevalence of Fusobacterium necrophorum and other upper respiratory tract pathogens isolated from throat swabs. Br J Biomed Sci.
3878 Becker N, Deeg E, Rudiger T, et al. (2005). Medical history and risk for lymphoma: results of a population-based case-control study in Germany. Eur J Cancer.
3879 Bedajit RK, Singh IK, Nalini O, et al. (2005). Otitis media among school children of Imphal in Manipur. JMS - Journal of Medical Society.
3880 Begum S, Cao D, Gillison M, et al. (2005). Tissue distribution of human papillomavirus 16 DNA integration in patients with tonsillar carcinoma. Clin Cancer Res.
3881 Bennett AM, Clark AB, Bath AP, et al. (2005). Meta-analysis of the timing of haemorrhage after tonsillectomy: an important factor in determining the safety of performing tonsillectomy as a day case procedure. Clin Otolaryngol.
3882 Blackham R, Lannigan F. (2005). Second branchial cleft sinus presenting after adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
3883 Blomgren K, Qvarnberg Y, Valtonen H. (2005). Patients' preferences for length of stay: valuable in day-case tonsillectomy planning. Eur Arch Otorhinolaryngol.
3884 Blumer JL, Reed MD, Kaplan EL, et al. (2005). Explaining the poor bacteriologic eradication rate of single-dose ceftriaxone in group a streptococcal tonsillopharyngitis: a reverse engineering solution using pharmacodynamic modeling. Pediatrics.
3885 Bocciolini C, Dall'Olio D, Cunsolo E, et al. (2005). Grisel's syndrome: a rare complication following adenoidectomy. Acta Otorhinolaryngol Ital.
3886 Boninsegna M, Marioni G, Stramare R, et al. (2005). Cervical necrotizing fasciitis: an unusual complication of genuine peritonsillar abscess. J Otolaryngol.
3887 Bothra R, Pai PS, Chaturvedi P, et al. (2005). Follicular dendritic cell tumour of tonsil - is it an under-diagnosed entity?. Indian J Cancer.
3888 Bowden MT, Kezirian EJ, Utley D, et al. (2005). Outcomes of hyoid suspension for the treatment of obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
3889 Bower CM. (2005). Lingual tonsillectomy. Operative Techniques in Otolaryngology - Head and Neck Surgery.
3890 Breitmeier D, Wilke N, Schulz Y, et al. (2005). The lingual tonsillar hyperplasia in relation to unanticipated difficult intubation: is there any relationship between lingual tonsillar hyperplasia and tonsillectomy?. Am J Forensic Med Pathol.
3891 Brook I. (2005). The association of anaerobic bacteria with infectious mononucleosis. Anaerobe.
3892 Brook I. (2005). Beta-lactamase-producing bacteria and their role in infection. Reviews in Medical Microbiology.
3893 Brook I, Foote PA. (2005). Efficacy of penicillin versus cefdinir in eradication of group A streptococci and tonsillar flora. Antimicrob Agents Chemother.
3894 Brook I, Gober AE. (2005). Treatment of non-streptococcal tonsillitis with metronidazole. Int J Pediatr Otorhinolaryngol.
3895 Browning GG. (2005). An important, randomized controlled trial of adenotonsillectomy. Clin Otolaryngol.
3896 Buck J, Davies SC. (2005). Surgery in sickle cell disease. Hematol Oncol Clin North Am.
3897 Burkart CM, Steward DL. (2005). Antibiotics for reduction of posttonsillectomy morbidity: a meta-analysis. Laryngoscope.
3898 Calabrese L, Jereczek-Fossa BA, Jassem J, et al. (2005). Diagnosis and management of neck metastases from an unknown primary. Acta Otorhinolaryngol Ital.
3899 Cardwell M, Siviter G, Smith A. (2005). Non-steroidal anti-inflammatory drugs and perioperative bleeding in paediatric tonsillectomy. Cochrane Database Syst Rev.
3900 Carroll T, Ladner K, Meyers AD. (2005). Alternative surgical dissection techniques. Otolaryngol Clin North Am.
3901 Casey JR, Pichichero ME. (2005). Metaanalysis of short course antibiotic treatment for group a streptococcal tonsillopharyngitis. Pediatr Infect Dis J.
3902 Casey JR, Pichichero ME. (2005). Higher dosages of azithromycin are more effective in treatment of group A streptococcal tonsillopharyngitis. Clin Infect Dis.
3903 Cemek M, Dede S, Bayiroglu F, et al. (2005). Oxidant and antioxidant levels in children with acute otitis media and tonsillitis: a comparative study. Int J Pediatr Otorhinolaryngol.
3904 Chacra ZA, Manoukian JJ, Al-Qahtani K, et al. (2005). Hydrogen peroxide mouth rinse: an analgesic post-tonsillectomy. J Otolaryngol.
3905 Chang AR, Wu HG, Park CI, et al. (2005). Retrospective analysis of the treatment results for patients with squamous cell carcinoma of tonsil. Cancer Res Treat.
3906 Chaturvedi S. (2005). A comparative study of topical analgesia with 4% lignocaine and 0.5% bupivacaine following tonsillectomy. Indian journal of anaesthesia.
3907 Chen R, Sehr P, Waterboer T, et al. (2005). Presence of DNA of human papillomavirus 16 but no other types in tumor-free tonsillar tissue. J Clin Microbiol.
3908 Chien CY, Chen AM, Hwang CF, et al. (2005). The clinical significance of adenoid-choanae area ratio in children with adenoid hypertrophy. Int J Pediatr Otorhinolaryngol.
3909 Chinn K, Brown OE, Manning SC. (2005). Effects of inhalant anesthesia: tympanometry validation (R98/217). Int J Pediatr Otorhinolaryngol.
3910 Chisholm EJ, Lew-Gor S, Hajioff D, et al. (2005). Adenoid size assessment: a comparison of palpation, nasendoscopy and mirror examination. Clin Otolaryngol.
3911 Cho W, Lee S, Kang HY, et al. (2005). Setting national priorities for quality assessment of health care services in Korea. Int J Qual Health Care.
3912 Clark WD. (2005). Preventing dentofacial abnormalities with the proper correction of pediatric upper airway obstruction. Arch Otolaryngol Head Neck Surg.
3913 Cohen IT, Joffe D, Hummer K, et al. (2005). Ondansetron oral disintegrating tablets: acceptability and efficacy in children undergoing adenotonsillectomy. Anesth Analg.
3914 Collet S, Eloy P, Rombaux P, et al. (2005). Taste disorders after tonsillectomy: case report and literature review. Ann Otol Rhinol Laryngol.
3915 Cookson BD. (2005). Tonsillectomy and MRSA carriage. J Hosp Infect.
3916 Dallari S, Morandi U, Bergamini G, et al. (2005). Descending necrotizing mediastinitis following lingual tonsillectomy and elective tracheotomy. Otolaryngol Head Neck Surg.
3917 Davies J, Coatesworth AP. (2005). Double-blind randomized controlled study of coblation tonsillotomy versus coblation tonsillectomy on post-operative pain. Clin Otolaryngol.
3918 DeFatta RJ, Verret DJ, Bauer P. (2005). Extracranial internal carotid artery pseudoaneurysm. Int J Pediatr Otorhinolaryngol.
3919 Delgado-Cervino E, Fontan G, Lopez-Trascasa M. (2005). C5 complement deficiency in a Spanish family. Molecular characterization of the double mutation responsible for the defect. Mol Immunol.
3920 Dell'Aringa AR, Juares AJ, Melo C, et al. (2005). Histological analysis of tonsillectomy and adenoidectomy specimens--January 2001 to May 2003. Braz J Otorhinolaryngol.
3921 Dhiwakar M, Brown PM. (2005). Are adjuvant therapies for tonsillectomy evidence based?. J Laryngol Otol.
3922 Dierks EJ. (2005). No convincing premise for efficacy of prophylactic adenotonsillar ablation. Arch Otolaryngol Head Neck Surg.
3923 Din S, Khan AR, Khan NS, et al. (2005). Management of secretory otitis media in children. Journal of Postgraduate Medical Institute.
3924 Divi V, Benninger M. (2005). Postoperative tonsillectomy bleed: coblation versus noncoblation. Laryngoscope.
3925 Dominguez O, Rojo P, de Las Heras S, et al. (2005). Clinical presentation and characteristics of pharyngeal adenovirus infections. Pediatr Infect Dis J.
3926 Don DM, Goldstein NA, Crockett DM, et al. (2005). Antimicrobial therapy for children with adenotonsillar hypertrophy and obstructive sleep apnea: a prospective randomized trial comparing azithromycin vs placebo. Otolaryngol Head Neck Surg.
3927 Edmonson MB, Farwell KR. (2005). Relationship between the clinical likelihood of group a streptococcal pharyngitis and the sensitivity of a rapid antigen-detection test in a pediatric practice. Pediatrics.
3928 Egeli E, Harputluoglu U, Oghan F, et al. (2005). Does topical lidocaine with adrenaline have an effect on morbidity in pediatric tonsillectomy?. Int J Pediatr Otorhinolaryngol.
3929 Egeli E, Oghan F, Ozturk O, et al. (2005). Measuring the correlation between adenoidal-nasopharyngeal ratio (AN ratio) and tympanogram in children. Int J Pediatr Otorhinolaryngol.
3930 Eiholzer U. (2005). Deaths in children with Prader-Willi syndrome. A contribution to the debate about the safety of growth hormone treatment in children with PWS. Horm Res.
3931 Elluru RG. (2005). Adenoid facies and nasal airway obstruction: cause and effect?. Arch Otolaryngol Head Neck Surg.
3932 England TRCoSo. (2005). National Prospective Tonsillectomy Audit.
3933 Erdag TK, Ecevit MC, Guneri EA, et al. (2005). Pathologic evaluation of routine tonsillectomy and adenoidectomy specimens in the pediatric population: is it really necessary?. Int J Pediatr Otorhinolaryngol.
3934 Ersoy B, Yuceturk AV, Taneli F, et al. (2005). Changes in growth pattern, body composition and biochemical markers of growth after adenotonsillectomy in prepubertal children. Int J Pediatr Otorhinolaryngol.
3935 Euctr GB. (2005). A randomized, multi-center, double-blind, parallel-group, multiple-dose study assessing the analgesic efficacy and safety of 3 different doses of GRT0151Y compared to placebo and an active comparator in adults following tonsillectomy. EUCTR [www.clinicaltrialsregister.eu].
3936 Ezike EN, Rongkavilit C, Fairfax MR, et al. (2005). Effect of using 2 throat swabs vs 1 throat swab on detection of group A streptococcus by a rapid antigen detection test. Arch Pediatr Adolesc Med.
3937 Fasano CJ, Chudnofsky C, Vanderbeek P. (2005). Bilateral peritonsillar abscesses: not your usual sore throat. J Emerg Med.
3938 Fischer T, Fischer S, Kochen MM, et al. (2005). Influence of patient symptoms and physical findings on general practitioners' treatment of respiratory tract infections: a direct observation study. BMC Fam Pract.
3939 Friedman NR. (2005). A modified technique to treat oropharyngeal obstruction: The uvulopalatal flap. Operative Techniques in Otolaryngology - Head and Neck Surgery.
3940 Friedman NR. (2005). Inferior turbinate reduction: An application for the microdebrider. Operative Techniques in Otolaryngology - Head and Neck Surgery.
3941 Friedman NR. (2005). Introduction. Operative Techniques in Otolaryngology - Head and Neck Surgery.
3942 Frohna JG. (2005). Effectiveness of adenotonsillectomy in children with mild symptoms of throat infections or adenotonsillar hypertrophy: open, randomised controlled trial. J Pediatr.
3943 Fujihara K, Goto H, Hiraoka M, et al. (2005). Tonsillitis index: an objective tool for quantifying the indications for tonsillectomy for recurrent acute tonsillitis. Int J Pediatr Otorhinolaryngol.
3944 Fukuchi I, Morato MM, Rodrigues RE, et al. (2005). Pre and postoperative psychological profile of children submitted to adenoidectomy and/or tonsillectomy. Braz J Otorhinolaryngol.
3945 Gaissert HA, Grillo HC, Shadmehr BM, et al. (2005). Laryngotracheoplastic resection for primary tumors of the proximal airway. J Thorac Cardiovasc Surg.
3946 Gendy S, O'Leary M, Colreavy M, et al. (2005). Tonsillectomy--cold dissection vs. hot dissection: a prospective study. Ir Med J.
3947 Georgalas C, Thomas K, Owens C, et al. (2005). Medical treatment for rhinosinusitis associated with adenoidal hypertrophy in children: an evaluation of clinical response and changes on magnetic resonance imaging. Ann Otol Rhinol Laryngol.
3948 George A, Sinha V. (2005). Balloon and bougie dilation of benign esophageal strictures. Indian J Otolaryngol Head Neck Surg.
3949 Giger R, Landis BN, Dulguerov P. (2005). Hemorrhage risk after quinsy tonsillectomy. Otolaryngol Head Neck Surg.
3950 Gillot C, Tombu S, Crestani V, et al. (2005). Subcutaneous emphysema and mediastinitis: unusual complications of tonsillectomy. B-ent.
3951 Ginstrom R, Silvola J, Saarnivaara L. (2005). Local bupivacaine-epinephrine infiltration combined with general anesthesia for adult tonsillectomy. Acta Otolaryngol.
3952 Goldbart AD, Goldman JL, Veling MC, et al. (2005). Leukotriene modifier therapy for mild sleep-disordered breathing in children. Am J Respir Crit Care Med.
3953 Goldbart AD, Veling MC, Goldman JL, et al. (2005). Glucocorticoid receptor subunit expression in adenotonsillar tissue of children with obstructive sleep apnea. Pediatr Res.
3954 Goldberg S, Shatz A, Picard E, et al. (2005). Endoscopic findings in children with obstructive sleep apnea: effects of age and hypotonia. Pediatr Pulmonol.
3955 Grivel JC, Garcia M, Moss WJ, et al. (2005). Inhibition of HIV-1 replication in human lymphoid tissues ex vivo by measles virus. J Infect Dis.
3956 Guler G, Akin A, Tosun Z, et al. (2005). Single-dose dexmedetomidine reduces agitation and provides smooth extubation after pediatric adenotonsillectomy. Paediatr Anaesth.
3957 Hadi U, El-Hajj M, Uwaydah M, et al. (2005). Characteristics of pathogens recovered from the tonsils and adenoids in a group of Lebanese children undergoing tonsillectomy and adenoidectomy. Journal of Applied Research.
3958 Hadzic R, Forsgren A, Cardell LO, et al. (2005). The CD19 molecule is crucial for MID-dependent activation of tonsillar B cells from children. Scand J Immunol.
3959 Hammaren-Malmi S, Saxen H, Tarkkanen J, et al. (2005). Adenoidectomy does not significantly reduce the incidence of otitis media in conjunction with the insertion of tympanostomy tubes in children who are younger than 4 years: a randomized trial. Pediatrics.
3960 Hamunen K, Kontinen V. (2005). Systematic review on analgesics given for pain following tonsillectomy in children. Pain.
3961 Hannaford PC, Simpson JA, Bisset AF, et al. (2005). The prevalence of ear, nose and throat problems in the community: results from a national cross-sectional postal survey in Scotland. Fam Pract.
3962 Henry LR, Gal TJ, Mair EA. (2005). Does increased electrocautery during adenoidectomy lead to neck pain?. Otolaryngol Head Neck Surg.
3963 Hoban TF. (2005). Obstructive sleep apnea in children. Curr Treat Options Neurol.
3964 Hofman R, Zeebregts CJ, Dikkers FG. (2005). Fulminant post-tonsillectomy haemorrhage caused by aberrant course of the external carotid artery. J Laryngol Otol.
3965 Hopkins C, Ajulo P, Krywawych M, et al. (2005). The impact of the interim report of the National Prospective Tonsillectomy Audit. Clin Otolaryngol.
3966 Hultcrantz E, Linder A, Markstrom A. (2005). Long-term effects of intracapsular partial tonsillectomy (tonsillotomy) compared with full tonsillectomy. Int J Pediatr Otorhinolaryngol.
3967 Hunt A, Karela M, Robb PJ. (2005). Day-case adenoidectomy: outcomes are improved using suction coagulation and prophylactic anti-emetic treatment. Int J Pediatr Otorhinolaryngol.
3968 Idvall E, Holm C, Runeson I. (2005). Pain experiences and non-pharmacological strategies for pain management after tonsillectomy: a qualitative interview study of children and parents. J Child Health Care.
3969 Iqbal SM, Khan A. (2005). A comparative analysis of performing tonsillectomy by diathermy versus dissection method. J Surg Pak.
3970 Isaacson G. (2005). Inside-out complete tonsillectomy: extended intracapsular tonsillectomy for severe sore throat. Ann Otol Rhinol Laryngol.
3971 Ishlah LW, Fahmi AM, Srinovianti N. (2005). Laser versus dissection technique of tonsillectomy. Med J Malaysia.
3972 Itasaka Y, Miyazaki S, Yin M, et al. (2005). Effectiveness of surgical treatments for obstructive sleep-related breathing disorders: Upper airway pressure analysis. Sleep and Biological Rhythms.
3973 Itoh A, Iwase H, Takatani T, et al. (2005). Disordered balance of IgA subclass production in the tonsils of some IgA nephropathy patients. J Nephrol.
3974 Jamil M, Gilani SM, Khan SA. (2005). Comparison of metoclopramide, prochlorperazine and placebo in prevention of postoperative nausea and vomiting (PONV) following tonsillectomy in young adults. J Ayub Med Coll Abbottabad.
3975 Jensen DM, Brousseau DC, Tumpach EA, et al. (2005). Intervention to improve interobserver agreement in the assessment of children with pharyngitis. Pediatr Emerg Care.
3976 Jeon Y, Park H, Kim J, et al. (2005). The effect of glossopharyngeal nerve block with ropivacaine on immediate postoperative pain relief after tonsillectomy in adult patients: A-390. European journal of anaesthesiology.
3977 Johnson RF, Stewart MG. (2005). The contemporary approach to diagnosis and management of peritonsillar abscess. Curr Opin Otolaryngol Head Neck Surg.
3978 Jombo GT, Egah DZ, Banwat EB. (2005). Hepatitis B virus infection in a rural settlement of northern Nigeria. Niger J Med.
3979 Kabalak AA, Akcay M, Akcay F, et al. (2005). Transcutaneous electrical acupoint stimulation versus ondansetron in the prevention of postoperative vomiting following pediatric tonsillectomy. J Altern Complement Med.
3980 Kabell S, Handberg KJ, Kusk M, et al. (2005). Detection of infectious bursal disease virus in various lymphoid tissues of experimentally infected specific pathogen free chickens by different reverse transcription polymerase chain reaction assays. Avian Dis.
3981 Kalra M, Buncher R, Amin RS. (2005). Asthma as a risk factor for respiratory complications after adenotonsillectomy in children with obstructive breathing during sleep. Ann Allergy Asthma Immunol.
3982 Kalra M, Kimball TR, Daniels SR, et al. (2005). Structural cardiac changes as a predictor of respiratory complications after adenotonsillectomy for obstructive breathing during sleep in children. Sleep Med.
3983 Karatzias GT, Lachanas VA, Papouliakos SM, et al. (2005). Tonsillectomy using the thermal welding system. ORL J Otorhinolaryngol Relat Spec.
3984 Kasenomm P, Piirsoo A, Kull M, et al. (2005). Selection of indicators for tonsillectomy in adults with recurrent tonsillitis. BMC Ear, Nose and Throat Disorders.
3985 Kay DJ, Bryson PC, Casselbrant M. (2005). Rates and risk factors for subsequent tonsillectomy after prior adenoidectomy: a regression analysis. Arch Otolaryngol Head Neck Surg.
3986 Kennedy JD, Waters KA. (2005). 8. Investigation and treatment of upper-airway obstruction: childhood sleep disorders I. Med J Aust.
3987 Khademi B, Imanieh MH, Gandomi B, et al. (2005). Investigation of H pylori colonization in adenotonsillectomy specimens by means of rapid urease (CLO) test. Iranian Journal of Medical Sciences.
3988 Khan Joad AS, Saxena MV. (2005). Anaesthesia for myotonic dystrophy. Journal of Anaesthesiology Clinical Pharmacology.
3989 Khan SA, Zaman J. (2005). Effect of topical bupivacaine on postoperative pain after tonsillectomy. Medical Channel.
3990 Khayr W, Taepke J. (2005). Management of peritonsillar abscess: needle aspiration versus incision and drainage versus tonsillectomy. Am J Ther.
3991 Kim JA, Lee JJ, Jung HH. (2005). Predictive factors of immediate postoperative complications after uvulopalatopharyngoplasty. Laryngoscope.
3992 Kim JB. (2005). The effectiveness of myprodol(R) on the post-tonsillectomy pain control and time to return to normal daily activities. Korean J Otolaryngol - Head Neck Surg.
3993 Kocaturk S, Yildirim A, Demiray T, et al. (2005). Cold dissection versus bipolar cauterizing tonsillectomy for bacteriemia. Am J Otolaryngol.
3994 Koempel JA. (2005). Greenfield sluder and subtotal tonsillectomy. Arch Otolaryngol Head Neck Surg.
3995 Komatsu H, Fujimoto S, Hara S, et al. (2005). Multivariate analysis of prognostic factors and effect of treatment in patients with IgA nephropathy. Ren Fail.
3996 Komorowska A, Komorowski J, Banasik M, et al. (2005). Cytokines locally produced by lymphocytes removed from the hypertrophic nasopharyngeal and palatine tonsils. Int J Pediatr Otorhinolaryngol.
3997 Konstantinidis I, Triaridis S, Triaridis A, et al. (2005). How do children with adenoid hypertrophy smell and taste? Clinical assessment of olfactory function pre- and post-adenoidectomy. Int J Pediatr Otorhinolaryngol.
3998 Krumina A, Logina I, Donaghy M, et al. (2005). Diphtheria with polyneuropathy in a closed community despite receiving recent booster vaccination. J Neurol Neurosurg Psychiatry.
3999 Kuhne M, Klein G, Gasse H. (2005). Shortening of the bovine tongue according to regulation (EC) 999/2001 is not complying with the current legal definition of specified risk material - a macroscopical and histological preliminary study. J Vet Med B Infect Dis Vet Public Health.
4000 Kumai A, Gupta V, Chandra K, et al. (2005). Clinico bacteriological evaluation of surface and core microflora in chronic tonsillitis. Indian J Otolaryngol Head Neck Surg.
4001 Kumar VV, Gaughan J, Isaacson G, et al. (2005). Oxymetazoline is equivalent to ciprofloxacin in preventing postoperative otorrhea or tympanostomy tube obstruction. Laryngoscope.
4002 Kurien M, Lepcha A, Mathew J, et al. (2005). X-Rays in the evaluation of adenoid hypertrophy: It's role in the endoscopic era. Indian J Otolaryngol Head Neck Surg.
4003 Kwak HJ, Kim JY, Kim JH, et al. (2005). The Effect of Ketamine and Fentanyl on the Incidence of Emergence Agitation after Sevoflurane Anesthesia in Children undergoing Tonsillectomy. Korean Journal of Anesthesiology.
4004 Kwon Jk. (2005). Is the patient-controlled analgesia(PCA) helpful for the recovery from the tonsillectomy?. Korean J Otolaryngol - Head Neck Surg.
4005 Lachanas VA, Prokopakis EP, Bourolias CA, et al. (2005). Ligasure versus cold knife tonsillectomy. Laryngoscope.
4006 Larsson M, Falkenberg T, Dardashti A, et al. (2005). Overprescribing of antibiotics to children in rural Vietnam. Scand J Infect Dis.
4007 Lee MS, Montague ML, Hussain SS. (2005). The influence of weather on the frequency of secondary post-tonsillectomy haemorrhage. J Laryngol Otol.
4008 Leenders AC, Renders NR, Pelk M, et al. (2005). Tonsillectomy for treatment of persistent methicillin-resistant Staphylococcus aureus throat carriage. J Hosp Infect.
4009 Lehnerdt G, Senska K, Fischer M, et al. (2005). Bilateral peritonsillar abscesses. Eur Arch Otorhinolaryngol.
4010 Lehnerdt G, Senska K, Jahnke K, et al. (2005). Post-tonsillectomy haemorrhage: a retrospective comparison of abscess- and elective tonsillectomy. Acta Otolaryngol.
4011 Lehnerdt G, van Delden A, Lautermann J. (2005). Management of an “Ear Camp” for children in Namibia. Int J Pediatr Otorhinolaryngol.
4012 Li AM, Chan DFY, Lam S, et al. (2005). Childhood obstructive sleep apnoea: What parents want to know. Hong Kong Journal of Paediatrics.
4013 Li HY, Li KK, Chen NH, et al. (2005). Three-dimensional computed tomography and polysomnography findings after extended uvulopalatal flap surgery for obstructive sleep apnea. Am J Otolaryngol.
4014 Li HY, Wang PC, Hsu CY, et al. (2005). Combined nasal-palatopharyngeal surgery for obstructive sleep apnea: simultaneous or staged?. Acta Otolaryngol.
4015 Liasis A, Nischal KK, Leighton S, et al. (2005). Adenoid-tonsillectomy to treat visual dysfunction in a child with craniosynostosis. Pediatr Neurosurg.
4016 Lima RA, Tavares MR, Dias FL, et al. (2005). Clinical prognostic factors in malignant parotid gland tumors. Otolaryngol Head Neck Surg.
4017 Lima WL, Correa NS, de Campos JL, et al. (2005). Subcutaneous emphysema after tonsillectomy: case report. Rev Bras Anestesiol.
4018 Lindbaek M, Hoiby EA, Lermark G, et al. (2005). Clinical symptoms and signs in sore throat patients with large colony variant beta-haemolytic streptococci groups C or G versus group A. Br J Gen Pract.
4019 Linder JA, Bates DW, Lee GM, et al. (2005). Antibiotic treatment of children with sore throat. JAMA.
4020 Lipman DS. (2005). Tonsillectomy techniques. Arch Otolaryngol Head Neck Surg.
4021 Littlefield PD, Hall DJ, Holtel MR. (2005). Radiofrequency excision versus monopolar electrosurgical excision for tonsillectomy. Otolaryngology--head and neck surgery.
4022 Lourenco EA, Lopes Kde C, Pontes A, et al. (2005). Comparison between radiological and nasopharyngolaryngoscopic assessment of adenoid tissue volume in mouth breathing children. Braz J Otorhinolaryngol.
4023 Luukkaa H, Klemi P, Leivo I, et al. (2005). Salivary gland cancer in Finland 1991--96: an evaluation of 237 cases. Acta Otolaryngol.
4024 Mahakit P, Moungthong G, Sombulna T, et al. (2005). The correlation of micro-organisms between tonsillar crypt culture and tonsillar core culture in chronic tonsillitis. J Med Assoc Thai.
4025 Maher DM, Zhang ZQ, Schacker TW, et al. (2005). Ex vivo modeling of oral HIV transmission in human palatine tonsil. J Histochem Cytochem.
4026 Malde AD, Sonawane VS, Jagtap SR, et al. (2005). Effect of dexamethasone on post tonsillectomy morbidities. Indian journal of anaesthesia.
4027 Malhotra-Kumar S, Lammens C, Chapelle S, et al. (2005). Clonal spread of fluoroquinolone non-susceptible Streptococcus pyogenes. J Antimicrob Chemother.
4028 Malhotra-Kumar S, Lammens C, Chapelle S, et al. (2005). Macrolide- and telithromycin-resistant Streptococcus pyogenes, Belgium, 1999-2003. Emerg Infect Dis.
4029 Marcus CL, Katz ES, Lutz J, et al. (2005). Upper airway dynamic responses in children with the obstructive sleep apnea syndrome. Pediatr Res.
4030 Materia E, Baglio G, Bellussi L, et al. (2005). The clinical and organisational appropriateness of tonsillectomy and adenoidectomy-an Italian perspective. Int J Pediatr Otorhinolaryngol.
4031 Mathew SJ, Amiel JM, Sackeim HA. (2005). Electroconvulsive therapy in treatment-resistant depression. Primary Psychiatry.
4032 McClelland L, Jones NS. (2005). Tonsillectomy: haemorrhaging ideas. J Laryngol Otol.
4033 McGirt MJ, Nimjee SM, Floyd J, et al. (2005). Correlation of cerebrospinal fluid flow dynamics and headache in Chiari I malformation. Neurosurgery.
4034 McKerrow WS. (2005). Comments on the Dutch tonsil randomized controlled trial. Clin Otolaryngol.
4035 Medina-Santillan R, Perez-Flores E, Mateos-Garcia E, et al. (2005). A B-vitamin mixture reduces the requirements of diclofenac after tonsillectomy: A double-blind study. Drug Development Research.
4036 Mendez JE, Fey JV, Cody H, et al. (2005). Can sentinel lymph node biopsy be omitted in patients with favorable breast cancer histology?. Ann Surg Oncol.
4037 Messner AH. (2005). Tonsillectomy. Operative Techniques in Otolaryngology - Head and Neck Surgery.
4038 Mikkelsen S, Hilsted KL, Andersen PJ, et al. (2005). The effect of Gabapentin on postoperative pain after tonsillectomy in adults. XXIX Congress of the Nordic Association of Otolaryngology.
4039 Miller FR, Hussey D, Beeram M, et al. (2005). Positron emission tomography in the management of unknown primary head and neck carcinoma. Arch Otolaryngol Head Neck Surg.
4040 Mitchell RB. (2005). Adenoidectomy techniques for sleep disordered breathing. Operative Techniques in Otolaryngology - Head and Neck Surgery.
4041 Mitchell RB. (2005). Sleep-disordered breathing in children: are we underestimating the problem?. Eur Respir J.
4042 Mitchell RB, Kelly J. (2005). Child behavior after adenotonsillectomy for obstructive sleep apnea syndrome. Laryngoscope.
4043 Mitchell RB, Kelly J. (2005). Quality of life after adenotonsillectomy for SDB in children. Otolaryngol Head Neck Surg.
4044 Mitchell RB, Kelly J. (2005). Outcome of adenotonsillectomy for obstructive sleep apnea in children under 3 years. Otolaryngol Head Neck Surg.
4045 Modayil PC, Joseph A, Thomas I, et al. (2005). Choristoma of the tonsil. Indian J Otolaryngol Head Neck Surg.
4046 Mohammadianpanah M, Omidvai S, Mosalei A, et al. (2005). Treatment results of tonsillar lymphoma: a 10-year experience. Ann Hematol.
4047 Molnar Z, Farkas V, Nemes L, et al. (2005). Hyponatraemic seizures resulting from inadequate post-operative fluid intake following a single dose of desmopressin. Nephrol Dial Transplant.
4048 Montgomery-Downs HE, Crabtree VM, Gozal D. (2005). Cognition, sleep and respiration in at-risk children treated for obstructive sleep apnoea. Eur Respir J.
4049 Moorthy R, Scott A. (2005). Double-blind randomized control trial of coblation tonsillotomy versus coblation tonsillectomy on post-operative pain in children. Clin Otolaryngol.
4050 Morgado PF. (2005). A new instrument to expose the human larynx. Otolaryngol Head Neck Surg.
4051 Mueller D, Oro JJ. (2005). Prospective analysis of self-perceived quality of life before and after posterior fossa decompression in 112 patients with Chiari malformation with or without syringomyelia. Neurosurg Focus.
4052 Nabili V, Koempel JA. (2005). Electrocautery tonsillectomy: common practice since the 1930s?. Otolaryngol Head Neck Surg.
4053 Naesh O, Niles LA, Gilbert JG, et al. (2005). A randomized, placebo-controlled study of rofecoxib with paracetamol in early post-tonsillectomy pain in adults. Eur J Anaesthesiol.
4054 Nafstad P, Jaakkola JJ, Skrondal A, et al. (2005). Day care center characteristics and children's respiratory health. Indoor Air.
4055 Naja MZ, El-Rajab M, Kabalan W, et al. (2005). Pre-incisional infiltration for pediatric tonsillectomy: a randomized double-blind clinical trial. Int J Pediatr Otorhinolaryngol.
4056 Naja MZ, El-Rajab M, Sidani H, et al. (2005). Modified infiltration technique in tonsillectomy: expanded case report of 25 children. Int J Pediatr Otorhinolaryngol.
4057 Nakamoto Y, Tatsumi M, Hammoud D, et al. (2005). Normal FDG distribution patterns in the head and neck: PET/CT evaluation. Radiology.
4058 Niedzielska G. (2005). Acoustic estimation of voice when incorrect resonance function of the nose takes place. Int J Pediatr Otorhinolaryngol.
4059 Nikanne E, Kokki H, Salo J, et al. (2005). Celecoxib and ketoprofen for pain management during tonsillectomy: a placebo-controlled clinical trial. Otolaryngol Head Neck Surg.
4060 Nixon GM, Kermack AS, McGregor CD, et al. (2005). Sleep and breathing on the first night after adenotonsillectomy for obstructive sleep apnea. Pediatr Pulmonol.
4061 Nixon I, Balaji N, Hilmy O, et al. (2005). A prospective study comparing conventional methods against a structured method of gaining patients' informed consent for tonsillectomy. Clin Otolaryngol.
4062 Nozawa H, Kishibe K, Takahara M, et al. (2005). Expression of cutaneous lymphocyte-associated antigen (CLA) in tonsillar T-cells and its induction by in vitro stimulation with alpha-streptococci in patients with pustulosis palmaris et plantaris (PPP). Clin Immunol.
4063 Oguz A, Karadeniz C, Citak EC, et al. (2005). Thymic and adenotonsillar enlargement after successful treatment of malignancies. Pediatr Hematol Oncol.
4064 O'Leary S, Vorrath J. (2005). Postoperative bleeding after diathermy and dissection tonsillectomy. Laryngoscope.
4065 Onodera K, Sakata H, Niikuni N, et al. (2005). Survey of the present status of sleep-disordered breathing in children with achondroplasia Part I. A questionnaire survey. Int J Pediatr Otorhinolaryngol.
4066 Oomen KP, Rovers MM, van den Akker EH, et al. (2005). Effect of adenotonsillectomy on middle ear status in children. Laryngoscope.
4067 Owens D, Jaramillo M, Saunders M. (2005). Suction diathermy adenoid ablation. J Laryngol Otol.
4068 Ozalevli M, Unlugenc H, Tuncer U, et al. (2005). Comparison of morphine and tramadol by patient-controlled analgesia for postoperative analgesia after tonsillectomy in children. Paediatr Anaesth.
4069 Pac A, Karadag A, Kurtaran H, et al. (2005). Comparison of cardiac function and valvular damage in children with and without adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
4070 Pai I, Lo S, Brown S, et al. (2005). Does hydrogen peroxide mouthwash improve the outcome of secondary post-tonsillectomy bleed? A 10-year review. Otolaryngol Head Neck Surg.
4071 Pajusto M, Tarkkanen J, Mattila PS. (2005). Platelet endothelial cell adhesion molecule-1 is expressed in adenoidal crypt epithelial cells. Scand J Immunol.
4072 Panerari AC, Soter AC, Silva FL, et al. (2005). Onset of subcutaneous emphysema and pneumomediastinum after tonsillectomy: a case report. Braz J Otorhinolaryngol.
4073 Paradise JL. (2005). Effectiveness of tonsillectomy depends on stringency of indications. Arch Dis Child.
4074 Parmod JK. (2005). How we do it: Jain tonsil ‘A’ frame--a solution to slipping rods. Clin Otolaryngol.
4075 Patel N, Brookes G. (2005). Surgical emphysema following tonsillectomy. Ear Nose Throat J.
4076 Pereira KD, Roebuck JC, Howell L. (2005). The effect of body position on sleep apnea in children younger than 3 years. Arch Otolaryngol Head Neck Surg.
4077 Pereira MB, Pereira DR, Costa SS. (2005). Tympanostomy tube sequelae in children with otitis media with effusion: a three-year follow-up study. Braz J Otorhinolaryngol.
4078 Perez DE, Pires FR, Alves Fde A, et al. (2005). Sublingual salivary gland tumors: clinicopathologic study of six cases. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
4079 Peters CA, Altose MD, Coticchia JM. (2005). Tracheomalacia secondary to obstructive sleep apnea. Am J Otolaryngol.
4080 Petrou-Amerikanou C, Belazi MA, Daskalopoulou E, et al. (2005). Oral findings in patients with obstructive sleep apnea syndrome. Quintessence Int.
4081 Philpott CM, Wild DC, Mehta D, et al. (2005). A double-blinded randomized controlled trial of coblation versus conventional dissection tonsillectomy on post-operative symptoms. Clin Otolaryngol.
4082 Piltcher OB, Scarton FB. (2005). Antibiotic use in tonsillectomies: therapeutic or prophylactic? Required or excessive?. Braz J Otorhinolaryngol.
4083 Pires MG, Di Francesco RC, Grumach AS, et al. (2005). Evaluation of inspiratory pressure in children with enlarged tonsils and adenoids. Braz J Otorhinolaryngol.
4084 Pires R, Rolo D, Gama-Norton L, et al. (2005). Group A Streptococci from carriage and disease in Portugal: evolution of antimicrobial resistance and T antigenic types during 2000-2002. Microb Drug Resist.
4085 Pirotte T, Ikabu C. (2005). Nasal foreign bodies in children: a possible pitfall for the anesthesiologist. Paediatr Anaesth.
4086 Pitkaranta A, Kolho KL, Rautelin H. (2005). Helicobacter pylori in children who are prone to upper respiratory tract infections. Arch Otolaryngol Head Neck Surg.
4087 Potts KL, Augenstein A, Goldman JL. (2005). A parallel group analysis of tonsillectomy using the harmonic scalpel vs electrocautery. Arch Otolaryngol Head Neck Surg.
4088 Prakash S, Kale S, Gupta B, et al. (2005). Obstructive sleep apnoea syndrome in a child - A case report and review of the literature. Journal of Anaesthesiology Clinical Pharmacology.
4089 Prepageran N, Omar R, Raman R. (2005). Tonsillectomy without headlights: a unique solution. Ear Nose Throat J.
4090 Prokopakis EP, Lachanas VA, Benakis AA, et al. (2005). Tonsillectomy using the Ligasure vessel sealing system. A preliminary report. Int J Pediatr Otorhinolaryngol.
4091 Puura A, Puura K, Rorarius M, et al. (2005). Children's drawings as a measure of anxiety level: a clinical pilot study. Paediatr Anaesth.
4092 Qudah A. (2005). Paracetamol versus ibuprofen for post-tonsillectomy pain. Medical journal of Cairo University.
4093 Rachmanidou A, Robb PJ, Timms M. (2005). A double-blinded randomized controlled trial of coblation versus conventional dissection tonsillectomy on postoperative symptoms. Clinical otolaryngology.
4094 Ragab SM. (2005). The effect of radiofrequency and mitomycin C on the closure rate of human tympanostomy. Otol Neurotol.
4095 Ray RM, Bower CM. (2005). Pediatric obstructive sleep apnea: the year in review. Curr Opin Otolaryngol Head Neck Surg.
4096 Razon Y, Ashkenazi S, Cohen A, et al. (2005). Effect of educational intervention on antibiotic prescription practices for upper respiratory infections in children: a multicentre study. J Antimicrob Chemother.
4097 Refaat M, Metry A, Dawood A, et al. (2005). Anatomic tonsililar infiltration with warming buffered lidocaine for paediatric tonsillectomy. Al-Azhar Medical Journal.
4098 Reuben SS. (2005). The safety of the perioperative administration of cyclooxygenase-2 inhibitors for post-surgical pain. Acta Anaesthesiol Scand.
4099 Rieder AA, Flanary V. (2005). The effect of polysomnography on pediatric adenotonsillectomy postoperative management. Otolaryngol Head Neck Surg.
4100 Rienzo Businco L, D'Emilia M, Lauriello M, et al. (2005). Coblation tonsillectomy versus dissection in adults: comparison of techniques.
4101 Roberson DW, Kentala E, Forbes P. (2005). Development and validation of an objective instrument to measure surgical performance at tonsillectomy. Laryngoscope.
4102 Rombaux P, Marque A, Hamoir M, et al. (2005). Post-transplant lymphoproliferative disorder with supraglottic involvement. B-ENT.
4103 Ryding M, White P, Kalm O. (2005). Course and long-term outcome of ‘refractory’ secretory otitis media. J Laryngol Otol.
4104 Sachse F, Ahlers F, Stoll W, et al. (2005). Neutrophil chemokines in epithelial inflammatory processes of human tonsils. Clin Exp Immunol.
4105 Saengpanich S, Kerekhanjanarong V, Aramwatanapong P, et al. (2005). Comparison of pain after radiofrequency tonsillectomy compared with conventional tonsillectomy: a pilot study. J Med Assoc Thai.
4106 Sakuragi T, Hori K, Shiratake T, et al. (2005). Tracheal intubation in an adult male with Mallampati class zero airway. Can J Anaesth.
4107 Sanchez-Carrion S, Prim MP, De Diego JI, et al. (2005). Bacteremia following pediatric adenoidectomy. Int J Pediatr Otorhinolaryngol.
4108 Sanz EJ, Hernandez MA, Ratchina S, et al. (2005). Prescribers' indications for drugs in childhood: a survey of five European countries (Spain, France, Bulgaria, Slovakia and Russia). Acta Paediatr.
4109 Savage J, Pace-Balzan A. (2005). An alternative to a postnasal pack for the arrest of perioperative hemorrhage following curettage adenoidectomy. Ear Nose Throat J.
4110 Sayed K, Van Savell H, Hutchison RE, et al. (2005). Review of tonsillar lymphoma in pediatric patients from the pediatric oncology group: what can be learned about some indications for microscopic examination?. Pediatr Dev Pathol.
4111 Scarlett M, Tennant I, Ehikhametalor K, et al. (2005). Vomiting post tonsillectomy at the University Hospital of the West Indies. West Indian Med J.
4112 Schmidt A, Tzanova I, Kobler AM, et al. (2005). Orthotopic liver transplantation in a malignant hyperthermia susceptible patient. J Clin Anesth.
4113 Sharma A, Muna S, Fahmy FF, et al. (2005). The ultrasonically activated scalpel versus bipolar diathermy for tonsillectomy: A prospective randomized trial [2] (multiple letters). Clinical otolaryngology.
4114 Shehata EM, Ragab SM, Behiry AB, et al. (2005). Telescopic-assisted radiofrequency adenoidectomy: a prospective randomized controlled trial. Laryngoscope.
4115 Shine NP, Coates HL, Lannigan FJ. (2005). Obstructive sleep apnea, morbid obesity, and adenotonsillar surgery: a review of the literature. Int J Pediatr Otorhinolaryngol.
4116 Shine NP, Lannigan FJ, Wilson A. (2005). Clinical evaluation is insufficient for diagnosis of pediatric OSAS. Int J Pediatr Otorhinolaryngol.
4117 Shine NP, Sader C, Coates H. (2005). Cervicofacial emphysema and pneumomediastinum following pediatric adenotonsillectomy: a rare complication. Int J Pediatr Otorhinolaryngol.
4118 Shlizerman L, Ashkenazi D. (2005). Peripheral facial nerve paralysis after peritonsillar infiltration of bupivacaine: a case report. Am J Otolaryngol.
4119 Shott SR. (2005). Pediatric sleep disordered breathing - Macroglossia. Operative Techniques in Otolaryngology - Head and Neck Surgery.
4120 Silvestre-Donat FJ, Pla-Mocholi A, Estelles-Ferriol E, et al. (2005). Giant tonsillolith: report of a case. Med Oral Patol Oral Cir Bucal.
4121 Singarelli S, Berni A, Coppo G, et al. (2005). Day-surgery, one-day surgery: the experience of an ENT unit in a 250 bed hospital. Acta Otorhinolaryngol Ital.
4122 Smith AC, Williams J, Agnew J, et al. (2005). Realtime telemedicine for paediatric otolaryngology pre-admission screening. J Telemed Telecare.
4123 Smith ME. (2005). Prevention and treatment of nasopharyngeal stenosis. Operative Techniques in Otolaryngology - Head and Neck Surgery.
4124 Sobol SE, Samadi DS, Kazahaya K, et al. (2005). Trends in the management of pediatric chronic sinusitis: survey of the American Society of Pediatric Otolaryngology. Laryngoscope.
4125 Sogut A, Altin R, Uzun L, et al. (2005). Prevalence of obstructive sleep apnea syndrome and associated symptoms in 3--11-year-old Turkish children. Pediatr Pulmonol.
4126 Sokmensuer LK, Muftuoglu S, Asan E. (2005). Immunohistochemical analysis of CD71, CD98 and CD99 activation antigens in human palatine and nasopharyngeal tonsils. Saudi Med J.
4127 Solares CA, Koempel JA, Hirose K, et al. (2005). Safety and efficacy of powered intracapsular tonsillectomy in children: a multi-center retrospective case series. Int J Pediatr Otorhinolaryngol.
4128 Sonbolestan SM, Mirmohammadsadeghi M, Rogha M, et al. (2005). Prevalence of dental occlusal patterns and their association with obstractive upper airway diseases in primary school children, Isfahan, Iran. Journal of Research in Medical Sciences.
4129 Sousa A, Iniciarte L, Levine H. (2005). Powered Endoscopic Nasal Septal Surgery. Acta Med Port.
4130 Spinou C, Kubba H, Konstantinidis I, et al. (2005). Role of tonsillectomy in histology for adults with unilateral tonsillar enlargement. Br J Oral Maxillofac Surg.
4131 Stevens MH, Stevens DC. (2005). Pain reduction by fibrin sealant in older children and adult tonsillectomy. Laryngoscope.
4132 Stewart MG, Glaze DG, Friedman EM, et al. (2005). Quality of life and sleep study findings after adenotonsillectomy in children with obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
4133 Strocker AM, Carrer A, Shapiro NL. (2005). The validity of the OSA-18 among three groups of pediatric patients. Int J Pediatr Otorhinolaryngol.
4134 Struben VM, Wieringa MH, Mantingh CJ, et al. (2005). Nasal NO: normal values in children age 6 through to 17 years. Eur Respir J.
4135 Sugiyama H, Watanabe N, Onoda T, et al. (2005). Successful treatment of progressive Henoch-Schonlein purpura nephritis with tonsillectomy and steroid pulse therapy. Intern Med.
4136 Sutters KA, Miaskowski C, Holdridge-Zeuner D, et al. (2005). Time-contingent dosing of an opioid analgesic after tonsillectomy does not increase moderate-to-severe side effects in children. Pain Manag Nurs.
4137 Takahara M, Kishibe K, Nozawa H, et al. (2005). Increase of activated T-cells and up-regulation of Smad7 without elevation of TGF-beta expression in tonsils from patients with pustulosis palmaris et plantaris. Clin Immunol.
4138 Tewodros W, Kronvall G. (2005). M protein gene (emm type) analysis of group A beta-hemolytic streptococci from Ethiopia reveals unique patterns. J Clin Microbiol.
4139 Tezer MS, Karanfil A, Aktas D. (2005). Association between adenoidal-nasopharyngeal ratio and right ventricular diastolic functions in children with adenoid hypertrophy causing upper airway obstruction. Int J Pediatr Otorhinolaryngol.
4140 Thompson SK, Doerr TD, Hengerer AS. (2005). Infectious mononucleosis and corticosteroids: management practices and outcomes. Arch Otolaryngol Head Neck Surg.
4141 Timms MS, Ghosh S, Roper A. (2005). Adenoidectomy with the coblator: a logical extension of radiofrequency tonsillectomy. J Laryngol Otol.
4142 Tomkinson A. (2005). Jain tonsil “A” frame--a solution to slipping rods. Clin Otolaryngol.
4143 Tomkinson A, Phillips P, Scott JB, et al. (2005). A laboratory and clinical evaluation of single-use instruments for tonsil and adenoid surgery. Clin Otolaryngol.
4144 Tomofuji S, Sakagami M, Kushida K, et al. (2005). Taste disturbance after tonsillectomy and laryngomicrosurgery. Auris Nasus Larynx.
4145 Torre V, Bucolo S, Giordano C, et al. (2005). Palatine tonsils in smoker and non-smoker patients: a pilot clinicopathological and ultrastructural study. J Oral Pathol Med.
4146 Tran KD, Nguyen CD, Weedon J, et al. (2005). Child behavior and quality of life in pediatric obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
4147 Tsai MH, Hsu CY, Yen MH, et al. (2005). Epstein-Barr virus-associated infectious mononucleosis and risk factor analysis for complications in hospitalized children. J Microbiol Immunol Infect.
4148 Tshifularo M, Joseph CA, Ogunbanjo GA. (2005). Post-tonsillectomy haemorrhage following traditional uvulectomy in an adult patient. South African Family Practice.
4149 Ueda F, Suzuki M, Matsui O, et al. (2005). MR findings of nine cases of palatal tumor. Magn Reson Med Sci.
4150 Unal M, Celik A, Ates NA, et al. (2005). Cytogenetic biomonitoring in children with chronic tonsillitis: micronucleus frequency in exfoliated buccal epithelium cells. Int J Pediatr Otorhinolaryngol.
4151 Unal M, Cimen MY, Dogruer ZN, et al. (2005). The potential inflammatory role of arginase and iNOS in children with chronic adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
4152 Unkel C, Lehnerdt G, Schmitz KJ, et al. (2005). Laser-tonsillotomy for treatment of obstructive tonsillar hyperplasia in early childhood: a retrospective review. Int J Pediatr Otorhinolaryngol.
4153 Valera FC, Avelino MA, Pettermann MB, et al. (2005). OSAS in children: correlation between endoscopic and polysomnographic findings. Otolaryngol Head Neck Surg.
4154 van Staaij BK, van den Akker EH, van der Heijden GJ, et al. (2005). Adenotonsillectomy for upper respiratory infections: evidence based?. Arch Dis Child.
4155 Vassallo J, Camargo LA, Chagas CA, et al. (2005). Search for Herpesvirus 1 and 2 by in situ hybridization in tonsils and adenoids. Int J Pediatr Otorhinolaryngol.
4156 Verse T. (2005). Reconstructive procedures for disturbed functions within the upper airway: pharyngeal breathing/snoring. GMS Curr Top Otorhinolaryngol Head Neck Surg.
4157 Vicheva D. (2005). Otitis media with effusion in children: Conservative and surgical management. Acta Medica Bulgarica.
4158 Vontetsianos HS, Davris SE, Christopoulos GD, et al. (2005). Improved somatic growth following adenoidectomy and tonsillectomy in young children. Possible pathogenetic mechanisms. Hormones (Athens).
4159 Walshe P, Ramos E, Low C, et al. (2005). An unusual complication of tonsillectomy. Surgeon.
4160 Wan YM, Wong KC, Ma KH. (2005). Endoscopic-guided adenoidectomy using a classic adenoid curette: a simple way to improve adenoidectomy. Hong Kong Med J.
4161 White MC, Nolan JA. (2005). An evaluation of pain and postoperative nausea and vomiting following the introduction of guidelines for tonsillectomy. Paediatr Anaesth.
4162 Windfuhr JP, Chen YS, Remmert S. (2005). Hemorrhage following tonsillectomy and adenoidectomy in 15,218 patients. Otolaryngol Head Neck Surg.
4163 Windfuhr JP, Deck JC, Remmert S. (2005). Hemorrhage following coblation tonsillectomy. Ann Otol Rhinol Laryngol.
4164 Wise JB, Sehgal K, Guttenberg M, et al. (2005). Ectopic salivary tissue of the tonsil: a case report. Int J Pediatr Otorhinolaryngol.
4165 Xenellis J, Paschalidis J, Georgalas C, et al. (2005). Factors influencing the presence of otitis media with effusion 16 months after initial diagnosis in a cohort of school-age children in rural Greece: a prospective study. Int J Pediatr Otorhinolaryngol.
4166 Yilmaz MD, Aktepe O, Cetinkol Y, et al. (2005). Does Helicobacter pylori have role in development of otitis media with effusion?. Int J Pediatr Otorhinolaryngol.
4167 Yilmaz MD, Onrat E, Altuntas A, et al. (2005). The effects of tonsillectomy and adenoidectomy on pulmonary arterial pressure in children. Am J Otolaryngol.
4168 Zonato AI, Martinho FL, Bittencourt LR, et al. (2005). Head and neck physical examination: comparison between nonapneic and obstructive sleep apnea patients. Laryngoscope.
4169 (2006). Did CRNA get off the hook in this case?. Nurs Law Regan Rep.
4170 Abadi U, Hadary R, Shilo L, et al. (2006). Myositis in Behcet's disease after tonsillectomy. Isr Med Assoc J.
4171 Abdel-Galil K, Anand R, Jain PK, et al. (2006). How we do it: The Jain tonsil ‘A’ frame--A new use in cleft surgery. Br J Oral Maxillofac Surg.
4172 Abdullah B, Hassan S, Sidek D, et al. (2006). Adenoid mast cells and their role in the pathogenesis of otitis media with effusion. J Laryngol Otol.
4173 Abel K, Pahar B, Van Rompay KK, et al. (2006). Rapid virus dissemination in infant macaques after oral simian immunodeficiency virus exposure in the presence of local innate immune responses. J Virol.
4174 Abou-Elhamd KE, Sayed RH. (2006). Assessment of nasal obstruction with flexible nasal endoscopy. Saudi Med J.
4175 Abu-Sabaah AH, Ghazi HO. (2006). Better diagnosis and treatment of throat infections caused by group A beta-haemolytic streptococci. Br J Biomed Sci.
4176 Adappa ND, Coticchia JM. (2006). Management of refractory chronic rhinosinusitis in children. Am J Otolaryngol.
4177 Afman CE, Welge JA, Steward DL. (2006). Steroids for post-tonsillectomy pain reduction: meta-analysis of randomized controlled trials. Otolaryngol Head Neck Surg.
4178 Agirdir BV, Bozova S, Derin AT, et al. (2006). Chronic otitis media with effusion and Helicobacter pylori. Int J Pediatr Otorhinolaryngol.
4179 Ahn JH, Yoon TH, Pae KH, et al. (2006). Clinical manifestations and risk factors of children receiving triple ventilating tube insertions for treatment of recurrent otitis media with effusion. Pediatrics.
4180 Akcay A, Kara CO, Dagdeviren E, et al. (2006). Variation in tonsil size in 4- to 17-year-old schoolchildren. J Otolaryngol.
4181 Akcay A, Tamay Z, Dagdeviren E, et al. (2006). Childhood asthma and its relationship with tonsillar tissue. Asian Pac J Allergy Immunol.
4182 Akoglu E, Akkurt BC, Inanoglu K, et al. (2006). Ropivacaine compared to bupivacaine for post-tonsillectomy pain relief in children: a randomized controlled study. Int J Pediatr Otorhinolaryngol.
4183 Al Anazy FH. (2006). Iatrogenic cholesteatoma in children with OME in a training program. Int J Pediatr Otorhinolaryngol.
4184 Alatas N, San I, Cengiz M, et al. (2006). A mean red blood cell volume loss in tonsillectomy, adenoidectomy and adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
4185 Aldakhail AA, Khan MI. (2006). A retrospective study of peritonsillar abscess in Riyadh Medical Complex [corrected]. Saudi Med J.
4186 Alhashemi JA, Daghistani MF. (2006). Effects of intraoperative i.v. acetaminophen vs i.m. meperidine on post-tonsillectomy pain in children. Br J Anaesth.
4187 Al-Jaouni SK, Al-Muhayawi SM, Qari MH, et al. (2006). Randomized clinical trial to evaluate the safety of avoiding pre-operative transfusion in sickle cell anemia. Bahrain Medical Bulletin.
4188 Al-Khatib IA, Tabakhna H. (2006). Housing conditions and health in Jalazone Refugee Camp in Palestine. East Mediterr Health J.
4189 Al-Khtoum N. (2006). Comparative study of local infiltration of bupivacaine and parenteral administration of diclofenac sodium for post tonsillectomy pain in adults. Middle East Journal of Family Medicine.
4190 Al-Saadi MM. (2006). Reversible pulmonary hypertension post adenotonsillectomy. Saudi Med J.
4191 Al-Tatari H, Abdel-Haq N, Asmar B, et al. (2006). Picture of the month. Tonsillar actinomycosis. Arch Pediatr Adolesc Med.
4192 An TH, Jung JD, Yang IH. (2006). The Effects of Remifentanil to Prevent the Hemodynamic Changes to Mouth Gag Insertion in Tonsillectomy. Anesthesia and Pain Medicine.
4193 Anderson K, Gambhir S, Glavin R, et al. (2006). The use of an anaesthetic simulator to assess single-use laryngoscopy equipment. International journal for quality in health care.
4194 Appel GB, Waldman M. (2006). The IgA nephropathy treatment dilemma. Kidney Int.
4195 Arikan OK, Ozcan S, Kazkayasi M, et al. (2006). Preincisional infiltration of tonsils with ropivacaine in post-tonsillectomy pain relief: double-blind, randomized, placebo-controlled intraindividual study. J Otolaryngol.
4196 Arima H, Ota H, Fukumoto M. (2006). Migration of cut Foley catheter for posterior nasal packing into main bronchus. International Journal of Pediatric Otorhinolaryngology Extra.
4197 Arrica M, Crawford MW. (2006). Complete upper airway obstruction after induction of anesthesia in a child with undiagnosed lingual tonsil hypertrophy. Paediatr Anaesth.
4198 Ascani G, Pieramici T, Messi M, et al. (2006). Salivary glands tumours: a retrospective study of 454 patients. Minerva Stomatol.
4199 Asiri SM, Abu-Bakr YA, Al-Enazi F. (2006). Paediatric ENT day surgery. Is it safe practice?. Ambulatory Surgery.
4200 Avanzini MA, Ricci A, Scaramuzza C, et al. (2006). Deficiency of INFgamma producing cells in adenoids of children exposed to passive smoke. Int J Immunopathol Pharmacol.
4201 Avitia S, Osborne RF. (2006). Parathyroid adenoma mimicking cervical recurrence on CT/PET fusion scan. Ear Nose Throat J.
4202 Aydin E, Ozluoglu LN, Demirhan B, et al. (2006). Follicular dendritic cell sarcoma of the tonsil: case report. Eur Arch Otorhinolaryngol.
4203 Aziz L, Bashir K. (2006). Comparison of armoured laryngeal mask airway with endotracheal tube for adenotonsillectomy. J Coll Physicians Surg Pak.
4204 Badran K, Karkos PD, Acharya M, et al. (2006). Transtonsillar drainage of parapharyngeal abscess. Eur Arch Otorhinolaryngol.
4205 Bagade A, Jefferson P, Ball DR. (2006). Pain relief after daycase tonsillectomy in children. Anaesthesia.
4206 Bahadir O, Caylan R, Bektas D, et al. (2006). Effects of adenoidectomy in children with symptoms of adenoidal hypertrophy. Eur Arch Otorhinolaryngol.
4207 Baharudin A, Shahid H, Rhendra MZ. (2006). Laser tonsillotomy in children with tonsillar hyperplasia. Med J Malaysia.
4208 Bahnassy AA, Zekri AR, Asaad N, et al. (2006). Epstein-Barr viral infection in extranodal lymphoma of the head and neck: correlation with prognosis and response to treatment. Histopathology.
4209 Baker K. (2006). An overview of current techniques for tonsillectomy. ORL Head Neck Nurs.
4210 Bal N, Saricaoglu F, Uzun S, et al. (2006). Perioperative anxiety and postoperative behavioural disturbances in children: comparison between induction techniques. Eur J Anaesthesiol.
4211 Baumann I, Kucheida H, Blumenstock G, et al. (2006). Benefit from tonsillectomy in adult patients with chronic tonsillitis. Eur Arch Otorhinolaryngol.
4212 Baxter RL, Baxter HC, Campbell GA, et al. (2006). Quantitative analysis of residual protein contamination on reprocessed surgical instruments. J Hosp Infect.
4213 Beebe DW. (2006). Neurobehavioral morbidity associated with disordered breathing during sleep in children: a comprehensive review. Sleep.
4214 Belloso A, Morar P, Tahery J, et al. (2006). Randomized-controlled study comparing post-operative pain between coblation palatoplasty and laser palatoplasty. Clinical otolaryngology.
4215 Benk V, Przybysz R, McGowan T, et al. (2006). Waiting times for radiation therapy in Ontario. Can J Surg.
4216 Beriault M, Green J, Hui A. (2006). Innovative airway management for peritonsillar abscess. Can J Anaesth.
4217 Bernstein JM, Haase E, Scannapieco F, et al. (2006). Bacterial interference of penicillin-sensitive and -resistant Streptococcus pneumoniae by Streptococcus oralis in an adenoid organ culture: implications for the treatment of recurrent upper respiratory tract infections in children and adults. Ann Otol Rhinol Laryngol.
4218 Berzanskyte A, Valinteliene R, Haaijer-Ruskamp FM, et al. (2006). Self-medication with antibiotics in Lithuania. Int J Occup Med Environ Health.
4219 Bhadoria P, Rathore PK, Mandal S, et al. (2006). Role of Bupivacaine in reducing post tonsillectomy pain. Indian J Otolaryngol Head Neck Surg.
4220 Bhombal S, Bothwell MR, Bauer SM. (2006). Prevalence of elevated total IgE and food allergies in a consecutive series of ENT pediatric patients. Otolaryngol Head Neck Surg.
4221 Bista M, Amatya RC, Basnet P. (2006). Tonsillar microbial flora: a comparison of infected and non-infected tonsils. Kathmandu Univ Med J (KUMJ).
4222 Bitar M, Mahfouz R, Soweid A, et al. (2006). Does Helicobacter pylori colonize the nasopharynx of children and contribute to their middle ear disease?. Acta Otolaryngol.
4223 Bitar MA, Rahi A, Khalifeh M, et al. (2006). A suggested clinical score to predict the severity of adenoid obstruction in children. Eur Arch Otorhinolaryngol.
4224 Bolton CM, Myles PS, Nolan T, et al. (2006). Prophylaxis of postoperative vomiting in children undergoing tonsillectomy: a systematic review and meta-analysis. Br J Anaesth.
4225 Bond J, Wilson J, Eccles M, et al. (2006). Protocol for north of England and Scotland study of tonsillectomy and adeno-tonsillectomy in children (NESSTAC). A pragmatic randomised controlled trial comparing surgical intervention with conventional medical treatment in children with recurrent sore throats. BMC Ear Nose Throat Disord.
4226 Bonuck K, Parikh S, Bassila M. (2006). Growth failure and sleep disordered breathing: a review of the literature. Int J Pediatr Otorhinolaryngol.
4227 Borschmann ME, Berkowitz RG. (2006). One-off streptococcal serologic testing in young children with recurrent tonsillitis. Ann Otol Rhinol Laryngol.
4228 Boseley ME, Cunningham MJ, Volk MS, et al. (2006). Validation of the Pediatric Voice-Related Quality-of-Life survey. Arch Otolaryngol Head Neck Surg.
4229 Brietzke SE, Gallagher D. (2006). The effectiveness of tonsillectomy and adenoidectomy in the treatment of pediatric obstructive sleep apnea/hypopnea syndrome: a meta-analysis. Otolaryngol Head Neck Surg.
4230 Brietzke SE, Kenna M, Katz ES, et al. (2006). Pediatric adenoidectomy: what is the effect of obstructive symptoms on the likelihood of future surgery?. Int J Pediatr Otorhinolaryngol.
4231 Brigger MT, Brietzke SE. (2006). Outpatient tonsillectomy in children: a systematic review. Otolaryngol Head Neck Surg.
4232 Broad RD, Wheeler K. (2006). An adult with childhood medical trauma treated with psychoanalytic psychotherapy and EMDR: a case study. Perspect Psychiatr Care.
4233 Brook I, Foote PA. (2006). Isolation of methicillin resistant Staphylococcus aureus from the surface and core of tonsils in children. Int J Pediatr Otorhinolaryngol.
4234 Brook I, Gober AE. (2006). Recovery of interfering and beta-lactamase-producing bacteria from group A beta-haemolytic streptococci carriers and non-carriers. J Med Microbiol.
4235 Brook I, Gober AE. (2006). Increased recovery of Moraxella catarrhalis and Haemophilus influenzae in association with group A beta-haemolytic streptococci in healthy children and those with pharyngo-tonsillitis. J Med Microbiol.
4236 Brown KA. (2006). The impact of pediatric obstructive sleep apnea on ambulatory surgery. Ambulatory Surgery.
4237 Brown KA, Laferriere A, Lakheeram I, et al. (2006). Recurrent hypoxemia in children is associated with increased analgesic sensitivity to opiates. Anesthesiology.
4238 Brown PM. (2006). How safe is paediatric tonsillectomy?. Int J Pediatr Otorhinolaryngol.
4239 Bulut Y, Agacayak A, Karlidag T, et al. (2006). Association of cagA+ Helicobacter pylori with adenotonsillar hypertrophy. Tohoku J Exp Med.
4240 Bustamante SE, Appachi E. (2006). Acute pancreatitis after anesthesia with propofol in a child with glycogen storage disease type IA. Paediatr Anaesth.
4241 Cantarella G, Pagani D, Biondetti P. (2006). An unusual cause of mechanical dysphagia: an agglomerate of calculi in a tonsillar residue. Dysphagia.
4242 Carding PN, Roulstone S, Northstone K. (2006). The prevalence of childhood dysphonia: a cross-sectional study. J Voice.
4243 Carignan M, Dorion D, Stephenson MF, et al. (2006). First myringotomy with insertion of a modified Goode T-Tube: changing the perforation paradigm. J Otolaryngol.
4244 Carron JD. (2006). Bifid epiglottis revisited. International Journal of Pediatric Otorhinolaryngology Extra.
4245 Cassano M, Cassano P, Luigi M, et al. (2006). Rhino-bronchial syndrome in children: pathogenic correlations and clinical-experimental aspects. Int J Pediatr Otorhinolaryngol.
4246 Cengel S, Akyol MU. (2006). The role of topical nasal steroids in the treatment of children with otitis media with effusion and/or adenoid hypertrophy. Int J Pediatr Otorhinolaryngol.
4247 Chagas CA, Endo LH, Sakano E, et al. (2006). Detection of herpesvirus type 8 (HHV8) in children's tonsils and adenoids by immunohistochemistry and in situ hybridization. Int J Pediatr Otorhinolaryngol.
4248 Chan JC, Trachtman H. (2006). Modulating the progression in IgA nephropathy. Nephron Clin Pract.
4249 Chavolla R, Dolci GF, Hernandez JFM, et al. (2006). Primary tuberculosis of the tonsil. International Journal of Pediatric Otorhinolaryngology Extra.
4250 Chegar BE, Tatum SA, Marrinan E, et al. (2006). Upper airway asymmetry in velo-cardio-facial syndrome. Int J Pediatr Otorhinolaryngol.
4251 Chen AM, Bucci MK, Weinberg V, et al. (2006). Adenoid cystic carcinoma of the head and neck treated by surgery with or without postoperative radiation therapy: prognostic features of recurrence. Int J Radiat Oncol Biol Phys.
4252 Chervin RD, Ruzicka DL, Giordani BJ, et al. (2006). Sleep-disordered breathing, behavior, and cognition in children before and after adenotonsillectomy. Pediatrics.
4253 Chervin RD, Weatherly RA, Ruzicka DL, et al. (2006). Subjective sleepiness and polysomnographic correlates in children scheduled for adenotonsillectomy vs other surgical care. Sleep.
4254 Childers NK, Li F, Dasanayake AP, et al. (2006). Immune response in humans to a nasal boost with Streptococcus mutans antigens. Oral Microbiol Immunol.
4255 Chmielik M, Brozek-Madry E, Debska M. (2006). Surgical treatment of secretory otitis media in children. New Medicine.
4256 Chu WC, Lam WW, Chan YL, et al. (2006). Relative shortening and functional tethering of spinal cord in adolescent idiopathic scoliosis?: study with multiplanar reformat magnetic resonance imaging and somatosensory evoked potential. Spine (Phila Pa 1976).
4257 Clark MP, Smithard A, Jervis P. (2006). How we do it: coblation tonsillectomy complication rates from a single ENT department compared with the National Prospective Tonsillectomy Audit. Clin Otolaryngol.
4258 Clement P, Saint-Blancard P, Minvielle F, et al. (2006). Follicular dendritic cell sarcoma of the tonsil: a case report. Am J Otolaryngol.
4259 Cote CJ, Wilson S. (2006). Guidelines for monitoring and management of pediatric patients during and after sedation for diagnostic and therapeutic procedures: an update. Pediatrics.
4260 da Cruz Perez DE, de Abreu Alves F, Nobuko Nishimoto I, et al. (2006). Prognostic factors in head and neck adenoid cystic carcinoma. Oral Oncol.
4261 da Cruz Perez DE, Pires FR, Lopes MA, et al. (2006). Adenoid cystic carcinoma and mucoepidermoid carcinoma of the maxillary sinus: report of a 44-year experience of 25 cases from a single institution. J Oral Maxillofac Surg.
4262 Dahshan A, Donovan GK. (2006). Severe methemoglobinemia complicating topical benzocaine use during endoscopy in a toddler: a case report and review of the literature. Pediatrics.
4263 Dal Rio AC, Passos CA, Nicola JH, et al. (2006). CO2 laser cryptolysis by coagulation for the treatment of halitosis. Photomed Laser Surg.
4264 Danilova E, Jenum PA, Skogen V, et al. (2006). Antidiphtheria antibody responses in patients and carriers of Corynebacterium diphtheriae in the Arkhangelsk region of Russia. Clin Vaccine Immunol.
4265 De Diego JI, Prim MP, Hardisson D, et al. (2006). Nasopharyngeal cyst after adenoidectomy in a child with liver transplantation. International Journal of Pediatric Otorhinolaryngology Extra.
4266 DePond WD, Flauta VS, Lingamfelter DC, et al. (2006). Adenoid basal carcinoma of the cervix in a 20-year-old female: a case report. Diagn Pathol.
4267 Desai AA, Pandya VK, Chougule S, et al. (2006). Recurrent thyroid abscess - Is it a fourth branchial archanomaly?. Indian J Otolaryngol Head Neck Surg.
4268 Dewil B, Jorissen M, Lemkens P. (2006). Routine pathological evaluation after tonsillectomy: is it necessary?. B-ENT.
4269 Deyell R, Jackson S, Spier S, et al. (2006). Low oxygen saturation by pulse oximetry may be associated with a low oxygen affinity hemoglobin variant, hemoglobin Titusville. J Pediatr Hematol Oncol.
4270 Dhiwakar M, Eng CY, Selvaraj S, et al. (2006). Antibiotics to improve recovery following tonsillectomy: a systematic review. Otolaryngol Head Neck Surg.
4271 Diez-Montiel A, de Diego JI, Prim MP, et al. (2006). Quality of life after surgical treatment of children with obstructive sleep apnea: long-term results. Int J Pediatr Otorhinolaryngol.
4272 Diluvio L, Vollmer S, Besgen P, et al. (2006). Identical TCR beta-chain rearrangements in streptococcal angina and skin lesions of patients with psoriasis vulgaris. J Immunol.
4273 Dolitsky J. (2006). Tonsillectomy debate and public education. Otolaryngol Head Neck Surg.
4274 Doshi J, Carrie S. (2006). A survey of undergraduate otolaryngology experience at Newcastle University Medical School. J Laryngol Otol.
4275 Duke RL, Scott JP, Panepinto JA, et al. (2006). Perioperative management of sickle cell disease children undergoing adenotonsillectomy. Otolaryngol Head Neck Surg.
4276 Eisert S, Hovermann M, Bier H, et al. (2006). Preoperative screening for coagulation disorders in children undergoing adenoidectomy (AT) and tonsillectomy (TE): does it prevent bleeding complications?. Klin Padiatr.
4277 Elsammak M, Hanna H, Ghazal A, et al. (2006). Diagnostic value of serum procalcitonin and C-reactive protein in Egyptian children with streptococcal tonsillopharyngitis. Pediatr Infect Dis J.
4278 Elsheikh MN, Mahfouz ME. (2006). Up-regulation of MUC5AC and MUC5B mucin genes in nasopharyngeal respiratory mucosa and selective up-regulation of MUC5B in middle ear in pediatric otitis media with effusion. Laryngoscope.
4279 Emerick KS, Cunningham MJ. (2006). Tubal tonsil hypertrophy: a cause of recurrent symptoms after adenoidectomy. Arch Otolaryngol Head Neck Surg.
4280 Endo Y, Yazumi S, Kimura Y, et al. (2006). Hepatobiliary and pancreatic: tonsillar metastases from hepatocellular carcinoma. J Gastroenterol Hepatol.
4281 Ertugrul F, Akbas M, Karsli B, et al. (2006). Pain relief for children after adenotonsillectomy. J Int Med Res.
4282 Esposito S, Bosis S, Begliatti E, et al. (2006). Acute tonsillopharyngitis associated with atypical bacterial infection in children: natural history and impact of macrolide therapy. Clin Infect Dis.
4283 Esposito S, Noviello S, D'Errico G, et al. (2006). Concentration of moxifloxacin in plasma and tonsillar tissue after multiple administration in adult patients. J Antimicrob Chemother.
4284 Essex C. (2006). Re: The implications of the David Glass case for future clinical practice in the UK. Arch Dis Child.
4285 Ewah B. (2006). An evaluation of pain, postoperative nausea and vomiting following the introduction of guidelines for tonsillectomy. Paediatr Anaesth.
4286 Ewah BN, Robb PJ, Raw M. (2006). Postoperative pain, nausea and vomiting following paediatric day-case tonsillectomy. Anaesthesia.
4287 Falagas ME, Kavvadia PK, Mantadakis E, et al. (2006). Morganella morganii infections in a general tertiary hospital. Infection.
4288 Faramarzi A, Shamseddin A, Ghaderi A. (2006). IgM, IgG Serum Levels and Lymphocytes Count before and after Adenotonsillectomy. Iran J Immunol.
4289 Farooq U, Sheikh SM, Hafeez A, et al. (2006). Post Tonsillectomy Pain: Dissection ligation vs bipolar electro dissection. Pakistan journal of otolaryngology, head and neck surgery.
4290 Felippe F, Gomes GA, de Souza BP, et al. (2006). Evaluation of the utility of histopathologic exam as a routine in tonsillectomies. Braz J Otorhinolaryngol.
4291 Firoozi F, Batniji R, Aslan AR, et al. (2006). Resolution of diurnal incontinence and nocturnal enuresis after adenotonsillectomy in children. J Urol.
4292 Firouzi F, Bahari A, Aghazadeh R, et al. (2006). Appendectomy, tonsillectomy, and risk of inflammatory bowel disease: a case control study in Iran. International journal of colorectal disease.
4293 Fox R, Tomkinson A, Myers P. (2006). Morbidity in patients waiting for tonsillectomy in Cardiff: a cross-sectional study. J Laryngol Otol.
4294 Francis A, Eltaki K, Bash T, et al. (2006). The safety of preoperative sedation in children with sleep-disordered breathing. Int J Pediatr Otorhinolaryngol.
4295 Fregosi RF, Quan SF, Morgan WL, et al. (2006). Pharyngeal critical pressure in children with mild sleep-disordered breathing. J Appl Physiol (1985).
4296 Fricke BL, Donnelly LF, Shott SR, et al. (2006). Comparison of lingual tonsil size as depicted on MR imaging between children with obstructive sleep apnea despite previous tonsillectomy and adenoidectomy and normal controls. Pediatr Radiol.
4297 Fujihara K, Koltai PJ, Hayashi M, et al. (2006). Cost-effectiveness of tonsillectomy for recurrent acute tonsillitis. Ann Otol Rhinol Laryngol.
4298 Fujimura Y, Akisada T, Harada T, et al. (2006). Uptake of microparticles into the epithelium of human nasopharyngeal lymphoid tissue. Med Mol Morphol.
4299 Gaissert HA, Grillo HC, Shadmehr MB, et al. (2006). Uncommon primary tracheal tumors. Ann Thorac Surg.
4300 Gallagher MJ, Muqit MM, Jones D, et al. (2006). Post-streptococcal uveitis. Acta Ophthalmol Scand.
4301 Galland BC, Dawes PJ, Tripp EG, et al. (2006). Changes in behavior and attentional capacity after adenotonsillectomy. Pediatr Res.
4302 Garg S, Singh H. (2006). Propofol prior to extubation: To prevent or to treat [1]. Journal of Anaesthesiology Clinical Pharmacology.
4303 Genc E, Hanci D, Ergin NT, et al. (2006). Can mucosal sealing reduce tonsillectomy pain?. Int J Pediatr Otorhinolaryngol.
4304 Glade RS, Pearson SE, Zalzal GH, et al. (2006). Coblation adenotonsillectomy: an improvement over electrocautery technique?. Otolaryngol Head Neck Surg.
4305 Goldenberg D, Sciubba J, Koch WM. (2006). Cystic metastasis from head and neck squamous cell cancer: a distinct disease variant?. Head Neck.
4306 Gordon JE, Hughes MS, Shepherd K, et al. (2006). Obstructive sleep apnoea syndrome in morbidly obese children with tibia vara. J Bone Joint Surg Br.
4307 Gorur K, Ozcan C, Talas DU. (2006). The computed tomographical and tympanometrical evaluation of mastoid pneumatization and attic blockage in patients with chronic otitis media with effusion. Int J Pediatr Otorhinolaryngol.
4308 Gozal D, Kheirandish-Gozal L. (2006). Sleep apnea in children--treatment considerations. Paediatr Respir Rev.
4309 Grimes ER, Isaacson G. (2006). The mechanical reduction of early acquired cholesteatomas in children: indications and limitations. Ear Nose Throat J.
4310 Grivea IN, Al-Lahham A, Katopodis GD, et al. (2006). Resistance to erythromycin and telithromycin in Streptococcus pyogenes isolates obtained between 1999 and 2002 from Greek children with tonsillopharyngitis: phenotypic and genotypic analysis. Antimicrob Agents Chemother.
4311 Grobler A, Carney AS. (2006). Radiofrequency coblation tonsillectomy. Br J Hosp Med (Lond).
4312 Gross D, Reuss S, Dillier CM, et al. (2006). Early vs late intraoperative administration of tropisetron for the prevention of nausea and vomiting in children undergoing tonsillectomy and/or adenoidectomy. Paediatr Anaesth.
4313 Grossan M. (2006). Readers' responses and author's reply to “the reality of ‘traditional Chinese’ medicines” [23]. MedGenMed Medscape General Medicine.
4314 Gulia JS, Singh V, Yadav SPS, et al. (2006). Giant tonsillolith in a child. International Journal of Pediatric Otorhinolaryngology Extra.
4315 Gunter JB, McAuliffe JJ, Beckman EC, et al. (2006). A factorial study of ondansetron, metoclopramide, and dexamethasone for emesis prophylaxis after adenotonsillectomy in children. Paediatr Anaesth.
4316 Guntinas-Lichius O, Peter Klussmann J, Dinh S, et al. (2006). Diagnostic work-up and outcome of cervical metastases from an unknown primary. Acta Otolaryngol.
4317 Haapkyla J, Karevold G, Kvaerner KJ, et al. (2006). Finnish adenoidectomy and tympanostomy rates in children; national variation. Int J Pediatr Otorhinolaryngol.
4318 Haddow K, Montague ML, Hussain SS. (2006). Post-tonsillectomy haemorrhage: a prospective, randomized, controlled clinical trial of cold dissection versus bipolar diathermy dissection. J Laryngol Otol.
4319 Han U, Uner A, Yimazer D. (2006). Unusual behavior of primary tonsillary lymphoma. Am J Hematol.
4320 Hanna BC, Thompson P, Smyth C, et al. (2006). Blood splash from different diathermy instruments during tonsillectomy. J Laryngol Otol.
4321 Hariharan S, Chen D, Merritt-Charles L, et al. (2006). Performance of a pediatric ambulatory anesthesia program--a developing country experience. Paediatr Anaesth.
4322 Harris D, Thomas M, Johnson D, et al. (2006). The CARI guidelines. Prevention of progression of kidney disease. Nephrology (Carlton).
4323 Hathaway B, Johnson JT. (2006). Safety of uvulopalatopharyngoplasty as outpatient surgery. Otolaryngol Head Neck Surg.
4324 Herman ST. (2006). Epilepsy and sleep. Current Treatment Options in Neurology.
4325 Herrmann BW, Sweet SC, Hayashi RJ, et al. (2006). Otolaryngological manifestations of posttransplant lymphoproliferative disorder in pediatric thoracic transplant patients. Int J Pediatr Otorhinolaryngol.
4326 Herzon FS, Martin AD. (2006). Medical and surgical treatment of peritonsillar, retropharyngeal, and parapharyngeal abscesses. Curr Infect Dis Rep.
4327 Hill CM, Hogan AM, Onugha N, et al. (2006). Increased cerebral blood flow velocity in children with mild sleep-disordered breathing: a possible association with abnormal neuropsychological function. Pediatrics.
4328 Hirschberg J, Bok S, Juhasz M, et al. (2006). Adaptation of nasometry to Hungarian language and experiences with its clinical application. Int J Pediatr Otorhinolaryngol.
4329 Hobbs CG, Rees LE, Heyderman RS, et al. (2006). Major histocompatibility complex class I expression in human tonsillar and laryngeal epithelium. Clin Exp Immunol.
4330 Hobson JC, Malla JV, Kay NJ. (2006). Horner's syndrome following tonsillectomy. J Laryngol Otol.
4331 Hockstein NG, O'Malley BW, Weinstein GS. (2006). Assessment of intraoperative safety in transoral robotic surgery. Laryngoscope.
4332 Hofmann U, O'Connor JP, Biyani CS, et al. (2006). Retroperitoneal metastatic squamous cell carcinoma of the tonsil (with elevated beta human chorionic gonadotrophin): a misdiagnosis as extra-gonadal germ cell tumour. J Laryngol Otol.
4333 Hsu WC, Lim KE, Hsu YY. (2006). Emergency endovascular balloon embolization of an active oral bleeder - A case report. Tzu Chi Medical Journal.
4334 Hullett BJ, Chambers NA, Pascoe EM, et al. (2006). Tramadol vs morphine during adenotonsillectomy for obstructive sleep apnea in children. Paediatr Anaesth.
4335 Humair JP, Revaz SA, Bovier P, et al. (2006). Management of acute pharyngitis in adults: reliability of rapid streptococcal tests and clinical findings. Arch Intern Med.
4336 Ikinciogullari A, Ikinciogullari A, Dogu F, et al. (2006). Tonsillectomy and the immune system. Int J Pediatr Otorhinolaryngol.
4337 Inoue M, Kaneko K, Akizawa K, et al. (2006). Antimicrobial susceptibility of respiratory tract pathogens in Japan during PROTEKT years 1-3 (1999-2002). J Infect Chemother.
4338 Ironside JW, Bishop MT, Connolly K, et al. (2006). Variant Creutzfeldt-Jakob disease: prion protein genotype analysis of positive appendix tissue samples from a retrospective prevalence study. BMJ.
4339 Isenberg SF. (2006). Double trouble. Ear Nose Throat J.
4340 Isenberg SF. (2006). Modifier 78. Ear Nose Throat J.
4341 Ivarsson M, Lundin BS. (2006). Cytokines produced by T cells in adenoid surface secretion are mainly downregulatory or of Th1 type. Acta Otolaryngol.
4342 Iyer S, DeFoor W, Grocela J, et al. (2006). The use of perioperative antibiotics in tonsillectomy: does it decrease morbidity?. Int J Pediatr Otorhinolaryngol.
4343 Iyngkaran T, Kanagalingam J, Rajeswaran R, et al. (2006). Long-term outcomes of laser-assisted uvulopalatoplasty in 168 patients with snoring. J Laryngol Otol.
4344 Jalaludhin J, Fischer J, Malek I, et al. (2006). The effect of postoperative instructions after tonsillectomy and adenoidectomy.
4345 Jansen AG, Sanders EA, Schilder AG, et al. (2006). Primary care management of respiratory tract infections in Dutch preschool children. Scand J Prim Health Care.
4346 Jesic S, Stojiljkovic L, Petrovic Z, et al. (2006). Alteration of adenoid tissue alkaline and acid phosphatase in children with secretory otitis media. Int J Pediatr Otorhinolaryngol.
4347 Jimenez A, Lopez-Gonzalez MA, Solano F, et al. (2006). Hypomethylation of DNA and resistance to apoptosis in tonsillar hypertrophy in children. Pediatr Allergy Immunol.
4348 Jo SH. (2006). Randomized controlled trial of FloSeal in adenotonsillectomy. Otolaryngology - Head and Neck Surgery.
4349 Johr M. (2006). Anaesthesia for tonsillectomy. Curr Opin Anaesthesiol.
4350 Jombo GT, Egah DZ, Banwat EB. (2006). Human immunodeficiency virus infection in a rural community of plateau state: effective control measures still a nightmare?. Niger J Med.
4351 Joshua B, Bahar G, Sulkes J, et al. (2006). Adenoidectomy: long-term follow-up. Otolaryngol Head Neck Surg.
4352 Jprn C. (2006). The effects of tonsillectomy and steroid pulse therapy in patients with IgA nephropathy : multicenter,radomized trial. JPRN [www.umin.ac.jp].
4353 Judd O, Garise F. (2006). Double-blind randomised controlled study of coblation tonsillotomy versus coblation tonsillectomy on postoperative pain in children. Clin Otolaryngol.
4354 Just T, Gafumbegete E, Gramberg J, et al. (2006). Differential proteome analysis of tonsils from children with chronic tonsillitis or with hyperplasia reveals disease-associated protein expression differences. Anal Bioanal Chem.
4355 Kaddoum RN, Chidiac EJ, Zestos MM, et al. (2006). Electrocautery-induced fire during adenotonsillectomy: report of two cases. J Clin Anesth.
4356 Kain ZN, Mayes LC, Caldwell-Andrews AA, et al. (2006). Preoperative anxiety, postoperative pain, and behavioral recovery in young children undergoing surgery. Pediatrics.
4357 Kalantar N, Takehana CS, Shapiro NL. (2006). Outcomes of reduced postoperative stay following outpatient pediatric tonsillectomy. Int J Pediatr Otorhinolaryngol.
4358 Kalyoncu M, Acar BC, Cakar N, et al. (2006). Are carriers for MEFV mutations “healthy”?. Clin Exp Rheumatol.
4359 Kang WL, Balakrishnan A. (2006). Operative workload of a paediatric otolaryngology department over a five-year period. Singapore Med J.
4360 Kanniah SK. (2006). Laryngeal mask airway and tonsillectomy. Anesth Analg.
4361 Karatzias GT, Lachanas VA, Sandris VG. (2006). Thermal welding versus bipolar tonsillectomy: a comparative study. Otolaryngol Head Neck Surg.
4362 Karevold G, Kvestad E, Nafstad P, et al. (2006). Respiratory infections in schoolchildren: co-morbidity and risk factors. Arch Dis Child.
4363 Kaur S, Gupta A, Sharma A, et al. (2006). Role of propofol in prevention of extubation related complications in oral surgery. Journal of Anaesthesiology Clinical Pharmacology.
4364 Kawasaki Y, Takano K, Suyama K, et al. (2006). Efficacy of tonsillectomy pulse therapy versus multiple-drug therapy for IgA nephropathy. Pediatr Nephrol.
4365 Kaylie DM, Wittkopf JE, Coppit G, et al. (2006). Revision lateral skull base surgery. Otol Neurotol.
4366 Kelley PE. (2006). Painless tonsillectomy. Curr Opin Otolaryngol Head Neck Surg.
4367 Kendrisic M, Ivic G, Kendrisic ML. (2006). Volatile induction maintenance anaesthesia (VIMA) with sevoflurane for tonsillectomy in children.
4368 Kerschner JE, Conley SF, Cook SP. (2006). Surgical techniques of pediatric tonsillectomy: Is there evidence of better outcomes?. Operative Techniques in Otolaryngology - Head and Neck Surgery.
4369 Khan F, Asif M, Farooqi GH, et al. (2006). Management outcome of secretory otitis media. J Ayub Med Coll Abbottabad.
4370 Kheirandish L, Goldbart AD, Gozal D. (2006). Intranasal steroids and oral leukotriene modifier therapy in residual sleep-disordered breathing after tonsillectomy and adenoidectomy in children. Pediatrics.
4371 Kheirandish-Gozal L, Capdevila OS, Tauman R, et al. (2006). Plasma C-reactive protein in nonobese children with obstructive sleep apnea before and after adenotonsillectomy. J Clin Sleep Med.
4372 Kiroglu AF, Noyan T, Oger M, et al. (2006). Oxidants and antioxidants in tonsillar and adenoidal tissue in chronic adenotonsillitis and adenotonsillar hypertrophy in children. Int J Pediatr Otorhinolaryngol.
4373 Kluszynski BA, Matt BH. (2006). Lingual tonsillectomy in a child with obstructive sleep apnea: a novel technique. Laryngoscope.
4374 Knutsson J, Tibbelin A, Von Unge M. (2006). Postoperative pain after paediatric adenoidectomy and differences between the pain scores made by the recovery room staff, the parent and the child. Acta Otolaryngol.
4375 Knutsson J, Tibbelin A, Von Unge M. (2006). Adjuvant local anaesthetics in the epipharyngeal space in day-case adenoidectomy: a prospective, randomized, double-blind, placebo-controlled trial. Acta Otolaryngol.
4376 Koempel JA, Solares CA, Koltai PJ. (2006). The evolution of tonsil surgery and rethinking the surgical approach to obstructive sleep-disordered breathing in children. J Laryngol Otol.
4377 Kohdera U, Kino M, Ito M. (2006). Detection of adenovirus DNA in throat swabs and blood by SYBR green real-time PCR assay in patients with adenovirus-associated tonsillitis. Jpn J Infect Dis.
4378 Kum-Nji P, Mangrem CL, Wells PJ, et al. (2006). Black/white differential use of health services by young children in a rural Mississippi community. South Med J.
4379 Kurnatowski P, Putynski L, Lapienis M, et al. (2006). Neurocognitive abilities in children with adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
4380 Kvestad E, Kvaerner KJ, Roysamb E, et al. (2006). Recurrent otitis media and tonsillitis: common disease predisposition. Int J Pediatr Otorhinolaryngol.
4381 Lam YY, Chan EY, Ng DK, et al. (2006). The correlation among obesity, apnea-hypopnea index, and tonsil size in children. Chest.
4382 Landis BN, Lacroix JS. (2006). Postoperative/posttraumatic gustatory dysfunction. Adv Otorhinolaryngol.
4383 Lankinen U, Avela R, Tarkkila P. (2006). The prevention of emergence agitation with tropisetron or clonidine after sevoflurane anesthesia in small children undergoing adenoidectomy. Anesth Analg.
4384 Laureyns G, Lemkens P, Jorissen M. (2006). Tonsillectomy as a day-case surgery: a safe procedure?. B-ENT.
4385 Lawson R. (2006). Anaesthesia for paediatric ENT surgery. Anaesthesia and Intensive Care Medicine.
4386 Lee SM, Kwon BC, Choi SY, et al. (2006). Peritonsillar abscess in a 40-day-old infant. Yonsei Med J.
4387 Leiberman A, Stiller-Timor L, Tarasiuk A, et al. (2006). The effect of adenotonsillectomy on children suffering from obstructive sleep apnea syndrome (OSAS): the Negev perspective. Int J Pediatr Otorhinolaryngol.
4388 Leong SC, Karkos PD, Apostolidou MT. (2006). Is there a role for the otolaryngologist in PFAPA syndrome? A systematic review. Int J Pediatr Otorhinolaryngol.
4389 Lesmeister MJ, Bothwell MR, Misfeldt ML. (2006). Toll-like receptor expression in the human nasopharyngeal tonsil (adenoid) and palantine tonsils: a preliminary report. Int J Pediatr Otorhinolaryngol.
4390 Li HY, Huang YS, Chen NH, et al. (2006). Impact of adenotonsillectomy on behavior in children with sleep-disordered breathing. Laryngoscope.
4391 Liapi A, Dhanasekar G, Turner NO. (2006). Role of revision adenoidectomy in paediatric otolaryngological practice. J Laryngol Otol.
4392 Licup AT, Arkia H, Mabel A, et al. (2006). Partial neurolysis of the hypoglossal nerve for selective lingual atrophy in a porcine model. Ann Otol Rhinol Laryngol.
4393 Lin S. (2006). Hot versus cold tonsillectomy. Otolaryngol Head Neck Surg.
4394 Lister MT, Cunningham MJ, Benjamin B, et al. (2006). Microdebrider tonsillotomy vs electrosurgical tonsillectomy: a randomized, double-blind, paired control study of postoperative pain. Arch Otolaryngol Head Neck Surg.
4395 Llorente JL, Nazar G, Cabanillas R, et al. (2006). Subtemporal-preauricular approach in the management of infratemporal and nasopharyngeal tumours. J Otolaryngol.
4396 Lloyd CA, Jacob SE, Menon T. (2006). Pharyngeal carriage of group A streptococci in school children in Chennai. Indian J Med Res.
4397 Lo S, Rowe-Jones J. (2006). How we do it: Transoral suction diathermy adenoid ablation under direct vision using a 45 degree endoscope. Clin Otolaryngol.
4398 Locatelli F, Vecchio LD, Pozzi C. (2006). IgA glomerulonephritis: beyond angiotensin-converting enzyme inhibitors. Nat Clin Pract Nephrol.
4399 Loganathan A, Arumainathan UD, Raman R. (2006). Comparative study of bacteriology in recurrent tonsillitis among children and adults. Singapore Med J.
4400 Louizos AA, Pandazi AB, Koraka CP, et al. (2006). Preoperative administration of rofecoxib versus ketoprofen for pain relief after tonsillectomy. Annals of otology, rhinology, and laryngology.
4401 Lynch NE, Deiratany S, Webb DW, et al. (2006). PANDAS (Paediatric Autoimmune Neuropsychiatric Disorder Associated with Streptococcal Infection). Ir Med J.
4402 Mahakit P, Vicente JG, Butt DI, et al. (2006). Oral clindamycin 300 mg BID compared with oral amoxicillin/clavulanic acid 1 g BID in the outpatient treatment of acute recurrent pharyngotonsillitis caused by group a beta-hemolytic streptococci: an international, multicenter, randomized, investigator-blinded, prospective trial in patients between the ages of 12 and 60 years. Clin Ther.
4403 Malow BA, McGrew SG, Harvey M, et al. (2006). Impact of treating sleep apnea in a child with autism spectrum disorder. Pediatr Neurol.
4404 Mansson A, Adner M, Cardell LO. (2006). Toll-like receptors in cellular subsets of human tonsil T cells: altered expression during recurrent tonsillitis. Respir Res.
4405 Mansson A, Adner M, Hockerfelt U, et al. (2006). A distinct Toll-like receptor repertoire in human tonsillar B cells, directly activated by PamCSK, R-837 and CpG-2006 stimulation. Immunology.
4406 Marcus CL, Rosen G, Ward SL, et al. (2006). Adherence to and effectiveness of positive airway pressure therapy in children with obstructive sleep apnea. Pediatrics.
4407 Martens PJ, Fransoo R, Burchill C, et al. (2006). Health status and healthcare use patterns of rural, northern and urban Manitobans: is Romanow right?. Healthc Policy.
4408 Martinho FL, Zonato AI, Bittencourt LR, et al. (2006). Obese obstructive sleep apnea patients with tonsil hypertrophy submitted to tonsillectomy. Braz J Med Biol Res.
4409 Maturo SC, Mair EA. (2006). Coblation lingual tonsillectomy. Otolaryngol Head Neck Surg.
4410 McCluney NA, Lee MSW, Loveland M, et al. (2006). Patient pre-assessment demonstrated as an effective tool in providing an efficient ENT service: A prospective closed loop audit of adult in-patient pre-assessment. Otorhinolaryngologist.
4411 McGirt MJ, Nimjee SM, Fuchs HE, et al. (2006). Relationship of cine phase-contrast magnetic resonance imaging with outcome after decompression for Chiari I malformations. Neurosurgery.
4412 McKean S, Kochilas X, Kelleher R, et al. (2006). Use of intravenous steroids at induction of anaesthesia for adult tonsillectomy to reduce post-operative nausea and vomiting and pain: a double-blind randomized controlled trial. Clin Otolaryngol.
4413 Megale SR, Scanavini AB, Andrade EC, et al. (2006). Gastroesophageal reflux disease: its importance in ear, nose, and throat practice. Int J Pediatr Otorhinolaryngol.
4414 Mehta VM, Har-El G, Goldstein NA. (2006). Postobstructive pulmonary edema after laryngospasm in the otolaryngology patient. Laryngoscope.
4415 Melgarejo Moreno P, Hellin Meseguer D, Marco Garrido A, et al. (2006). A correlation between age and Actinomyces in the adenotonsillar tissue of children. B-ENT.
4416 Mendonca R, Lima TT, Oppitz PP, et al. (2006). Herniation of the cerebellar tonsils after suprasellar arachnoid cyst shunt: case report. Arq Neuropsiquiatr.
4417 Meyer JE, Beier UH, Gorogh T, et al. (2006). Defensin and chemokine expression patterns in the palatine tonsil: a model of their local interaction. Eur Arch Otorhinolaryngol.
4418 Mikkelsen S, Hilsted KL, Andersen PJ, et al. (2006). The effect of gabapentin on post-operative pain following tonsillectomy in adults. Acta Anaesthesiol Scand.
4419 Miller J, Silverstein J, Shuster J, et al. (2006). Short-term effects of growth hormone on sleep abnormalities in Prader-Willi syndrome. J Clin Endocrinol Metab.
4420 Mitchell RB, Kelly J. (2006). Long-term changes in behavior after adenotonsillectomy for obstructive sleep apnea syndrome in children. Otolaryngol Head Neck Surg.
4421 Mitchell RB, Pereira KD, Friedman NR. (2006). Sleep-disordered breathing in children: survey of current practice. Laryngoscope.
4422 MJ DAC, Bruggemann DACD, Carneiro Leao C. (2006). Effect of an intravenous single dose of ketamine on postoperative pain in tonsillectomy patients. Paediatr Anaesth.
4423 Monfared A, Messner A. (2006). Death following tonsillectomy in a child with Williams syndrome. Int J Pediatr Otorhinolaryngol.
4424 Morer A, Vinas O, Lazaro L, et al. (2006). Subtyping obsessive-compulsive disorder: clinical and immunological findings in child and adult onset. J Psychiatr Res.
4425 Moss IR, Brown KA, Laferriere A. (2006). Recurrent hypoxia in rats during development increases subsequent respiratory sensitivity to fentanyl. Anesthesiology.
4426 Mowatt G, Cook JA, Fraser C, et al. (2006). Systematic review of the safety of electrosurgery for tonsillectomy. Clin Otolaryngol.
4427 Mulwafu W, Fagan JJ, Isaacs S. (2006). Adult tonsillectomy--are long waiting lists putting patients at risk?. S Afr J Surg.
4428 Myers NE, Compliment JM, Post JC, et al. (2006). Tonsilloliths a common finding in pediatric patients. Nurse Pract.
4429 Nakata S, Noda A, Yanagi E, et al. (2006). Tonsil size and body mass index are important factors for efficacy of simple tonsillectomy in obstructive sleep apnoea syndrome. Clin Otolaryngol.
4430 Neri G, Baffa C, Vitullio F, et al. (2006). Single-blind evaluation of post-tonsillectomy pain treatment with an eutectic mixture of local anesthetics. European Journal of Inflammation.
4431 Njoroge GN, Bussmann RW. (2006). Traditional management of ear, nose and throat (ENT) diseases in Central Kenya. J Ethnobiol Ethnomed.
4432 Noordzij JP, Affleck BD. (2006). Coblation versus unipolar electrocautery tonsillectomy: a prospective, randomized, single-blind study in adult patients. Laryngoscope.
4433 Nze PU, Onyekwulu F. (2006). Intraoperative diclofenac for post-adenoidectomy analgesia in small children. Niger J Clin Pract.
4434 O'Brien LM, Sitha S, Baur LA, et al. (2006). Obesity increases the risk for persisting obstructive sleep apnea after treatment in children. Int J Pediatr Otorhinolaryngol.
4435 Odemis E, Catal F, Karadag A, et al. (2006). Assessment of cardiac function and rheumatic heart disease in children with adenotonsillar hypertrophy. J Natl Med Assoc.
4436 Oluwasanmi AF, Thornton MR, Khalil HS, et al. (2006). Effect of tonsillectomy on recurrent sore throats in adults: patients' perspectives. J Laryngol Otol.
4437 Oluwasanmi AF, Wood SJ, Baldwin DL, et al. (2006). Malignancy in asymmetrical but otherwise normal palatine tonsils. Ear Nose Throat J.
4438 Onodera K, Niikuni N, Chigono T, et al. (2006). Sleep disordered breathing in children with achondroplasia. Part 2. Relationship with craniofacial and airway morphology. Int J Pediatr Otorhinolaryngol.
4439 Osuagwu FC, Lazareff JA, Rahman S, et al. (2006). Chiari I anatomy after ventriculoperitoneal shunting: posterior fossa volumetric evaluation with MRI. Childs Nerv Syst.
4440 Owczarzak V, Haddad J. (2006). Comparison of oral versus rectal administration of acetaminophen with codeine in postoperative pediatric adenotonsillectomy patients. Laryngoscope.
4441 Ozcan E, Ural A, Oktemer TK, et al. (2006). Bilateral tonsillolithiasis: a case report. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
4442 Ozlugedik S, Genc S, Unal A, et al. (2006). Can postoperative pains following tonsillectomy be relieved by honey? A prospective, randomized, placebo controlled preliminary study. Int J Pediatr Otorhinolaryngol.
4443 Palmer JM. (2006). Bipolar radiofrequency for adenoidectomy. Otolaryngol Head Neck Surg.
4444 Pang KP. (2006). Lateral pharyngoplasty in the treatment of obstructive sleep apnea. Operative Techniques in Otolaryngology - Head and Neck Surgery.
4445 Pang KP, Woodson BT. (2006). Expansion sphincter pharyngoplasty in the treatment of obstructive sleep apnea. Operative Techniques in Otolaryngology - Head and Neck Surgery.
4446 Parell GJ. (2006). How I do it: Control of post-tonsillectomy bleeding with the tonsil lolly. Ear Nose Throat J.
4447 Parikh SR, Coronel M, Lee JJ, et al. (2006). Validation of a new grading system for endoscopic examination of adenoid hypertrophy. Otolaryngol Head Neck Surg.
4448 Patiar S, Lo S, Duvvi S, et al. (2006). Patient satisfaction with NHS elective tonsillectomy outsourced to the private sector under the Patient Choice Programme. J Eval Clin Pract.
4449 Pavone M, Paglietti MG, Petrone A, et al. (2006). Adenotonsillectomy for obstructive sleep apnea in children with Prader-Willi syndrome. Pediatr Pulmonol.
4450 Petersen I, Thomas JM, Hamilton WT, et al. (2006). Risk and predictors of fatigue after infectious mononucleosis in a large primary-care cohort. Qjm.
4451 Philpott CM, Tassone P. (2006). Randomised-controlled study comparing post-operative pain between coblation palatoplasty and laser palatoplasty. Clin Otolaryngol.
4452 Plug I, Mauser-Bunschoten EP, Brocker-Vriends AH, et al. (2006). Bleeding in carriers of hemophilia. Blood.
4453 Polites N, Joniau S, Wabnitz D, et al. (2006). Postoperative pain following coblation tonsillectomy: randomized clinical trial. ANZ journal of surgery.
4454 Poulios A, Prior M. (2006). Is day case tonsillectomy achievable within the ‘payment by results’ policy in remote areas?. Clin Otolaryngol.
4455 Price T, Pickles J. (2006). Synchronous bilateral tonsillar carcinoma: role of fluoro-deoxyglucose positron emission tomography scanning in detecting occult primary tumours in metastatic nodal disease of the head and neck. J Laryngol Otol.
4456 Qiu Y, Zhu Z, Wang B, et al. (2006). Abnormal spread of junctional acetylcholine receptor of paraspinal muscles in scoliosis associated with syringomyelia. Stud Health Technol Inform.
4457 Qureshi SS, Chaukar DA, Talole SD, et al. (2006). Clinical characteristics and outcome of non-squamous cell malignancies of the maxillary sinus. J Surg Oncol.
4458 Rallis E, Balatsouras DG, Kouskoukis C, et al. (2006). Drug eruptions in children with ENT infections. Int J Pediatr Otorhinolaryngol.
4459 Ramos RT, da Cunha Daltro CH, Gregorio PB, et al. (2006). OSAS in children: clinical and polysomnographic respiratory profile. Braz J Otorhinolaryngol.
4460 Reilly MJ, Milmoe G, Pena M. (2006). Three extraordinary complications of adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
4461 Ribeiro KM, Alvez JM, Pignatari SS, et al. (2006). Detection of human papilloma virus in the tonsils of children undergoing tonsillectomy. Braz J Infect Dis.
4462 Ricciardiello F, Martufi S, Cardone M, et al. (2006). Otorhinolaryngology-related tuberculosis. Acta Otorhinolaryngol Ital.
4463 Richter GT, Bower CM. (2006). Cervical complications following routine tonsillectomy and adenoidectomy. Curr Opin Otolaryngol Head Neck Surg.
4464 Robb PJ. (2006). Meta-analysis of the timing of haemorrhage after tonsillectomy. Clin Otolaryngol.
4465 Robinson S, Ettema SL, Brusky L, et al. (2006). Lingual tonsillectomy using bipolar radiofrequency plasma excision. Otolaryngol Head Neck Surg.
4466 Roemmich JN, Barkley JE, D'Andrea L, et al. (2006). Increases in overweight after adenotonsillectomy in overweight children with obstructive sleep-disordered breathing are associated with decreases in motor activity and hyperactivity. Pediatrics.
4467 Roosli C, Schneider S, Hausler R. (2006). Long-term results and complications following uvulopalatopharyngoplasty in 116 consecutive patients. Eur Arch Otorhinolaryngol.
4468 Rudnick EF, Mitchell RB. (2006). Improvements in quality of life in children after surgical therapy for sinonasal disease. Otolaryngol Head Neck Surg.
4469 Rufener JB, Yaremchuk KL, Payne SC. (2006). Evaluation of culture and antibiotic use in patients with pharyngitis. Laryngoscope.
4470 Ruotolo RA, Veitia NA, Corbin A, et al. (2006). Velopharyngeal anatomy in 22q11.2 deletion syndrome: a three-dimensional cephalometric analysis. Cleft Palate Craniofac J.
4471 Sanchez-Carrion S, Prim MP, De Diego JI, et al. (2006). Utility of prophylactic antibiotics in pediatric adenoidectomy. Int J Pediatr Otorhinolaryngol.
4472 Sanders JC, King MA, Mitchell RB, et al. (2006). Perioperative complications of adenotonsillectomy in children with obstructive sleep apnea syndrome. Anesth Analg.
4473 Saussez S, Mahillon V, Haller A, et al. (2006). Clinically unsuspected tonsillar sarcoidosis in a child revealed by routine histologic examination. Int J Pediatr Otorhinolaryngol.
4474 Scott A. (2006). Hot techniques for tonsillectomy. Issues Emerg Health Technol.
4475 Sery O, Hrazdilova O, Didden W, et al. (2006). The association of monoamine oxidase B functional polymorphism with postoperative pain intensity. Neuro Endocrinol Lett.
4476 Sharifian HA, Fathololoomi MR, Fattahi Bafghi A, et al. (2006). Effect of local bupivacaine infiltration on post-tonsillectomy pain. Tanaffos.
4477 Shi ZP, Wang CC, Lee JC, et al. (2006). Post-tonsillectomy hematoma of the mouth floor. Eur Arch Otorhinolaryngol.
4478 Shine NP, Coates HL, Lannigan FJ, et al. (2006). Adenotonsillar surgery in morbidly obese children: routine elective admission of all patients to the intensive care unit is unnecessary. Anaesth Intensive Care.
4479 Shine NP, Lannigan FJ, Coates HL, et al. (2006). Adenotonsillectomy for obstructive sleep apnea in obese children: effects on respiratory parameters and clinical outcome. Arch Otolaryngol Head Neck Surg.
4480 Sie KC. (2006). Cleft palate speech and velopharyngeal insufficiency: surgical approach. B-ENT.
4481 Silva VC, Leite AJ. (2006). Quality of life in children with sleep-disordered breathing: evaluation by OSA-18. Braz J Otorhinolaryngol.
4482 Simurina T, Mikulandra S, Mraovic B, et al. (2006). The effect of propofol and fentanyl as compared with sevoflurane on postoperative vomiting in children after adenotonsillectomy. Coll Antropol.
4483 Singh GB, Yadav SP, Singh J. (2006). Comrarative study of infiltration and surface application of bupivacaine in post tonsillectomy pain. Indian J Otolaryngol Head Neck Surg.
4484 Singh SK, Gupta AK, Jha V, et al. (2006). Treatment of oropharyngeal cancer in renal transplant recipients without cessation of immunosuppressive therapy. Transplant Proc.
4485 Sisk J, Schweinfurth JM, Wang XT, et al. (2006). Presence of human papillomavirus DNA in tonsillectomy specimens. Laryngoscope.
4486 Song JJ, Hwang KS, Woo JS, et al. (2006). Expression of cathelicidin in recurrent throat infection. Int J Pediatr Otorhinolaryngol.
4487 Statham MM, Elluru RG, Buncher R, et al. (2006). Adenotonsillectomy for obstructive sleep apnea syndrome in young children: prevalence of pulmonary complications. Arch Otolaryngol Head Neck Surg.
4488 Stern Y, Segal K, Yaniv E. (2006). Endoscopic adenoidectomy in children with submucosal cleft palate. Int J Pediatr Otorhinolaryngol.
4489 Street I, Beech T, Jennings C. (2006). The Birmingham trainer: a simulator for ligating the lower tonsillar pole. Clin Otolaryngol.
4490 Su WY, Hsu WC, Wang CP. (2006). Inferior pole peritonsillar abscess successfully treated with non-surgical approach in four cases. Tzu Chi Medical Journal.
4491 Sunkaraneni VS, Jones SE, Prasai A, et al. (2006). Is unilateral tonsillar enlargement alone an indication for tonsillectomy?. J Laryngol Otol.
4492 Suratt PM, Peruggia M, D'Andrea L, et al. (2006). Cognitive function and behavior of children with adenotonsillar hypertrophy suspected of having obstructive sleep-disordered breathing. Pediatrics.
4493 Suvilehto J, Roivainen M, Seppanen M, et al. (2006). Rhinovirus/enterovirus RNA in tonsillar tissue of children with tonsillar disease. J Clin Virol.
4494 Svancara P, Horacek J, Vokral J, et al. (2006). Computational modelling of effect of tonsillectomy on voice production. Logoped Phoniatr Vocol.
4495 Tabaee A, Lin JW, Dupiton V, et al. (2006). The role of oral fluid intake following adeno-tonsillectomy. Int J Pediatr Otorhinolaryngol.
4496 Taghipour M, Zamanizadeh B, Zare Z. (2006). Brain abscess after tonsillectomy. Neurosurgery Quarterly.
4497 Takasaki K, Kitaoka K, Kaieda S, et al. (2006). A case of actinomycosis causing unilateral tonsillar hypertrophy. Acta Otolaryngol.
4498 Tan AK, Hsu PP, Eng SP, et al. (2006). Coblation vs electrocautery tonsillectomy: postoperative recovery in adults. Otolaryngology--head and neck surgery.
4499 Tariq MA, Kamran M. (2006). Incidence of pain on propofol injection and efficacy of addition of lignocaine or selecting big vein or both combined in reducing it: A randomized control trial. Journal of Postgraduate Medical Institute.
4500 Tasher D, Somekh E, Dalal I. (2006). PFAPA syndrome: new clinical aspects disclosed. Arch Dis Child.
4501 Tauman R, Gulliver TE, Krishna J, et al. (2006). Persistence of obstructive sleep apnea syndrome in children after adenotonsillectomy. J Pediatr.
4502 Teppo H, Virkkunen H, Revonta M. (2006). Topical adrenaline in the control of intraoperative bleeding in adenoidectomy: a randomised, controlled trial. Clin Otolaryngol.
4503 Tomasini C, Seia Z, Dapavo P, et al. (2006). Infantile erythema elevatum diutinum: report of a vesiculo-bullous case. Eur J Dermatol.
4504 Tsikoudas A, Davage M, Gardiner Q. (2006). Evidence based management of infectious monomucleosis with antibiotics and steroids. An ENT perspective. Otorhinolaryngologist.
4505 Tsuboi H, Katsuoka K. (2006). Pustulosis palmaris et plantaris with prominent hyperkeratosis of the soles. J Dermatol.
4506 Ungkanont K, Areyasathidmon S. (2006). Factors affecting quality of life of pediatric outpatients with symptoms suggestive of sleep-disordered breathing. Int J Pediatr Otorhinolaryngol.
4507 Vaiman M, Krakovski D, Gavriel H. (2006). Fibrin sealant reduces pain after tonsillectomy: prospective randomized study. Annals of otology, rhinology, and laryngology.
4508 Vaiman M, Krakovsky D, Eviatar E. (2006). The influence of tonsillitis on oral and throat muscles in children. Int J Pediatr Otorhinolaryngol.
4509 Valera FC, Trawitzki LV, Anselmo-Lima WT. (2006). Myofunctional evaluation after surgery for tonsils hypertrophy and its correlation to breathing pattern: a 2-year-follow up. Int J Pediatr Otorhinolaryngol.
4510 van den Akker EH, Sanders EA, van Staaij BK, et al. (2006). Long-term effects of pediatric adenotonsillectomy on serum immunoglobulin levels: results of a randomized controlled trial. Ann Allergy Asthma Immunol.
4511 van der Veen EL, Sanders EA, Videler WJ, et al. (2006). Optimal site for throat culture: tonsillar surface versus posterior pharyngeal wall. Eur Arch Otorhinolaryngol.
4512 van Hattum ES, Balemans WA, Rovers MM, et al. (2006). Adenoidectomy and/or tonsillectomy in childhood is not associated with atopic disease later in life. Clin Exp Allergy.
4513 Varricchio A, Tricarico D, De Lucia A, et al. (2006). Inhaled tobramycin in children with acute bacterial rhinopharyngitis. Int J Immunopathol Pharmacol.
4514 Verse T, Baisch A, Maurer JT, et al. (2006). Multilevel surgery for obstructive sleep apnea: short-term results. Otolaryngology--head and neck surgery : official journal of American Academy of Otolaryngology-Head and Neck Surgery.
4515 Vilella Bde S, Vilella Ode V, Koch HA. (2006). Growth of the nasopharynx and adenoidal development in Brazilian subjects. Braz Oral Res.
4516 Wasserman JM, Sclafani SJ, Goldstein NA. (2006). Intraoperative evaluation of a pulsatile oropharyngeal mass during adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
4517 Weber SA, Lima Neto AC, Ternes FJ, et al. (2006). Hyperactivity and attention deficit syndrome in obstructive sleep apnea syndrome: is there improvement with surgical management?. Braz J Otorhinolaryngol.
4518 Weissbach A, Leiberman A, Tarasiuk A, et al. (2006). Adenotonsilectomy improves enuresis in children with obstructive sleep apnea syndrome. Int J Pediatr Otorhinolaryngol.
4519 Whatley WS, Thompson JW, Rao B. (2006). Salivary gland tumors in survivors of childhood cancer. Otolaryngol Head Neck Surg.
4520 Williams MD, Chakravarti N, Kies MS, et al. (2006). Implications of methylation patterns of cancer genes in salivary gland tumors. Clin Cancer Res.
4521 Wilson ME, Helgadottir HL. (2006). Patterns of pain and analgesic use in 3- to 7-year-old children after tonsillectomy. Pain Manag Nurs.
4522 Xu C, Sin S, McDonough JM, et al. (2006). Computational fluid dynamics modeling of the upper airway of children with obstructive sleep apnea syndrome in steady flow. J Biomech.
4523 Xu Z, Cheuk DK, Lee SL. (2006). Clinical evaluation in predicting childhood obstructive sleep apnea. Chest.
4524 Xu ZF, Cheuk DK, Lee SL. (2006). Efficacy of tonsillectomy and adenoidectomy in Asian childhood obstructive sleep apnea/hypopnea syndrome: a case control study. Zhongguo Dang Dai Er Ke Za Zhi.
4525 Yasan H, Dogru H, Candir O, et al. (2006). Incidence of unexpected pathology in routine adenoidectomy specimens. Int J Pediatr Otorhinolaryngol.
4526 Yeh DD, Koch B, Crone KR. (2006). Intraoperative ultrasonography used to determine the extent of surgery necessary during posterior fossa decompression in children with Chiari malformation type I. J Neurosurg.
4527 Yildirim SV, Durmaz C, Pourbagher MA, et al. (2006). A case of achondroplasia with severe pulmonary hypertension due to obstructive sleep apnea. Eur Arch Otorhinolaryngol.
4528 Yilmaz F, Gunduz H, Karaaslan K, et al. (2006). Holter analyses in children with adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
4529 Yilmaz T, Ceylan M, Akyon Y, et al. (2006). Helicobacter pylori: a possible association with otitis media with effusion. Otolaryngol Head Neck Surg.
4530 Yokoi H, Okayama Y, Niyonsaba F, et al. (2006). Comparison of human tonsillar mast cell localization and ultrastructural observations between IgE-mediated allergic and nonallergic donors. Allergy Asthma Proc.
4531 Yousefi M, Payne JR, Barnhill RL. (2006). Alopecia areata associated with regression of cutaneous melanoma. Int J Dermatol.
4532 Yousuf K, Lui B, Lemckert R, et al. (2006). Recurrent adult epiglottitis: contiguous spread from group A streptococcus lingual tonsillitis. J Otolaryngol.
4533 Zakrzewska A, Gryczynska D, Kobos J, et al. (2006). Expression of Fas ligand and CTLA4 in adenoids has a predictive value for allergic rhinitis development in children. Int Arch Allergy Immunol.
4534 Zettergren-Wijk L, Forsberg CM, Linder-Aronson S. (2006). Changes in dentofacial morphology after adeno-/tonsillectomy in young children with obstructive sleep apnoea--a 5-year follow-up study. Eur J Orthod.
4535 Zhang Q, Bernatoniene J, Bagrade L, et al. (2006). Serum and mucosal antibody responses to pneumococcal protein antigens in children: relationships with carriage status. Eur J Immunol.
4536 Zhang XW, Zhou F, Li Y, et al. (2006). Sleep architecture in children with adenoidal hypertrophy. J Paediatr Child Health.
4537 Zhibin W, Min J. (2006). Design and clinical application of the ‘styloidectome’ styloid process cutter. J Laryngol Otol.
4538 Ziliotto KN, dos Santos MF, Monteiro VG, et al. (2006). Auditory processing assessment in children with obstructive sleep apnea syndrome. Braz J Otorhinolaryngol.
4539 Zonato AI, Bittencourt LR, Martinho FL, et al. (2006). Upper airway surgery: the effect on nasal continuous positive airway pressure titration on obstructive sleep apnea patients. Eur Arch Otorhinolaryngol.
4540 Zuliani G, Carron M, Gurrola J, et al. (2006). Identification of adenoid biofilms in chronic rhinosinusitis. Int J Pediatr Otorhinolaryngol.
4541 (2007). Amoxicillin pulsatile - MiddleBrook: APC 111, APC-111, PULSYS-enhanced amoxicillin. Drugs R D.
4542 Abd El-Fattah AM, Abdul Maksoud GA, Ramadan AS, et al. (2007). Pepsin assay: a marker for reflux in pediatric glue ear. Otolaryngol Head Neck Surg.
4543 Aboushanab OA, Alotaibi SA, Shaalan YA. (2007). Late onset central hypoventilation syndrome with hypothalamic dysfunction in a Kuwaiti girl. Kuwait Medical Journal.
4544 Abu-Shahwan I. (2007). Ambulatory anesthesia and the lack of consensus among Canadian pediatric anesthesiologists: a survey. Paediatr Anaesth.
4545 Adam MP, Abramowsky CR, Brady AN, et al. (2007). Rhabdomyomatous hamartomata of the pharyngeal region with bilateral microtia and aural atresia: a new association?. Birth Defects Res A Clin Mol Teratol.
4546 Ahsan F, Rashid H, Eng C, et al. (2007). Is secondary haemorrhage after tonsillectomy in adults an infective condition? Objective measures of infection in a prospective cohort. Clin Otolaryngol.
4547 Aktepe F, Sahin O, Dilek H, et al. (2007). Immunohistochemical assesment of heat shock protein 70 in adenoid tissue. Int J Pediatr Otorhinolaryngol.
4548 Alho OP, Koivunen P, Penna T, et al. (2007). Tonsillectomy versus watchful waiting in recurrent streptococcal pharyngitis in adults: randomised controlled trial. BMJ.
4549 Al-Khateeb TH, Ababneh KT. (2007). Salivary tumors in north Jordanians: a descriptive study. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
4550 Almeyda R, Chau H, Wood S. (2007). The FY2 tonsillar tie trainer. Clin Otolaryngol.
4551 Al-Sebeih K, Katchy K. (2007). Adenotonsillar granuloma: histopathological correlation. Med Princ Pract.
4552 Al-Shehri AM. (2007). Prophylactic use of dexamethasone in tonsillectomy among children. Current Pediatric Research.
4553 Ameli F, Brocchetti F, Semino L, et al. (2007). Adenotonsillectomy in obstructive sleep apnea syndrome. Proposal of a surgical decision-taking algorithm. Int J Pediatr Otorhinolaryngol.
4554 Amin M, Glynn F, Phelan S, et al. (2007). Silver nitrate cauterisation, does concentration matter?. Clin Otolaryngol.
4555 Andreu-Ballester JC, Perez-Griera J, Ballester F, et al. (2007). Secretory immunoglobulin A (sIgA) deficiency in serum of patients with GALTectomy (appendectomy and tonsillectomy). Clin Immunol.
4556 Antunes ML, Frazatto R, Macoto EK, et al. (2007). Adeno-tonsillectomy surgery in a joint aid effort: a feasible solution?. Braz J Otorhinolaryngol.
4557 Arnaud E, Marchac D, Renier D. (2007). Reduction of morbidity of the frontofacial monobloc advancement in children by the use of internal distraction. Plast Reconstr Surg.
4558 Arrarte J, Lubianca Neto JF, Fischer GB. (2007). The effect of adenotonsillectomy on oxygen saturation in children with sleep breathing disorders. Int J Pediatr Otorhinolaryngol.
4559 Arrarte JL, Lubianca Neto JF, Fischer GB. (2007). The effect of adenotonsillectomy on oxygen saturation in children with sleep disordered breathing. J Bras Pneumol.
4560 Ashbach MN, Ostrower ST, Parikh SR. (2007). Tonsillectomy techniques and pain: a review of randomized controlled trials and call for standardization. ORL J Otorhinolaryngol Relat Spec.
4561 Aslan S, Yilmaz I, Bal N, et al. (2007). Investigation of Helicobacter pylori in tonsillary tissue with Pronto Dry test and pathologic examination. Auris Nasus Larynx.
4562 Aydin ON, Ugur B, Ozgun S, et al. (2007). Pain prevention with intraoperative ketamine in outpatient children undergoing tonsillectomy or tonsillectomy and adenotomy. J Clin Anesth.
4563 Aydogan M, Toprak D, Hatun S, et al. (2007). The effect of recurrent tonsillitis and adenotonsillectomy on growth in childhood. Int J Pediatr Otorhinolaryngol.
4564 Bader-Meunier B, Francois M, Verlhac S, et al. (2007). Increased cerebral blood flow velocity in children with sickle cell disease: adenotonsillectomy or transfusion regimens?. Pediatrics.
4565 Ball SL, Siou GP, Wilson JA, et al. (2007). Expression and immunolocalisation of antimicrobial peptides within human palatine tonsils. J Laryngol Otol.
4566 Barr GD. (2007). How to reduce diathermy in tonsillectomy: description of technique and analysis of results. Eur Arch Otorhinolaryngol.
4567 Barreto I, Juliano P, Chagas C, et al. (2007). Lymphoid polyps of the palatine tonsil. Int J Surg Pathol.
4568 Bartolek D, Lajtman Z, Zdravcevic-Sakic K, et al. (2007). The optimal pediatric induction dose of propofol in combination with reduced-dose rocuronium and alfentanil for day-case tonsillectomy in children. Int J Pediatr Otorhinolaryngol.
4569 Batra YK, Shamsah M, Al-Khasti MJ, et al. (2007). Intraoperative small-dose ketamine does not reduce pain or analgesic consumption during perioperative opioid analgesia in children after tonsillectomy. Int J Clin Pharmacol Ther.
4570 Bayrak F, Gunday I, Memis D, et al. (2007). A comparison of oral midazolam, oral tramadol, and intranasal sufentanil premedication in pediatric patients. J Opioid Manag.
4571 Bayram C, Knox S, Miller G, et al. (2007). Clinical activity of overseas-trained doctors practising in general practice in Australia. Aust Health Rev.
4572 Bean-Lijewski JD, Kruitbosch SH, Hutchinson L, et al. (2007). Post-tonsillectomy pain management in children: can we do better?. Otolaryngol Head Neck Surg.
4573 Beier UH, Holtmeier C, Weise JB, et al. (2007). Fibronectin suppression in head and neck cancers, inflammatory tissues and the molecular mechanisms potentially involved. Int J Oncol.
4574 Benninger M, Walner D. (2007). Obstructive sleep-disordered breathing in children. Clin Cornerstone.
4575 Benninger M, Walner D. (2007). Coblation: improving outcomes for children following adenotonsillectomy. Clin Cornerstone.
4576 Bentdal YE, Karevold G, Nafstad P, et al. (2007). Early acute otitis media: predictor for AOM and respiratory infections in schoolchildren?. Int J Pediatr Otorhinolaryngol.
4577 Bercin AS, Ural A, Kutluhan A, et al. (2007). Relationship between sinusitis and adenoid size in pediatric age group. Ann Otol Rhinol Laryngol.
4578 Berlucchi M, Salsi D, Valetti L, et al. (2007). The role of mometasone furoate aqueous nasal spray in the treatment of adenoidal hypertrophy in the pediatric age group: preliminary results of a prospective, randomized study. Pediatrics.
4579 Bonnaud I, Cottier JP, Debiais S, et al. (2007). Internal carotid artery dissection after tonsillectomy in an adult woman. Cerebrovasc Dis.
4580 Boppana SB, Fowler KB. (2007). Persistence in the population: epidemiology and transmisson. Arvin A, Campadelli-Fiume G, Mocarski E, Moore PS, Roizman B, Whitley R, et al., editors. Human Herpesviruses: Biology, Therapy, and Immunoprophylaxis.
4581 Brook I. (2007). The role of anaerobic bacteria in upper respiratory tract and other head and neck infections. Curr Infect Dis Rep.
4582 Burton MJ, Doree C. (2007). Coblation versus other surgical techniques for tonsillectomy. Cochrane Database Syst Rev.
4583 Burton MJ, Perera R. (2007). A pilot randomised controlled trial of coblation tonsillectomy versus dissection tonsillectomy with bipolar diathermy. Clin Otolaryngol.
4584 Caldarelli M, Novegno F, Vassimi L, et al. (2007). The role of limited posterior fossa craniectomy in the surgical treatment of Chiari malformation Type I: experience with a pediatric series. J Neurosurg.
4585 Caldas MP, Neves EG, Manzi FR, et al. (2007). Tonsillolith--report of an unusual case. Br Dent J.
4586 Calkin CV, Carandang CG. (2007). Certain eating disorders may be a neuropsychiatric manifestation of PANDAS: Case report. Journal of the Canadian Academy of Child and Adolescent Psychiatry.
4587 Cannizzaro E, Albisetti M, Wohlrab G, et al. (2007). Severe bleeding complications during antiepileptic treatment with valproic acid in children. Neuropediatrics.
4588 Cardozo AA, Hallikeri C, Lawrence H, et al. (2007). Teenage and adult tonsillectomy: dose-response relationship between diathermy energy used and morbidity. Clin Otolaryngol.
4589 Cardwell CR, Carson DJ, McNaboe EJ, et al. (2007). Tonsillectomy and adenoidectomy are not associated with an altered risk of childhood-onset type 1 diabetes. Diabetes Care.
4590 Carr E, Obholzer R, Caulfield H. (2007). A prospective study to determine the incidence of atopy in children undergoing adenotonsillectomy for obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
4591 Carrillo JF, Vazquez R, Ramirez-Ortega MC, et al. (2007). Multivariate prediction of the probability of recurrence in patients with carcinoma of the parotid gland. Cancer.
4592 Carvalho KS, Edwards-Brown M, Golomb MR. (2007). Carotid dissection and stroke after tonsillectomy and adenoidectomy. Pediatr Neurol.
4593 Casey JR, Pichichero ME. (2007). Symptomatic relapse of group A beta-hemolytic streptococcal tonsillopharyngitis in children. Clin Pediatr (Phila).
4594 Cernea CR, Dias FL, Lima RA, et al. (2007). Atypical facial access: an unusually high prevalence of use among patients with skull base tumors treated at 2 centers. Arch Otolaryngol Head Neck Surg.
4595 Chadha NK. (2007). Tonsillectomy return-to-theatre rates demonstrate a monthly and seasonal variation: an analysis of 256,799 patients. J Laryngol Otol.
4596 Chegar BE, Shprintzen RJ, Curtis MS, et al. (2007). Pharyngeal flap and obstructive apnea: maximizing speech outcome while limiting complications. Arch Facial Plast Surg.
4597 Chen AM, Garcia J, Lee NY, et al. (2007). Patterns of nodal relapse after surgery and postoperative radiation therapy for carcinomas of the major and minor salivary glands: what is the role of elective neck irradiation?. Int J Radiat Oncol Biol Phys.
4598 Chen AM, Granchi PJ, Garcia J, et al. (2007). Local-regional recurrence after surgery without postoperative irradiation for carcinomas of the major salivary glands: implications for adjuvant therapy. Int J Radiat Oncol Biol Phys.
4599 Chen Y, Tang Z, Wang Q, et al. (2007). Long-term efficacy of tonsillectomy in Chinese patients with IgA nephropathy. Am J Nephrol.
4600 Chernausek SD, Backeljauw PF, Frane J, et al. (2007). Long-term treatment with recombinant insulin-like growth factor (IGF)-I in children with severe IGF-I deficiency due to growth hormone insensitivity. J Clin Endocrinol Metab.
4601 Cherry JR. (2007). Re: is secondary haemorrhage after tonsillectomy in adults an infective condition? Objective measures of infection in a prospective cohort. Clin Otolaryngol.
4602 Chervin RD, Weatherly RA, Garetz SL, et al. (2007). Pediatric sleep questionnaire: prediction of sleep apnea and outcomes. Arch Otolaryngol Head Neck Surg.
4603 Chu WC, Man GC, Lam WW, et al. (2007). A detailed morphologic and functional magnetic resonance imaging study of the craniocervical junction in adolescent idiopathic scoliosis. Spine (Phila Pa 1976).
4604 Ciprandi G, Varricchio A, Capasso M, et al. (2007). Intranasal flunisolide treatment in children with adenoidal hypertrophy. Int J Immunopathol Pharmacol.
4605 Clarke MB, Forster P, Cook TM. (2007). Airway management for tonsillectomy: a national survey of UK practice. Br J Anaesth.
4606 Cohen MS, Getz AE, Isaacson G, et al. (2007). Intracapsular vs. extracapsular tonsillectomy: a comparison of pain. Laryngoscope.
4607 Cole SM, Patterson MB, Cupp CL. (2007). Tonsillectomy in the anticoagulated patient. Ann Otol Rhinol Laryngol.
4608 Collins WO, Choi SS. (2007). Otolaryngologic manifestations of achondroplasia. Arch Otolaryngol Head Neck Surg.
4609 Constantin E, Kermack A, Nixon GM, et al. (2007). Adenotonsillectomy improves sleep, breathing, and quality of life but not behavior. J Pediatr.
4610 Coticchia J, Zuliani G, Coleman C, et al. (2007). Biofilm surface area in the pediatric nasopharynx: Chronic rhinosinusitis vs obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
4611 Cox RG. (2007). Anesthetic management of pediatric adenotonsillectomy. Can J Anaesth.
4612 Crayford TJ. (2007). Time to stop doing tonsillectomies?. Bmj.
4613 Cruise AS, Mansuri MS, Clarke PM. (2007). Use of a towel clip to prevent slipping of Draffin rods. Clin Otolaryngol.
4614 Curry JM, Cognetti DM, Harrop J, et al. (2007). Cervical discitis and epidural abscess after tonsillectomy. Laryngoscope.
4615 Dal D, Celebi N, Elvan EG, et al. (2007). The efficacy of intravenous or peritonsillar infiltration of ketamine for postoperative pain relief in children following adenotonsillectomy. Paediatr Anaesth.
4616 Danielpour M, Wilcox WR, Alanay Y, et al. (2007). Dynamic cervicomedullary cord compression and alterations in cerebrospinal fluid dynamics in children with achondroplasia. Report of four cases. J Neurosurg.
4617 Darrow DH. (2007). Surgery for pediatric sleep apnea. Otolaryngol Clin North Am.
4618 Dayyat E, Maarafeya MM, Capdevila OS, et al. (2007). Nocturnal body position in sleeping children with and without obstructive sleep apnea. Pediatr Pulmonol.
4619 de Lange de Klerk ESM. (2007). Does Arnica montana soothe pain and promote healing after tonsillectomy in adults? Commentary. Focus on Alternative and Complementary Therapies.
4620 de Zoysa H, Morecroft E. (2007). Cleaning, disinfection and sterilization of equipment. Anaesthesia and Intensive Care Medicine.
4621 Derekoy FS, Fidan H, Fidan F, et al. (2007). Tonsillar lipoma causing difficult intubation: a case report. Kulak Burun Bogaz Ihtis Derg.
4622 Dillon JE, Blunden S, Ruzicka DL, et al. (2007). DSM-IV diagnoses and obstructive sleep apnea in children before and 1 year after adenotonsillectomy. J Am Acad Child Adolesc Psychiatry.
4623 Duca KA, Shapiro M, Delgado-Eckert E, et al. (2007). A virtual look at Epstein-Barr virus infection: biological interpretations. PLoS Pathog.
4624 Edler AA, Mariano ER, Golianu B, et al. (2007). An analysis of factors influencing postanesthesia recovery after pediatric ambulatory tonsillectomy and adenoidectomy. Anesth Analg.
4625 El-Hawrani A, Johnson E, Dhunnoo I, et al. (2007). Bell's like mononeuropathies of two lower cranial nerves and review of the literature. International Journal of Pediatric Otorhinolaryngology Extra.
4626 Erhan OL, Goksu H, Alpay C, et al. (2007). Ketamine in post-tonsillectomy pain. Int J Pediatr Otorhinolaryngol.
4627 Ericsson E, Hultcrantz E. (2007). Tonsil surgery in youths: good results with a less invasive method. Laryngoscope.
4628 Ericsson E, Ledin T, Hultcrantz E. (2007). Long-term improvement of quality of life as a result of tonsillotomy (with radiofrequency technique) and tonsillectomy in youths. Laryngoscope.
4629 Eriksson JC, Cox RJ, Szyszko E, et al. (2007). Local and systemic cytokine and chemokine responses after parenteral influenza vaccination. Influenza Other Respir Viruses.
4630 Erk G, Ornek D, Donmez NF, et al. (2007). The use of ketamine or ketamine-midazolam for adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
4631 Ernst E. (2007). Study by Robertson et al is a fine example of nonsensical, misleading statistics. Homeopathy.
4632 Euctr GB. (2007). A prospective, randomised, phase IV, open label clinical trial to study the therapeutic use of buprenorphine 20 mg (BuTrans 20µg/h) matrix transdermal patch in the management of post tonsillectomy pain in adults - PATCH Trial. EUCTR.
4633 Eustace N, O'Hare B. (2007). Use of nonsteroidal anti-inflammatory drugs in infants. A survey of members of the Association of Paediatric Anaesthetists of Great Britain and Ireland. Paediatr Anaesth.
4634 Fazel MR, Yegane-Moghaddam A, Forghani Z, et al. (2007). The effect of dexamethasone on postoperative vomiting and oral intake after adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
4635 Fennessy BG, Harney M, O'Sullivan MJ, et al. (2007). Antimicrobial prophylaxis in otorhinolaryngology/head and neck surgery. Clin Otolaryngol.
4636 Ferri E, Armato E, Capuzzo P. (2007). Argon plasma coagulation versus cold dissection tonsillectomy in adults: a clinical prospective randomized study. Am J Otolaryngol.
4637 Fitzgerald DA, Paul A, Richmond C. (2007). Severity of obstructive apnoea in children with Down syndrome who snore. Arch Dis Child.
4638 Flook E. (2007). Re: is secondary haemorrhage after tonsillectomy in adults an infective condition?. Clin Otolaryngol.
4639 Foghsgaard S, Foghsgaard J, Homoe P. (2007). Early post-operative morbidity after superficial parotidectomy: a prospective study concerning pain and resumption of normal activity. Clin Otolaryngol.
4640 Frackiewicz M, Garstecka A, Drozniewska M, et al. (2007). Laryngological problems in children with Down syndrome. New Medicine.
4641 Friedman J, Brouillette RT, Constantin E, et al. (2007). Case 1: Sounds like trouble. Paediatrics and Child Health.
4642 Friedman M. (2007). Response to: “adenotonsillectomy and obstructive sleep apnea in children: a prospective survey”. Otolaryngol Head Neck Surg.
4643 Friedman NR. (2007). Polysomnography should not be required both before and after adenotonsillectomy for childhood sleep disordered breathing. J Clin Sleep Med.
4644 Fujimoto T, Shinohara M, Ito M, et al. (2007). Detection of dual-infected cases of adenoviruses and coxsackieviruses type B by real-time PCR but not by the conventional viral culture technique. Clin Lab.
4645 Galarza M, Sood S, Ham S. (2007). Relevance of surgical strategies for the management of pediatric Chiari type I malformation. Childs Nerv Syst.
4646 Galli J, Ardito F, Calo L, et al. (2007). Recurrent upper airway infections and bacterial biofilms. J Laryngol Otol.
4647 Galli J, Calo L, Ardito F, et al. (2007). Biofilm formation by Haemophilus influenzae isolated from adeno-tonsil tissue samples, and its role in recurrent adenotonsillitis. Acta Otorhinolaryngol Ital.
4648 Garnett CT, Pao CI, Gooding LR. (2007). Detection and quantitation of subgroup C adenovirus DNA in human tissue samples by real-time PCR. Methods in molecular medicine.
4649 Georgalas C, Babar-Craig H, Arora A, et al. (2007). Health outcome measurements in children with sleep disordered breathing. Clin Otolaryngol.
4650 Georgalas CC, Tolley NS, Narula A. (2007). Recurrent throat infections (tonsillitis). BMJ Clin Evid.
4651 George A, Coulson C, De R. (2007). Procalcitonin: a bacterial specific marker of infection. Clin Otolaryngol.
4652 George GB. (2007). A relevant or irrelevant tonsillectomy trial?. Clin Otolaryngol.
4653 Glynn F, Skinner LJ, Riley N, et al. (2007). Parapharyngeal abscess in an insulin dependant diabetic patient following an elective tonsillectomy. J Laryngol Otol.
4654 Goldbart AD, Mager E, Veling MC, et al. (2007). Neurotrophins and tonsillar hypertrophy in children with obstructive sleep apnea. Pediatr Res.
4655 Gosepath J, Spix C, Talebloo B, et al. (2007). Incidence of childhood cancer of the head and neck in Germany. Ann Oncol.
4656 Gozal D, Kheirandish-Gozal L, Serpero LD, et al. (2007). Obstructive sleep apnea and endothelial function in school-aged nonobese children: effect of adenotonsillectomy. Circulation.
4657 Grasso DL, Guerci VI, Zocconi E, et al. (2007). MBL2 genetic polymorphisms in Italian children with adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
4658 Grob GN. (2007). The rise and decline of tonsillectomy in twentieth-century America. J Hist Med Allied Sci.
4659 Guilleminault C, Huang YS, Chan A, et al. (2007). Cyanotic breath-holding spells in children respond to adenotonsillectomy for sleep-disordered breathing. J Sleep Res.
4660 Guilleminault C, Huang YS, Glamann C, et al. (2007). Adenotonsillectomy and obstructive sleep apnea in children: a prospective survey. Otolaryngol Head Neck Surg.
4661 Gul M, Okur E, Ciragil P, et al. (2007). The comparison of tonsillar surface and core cultures in recurrent tonsillitis. Am J Otolaryngol.
4662 Gulcu N, Karaaslan K, Suslu AE, et al. (2007). The treatment of postoperative inspiratory stridor with intraoral epinephrine. Paediatr Anaesth.
4663 Hamid WA, Flood LM, Martin FW. (2007). Departmental audit of tonsillectomy haemorrhage rates: pitfalls in interpretation. J Laryngol Otol.
4664 Hamilton MA, Patel A. (2007). Laryngeal mask airway and tonsillectomy: a question of training. Anesth Analg.
4665 Heaney M, Looney Y, McKinstry C, et al. (2007). Sequential clot strength analyses following diclofenac in pediatric adenotonsillectomy. Paediatr Anaesth.
4666 Heike CL, Avellino AM, Mirza SK, et al. (2007). Sleep disturbances in 22q11.2 deletion syndrome: a case with obstructive and central sleep apnea. Cleft Palate Craniofac J.
4667 Heiniger N, Spaniol V, Troller R, et al. (2007). A reservoir of Moraxella catarrhalis in human pharyngeal lymphoid tissue. J Infect Dis.
4668 Heller JB, Lazareff J, Gabbay JS, et al. (2007). Posterior cranial fossa box expansion leads to resolution of symptomatic cerebellar ptosis following Chiari I malformation repair. J Craniofac Surg.
4669 Hirabayashi Y. (2007). Pharyngeal injury related to GlideScope videolaryngoscope. Otolaryngol Head Neck Surg.
4670 Hoban TF. (2007). Polysomnography should be required both before and after adenotonsillectomy for childhood sleep disordered breathing. J Clin Sleep Med.
4671 Hoban TF, Chervin RD. (2007). Sleep-Related Breathing Disorders of Childhood: Description and Clinical Picture, Diagnosis, and Treatment Approaches. Sleep Medicine Clinics.
4672 Hope A, Lo S. (2007). Hydrogen peroxide mouthwash in post-tonsillectomy haemorrhage. Clin Otolaryngol.
4673 Hore I, Bajaj Y, Denyer J, et al. (2007). The management of general and disease specific ENT problems in children with Epidermolysis Bullosa--a retrospective case note review. Int J Pediatr Otorhinolaryngol.
4674 Hsu AP, Tan KL, Tan YB, et al. (2007). Benefits and efficacy of tonsillectomy for recurrent tonsillitis in adults. Acta Otolaryngol.
4675 Huang H, Peng Y, Liu F, et al. (2007). Is IgA nephropathy induced by abnormalities of CD4+CD25+Treg cells in the tonsils?. Med Hypotheses.
4676 Huang YS, Guilleminault C, Li HY, et al. (2007). Attention-deficit/hyperactivity disorder with obstructive sleep apnea: a treatment outcome study. Sleep Med.
4677 Hui Y, Wong BYH. (2007). Tonsillectomy and adenoidectomy: Otolaryngologist's perspective. Hong Kong Journal of Paediatrics.
4678 Huth MM, Broome ME. (2007). A snapshot of children's postoperative tonsillectomy outcomes at home. J Spec Pediatr Nurs.
4679 Ieiri N, Hotta O, Taguma Y. (2007). Impact of annual urine health check-up system to obtain clinical remission in patients with IgA nephropathy. Contrib Nephrol.
4680 Imchen S, Bedajit RK, Ibohal Singh T. (2007). Ventilation tube insertion in the management of otitis media with effusion. JMS - Journal of Medical Society.
4681 Inoue CN, Chiba Y, Morimoto T, et al. (2007). Tonsillectomy in the treatment of pediatric Henoch-Schonlein nephritis. Clin Nephrol.
4682 Ivanhoe JR, Lefebvre CA, Stockstill JW. (2007). Sleep disordered breathing in infants and children: a review of the literature. Pediatr Dent.
4683 Javed F, Sadri M, Uddin J, et al. (2007). A completed audit cycle on post-tonsillectomy haemorrhage rate: coblation versus standard tonsillectomy. Acta Otolaryngol.
4684 Jelavic B, Bevanda M, Ostojic M, et al. (2007). Tonsillar colonization is unlikely to play important role in Helicobacter pylori infection in children. Int J Pediatr Otorhinolaryngol.
4685 Jensen A, Hagelskjaer Kristensen L, Prag J. (2007). Detection of Fusobacterium necrophorum subsp. funduliforme in tonsillitis in young adults by real-time PCR. Clin Microbiol Infect.
4686 Jeong JH, Lee DW, Ryu RA, et al. (2007). Bacteriologic comparison of tonsil core in recurrent tonsillitis and tonsillar hypertrophy. Laryngoscope.
4687 Jo SH, Mathiasen RA, Gurushanthaiah D. (2007). Prospective, randomized, controlled trial of a hemostatic sealant in children undergoing adenotonsillectomy. Otolaryngol Head Neck Surg.
4688 Jonas NE, Sayed R, Prescott CA. (2007). Prospective, randomized, single-blind, controlled study to compare two methods of performing adenoidectomy. Int J Pediatr Otorhinolaryngol.
4689 Kadhim AL, Spilsbury K, Semmens JB, et al. (2007). Adenoidectomy for middle ear effusion: a study of 50,000 children over 24 years. Laryngoscope.
4690 Kalala F, Loules C, Mamara A, et al. (2007). Clinical immunology quiz - Case 3. Archives of Hellenic Medicine.
4691 Kania RE, Lamers GE, Vonk MJ, et al. (2007). Demonstration of bacterial cells and glycocalyx in biofilms on human tonsils. Arch Otolaryngol Head Neck Surg.
4692 Kara N, Murray A. (2007). Hazards of hydrogen peroxide in ENT practice. Otorhinolaryngologist.
4693 Karabulut H, Acar B, Babademez MA, et al. (2007). In reference to effectiveness of adenotonsillectomy in the resolution of nocturnal enuresis secondary to obstructive sleep apnea. Laryngoscope.
4694 Karatzanis AD, Bourolias CA, Prokopakis EP, et al. (2007). Tonsillectomy with thermal welding technology using the TLS(2) thermal ligating shear. Int J Pediatr Otorhinolaryngol.
4695 Karevold G, Haapkyla J, Pitkaranta A, et al. (2007). Otitis media surgery: large variability between Finland and Norway. Int J Pediatr Otorhinolaryngol.
4696 Karevold G, Haapkyla J, Pitkaranta A, et al. (2007). Paediatric otitis media surgery in Norway. Acta Otolaryngol.
4697 Kawamura T. (2007). Treatment of IgA nephropathy: corticosteroids, tonsillectomy, and mycophenolate mofetil. Contrib Nephrol.
4698 Kawasaki Y, Suyama K, Matsumoto A, et al. (2007). Efficacy of tonsillectomy plus methylprednisolone pulse therapy for a child with Henoch-Schoenlein purpura nephritis. Tohoku J Exp Med.
4699 Khademi B, Niknejad N, Gandomi B, et al. (2007). Comparison of Helicobacter pylori colonization on the tonsillar surface versus tonsillar core tissue as determined by the CLO test. Ear Nose Throat J.
4700 Khan A, Ramar K. (2007). Sleep disordered breathing: Alternatives to CPAP therapy. Current Respiratory Medicine Reviews.
4701 Khan AR. (2007). Comparison between silk ligation and bipolar cautery in tonsillectomy. Gomal Journal of Medical Sciences.
4702 Khan S, Campo J, Bridge JA, et al. (2007). Long-term outcome of functional childhood constipation. Dig Dis Sci.
4703 Kim HJ, Baik SW, Baek SH, et al. (2007). The Effect of Remifentanil on Delirium after Sevoflurane Anesthesia in the Pediatric Patients. Korean Journal of Anesthesiology.
4704 Ko AB, Simons JP, Mandell DL. (2007). Introduction of visually oriented information handouts in an academic pediatric otolaryngology practice. Otolaryngol Head Neck Surg.
4705 Kodama S, Suzuki M. (2007). Tonsillectomy as part of the treatment for IgA nephropathy: cooperation between nephrologists and otolaryngologists. Clin Exp Nephrol.
4706 Koelsch K, Zheng NY, Zhang Q, et al. (2007). Mature B cells class switched to IgD are autoreactive in healthy individuals. J Clin Invest.
4707 Korpela R, Silvola J, Laakso E, et al. (2007). Oral naproxen but not oral paracetamol reduces the need for rescue analgesic after adenoidectomy in children. Acta Anaesthesiol Scand.
4708 Koturoglu G, Onay H, Midilli R, et al. (2007). Evidence of an association between mannose binding lectin codon 54 polymorphism and adenoidectomy and/or tonsillectomy in children. Int J Pediatr Otorhinolaryngol.
4709 Kousha A, Fotoohi N, Banan R. (2007). Cold dissection versus bipolar electrocautery tonsillectomy. Journal of Research in Medical Sciences.
4710 Koutsourelakis I, Perraki E, Dimitrokali P, et al. (2007). Severe obstructive sleep apnoea syndrome in a 5-year-old girl. International Journal of Pediatric Otorhinolaryngology Extra.
4711 Kuiper S, Muris JW, Dompeling E, et al. (2007). Interactive effect of family history and environmental factors on respiratory tract-related morbidity in infancy. J Allergy Clin Immunol.
4712 Kumar S, Kalra M. (2007). Obesity and obstructive sleep apnea. Minerva Pneumologica.
4713 Kusano K, Tokunaga O, Ando T, et al. (2007). Helicobacter pylori in the palatine tonsils of patients with IgA nephropathy compared with those of patients with recurrent pharyngotonsillitis. Hum Pathol.
4714 Lachanas VA, Hajiioannou JK, Karatzias GT, et al. (2007). Comparison of LigaSure vessel sealing system, harmonic scalpel, and cold knife tonsillectomy. Otolaryngol Head Neck Surg.
4715 LaForce C, Man CY, Henderson FW, et al. (2007). Efficacy and safety of inhaled zanamivir in the prevention of influenza in community-dwelling, high-risk adult and adolescent subjects: a 28-day, multicenter, randomized, double-blind, placebo-controlled trial. Clin Ther.
4716 Lam JC, Mason TBA. (2007). Treatment of sleep disorders in children. Current Treatment Options in Neurology.
4717 Lamberg L. (2007). Sleep-disordered breathing may spur behavioral, learning problems in children. Jama.
4718 Lane MH, Flynn F, Hepburn LH, et al. (2007). Factors influencing postanesthesia recovery after pediatric ambulatory tonsillectomy and adenoidectomy. Anesth Analg.
4719 Laskar S, Bahl G, Muckaden MA, et al. (2007). Primary diffuse large B-cell lymphoma of the tonsil: is a higher radiotherapy dose required?. Cancer.
4720 Lau KK, Butani L. (2007). Treatment of pediatric IgA nephropathy. Hong Kong Journal of Nephrology.
4721 Le T, Drolet J, Parayno E, et al. (2007). Follow-up phone calls after pediatric ambulatory surgery for tonsillectomy: what can we learn from families?. J Perianesth Nurs.
4722 Lee J, Cohen-Kerem R, Crysdale WS. (2007). Preoperative characteristics and postoperative outcomes following adenoidectomy in children. J Otolaryngol.
4723 Leong AC, Davis JP. (2007). Morbidity after adenotonsillectomy for paediatric obstructive sleep apnoea syndrome: waking up to a pragmatic approach. J Laryngol Otol.
4724 Leong SC, Karkos PD, Papouliakos SM, et al. (2007). Unusual complications of tonsillectomy: a systematic review. Am J Otolaryngol.
4725 Levin B, Sacks R. (2007). Post-tonsillectomy bleeding. Otolaryngol Head Neck Surg.
4726 Liechti M, Feurer R, Gross D, et al. (2007). Prevention of postoperative nausea and vomiting in children following adenotonsillectomy, using tropisetron with or without low-dose dexamethasone. J Anesth.
4727 Lin CH, Huang YC, Chiu CH, et al. (2007). A cluster of adenovirus serotype 3 infections in children in northern Taiwan: clinical features and laboratory findings. J Microbiol Immunol Infect.
4728 Lisco A, Grivel JC, Biancotto A, et al. (2007). Viral interactions in human lymphoid tissue: Human herpesvirus 7 suppresses the replication of CCR5-tropic human immunodeficiency virus type 1 via CD4 modulation. J Virol.
4729 Little P. (2007). Recurrent pharyngo-tonsillitis. Bmj.
4730 Lofstrand-Tidestrom B, Hultcrantz E. (2007). The development of snoring and sleep related breathing distress from 4 to 6 years in a cohort of Swedish children. Int J Pediatr Otorhinolaryngol.
4731 Lopez OJ, Oliveira MF, Garcia EA, et al. (2007). Protection against porcine reproductive and respiratory syndrome virus (PRRSV) infection through passive transfer of PRRSV-neutralizing antibodies is dose dependent. Clin Vaccine Immunol.
4732 Lowe D. (2007). Consent issues with the National Prospective Tonsillectomy Audit: the Oxford experience. Clin Otolaryngol.
4733 Lu X, Li D, Dalley NK, et al. (2007). Structure elucidation of compounds extracted from the Chinese medicinal plant Patrinia heterophylla. Nat Prod Res.
4734 Ludemann JP, Wong KK, Moxham JP. (2007). Return to home, school, and sports after electrosurgical adenoidectomy: when is it safe?. J Otolaryngol.
4735 Lupinetti AD, Roberts DB, Williams MD, et al. (2007). Sinonasal adenoid cystic carcinoma: the M. D. Anderson Cancer Center experience. Cancer.
4736 Luukkaa H, Laitakari J, Vahlberg T, et al. (2007). Morphometric analysis using automated image analysis of CD34-positive vessels in salivary gland acinic cell carcinoma. Acta Otolaryngol.
4737 Macassey EA, Baguley C, Dawes P, et al. (2007). 15-year audit of post-tonsillectomy haemorrhage at Dunedin Hospital. ANZ J Surg.
4738 Madani M. (2007). Radiofrequency treatment of the soft palate, nasal turbinates and tonsils for the treatment of snoring and mild to moderate obstructive sleep apnea. Atlas Oral Maxillofac Surg Clin North Am.
4739 Mahmoud M, Bryan Y, Gunter J, et al. (2007). Anesthetic implications of undiagnosed late onset central hypoventilation syndrome in a child: from elective tonsillectomy to tracheostomy. Paediatr Anaesth.
4740 Maiorano E, Favia G, Pece S, et al. (2007). Prognostic implications of NUMB immunoreactivity in salivary gland carcinomas. Int J Immunopathol Pharmacol.
4741 Majkowska-Wojciechowska B, Pelka J, Korzon L, et al. (2007). Prevalence of allergy, patterns of allergic sensitization and allergy risk factors in rural and urban children. Allergy.
4742 Mandell DL, Yellon RF. (2007). Synchronous airway lesions and esophagitis in young patients undergoing adenoidectomy. Arch Otolaryngol Head Neck Surg.
4743 Marseglia GL, Pagella F, Klersy C, et al. (2007). The 10-day mark is a good way to diagnose not only acute rhinosinusitis but also adenoiditis, as confirmed by endoscopy. Int J Pediatr Otorhinolaryngol.
4744 McIntosh DL, Douglas G, Lee K, et al. (2007). External carotid artery blood supply to the orbit. Int J Pediatr Otorhinolaryngol.
4745 Merrell JA, Shott SR. (2007). OSAS in Down syndrome: T&A versus T&A plus lateral pharyngoplasty. Int J Pediatr Otorhinolaryngol.
4746 Militana CJ, Ditkoff MK, Mattucci KF. (2007). Use of the laryngeal mask airway in preventing airway fires during adenoidectomies in children: a study of 25 patients. Ear Nose Throat J.
4747 Mitchell RB. (2007). Adenotonsillectomy for obstructive sleep apnea in children: outcome evaluated by pre- and postoperative polysomnography. Laryngoscope.
4748 Mitchell RB, Kelly J. (2007). Behavioral changes in children with mild sleep-disordered breathing or obstructive sleep apnea after adenotonsillectomy. Laryngoscope.
4749 Mitchell RB, Kelly J. (2007). Outcome of adenotonsillectomy for obstructive sleep apnea in obese and normal-weight children. Otolaryngol Head Neck Surg.
4750 Mitchell RB, Kelly J. (2007). Outcomes and quality of life following adenotonsillectomy for sleep-disordered breathing in children. ORL J Otorhinolaryngol Relat Spec.
4751 Mitzner R, Brodsky L. (2007). Multilevel esophageal biopsy in children with airway manifestations of extraesophageal reflux disease. Ann Otol Rhinol Laryngol.
4752 Mixson CM, Weinberger PM, Austin MB. (2007). Comparison of microdebrider subcapsular tonsillectomy to harmonic scalpel and electrocautery total tonsillectomy. Am J Otolaryngol.
4753 Miyao E, Nakayama M, Noda A, et al. (2007). Oral appliance therapy for a child with sleep apnea syndrome due to palatine tonsil hypertrophy. Sleep and Biological Rhythms.
4754 Miyazaki M, Hotta O, Komatsuda A, et al. (2007). A multicenter prospective cohort study of tonsillectomy and steroid therapy in Japanese patients with IgA nephropathy: a 5-year report. Contrib Nephrol.
4755 Miziara ID. (2007). Tonsilectomies drive. Braz J Otorhinolaryngol.
4756 Modrzynski M, Zawisza E. (2007). The influence of birch pollination on the adenoid size in children with intermittent allergic rhinitis. Int J Pediatr Otorhinolaryngol.
4757 Modrzynski M, Zawisza E. (2007). An analysis of the incidence of adenoid hypertrophy in allergic children. Int J Pediatr Otorhinolaryngol.
4758 Mohamad I, Hassan S, Salim R. (2007). The routine histopathological examination of tonsillectomy specimens at Hospital Universiti Sains Malaysia - A retrospective study and its implication. Malaysian Journal of Medical Sciences.
4759 Mohamad IB, Hassan S, Salim R. (2007). The routine histopathological examination of tonsillectomy specimens at hospital universiti sains Malaysia - Retrospective study and its implication. Malaysian Journal of Medical Sciences.
4760 Mohammadi G, Moghaddam J, Radfar R. (2007). Co2 laser tonsillectomy: A comparison with conventional technique. Rawal Med J.
4761 Molina JR, Aubry MC, Lewis JE, et al. (2007). Primary salivary gland-type lung cancer: spectrum of clinical presentation, histopathologic and prognostic factors. Cancer.
4762 Monobe H, Suzuki S, Nakashima M, et al. (2007). Peritonsillar abscess with parapharyngeal and retropharyngeal involvement: incidence and intraoral approach. Acta Otolaryngol Suppl.
4763 Montague ML, Lee MS, Hussain SS. (2007). ‘Group and save’ for paediatric tonsillectomy: is it required routinely?. J Laryngol Otol.
4764 Mora R, Crippa B, Dellepiane M, et al. (2007). Effects of adenotonsillectomy on speech spectrum in children. Int J Pediatr Otorhinolaryngol.
4765 Mozafarinia K, Amizadeh M. (2007). Evaluation of local injection of 0.5% Bupivacaine + 1/200000 Epinephrine for post tonsillectomy pain reduction. American Journal of Pharmacology and Toxicology.
4766 Mucha K, Foroncewicz B, Niemczyk K, et al. (2007). Tonsil enlargement after liver transplantation in adults--reason enough for tonsillectomy? Two cases of tonsillar posttransplantation lymphoproliferative disease. Liver Transpl.
4767 Mueller CA, Khatib S, Landis BN, et al. (2007). Gustatory function after tonsillectomy. Arch Otolaryngol Head Neck Surg.
4768 Muratbegovic A, Markovic N, Ganibegovic Selimovic M. (2007). Molar incisor hypomineralisation in Bosnia and Herzegovina: aetiology and clinical consequences in medium caries activity population. Eur Arch Paediatr Dent.
4769 Murrell GL, Sandberg KM, Murrell SA. (2007). GlideScope video laryngoscopes. Otolaryngol Head Neck Surg.
4770 Nagler J, Ruebner RL. (2007). Suppurative complications and upper airway obstruction in infectious mononucleosis. J Hosp Med.
4771 Nakata S, Miyazaki S, Ohki M, et al. (2007). Reduced nasal resistance after simple tonsillectomy in patients with obstructive sleep apnea. Am J Rhinol.
4772 Natsuga K, Sawamura D, Homma E, et al. (2007). Amicrobial pustulosis associated with IgA nephropathy and Sjogren's syndrome. J Am Acad Dermatol.
4773 Nelson EA, Tam JS, Yu LM, et al. (2007). Assessing disease burden of respiratory disorders in Hong Kong children with hospital discharge data and linked laboratory data. Hong Kong Med J.
4774 Nelson LM, Barrera JE. (2007). High energy single session radiofrequency tongue treatment in obstructive sleep apnea surgery. Otolaryngol Head Neck Surg.
4775 Neumann C, Street I, Lowe D, et al. (2007). Harmonic scalpel tonsillectomy: a systematic review of evidence for postoperative hemorrhage. Otolaryngol Head Neck Surg.
4776 Nishiike S, Kato T, Nagai M, et al. (2007). Preoperative flurbiprofen for pain prevention after tonsillectomy in adults. Journal of clinical anesthesia.
4777 Nishiike S, Kato T, Nagai M, et al. (2007). Preoperative flurbiprofen for pain after tonsillectomy. European Archives of Oto-Rhino-Laryngology and Head & Neck.
4778 Noda K, Kodama S, Suenaga S, et al. (2007). Tonsillar focal infectious disease involving IgA nephropathy, pustulosis, and ossification. Clin Exp Nephrol.
4779 O'Connor-Reina C, Garcia-Iriarte MT, Angel DG, et al. (2007). Radiofrequency volumetric tissue reduction for treatment of turbinate hypertrophy in children. Int J Pediatr Otorhinolaryngol.
4780 O'Flynn P, Silva S, Kothari P, et al. (2007). A multicentre audit of single-use surgical instruments (SUSI) for tonsillectomy and adenoidectomy. Ann R Coll Surg Engl.
4781 Ogawa N, Yano S, Yamane Y, et al. (2007). MPO-ANCA-positive IgA nephropathy successfully treated with tonsillectomy. Clin Exp Nephrol.
4782 Ohta S, Hanashiro K, Sunagawa M, et al. (2007). Involvement of Epstein-Barr virus (EBV)-encoded latent membrane protein (LMP)-1 in the potentiation of C epsilon mRNA expression in human tonsil-derived cells. Eur Arch Otorhinolaryngol.
4783 Olutoye O, Kim T, Giannoni C, et al. (2007). Dexmedetomidine as an analgesic for pediatric tonsillectomy and adenoidectomy. Paediatric anaesthesia.
4784 Orji FT, Mgbor NC. (2007). Otoscopy compared with tympanometry: an evaluation of the accuracy of simple otoscopy. Niger J Med.
4785 Ottonello G, Villa G, Moscatelli A, et al. (2007). Noninvasive ventilation in a child affected by achondroplasia respiratory difficulty syndrome. Paediatr Anaesth.
4786 Ozer C, Ozer F, Sener M, et al. (2007). A forgotten gauze pack in the nasopharynx: an unfortunate complication of adenotonsillectomy. Am J Otolaryngol.
4787 Ozgur Z, Celik S, Govsa F, et al. (2007). A study of the course of the internal carotid artery in the parapharyngeal space and its clinical importance. Eur Arch Otorhinolaryngol.
4788 Panasiuk L, Lukas W, Paprzycki P. (2007). Empirical first-line antibioticotherapy in adult rural patients with acute respiratory tract infections. Ann Agric Environ Med.
4789 Pang KP, Woodson BT. (2007). Expansion sphincter pharyngoplasty: a new technique for the treatment of obstructive sleep apnea. Otolaryngology--head and neck surgery.
4790 Park HP, Hwang JW, Park SH, et al. (2007). The effects of glossopharyngeal nerve block on postoperative pain relief after tonsillectomy: the importance of the extent of obtunded gag reflex as a clinical indicator. Anesthesia and analgesia.
4791 Peltola V, Toikka P, Irjala K, et al. (2007). Discrepancy between total white blood cell counts and serum C-reactive protein levels in febrile children. Scand J Infect Dis.
4792 Peltomaki T. (2007). The effect of mode of breathing on craniofacial growth--revisited. Eur J Orthod.
4793 Pfaar O, Spielhaupter M, Schirkowski A, et al. (2007). Treatment of hypertrophic palatine tonsils using bipolar radiofrequency-induced thermotherapy (RFITT.). Acta Otolaryngol.
4794 Pherwani A, Mankekar G, Chavan K. (2007). The study of co-morbid conditions in children with allergic rhinitis, from Mumbai, Maharashtra, India. Indian J Otolaryngol Head Neck Surg.
4795 Pichichero ME, Casey JR. (2007). Bacterial eradication rates with shortened courses of 2nd- and 3rd-generation cephalosporins versus 10 days of penicillin for treatment of group A streptococcal tonsillopharyngitis in adults. Diagn Microbiol Infect Dis.
4796 Pop RS, Manworren RC, Guzzetta CE, et al. (2007). Perianesthesia nurses' pain management after tonsillectomy and adenoidectomy: pediatric patient outcomes. J Perianesth Nurs.
4797 Possamai VJ, Griffiths H. (2007). One size fits all? A novel application of the adult Merocel epistaxis pack. J Laryngol Otol.
4798 Postelmans JT, Cleffken B, Stokroos RJ. (2007). Post-operative complications of cochlear implantation in adults and children: five years' experience in Maastricht. J Laryngol Otol.
4799 Pothier DD, Nankivell PC, Matthee W, et al. (2007). The NPTA may have underestimated tonsillectomy complications: a case note review of data submitted by two hospitals. Clin Otolaryngol.
4800 Pourhassan S, Grotemeyer D, Fokou M, et al. (2007). Extracranial carotid arteries aneurysms in children: single-center experiences in 4 patients and review of the literature. J Pediatr Surg.
4801 Pueyrredon F, Spaho N, Arroyave I, et al. (2007). Histological findings in cerebellar tonsils of patients with Chiari type I malformation. Childs Nerv Syst.
4802 Puttasiddaiah P, Kumar M, Gopalan P, et al. (2007). Tonsillectomy and biopsy for asymptomatic asymmetric tonsillar enlargement: are we right?. J Otolaryngol.
4803 R DE. (2007). Quantum resonance tonsillectomy in children. Otolaryngology - Head and Neck Surgery.
4804 Rachel Homer J, Elwood T, Peterson D, et al. (2007). Risk factors for adverse events in children with colds emerging from anesthesia: a logistic regression. Paediatr Anaesth.
4805 Rahman Al-Refai A, Al-Mujadi H, Petrova Ivanova M, et al. (2007). Prevention of pain on injection of propofol: a comparison of remifentanil with alfentanil in children. Minerva Anestesiol.
4806 Ramadan HH, Tiu J. (2007). Failures of adenoidectomy for chronic rhinosinusitis in children: for whom and when do they fail?. Laryngoscope.
4807 Randall DA, Martin PJ, Thompson LD. (2007). Routine histologic examination is unnecessary for tonsillectomy or adenoidectomy. Laryngoscope.
4808 Reichel O, Mayr D, Winterhoff J, et al. (2007). Tonsillotomy or tonsillectomy?--a prospective study comparing histological and immunological findings in recurrent tonsillitis and tonsillar hyperplasia. Eur Arch Otorhinolaryngol.
4809 Renko M, Kristo A, Tapiainen T, et al. (2007). Nasopharyngeal dimensions in magnetic resonance imaging and the risk of acute otitis media. J Laryngol Otol.
4810 Renko M, Salo E, Putto-Laurila A, et al. (2007). A randomized, controlled trial of tonsillectomy in periodic fever, aphthous stomatitis, pharyngitis, and adenitis syndrome. J Pediatr.
4811 Rezes S, Kesmarki K, Sipka S, et al. (2007). Characterization of otitis media with effusion based on the ratio of albumin and immunoglobulin G concentrations in the effusion. Otol Neurotol.
4812 Richards AL, Bailey M, Hooper R, et al. (2007). Quality-of-life effect of tonsillectomy in a young adult group. ANZ J Surg.
4813 Robb PJ. (2007). Adenoidectomy: does it work?. J Laryngol Otol.
4814 Robertson A, Suryanarayanan R, Banerjee A. (2007). Homeopathic Arnica montana for post-tonsillectomy analgesia: a randomised placebo control trial. Homeopathy.
4815 Roper AJ, Laha SK. (2007). Airway management for tonsillectomy. Br J Anaesth.
4816 Rose M. (2007). Systemic analgesics for children. Anaesthesia and Intensive Care Medicine.
4817 Ross SK, Jaiswal V, Jones NS. (2007). Nottingham tonsillectomy haemostasis simulator. Clin Otolaryngol.
4818 Rudnick EF, Mitchell RB. (2007). Long-term improvements in quality-of-life after surgical therapy for pediatric sinonasal disease. Otolaryngol Head Neck Surg.
4819 Rudnick EF, Mitchell RB. (2007). Behavior and obstructive sleep apnea in children: is obesity a factor?. Laryngoscope.
4820 Rudnick EF, Walsh JS, Hampton MC, et al. (2007). Prevalence and ethnicity of sleep-disordered breathing and obesity in children. Otolaryngol Head Neck Surg.
4821 Sahin F, Gerceker D, Karasartova D, et al. (2007). Detection of herpes simplex virus type 1 in addition to Epstein-Bar virus in tonsils using a new multiplex polymerase chain reaction assay. Diagn Microbiol Infect Dis.
4822 Sahlman J, Pukkila M, Seppa J, et al. (2007). Evolution of mild obstructive sleep apnea after different treatments. Laryngoscope.
4823 Saito H, Araki K, Ozawa H, et al. (2007). Pulse-oximetery is useful in determining the indications for adeno-tonsillectomy in pediatric sleep-disordered breathing. Int J Pediatr Otorhinolaryngol.
4824 Sampaio AL, Pinheiro TG, Furtado PL, et al. (2007). Evaluation of early postoperative morbidity in pediatric tonsillectomy with the use of sucralfate. Int J Pediatr Otorhinolaryngol.
4825 Sanguineti G, Adapala P, Endres EJ, et al. (2007). Dosimetric predictors of laryngeal edema. Int J Radiat Oncol Biol Phys.
4826 Santamaria F, Andreucci MV, Parenti G, et al. (2007). Upper airway obstructive disease in mucopolysaccharidoses: polysomnography, computed tomography and nasal endoscopy findings. J Inherit Metab Dis.
4827 Sargi Z, Younis RT. (2007). Pediatric obstructive sleep apnea: current management. ORL J Otorhinolaryngol Relat Spec.
4828 Sargi Z, Younis RT. (2007). Tonsillectomy and adenoidectomy techniques: past, present and future. ORL J Otorhinolaryngol Relat Spec.
4829 Sato K, Niikuni N, Nakajima I, et al. (2007). Surgical treatment for sleep apnea: changes in craniofacial and pharyngeal airway morphology in a child with achondroplasia. J Oral Sci.
4830 Sawada H, Mitani Y, Ohashi H, et al. (2007). Reversal of increased pulmonary arterial pressure associated with systemic venous collaterals after tonsillectomy in a Fontan candidate after the Glenn procedure: impact of obstructive sleep apnea on Fontan circulation. J Thorac Cardiovasc Surg.
4831 Schachtel BP, Pan S, Kohles JD, et al. (2007). Utility and sensitivity of the sore throat pain model: results of a randomized controlled trial on the COX-2 selective inhibitor valdecoxib. J Clin Pharmacol.
4832 Schmalbach CE, Miller FR. (2007). Occult primary head and neck carcinoma. Curr Oncol Rep.
4833 Schmidt R, Herzog A, Cook S, et al. (2007). Complications of tonsillectomy: a comparison of techniques. Arch Otolaryngol Head Neck Surg.
4834 Schmidt R, Herzog A, Cook S, et al. (2007). Powered intracapsular tonsillectomy in the management of recurrent tonsillitis. Otolaryngol Head Neck Surg.
4835 Schwentner I, Hofer S, Schmutzhard J, et al. (2007). Impact of tonsillectomy on quality of life in adults with chronic tonsillitis. Swiss Med Wkly.
4836 Schwentner I, Schwentner C, Schmutzhard J, et al. (2007). Validation of the German Glasgow children's benefit inventory. J Eval Clin Pract.
4837 Shah RK, Preciado DA. (2007). Re: the efficacy of intravenous or peritonsillar infiltration of ketamine for postoperative pain relief in children following adenotonsillectomy. Paediatr Anaesth.
4838 Shah SA, Ghani R. (2007). Evaluation of safety of bipolar diathermy tonsillectomy. J Ayub Med Coll Abbottabad.
4839 Shah UK, Dunham B. (2007). Coblation for tonsillectomy: an evidence-based review. ORL J Otorhinolaryngol Relat Spec.
4840 Sharma K, Kumar D, Sheemar S. (2007). Evaluation of bismuth subgallate and adrenaline paste as haemostat in tonsillectomy bleeding. Indian J Otolaryngol Head Neck Surg.
4841 Shuman AG, Heth JA, Marentette LJ, et al. (2007). Extracranial nasopharyngeal craniopharyngioma: case report. Neurosurgery.
4842 Silvanto M, Munsterhjelm E, Savolainen S, et al. (2007). Effect of 3 g of intravenous paracetamol on post-operative analgesia, platelet function and liver enzymes in patients undergoing tonsillectomy under local anaesthesia. Acta anaesthesiologica Scandinavica.
4843 Singh A, Kotecha B. (2007). In reference to plasma radiofrequency preceded by pressure recording enhances success for treating sleep-related breathing disorders. Laryngoscope.
4844 Skilbeck CJ, Tweedie DJ, Lloyd-Thomas AR, et al. (2007). Suction diathermy for adenoidectomy: complications and risk of recurrence. Int J Pediatr Otorhinolaryngol.
4845 Smith SL, Pereira KD. (2007). Tonsillectomy in children: indications, diagnosis and complications. ORL J Otorhinolaryngol Relat Spec.
4846 Solomon D, Isaacson G. (2007). Transoral “adenoidectomy” excision of juvenile nasopharyngeal angiofibromas. Ann Otol Rhinol Laryngol.
4847 Stahl-Hennig C, Kuate S, Franz M, et al. (2007). Atraumatic oral spray immunization with replication-deficient viral vector vaccines. J Virol.
4848 Stavroulaki P, Skoulakis C, Theos E, et al. (2007). Thermal welding versus cold dissection tonsillectomy: a prospective, randomized, single-blind study in adult patients. Annals of otology, rhinology, and laryngology.
4849 Strianese D, Baldi G, Staibano S, et al. (2007). Expression of apoptosis-related markers in malignant epithelial tumours of the lacrimal gland and their relation to clinical outcome. Br J Ophthalmol.
4850 Strocker AM, Shapiro NL. (2007). Parental understanding and attitudes of pediatric obstructive sleep apnea and adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
4851 Subashini P, Ravikumar A, Ranjit MS, et al. (2007). Adenoid hypertrophy presenting with systemic hypertension. Indian J Otolaryngol Head Neck Surg.
4852 Surani S, Khan A. (2007). Sleep related disorders in the elderly: An overview. Current Respiratory Medicine Reviews.
4853 Suratt PM, Barth JT, Diamond R, et al. (2007). Reduced time in bed and obstructive sleep-disordered breathing in children are associated with cognitive impairment. Pediatrics.
4854 Suryadevara AC, Tatum SA. (2007). Floating the uvula: an intraoperative method for detecting bifidity. Int J Pediatr Otorhinolaryngol.
4855 Sutters KA, Savedra MC, Miaskowski C, et al. (2007). Children's expectations of pain, perceptions of analgesic efficacy, and experiences with nonpharmacologic pain management strategies at home following tonsillectomy. J Spec Pediatr Nurs.
4856 Suvilehto J, Seppanen M, Notkola IL, et al. (2007). Association of allergy, asthma and IgE sensitisation to adenoidectomy and infections in children. Rhinology.
4857 Suwabe T, Ubara Y, Sogawa Y, et al. (2007). Tonsillectomy and corticosteroid therapy with concomitant methylprednisolone pulse therapy for IgA nephropathy. Contrib Nephrol.
4858 Swidsinski A, Goktas O, Bessler C, et al. (2007). Spatial organisation of microbiota in quiescent adenoiditis and tonsillitis. J Clin Pathol.
4859 Takwoingi YM, Shykhon M, Wake M. (2007). Effect of post-operative analgesia duration on post-tonsillectomy readmission rate: comparison of five-day and 14-day regime. J Laryngol Otol.
4860 Tanpowpong K, Saisukul I, Kittimanont H, et al. (2007). Outcome of myringotomy with ventilation tube for otitis media with effusion in Thai children: Ramathibodi experiences. J Med Assoc Thai.
4861 Teng A, Pokorny CS. (2007). Investigating the child who snores. Medicine Today.
4862 Terletskaia-Ladwig E, Leinmuller M, Schneider F, et al. (2007). Laboratory approaches to the diagnosis of adenovirus infection depending on clinical manifestations. Infection.
4863 Toh ST, Yuen HW, Goh YH. (2007). Actinomycetes colonization of tonsils: a comparative study between patients with and without recurrent tonsillitis. J Laryngol Otol.
4864 Tomino Y. (2007). Treatment for IgA nephropathy. Contrib Nephrol.
4865 Tomkinson A, Fox R, Temple M. (2007). More advice to clinicians. Bmj.
4866 Traverso LW. (2007). Presidential address: adjusting the art and the science of surgery. J Gastrointest Surg.
4867 Tubbs RS, Loukas M, Shoja MM, et al. (2007). Observations at the craniocervical junction with simultaneous caudal traction of the spinal cord. Childs Nerv Syst.
4868 Tweedie DJ, Skilbeck CJ, Lloyd-Thomas AR, et al. (2007). The nasopharyngeal prong airway: an effective post-operative adjunct after adenotonsillectomy for obstructive sleep apnoea in children. Int J Pediatr Otorhinolaryngol.
4869 Udaka T, Hiraki N, Shiomori T, et al. (2007). Eikenella corrodens in head and neck infections. J Infect.
4870 Unal Y, Pampal K, Korkmaz S, et al. (2007). Comparison of bupivacaine and ropivacaine on postoperative pain after tonsillectomy in paediatric patients. Int J Pediatr Otorhinolaryngol.
4871 Unsworth V, Franck LS, Choonara I. (2007). Parental assessment and management of children's postoperative pain: a randomized clinical trial. J Child Health Care.
4872 Uong EC, Epperson M, Bathon SA, et al. (2007). Adherence to nasal positive airway pressure therapy among school-aged children and adolescents with obstructive sleep apnea syndrome. Pediatrics.
4873 Vaiman M, Gavrieli H. (2007). Complex evaluation of pain after tonsillectomy. Acta Otolaryngol.
4874 Vaiman M, Gavrieli H, Krakovski D. (2007). Electromyography in evaluation of pain after different types of tonsillectomy: prospective randomized study. ORL; journal for oto-rhino-laryngology and its related specialties.
4875 Vaiman M, Krakovski D, Gavriel H. (2007). Swallowing before and after tonsillectomy as evaluated by surface electromyography. Otolaryngol Head Neck Surg.
4876 Vallee E, Carignan M, Lafrenaye S, et al. (2007). Comparative study of acetaminophen-morphine versus rofecoxib-morphine for post-tonsillectomy pain control. J Otolaryngol.
4877 Van Kuiken DM, Li L, Martz Huth M. (2007). The difficulties of studying children's pain at home. West J Nurs Res.
4878 van Lierop AC, Prescott CA, Fagan JJ, et al. (2007). Is diagnostic tonsillectomy indicated in all children with asymmetrically enlarged tonsils?. S Afr Med J.
4879 van Lierop AC, Prescott CA, Sinclair-Smith CC. (2007). An investigation of the significance of Actinomycosis in tonsil disease. Int J Pediatr Otorhinolaryngol.
4880 Vanpouille C, Biancotto A, Lisco A, et al. (2007). Interactions between human immunodeficiency virus type 1 and vaccinia virus in human lymphoid tissue ex vivo. J Virol.
4881 Vargas PA, Torres-Rendon A, Speight PM. (2007). DNA ploidy analysis in salivary gland tumours by image cytometry. J Oral Pathol Med.
4882 Vasku V, Bienertova Vasku J, Pavkova Goldbergova M, et al. (2007). Three retinoid X receptor gene polymorphisms in plaque psoriasis and psoriasis guttata. Dermatology.
4883 Vaughan AH, Derkay CS. (2007). Microdebrider intracapsular tonsillectomy. ORL J Otorhinolaryngol Relat Spec.
4884 Verhulst SL, Schrauwen N, Haentjens D, et al. (2007). Sleep-disordered breathing in overweight and obese children and adolescents: prevalence, characteristics and the role of fat distribution. Arch Dis Child.
4885 Verma A, Al Nabhani S, Al-Khabori M. (2007). Adult tonsillectomy and day care surgery. Indian J Otolaryngol Head Neck Surg.
4886 Vestergaard H, Wohlfahrt J, Westergaard T, et al. (2007). Incidence of tonsillectomy in Denmark, 1980 to 2001. Pediatr Infect Dis J.
4887 Villa MP, Malagola C, Pagani J, et al. (2007). Rapid maxillary expansion in children with obstructive sleep apnea syndrome: 12-month follow-up. Sleep Med.
4888 Vlahovic P, Avramovic V, Stankovic M, et al. (2007). Elevated serum dipeptidyl peptidase IV activity in patients with chronic tonsillitis. Ann Clin Biochem.
4889 Voronov P, Przybylo HJ, Jagannathan N. (2007). Apnea in a child after oral codeine: a genetic variant - an ultra-rapid metabolizer. Paediatr Anaesth.
4890 Vuono IM, Zanoteli E, de Oliveira AS, et al. (2007). Histological analysis of palatopharyngeal muscle from children with snoring and obstructive sleep apnea syndrome. Int J Pediatr Otorhinolaryngol.
4891 Walker P, Gillies D. (2007). Post-tonsillectomy hemorrhage rates: are they technique-dependent?. Otolaryngol Head Neck Surg.
4892 Walker P, Whitehead B, Rowley M. (2007). Elective admission to PICU after adenotonsillectomy for severe obstructive sleep apnoea. Anaesth Intensive Care.
4893 Walner DL, Parker NP, Miller RP. (2007). Past and present instrument use in pediatric adenotonsillectomy. Otolaryngol Head Neck Surg.
4894 Wang CP, Kwan PC, Ho CY. (2007). Lipoma of the palatine tonsil. J Formos Med Assoc.
4895 Watanabe IC, Billis A, Guimaraes MS, et al. (2007). Renal medullary carcinoma: report of seven cases from Brazil. Mod Pathol.
4896 Wei JL, Mayo MS, Smith HJ, et al. (2007). Improved behavior and sleep after adenotonsillectomy in children with sleep-disordered breathing. Arch Otolaryngol Head Neck Surg.
4897 Weinstein GS, O'Malley BW, Snyder W, et al. (2007). Transoral robotic surgery: radical tonsillectomy. Archives of otolaryngology--head & neck surgery.
4898 Westhout F, Hasso A, Jalili M, et al. (2007). Lemierre syndrome complicated by cavernous sinus thrombosis, the development of subdural empyemas, and internal carotid artery narrowing without cerebral infarction. Case report. J Neurosurg.
4899 Wiggins SA, Foster RL. (2007). Pain after tonsillectomy and adenoidectomy: “ouch it did hurt bad”. Pain Manag Nurs.
4900 Wong BYH, Ng YW, Hui Y. (2007). A 10 year review of tonsillectomy in a tertiary centre. Hong Kong Journal of Paediatrics.
4901 Woodson BT. (2007). Innovative technique for lingual tonsillectomy and midline posterior glossectomy for obstructive sleep apnea. Operative Techniques in Otolaryngology - Head and Neck Surgery.
4902 Woodson BT. (2007). Transpalatal advancement pharyngoplasty. Operative Techniques in Otolaryngology - Head and Neck Surgery.
4903 Woodson BT, Robinson S. (2007). Reply to: coblation lingual tonsillectomy. Otolaryngol Head Neck Surg.
4904 Worley NK, Abdalkhani A, Hagmann MA, et al. (2007). Gold laser versus curettage adenoidectomy: incidence of complications and otorrhea after concurrent pressure-equalization tube placement. Laryngoscope.
4905 Wu K, Walker E, Owen G. (2007). Nurse-led ‘one stop’ clinic for elective tonsillectomy referrals. J Laryngol Otol.
4906 Yeo SG, Park DC, Choo JH, et al. (2007). Squamous metaplasia and BCL-6 in pediatric adenoid accompanied by otitis media with effusion. Yonsei Med J.
4907 Zhang CY, Mao L, Li L, et al. (2007). Promoter methylation as a common mechanism for inactivating E-cadherin in human salivary gland adenoid cystic carcinoma. Cancer.
4908 Zhang Q, Bagrade L, Bernatoniene J, et al. (2007). Low CD4 T cell immunity to pneumolysin is associated with nasopharyngeal carriage of pneumococci in children. J Infect Dis.
4909 Zhang XW, Li Y, Zhou F, et al. (2007). Comparison of polygraphic parameters in children with adenotonsillar hypertrophy with vs without obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
4910 Zhu Z, Qiu Y, Wang B, et al. (2007). Abnormal spreading and subunit expression of junctional acetylcholine receptors of paraspinal muscles in scoliosis associated with syringomyelia. Spine (Phila Pa 1976).
4911 (2008). Guideline for monitoring and management of pediatric patients during and after sedation for diagnostic and therapeutic procedures. Pediatr Dent.
4912 (2008). An extension of the Jerger classification of tympanograms for ventilation tube patency--specification and evaluation of equivalent ear-canal volume criteria. Ear Hear.
4913 Abdelwhab S, Dessoukey KM, Lotfy G, et al. (2008). Effect of tonsillectomy and/or adenoidectomy on pulmonary arterial pressure in adults. Central European Journal of Medicine.
4914 Abdullah B, Othman NAN, Daud MK. (2008). Outcome of laser-assisted uvulopalatoplasty (LAUP) in the management of snoring in Hospital Universiti Sains Malaysia (USM). Malaysian Journal of Medical Sciences.
4915 Abreu RR, Rocha RL, Lamounier JA, et al. (2008). Etiology, clinical manifestations and concurrent findings in mouth-breathing children. J Pediatr (Rio J).
4916 Abu-Shahwan I. (2008). Ketamine does not reduce postoperative morphine consumption after tonsillectomy in children. Clin J Pain.
4917 Adnan MT, Abdel-Fattah MM, Makhdoom NK, et al. (2008). Does the use of radiofrequency ultrasonic dissector in tonsillectomy have a beneficial effect over the use of laser?. Saudi Med J.
4918 Adoga AS, Onakoya PA, Mgbor NC, et al. (2008). Day case adenotonsiletomy: experience of two private clinics in Nigeria. Niger J Med.
4919 Agarwal JP, Jain S, Gupta T, et al. (2008). Intraoral adenoid cystic carcinoma: prognostic factors and outcome. Oral Oncol.
4920 Ajala AM, Goodwin JA, Goodwin SR, et al. (2008). Undiagnosed Graves' Disease contributing to sleep disordered breathing in a child undergoing adenotonsillectomy. Paediatr Anaesth.
4921 Al-Abbasi AM, Saeed ZK. (2008). Hydrogen Peroxide 3%: Is it Beneficial in Tonsillectomy?. Sultan Qaboos Univ Med J.
4922 Alabidi A. (2008). Aspiration of an incisor tooth after adenotonsillectomy in a 10-year-old Saudi boy. East Mediterr Health J.
4923 Alatas N, Baba F. (2008). Proliferating active cells, lymphocyte subsets, and dendritic cells in recurrent tonsillitis: their effect on hypertrophy. Arch Otolaryngol Head Neck Surg.
4924 Alhamarneh O, Raja H, England RJ. (2008). Inadequate analgesic prescription increases secondary post-tonsillectomy bleed rates: a completed audit loop. J Laryngol Otol.
4925 Ali RB, Smyth D, Kane R, et al. (2008). Post-tonsillectomy bleeding: a regional hospital experience. Ir J Med Sci.
4926 Ali SM, Shahrbano S, Ulhaq TS. (2008). Tramadol for pain relief in children undergoing adenotonsillectomy: a comparison with dextromethorphan. Laryngoscope.
4927 Al-Mazrou KA, Al-Khattaf AS. (2008). Adherent biofilms in adenotonsillar diseases in children. Arch Otolaryngol Head Neck Surg.
4928 Al-Najjar FY, Uduman SA. (2008). Clinical utility of a new rapid test for the detection of group A Streptococcus and discriminate use of antibiotics for bacterial pharyngitis in an outpatient setting. Int J Infect Dis.
4929 Al-Saab F, Manoukian JJ, Al-Sabah B, et al. (2008). Linking laryngopharyngeal reflux to otitis media with effusion: pepsinogen study of adenoid tissue and middle ear fluid. J Otolaryngol Head Neck Surg.
4930 Al-Shamahy HA, Jabbar AAR, Al-Nabhi B, et al. (2008). The prevalence of Streptococcus pneumoniae carriage among healthy children in Yemen. Emirates Medical Journal.
4931 Amin R, Anthony L, Somers V, et al. (2008). Growth velocity predicts recurrence of sleep-disordered breathing 1 year after adenotonsillectomy. Am J Respir Crit Care Med.
4932 Anwar M, Awad Z. (2008). Re: Digital tonsil dissection. Clin Otolaryngol.
4933 Apostolidou MT, Alexopoulos EI, Chaidas K, et al. (2008). Obesity and persisting sleep apnea after adenotonsillectomy in Greek children. Chest.
4934 Apostolidou MT, Alexopoulos EI, Damani E, et al. (2008). Absence of blood pressure, metabolic, and inflammatory marker changes after adenotonsillectomy for sleep apnea in Greek children. Pediatr Pulmonol.
4935 Arikan OK, Sahin S, Kazkayasi M, et al. (2008). High-dose ropivacaine versus bupivacaine for posttonsillectomy pain relief in adults. J Otolaryngol Head Neck Surg.
4936 Ariyoshi Y, Shimahara M, Omura K, et al. (2008). Epidemiological study of malignant tumors in the oral and maxillofacial region: survey of member institutions of the Japanese Society of Oral and Maxillofacial Surgeons, 2002. Int J Clin Oncol.
4937 Arora S, Agrawal M, Nazmi M, et al. (2008). Histological study of routine tonsillectomy specimen. Indian J Otolaryngol Head Neck Surg.
4938 Atef A, Fawaz AA. (2008). Peritonsillar infiltration with tramadol improves pediatric tonsillectomy pain. Eur Arch Otorhinolaryngol.
4939 Atef A, Fawaz AA. (2008). Intravenous paracetamol is highly effective in pain treatment after tonsillectomy in adults. European archives of oto-rhino-laryngology.
4940 Audit NP. (2008). Impact of NICE guidance on rates of haemorrhage after tonsillectomy: an evaluation of guidance issued during an ongoing national tonsillectomy audit. Qual Saf Health Care.
4941 Avanzini AM, Castellazzi AM, Marconi M, et al. (2008). Children with recurrent otitis show defective IFN gamma-producing cells in adenoids. Pediatr Allergy Immunol.
4942 Aydil U, Iseri E, Kizil Y, et al. (2008). Obstructive upper airway problems and primary enuresis nocturna relationship in pediatric patients: reciprocal study. J Otolaryngol Head Neck Surg.
4943 Aydin O, Ustundag E, Iseri M, et al. (2008). Laryngeal adenoid cystic carcinoma in an adolescent. Kulak Burun Bogaz Ihtis Derg.
4944 Aydin S, Sanli A, Celebi O, et al. (2008). Prevalence of adenoid hypertrophy and nocturnal enuresis in primary school children in Istanbul, Turkey. Int J Pediatr Otorhinolaryngol.
4945 Badolato R, Ghidini C, Facchetti F, et al. (2008). Type I interferon-dependent gene MxA in perinatal HIV-infected patients under antiretroviral therapy as marker for therapy failure and blood plasmacytoid dendritic cells depletion. J Transl Med.
4946 Bae JY, Song E, Kim JT, et al. (2008). Comparison of emergence agitation between sevoflurane, desflurane, and propofol with bispectral index monitoring in pediatric anesthesia. Korean Journal of Anesthesiology.
4947 Bagan P, Le Pimpec-Barthes F, Badia A, et al. (2008). Bronchial sleeve resections: lung function resurrecting procedure. Eur J Cardiothorac Surg.
4948 Baldassari CM, Mitchell RB, Schubert C, et al. (2008). Pediatric obstructive sleep apnea and quality of life: a meta-analysis. Otolaryngol Head Neck Surg.
4949 Banhidy F, Acs N, Puho EH, et al. (2008). Maternal acute respiratory infectious diseases during pregnancy and birth outcomes. Eur J Epidemiol.
4950 Barakate M, Havas T. (2008). Lingual tonsillectomy: a review of 5 years experience and evolution of surgical technique. Otolaryngol Head Neck Surg.
4951 Barrera JE, Shroyer KR, Said S, et al. (2008). Estrogen and progesterone receptor and p53 gene expression in adenoid cystic cancer. Head Neck Pathol.
4952 Batra YK, Rajeev S, Nishtala S, et al. (2008). Anesthetic implications of Carpenter syndrome (Acrocephalopolysyndactyly type II). Paediatr Anaesth.
4953 Bauer I, Hassmann-Poznanska E, Wysocka J, et al. (2008). Adenoid as a source of lymphocytes in the surface secretions of nasopharynx. Int J Pediatr Otorhinolaryngol.
4954 Bennett AM, Emery PJ. (2008). A significant reduction in paediatric post-tonsillectomy vomiting through audit. Ann R Coll Surg Engl.
4955 Bercin S, Kutluhan A, Cetin H, et al. (2008). Relationship between adenoid vegetation and anatomic variations of paranasal sinuses. Acta Otolaryngol.
4956 Berlucchi M, Valetti L, Parrinello G, et al. (2008). Long-term follow-up of children undergoing topical intranasal steroid therapy for adenoidal hypertrophy. Int J Pediatr Otorhinolaryngol.
4957 Berry S, Pascal I, Whittet HB. (2008). Tonsillectomy a chaud for quinsy: revisited. Eur Arch Otorhinolaryngol.
4958 Biltagi MA, Maguid MA, Ghafar MA, et al. (2008). Correlation of 8-isoprostane, interleukin-6 and cardiac functions with clinical score in childhood obstructive sleep apnoea. Acta Paediatr.
4959 Biswas C, Kay NJ. (2008). Re: A tonsillectomy assistant. Clin Otolaryngol.
4960 Bitar M, Khalaf R, Shamseddeen W, et al. (2008). Killer cell immunoglobulin-like receptor (KIR) genotypes in patients with recurrent tonsillitis. Genet Test.
4961 Blackmore KJ, O'Hara J, Flood LM, et al. (2008). The effect of FloSeal on post-tonsillectomy pain: a randomised controlled pilot study. Clinical otolaryngology.
4962 Blenke EJ, Anderson AR, Raja H, et al. (2008). Obstructive sleep apnoea adenotonsillectomy in children: when to refer to a centre with a paediatric intensive care unit?. J Laryngol Otol.
4963 Bock JM, Trask DK. (2008). Coblation-assisted lingual tonsillectomy for dysphagia secondary to tongue base hypertrophy. Ann Otol Rhinol Laryngol.
4964 Braillon A. (2008). Sluder banned from France!. Acta Otolaryngol.
4965 Brinckmann CA, Scapin FP, Bernd LA, et al. (2008). Effect of improved nasal airflow after adenoidectomy on nasal erectile tissue. Arch Otolaryngol Head Neck Surg.
4966 Brook I, Gober AE. (2008). Failure to eradicate streptococci and beta-lactamase producing bacteria. Acta Paediatr.
4967 Brookes JT, Smith RJ, Menezes AH, et al. (2008). Median labiomandibular glossotomy approach to the craniocervical region. Childs Nerv Syst.
4968 Bryborn M, Mansson A, Cardell LO, et al. (2008). Differentiated S100A7 expression in infected tonsils and tonsils from allergic individuals. FEMS Immunol Med Microbiol.
4969 Burton MJ. (2008). Commentary: Tonsillectomy--then and now. Int J Epidemiol.
4970 Byard RW. (2008). Tonsillitis and sudden childhood death. J Forensic Leg Med.
4971 C TP, Weckx LL. (2008). ENT care of children and adolescents in the Brazilian public healthy system in three different municipalities. Braz J Otorhinolaryngol.
4972 Caliskan E, Bozdogan N, Kocum A, et al. (2008). Anesthetic management of adenotonsillectomy in a child with bidirectional superior cavapulmonary shunt. Paediatr Anaesth.
4973 Canbay O, Celebi N, Uzun S, et al. (2008). Topical ketamine and morphine for post-tonsillectomy pain. Eur J Anaesthesiol.
4974 Capici F, Ingelmo PM, Davidson A, et al. (2008). Randomized controlled trial of duration of analgesia following intravenous or rectal acetaminophen after adenotonsillectomy in children. Br J Anaesth.
4975 Carney AS, Harris PK, MacFarlane PL, et al. (2008). The coblation tonsillectomy learning curve. Otolaryngol Head Neck Surg.
4976 Carr S, Fraser L. (2008). Re: Use of a towel clip to prevent slipping of Draffin rods. Clin Otolaryngol.
4977 Casey JR, Kahn R, Gmoser D, et al. (2008). Frequency of symptomatic relapses of group A beta-hemolytic streptococcal tonsillopharyngitis in children from 4 pediatric practices following penicillin, amoxicillin, and cephalosporin antibiotic treatment. Clin Pediatr (Phila).
4978 Caspari SS, Strand EA, Kotagal S, et al. (2008). Obstructive sleep apnea, seizures, and childhood apraxia of speech. Pediatr Neurol.
4979 Castorena-Maldonado A, Torre-Bouscoulet L, Meza-Vargas S, et al. (2008). Preoperative continuous positive airway pressure compliance in children with obstructive sleep apnea syndrome: assessed by a simplified approach. Int J Pediatr Otorhinolaryngol.
4980 Celenk F, Bayazit YA, Yilmaz M, et al. (2008). Tonsillar regrowth following partial tonsillectomy with radiofrequency. Int J Pediatr Otorhinolaryngol.
4981 Chandrashekariah R, Shaman Z, Auckley D. (2008). Impact of upper airway surgery on CPAP compliance in difficult-to-manage obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
4982 Chang SY, Lee CN, Lin PH, et al. (2008). A community-derived outbreak of adenovirus type 3 in children in Taiwan between 2004 and 2005. J Med Virol.
4983 Che X, Reichelt M, Sommer MH, et al. (2008). Functions of the ORF9-to-ORF12 gene cluster in varicella-zoster virus replication and in the pathogenesis of skin infection. J Virol.
4984 Chen WT, Soong WJ, Lee YS, et al. (2008). The safety of aerodigestive tract flexible endoscopy as an outpatient procedure in young children. J Chin Med Assoc.
4985 Cheng CC, Huang LM, Kao CL, et al. (2008). Molecular and clinical characteristics of adenoviral infections in Taiwanese children in 2004-2005. Eur J Pediatr.
4986 Chlabicz S, Pytel-Krolczuk B, Oltarzewska AM, et al. (2008). Management of sore throat in Polish primary care facilities: an example from the country with rare use of microbiological testing. J Clin Pharm Ther.
4987 Chu WC, Man GC, Lam WW, et al. (2008). Morphological and functional electrophysiological evidence of relative spinal cord tethering in adolescent idiopathic scoliosis. Spine (Phila Pa 1976).
4988 Cohen D, Dor M. (2008). Morbidity and mortality of post-tonsillectomy bleeding: analysis of cases. J Laryngol Otol.
4989 Colen TY, Seidman C, Weedon J, et al. (2008). Effect of intracapsular tonsillectomy on quality of life for children with obstructive sleep-disordered breathing. Arch Otolaryngol Head Neck Surg.
4990 Constantin E, McGregor CD, Cote V, et al. (2008). Pulse rate and pulse rate variability decrease after adenotonsillectomy for obstructive sleep apnea. Pediatr Pulmonol.
4991 Copelli C, Bianchi B, Ferrari S, et al. (2008). Malignant tumors of intraoral minor salivary glands. Oral Oncol.
4992 Coppo R. (2008). Pediatric IgA nephropathy: clinical and therapeutic perspectives. Semin Nephrol.
4993 Costantini F, Salamanca F, Amaina T, et al. (2008). Videoendoscopic adenoidectomy with microdebrider. Acta Otorhinolaryngol Ital.
4994 Costantini M, Montalti R, Rossi G, et al. (2008). Adenocarcinoid tumor of the extrahepatic biliary tract. Int J Surg Pathol.
4995 Couch JR. (2008). Spontaneous intracranial hypotension: the syndrome and its complications. Curr Treat Options Neurol.
4996 Crandall M, Lammers C, Senders C, et al. (2008). Children's pre-operative tonsillectomy pain education: clinical outcomes. Int J Pediatr Otorhinolaryngol.
4997 Criddle MW, Stinson A, Savliwala M, et al. (2008). Pediatric chronic rhinosinusitis: a retrospective review. Am J Otolaryngol.
4998 Dalalah D, Magableh S. (2008). A remote fuzzy multicriteria diagnosis of sore throat. Telemed J E Health.
4999 Davenport V, Groves E, Horton RE, et al. (2008). Mucosal immunity in healthy adults after parenteral vaccination with outer-membrane vesicles from Neisseria meningitidis serogroup B. J Infect Dis.
5000 Davis PJ, Fertal KM, Boretsky KR, et al. (2008). The effects of oral ondansetron disintegrating tablets for prevention of at-home emesis in pediatric patients after ear-nose-throat surgery. Anesth Analg.
5001 De Felice C, De Capua B, Costantini D, et al. (2008). Recurrent otitis media with effusion in preterm infants with histologic chorioamnionitis--a 3 years follow-up study. Early Hum Dev.
5002 de la Chaux R, Klemens C, Patscheider M, et al. (2008). Tonsillotomy in the treatment of obstructive sleep apnea syndrome in children: polysomnographic results. Int J Pediatr Otorhinolaryngol.
5003 Demars SM, Harsha WJ, Crawford JV. (2008). The effects of smoking on the rate of postoperative hemorrhage after tonsillectomy and uvulopalatopharyngoplasty. Arch Otolaryngol Head Neck Surg.
5004 Devaney KO, Rinaldo A, Ferlito A, et al. (2008). Squamous carcinoma arising in a branchial cleft cyst: have you ever treated one? Will you?. J Laryngol Otol.
5005 Dewell RD, Hoffman TW, Woerner DR, et al. (2008). Estimated compliance for removal of specified risk materials from 18 U.S. beef packing plants. J Food Prot.
5006 Dhiwakar M, McKerrow WS. (2008). Re: Antimicrobial prophylaxis in otorhinolaryngology/head and neck surgery. Clin Otolaryngol.
5007 Di Francesco R, Paulucci B, Nery C, et al. (2008). Craniofacial morphology and otitis media with effusion in children. Int J Pediatr Otorhinolaryngol.
5008 Dirjomuljono M, Kristyono I, Tjandrawinata RR, et al. (2008). Symptomatic treatment of acute tonsillo-pharyngitis patients with a combination of Nigella sativa and Phyllanthus niruri extract. Int J Clin Pharmacol Ther.
5009 Dolev Y, Daniel SJ. (2008). The presence of unilateral tonsillar enlargement in patients diagnosed with palatine tonsil lymphoma: experience at a tertiary care pediatric hospital. Int J Pediatr Otorhinolaryngol.
5010 Donovan TJ. (2008). Sinusitis in the pediatric population. Mo Med.
5011 Doshi J, Damadora M, Gregory S, et al. (2008). Post-tonsillectomy morbidity statistics: are they underestimated?. J Laryngol Otol.
5012 Duggal P, Chakravorty S, Sharma S, et al. (2008). Pedunculated hamartomatous polyp of palatine tonsil in a child: A new presentation. International Journal of Pediatric Otorhinolaryngology Extra.
5013 Duman D, Naiboglu B, Esen HS, et al. (2008). Impaired right ventricular function in adenotonsillar hypertrophy. Int J Cardiovasc Imaging.
5014 Durakovic Z, Misigoj Durakovic M, Skavic J, et al. (2008). Myopericarditis and sudden cardiac death due to physical exercise in male athletes. Coll Antropol.
5015 Duval M, Daniel SJ. (2008). Retropharyngeal and parapharyngeal abscesses or phlegmons in children. Is there an association with adenotonsillectomy? Int J Pediatr Otorhinolaryngol.
5016 Eftekharian A, Raad N, Gholami-Ghasri N. (2008). Bruxism and adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
5017 Eker HE, Alkis N, Alkaya F. (2008). Comparison of multimodal analgesia regimens for adult tonsillectomy: Prospective clinical study. Anestezi Dergisi.
5018 Elwany S, Nour YA, Magdy EA. (2008). Does laryngopharyngeal reflux affect healing and recovery after tonsillectomy?. J Laryngol Otol.
5019 Erdem AF, Yoruk O, Alici HA, et al. (2008). Subhypnotic propofol infusion plus dexamethasone is more effective than dexamethasone alone for the prevention of vomiting in children after tonsillectomy. Paediatr Anaesth.
5020 Erovic BM, Woegerbauer M, Pammer J, et al. (2008). Strong evidence for up-regulation of cyclooxygenase-1 in head and neck cancer. Eur J Clin Invest.
5021 Ertugrul BM, Basak O, Eyigor M, et al. (2008). Two cases of extraordinary chronic rhinosinusitis in pediatrics: Take care of antibiotic overprescribing in primary care. International Journal of Pediatric Otorhinolaryngology Extra.
5022 Erzin Y, Telaku S, Yirmibescik S, et al. (2008). Prevalence of appendectomy and tonsillectomy in patients with inflammatory bowel disease: a case-control study. Turk J Gastroenterol.
5023 Escher R, Haltmeier S, von Steiger N, et al. (2008). Advanced Lemierre syndrome requiring surgery. Infection.
5024 Esposito S, Marchisio P, Capaccio P, et al. (2008). Role of atypical bacteria in children undergoing tonsillectomy because of severely recurrent acute tonsillopharyngitis. Eur J Clin Microbiol Infect Dis.
5025 Falagas ME, Vouloumanou EK, Matthaiou DK, et al. (2008). Effectiveness and safety of short-course vs long-course antibiotic therapy for group a beta hemolytic streptococcal tonsillopharyngitis: a meta-analysis of randomized trials. Mayo Clin Proc.
5026 Farris AB, Lauwers GY, Ferry JA, et al. (2008). The rectal tonsil: a reactive lymphoid proliferation that may mimic lymphoma. Am J Surg Pathol.
5027 Femiano F, Lanza A, Buonaiuto C, et al. (2008). Oral aphthous-like lesions, PFAPA syndrome: a review. J Oral Pathol Med.
5028 Fidan T, Fidan V. (2008). The impact of adenotonsillectomy on attention-deficit hyperactivity and disruptive behavioral symptoms. Eurasian J Med.
5029 Fiechtl JF, Stack LB. (2008). Images in clinical medicine. Bilateral peritonsillar abscesses. N Engl J Med.
5030 Fischer T, Fischer S, Himmel W, et al. (2008). Family practitioners' diagnostic decision-making processes regarding patients with respiratory tract infections: an observational study. Med Decis Making.
5031 Fishpool SJ, Harris R, Toma A. (2008). Marking paediatric patients preoperatively. Clin Otolaryngol.
5032 Fox HR, Joice P, Hussain SS. (2008). Travel time to hospital: an important factor for day-case tonsillectomy. Clin Otolaryngol.
5033 Fox R, Temple M, Owens D, et al. (2008). Does tonsillectomy lead to improved outcomes over and above the effect of time? A longitudinal study. J Laryngol Otol.
5034 Garetz SL. (2008). Behavior, cognition, and quality of life after adenotonsillectomy for pediatric sleep-disordered breathing: summary of the literature. Otolaryngol Head Neck Surg.
5035 Gavriel H, Vaiman M, Kessler A, et al. (2008). Microbiology of peritonsillar abscess as an indication for tonsillectomy. Medicine (Baltimore).
5036 Gbotolorun OM, Arotiba GT, Effiom OA, et al. (2008). Minor salivary gland tumours in a Nigerian hospital: a retrospective review of 146 cases. Odontostomatol Trop.
5037 German V, Kopterides P, Poulikakos P, et al. (2008). Respiratory tract infections in a military recruit setting: a prospective cohort study. J Infect Public Health.
5038 Gibb IA, Anderson BJ. (2008). Paracetamol (acetaminophen) pharmacodynamics: interpreting the plasma concentration. Arch Dis Child.
5039 Gilbey P, Gadban H, Letichevsky V, et al. (2008). Harmonic scalpel tonsillectomy using the curved shears instrument versus cold dissection tonsillectomy: a retrospective study. Ann Otol Rhinol Laryngol.
5040 Giordani B, Hodges EK, Guire KE, et al. (2008). Neuropsychological and behavioral functioning in children with and without obstructive sleep apnea referred for tonsillectomy. J Int Neuropsychol Soc.
5041 Gleizal A, Wan DC, Kwan MD, et al. (2008). Myoplasty for congenital macrostomia. Cleft Palate Craniofac J.
5042 Glover JA. (2008). The incidence of tonsillectomy in school children. 1938. Int J Epidemiol.
5043 Gobindram A, Patel A. (2008). ENT emergencies. Anaesthesia and Intensive Care Medicine.
5044 Gois EG, Ribeiro-Junior HC, Vale MP, et al. (2008). Influence of nonnutritive sucking habits, breathing pattern and adenoid size on the development of malocclusion. Angle Orthod.
5045 Goldstein NA, Stewart MG, Witsell DL, et al. (2008). Quality of life after tonsillectomy in children with recurrent tonsillitis. Otolaryngol Head Neck Surg.
5046 Gomez DR, Hoppe BS, Wolden SL, et al. (2008). Outcomes and prognostic variables in adenoid cystic carcinoma of the head and neck: a recent experience. Int J Radiat Oncol Biol Phys.
5047 Gorini E, Mevio N, Mullace M, et al. (2008). Aberrant internal carotid artery presenting in the retropharyngeal space: Case report. Gazzetta Medica Italiana Archivio per le Scienze Mediche.
5048 Goto T, Bandoh N, Yoshizaki T, et al. (2008). Increase in B-cell-activation factor (BAFF) and IFN-gamma productions by tonsillar mononuclear cells stimulated with deoxycytidyl-deoxyguanosine oligodeoxynucleotides (CpG-ODN) in patients with IgA nephropathy. Clin Immunol.
5049 Gozal D, Capdevila OS, Kheirandish-Gozal L. (2008). Metabolic alterations and systemic inflammation in obstructive sleep apnea among nonobese and obese prepubertal children. Am J Respir Crit Care Med.
5050 Gozal D, Kheirandish-Gozal L, Capdevila OS, et al. (2008). Prevalence of recurrent otitis media in habitually snoring school-aged children. Sleep Med.
5051 Gozal D, Serpero LD, Sans Capdevila O, et al. (2008). Systemic inflammation in non-obese children with obstructive sleep apnea. Sleep Med.
5052 Graf G, Jelen M, Jamnig D, et al. (2008). A comparison of the efficacy and rate of side-effects of mefenamic acid and naproxen in adult patients following elective tonsillectomy: a randomized double-blind study. Acute Pain.
5053 Grainger J, Saravanappa N. (2008). Local anaesthetic for post-tonsillectomy pain: a systematic review and meta-analysis. Clin Otolaryngol.
5054 Grob GN. (2008). A cautionary tale: tonsillectomy in modern America. MD Advis.
5055 Guerra MM, Garcia E, Pilan RR, et al. (2008). Antibiotic use in post-adenotonsillectomy morbidity: a randomized prospective study. Braz J Otorhinolaryngol.
5056 Guilleminault C, Davis K, Huynh NT. (2008). Prospective randomized study of patients with insomnia and mild sleep disordered breathing. Sleep.
5057 Guilleminault C, Quo S, Huynh NT, et al. (2008). Orthodontic expansion treatment and adenotonsillectomy in the treatment of obstructive sleep apnea in prepubertal children. Sleep.
5058 Guimaraes CV, Kalra M, Donnelly LF, et al. (2008). The frequency of lingual tonsil enlargement in obese children. AJR Am J Roentgenol.
5059 Gurgel RK, Brookes JT, Weinberger MM, et al. (2008). Chronic cough and tonsillar hypertrophy: a case series. Pediatr Pulmonol.
5060 Haapkyla J, Karevold G, Kvaerner KJ, et al. (2008). Trends in otitis media surgery: a decrease in adenoidectomy. Int J Pediatr Otorhinolaryngol.
5061 Hagelskjaer Kristensen L, Prag J. (2008). Localised Fusobacterium necrophorum infections: a prospective laboratory-based Danish study. Eur J Clin Microbiol Infect Dis.
5062 Halbower AC, McGinley BM, Smith PL. (2008). Treatment alternatives for sleep-disordered breathing in the pediatric population. Curr Opin Pulm Med.
5063 Hall CJ, Thompson JW, Bailey J. (2008). Health care reform: pediatric elective surgery payer mix and utilization under Tenncare managed competition. Tenn Med.
5064 Hamdan AL, Sabra O, Hadi U. (2008). Prevalence of adenoid hypertrophy in adults with nasal obstruction. J Otolaryngol Head Neck Surg.
5065 Harris RL, Mitchell JE, Jonathan DA. (2008). A telephone audit in parallel with the UK national tonsillectomy audit to investigate re-admission as a measure of secondary haemorrhage rate. Auris Nasus Larynx.
5066 Hasan H, Raitiola H, Chrapek W, et al. (2008). Randomized study comparing postoperative pain between coblation and bipolar scissor tonsillectomy. Eur Arch Otorhinolaryngol.
5067 Hauswald H, Lindel K, Rochet N, et al. (2008). Surgery with complete resection improves survival in radiooncologically treated patients with cervical lymph node metastases from cancer of unknown primary. Strahlenther Onkol.
5068 Head MW, Ironside JW. (2008). Creutzfeldt-Jakob disease and the eye. Expert Review of Ophthalmology.
5069 Henney SE. (2008). Tonsillectomy trial outcome analysis. Clin Otolaryngol.
5070 Hobbs CG, Groves E, Davenport V, et al. (2008). Tonsil T cell immunity to human papillomavirus in the absence of detectable virus in healthy adults. Laryngoscope.
5071 Hodges EK, Bloomfield E, Coulas T, et al. (2008). Cognitive and behavioral change after adenotonsillectomy in children with sleep-disordered breathing: A review. Minerva Psichiatrica.
5072 Hofer MF. (2008). Cured by tonsillectomy: was it really a PFAPA syndrome?. J Pediatr.
5073 Hogan AM, Hill CM, Harrison D, et al. (2008). Cerebral blood flow velocity and cognition in children before and after adenotonsillectomy. Pediatrics.
5074 Honarmand A, Safavi MR, Jamshidi M. (2008). The preventative analgesic effect of preincisional peritonsillar infiltration of two low doses of ketamine for postoperative pain relief in children following adenotonsillectomy. A randomized, double-blind, placebo-controlled study. Paediatr Anaesth.
5075 Hong CK, Park DC, Kim SW, et al. (2008). Effect of paranasal sinusitis on the development of otitis media with effusion: influence of eustachian tube function and adenoid immunity. Int J Pediatr Otorhinolaryngol.
5076 Hsiao KH, Nixon GM. (2008). The effect of treatment of obstructive sleep apnea on quality of life in children with cerebral palsy. Res Dev Disabil.
5077 Hu TL, Yun C, Wang R, et al. (2008). Management of velopharyngeal insufficiency in the presence of enlarged tonsils: comparing a one-stage versus two-stage treatment result. J Plast Reconstr Aesthet Surg.
5078 Hugg T, Ruotsalainen R, Jaakkola MS, et al. (2008). Comparison of allergic diseases, symptoms and respiratory infections between Finnish and Russian school children. Eur J Epidemiol.
5079 Humber N, Frecker T. (2008). Rural surgery in British Columbia: is there anybody out there?. Can J Surg.
5080 Ingarfield SL, Celenza A, Jacobs IG, et al. (2008). Acute upper respiratory infections in Western Australian emergency departments, 2000-2003. Aust Health Rev.
5081 Inoue CN, Nagasaka T, Matsutani S, et al. (2008). Efficacy of early dental and ENT therapy in preventing nephropathy in pediatric Henoch-Schonlein purpura. Clin Rheumatol.
5082 Isaacson G, Parikh T. (2008). Developmental anatomy of the tonsil and its implications for intracapsular tonsillectomy. Int J Pediatr Otorhinolaryngol.
5083 Islam A, Oko M. (2008). Cervical necrotising fasciitis and descending mediastinitis secondary to unilateral tonsillitis: a case report. J Med Case Rep.
5084 Jain A, Shukla VK, Tiwari V, et al. (2008). Antibiotic resistance pattern of group-a beta-hemolytic streptococci isolated from north Indian children. Indian J Med Sci.
5085 Janjanin S, Djouad F, Shanti RM, et al. (2008). Human palatine tonsil: a new potential tissue source of multipotent mesenchymal progenitor cells. Arthritis Res Ther.
5086 Jeyakumar A, Brickman TM, Williamson ME, et al. (2008). Nonsteroidal anti-inflammatory drugs and postoperative bleeding following adenotonsillectomy in pediatric patients. Arch Otolaryngol Head Neck Surg.
5087 Jha AK, Sharma S. (2008). Patients with tonsil problems at NMCTH--a report. Nepal Med Coll J.
5088 Johnson K, Vaughan A, Derkay C, et al. (2008). Microdebrider vs electrocautery: a comparison of tonsillar wound healing histopathology in a canine model. Otolaryngol Head Neck Surg.
5089 Johnson KP, Malow BA. (2008). Sleep in children with autism spectrum disorders. Current Treatment Options in Neurology.
5090 Jong YH, Gendeh BS. (2008). Transoral endoscopic adenoidectomy: initial experience. Med J Malaysia.
5091 Joshi SK, Dudani I. (2008). Environmental health effects of brick kilns in Kathmandu valley. Kathmandu Univ Med J (KUMJ).
5092 Juvonen R, Bloigu A, Peitso A, et al. (2008). Training improves physical fitness and decreases CRP also in asthmatic conscripts. J Asthma.
5093 Kaditis A. (2008). Blood pressure after adenotonsillectomy in children with obstructive sleep-disordered breathing. Am J Respir Crit Care Med.
5094 Kaditis AG, Alexopoulos EI, Hatzi F, et al. (2008). Adiposity in relation to age as predictor of severity of sleep apnea in children with snoring. Sleep Breath.
5095 Kaditis AG, Ioannou MG, Chaidas K, et al. (2008). Cysteinyl leukotriene receptors are expressed by tonsillar T cells of children with obstructive sleep apnea. Chest.
5096 Kandogan T, Olgun L, Ozuer MZ. (2008). Management of lingual tonsillar hypertrophy using microdebrider. Kulak Burun Bogaz Ihtis Derg.
5097 Kang JM, Auo HJ, Yoo YH, et al. (2008). Changes in serum levels of IGF-1 and in growth following adenotonsillectomy in children. Int J Pediatr Otorhinolaryngol.
5098 Kania RE, Lamers GE, Vonk MJ, et al. (2008). Characterization of mucosal biofilms on human adenoid tissues. Laryngoscope.
5099 Kanotra S, Kanotra S, Paul J. (2008). A giant tonsillolith. Indian J Otolaryngol Head Neck Surg.
5100 Kara CO, Tumkaya F, Ardic N, et al. (2008). Does tonsillectomy reduce the risk of being a habitual or severe snorer?. Eur Arch Otorhinolaryngol.
5101 Kara CO, Yilmaz M, Kirac S. (2008). Tonsillectomy does not decrease the risk of Helicobacter pylori transmission. J Clin Gastroenterol.
5102 Karaaslan K, Yilmaz F, Gulcu N, et al. (2008). The effects of levobupivacaine versus levobupivacaine plus magnesium infiltration on postoperative analgesia and laryngospasm in pediatric tonsillectomy patients. Int J Pediatr Otorhinolaryngol.
5103 Karatas E, Goksu S, Gul R, et al. (2008). Acute respiratory complications after uvulopalatopharyngoplasty. Turkiye Klinikleri Journal of Medical Sciences.
5104 Karatzanis A, Bourolias C, Prokopakis E, et al. (2008). Thermal welding technology vs ligasure tonsillectomy: a comparative study. Am J Otolaryngol.
5105 Karlson KH. (2008). Whats new in pediatric obstructive sleep apnea?. Clinical Pulmonary Medicine.
5106 Katotomichelakis M, Balatsouras DG, Bassioukas K, et al. (2008). Recurrent prurigo nodularis related to infected tonsils: A case report. Journal of Medical Case Reports.
5107 Kawasaki Y. (2008). The pathogenesis and treatment of IgA nephropathy. Fukushima J Med Sci.
5108 Khalil SN, Maposa D, Ghelber O, et al. (2008). Caffeine in children with obstructive sleep apnea. Middle East J Anaesthesiol.
5109 Kheirandish-Gozal L, Gozal D. (2008). Intranasal budesonide treatment for children with mild obstructive sleep apnea syndrome. Pediatrics.
5110 Kilty SJ, Gaboury I. (2008). Clinical predictors of peritonsillar abscess in adults. J Otolaryngol Head Neck Surg.
5111 Kim DY, Rah YC, Kim DW, et al. (2008). Impact of tonsillectomy on pediatric psychological status. Int J Pediatr Otorhinolaryngol.
5112 Kim E, Hansen K, Frizzi J. (2008). Eagle syndrome: case report and review of the literature. Ear Nose Throat J.
5113 Kim HY, Kim MB, Dhong HJ, et al. (2008). Changes of maxillary sinus volume and bony thickness of the paranasal sinuses in longstanding pediatric chronic rhinosinusitis. Int J Pediatr Otorhinolaryngol.
5114 Kim MS, Park K, Kim JH, et al. (2008). Gamma knife radiosurgery for orbital tumors. Clin Neurol Neurosurg.
5115 Kindermann CA, Roithmann R, Lubianca Neto JF. (2008). Obstruction of the eustachian tube orifice and pressure changes in the middle ear: are they correlated?. Ann Otol Rhinol Laryngol.
5116 Kindermann CA, Roithmann R, Lubianca Neto JF. (2008). Sensitivity and specificity of nasal flexible fiberoptic endoscopy in the diagnosis of adenoid hypertrophy in children. Int J Pediatr Otorhinolaryngol.
5117 Klemetti S, Suominen T. (2008). Fasting in paediatric ambulatory surgery. Int J Nurs Pract.
5118 Kojima M, Nakamura N, Shimizu K, et al. (2008). Marginal zone B-Cell lymphoma among primary B-Cell lymphoma of Waldeyer's ring: histopathologic and immunohistochemical study of 16 tonsillectomy specimens. Int J Surg Pathol.
5119 Komatsu H, Fujimoto S, Hara S, et al. (2008). Effect of tonsillectomy plus steroid pulse therapy on clinical remission of IgA nephropathy: a controlled study. Clin J Am Soc Nephrol.
5120 Koshiba S, Ichimiya S, Nagashima T, et al. (2008). Tonsillar crypt epithelium of palmoplantar pustulosis secretes interleukin-6 to support B-cell development via p63/p73 transcription factors. J Pathol.
5121 Kothari P, Randhawa PS, Farrell R. (2008). Role of tonsillectomy in the search for a squamous cell carcinoma from an unknown primary in the head and neck. Br J Oral Maxillofac Surg.
5122 Kumar R, Kalra SK, Vaid VK, et al. (2008). Chiari I malformation: surgical experience over a decade of management. Br J Neurosurg.
5123 Kurnatowski P, Putynski L, Lapienis M, et al. (2008). Physical and emotional disturbances in children with adenotonsillar hypertrophy. J Laryngol Otol.
5124 Kurtaran H, Uyar ME, Kasapoglu B, et al. (2008). Role of Helicobacter pylori in pathogenesis of upper respiratory system diseases. J Natl Med Assoc.
5125 Lachance M, Lacroix Y, Audet N, et al. (2008). The use of dexamethasone to reduce pain after tonsillectomy in adults: a double-blind prospective randomized trial. Laryngoscope.
5126 Lam S, Batzdorf U, Bergsneider M. (2008). Thecal shunt placement for treatment of obstructive primary syringomyelia. J Neurosurg Spine.
5127 Lasisi AO, Olayemi O, Irabor AE. (2008). Early onset otitis media: risk factors and effects on the outcome of chronic suppurative otitis media. Eur Arch Otorhinolaryngol.
5128 Lee JH, Uhl JR, Cockerill FR, et al. (2008). Real-time PCR vs standard culture detection of group A beta-hemolytic streptococci at various anatomic sites in tonsillectomy patients. Arch Otolaryngol Head Neck Surg.
5129 Lee KD, Lee HS, Hong JC, et al. (2008). Diameter of vessels across the tonsillar capsule as an anatomical consideration for tonsillectomy. Clin Anat.
5130 Leonard DS, Timon C. (2008). Evaluation of the ultracision ultrasonic dissector in head and neck surgery. Operative Techniques in Otolaryngology - Head and Neck Surgery.
5131 Leonetti JP, Marzo SJ, Agarwal N. (2008). Adenoid cystic carcinoma of the parotid gland with temporal bone invasion. Otol Neurotol.
5132 Lerman J. (2008). Did opioid sensitivity contribute to post-tonsillectomy arrest?. Paediatr Anaesth.
5133 Li AM, Chan MH, Yin J, et al. (2008). C-reactive protein in children with obstructive sleep apnea and the effects of treatment. Pediatr Pulmonol.
5134 Li L, Lin L, Wei M. (2008). Tonsillectomy for peritonsillar abscess. Chinese Archives of Otolaryngology-head and Neck Surgery.
5135 Li LJ, Li Y, Wen YM, et al. (2008). Clinical analysis of salivary gland tumor cases in West China in past 50 years. Oral Oncol.
5136 Licameli G, Jeffrey J, Luz J, et al. (2008). Effect of adenotonsillectomy in PFAPA syndrome. Arch Otolaryngol Head Neck Surg.
5137 Licameli GR, Jones DT, Santosuosso J, et al. (2008). Use of a preoperative bleeding questionnaire in pediatric patients who undergo adenotonsillectomy. Otolaryngol Head Neck Surg.
5138 Lima Junior JM, Silva VC, Freitas MR. (2008). Long term results in the life quality of children with obstructive sleep disorders submitted to adenoidectomy/adenotonsillectomy. Braz J Otorhinolaryngol.
5139 Little SA, Veitch DY. (2008). Digital tonsil dissection. Clin Otolaryngol.
5140 Liukkonen K, Virkkula P, Aronen ET, et al. (2008). All snoring is not adenoids in young children. Int J Pediatr Otorhinolaryngol.
5141 Lowe DA. (2008). Re: Teenage and adult tonsillectomy: dose-response relationship between diathermy energy used and morbidity. Clin Otolaryngol.
5142 Lowe DA. (2008). Response to Pothier et al. on ‘The NPTA may have underestimated tonsillectomy complications: a case note review of data submitted by two hospitals’. Clin Otolaryngol.
5143 Lu YJ, Gross J, Bogaert D, et al. (2008). Interleukin-17A mediates acquired immunity to pneumococcal colonization. PLoS Pathog.
5144 Macfarlane PL, Nasser S, Coman WB, et al. (2008). Tonsillectomy in Australia: an audit of surgical technique and postoperative care. Otolaryngol Head Neck Surg.
5145 MacLaren JE, Kain ZN. (2008). Prevalence and predictors of significant sleep disturbances in children undergoing ambulatory tonsillectomy and adenoidectomy. J Pediatr Psychol.
5146 Magdy EA, Elwany S, el-Daly AS, et al. (2008). Coblation tonsillectomy: a prospective, double-blind, randomised, clinical and histopathological comparison with dissection-ligation, monopolar electrocautery and laser tonsillectomies. J Laryngol Otol.
5147 Maltezou HC, Tsagris V, Antoniadou A, et al. (2008). Evaluation of a rapid antigen detection test in the diagnosis of streptococcal pharyngitis in children and its impact on antibiotic prescription. J Antimicrob Chemother.
5148 Manrique D, Sato J, Anastacio EM. (2008). Postoperative acute respiratory insufficiency following adenotonsillectomy in children with neuropathy. Int J Pediatr Otorhinolaryngol.
5149 Marchese-Ragona R, Maria Ferraro S, Marioni G, et al. (2008). Abducent nerve paralysis: first clinical sign of clivus metastasis from tonsillar carcinoma. Acta Otolaryngol.
5150 Marcus CL. (2008). Childhood obstructive sleep apnea syndrome: unanswered questions. Chest.
5151 Marshall S. (2008). Giving advice on sore throats. Pharmaceutical Journal.
5152 Massimi L, Caldarelli M, Paternoster G, et al. (2008). Mini-invasive surgery for Chiari type I malformation. Neuroradiol J.
5153 Masud-Ul-Haq M, Waseem R, Hussain S. (2008). Adenoidectomy, results and assessment. Pakistan Paediatric Journal.
5154 Mazumder SM, Tarafder KH, Doulatuzzaman, et al. (2008). Parotidectomy--a prospective study. J Indian Med Assoc.
5155 McGirt MJ, Atiba A, Attenello FJ, et al. (2008). Correlation of hindbrain CSF flow and outcome after surgical decompression for Chiari I malformation. Childs Nerv Syst.
5156 McGirt MJ, Attenello FJ, Atiba A, et al. (2008). Symptom recurrence after suboccipital decompression for pediatric Chiari I malformation: analysis of 256 consecutive cases. Childs Nerv Syst.
5157 McGirt MJ, Attenello FJ, Datoo G, et al. (2008). Intraoperative ultrasonography as a guide to patient selection for duraplasty after suboccipital decompression in children with Chiari malformation Type I. J Neurosurg Pediatr.
5158 McKean SA, Lee MS, Hussain SS. (2008). Comparative study of posttonsillectomy hemorrhage with the use of diclofenac versus dihydrocodeine for postoperative analgesia and review of the literature. J Otolaryngol Head Neck Surg.
5159 McKenzie SA, Bhattacharya A, Sureshkumar R, et al. (2008). Which obese children should have a sleep study?. Respir Med.
5160 Michel RG, Tsau K, Weinstock BI. (2008). Tissue welding forceps usage in superficial parotidectomy: a clinical assessment. Am Surg.
5161 Michel RG, Weinstock BI, Tsau K. (2008). Safety and efficacy of pressure-assisted tissue-welding tonsillectomy: a preliminary evaluation. Ear Nose Throat J.
5162 Mihaescu M, Murugappan S, Gutmark E, et al. (2008). Computational modeling of upper airway before and after adenotonsillectomy for obstructive sleep apnea. Laryngoscope.
5163 Mitchell RB. (2008). Sleep-disordered breathing in children. Mo Med.
5164 Mogoanta CA, Ionita E, Pirici D, et al. (2008). Chronic tonsillitis: histological and immunohistochemical aspects. Rom J Morphol Embryol.
5165 Monroy A, Behar P, Brodsky L. (2008). Revision adenoidectomy--a retrospective study. Int J Pediatr Otorhinolaryngol.
5166 Morris LG, Lieberman SM, Reitzen SD, et al. (2008). Characteristics and outcomes of malpractice claims after tonsillectomy. Otolaryngol Head Neck Surg.
5167 Motta G, Casolino D, Cassiano B, et al. (2008). Adeno-tonsillar surgery in Italy. Acta Otorhinolaryngol Ital.
5168 Mowry SE, Strocker AM, Chan J, et al. (2008). Immunohistochemical analysis and Epstein-Barr virus in the tonsils of transplant recipients and healthy controls. Arch Otolaryngol Head Neck Surg.
5169 Mueller DT, Isaacson G. (2008). Staged tympanostomy tube placement facilitates pediatric cholesteatoma management. Int J Pediatr Otorhinolaryngol.
5170 Munir N, Bradley PJ. (2008). Diagnosis and management of neoplastic lesions of the submandibular triangle. Oral Oncol.
5171 Muntz H, Wilson M, Park A, et al. (2008). Sleep disordered breathing and obstructive sleep apnea in the cleft population. Laryngoscope.
5172 Musani MA, Sohail Z, Zafar S, et al. (2008). Morphological pattern of parotid gland tumours. J Coll Physicians Surg Pak.
5173 Musiatowicz M, Koda M, Sulkowski S. (2008). The Bak protein expression in germinal centers of hypertrophied adenoids in children. Int J Pediatr Otorhinolaryngol.
5174 Nafiu OO, Chimbira WT, Woolford SJ, et al. (2008). Does high BMI influence hospital charges in children undergoing adenotonsillectomy?. Obesity (Silver Spring).
5175 Naguib MB, Telmessani L, Mowafi HA, et al. (2008). One-day otolaryngologic surgery. A one-year evaluation in an oriental community. Ambulatory Surgery.
5176 Naiboglu B, Deveci S, Duman D, et al. (2008). Effect of upper airway obstruction on pulmonary arterial pressure in children. Int J Pediatr Otorhinolaryngol.
5177 Nalcaci R, Dulgergil T, Oba AA, et al. (2008). Prevalence of breath malodour in 7- 11-year-old children living in Middle Anatolia, Turkey. Community Dent Health.
5178 Nasr VG, Bitar MA, Chehade JM, et al. (2008). Postoperative severe uvular edema following tonsillectomy in a child with a history of obstructive sleep apnea. Paediatr Anaesth.
5179 Nasr VG, Dagher WI, Baraka AS. (2008). Iatrogenic severe hyperglycemia in a child undergoing adenoidectomy and tonsillectomy. Paediatr Anaesth.
5180 Nencioni E, Chiappini E, Liguori A, et al. (2008). Recurrent respiratory infections: why not talking about it any more?. Minerva Pediatr.
5181 Ng SK, Tong MCF. (2008). Obstructive sleep apnoea syndrome in children: What can ENT surgeons offer?. Hong Kong Journal of Paediatrics.
5182 Nia KM, Salehi S. (2008). Evaluation of changes in serum insulin-like growth factor-1 and insulin-like growth factor binding protein 3 in children with adenotonsillar hypertrophy before and after surgery. Journal of Medical Sciences.
5183 Nicolai P, Battaglia P, Bignami M, et al. (2008). Endoscopic surgery for malignant tumors of the sinonasal tract and adjacent skull base: a 10-year experience. Am J Rhinol.
5184 Nicolle LE. (2008). The regulation of infection. Canadian Journal of Infectious Diseases and Medical Microbiology.
5185 Niedzielska G, Kotowski M, Niedzielski A. (2008). Assessment of pulmonary function and nasal flow in children with adenoid hypertrophy. Int J Pediatr Otorhinolaryngol.
5186 Nikandish R, Maghsoodi B, Khademi S, et al. (2008). Peritonsillar infiltration with bupivacaine and pethidine for relief of post-tonsillectomy pain: a randomised double-blind study. Anaesthesia.
5187 Nozawa H, Takahara M, Yoshizaki T, et al. (2008). Selective expansion of T cell receptor (TCR) V beta 6 in tonsillar and peripheral blood T cells and its induction by in vitro stimulation with Haemophilus parainfluenzae in patients with IgA nephropathy. Clin Exp Immunol.
5188 Nuara MJ, Park AH, Alder SC, et al. (2008). Perioral burns after adenotonsillectomy: a potentially serious complication. Arch Otolaryngol Head Neck Surg.
5189 O'Conner-Von S. (2008). Preparation of adolescents for outpatient surgery: using an Internet program. AORN J.
5190 Oettle LC. (2008). Anaesthetic aspects of cutaneous mastocytosis in a child presenting for day surgery: Case presentation. Current Allergy and Clinical Immunology.
5191 Oghan F, Harputluoglu U, Guclu E, et al. (2008). Does topical ropivacaine reduce the post-tonsillectomy morbidity in pediatric patients?. Int J Pediatr Otorhinolaryngol.
5192 Oghan F, Harputluoglu U, Ozturk O, et al. (2008). Does the prevalence of otolaryngological diseases in deaf children differ from children without hearing impairment?. Eur Arch Otorhinolaryngol.
5193 Ogose T. (2008). Tonsillectomy for periodic fever, aphthous stomatitis, pharyngitis, and adenitis syndrome is not always successful. J Pediatr.
5194 Okada T, Saito K, Takahashi M, et al. (2008). En bloc petrosectomy for malignant tumors involving the external auditory canal and middle ear: surgical methods and long-term outcome. J Neurosurg.
5195 Okuyucu S, Inanoglu K, Akkurt CO, et al. (2008). The effect of anesthetic agents on perioperative bleeding during tonsillectomy: propofol-based versus desflurane-based anesthesia. Otolaryngol Head Neck Surg.
5196 Omurzakova NA, Yamano Y, Sato T, et al. (2008). Increased prevalence of group A beta-hemolytic streptococcus among an ethnic population in Kyrgyzstan detected by the rapid antigen detection test. Mol Med Rep.
5197 Orji FT, Ezeanolue BC. (2008). Evaluation of adenoidal obstruction in children: clinical symptoms compared with roentgenographic assessment. J Laryngol Otol.
5198 Ozgursoy OB, Kemal O, Saatci MR, et al. (2008). Actinomycosis in the etiology of recurrent tonsillitis and obstructive tonsillar hypertrophy: answer from a histopathologic point of view. J Otolaryngol Head Neck Surg.
5199 Padeh S, Stoffman N, Berkun Y. (2008). Periodic fever accompanied by aphthous stomatitis, pharyngitis and cervical adenitis syndrome (PFAPA syndrome) in adults. Isr Med Assoc J.
5200 Page C, Biet A, Zaatar R, et al. (2008). Parapharyngeal abscess: diagnosis and treatment. Eur Arch Otorhinolaryngol.
5201 Pantukosit P, Arpornsuwan M, Sookananta K. (2008). A diphtheria outbreak in Buri Ram, Thailand. Southeast Asian J Trop Med Public Health.
5202 Paradise JL. (2008). Indications for tonsillectomy: setting the bar high enough. Arch Otolaryngol Head Neck Surg.
5203 Patel AA, Madigan L, Poelstra KA, et al. (2008). Acute cervical osteomyelitis and prevertebral abscess after routine tonsillectomy. Spine J.
5204 Pereira NA, Motta AR, Vicente LC. (2008). Swallowing reflex: analysis of the efficiency of different stimuli on healthy young individuals. Pro Fono.
5205 Perez IA, Ward SL. (2008). The snoring child. Pediatr Ann.
5206 Persaud R, Awad Z, Georgalas C. (2008). Re: Morbidity after adenotonsillectomy for paediatric obstructive sleep apnoea syndrome: waking up to a pragmatic approach. J Laryngol Otol.
5207 Phillips J, Ward T, Montgomery PQ. (2008). Variations in posttonsillectomy hemorrhage rates are scale invariant. Laryngoscope.
5208 Philpott CM, Wild DC, Wolstensholme CR, et al. (2008). The presence of ovarian hormone receptors in the nasal mucosa and their relationship to nasal symptoms. Rhinology.
5209 Pichichero ME, Casey JR, Block SL, et al. (2008). Pharmacodynamic analysis and clinical trial of amoxicillin sprinkle administered once daily for 7 days compared to penicillin V potassium administered four times daily for 10 days in the treatment of tonsillopharyngitis due to Streptococcus pyogenes in children. Antimicrob Agents Chemother.
5210 Pinto Pereira LM, Juman S, Bekele I, et al. (2008). Selected bacterial recovery in Trinidadian children with chronic tonsillar disease. Braz J Otorhinolaryngol.
5211 Pothier D, Nankivell P. (2008). Response to Lowe on ‘The NPTA may have underestimated tonsillectomy complications: a case note review of data submitted by two hospitals’. Clin Otolaryngol.
5212 Power DA, Burton JP, Chilcott CN, et al. (2008). Preliminary investigations of the colonisation of upper respiratory tract tissues of infants using a paediatric formulation of the oral probiotic Streptococcus salivarius K12. Eur J Clin Microbiol Infect Dis.
5213 Prasai A, Conboy P. (2008). A tonsillectomy assistant. Clin Otolaryngol.
5214 Praud JP, Dorion D. (2008). Obstructive sleep disordered breathing in children: beyond adenotonsillectomy. Pediatr Pulmonol.
5215 Quinn AG, Gouws P, Headland S, et al. (2008). Obstructive sleep apnea syndrome with bilateral papilledema and vision loss in a 3-year-old child. J aapos.
5216 Racic G, Kurtovic D, Colovic Z, et al. (2008). Influence of meteorological conditions on post-tonsillectomy haemorrhage. J Laryngol Otol.
5217 Raja MK, Haneefa MA, Chidambaram A. (2008). Yorick's skull model for tonsillectomy tie training. Clin Otolaryngol.
5218 Ramadan HH, Cost JL. (2008). Outcome of adenoidectomy versus adenoidectomy with maxillary sinus wash for chronic rhinosinusitis in children. Laryngoscope.
5219 Ranuncolo SM, Wang L, Polo JM, et al. (2008). BCL6-mediated attenuation of DNA damage sensing triggers growth arrest and senescence through a p53-dependent pathway in a cell context-dependent manner. J Biol Chem.
5220 Rao PH, Roberts D, Zhao YJ, et al. (2008). Deletion of 1p32-p36 is the most frequent genetic change and poor prognostic marker in adenoid cystic carcinoma of the salivary glands. Clin Cancer Res.
5221 Rekabi H, Khosravi AD, Ahmadi K, et al. (2008). The microbiologic comparison of the surface and deep tissue tonsillar cultures in patients underwent tonsillectomy. Journal of Medical Sciences.
5222 Rio AC, Franchi-Teixeira AR, Nicola EM. (2008). Relationship between the presence of tonsilloliths and halitosis in patients with chronic caseous tonsillitis. Br Dent J.
5223 Risberg S, Engfeldt P, Hugosson S. (2008). Incidence of peritonsillar abscess and relationship to age and gender: retrospective study. Scand J Infect Dis.
5224 Roh JL, Choi SH, Lee SW, et al. (2008). Carcinomas arising in the submandibular gland: high propensity for systemic failure. J Surg Oncol.
5225 Rollin M, Majithia A, Stearns M. (2008). Parapharyngeal abscess in a previously tonsillectomised child with periodic fever, aphthous stomatitis, pharyngitis and adenitis syndrome: first reported case. J Laryngol Otol.
5226 Roshan A, Agarwal S, England RJ. (2008). Role of information available over the internet: what are the parents of children undergoing tonsillectomy likely to find?. Ann R Coll Surg Engl.
5227 Rosman S, Le Vaillant M, Schellevis F, et al. (2008). Prescribing patterns for upper respiratory tract infections in general practice in France and in the Netherlands. Eur J Public Health.
5228 Ross SK, Jaiswal V, Thomas S. (2008). Re: Yorick's skull model for tonsillectomy tie training. Clin Otolaryngol.
5229 Roth JA, Pincock T, Sacks R, et al. (2008). Harmonic scalpel tonsillectomy versus monopolar diathermy tonsillectomy: a prospective study. Ear Nose Throat J.
5230 Roy S, Vivero RJ, Smith LP. (2008). Adenotonsillar pathology in post-transplant patients. Int J Pediatr Otorhinolaryngol.
5231 Saigusa H, Suzuki M, Kodera K. (2008). Postoperative monitoring of esophageal pressure in patients with obstructive sleep apnea who had undergone tonsillectomy with uvulopalatopharyngoplasty [Abstract]. Sleep.
5232 Sakiyama H, Kobayashi S, Dianzani U, et al. (2008). Possible involvement of T cell co-stimulation in pustulosis palmaris et plantaris via the induction of inducible co-stimulator in chronic focal infections. J Dermatol Sci.
5233 Salami A, Jankowska B, Dellepiane M, et al. (2008). The impact of tonsillectomy with or without adenoidectomy on speech and voice. Int J Pediatr Otorhinolaryngol.
5234 Salvaggio I, Adducci E, Dell'Aquila L, et al. (2008). Facial pain: a possible therapy with stellate ganglion block. Pain medicine (Malden, Mass.).
5235 Sato T, Fujieda M, Tanaka E, et al. (2008). Monitoring of Epstein-Barr virus load and antibody in pediatric renal transplant patients. Pediatr Int.
5236 Scarborough D, Bailey-Van Kuren M, Hughes M. (2008). Altering the gag reflex via a palm pressure point. J Am Dent Assoc.
5237 Schneider AB, Ron E, Lubin J, et al. (2008). Acoustic neuromas following childhood radiation treatment for benign conditions of the head and neck. Neuro Oncol.
5238 Schwarz S, Ettl T, Kleinsasser N, et al. (2008). Loss of Maspin expression is a negative prognostic factor in common salivary gland tumors. Oral Oncol.
5239 Schwentner I, Schmutzhard J, Schwentner C, et al. (2008). The impact of adenotonsillectomy on children's quality of life. Clin Otolaryngol.
5240 Scinska A, Jodkowska A, Korkosz A, et al. (2008). Post-tonsillectomy dysgeusia with weight loss: possible involvement of soft palate. J Laryngol Otol.
5241 Sckolnick JS, Mantle B, Li J, et al. (2008). Pediatric myringoplasty: factors that affect success-a retrospective study. Laryngoscope.
5242 Segal N, Puterman M, Rotem E, et al. (2008). A prospective randomized double-blind trial of fibrin glue for reducing pain and bleeding after tonsillectomy. Int J Pediatr Otorhinolaryngol.
5243 Segerdahl M, Warren-Stomberg M, Rawal N, et al. (2008). Children in day surgery: clinical practice and routines. The results from a nation-wide survey. Acta Anaesthesiol Scand.
5244 Sekula RF, Kathpal M, Blumenkopf B, et al. (2008). Delayed cervical spinal cord tethering following tonsillar resection for Chiari malformation. Br J Neurosurg.
5245 Shah RK, Welborn L, Ashktorab S, et al. (2008). Safety and outcomes of outpatient pediatric otolaryngology procedures at an ambulatory surgery center. Laryngoscope.
5246 Shah UK. (2008). A simple suggestion to reduce perioral burns during adenotonsillectomy. Arch Otolaryngol Head Neck Surg.
5247 Shimozato S, Hiki Y, Odani H, et al. (2008). Serum under-galactosylated IgA1 is increased in Japanese patients with IgA nephropathy. Nephrol Dial Transplant.
5248 Shin KS, Cho SH, Kim KR, et al. (2008). The role of adenoids in pediatric rhinosinusitis. Int J Pediatr Otorhinolaryngol.
5249 Sidman JD, Lander TA, Finkelstein M. (2008). Platelet-rich plasma for pediatric tonsillectomy patients. Laryngoscope.
5250 Siedek V, Reichel O, Harreus U. (2008). Spontaneous intratonsillar haemorrhage with acute dysphagia. Eur Arch Otorhinolaryngol.
5251 Silva P, Slevin NJ, Sloan P, et al. (2008). Prognostic significance of tumor hypoxia inducible factor-1alpha expression for outcome after radiotherapy in oropharyngeal cancer. Int J Radiat Oncol Biol Phys.
5252 Simo R, O'Connell M. (2008). Metastatic squamous cell carcinoma of occult primary: beware the tonsillar remnant. J Laryngol Otol.
5253 Singh A, Stephens J, Ghufoor K, et al. (2008). A prospective study comparing PlasmaKnife with bipolar dissection tonsillectomy: a preliminary communication of an emerging technology. Clinical otolaryngology.
5254 Skoulakis C, Tigiroglou E, Gkarelis K, et al. (2008). Level of Streptococcus pyogenes in patients with recurrent tonsillitis and tonsillar hypertrophy. Scand J Infect Dis.
5255 Son JY, Kim BY, Lee TH, et al. (2008). Ischemic brain damage induced after adenotonsillectomy in achondroplasia. Otolaryngol Head Neck Surg.
5256 Spalding SJ, Hashkes PJ. (2008). The role of tonsillectomy in management of periodic fever, aphthous stomatitis, pharyngitis, and adenopathy: Unanswered questions. J Pediatr.
5257 Spielmann PM, McKee H, Adamson RM, et al. (2008). Follow up after middle-ear ventilation tube insertion: what is needed and when?. J Laryngol Otol.
5258 Stankovic M, Vlahovic P, Avramovic V, et al. (2008). Distribution of dipeptidyl peptidase IV in patients with chronic tonsillitis. Clin Vaccine Immunol.
5259 Stapleton A, Brodsky L. (2008). Extra-esophageal acid reflux induced adenotonsillar hyperplasia: case report and literature review. Int J Pediatr Otorhinolaryngol.
5260 Stephens JC, Georgalas C, Kyi M, et al. (2008). Is bacterial colonisation of the tonsillar fossa a factor in post-tonsillectomy haemorrhage?. J Laryngol Otol.
5261 Stewart MG. (2008). Outcomes assessment in tonsil and adenoid disease. Otolaryngol Head Neck Surg.
5262 Stringer MD, Horwood LJ. (2008). Lack of association between tonsillectomy and subsequent appendicectomy. J Pediatr Surg.
5263 Stuck BA, Gotte K, Windfuhr JP, et al. (2008). Tonsillectomy in children. Dtsch Arztebl Int.
5264 Suehara AB, Goncalves AJ, Alcadipani FA, et al. (2008). Deep neck infection: analysis of 80 cases. Braz J Otorhinolaryngol.
5265 Sullivan S, Li K, Guilleminault C. (2008). Nasal obstruction in children with sleep-disordered breathing. Ann Acad Med Singapore.
5266 Suvilehto J, Jarva H, Seppanen M, et al. (2008). Binding of complement regulators factor H and C4b binding protein to group A streptococcal strains isolated from tonsillar tissue and blood. Microbes Infect.
5267 Suzuki M, Saigusa H, Kurogi R, et al. (2008). Postoperative monitoring of esophageal pressure in patients with obstructive sleep apnea-hypopnea syndrome who have undergone tonsillectomy with uvulopalatopharyngoplasty. Annals of otology, rhinology, and laryngology.
5268 Tait AR, Voepel-Lewis T, Burke C, et al. (2008). Incidence and risk factors for perioperative adverse respiratory events in children who are obese. Anesthesiology.
5269 Talebian A, Tazhibi M, Iranpoor R, et al. (2008). Relationship between tonsil odor and oral malodor: a clinical study on 48 Iranian patients. J Breath Res.
5270 Talmon Y, Gilbey P, Fridman N, et al. (2008). Acute myopericarditis complicating acute tonsillitis: beware the young male patient with tonsillitis complaining of chest pain. Ann Otol Rhinol Laryngol.
5271 Tang JP. (2008). Obesity and obstructive sleep apnoea hypopnoea syndrome in Singapore children. Ann Acad Med Singapore.
5272 Taricco MA, Melo LR. (2008). Retrospective study of patients with Chiari: malformation submitted to surgical treatment. Arq Neuropsiquiatr.
5273 Tekin D, Suskan E, Pekpak E. (2008). Re: Resolution of diurnal incontinence and nocturnal enuresis after adenotonsillectomy in children. F. Firoozi, R. Batniji, A. R. Aslan, P. A. Longhurst and B. A. Kogan. J Urol 2006; 175: 1885-1888. J Urol.
5274 Thakur JS, Minhas RS, Thakur A, et al. (2008). Giant tonsillolith causing odynophagia in a child: a rare case report. Cases J.
5275 Thong JF, Pang KP. (2008). Clinical parameters in obstructive sleep apnea: are there any correlations?. J Otolaryngol Head Neck Surg.
5276 Ting JY, Miyamoto RC. (2008). Lingual tonsillitis presenting as hemoptysis. International Journal of Pediatric Otorhinolaryngology Extra.
5277 Trigylidas T, Baronia B, Vassilyadi M, et al. (2008). Posterior fossa dimension and volume estimates in pediatric patients with Chiari I malformations. Childs Nerv Syst.
5278 Tsalkidis A, Gardikis S, Cassimos D, et al. (2008). Acute abdomen in children due to extra-abdominal causes. Pediatr Int.
5279 Tucker Woodson B. (2008). Structural effectiveness of pharyngeal sleep apnea surgery. Sleep Med Rev.
5280 Tunkel DE, Hotchkiss KS, Carson KA, et al. (2008). Efficacy of powered intracapsular tonsillectomy and adenoidectomy. Laryngoscope.
5281 Ugras S, Kutluhan A. (2008). Chronic tonsillitis can be diagnosed with histopathologic findings. European Journal of General Medicine.
5282 Ugur MB, Dogan SM, Sogut A, et al. (2008). Effect of adenoidectomy and/or tonsillectomy on cardiac functions in children with obstructive sleep apnea. ORL J Otorhinolaryngol Relat Spec.
5283 Ugur MB, Yilmaz M, Altunkaya H, et al. (2008). Effects of intramuscular and peritonsillar injection of tramadol before tonsillectomy: a double blind, randomized, placebo-controlled clinical trial. Int J Pediatr Otorhinolaryngol.
5284 Ullah N, Khan Q, Said M, et al. (2008). Tympanoplasty in young patients. Journal of Postgraduate Medical Institute.
5285 Vallee E, Lafrenaye S, Tetrault JP, et al. (2008). Pain management after tonsillectomy: morphine is not enough. J Otolaryngol Head Neck Surg.
5286 van Cruijsen N, Gravendeel J, Dikkers FG. (2008). Severe delayed posttonsillectomy haemorrhage due to a pseudoaneurysm of the lingual artery. Eur Arch Otorhinolaryngol.
5287 van den Broek AM, Feenstra L, de Baat C. (2008). A review of the current literature on management of halitosis. Oral Dis.
5288 Van Lierde KM, Bonte K, Baudonck N, et al. (2008). Speech outcome regarding overall intelligibility, articulation, resonance and voice in Flemish children a year after pharyngeal flap surgery. A pilot study. Folia Phoniatr Logop.
5289 Vargas PA, Cheng Y, Barrett AW, et al. (2008). Expression of Mcm-2, Ki-67 and geminin in benign and malignant salivary gland tumours. J Oral Pathol Med.
5290 Vargas PA, Speight PM, Bingle CD, et al. (2008). Expression of PLUNC family members in benign and malignant salivary gland tumours. Oral Dis.
5291 Vayisoglu Y, Ozcan C, Polat A, et al. (2008). Does Helicobacter pylori play a role in the development of chronic adenotonsillitis?. Int J Pediatr Otorhinolaryngol.
5292 Verhulst SL, De Backer J, Van Gaal L, et al. (2008). Adenotonsillectomy as first-line treatment for sleep-disordered breathing in obese children. Am J Respir Crit Care Med.
5293 Vestergaard H, Westergaard T, Wohlfahrt J, et al. (2008). Association between intussusception and tonsil disease in childhood. Epidemiology.
5294 Vicente JL, Torres-Rodriguez A, Higgins SE, et al. (2008). Effect of a selected Lactobacillus spp.-based probiotic on Salmonella enterica serovar enteritidis-infected broiler chicks. Avian Dis.
5295 Vind I, Riis L, Jespersgaard C, et al. (2008). Genetic and environmental factors as predictors of disease severity and extent at time of diagnosis in an inception cohort of inflammatory bowel disease, Copenhagen County and City 2003-2005. J Crohns Colitis.
5296 Walker P, Whitehead B, Gulliver T. (2008). Polysomnographic outcome of adenotonsillectomy for obstructive sleep apnea in children under 5 years old. Otolaryngol Head Neck Surg.
5297 Wan MJ, Nomura H, Tator CH. (2008). Conversion to symptomatic Chiari I malformation after minor head or neck trauma. Neurosurgery.
5298 Wen YH, Yang RH, Chen PR, et al. (2008). Hepatocellular carcinoma metastatic to the palatine tonsil. Tzu Chi Medical Journal.
5299 Willmott NS, Bryan RA, Duggal MS. (2008). Molar-incisor-hypomineralisation: a literature review. Eur Arch Paediatr Dent.
5300 Windfuhr JP, Schloendorff G, Baburi D, et al. (2008). Lethal outcome of post-tonsillectomy hemorrhage. Eur Arch Otorhinolaryngol.
5301 Windfuhr JP, Schloendorff G, Baburi D, et al. (2008). Life-threatening posttonsillectomy hemorrhage. Laryngoscope.
5302 Windfuhr JP, Schloendorff G, Baburi D, et al. (2008). Serious post-tonsillectomy hemorrhage with and without lethal outcome in children and adolescents. Int J Pediatr Otorhinolaryngol.
5303 Witsell DL, Orvidas LJ, Stewart MG, et al. (2008). Quality of life after tonsillectomy in adults with recurrent or chronic tonsillitis. Otolaryngol Head Neck Surg.
5304 Wong KK, Finlay JC, Moxham JP. (2008). Role of Tonsillectomy in PFAPA Syndrome. Arch Otolaryngol Head Neck Surg.
5305 Woods AI, Blanco AN, Chuit R, et al. (2008). Major haemorrhage related to surgery in patients with type 1 and possible type 1 von Willebrand disease. Thromb Haemost.
5306 Xu Z, Jiaqing A, Yuchuan L, et al. (2008). A case-control study of obstructive sleep apnea-hypopnea syndrome in obese and nonobese chinese children. Chest.
5307 Yildirim I, Ceyhan M, Gur D, et al. (2008). Comparison of the effect of benzathine penicillin G, clarithromycin, cefprozil and amoxicillin/clavulanate on the bacteriological response and throat flora in group A beta hemolytic streptococcal tonsillopharyngitis. Turk J Pediatr.
5308 Yildirim N, Sahan M, Karslioglu Y. (2008). Adenoid hypertrophy in adults: clinical and morphological characteristics. J Int Med Res.
5309 Yilmaz I, Caylakli F, Yilmazer C, et al. (2008). Correlation of diagnostic systems with adenoidal tissue volume: a blind prospective study. Int J Pediatr Otorhinolaryngol.
5310 Yoruk O, Ates O, Araz O, et al. (2008). The effects of silica exposure on upper airways and eyes in denim sandblasters. Rhinology.
5311 Ysunza A, Pamplona MC, Ortega JM, et al. (2008). Video fluoroscopy for evaluating adenoid hypertrophy in children. Int J Pediatr Otorhinolaryngol.
5312 Yum JH, Park YS, Jeon EJ, et al. (2008). Factors affecting the persistence of tympanic membrane perforation developed with the extubation of ventilation tube. Int J Pediatr Otorhinolaryngol.
5313 Zahra FA, Abudallah HM, Shabana RI, et al. (2008). Intramuscular ketamine for prevention of postanesthesia shivering in children. Saudi Med J.
5314 Zhengjaiang L, Pingzhang T, Dechao Z, et al. (2008). Primary tracheal tumours: 21 years of experience at Peking Union Medical College, Beijing, China. J Laryngol Otol.
5315 Zingade ND, Zingade NN. (2008). A rare case of Proteus syndrome. J Laryngol Otol.
5316 (2009). Mecasermin: new drug. Insufficient improvement in statural growth. Prescrire Int.
5317 (2009). Dexmedetomidine for immediate perioperative analgesia in pediatric patients undergoing tonsillectomy [completed]. ClinicalTrials.gov.
5318 Abad VC, Guilleminault C. (2009). Treatment options for obstructive sleep apnea. Curr Treat Options Neurol.
5319 Abd El-Moneim ES, Badawy BS, Atya M. (2009). The effect of adenoidectomy on right ventricular performance in children. Int J Pediatr Otorhinolaryngol.
5320 Abdel-Aziz M, Dewidar H, El-Hoshy H, et al. (2009). Treatment of persistent post-adenoidectomy velopharyngeal insufficiency by sphincter pharyngoplasty. Int J Pediatr Otorhinolaryngol.
5321 Abou-Bieh A. (2009). Dexamethasone effect on post-tonsillectomy recovery period. 113th American Academy of Otolaryngology - Head & Neck Surgery Annual Meeting & Oto Expo, 2009. Otolaryngology - Head and Neck Surgery.
5322 Aboudara C, Nielsen I, Huang JC, et al. (2009). Comparison of airway space with conventional lateral headfilms and 3-dimensional reconstruction from cone-beam computed tomography. Am J Orthod Dentofacial Orthop.
5323 Acar B, Babademez MA, Karabulut H, et al. (2009). Otorhinolaryngologic examination in obstructive sleep apnea syndrome: the correlation between the severity of sleep disorder and physical examination. Kulak Burun Bogaz Ihtis Derg.
5324 Adams MT, Wilhelm MJ, Demars SM, et al. (2009). Effects of synchronous nasal surgery on posttonsillectomy hemorrhage. Arch Otolaryngol Head Neck Surg.
5325 Afolabi OA, Alabi BS, Ologe FE, et al. (2009). Parental satisfaction with post-adenotonsillectomy in the developing world. Int J Pediatr Otorhinolaryngol.
5326 Ahmad SM, Esmaeli B, Williams M, et al. (2009). American Joint Committee on Cancer classification predicts outcome of patients with lacrimal gland adenoid cystic carcinoma. Ophthalmology.
5327 Ahn Y, Chang H, Lim YS, et al. (2009). Primary tracheal tumors: review of 37 cases. J Thorac Oncol.
5328 Akgun D, Seymour FK, Qayyum A, et al. (2009). Assessment of clinical improvement and quality of life before and after tonsillectomy. J Laryngol Otol.
5329 Akkaya T, Bedirli N, Ceylan T, et al. (2009). Comparison of intravenous and peritonsillar infiltration of tramadol for postoperative pain relief in children following adenotonsillectomy. Eur J Anaesthesiol.
5330 Akpinar ME, Kocak I, Gurpinar B, et al. (2009). Henoch-Schonlein purpura after adenotonsillectomy. Otolaryngol Head Neck Surg.
5331 Al-Abbasi AM. (2009). Tonsillectomy for the treatment of halitosis. Niger J Med.
5332 Al-Bassiouny AMM. (2009). Harmonic Scalpel Tonsillectomy Versus Bipolar Electrocautery and Cold Dissection. Medical journal of Cairo University.
5333 Al-khotum N, Hiari MD, Al-Junndi A, Al-Roosan M, Al-Qudah A, Shawakfeh N. (2009). Comparitive study of orogastric suction and dexamethasone to reduce vomiting after pediatric tonsillectomy. J Res Med Sci.
5334 Al-Layla AM, Al-Barzangi B, Badran I. (2009). Surgical emphysema after tonsillectomy in Jordan university hospital. Jordan Medical Journal.
5335 Allford M, Guruswamy V. (2009). A national survey of the anesthetic management of tonsillectomy surgery in children. Paediatr Anaesth.
5336 Almac A, Elicora SS, Yumuk Z, et al. (2009). The relationship between chronic otitis media with effusion and surface and deep flora of hypertrophic adenoids. Int J Pediatr Otorhinolaryngol.
5337 Al-Mazrou KA, Al-Qahtani A, Al-Fayez AI. (2009). Effectiveness of transnasal endoscopic powered adenoidectomy in patients with choanal adenoids. Int J Pediatr Otorhinolaryngol.
5338 Al-Mazrou KA, Makki FM, Allam OS, et al. (2009). Surgical emergencies in pediatric otolaryngology. Saudi Med J.
5339 Al-reefy H, Fleming J, Mitchell D. (2009). Re: Tonsillectomy and adenoidectomy in children with sleep-related breathing disorders: consensus statement of a UK multidisciplinary working party. Clin Otolaryngol.
5340 Amonoo-Kuofi K, Phillips SP, Randhawa PS, et al. (2009). Adenotonsillectomy for sleep-disordered breathing in children with syndromic craniosynostosis. J Craniofac Surg.
5341 Anand TS, Tatavarthy S, Kumar S. (2009). Radiology Quiz Case 2. Giant tonsillolith. Arch Otolaryngol Head Neck Surg.
5342 Ando E, Ogawa T, Shigeta Y, et al. (2009). A case of obstructive sleep apnoea with anterior cervical osteophytes. J Oral Rehabil.
5343 Andreu-Ballester JC, Ballester F, Perez-Griera J, et al. (2009). Differential effect of appendectomy and tonsillectomy on anti-Kudoa sp. antibodies in patients with MALTectomy. Parasitol Int.
5344 Annam V, Kulkarni MH, Puranik RB. (2009). Clinicopathologic profile of significant cervical lymphadenopathy in children aged 1-12 years. Acta Cytol.
5345 Aquilina K, Merchant TE, Boop FA, et al. (2009). Chiari I malformation after cranial radiation therapy in childhood: a dynamic process associated with changes in clival growth. Childs Nerv Syst.
5346 Arn P, Wraith JE, Underhill L. (2009). Characterization of surgical procedures in patients with mucopolysaccharidosis type I: findings from the MPS I Registry. J Pediatr.
5347 Arora S, Sharma JK, Pippal SK, et al. (2009). An unusual foreign body (sewing needle tip) in the tonsils. Braz J Otorhinolaryngol.
5348 Astrauskiene D, Bernotiene E, Bytautiene J, et al. (2009). Recurrent tonsillitis and tonsillectomy in juvenile idiopathic arthritis. Scand J Rheumatol.
5349 Astuto M, Arena G, Ferla L, et al. (2009). Perioperative recommendations in a child with Fish Odor syndrome. Paediatr Anaesth.
5350 Attner P, Haraldsson PO, Hemlin C, et al. (2009). A 4-year consecutive study of post-tonsillectomy haemorrhage. ORL J Otorhinolaryngol Relat Spec.
5351 August DA, Ramos DC. (2009). Anesthesia for a child with Hajdu-Cheney syndrome. Paediatr Anaesth.
5352 Awad Z, Salter V, Hunt D, et al. (2009). Audit of specifically designed adenotonsillectomy operation sheet: how we do it. Clin Otolaryngol.
5353 Ayala M, Bruggers D, Yarbrough J, et al. (2009). The postoperative use of amoxicillin in adult tonsillectomy patients. Laryngoscope.
5354 Aycicek A, Dilek H, Sargin R, et al. (2009). Heat shock protein 70 and inducible nitric oxide synthase expression in adenoid tissue of children exposed to passive smoke. Turkiye Klinikleri Journal of Medical Sciences.
5355 Back L, Tervahartiala P, Piilonen A, et al. (2009). Assessment of submucosal radiofrequency tonsil reduction by magnetic resonance imaging. J Otolaryngol Head Neck Surg.
5356 Bakhamees HS, Mercan A, El-Halafawy YM. (2009). Combination effect of low dose fentanyl and propofol on emergence agitation in children following sevoflurane anesthesia. Saudi Med J.
5357 Balbani AP, Montovani JC, Carvalho LR. (2009). Pharyngotonsillitis in children: view from a sample of pediatricians and otorhinolaryngologists. Braz J Otorhinolaryngol.
5358 Barone JG, Hanson C, DaJusta DG, et al. (2009). Nocturnal enuresis and overweight are associated with obstructive sleep apnea. Pediatrics.
5359 Beraldin BS, Rayes TR, Villela PH, et al. (2009). Assessing the impact adenotonsilectomy has on the lives of children with hypertrophy of palatine and pharyngeal tonsils. Braz J Otorhinolaryngol.
5360 Bettelli G. (2009). High risk patients in day surgery. Minerva Anestesiol.
5361 Bhattacharjee R, Dayyat E, Kheirandish-Gozal L, et al. (2009). Nocturnal polysomnographic characteristics of habitually snoring children initially referred to pediatric ENT or sleep clinics. Sleep Med.
5362 Biermans MC, Theuns-Lamers EH, Spreeuwenberg P, et al. (2009). Decreasing incidence of adenotonsillar problems in Dutch general practice: real or artefact?. Br J Gen Pract.
5363 Bist SS, Varshney S, Kumar R, et al. (2009). Fistulography: a useful imaging modality for identifying the exact location and extent of complete branchial fistulas. Ear Nose Throat J.
5364 Bitar MA, Birjawi G, Youssef M, et al. (2009). How frequent is adenoid obstruction? Impact on the diagnostic approach. Pediatr Int.
5365 Bixler EO, Vgontzas AN, Calhoun S. (2009). The Penn State Child Cohort: Diagnostic Criteria and Possible Etiologic Factors of Sleep Apnea Based on Objective Clinical Outcomes. Sleep Medicine Clinics.
5366 Bixler EO, Vgontzas AN, Lin HM, et al. (2009). Sleep disordered breathing in children in a general population sample: prevalence and risk factors. Sleep.
5367 Blakley BW. (2009). Post-tonsillectomy bleeding: how much is too much?. Otolaryngol Head Neck Surg.
5368 Bonaparte JP, Trites J, Hart R, et al. (2009). Survival when treating adenoid cystic carcinoma of the external auditory canal: quantitative assessment of case reports. J Otolaryngol Head Neck Surg.
5369 Bonuck KA, Freeman K, Henderson J. (2009). Growth and growth biomarker changes after adenotonsillectomy: systematic review and meta-analysis. Arch Dis Child.
5370 Brar MS. (2009). Airway management in a bleeding adult following tonsillectomy: a case report. Aana j.
5371 Brasky TM, Bonner MR, Dorn J, et al. (2009). Tonsillectomy and breast cancer risk in the Western New York Diet Study. Cancer Causes Control.
5372 Brook I. (2009). Current management of upper respiratory tract and head and neck infections. Eur Arch Otorhinolaryngol.
5373 Brook I. (2009). Anaerobic bacteria in upper respiratory tract and head and neck infections in children: Microbiology and management. Journal of Pediatric Infectious Diseases.
5374 Brook I, Gober AE. (2009). Rate of eradication of group A beta-hemolytic streptococci in children with pharyngo-tonsillitis by amoxicillin and cefdinir. Int J Pediatr Otorhinolaryngol.
5375 Burton MJ, Glasziou PP. (2009). Tonsillectomy or adeno-tonsillectomy versus non-surgical treatment for chronic/recurrent acute tonsillitis. Cochrane Database Syst Rev.
5376 Burton MJ, Isaacson G, Rosenfeld RM. (2009). Extracts from The Cochrane Library: Tonsillectomy for chronic/recurrent acute tonsillitis. Otolaryngol Head Neck Surg.
5377 Caldarelli M, Novegno F, Di Rocco C. (2009). A late complication of CSF shunting: acquired Chiari I malformation. Childs Nerv Syst.
5378 Canapari C. (2009). Obstructive sleep apnea in children. Journal of Clinical Outcomes Management.
5379 Capua M, Ahmadi N, Shapiro C. (2009). Overview of obstructive sleep apnea in children: exploring the role of dentists in diagnosis and treatment. J Can Dent Assoc.
5380 Cardoso SV, Souza KC, Faria PR, et al. (2009). Assessment of angiogenesis by CD105 antigen in epithelial salivary gland neoplasms with diverse metastatic behavior. BMC Cancer.
5381 Casselbrant ML, Mandel EM, Rockette HE, et al. (2009). Adenoidectomy for otitis media with effusion in 2-3-year-old children. Int J Pediatr Otorhinolaryngol.
5382 Caylakli F, Hizal E, Yilmaz I, et al. (2009). Correlation between adenoid-nasopharynx ratio and endoscopic examination of adenoid hypertrophy: a blind, prospective clinical study. Int J Pediatr Otorhinolaryngol.
5383 Cederblad L, Johansson S, Enblad G, et al. (2009). Cancer of the parotid gland; long-term follow-up. A single centre experience on recurrence and survival. Acta Oncol.
5384 Chan JY, Li AM, Au CT, et al. (2009). Cardiac remodelling and dysfunction in children with obstructive sleep apnoea: a community based study. Thorax.
5385 Charlett SD, Knight LC. (2009). Pediatric myringoplasty: does previous adenoidectomy improve the likelihood of perforation closure?. Otol Neurotol.
5386 Chen SY, Cheng PW. (2009). Re: Life-threatening posttonsillectomy hemorrhage. Laryngoscope.
5387 Chervin RD, Fetterolf JL, Ruzicka DL, et al. (2009). Sleep stage dynamics differ between children with and without obstructive sleep apnea. Sleep.
5388 Chiari S, Romsdorfer P, Swoboda H, et al. (2009). Effects of rapid maxillary expansion on the airways and ears--a pilot study. Eur J Orthod.
5389 Chiu LL, Sie KCY. (2009). Sphincter pharyngoplasty for management of velopharyngeal insufficiency. Operative Techniques in Otolaryngology - Head and Neck Surgery.
5390 Choby BA. (2009). Diagnosis and treatment of streptococcal pharyngitis. Am Fam Physician.
5391 Choi JH, Kim EJ, Choi J, et al. (2009). The effect of adenotonsillectomy on changes of position during sleep in pediatric obstructive sleep apnea syndrome. Am J Rhinol Allergy.
5392 Chung YL, Lee MY, Horng CF, et al. (2009). Use of combined molecular biomarkers for prediction of clinical outcomes in locally advanced tonsillar cancers treated with chemoradiotherapy alone. Head Neck.
5393 Cianchetti M, Mancuso AA, Amdur RJ, et al. (2009). Diagnostic evaluation of squamous cell carcinoma metastatic to cervical lymph nodes from an unknown head and neck primary site. Laryngoscope.
5394 Cicin I, Usta U, Sezer A, et al. (2009). Synchronous tonsil, gallbladder, and cardiac metastases without any other visceral metastases of malignant melanoma. Onkologie.
5395 Ciszkowski C, Madadi P, Phillips MS, et al. (2009). Codeine, ultrarapid-metabolism genotype, and postoperative death. N Engl J Med.
5396 Clewley JP, Kelly CM, Andrews N, et al. (2009). Prevalence of disease related prion protein in anonymous tonsil specimens in Britain: cross sectional opportunistic survey. Bmj.
5397 Clifton NJ, Raghavan U, Birkin J, et al. (2009). Prescribing antibiotics for sore throat: adherence to guidelines in patients admitted to hospital. Postgrad Med J.
5398 Conley SF, Beecher RB, Delaney AL, et al. (2009). Outcomes of tonsillectomy in neurologically impaired children. Laryngoscope.
5399 Corcione A, Ferretti E, Bertolotto M, et al. (2009). CX3CR1 is expressed by human B lymphocytes and mediates [corrected] CX3CL1 driven chemotaxis of tonsil centrocytes. PLoS One.
5400 Cosmi B, Alatri A, Cattaneo M, et al. (2009). Assessment of the risk of bleeding in patients undergoing surgery or invasive procedures: Guidelines of the Italian Society for Haemostasis and Thrombosis (SISET). Thromb Res.
5401 Costa DJ, Mitchell R. (2009). Adenotonsillectomy for obstructive sleep apnea in obese children: a meta-analysis. Otolaryngol Head Neck Surg.
5402 Crandall M, Lammers C, Senders C, et al. (2009). Children's tonsillectomy experiences: influencing factors. J Child Health Care.
5403 Culpepper L, Roth T. (2009). Recognizing and managing obstructive sleep apnea in primary care. Primary Care Companion to the Journal of Clinical Psychiatry.
5404 Cushing SL, Smith O, Chiodo A, et al. (2009). Evaluating postoperative pain in monopolar cautery versus harmonic scalpel tonsillectomy. Otolaryngol Head Neck Surg.
5405 Cvetkovic T, Vlahovic P, Todorovic M, et al. (2009). Investigation of oxidative stress in patients with chronic tonsillitis. Auris Nasus Larynx.
5406 Dalati T, Hussein MR. (2009). Juvenile pleomorphic adenoma of the cheek: a case report and review of literature. Diagn Pathol.
5407 Daneshbod Y, Daneshbod K, Khademi B. (2009). Diagnostic difficulties in the interpretation of fine needle aspirate samples in salivary lesions: diagnostic pitfalls revisited. Acta Cytol.
5408 Das UM, Beena JP. (2009). Effectiveness of circumoral muscle exercises in the developing dentofacial morphology in adenotonsillectomized children: an ultrasonographic evaluation. J Indian Soc Pedod Prev Dent.
5409 Dashti GA, Amini S, Zanguee E. (2009). The prophylactic effect of rectal acetaminophen on postoperative pain and opioid requirements after adenotonsillectomy in children. Middle East J Anaesthesiol.
5410 Datta R, Singh VP, Deshpal. (2009). Conventional versus endoscopic powered adenoidectomy: A comparative study. Medical Journal Armed Forces India.
5411 Dayyat E, Kheirandish-Gozal L, Sans Capdevila O, et al. (2009). Obstructive sleep apnea in children: relative contributions of body mass index and adenotonsillar hypertrophy. Chest.
5412 Dayyat E, Serpero LD, Kheirandish-Gozal L, et al. (2009). Leukotriene pathways and in vitro adenotonsillar cell proliferation in children with obstructive sleep apnea. Chest.
5413 De Stefano A, Baffa C, Cerrone D, et al. (2009). Management of recurrent otitis media with rapid maxillary expansion: our experience. B-ENT.
5414 Dehdashti AR, Ganna A, Witterick I, et al. (2009). Expanded endoscopic endonasal approach for anterior cranial base and suprasellar lesions: indications and limitations. Neurosurgery.
5415 den Engelsen C, van der Werf C, Matute AJ, et al. (2009). Infectious diseases and the use of antibiotics in outpatients at the emergency department of the University Hospital of Leon, Nicaragua. Int J Infect Dis.
5416 Dias EP, Rocha ML, Carvalho MO, et al. (2009). Braz J Otorhinolaryngol.
5417 Don DM, Geller KA, Koempel JA, et al. (2009). Age specific differences in pediatric obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
5418 Doobaree IU, Landis SH, Linklater KM, et al. (2009). Head and neck cancer in South East England between 1995-1999 and 2000-2004: An estimation of incidence and distribution by site, stage and histological type. Oral Oncol.
5419 Doshi J, Henney S, Arullendran P. (2009). Introduction of adult day case tonsillectomy to an ENT unit; a completed audit cycle. Otorhinolaryngologist.
5420 Dunmade AD, Alabi BS. (2009). Day case adenoidectomy: is it safe?. Niger J Clin Pract.
5421 Ehlers Klug T, Rusan M, Fuursted K, et al. (2009). Fusobacterium necrophorum: most prevalent pathogen in peritonsillar abscess in Denmark. Clin Infect Dis.
5422 Eipe N, Lai L, Doherty DR. (2009). Severe pulmonary hypertension and adenotonsillectomy in a child with Trisomy-21 and obstructive sleep apnea. Paediatr Anaesth.
5423 El-Badrawy A, Abdel-Aziz M. (2009). Transoral endoscopic adenoidectomy. Int J Otolaryngol.
5424 Erdil F, Demirbilek S, Begec Z, et al. (2009). The effects of dexmedetomidine and fentanyl on emergence characteristics after adenoidectomy in children. Anaesth Intensive Care.
5425 Erduran E, Aksoy A, Zaman D. (2009). The use of recombinant FVIIa in a patient with Glanzmann thrombasthenia with uncontrolled bleeding after tonsillectomy. Blood Coagul Fibrinolysis.
5426 Erickson BK, Larson DR, St Sauver JL, et al. (2009). Changes in incidence and indications of tonsillectomy and adenotonsillectomy, 1970-2005. Otolaryngol Head Neck Surg.
5427 Espinosa E, Velazquez-Villasenor L, Soda-Merhy A, et al. (2009). Endoscopic assessment of adenoid size is an indicator of tissue virologic response to highly active antiretroviral therapy. J Otolaryngol Head Neck Surg.
5428 Esposito S, Marchisio P, Capaccio P, et al. (2009). Risk factors for bacteremia during and after adenoidectomy and/or adenotonsillectomy. J Infect.
5429 Ethunandan M, Davies B, Pratt CA, et al. (2009). Primary epithelial submandibular salivary gland tumours--review of management in a district general hospital setting. Oral Oncol.
5430 Eun YG, Park DC, Kim SG, et al. (2009). Immunoglobulins and transcription factors in adenoids of children with otitis media with effusion and chronic rhinosinusitis. Int J Pediatr Otorhinolaryngol.
5431 Evans RG. (2009). There's no reason for it, it's just our policy. Healthcare Policy.
5432 Eviatar E, Kessler A, Shlamkovitch N, et al. (2009). Tonsillectomy vs. partial tonsillectomy for OSAS in children--10 years post-surgery follow-up. Int J Pediatr Otorhinolaryngol.
5433 Eyigor M, Eyigor H, Gultekin B, et al. (2009). Detection of Helicobacter pylori in adenotonsiller tissue specimens by rapid urease test and polymerase chain reaction. Eur Arch Otorhinolaryngol.
5434 Fancy T, Mathers PH, Ramadan HH. (2009). Otitis media with effusion: a possible role for Helicobacter pylori?. Otolaryngol Head Neck Surg.
5435 Faramarzi A, Ashraf MJ, Hashemi B, et al. (2009). Histopathological screening of tonsillectomy and/or adenoidectomy specimens: a report from southern Iran. Int J Pediatr Otorhinolaryngol.
5436 Favaro S, Hilliard T, Henderson J. (2009). Obstructive sleep apnoea in children. Paediatrics and Child Health.
5437 Fedeli U, Marchesan M, Avossa F, et al. (2009). Variability of adenoidectomy/tonsillectomy rates among children of the Veneto Region, Italy. BMC Health Serv Res.
5438 Fernandez MC, Bes D, De Davila M, et al. (2009). Post-transplant lymphoproliferative disorder after pediatric liver transplantation: characteristics and outcome. Pediatr Transplant.
5439 Figueroa RA, Lozano LE, Romero IC, et al. (2009). Detection of Leishmania in unaffected mucosal tissues of patients with cutaneous leishmaniasis caused by Leishmania (Viannia) species. J Infect Dis.
5440 Fortier MA, MacLaren JE, Martin SR, et al. (2009). Pediatric pain after ambulatory surgery: where's the medication?. Pediatrics.
5441 Fox HR. (2009). Out-of-hours ENT guidelines. Clin Otolaryngol.
5442 Fretzayas A, Moustaki M, Kitsiou S, et al. (2009). The clinical pattern of group C streptococcal pharyngitis in children. J Infect Chemother.
5443 Friberg D, Sundquist J, Li X, et al. (2009). Sibling risk of pediatric obstructive sleep apnea syndrome and adenotonsillar hypertrophy. Sleep.
5444 Friedman M, Wilson M, Lin HC, et al. (2009). Updated systematic review of tonsillectomy and adenoidectomy for treatment of pediatric obstructive sleep apnea/hypopnea syndrome. Otolaryngol Head Neck Surg.
5445 Friedman M, Wilson MN, Friedman J, et al. (2009). Intracapsular coblation tonsillectomy and adenoidectomy for the treatment of pediatric obstructive sleep apnea/hypopnea syndrome. Otolaryngol Head Neck Surg.
5446 Fujii Y. (2009). Current management of vomiting after tonsillectomy in children. Curr Drug Saf.
5447 Gallina S, Dispenza F, Kulamarva G, et al. (2009). Uvulopalatopharyngoplasty with tonsillectomy in the treatment of severe OSAS. B-ENT.
5448 Gan K, Tomlinson C, El-Hakim H. (2009). Post-operative bleeding is less after partial intracapsular tonsillectomy than bipolar total procedure. Int J Pediatr Otorhinolaryngol.
5449 Garavello W, Romagnoli M, Gaini RM. (2009). Effectiveness of adenotonsillectomy in PFAPA syndrome: a randomized study. J Pediatr.
5450 Gemma M, Piccioni LO, Gioia L, et al. (2009). Ropivacaine peritonsillar infiltration for analgesia after adenotonsillectomy in children: a randomized, double-blind, placebo-controlled study. Ann Otol Rhinol Laryngol.
5451 Gerber MA, Baltimore RS, Eaton CB, et al. (2009). Prevention of rheumatic fever and diagnosis and treatment of acute Streptococcal pharyngitis: a scientific statement from the American Heart Association Rheumatic Fever, Endocarditis, and Kawasaki Disease Committee of the Council on Cardiovascular Disease in the Young, the Interdisciplinary Council on Functional Genomics and Translational Biology, and the Interdisciplinary Council on Quality of Care and Outcomes Research: endorsed by the American Academy of Pediatrics. Circulation.
5452 Gil Z, Carlson DL, Gupta A, et al. (2009). Patterns and incidence of neural invasion in patients with cancers of the paranasal sinuses. Arch Otolaryngol Head Neck Surg.
5453 Giles JE, Worley NK, Telusca N. (2009). Gold laser tonsillectomy--a safe new method. Int J Pediatr Otorhinolaryngol.
5454 Gjoni D, Mbamalu D, Banerjee A, et al. (2009). An unusual complication of an attempt to open the airway in a choking child. Br J Hosp Med (Lond).
5455 Goodman DC. (2009). Unwarranted variation in pediatric medical care. Pediatr Clin North Am.
5456 Gradoni G, Gradoni P. (2009). Role of an anti-acetonemic diet in reducing the need for tonsillectomy in children with recurrent tonsillitis. Auris Nasus Larynx.
5457 Grant WB. (2009). Tonsillectomy may be an indicator of low vitamin D status, a risk factor for cancer later in life. Cancer Causes Control.
5458 Grasso DL, Segat L, Zocconi E, et al. (2009). MBL expression in patients with recurrent tonsillitis. Int J Pediatr Otorhinolaryngol.
5459 Gravningsbraten R, Nicklasson B, Raeder J. (2009). Safety of laryngeal mask airway and short-stay practice in office-based adenotonsillectomy. Acta Anaesthesiol Scand.
5460 Grisel J, Arjmand E. (2009). Comparing quality at an ambulatory surgery center and a hospital-based facility: preliminary findings. Otolaryngol Head Neck Surg.
5461 Gumussoy M, Atmaca S, Bilgici B, et al. (2009). Changes in IGF-I, IGFBP-3 and ghrelin levels after adenotonsillectomy in children with sleep disordered breathing. Int J Pediatr Otorhinolaryngol.
5462 Gunter JB, Willging JP, Myer CM. (2009). Dexamethasone and postoperative bleeding after tonsillectomy in children. Jama.
5463 Gupta N, Gupta SD, Varshney S, et al. (2009). Orthodontic treatment after adenoidectomy patients: effect on jaw relations in saggital plane. Indian J Otolaryngol Head Neck Surg.
5464 Hafeez A, Khan MY, Minhas LA. (2009). A comparative histological study of the surface epithelium and high endothelial venules in the subepithelial compartments of human nasopharyngeal and palatine tonsils. J Coll Physicians Surg Pak.
5465 Hagander L, Harlid R, Svanborg E. (2009). Quantitative sensory testing in the oropharynx: a means of showing nervous lesions in patients with obstructive sleep apnea and snoring. Chest.
5466 Hahn CH, Rungby JA, Overgaard T, et al. (2009). Effect of diathermy on pain and healing in tonsillectomy, compared with other methods of haemostasis: a randomised study. J Laryngol Otol.
5467 Handa U, Dhingra N, Chopra R, et al. (2009). Pleomorphic adenoma: Cytologic variations and potential diagnostic pitfalls. Diagn Cytopathol.
5468 Hanna E, DeMonte F, Ibrahim S, et al. (2009). Endoscopic resection of sinonasal cancers with and without craniotomy: oncologic results. Arch Otolaryngol Head Neck Surg.
5469 Harada H, Omura K. (2009). Metastasis of oral cancer to the parotid node. Eur J Surg Oncol.
5470 Harris PK, Hussey DJ, Watson DI, et al. (2009). Reflux changes in adenoidal hyperplasia: a controlled prospective study to investigate its aetiology. Clin Otolaryngol.
5471 Hayashi M, Fujihara K, Beder LB, et al. (2009). Pathogenic role of tonsillar lymphocytes in associated with HSP60/65 in Pustulosis palmaris et plantaris. Auris Nasus Larynx.
5472 Heidemann CH, Wallen M, Aakesson M, et al. (2009). Post-tonsillectomy hemorrhage: assessment of risk factors with special attention to introduction of coblation technique. Eur Arch Otorhinolaryngol.
5473 Henry HL, Fernandez CV, Corsten G. (2009). Post-transplant lymphoproliferative disorder in an adolescent masquerading as a complicated primary EBV infection. BMJ Case Rep.
5474 Hermans C, Altisent C, Batorova A, et al. (2009). Replacement therapy for invasive procedures in patients with haemophilia: literature review, European survey and recommendations. Haemophilia.
5475 Heusner TA, Hahn S, Hamami ME, et al. (2009). Incidental head and neck (18)F-FDG uptake on PET/CT without corresponding morphological lesion: early predictor of cancer development?. Eur J Nucl Med Mol Imaging.
5476 Hirunwiwatkul P, Chaikitthai N, Wadwongtham W, et al. (2009). Vessel sealing system tonsillectomy vs cold knife tonsillectomy: A randomized, paired control study of efficacy and adverse effects. Asian Biomedicine.
5477 Hoa M, Tomovic S, Nistico L, et al. (2009). Identification of adenoid biofilms with middle ear pathogens in otitis-prone children utilizing SEM and FISH. Int J Pediatr Otorhinolaryngol.
5478 Hoddeson EK, Gourin CG. (2009). Adult tonsillectomy: current indications and outcomes. Otolaryngol Head Neck Surg.
5479 Hornibrook J. (2009). The role of tonsillectomy in reducing recurrent pharyngitis: a systematic review. Otolaryngol Head Neck Surg.
5480 Howard NS, Brietzke SE. (2009). Pediatric tonsil size: objective vs subjective measurements correlated to overnight polysomnogram. Otolaryngol Head Neck Surg.
5481 Hung MH, Shih PY, Yang YM, et al. (2009). Cervicofacial subcutaneous emphysema following tonsillectomy: implications for anesthesiologists. Acta Anaesthesiol Taiwan.
5482 Hyland KA, Brennan R, Olmsted SB, et al. (2009). The early interferon response of nasal-associated lymphoid tissue to Streptococcus pyogenes infection. FEMS Immunol Med Microbiol.
5483 Ida JB, Worley NK, Amedee RG. (2009). Gold laser adenoidectomy: long-term safety and efficacy results. Int J Pediatr Otorhinolaryngol.
5484 Inanoglu K, Ozbakis Akkurt BC, Turhanoglu S, et al. (2009). Intravenous ketamine and local bupivacaine infiltration are effective as part of a multimodal regime for reducing post-tonsillectomy pain. Med Sci Monit.
5485 Inci N, Basut O, Kasapoglu F, et al. (2009). Management of pain after tonsillectomy: a prospective, randomized clinical study. Kulak Burun Bogaz Ihtis Derg.
5486 Iqbal Z, Rabbani MZ, Zafar MJ. (2009). Post tonsillectomy hemorrhage incidence: A comparison between dissection and bipolar diathermy techniques. Rawal Medical Journal.
5487 Isaacson G. (2009). Avoiding airway obstruction after pediatric adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
5488 Iseli TA, Karnell LH, Graham SM, et al. (2009). Role of radiotherapy in adenoid cystic carcinoma of the head and neck. J Laryngol Otol.
5489 Ishiki H, Miyajima C, Nakao K, et al. (2009). Synovial sarcoma of the head and neck: rare case of cervical metastasis. Head Neck.
5490 Isik B, Arslan M, Ozsoylar O, et al. (2009). Effects of preoperative lornoxicam versus tramadol on postoperative pain and adverse effects in adult tonsillectomy patients. Agri.
5491 Jabbari Moghaddam Y, Rafeey M, Radfar R. (2009). Comparative assessment of Helicobacter pylori colonization in children tonsillar tissues. Int J Pediatr Otorhinolaryngol.
5492 Jahromi SAH, Valami SMH, Naseh N. (2009). A comparison of the effect of oral paracetamol and clonidine on pediatric preoperative anxiety in adenotonsillectomy. Pakistan Journal of Medical Sciences.
5493 Janjanin S, Prgomet D. (2009). Acute lingual tonsillitis: an overlooked cause of severe sore throat in adults who have had a palatine tonsillectomy?. Med J Aust.
5494 Jeanmonod R. (2009). On surgeons and doughnuts. Ann Emerg Med.
5495 Jedrychowski W, Perera FP, Maugeri U, et al. (2009). Early wheezing phenotypes and severity of respiratory illness in very early childhood: study on intrauterine exposure to fine particle matter. Environ Int.
5496 Jeon EJ, Park YS, Park SS, et al. (2009). The effectiveness of gabapentin on post-tonsillectomy pain control. Eur Arch Otorhinolaryngol.
5497 Jeyakumar A, Williamson ME, Brickman TM, et al. (2009). Otolaryngologic manifestations of mitochondrial cytopathies. Am J Otolaryngol.
5498 Johnson PE, Rickert SM, Jones J. (2009). Duration-related efficacy of postoperative antibiotics following pediatric tonsillectomy: a prospective, randomized, placebo-controlled trial. Arch Otolaryngol Head Neck Surg.
5499 Jorgensen DM. (2009). Single-dose extended-release oral azithromycin vs. 3-day azithromycin for the treatment of group A beta-haemolytic streptococcal pharyngitis/tonsillitis in adults and adolescents: a double-blind, double-dummy study. Clin Microbiol Infect.
5500 Ju JH, Kang MH, Kim HG, et al. (2009). Successful treatment of syncope with chemotherapy irresponsive to cardiac pacemaker in head and neck cancer. Yonsei Med J.
5501 Juliano ML, Machado MA, Carvalho LB, et al. (2009). Mouth breathing children have cephalometric patterns similar to those of adult patients with obstructive sleep apnea syndrome. Arq Neuropsiquiatr.
5502 Kaditis AG, Alexopoulos E, Chaidas K, et al. (2009). Urine concentrations of cysteinyl leukotrienes in children with obstructive sleep-disordered breathing. Chest.
5503 Kaditis AG, Lianou L, Hatzinikolaou S, et al. (2009). Tonsillar size in 2- to 14-year-old children with and without snoring. Pediatr Pulmonol.
5504 Kager H, Likar R, Jabarzadeh H, et al. (2009). Electrical punctual stimulation (P-STIM) with ear acupuncture following tonsillectomy, a randomised, controlled pilot study. Acute Pain.
5505 Kager H, Likar R, Jabarzadeh H, et al. (2009). Electrical punctural stimulation (P-STIM) with ear acupuncture following tonsillectomy: A randomised, controlled pilot study. European Journal of Pain.
5506 Kantola K, Sadeghi M, Lahtinen A, et al. (2009). Merkel cell polyomavirus DNA in tumor-free tonsillar tissues and upper respiratory tract samples: implications for respiratory transmission and latency. J Clin Virol.
5507 Karaman E, Enver O, Alimoglu Y, et al. (2009). Oropharyngeal flora changes after tonsillectomy. Otolaryngol Head Neck Surg.
5508 Kargoshaie A, Akhlaghi M, Najafi M. (2009). Oxygen saturation improvement after adenotonsillectomy in children. Pak J Biol Sci.
5509 Kargoshaie AA, Najafi M, Akhlaghi M, et al. (2009). The correlation between tonsil size and academic performance is not a direct one, but the results of various factors. Acta Otorhinolaryngol Ital.
5510 Kawasaki Y, Suyama K, Abe Y, et al. (2009). Tonsillectomy with methylprednisolone pulse therapy as rescue treatment for steroid-resistant IgA nephropathy in children. Tohoku J Exp Med.
5511 Kaygusuz I, Alpay HC, Godekmerdan A, et al. (2009). Evaluation of long-term impacts of tonsillectomy on immune functions of children: a follow-up study. Int J Pediatr Otorhinolaryngol.
5512 Kennoki T, Ishida H, Yamaguchi Y, et al. (2009). Proteinuria-reducing effects of tonsillectomy alone in IgA nephropathy recurring after kidney transplantation. Transplantation.
5513 Kerstein R, Stimpson P, Caulfield H, et al. (2009). Iron deficiency and sleep disordered breathing in children--cause or effect?. Int J Pediatr Otorhinolaryngol.
5514 Khalil H. (2009). Does the peri-operative administration of antibiotics improve pain control in adults undergoing tonsillectomy?. mRCT.
5515 Khalyfa A, Capdevila OS, Buazza MO, et al. (2009). Genome-wide gene expression profiling in children with non-obese obstructive sleep apnea. Sleep Med.
5516 Khan NS, Khan AR, Ali F, et al. (2009). Management of tonsillectomy haemorrhage by bipolar versus dissection method. Journal of Medical Sciences.
5517 Kheirandish-Gozal L, Serpero LD, Dayyat E, et al. (2009). Corticosteroids suppress in vitro tonsillar proliferation in children with obstructive sleep apnoea. Eur Respir J.
5518 Kim J, Bhattacharjee R, Dayyat E, et al. (2009). Increased cellular proliferation and inflammatory cytokines in tonsils derived from children with obstructive sleep apnea. Pediatr Res.
5519 Kim JY, Chang YJ, Lee JY, et al. (2009). Post-induction alfentanil reduces sevoflurane-associated emergence agitation in children undergoing an adenotonsillectomy. Acta Anaesthesiol Scand.
5520 Klemetti S, Kinnunen I, Suominen T, et al. (2009). The effect of preoperative fasting on postoperative pain, nausea and vomiting in pediatric ambulatory tonsillectomy. Int J Pediatr Otorhinolaryngol.
5521 Koc S, Ozturk K, Buyukbas S, et al. (2009). Ghrelin levels in children with adenoid or chronic tonsil hypertrophies before and after surgery. Int J Pediatr Otorhinolaryngol.
5522 Koczmara C, Hyland S, Greenall J. (2009). Hospital-acquired acute hyponatremia and parenteral fluid administration in children. Canadian Journal of Hospital Pharmacy.
5523 Kohl SK, Simpson RJ, Wisecarver J. (2009). Chondroid metaplasia mimicking recurrent squamous cell carcinoma of the head and neck. Ear Nose Throat J.
5524 Kohler M. (2009). Risk factors and treatment for obstructive sleep apnea amongst obese children and adults. Curr Opin Allergy Clin Immunol.
5525 Kohler MJ, Lushington K, van den Heuvel CJ, et al. (2009). Adenotonsillectomy and neurocognitive deficits in children with Sleep Disordered Breathing. PLoS One.
5526 Konrad FM, Schroeder TH. (2009). Anaesthesia in patients with mastocytosis. Acta Anaesthesiol Scand.
5527 Koskenkorva T, Koivunen P, Penna T, et al. (2009). Factors affecting quality-of-life impact of adult tonsillectomy. J Laryngol Otol.
5528 Kovacs KB, Tisza B, Komaromi I, et al. (2009). Inherited factor V deficiency associated with a novel heterozygous missense mutation (p.G493R) in a patient with excessive surgical bleeding. Thromb Haemost.
5529 Kubba H. (2009). Paediatric commentary. Clin Otolaryngol.
5530 Kumar N, Hu WT. (2009). Extrapyramidal reaction to ondansetron and propofol. Mov Disord.
5531 Kunert P, Janowski M, Zakrzewska A, et al. (2009). Comparision of results between two different techniques of cranio-cervical decompression in patients with Chiari I malformation. Neurol Neurochir Pol.
5532 Lange MJ, Lasiter JC, Misfeldt ML. (2009). Toll-like receptors in tonsillar epithelial cells. Int J Pediatr Otorhinolaryngol.
5533 Lerman J. (2009). A disquisition on sleep-disordered breathing in children. Paediatr Anaesth.
5534 Lerman J, Houle TT, Matthews BT, et al. (2009). Propofol for tracheal intubation in children anesthetized with sevoflurane: a dose-response study. Paediatr Anaesth.
5535 Lesinskas E, Drigotas M. (2009). The incidence of adenoidal regrowth after adenoidectomy and its effect on persistent nasal symptoms. Eur Arch Otorhinolaryngol.
5536 Li HY, Lee LA. (2009). Sleep-disordered breathing in children. Chang Gung Medical Journal.
5537 Li HY, Lee LA. (2009). Relocation pharyngoplasty for obstructive sleep apnea. Laryngoscope.
5538 Liao Y, Zeng H, Wang X, et al. (2009). Expression patterns and prognostic significance of inhibitor of apoptosis proteins in adenoid cystic carcinoma and pleomorphic adenoma of lachrymal gland. Exp Eye Res.
5539 Lim J, McKean MC. (2009). Adenotonsillectomy for obstructive sleep apnoea in children. Cochrane Database Syst Rev.
5540 Lin AC, Koltai PJ. (2009). Persistent pediatric obstructive sleep apnea and lingual tonsillectomy. Otolaryngol Head Neck Surg.
5541 Lin SY, Laeeq K, Ishii M, et al. (2009). Development and pilot-testing of a feasible, reliable, and valid operative competency assessment tool for endoscopic sinus surgery. Am J Rhinol Allergy.
5542 Llor C, Calvino O, Hernandez S, et al. (2009). Repetition of the rapid antigen test in initially negative supposed streptococcal pharyngitis is not necessary in adults. Int J Clin Pract.
5543 Lo YC, Lauderdale TL, Chang SY, et al. (2009). Streptococcus pneumoniae colonization among patients with human immunodeficiency virus-1 who had received 23-valent polysaccharide pneumococcal vaccine. J Microbiol Immunol Infect.
5544 Locati LD, Bossi P, Perrone F, et al. (2009). Cetuximab in recurrent and/or metastatic salivary gland carcinomas: A phase II study. Oral Oncol.
5545 Loh KS, Barker E, Bruch G, et al. (2009). Prognostic factors in malignancy of the minor salivary glands. Head Neck.
5546 Lok W, Chenault MN, Anteunis LJ. (2009). Implementation of neonatal screening for hearing impairment: influence on pediatric otitis media surgery in The Netherlands. Int J Pediatr Otorhinolaryngol.
5547 Low TH, Harris P, Esterman A, et al. (2009). Pain versus bleeding risk following tonsillectomy: do patients and doctors agree?. J Laryngol Otol.
5548 Lowry TR, Workman JR. (2009). Avoiding oral burns during electrocautery tonsillectomy. Ear Nose Throat J.
5549 Lundeborg I, McAllister A, Graf J, et al. (2009). Oral motor dysfunction in children with adenotonsillar hypertrophy--effects of surgery. Logoped Phoniatr Vocol.
5550 Lundeborg I, McAllister A, Samuelsson C, et al. (2009). Phonological development in children with obstructive sleep-disordered breathing. Clin Linguist Phon.
5551 Lundkvist K, Januszkiewicz A, Friberg D. (2009). Uvulopalatopharyngoplasty in 158 OSAS patients failing non-surgical treatment. Acta Otolaryngol.
5552 Mabrouk AA, Eapen V. (2009). Challenges in the identification and treatment of PANDAS: a case series. J Trop Pediatr.
5553 Macchi A, Castelnuovo P. (2009). Aerosol antibiotic therapy in children with chronic upper airway infections: a potential alternative to surgery. Int J Immunopathol Pharmacol.
5554 Macdonald KD, McGinley BM, Brown DJ, et al. (2009). Primary snoring and growth failure in a patient with cystic fibrosis. Respir Care.
5555 Maggioni F, Marchese-Ragona R, Mampreso E, et al. (2009). Exertional headache as unusual presentation of the syndrome of an elongated styloid process. Headache.
5556 Manica D, Smith MM. (2009). Adenotonsillectomy -- immediate post operative respiratory distress. Braz J Otorhinolaryngol.
5557 Mariotti AJ, Agrawal R, Hotaling AJ. (2009). The role of tonsillectomy in pediatric IgA nephropathy. Arch Otolaryngol Head Neck Surg.
5558 Marseglia GL, Avanzini MA, Caimmi S, et al. (2009). Passive exposure to smoke results in defective interferon-gamma production by adenoids in children with recurrent respiratory infections. J Interferon Cytokine Res.
5559 Marseglia GL, Poddighe D, Caimmi D, et al. (2009). Role of adenoids and adenoiditis in children with allergy and otitis media. Curr Allergy Asthma Rep.
5560 Maruya S, Shirasaki T, Nagaki T, et al. (2009). Differential expression of topoisomerase IIalpha protein in salivary gland carcinomas: histogenetic and prognostic implications. BMC Cancer.
5561 Matheson MC, Walters EH, Simpson JA, et al. (2009). Relevance of the hygiene hypothesis to early vs. late onset allergic rhinitis. Clin Exp Allergy.
5562 Mattila PS, Hammaren-Malmi S, Pelkonen AS, et al. (2009). Effect of adenoidectomy on respiratory function: a randomised prospective study. Arch Dis Child.
5563 Maurer JT. (2009). Update on surgical treatments for sleep apnea. Swiss Med Wkly.
5564 McGinley B, Halbower A, Schwartz AR, et al. (2009). Effect of a high-flow open nasal cannula system on obstructive sleep apnea in children. Pediatrics.
5565 McLaren RE, Gibbins NE, Varia ME, et al. (2009). Response to Pothier et al. and Lowe on ‘The NPTA may have underestimated tonsillectomy complications: a case note review of data submitted by two hospitals’. Clin Otolaryngol.
5566 Milhorat TH, Bolognese PA, Nishikawa M, et al. (2009). Association of Chiari malformation type I and tethered cord syndrome: preliminary results of sectioning filum terminale. Surg Neurol.
5567 Mink JW, Shaha SH, Brodsky L. (2009). Making sense out of the tonsillectomy literature. Int J Pediatr Otorhinolaryngol.
5568 Mitchell RB. (2009). Pediatric turbinate reduction by coblation. Operative Techniques in Otolaryngology - Head and Neck Surgery.
5654 Shimoji K, Miyajima M, Karagiozov K, et al. (2009). Surgical considerations in fourth ventricular ependymoma with the transcerebellomedullary fissure approach in focus. Childs Nerv Syst.
5655 Shin SY, Choi GS, Lee KH, et al. (2009). IgE response to staphylococcal enterotoxins in adenoid tissues from atopic children. Laryngoscope.
5656 Shin SY, Choi GS, Park HS, et al. (2009). Immunological investigation in the adenoid tissues from children with chronic rhinosinusitis. Otolaryngol Head Neck Surg.
5657 Shin SY, Choi SJ, Hur GY, et al. (2009). Local production of total IgE and specific antibodies to the house dust mite in adenoid tissue. Pediatr Allergy Immunol.
5658 Shott SR. (2009). Pediatric obstructive sleep apnea-base of tongue obstruction. Operative Techniques in Otolaryngology - Head and Neck Surgery.
5659 Singh P, Whyte S. (2009). Anaesthesia for elective ear, nose and throat surgery in children. Anaesthesia and Intensive Care Medicine.
5660 Singh PK, Masood A, Chawla OP. (2009). Rare post-tonsillectomy complication in human immunodeficiency virus positive patient: ulcero-necrotic lesion of tonsillar fossa. J Laryngol Otol.
5661 Skladzien J, Strek P, Oles K, et al. (2009). Complications after tonsillectomy: Cervical epidural empyema. American Journal of Case Reports.
5662 Smith J, Newcomb P, Sundberg E, et al. (2009). Relationship of opioid analgesic protocols to assessed pain and length of stay in the pediatric postanesthesia unit following tonsillectomy. J Perianesth Nurs.
5663 Smith JE, Wren MK, Richardson MS, et al. (2009). Colonic duplication in the submandibular region of the neck. International Journal of Pediatric Otorhinolaryngology Extra.
5664 Smith LP, Chewaproug L, Spergel JM, et al. (2009). Otolaryngologists may not be doing enough to diagnose pediatric eosinophilic esophagitis. Int J Pediatr Otorhinolaryngol.
5665 Smithard A, Cullen C, Thirlwall AS, et al. (2009). Tonsillectomy may cause altered tongue sensation in adult patients. J Laryngol Otol.
5666 Snaathorst J, Sewnaik A, Paridaens D, et al. (2009). Primary epithelial tumors of the lacrimal gland; a retrospective analysis of 22 patients. Int J Oral Maxillofac Surg.
5667 Sogut A, Yilmaz O, Dinc G, et al. (2009). Prevalence of habitual snoring and symptoms of sleep-disordered breathing in adolescents. Int J Pediatr Otorhinolaryngol.
5668 Souki BQ, Pimenta GB, Souki MQ, et al. (2009). Prevalence of malocclusion among mouth breathing children: do expectations meet reality?. Int J Pediatr Otorhinolaryngol.
5669 Sproson EL, Hogan AM, Hill CM. (2009). Accuracy of clinical assessment of paediatric obstructive sleep apnoea in two English centres. J Laryngol Otol.
5670 Stelter K, Hempel JM, Berghaus A, et al. (2009). Application methods of local anaesthetic infiltrations for postoperative pain relief in tonsillectomy: a prospective, randomised, double-blind, clinical trial. Eur Arch Otorhinolaryngol.
5671 Stephens J, Singh A, Hughes J, et al. (2009). A prospective multi-centre randomised controlled trial comparing PlasmaKnife with bipolar dissection tonsillectomy: evaluating an emerging technology. Int J Pediatr Otorhinolaryngol.
5672 Stone RS, Spiegel JH. (2009). Prevalence of obstructive sleep disturbance in children with failure to thrive. J Otolaryngol Head Neck Surg.
5673 Stoodley P, Debeer D, Longwell M, et al. (2009). Tonsillolith: not just a stone but a living biofilm. Otolaryngol Head Neck Surg.
5674 Subramaniam V, Kumar P. (2009). Impact of tonsillectomy with or without adenoidectomy on the acoustic parameters of the voice: a comparative study. Arch Otolaryngol Head Neck Surg.
5675 Sun J, Shen Y, Weng YQ, et al. (2009). Lateral lip-splitting approach for total and subtotal maxillectomy. J Oral Maxillofac Surg.
5676 Sunkaraneni VS, Ismail-Koch H, Salib RJ, et al. (2009). Guillotine tonsillectomy: a neglected technique. J Laryngol Otol.
5677 Suzumoto M, Hotomi M, Billal DS, et al. (2009). A scoring system for management of acute pharyngo-tonsillitis in adults. Auris Nasus Larynx.
5678 Talmon Y, Ishai R, Samet A, et al. (2009). Acute myopericarditis complicating acute tonsillitis: a prospective study. Ann Otol Rhinol Laryngol.
5679 Tan LP, Wang M, Robertus JL, et al. (2009). miRNA profiling of B-cell subsets: specific miRNA profile for germinal center B cells with variation between centroblasts and centrocytes. Lab Invest.
5680 Tanna N, Choi SS. (2009). Efficacy and safety of adenotonsillectomy for pediatric obstructive sleep apnea in Prader-Willi syndrome. Ann Otol Rhinol Laryngol.
5681 Tatar EC, Karacay M, Saylam G, et al. (2009). Tonsillolithiasis with actinomycotic infection: a case report. Kulak Burun Bogaz Ihtis Derg.
5682 Tavakkolizadeh M, Glynn JC. (2009). Failure to inflate Ambu AuraFlex single-use LMA after insertion. Acta Anaesthesiol Scand.
5683 Tchoumi JC, Ambassa JC, Butera G. (2009). Pregnancy follow-up in a patient with mechanical valve: possible in sub-Saharan Africa?. Pan Afr Med J.
5684 Teker AM, Korkut AY, Gedikli O, et al. (2009). Prospective, controlled clinical trial of Ankaferd Blood Stopper in children undergoing tonsillectomy. Int J Pediatr Otorhinolaryngol.
5685 Thomas D, Singatullina N. (2009). Fresh frozen plasma transfusion for reversal of prolonged post-anaesthesia apnoea. Transfus Med.
5686 Thompson PL, Spyridis N, Sharland M, et al. (2009). Changes in clinical indications for community antibiotic prescribing for children in the UK from 1996 to 2006: will the new NICE prescribing guidance on upper respiratory tract infections just be ignored?. Arch Dis Child.
5687 Toh A, Mullin A, Grainger J, et al. (2009). Indications for tonsillectomy: are we documenting them?. Ann R Coll Surg Engl.
5688 Tweedie DJ, Skilbeck CJ, Wyatt ME, et al. (2009). Partial adenoidectomy by suction diathermy in children with cleft palate, to avoid velopharyngeal insufficiency. Int J Pediatr Otorhinolaryngol.
5689 Ulubil SA, Iseri M, Ozturk M, et al. (2009). Cervical necrotizing fasciitis. J Otolaryngol Head Neck Surg.
5690 Ushigome H, Suzuki T, Fujiki M, et al. (2009). Efficacy of tonsillectomy for patients with recurrence of IgA nephropathy after kidney transplantation. Clin Transplant.
5691 Vahedi H, Merat S, Momtahen S, et al. (2009). Epidemiologic characteristics of 500 patients with inflammatory bowel disease in Iran studied from 2004 through 2007. Arch Iran Med.
5692 Vaideeswar P, George SM, Kane SV, et al. (2009). Extranodal follicular dendritic cell sarcoma of the tonsil - case report of an epithelioid cell variant with osteoclastic giant cells. Pathol Res Pract.
5693 Vaiman M, Shoval G, Gavriel H. (2009). Malingering dysphagia and odynophagia electromyographic assessment. Am J Otolaryngol.
5694 Valdimarsson H, Thorleifsdottir R, Sigurdarttir S, et al. (2009). The impact of tonsillectomy on patients with chronic plaque psoriasis. European Journal of Immunology.
5695 Valdimarsson H, Thorleifsdottir RH, Sigurdardottir SL, et al. (2009). Psoriasis--as an autoimmune disease caused by molecular mimicry. Trends Immunol.
5696 van Lierop AC, Prescott CA. (2009). Is routine pathological examination required in South African children undergoing adenotonsillectomy?. S Afr Med J.
5697 Varricchio A, Tortoriello G, Capasso M, et al. (2009). Prevention of surgery in children with adenoidal hypertrophy treated with intranasal flunisolide: a 12-month follow-up. J Biol Regul Homeost Agents.
5698 Vasileiou I, Giannopoulos A, Klonaris C, et al. (2009). The potential role of primary care in the management of common ear, nose or throat disorders presenting to the emergency department in Greece. Qual Prim Care.
5699 Vasku V, Bienertova-Vasku J, Necas M, et al. (2009). MTHFR (methylenetetrahydrofolate reductase) C677T polymorphism and psoriasis. Clin Exp Med.
5700 Verberne CJ, De Boer HD, Loef BG. (2009). Unexpected prolonged neuromuscular block after a single intubating dose of mivacurium: A case report. Netherlands Journal of Critical Care.
5701 Verhulst S. (2009). Toward a multidisciplinary approach to the treatment of obstructive sleep apnea in the obese child. Otolaryngol Head Neck Surg.
5702 Verma SP, Stoddard T, Gonzalez-Gomez I, et al. (2009). Histologic analysis of pediatric tonsil and adenoid specimens: is it really necessary?. Int J Pediatr Otorhinolaryngol.
5703 Verstraete M, Vermylen J, Tyberghein J. (2009). Double blind evaluation of the haemostatic effect of adrenochrome monosemicarbazone, conjugated oestrogens and epsilonaminocaproic acid after adenotonsillectomy. Acta haematologica.
5704 Vlachos-Mayer H, Dorion D, Praud JP. (2009). Obstructive sleep disordered breathing in children and adolescence. Minerva Pneumologica.
5705 Walker H. (2009). The child who refuses to undergo anesthesia and surgery--a case scenario-based discussion of the ethical and legal issues. Paediatr Anaesth.
5706 Waltonen JD, Ozer E, Hall NC, et al. (2009). Metastatic carcinoma of the neck of unknown primary origin: evolution and efficacy of the modern workup. Arch Otolaryngol Head Neck Surg.
5707 Waltonen JD, Ozer E, Schuller DE, et al. (2009). Tonsillectomy vs. deep tonsil biopsies in detecting occult tonsil tumors. Laryngoscope.
5708 Wang GL, Li XY, Wang MY, et al. (2009). Cell-wall-deficient bacteria: a major etiological factor for psoriasis?. Chin Med J (Engl).
5709 Wang JH, Chung YS, Jang YJ, et al. (2009). Palatine tonsil size and its correlation with subjective tonsil size in patients with sleep-disordered breathing. Otolaryngol Head Neck Surg.
5710 Wang WL, Shen WD. (2009). A summary of studies in countries other than China on acupuncture in anesthesia and for postoperative complications. Journal of Chinese Integrative Medicine.
5711 Wasilewska J, Kaczmarski M, Citko D, et al. (2009). Sleep-wake schedules in preschool children who snore. Adv Med Sci.
5712 Wasson JD, De Zoysa N, Stephens J. (2009). Tissue-box tonsillar tie trainer. Clin Otolaryngol.
5713 Watanabe A, Horikoshi T, Uchida M, et al. (2009). Diagnostic value of spinal MR imaging in spontaneous intracranial hypotension syndrome. AJNR Am J Neuroradiol.
5714 Waters KA, Cheng AT. (2009). Adenotonsillectomy in the context of obstructive sleep apnoea. Paediatr Respir Rev.
5715 Watts TL, Kountakis SE. (2009). Intraoperative bupivacaine for reduction of post-tonsillectomy pain: a randomized, placebo-controlled, double-blind study of 26 patients. Ear, nose, & throat journal.
5716 Wei JL, Bond J, Mayo MS, et al. (2009). Improved behavior and sleep after adenotonsillectomy in children with sleep-disordered breathing: long-term follow-up. Arch Otolaryngol Head Neck Surg.
5717 Wieland A, Belden L, Cunningham M. (2009). Preoperative coagulation screening for adenotonsillectomy: a review and comparison of current physician practices. Otolaryngol Head Neck Surg.
5718 Wiggins SA. (2009). Family exemplars during implementation of a home pain management intervention. Issues Compr Pediatr Nurs.
5719 Wijga AH, Scholtens S, Wieringa MH, et al. (2009). Adenotonsillectomy and the development of overweight. Pediatrics.
5720 Willging JP. (2009). Superiorly based pharyngeal flap and posterior pharyngeal wall augmentation. Operative Techniques in Otolaryngology - Head and Neck Surgery.
5721 Wilson MN, Long LS, Ved S, et al. (2009). Younger pediatric adenotonsillar surgical patients exhibit more complications at mouth gag insertion with LMA use. Int J Pediatr Otorhinolaryngol.
5722 Windfuhr JP. (2009). In reference to Life-threatening posttonsillectomy hemorrhage. Laryngoscope.
5723 Windfuhr JP, Schloendorff G, Sesterhenn AM, et al. (2009). A devastating outcome after adenoidectomy and tonsillectomy: ideas for improved prevention and management. Otolaryngol Head Neck Surg.
5724 Windfuhr JP, Schlondorff G, Sesterhenn AM, et al. (2009). From the expert's office: localized neural lesions following tonsillectomy. Eur Arch Otorhinolaryngol.
5725 Windfuhr JP, Wienke A, Chen YS. (2009). Electrosurgery as a risk factor for secondary post-tonsillectomy hemorrhage. Eur Arch Otorhinolaryngol.
5726 Winther B, Gross BC, Hendley JO, et al. (2009). Location of bacterial biofilm in the mucus overlying the adenoid by light microscopy. Arch Otolaryngol Head Neck Surg.
5727 Witmer CM, Elden L, Butler RB, et al. (2009). Incidence of bleeding complications in pediatric patients with type 1 von Willebrand disease undergoing adenotonsillar procedures. J Pediatr.
5728 Woodson BT, O'Connor PD. (2009). Reconstruction of airway soft tissues in obstructive sleep apnea. Oral Maxillofac Surg Clin North Am.
5729 Wysocki J, Krasny M, Skarzynski PH. (2009). Patency of nasopharynx and a cephalometric image in the children with orthodontic problems. Int J Pediatr Otorhinolaryngol.
5730 Xue FS, Li TZ, Liao X. (2009). Safe use of a laryngeal mask airway in children undergoing a tonsillectomy. Acta Anaesthesiol Scand.
5731 Yagi H, Nakata S, Tsuge H, et al. (2009). Morphological examination of upper airway in obstructive sleep apnea. Auris Nasus Larynx.
5732 Yaşar H, Özkul H, Verim A. (2009). Comparison of the thermal welding technique and cold dissection for pediatric tonsillectomy. Balkan Medical Journal.
5733 Ye J, Liu H, Zhang G, et al. (2009). Postoperative respiratory complications of adenotonsillectomy for obstructive sleep apnea syndrome in older children: prevalence, risk factors, and impact on clinical outcome. J Otolaryngol Head Neck Surg.
5734 Yener M, Gultekin E, Ozdemir I. (2009). Adjuvant use of liquid alginate suspension for post-tonsillectomy morbidity: double-blind randomized clinical trial of efficacy. Otolaryngol Head Neck Surg.
5735 Yilmaz S, Demiraran Y, Akkan N, et al. (2009). The effects of topical levobupivacaine on morbidity in pediatric tonsillectomy patients. Int J Pediatr Otorhinolaryngol.
5736 Yoshizaki T, Bandoh N, Ueda S, et al. (2009). Up-regulation of CC chemokine receptor 6 on tonsillar T cells and its induction by in vitro stimulation with alpha-streptococci in patients with pustulosis palmaris et plantaris. Clin Exp Immunol.
5737 Yousaf M, Inayatullah, Khan AR, et al. (2009). The presentation pattern of otitis media with effusion. Journal of Medical Sciences.
5738 Ysunza A, Pamplona MC, Molina F, et al. (2009). Surgical planning for restoring velopharyngeal function in velocardiofacial syndrome. Int J Pediatr Otorhinolaryngol.
5739 Yue Z, Wang M, Xu W, et al. (2009). Secretion of antidiuretic hormone in children with obstructive sleep apnea-hypopnea syndrome. Acta Otolaryngol.
5740 Zuliani G, Carlisle M, Duberstein A, et al. (2009). Biofilm density in the pediatric nasopharynx: recurrent acute otitis media versus obstructive sleep apnea. Ann Otol Rhinol Laryngol.
5741 (2010). At the request of the corresponding (first) author, the editors of Sleep are retracting the following paper and erratum: Guilleminault C, Quo S, Huynh NT, Li K. Orthodontic expansion treatment and adenotonsillectomy in the treatment of obstructive sleep apnea in prepubertal children. Sleep;31(7):953-957 and Erratum to Guilleminault C, Quo S, Huynh NT, Li K. Orthodontic expansion treatment and adenotonsillectomy in the treatment of obstructive sleep apnea in prepubertal children. Sleep;31(7):953-957, in Sleep 2009;32(1):6. Sleep.
5742 (2010). Effect of antibiotics following paediatric tonsillectomy. Australian Journal of Pharmacy.
5743 (2010). Tonsillectomy in general practice. 1910. Practitioner.
5744 Abla AA, Link T, Fusco D, et al. (2010). Comparison of dural grafts in Chiari decompression surgery: Review of the literature. J Craniovertebr Junction Spine.
5745 Acharya A, Gurung R, Khanal B, et al. (2010). Bacteriology and antibiotic susceptibility pattern of peritonsillar abscess. JNMA J Nepal Med Assoc.
5746 Acharya K, Bhusal CL, Guragain RP. (2010). Endoscopic grading of adenoid in otitis media with effusion. JNMA J Nepal Med Assoc.
5747 Acioglu E, Yigit O, Alkan Z, et al. (2010). The role of matrix metalloproteinases in recurrent tonsillitis. Int J Pediatr Otorhinolaryngol.
5748 Aftandilian CC, Friedmann AM. (2010). Burkitt lymphoma with pancreatic involvement. J Pediatr Hematol Oncol.
5749 Ahmad R, Abdullah K, Amin Z, et al. (2010). Predicting safe tonsillectomy for ambulatory surgery. Auris Nasus Larynx.
5750 Ahmad Z, de Silva N, Morton RP, et al. (2010). Safety of day-stay tonsillectomy. Indian J Otolaryngol Head Neck Surg.
5751 Ahn YM. (2010). Treatment of obstructive sleep apnea in children. Korean J Pediatr.
5752 Ahsan F, Stevenson S. (2010). The Kiwi hoop for Boyle-Davies gag suspension during tonsillectomy. J Laryngol Otol.
5753 Akbay BK, Yildizbas S, Guclu E, et al. (2010). Analgesic efficacy of topical tramadol in the control of postoperative pain in children after tonsillectomy. J Anesth.
5754 Aksoy F, Ozturan O, Veyseller B, et al. (2010). Comparison of radiofrequency and monopolar electrocautery tonsillectomy. J Laryngol Otol.
5755 Ali R, Lang E, Chukudubelu O, et al. (2010). Efficacy of a direct booking system: A prospective cohort study. Ambulatory Surgery.
5756 Al-Khateeb TH, al Dajani TM, Al Jamal GA. (2010). Mineralization of the stylohyoid ligament complex in a Jordanian sample: a clinicoradiographic study. J Oral Maxillofac Surg.
5757 Allee J, Tobias JD. (2010). Perioperative care of a child with non-ketotic hyperglycinemia. Saudi J Anaesth.
5758 Allen U. (2010). Infective endocarditis: Updated guidelines. Canadian Journal of Infectious Diseases and Medical Microbiology.
5759 Al-Metwalli RR, Mowafi HA, Ismail SA. (2010). Gentle chest compression relieves extubation laryngospasm in children. J Anesth.
5760 Altumbabic H, Salkic A. (2010). Incidental metastasis of papillary thyroid carcinoma in lymph nodes of patient with squamous cell carcinoma of the oral cavity: A case report. Acta Medica Saliniana.
5761 Amaryan GG, Mkrtchyan NG, Arustamyan SS. (2010). Tonsillectomy in familial mediterranean fever in children: Clinical and genetic findings. New Armenian Medical Journal.
5762 Apan A, Aykac E, Kazkayasi M, et al. (2010). Magnesium sulphate infusion is not effective on discomfort or emergence phenomenon in paediatric adenoidectomy/tonsillectomy. Int J Pediatr Otorhinolaryngol.
5763 Arens R, Sin S, Willen S, et al. (2010). Rhino-sinus involvement in children with obstructive sleep apnea syndrome. Pediatr Pulmonol.
5764 Ark N, Kurtaran H, Ugur KS, et al. (2010). Comparison of adenoidectomy methods: examining with digital palpation vs. visualizing the placement of the curette. Int J Pediatr Otorhinolaryngol.
5765 Arweiler-Harbeck D, Ozturk E, Bankfalvi A, et al. (2010). Posttonsillectomy hemorrhage: blame on surgeons or genes?. Laryngoscope.
5766 Ashraf MJ, Azarpira N, Gandomi M. (2010). Cartilaginous choristoma in palatine tonsil. Iranian Red Crescent Medical Journal.
5767 Ashraf MJ, Azarpira N, Nowroozizadeh B, et al. (2010). Fine needle aspiration cytology of palatine tonsils: a study of 112 consecutive adult tonsillectomies. Cytopathology.
5768 Asimakopoulos P, Hendry J, Syed MI, et al. (2010). Length of stay in hospital for adult tonsillectomy: a prospective study on patients' preferences. Clin Otolaryngol.
5769 Astegiano S, Terlizzi ME, Elia M, et al. (2010). Prevalence of polyomaviruses BK, JC, SV40, KI, and WU in non-malignant tonsil specimens. Minerva Med.
5770 Attia G, Ahmad MA, Saleh AB, et al. (2010). Impact of obstructive sleep apnea on global myocardial performance in children assessed by tissue Doppler imaging. Pediatr Cardiol.
5771 Attner P, Hemlin C, Soderman AC. (2010). Ligasure versus diathermy scissors tonsillectomy: A controlled randomized study. Acta Otolaryngol.
5772 Aurora RN, Casey KR, Kristo D, et al. (2010). Practice parameters for the surgical modifications of the upper airway for obstructive sleep apnea in adults. Sleep.
5773 Averono G, Vidali M, Olina M, et al. (2010). Evaluation of amoxicillin plasma and tissue levels in pediatric patients undergoing tonsillectomy. Int J Pediatr Otorhinolaryngol.
5774 Ayyad S, Al-Owaisheer A, Al-Banwan F, et al. (2010). Evidence-based practice in the use of antibiotics for respiratory tract infections in primary health centers in Kuwait. Med Princ Pract.
5775 Babademez MA, Acar B, Karasen RM. (2010). Apnea/hypopnea index in the evaluation of tongue base procedures: is it enough for the determination of surgical success?. ORL J Otorhinolaryngol Relat Spec.
5776 Bachar GY, Goh C, Goldstein DP, et al. (2010). Long-term outcome analysis after surgical salvage for recurrent tonsil carcinoma following radical radiotherapy. Eur Arch Otorhinolaryngol.
5777 Banzatto MG, Grumach AS, Mello JF, et al. (2010). Adenotonsillectomy improves the strength of respiratory muscles in children with upper airway obstruction. Int J Pediatr Otorhinolaryngol.
5778 Bartley J, Barber C. (2010). Treatment of chronic nasopharyngitis with monopolar suction diathermy. J Laryngol Otol.
5779 Bartolek D, Jakobovic J, Bartolek F, et al. (2010). Reduced-dose rocuronium for day-case tonsillectomy in children where volatile anaesthetics are not used: operating room time saving. Paediatr Anaesth.
5780 Baum ED. (2010). Tonsillectomy and adenoidectomy and myringotomy with tube insertion. Pediatr Rev.
5781 Behzadi M, Hajimohamadi F, Alagha AE, et al. (2010). Endotracheal tube cuff lidocaine is not superior to intravenous lidocaine in short pediatric surgeries. Int J Pediatr Otorhinolaryngol.
5782 Bell D, Roberts D, Kies M, et al. (2010). Cell type-dependent biomarker expression in adenoid cystic carcinoma: biologic and therapeutic implications. Cancer.
5783 Bharti B, Bharti S. (2010). Randomized trial of adenotonsillectomy versus expectant treatment in PFAPA (periodic fever, aphthous stomatitis, pharyngitis, cervical adenitis) syndrome: is the impasse over?. Journal of pediatrics.
5784 Bhatia KS, Rasalkar DD, Lee YP, et al. (2010). Evaluation of real-time qualitative sonoelastography of focal lesions in the parotid and submandibular glands: applications and limitations. Eur Radiol.
5785 Bhattacharjee R, Kheirandish-Gozal L, Spruyt K, et al. (2010). Adenotonsillectomy outcomes in treatment of obstructive sleep apnea in children: a multicenter retrospective study. Am J Respir Crit Care Med.
5786 Bhattacharyya N, Lin HW. (2010). Changes and consistencies in the epidemiology of pediatric adenotonsillar surgery, 1996-2006. Otolaryngol Head Neck Surg.
5787 Bidlingmaier C, Olivieri M, Stelter K, et al. (2010). Postoperative bleeding in paediatric ENT surgery. First results of the German ESPED trial. Hamostaseologie.
5788 Biel MA. (2010). Photodynamic therapy of head and neck cancers. Methods Mol Biol.
5789 Biswas D, Ranganathan B, King R, et al. (2010). How we do it: ‘tonsillectomy mat’, scored rubber sheet to fix the Draffin's rods. Eur Arch Otorhinolaryngol.
5790 Bitar MA, Macari AT, Ghafari JG. (2010). Correspondence between subjective and linear measurements of the palatal airway on lateral cephalometric radiographs. Arch Otolaryngol Head Neck Surg.
5791 Bonanno A, Esmaeli B, Fingeret MC, et al. (2010). Social challenges of cancer patients with orbitofacial disfigurement. Ophthal Plast Reconstr Surg.
5792 Bonfitto VL, Demasi AP, Costa AF, et al. (2010). High-grade transformation of adenoid cystic carcinomas: a study of the expression of GLUT1 glucose transporter and of mitochondrial antigen. J Clin Pathol.
5793 Brichacek B, Vanpouille C, Kiselyeva Y, et al. (2010). Contrasting roles for TLR ligands in HIV-1 pathogenesis. PLoS One.
5794 Brigger MT, Cunningham MJ, Hartnick CJ. (2010). Dexamethasone administration and postoperative bleeding risk in children undergoing tonsillectomy. Arch Otolaryngol Head Neck Surg.
5795 Broekman BF, Olff M, Tan FM, et al. (2010). The psychological impact of an adenoidectomy and adenotonsillectomy on young children. Int J Pediatr Otorhinolaryngol.
5796 Browning GG. (2010). Prophylactic steroids and/or antibiotics to reduce post-tonsillectomy morbidity: a yet unanswered conundrum. Clin Otolaryngol.
5797 Buckley A, Savage E. (2010). Preoperative information needs of children undergoing tonsillectomy. J Clin Nurs.
5798 Burg CJ, Friedman NR. (2010). Diagnosis and treatment of sleep apnea in adolescents. Adolesc Med State Art Rev.
5799 Busino RS, Quraishi HA, Aguila HA, et al. (2010). The impact of adenotonsillectomy on asthma in children. Laryngoscope.
5800 Caorsi R, Pelagatti MA, Federici S, et al. (2010). Periodic fever, apthous stomatitis, pharyngitis and adenitis syndrome. Curr Opin Rheumatol.
5801 Casimir GJ, Mulier S, Hanssens L, et al. (2010). Gender differences in inflammatory markers in children. Shock.
5802 Casserly P, Kieran S, Phelan E, et al. (2010). Bacteremia during adenoidectomy: a comparison of suction diathermy adenoid ablation and adenoid curettage. Ann Otol Rhinol Laryngol.
5803 Castelino-Prabhu S, Li QK, Ali SZ. (2010). Nonsebaceous lymphadenoma of the parotid gland: cytopathologic findings and differential diagnosis. Diagn Cytopathol.
5804 Cecchi R, Pavesi M, Calamandrei P, et al. (2010). Tonsil metastasis from cutaneous melanoma: first clinical sign of recurrence after complete lymph node dissection. J Cutan Med Surg.
5805 Ceylan S, Salman S, Bora F. (2010). Anomaly of the internal carotid artery detected during tonsillectomy. J Craniofac Surg.
5806 Chakrabarti S, Bera M, Bhattacharya PK, et al. (2010). Study of salivary gland lesions with fine needle aspiration cytology and histopothology along with immunohistochemistry. J Indian Med Assoc.
5807 Chakravorty S, Finder JD. (2010). Positive airway pressure therapy in children. Sleep Medicine Clinics.
5808 Chan MA, Gigliotti NM, Matangkasombut P, et al. (2010). CD23-mediated cell signaling in human B cells differs from signaling in cells of the monocytic lineage. Clin Immunol.
5809 Chang V, Goshgarian H, Simoff M, et al. (2010). Chronic cough in an adult patient with Chiari type-I malformation. Neurosurgery Quarterly.
5810 Charleton PM, Dennis J, Marder E. (2010). Medical management of children with Down syndrome. Paediatrics and Child Health.
5811 Chen HH, Lovell MA, Chan KH. (2010). Bilateral lymphangiomatous polyps of the palatine tonsils. Int J Pediatr Otorhinolaryngol.
5812 Chen L, Cao ZL, Han F, et al. (2010). Chronic intermittent hypoxia from pedo-stage decreases glucose transporter 4 expression in adipose tissue and causes insulin resistance. Chin Med J (Engl).
5813 Choe BH, Kim JY, Lee JH, et al. (2010). Upper gastrointestinal bleeding in children with haemophilia: a clinical significance of Helicobacter pylori infection. Haemophilia.
5814 Choi JH, Kim EJ, Choi J, et al. (2010). Obstructive sleep apnea syndrome: a child is not just a small adult. Ann Otol Rhinol Laryngol.
5815 Choi SR, Lim YH, Lee SC, et al. (2010). Spectral entropy monitoring allowed lower sevoflurane concentration and faster recovery in children. Acta Anaesthesiol Scand.
5816 Chowdhury MA, Yasmeen N, Rabbani SG, Malakar M, Hoque F, Lisa TF. (2010). Advantages of ultrasonic tonsillectomy by harmonic scalpel. Bangladesh Journal of Otorhinolaryngology.
5817 Chukudebelu O, Leonard DS, Healy A, et al. (2010). The effect of gastric decompression on postoperative nausea and emesis in pediatric, tonsillectomy patients. Int J Pediatr Otorhinolaryngol.
5818 Chung JH, Kim YH, Ko YK, et al. (2010). Vomiting after a pediatric adenotonsillectomy: comparison between propofol induced sevoflurane-nitrous oxide maintained anesthesia and TIVA with propofol-remifentanil. Korean J Anesthesiol.
5819 Ciprandi G, Tosca MA, Signori A, et al. (2010). Comparison between symptoms and endoscopy in children with nasal obstruction. Int J Pediatr Otorhinolaryngol.
5820 Coetzee JF. (2010). Safety of pain control with morphine: New (and old) aspects of morphine pharmacokinetics and pharmacodynamics. Southern African Journal of Anaesthesia and Analgesia.
5821 Cohen PR, Tschen JA. (2010). Tonsillar actinomycosis mimicking a tonsillolith: colonization of the palantine tonsil presenting as a foul-smelling, removable, unilateral, giant tonsillar concretion. Int J Dermatol.
5822 Cohen S, Springer C, Perles Z, et al. (2010). Cardiac, lung, and brain thrombosis in a child with obstructive sleep apnea. Pediatr Pulmonol.
5823 Collins CE. (2010). Anesthesia for pediatric airway surgery: recommendations and review from a pediatric referral center. Anesthesiol Clin.
5824 Comar M, Grasso D, dal Molin G, et al. (2010). HHV-6 infection of tonsils and adenoids in children with hypertrophy and upper airway recurrent infections. Int J Pediatr Otorhinolaryngol.
5825 Contencin P, Malorgio E, Noce S, et al. (2010). Questionnaire and nocturnal oxymetry in children with adenotonsillar hypertrophy. Eur Ann Otorhinolaryngol Head Neck Dis.
5826 Cooper JD, Smith KJ, Ritchey AK. (2010). A cost-effectiveness analysis of coagulation testing prior to tonsillectomy and adenoidectomy in children. Pediatr Blood Cancer.
5827 Coppo R. (2010). Can a dysregulated mucosal immune system in IgA nephropathy be controlled by tonsillectomy?. Nephrol Dial Transplant.
5828 Corbi FC, Inaoka RJ, Felix RS, et al. (2010). Comparative expression of a set of genes to an internal housekeeping control in CDNA amplified and not amplified by PolyAPCR in non-Hodgkin's lymphoma samples obtained from fine-needle aspiration cytology. Diagn Mol Pathol.
5829 Cornejo S, Santiago BM, Breinbauer KH. (2010). Postoperative tonsillectomy pain: cold versus monopolar electrocautery technique: prospective randomized trial. Revista de Otorrinolaringologia.
5830 Daftary AS, Kotagal S. (2010). Treatment of childhood obstructive sleep apnea. Curr Treat Options Neurol.
5831 Daw Z, Padmore R, Chung A, et al. (2010). Recurrent pregnancy loss in a 33-year-old woman. Laboratory Medicine.
5832 De Oliveira SKF, Pelajo CF. (2010). Pediatric autoimmune neuropsychiatric disorders associated with streptococcal infection (PANDAS): A controversial diagnosis. Current Infectious Disease Reports.
5833 De Sanctis S, Nozzi M, Del Torto M, et al. (2010). Autoinflammatory syndromes: diagnosis and management. Ital J Pediatr.
5834 Deichmueller CM, Welkoborsky HJ. (2010). Grisel's syndrome--a rare complication following “small” operations and infections in the ENT region. Eur Arch Otorhinolaryngol.
5835 DeMarcantonio MA, Darrow DH, Gyuricsko E, et al. (2010). Obstructive sleep disorders in Prader-Willi syndrome: The role of surgery and growth hormone. Int J Pediatr Otorhinolaryngol.
5836 Demirhan H, Aksoy F, Ozturan O, et al. (2010). Medical treatment of adenoid hypertrophy with “fluticasone propionate nasal drops”. Int J Pediatr Otorhinolaryngol.
5837 Deng K, Li YN, Li GL, et al. (2010). Neural endoscopic assisted micro-invasive management of Chiari I malformation. Chin Med J (Engl).
5838 Di Rocco F, Juca CE, Arnaud E, et al. (2010). The role of endoscopic third ventriculostomy in the treatment of hydrocephalus associated with faciocraniosynostosis. J Neurosurg Pediatr.
5839 Dilek FH, Sahin O, Tokyol C, et al. (2010). Expression of cyclooxygenase-1 and 2 in chronic tonsillitis. Indian J Pathol Microbiol.
5840 Dincer N, Tezel GG, Sungur A, et al. (2010). Study of FHIT and WWOX expression in mucoepidermoid carcinoma and adenoid cystic carcinoma of salivary gland. Oral Oncol.
5841 Djurhuus BD, Faber CE, Skytthe A. (2010). Decreasing incidence rate for surgically treated middle ear cholesteatoma in Denmark 1977-2007. Dan Med Bull.
5842 Dogan B, Rota S, Gurbuzler L, et al. (2010). The correlation between EBV viral load in the palatine tonsils of patients with recurrent tonsillitis and concurrent serum titers of VCA-IgG. Eur Arch Otorhinolaryngol.
5843 Doksrod S, Lofgren B, Nordhammer A, et al. (2010). Reinforced laryngeal mask airway compared with endotracheal tube for adenotonsillectomies. Eur J Anaesthesiol.
5844 Dong YX, Meng LX, Wang Y, et al. (2010). The effect of remifentanil on the incidence of agitation on emergence from sevoflurane anaesthesia in children undergoing adenotonsillectomy. Anaesth Intensive Care.
5845 Drolet JP, Guay J, Nouhi Y, et al. (2010). Expression of semaphorin 4C by Th2-stimulated B cells. Allergy, Asthma and Clinical Immunology.
5846 Du W, Ma B, Guo Y, et al. (2010). Microdebrider vs. electrocautery for tonsillectomy: a meta-analysis. Int J Pediatr Otorhinolaryngol.
5847 Dunn AL, Cox Gill J. (2010). Adenotonsillectomy in patients with desmopressin responsive mild bleeding disorders: a review of the literature. Haemophilia.
5848 Durucu C, Baglam T, Karatas E, et al. (2010). Simultaneous mycobacterial infection of tonsil and cervical lymph node: Evidence to portal of entry. International Journal of Pediatric Otorhinolaryngology Extra.
5849 Egidi G. (2010). Recurrent tonsillitis in adults: quality of life after tonsillectomy. Not a trivial procedure. Dtsch Arztebl Int.
5850 Emmett SR, Nankivell P. (2010). Re: Audit of specifically designed adenotonsillectomy operation sheet. Clin Otolaryngol.
5851 Enoki AM, Testa JR, Morais Mde S, et al. (2010). Foreign body in the tonsillary region as a complication of tonsillectomy. Braz J Otorhinolaryngol.
5852 Ephros HD, Madani M, Yalamanchili SC. (2010). Surgical treatment of snoring & obstructive sleep apnoea. Indian J Med Res.
5853 Erdogan E, Cansever T, Secer HI, et al. (2010). The evaluation of surgical treatment options in the Chiari Malformation Type I. Turk Neurosurg.
5854 Eskiizmir G. (2010). Lingual tonsillectomy for the management of persistent obstructive sleep apnea after adenotonsillectomy in children. Otolaryngol Head Neck Surg.
5855 Esteitie R, Naclerio RM, Baroody FM. (2010). Vitamin D levels in children undergoing adenotonsillectomies. Int J Pediatr Otorhinolaryngol.
5856 Ezzat WF. (2010). Role of endoscopic nasal examination in reduction of nasopharyngeal adenoid recurrence rates. Int J Pediatr Otorhinolaryngol.
5857 Ezzat WF, Fawaz S, Abdelrazek Y. (2010). To what degree does adenotonsillectomy affect neurocognitive performance in children with obstructive sleep apnea hypopnea syndrome due to adenotonsillar enlargement?. ORL J Otorhinolaryngol Relat Spec.
5858 Faramarzi A, Heydari ST. (2010). Prevalence of Post-tonsillectomy Bleeding as Day-case Surgery with Combination Method; Cold Dissection Tonsillectomy and Bipolar Diathermy Hemostasis. Iran J Pediatr.
5859 Faramarzi A, Heydari ST. (2010). Prevalence of posttonsillectomy bleeding as daycase surgery with combination method; cold dissection tonsillectomy and bipolar diathermy hemostasis. Iranian Journal of Pediatrics.
5860 Faramarzi A, Kadivar MR, Heydari ST, et al. (2010). Assessment of the consensus about tonsillectomy and/or adenoidectomy among pediatricians and otolaryngologists. Int J Pediatr Otorhinolaryngol.
5861 Farboud A, Trinidade A, Harris M, et al. (2010). Fibroepithelial polyp of the tonsil: case report of a rare, benign tonsillar lesion. J Laryngol Otol.
5862 Farid M, Metwalli N. (2010). Computed tomographic evaluation of mouth breathers among paediatric patients. Dentomaxillofac Radiol.
5863 Feder HM, Salazar JC. (2010). A clinical review of 105 patients with PFAPA (a periodic fever syndrome). Acta Paediatr.
5864 Fekete-Szabo G, Berenyi I, Gabriella K, et al. (2010). Aerobic and anaerobic bacteriology of chronic adenoid disease in children. Int J Pediatr Otorhinolaryngol.
5865 Felstead AM, Perkins CS. (2010). Thrombosis of the internal jugular vein: A rare but important operative finding. Br J Oral Maxillofac Surg.
5866 Fennessy BG, O'Connor R, Cronin M, et al. (2010). Safety implications of the Boyle-Davis mouth gag and tracheal tube position in tonsillectomy. Br J Anaesth.
5867 Fernandes ML, Faria NC, Goncalves TF, et al. (2010). Anesthesia for tonsillectomy in a child with Klippel-Feil Syndrome associated with Down Syndrome. Case report. Rev Bras Anestesiol.
5868 Fields RG, Gencorelli FJ, Litman RS. (2010). Anesthetic management of the pediatric bleeding tonsil. Paediatr Anaesth.
5869 Fortier MA, Del Rosario AM, Rosenbaum A, et al. (2010). Beyond pain: predictors of postoperative maladaptive behavior change in children. Paediatr Anaesth.
5870 Fortier MA, Weinberg M, Vitulano LA, et al. (2010). Effects of therapeutic suggestion in children undergoing general anesthesia: a randomized controlled trial. Paediatr Anaesth.
5871 Friedman M, Wilson MN. (2010). Surgical Therapy for Sleep Breathing Disorders. Sleep Medicine Clinics.
5872 Friedman M, Wilson MN, Pulver T, et al. (2010). Screening for obstructive sleep apnea/hypopnea syndrome: subjective and objective factors. Otolaryngol Head Neck Surg.
5873 Fu B, Padgham N. (2010). ‘Raised leucocyte levels as a marker for post-tonsillectomy haemorrhage - a useful tool?’ More questions than answers. Clin Otolaryngol.
5874 Fujii Y, Itakura M. (2010). A prospective, randomized, double-blind, placebo-controlled study to assess the antiemetic effects of midazolam on postoperative nausea and vomiting in women undergoing laparoscopic gynecologic surgery. Clin Ther.
5875 Fujinaga S, Ohtomo Y, Hirano D, et al. (2010). Low-dose pulse methylprednisolone followed by short-term combination therapy and tonsillectomy for childhood IgA nephropathy. Pediatr Nephrol.
5876 Fung E, Cave D, Witmans M, et al. (2010). Postoperative respiratory complications and recovery in obese children following adenotonsillectomy for sleep-disordered breathing: a case-control study. Otolaryngol Head Neck Surg.
5877 Fusco FR, Pompa A, Bernardi G, et al. (2010). A case of PANDAS treated with tetrabenazine and tonsillectomy. J Child Neurol.
5878 Gadani HN, Chaudhary VP. (2010). Comparative study of the analgesic efficacy of rectal tramadol versus intravenous tramadol for adult tonsillectomy. Anesthesia, Essays and Researches.
5879 Gajjar P, Sinclair P, McCulloch M. (2010). Case report a case of microscopic polyangiitis. Current Allergy and Clinical Immunology.
5880 Galarza M, Martinez-Lage JF, Ham S, et al. (2010). Cerebral anomalies and Chiari type 1 malformation. Pediatr Neurosurg.
5881 Gallagher TQ, Wilcox L, McGuire E, et al. (2010). Analyzing factors associated with major complications after adenotonsillectomy in 4776 patients: comparing three tonsillectomy techniques. Otolaryngol Head Neck Surg.
5882 Galvan-Montano A, Reyes-Garcia G, Suarez-Roa Mde L, et al. (2010). Effective analgesic between acetominophen + B vitamins vs. acetominophen in pediatric ambulatory surgery. Cir Cir.
5883 Garg R, Hariharan UR, Sood R, et al. (2010). Perioperative anesthetic concerns in a child with systemic onset juvenile idiopathic arthritis syndrome. Paediatr Anaesth.
5884 Gearry RB, Richardson AK, Frampton CM, et al. (2010). Population-based cases control study of inflammatory bowel disease risk factors. J Gastroenterol Hepatol.
5885 Geibprasert S, Krings T, Armstrong D, et al. (2010). Predicting factors for the follow-up outcome and management decisions in vein of Galen aneurysmal malformations. Childs Nerv Syst.
5886 Ghabach B, Anderson WF, Curtis RE, et al. (2010). Adenoid cystic carcinoma of the breast in the United States (1977 to 2006): a population-based cohort study. Breast Cancer Res.
5887 Ghosh-Ray S, Kotecha B, Chawda S. (2010). Radiological appearances of oropharyngeal soft tissue reduction with bipolar radio-frequency treatment in sleep disordered breathing: A pilot study. Neuroradiology Journal.
5888 Gkouskou KK, Vlastos IM, Hajiioannou I, et al. (2010). Dietary habits of preschool aged children with tonsillar hypertrophy, pre- and post-operatively. Eur Rev Med Pharmacol Sci.
5889 Glazebrook KN, Reynolds C, Smith RL, et al. (2010). Adenoid cystic carcinoma of the breast. AJR Am J Roentgenol.
5890 Goldbart AD, Levitas A, Greenberg-Dotan S, et al. (2010). B-type natriuretic peptide and cardiovascular function in young children with obstructive sleep apnea. Chest.
5891 Goto F, Asama Y, Ogawa K. (2010). Sho-saiko-to-ka-kikyo-sekko as an alternative treatment for chronic tonsillitis to avoid surgery. Complement Ther Clin Pract.
5892 Gozal D, Kheirandish-Gozal L. (2010). New approaches to the diagnosis of sleep-disordered breathing in children. Sleep Med.
5893 Gozal D, Serpero LD, Kheirandish-Gozal L, et al. (2010). Sleep measures and morning plasma TNF-alpha levels in children with sleep-disordered breathing. Sleep.
5894 Granath A, Norrby-Teglund A, Uddman R, et al. (2010). Reduced iNOS expression in adenoids from children with otitis media with effusion. Pediatr Allergy Immunol.
5895 Granath A, Uddman R, Cardell LO. (2010). Increased TLR7 expression in the adenoids among children with otitis media with effusion. Acta Otolaryngol.
5896 Granzotto EH, Aquino FV, Flores JA, et al. (2010). Tonsil size as a predictor of cardiac complications in children with sleep-disordered breathing. Laryngoscope.
5897 Green B, Chandler S, MacDonald G, et al. (2010). Quantifying pain relief following administration of a novel formulation of paracetamol (acetaminophen). Journal of clinical pharmacology.
5898 Gustavii N, Bove M, Dahlin C. (2010). Postoperative morbidity in traditional versus coblation tonsillectomy. Ann Otol Rhinol Laryngol.
5899 Halme PR, Antila J, Antila H, et al. (2010). Uvulopalatopharyngoplasty with an ultrasound scalpel or laser: is there a difference?. Eur Arch Otorhinolaryngol.
5900 Hao L, Xiao-lin N, Qi C, et al. (2010). Nerve growth factor and vascular endothelial growth factor: retrospective analysis of 63 patients with salivary adenoid cystic carcinoma. Int J Oral Sci.
5901 Haque SA, Kallakury B, Shad A, et al. (2010). A 5-year old male with “leukemic form” of disseminated post-transplant lymphoproliferative disorder. Pediatric Reports.
5902 Hashemian F, Farahani F, Sanatkar M. (2010). Changes in growth pattern after adenotonsillectomy in children under 12 years old. Acta Med Iran.
5903 Heiser C, Landis BN, Giger R, et al. (2010). Taste disturbance following tonsillectomy--a prospective study. Laryngoscope.
5904 Heiss JD, Suffredini G, Smith R, et al. (2010). Pathophysiology of persistent syringomyelia after decompressive craniocervical surgery. Clinical article. J Neurosurg Spine.
5905 Hentschel SJ, Vora Y, Suki D, et al. (2010). Malignant tumors of the anterolateral skull base. Neurosurgery.
5906 Hervey-Jumper SL, Ghori AK, Quint DJ, et al. (2010). Cerebrospinal fluid leak with recurrent meningitis following tonsillectomy. J Neurosurg Pediatr.
5907 Hetzler D. (2010). In reference to histologic assessment of thermal injury to tonsillectomy specimens: a comparison of electrocautery, coblation, harmonic scalpel, and tonsillotome. Laryngoscope.
5908 Heywood RL, Khalil HM, Kothari S, et al. (2010). Radiological airway changes following bipolar radiofrequency volumetric tissue reduction. J Laryngol Otol.
5909 Hoa M, Syamal M, Schaeffer MA, et al. (2010). Biofilms and chronic otitis media: an initial exploration into the role of biofilms in the pathogenesis of chronic otitis media. Am J Otolaryngol.
5910 Hodgson NC, Lytwyn A, Bacopulos S, et al. (2010). Adenoid cystic breast carcinoma: high rates of margin positivity after breast conserving surgery. Am J Clin Oncol.
5911 Honings J, Gaissert HA, Weinberg AC, et al. (2010). Prognostic value of pathologic characteristics and resection margins in tracheal adenoid cystic carcinoma. Eur J Cardiothorac Surg.
5912 Hopkins C, Fairley J, Yung M, et al. (2010). The 14-item Paediatric Throat Disorders Outcome Test: a valid, sensitive, reliable, parent-reported outcome measure for paediatric throat disorders. J Laryngol Otol.
5913 Horcasitas R. (2010). Pre-incisional infiltration for pediatric tonsillectomy. Otolaryngology - Head and Neck Surgery.
5914 Howard K, Lo E, Sheppard S, et al. (2010). Behavior and quality of life measures after anesthesia for tonsillectomy or ear tube insertion in children. Paediatr Anaesth.
5915 Huang H, Peng Y, Liu H, et al. (2010). Decreased CD4+CD25+ cells and increased dimeric IgA-producing cells in tonsils in IgA nephropathy. J Nephrol.
5916 Huang WT, Lee PI, Chang LY, et al. (2010). Epidemic pleurodynia caused by coxsackievirus B3 at a medical center in northern Taiwan. J Microbiol Immunol Infect.
5917 Hubbard BA, Rice GB, Muzaffar AR. (2010). Adenoid involvement in velopharyngeal closure in children with cleft palate. Can J Plast Surg.
5918 Hug M, Dorner M, Frohlich FZ, et al. (2010). Pediatric epstein-barr virus carriers with or without tonsillar enlargement may substantially contribute to spreading of the virus. J Infect Dis.
5919 Hydri AS, Malik SM. (2010). Reduced mouth opening following tonsillectomy in children: myth or reality. J Coll Physicians Surg Pak.
5920 Hydri AS, Malik SM. (2010). Post-tonsillectomy pain and bupivacaine, an intra individual design study. J Coll Physicians Surg Pak.
5921 Iio K, Nagasawa Y, Iwatani H, et al. (2010). Microarray analysis of tonsils in immunoglobulin A nephropathy patients. Biochem Biophys Res Commun.
5922 Inoue T, Sugiyama H, Hiki Y, et al. (2010). Differential expression of glycogenes in tonsillar B lymphocytes in association with proteinuria and renal dysfunction in IgA nephropathy. Clin Immunol.
5923 Irving ND, Lim JH, Cohen B, et al. (2010). Sturge-Weber syndrome: ear, nose, and throat issues and neurologic status. Pediatr Neurol.
5924 Ishak AI, Mohd Yunus MR, Ami M, et al. (2010). Role of panendoscopy and biopsy in cervical lymph node metastasis with unknown primary: A tertiary center experience. Rawal Medical Journal.
5925 Isik M, Aksoy S, Dede DS, et al. (2010). Clinical and pathological characteristics of breast cancer patients with history of tonsillectomy. Breast.
5926 Iyengar P, Mazloom A, Shihadeh F, et al. (2010). Hodgkin lymphoma involving extranodal and nodal head and neck sites: characteristics and outcomes. Cancer.
5927 Iyer NG, Kim L, Nixon IJ, et al. (2010). Factors predicting outcome in malignant minor salivary gland tumors of the oropharynx. Arch Otolaryngol Head Neck Surg.
5928 Izu SC, Itamoto CH, Pradella-Hallinan M, et al. (2010). Obstructive sleep apnea syndrome (OSAS) in mouth breathing children. Braz J Otorhinolaryngol.
5929 Jacobs K, Jorissen M, Lemkens P. (2010). Current Belgian adenotonsillectomy practice: a survey among Belgian ENT specialists. B-ENT.
5930 Jain P, Ward M, Hasnaa IK, et al. (2010). Guillotine vs dissection tonsillectomy: A prospective study. Otolaryngology - Head and Neck Surgery.
5931 Jefferson Y. (2010). Mouth breathing: adverse effects on facial growth, health, academics, and behavior. Gen Dent.
5932 Jesic S, Stojiljkovic L, Stosic S, et al. (2010). Enzymatic study of tonsil tissue alkaline and acid phosphatase in children with recurrent tonsillitis and tonsil hypertrophy. Int J Pediatr Otorhinolaryngol.
5933 Jimenez N, Seidel K, Martin LD, et al. (2010). Perioperative analgesic treatment in Latino and non-Latino pediatric patients. J Health Care Poor Underserved.
5934 Johnston DR, Gaslin M, Boon M, et al. (2010). Postoperative complications of powered intracapsular tonsillectomy and monopolar electrocautery tonsillectomy in teens versus adults. Ann Otol Rhinol Laryngol.
5935 Jonsson AM, Papadogiannakis N, Granath A, et al. (2010). Maternal microchimerism in juvenile tonsils and adenoids. Pediatr Res.
5936 Jorgensen GH, Arnlaugsson S, Theodors A, et al. (2010). Immunoglobulin A deficiency and oral health status: a case-control study. J Clin Periodontol.
5937 Joseph J, Jaberoo MC, Dilkes M. (2010). Holmium:YAG laser: 12-year study of indications for use and outcomes in benign and malignant otolaryngological conditions. J Laryngol Otol.
5938 Joseph J, Stephens J, Scott D. (2010). Raised leucocyte levels as a marker for post-tonsillectomy haemorrhage - a useful tool?. Clin Otolaryngol.
5939 Joseph JA, Jaberoo MC, Sandison A, et al. (2010). Benign schwannoma of the tonsil. BMJ Case Rep.
5940 Jounio U, Juvonen R, Bloigu A, et al. (2010). Pneumococcal carriage is more common in asthmatic than in non-asthmatic young men. Clin Respir J.
5941 Junqueira P, Marchesan IQ, de Oliveira LR, et al. (2010). Speech-language pathology findings in patients with mouth breathing: multidisciplinary diagnosis according to etiology. Int J Orofacial Myology.
5942 Juszkat R, Korytowska A, Lukomska Z, et al. (2010). Facial artery pseudoaneurysm and severe bleeding after tonsillectomy - Endovascular treatment with PVA particle embolization. Polish Journal of Radiology.
5943 Kaditis AG, Kalampouka E, Hatzinikolaou S, et al. (2010). Associations of tonsillar hypertrophy and snoring with history of wheezing in childhood. Pediatr Pulmonol.
5944 Kalcioglu MT, Gurses I, Erdem T. (2010). Is the pathological examination of routine tonsillectomy and adenoidectomy specimens necessary? A retrospective study of 559 adenoidectomy and 1132 tonsillectomy specimens and a literature review. B-ent.
5945 Kalorin CM, Mouzakes J, Gavin JP, et al. (2010). Tonsillectomy does not improve bedwetting: Rresults of a prospective controlled trial. Journal of urology.
5946 Kalorin CM, Mouzakes J, Gavin JP, et al. (2010). Tonsillectomy does not improve bedwetting: results of a prospective controlled trial. J Urol.
5947 Kalu SU, Hall MC. (2010). A study of clinician adherence to treatment guidelines for otitis media with effusion. WMJ.
5948 Kane K. (2010). The surgical art of Barbara Hepworth and the Garnett Passe and Rodney Williams foundation. ANZ J Surg.
5949 Kara MI, Goze F, Ezirganli S, et al. (2010). Neoplasms of the salivary glands in a Turkish adult population. Med Oral Patol Oral Cir Bucal.
5950 Kasperska-Zajac A, Czecior E, Namyslowski G. (2010). Effect of tonsillectomy on the level of exhaled nitric oxide (NO) in patients with recurrent tonsillitis. Respir Med.
5951 Katz ES, D'Ambrosio CM. (2010). Pediatric obstructive sleep apnea syndrome. Clin Chest Med.
5952 Katzenell U, Bakshi E, Ashkenazi I, et al. (2010). A retrospective study of the eligibility for tonsillectomy. Isr Med Assoc J.
5953 Kawaguchi T, Ieiri N, Yamazaki S, et al. (2010). Clinical effectiveness of steroid pulse therapy combined with tonsillectomy in patients with immunoglobulin A nephropathy presenting glomerular haematuria and minimal proteinuria. Nephrology (Carlton).
5954 Keene S, Mohon R, Samples D, et al. (2010). BMI Percentile a potential tool for predicting pediatric obstructive sleep apnea. Canadian Journal of Respiratory Therapy.
5955 Kelley PM, Tempero RM. (2010). Lymphatic vessel hypertrophy in inflamed human tonsils. Lymphat Res Biol.
5956 Kezirian EJ, Malhotra A, Goldberg AN, et al. (2010). Changes in obstructive sleep apnea severity, biomarkers, and quality of life after multilevel surgery. Laryngoscope.
5957 Kezirian EJ, White DP, Malhotra A, et al. (2010). Interrater reliability of drug-induced sleep endoscopy. Arch Otolaryngol Head Neck Surg.
5958 Khalyfa A, Gharib SA, Kim J, et al. (2010). Transcriptomic analysis identifies phosphatases as novel targets for adenotonsillar hypertrophy of pediatric obstructive sleep apnea. Am J Respir Crit Care Med.
5959 Khan SU, Kenefick C, O'Leary G, et al. (2010). Non-Hodgkin lymphoma presenting as bilateral tonsillar hypertrophy: case report. Ear Nose Throat J.
5960 Kiernan F, Crowe S. (2010). Malpuech syndrome: implications for anesthetic management. Paediatr Anaesth.
5961 Kilpatrick LA, Kline RM, Hufnagle KE, et al. (2010). Postoperative management following sphincter pharyngoplasty. Otolaryngol Head Neck Surg.
5962 Kim IK, Wang KC, Kim IO, et al. (2010). Chiari 1.5 malformation : an advanced form of Chiari I malformation. J Korean Neurosurg Soc.
5963 Kim SY, Kang JH, Chun SH, et al. (2010). Interdigitating dendritic cell sarcoma of the tonsil. Asia Pac J Clin Oncol.
5964 Kim YS, Hong SJ, Choi J, et al. (2010). Spontaneous tonsillar hemorrhage and post-tonsillectomy hemorrhage. Clin Exp Otorhinolaryngol.
5965 Kiris M, Muderris T, Celebi S, et al. (2010). Changes in serum IGF-1 and IGFBP-3 levels and growth in children following adenoidectomy, tonsillectomy or adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
5966 Klemetti S, Kinnunen I, Suominen T, et al. (2010). Active preoperative nutrition is safely implemented by the parents in pediatric ambulatory tonsillectomy. Ambulatory surgery.
5967 Klemetti S, Kinnunen I, Suominen T, et al. (2010). The effect of preoperative fasting on postoperative thirst, hunger and oral intake in paediatric ambulatory tonsillectomy. J Clin Nurs.
5968 Klemetti S, Kinnunen I, Suominen T, et al. (2010). The effect of preoperative nutritional face-to-face counseling about child's fasting on parental knowledge, preoperative need-for-information, and anxiety, in pediatric ambulatory tonsillectomy. Patient Educ Couns.
5969 Klingenberg B, Hafkamp HC, Haesevoets A, et al. (2010). p16 INK4A overexpression is frequently detected in tumour-free tonsil tissue without association with HPV. Histopathology.
5970 Kohler MJ, Lushington K, Kennedy JD. (2010). Neurocognitive performance and behavior before and after treatment for sleep-disordered breathing in children. Nat Sci Sleep.
5971 Kojima M, Nakamura N, Murayama K, et al. (2010). Reactive lymphoid hyperplasia with giant follicles associated with a posttherapeutic state of hematological malignancies. A report of eight cases. Tumori.
5972 Kokki H. (2010). Ketoprofen pharmacokinetics, efficacy, and tolerability in pediatric patients. Paediatr Drugs.
5973 Kolo ES, Salisu AD, Tabari AM, et al. (2010). Plain radiographic evaluation of the nasopharynx: do raters agree?. Int J Pediatr Otorhinolaryngol.
5974 Kostrzewa JP, Sunde J, Riley KO, et al. (2010). Radiofrequency coblation decreases blood loss during endoscopic sinonasal and skull base tumor removal. ORL J Otorhinolaryngol Relat Spec.
5975 Kumbar S. (2010). Vicarious liability - Medicolegal status of anaesthesiologist. Indian Journal of Anaesthesia.
5976 Kuppersmith RB, Schams ST, Rosenfeld RM. (2010). Extracts from The Cochrane Library: Tonsillectomy for periodic fever, aphthous stomatitis, pharyngitis and cervical adenitis syndrome (PFAPA). Otolaryngol Head Neck Surg.
5977 Kusano K, Inokuchi A, Fujimoto K, et al. (2010). Coccoid Helicobacter pylori exists in the palatine tonsils of patients with IgA nephropathy. J Gastroenterol.
5978 Kvaerner KJ, Kristiansen HA, Russell MB. (2010). Otitis media history, surgery and allergy in 60-year perspective: a population-based study. Int J Pediatr Otorhinolaryngol.
5979 Leboulanger N, Roger G, Genty E, et al. (2010). Management of pharyngeal stenosis following tonsillectomy with local injection of steroids: Case report and literature review. International Journal of Pediatric Otorhinolaryngology Extra.
5980 Lee CJ, Lee SE, Oh MK, et al. (2010). The effect of propofol on emergence agitation in children receiving sevoflurane for adenotonsillectomy. Korean J Anesthesiol.
5981 Lee YS, Kim WY, Choi JH, et al. (2010). The effect of ketamine on the incidence of emergence agitation in children undergoing tonsillectomy and adenoidectomy under sevoflurane general anesthesia. Korean J Anesthesiol.
5982 Leikola J, Koljonen V, Valanne L, et al. (2010). The incidence of Chiari malformation in nonsyndromic, single suture craniosynostosis. Childs Nerv Syst.
5983 Lemkens N, Lemkens P, Egondi TW, et al. (2010). Antibiotic use and doctor visits are reduced after adenotonsillectomy. B-ENT.
5984 Leonard DS, Fenton JE, Hone S. (2010). ABO blood type as a risk factor for secondary post-tonsillectomy haemorrhage. Int J Pediatr Otorhinolaryngol.
5985 Leong SC, Kubba H, White PS. (2010). A review of outcomes following inferior turbinate reduction surgery in children for chronic nasal obstruction. Int J Pediatr Otorhinolaryngol.
5986 Lertsburapa K, Schroeder JW, Sullivan C. (2010). Assessment of adenoid size: A comparison of lateral radiographic measurements, radiologist assessment, and nasal endoscopy. Int J Pediatr Otorhinolaryngol.
5987 Li AM, Au CT, Ng SK, et al. (2010). Natural history and predictors for progression of mild childhood obstructive sleep apnoea. Thorax.
5988 Li AM, Au CT, So HK, et al. (2010). Prevalence and risk factors of habitual snoring in primary school children. Chest.
5989 Li AM, Ng C, Ng SK, et al. (2010). Adipokines in children with obstructive sleep apnea and the effects of treatment. Chest.
5990 Li AM, So HK, Au CT, et al. (2010). Epidemiology of obstructive sleep apnoea syndrome in Chinese children: a two-phase community study. Thorax.
5991 Liess BD, Mytyk C, Calhoun KH, et al. (2010). Tonsillectomy for the treatment of tonsillitis-induced immunoglobulin A nephropathy. Am J Otolaryngol.
5992 Lin HC, Wu PY, Friedman M, et al. (2010). Difference of Helicobacter pylori colonization in recurrent inflammatory and simple hyperplastic tonsil tissues. Arch Otolaryngol Head Neck Surg.
5993 Lin WN, Wang R, Cheong EC, et al. (2010). Use of hemisphincter pharyngoplasty in the management of velopharyngeal insufficiency after pharyngeal flap: an outcome study. Ann Plast Surg.
5994 Lipsitz JD, Zimmerman D, Kovalski N, et al. (2010). Chief complaints and diagnoses of displaced Israelis seeking medical treatment during the 2006 Israel-Lebanon War. Am J Disaster Med.
5995 Lock C, Baker R, Brittain K. (2010). ‘I've just taken you to see the man with the CD on his head’: the experience and management of recurrent sore throat in children. J Child Health Care.
5996 Lofstrand-Tidestrom B, Hultcrantz E. (2010). Development of craniofacial and dental arch morphology in relation to sleep disordered breathing from 4 to 12 years. Effects of adenotonsillar surgery. Int J Pediatr Otorhinolaryngol.
5997 Loghmanee DA, Sheldon SH. (2010). Pediatric obstructive sleep apnea: an update. Pediatr Ann.
5998 Loyo M, Rivas A, Brown D. (2010). Lipoblastoma: A rare soft palate mass. International Journal of Pediatric Otorhinolaryngology Extra.
5999 Lundkvist K, Friberg D. (2010). Pharyngeal disturbances in OSAS patients before and 1 year after UPPP. Acta Otolaryngol.
6000 Magill JC, Ferguson MS, Butler CR, et al. (2010). Inflammatory myofibroblastic tumour of the tonsil: case report and literature review. J Laryngol Otol.
6001 Mandel JE. (2010). Laryngeal mask airways in ear, nose, and throat procedures. Anesthesiol Clin.
6002 Mangiardi J, Graw-Panzer KD, Weedon J, et al. (2010). Polysomnography outcomes for partial intracapsular versus total tonsillectomy. Int J Pediatr Otorhinolaryngol.
6003 Marchisio P, Torretta S, Capaccio P, et al. (2010). Clinical assessment of adenoidal obstruction based on the nasal obstruction index is no longer useful in children. Otolaryngol Head Neck Surg.
6004 Marom T, Cinamon U, Itskoviz D, et al. (2010). Changing trends of peritonsillar abscess. Am J Otolaryngol.
6005 Maskell S, Cross G, Gluckman P. (2010). The internet and informed dissent. Lancet.
6006 Mattila PS, Hammaren-Malmi S, Saxen H, et al. (2010). Adenoidectomy and nasopharyngeal carriage of Streptococcus pneumoniae in young children. Arch Dis Child.
6007 Maurer JT. (2010). Surgical treatment of obstructive sleep apnea: standard and emerging techniques. Curr Opin Pulm Med.
6008 McCarthy GC, Megalla SA, Habib AS. (2010). Impact of intravenous lidocaine infusion on postoperative analgesia and recovery from surgery: a systematic review of randomized controlled trials. Drugs.
6009 McCoul ED. (2010). Legacies of the Tonsil Hospital. Otolaryngol Head Neck Surg.
6010 McGlaughlin KL, Witherow H, Dunaway DJ, et al. (2010). Spectrum of Antley-Bixler syndrome. J Craniofac Surg.
6011 Melink S, Vagner MV, Hocevar-Boltezar I, et al. (2010). Posterior crossbite in the deciduous dentition period, its relation with sucking habits, irregular orofacial functions, and otolaryngological findings. Am J Orthod Dentofacial Orthop.
6012 Meszaros D, Dharmage SC, Matheson MC, et al. (2010). Poor lung function and tonsillectomy in childhood are associated with mortality from age 18 to 44. Respir Med.
6013 Migita M, Gocho Y, Ueda T, et al. (2010). An 8-year-old girl with a recurrence of obstructive sleep apnea syndrome caused by hypertrophy of tubal tonsils 4 years after adenotonsillectomy. J Nippon Med Sch.
6014 Minocha A, Bollineni D, Johnson WD, et al. (2010). Racial differences in general health, suicidal thoughts, physical and sexual abuse in African-Americans and Caucasians with irritable bowel syndrome. South Med J.
6015 Mitke YB. (2010). Bloody traditional procedures performed during infancy in the oropharyngeal area among HIV+ children: implication from the perspective of mother-to-child transmission of HIV. AIDS Behav.
6016 Mohammadianpanah M, Daneshbod Y, Ramzi M, et al. (2010). Primary tonsillar lymphomas according to the new World Health Organization classification: to report 87 cases and literature review and analysis. Ann Hematol.
6017 Moonim MT, Alarcon L, Freeman J, et al. (2010). Identifying HIV infection in diagnostic histopathology tissue samples--the role of HIV-1 p24 immunohistochemistry in identifying clinically unsuspected HIV infection: a 3-year analysis. Histopathology.
6018 Mora R, Dellepiane M, Crippa B, et al. (2010). Ribosomal therapy in the treatment of recurrent acute adenoiditis. Eur Arch Otorhinolaryngol.
6019 Morandi F, Ferretti E, Bocca P, et al. (2010). A novel mechanism of soluble HLA-G mediated immune modulation: downregulation of T cell chemokine receptor expression and impairment of chemotaxis. PLoS One.
6020 Mowafi HA, Ismail SA. (2010). Preoperative peritonsillar lornoxicam infiltration is not superior to intravenous lornoxicam for pain relief following tonsillectomy in adults. European journal of anaesthesiology.
6021 Mowry SE, Ament M, Shapiro NL. (2010). Lingual tonsil hypertrophy causing severe dysphagia: treatment with plasma-mediated radiofrequency-based ablation (Coblation). Ear Nose Throat J.
6022 Mozet C. (2010). Efficacy of FloSeal in adults undergoing tonsillectomy. Otolaryngology - Head and Neck Surgery.
6023 Naiboglu B, Kulekci S, Kalaycik C, et al. (2010). Improvement in quality of life by adenotonsillectomy in children with adenotonsillar disease. Clin Otolaryngol.
6024 Najafi N, Velde A, Poelaert J. (2010). A randomized controlled trial to reduce postoperative pain in children undergoing tonsillectomy using aroundthe-clock analgesic administration by written vs verbal discharge instructions to parents. Paediatric anaesthesia.
6025 Neiva FC, Vieira FMJ, Figueiredo CR, et al. (2010). Therapeutic laser for pain relief after tonsillectomy. [Portuguese, English]. Revista Paulista de Pediatria.
6026 Nemati S, Banan R, Kousha A. (2010). Bipolar radiofrequency tonsillotomy compared with traditional cold dissection tonsillectomy in adults with recurrent tonsillitis. Otolaryngol Head Neck Surg.
6027 Nepal A, Chettri ST, Joshi RR, et al. (2010). Primary salivary gland tumors in eastern Nepal tertiary care hospital. J Nepal Health Res Counc.
6028 Nery Cde G, Buranello FS, Pereira C, et al. (2010). Otitis media with effusion and dental occlusion: is there any relationship?. Eur J Paediatr Dent.
6029 Ng DK, Wong JC, Chan CH, et al. (2010). Ambulatory blood pressure before and after adenotonsillectomy in children with obstructive sleep apnea. Sleep Med.
6030 Ng SK, Lee DL, Li AM, et al. (2010). Reproducibility of clinical grading of tonsillar size. Arch Otolaryngol Head Neck Surg.
6031 Nguyen NP, Ly BH, Betz M, et al. (2010). Importance of age as a prognostic factor for tonsillar carcinoma. Ann Surg Oncol.
6032 Norheim AJ, Liodden I, Howley M. (2010). Implementation of acupuncture and acupressure under surgical procedures in children: a pilot study. Acupunct Med.
6033 Nunes WR, Di Francesco RC. (2010). Variation of patterns of malocclusion by site of pharyngeal obstruction in children. Arch Otolaryngol Head Neck Surg.
6034 Obeso S, Rodrigo JP, Sanchez R, et al. (2010). Antibiotic prophylaxis in otolaryngologic surgery. Acta Otorrinolaringol Esp.
6035 Olutoye OA, Glover CD, Diefenderfer JW, et al. (2010). The effect of intraoperative dexmedetomidine on postoperative analgesia and sedation in pediatric patients undergoing tonsillectomy and adenoidectomy. Anesth Analg.
6036 Omurzakova NA, Yamano Y, Saatova GM, et al. (2010). Prevalence of Group A b-Hemolytic Streptococcus Among Children with Tonsillopharyngitis in Kyrgyzstan: The Difficulty of Diagnostics and Therapy. Open Rheumatol J.
6037 Orji FT, Okolugbo NE, Ezeanolue BC. (2010). The role of adenoidal obstruction in the pathogenesis of otitis media with effusion in Nigerian children. Niger J Med.
6038 Oron Y, Marom T, Russo E, et al. (2010). Don't overlook the complications of tonsillectomy. J Fam Pract.
6039 Ostrower ST, Fischer TC, Smith RV, et al. (2010). Gene expression in the oropharynx of children exposed to secondhand smoke. Laryngoscope.
6040 Ota T, Ota K, Jono H, et al. (2010). Midkine expression in malignant salivary gland tumors and its role in tumor angiogenesis. Oral Oncol.
6041 Ozer E, Bapna S, Agrawal A, et al. (2010). Maxillary removal and reinsertion: a favorable approach for extensive anterior cranial base tumors. Otolaryngol Head Neck Surg.
6042 Ozmen S, Ozmen OA. (2010). Hot saline irrigation for control of intraoperative bleeding in adenoidectomy: a randomized controlled trial. Otolaryngol Head Neck Surg.
6043 Paal P, Niederklapfer T, Keller C, et al. (2010). Head-position angles in children for opening the upper airway. Resuscitation.
6044 Page C, Chassery G, Boute P, et al. (2010). Immediate tonsillectomy: indications for use as first-line surgical management of peritonsillar abscess (quinsy) and parapharyngeal abscess. J Laryngol Otol.
6045 Pagella F, Pusateri A, Matti E, et al. (2010). Transoral endonasal-controlled combined adenoidectomy (TECCA). Laryngoscope.
6046 Paloheimo MP, Sahanne S, Uutela KH. (2010). Autonomic nervous system state: the effect of general anaesthesia and bilateral tonsillectomy after unilateral infiltration of lidocaine. Br J Anaesth.
6047 Panasiuk L, Lukas W, Paprzycki P, et al. (2010). Antibiotics in the treatment of upper respiratory tract infections in Poland. Is there any improvement? J Clin Pharm Ther.
6048 Parray T, Shah S, Apuya JS, et al. (2010). Atypical presentation of an impacted radiolucent esophageal foreign body. J Anesth.
6049 Patel A, Davidson M, Tran MC, et al. (2010). Dexmedetomidine infusion for analgesia and prevention of emergence agitation in children with obstructive sleep apnea syndrome undergoing tonsillectomy and adenoidectomy. Anesth Analg.
6050 Peridis S, Koudoumnakis E, Theodoridis A, et al. (2010). Surgical outcomes and histology findings after tonsillectomy in children with periodic fever, aphthous stomatitis, pharyngitis, and cervical adenitis syndrome. Am J Otolaryngol.
6051 Peridis S, Pilgrim G, Koudoumnakis E, et al. (2010). PFAPA syndrome in children: A meta-analysis on surgical versus medical treatment. Int J Pediatr Otorhinolaryngol.
6052 Piacentini GL, Peroni DG, Blasi F, et al. (2010). Atypical bacteria in adenoids and tonsils of children requiring adenotonsillectomy. Acta Otolaryngol.
6053 Piccoli A, Codognotto M, Tabbi MG, et al. (2010). Influence of tonsillectomy on the progression of mesangioproliferative glomerulonephritis. Nephrol Dial Transplant.
6054 Pieters BJ, Penn E, Nicklaus P, et al. (2010). Emergence delirium and postoperative pain in children undergoing adenotonsillectomy: a comparison of propofol vs sevoflurane anesthesia. Paediatr Anaesth.
6055 Pinho-Apezzato ML, Tannuri U, Tannuri AC, et al. (2010). Multiple clinical presentations of lymphoproliferative disorders in pediatric liver transplant recipients: a single-center experience. Transplant Proc.
6056 Pintucci JP, Corno S, Garotta M. (2010). Biofilms and infections of the upper respiratory tract. Eur Rev Med Pharmacol Sci.
6057 Popova D, Varbanova S, Popov TM. (2010). Comparison between myringotomy and tympanostomy tubes in combination with adenoidectomy in 3-7-year-old children with otitis media with effusion. Int J Pediatr Otorhinolaryngol.
6058 Powell S, Kubba H, O'Brien C, et al. (2010). Paediatric obstructive sleep apnoea. Clin Otolaryngol.
6059 Prager JD, Hopkins BS, Propst EJ, et al. (2010). Oropharyngeal stenosis: a complication of multilevel, single-stage upper airway surgery in children. Arch Otolaryngol Head Neck Surg.
6060 Prim MP, De Diego JI, Garcia-Bermudez C, et al. (2010). A method to calculate the volume of palatine tonsils. Anat Rec (Hoboken).
6061 Prokopakis EP, Lachanas VA, Vardouniotis AS, et al. (2010). The use of the Ligasure vessel sealing system in head and neck surgery: a report on six years of experience and a review of the literature. B-ent.
6062 Pushpanathan E, Sultan N, Sultan P. (2010). Anaesthesia for the bleeding tonsil. Br J Hosp Med (Lond).
6063 Rabbani MZ, Khan MN, Qureshi R, et al. (2010). Does the added benefit of ondansetron over dexamethasone, to control post-operative nausea and vomiting, justify the added cost in patients undergoing tonsillectomy and adenotonsillectomy?. J Pak Med Assoc.
6064 Rabiei S, Rahimi M, Ebrahimi A. (2010). Coblation assisted excision of lingual thyroid. Indian J Otolaryngol Head Neck Surg.
6065 Raghavendran S, Bagry H, Detheux G, et al. (2010). An anesthetic management protocol to decrease respiratory complications after adenotonsillectomy in children with severe sleep apnea. Anesth Analg.
6066 Ramadan HH, Terrell AM. (2010). Balloon catheter sinuplasty and adenoidectomy in children with chronic rhinosinusitis. Ann Otol Rhinol Laryngol.
6067 Randall DA. (2010). Taste impairment following tonsillectomy and adenoidectomy: an unusual complication. Ear Nose Throat J.
6068 Rhodes JL, Kolar JC, Fearon JA. (2010). Mercedes Benz pattern craniosynostosis. Plast Reconstr Surg.
6069 Rice A, Costy-Bennett S, Goodwin JL, et al. (2010). Control of breathing in children with mild sleep apnoea: a 6-year follow-up study. Eur Respir J.
6070 Rodriguez KD, Sun GH, Pike F, et al. (2010). Post-tonsillectomy bleeding in children with von Willebrand disease: a single-institution experience. Otolaryngol Head Neck Surg.
6071 Roeser MM, Alon EE, Olsen KD, et al. (2010). Synchronous bilateral tonsil squamous cell carcinoma. Laryngoscope.
6072 Rogers VE, Lewin DS, Winnie GB, et al. (2010). Polysomnographic characteristics of a referred sample of children with sickle cell disease. J Clin Sleep Med.
6073 Rothera M. (2010). BAPO response to Des Spence. Bmj.
6074 Rudra A, Ray M, Sengupta S, et al. (2010). Obstructive sleep apnoea syndrome in children and anaesthesia. Indian J Anaesth.
6075 Sadhasivam S, Cohen LL, Hosu L, et al. (2010). Real-time assessment of perioperative behaviors in children and parents: development and validation of the perioperative adult child behavioral interaction scale. Anesth Analg.
6076 Sahaya K, Patel NC. (2010). Venous sinus thrombosis and consumptive coagulopathy: a role for heparin?. Pediatr Neurol.
6077 Saikia L, Nath R, Saikia NJ, et al. (2010). A diphtheria outbreak in Assam, India. Southeast Asian J Trop Med Public Health.
6078 Salem A, Healy S, Pau H. (2010). Management of spontaneous tonsillar bleeding: review. J Laryngol Otol.
6079 Saliba I, El Khatib N, Quintal MC, et al. (2010). Tonsillar hairy polyp. J Otolaryngol Head Neck Surg.
6080 Sanchez-Luceros A, Meschengieser SS, Woods AI, et al. (2010). Biological and clinical response to desmopressin (DDAVP) in a retrospective cohort study of children with low von Willebrand factor levels and bleeding history. Thromb Haemost.
6081 Santos RR, Damasceno RW, de Pontes FS, et al. (2010). Ten-year follow-up of a case series of primary epithelial neoplasms of the lacrimal gland: clinical features, surgical treatment and histopathological findings. Arq Bras Oftalmol.
6082 Sarkar S, Roychoudhury A, Roychaudhuri BK. (2010). Foreign bodies in ENT in a teaching hospital in Eastern India. Indian J Otolaryngol Head Neck Surg.
6083 Sasi S, Larrier DR, Crouse H. (2010). Common postoperative complications in otolaryngology presenting to the pediatric emergency department. Clinical Pediatric Emergency Medicine.
6084 Saylam G, Tatar EC, Tatar I, et al. (2010). Association of adenoid surface biofilm formation and chronic otitis media with effusion. Arch Otolaryngol Head Neck Surg.
6085 Sbaihat A, Batarseh E. (2010). Comparison of recovery characteristics of sevoflurane and halothane in children undergoing adenotonsillectomy. Jordan Medical Journal.
6086 Scadding G. (2010). Non-surgical treatment of adenoidal hypertrophy: the role of treating IgE-mediated inflammation. Pediatr Allergy Immunol.
6087 Schaaf WE, Wootten CT, Donnelly LF, et al. (2010). Findings on MR sleep studies as biomarkers to predict outcome of genioglossus advancement in the treatment of obstructive sleep apnea in children and young adults. AJR Am J Roentgenol.
6088 Schwaab M, Gurr A, Hansen S, et al. (2010). Human beta-Defensins in different states of diseases of the tonsilla palatina. Eur Arch Otorhinolaryngol.
6089 Senska G, Ellermann S, Ernst S, et al. (2010). Recurrent tonsillitis in adults: quality of life after tonsillectomy. Dtsch Arztebl Int.
6090 Setoodeh G, Sharif F, Faramarzi A, et al. (2010). Effect of pre-operative psycho-educational interventions on anxiety and pain in children undergoing tonsillectomy in Shiraz Southern Iran. Iranian Red Crescent Medical Journal.
6091 Shakeel M, Trinidade A, Al-Adhami A, et al. (2010). Intraoperative dexamethasone and the risk of secondary posttonsillectomy hemorrhage. J Otolaryngol Head Neck Surg.
6092 Shamji MF, Ventureyra EC, Baronia B, et al. (2010). Classification of symptomatic Chiari I malformation to guide surgical strategy. Can J Neurol Sci.
6093 Sharma K, Rathi AK, Khurana N, et al. (2010). A retrospective study of 18 cases of adenoid cystic cancer at a tertiary care centre in Delhi. Indian J Cancer.
6094 Shete MM, Stocks RM, Sebelik ME, et al. (2010). Effects of adeno-tonsillectomy on polysomnography patterns in Down syndrome children with obstructive sleep apnea: a comparative study with children without Down syndrome. Int J Pediatr Otorhinolaryngol.
6095 Shi J, Wang S, Zhao E, et al. (2010). Paxillin expression levels are correlated with clinical stage and metastasis in salivary adenoid cystic carcinoma. J Oral Pathol Med.
6096 Shigeta T, Imadome K, Sakamoto S, et al. (2010). Epstein-Barr virus infection after pediatric living-related liver transplantation--management and risk factors. Transplant Proc.
6097 Shihada R, Goldsher M, Braun J, et al. (2010). Aberrant carotid artery as an incidental finding before tonsillectomy. Ear Nose Throat J.
6098 Shimizu S, Yukawa K, Kawaguchi S, et al. (2010). Fluctuating mixed-type hearing loss associated with synovitis-acne-pustulosis-hyperostosis-osteomyelitis (SAPHO) syndrome. Auris Nasus Larynx.
6099 Shires CB, Anold SL, Schoumacher RA, et al. (2010). Body mass index as an indicator of obstructive sleep apnea in pediatric Down syndrome. Int J Pediatr Otorhinolaryngol.
6100 Siau D, List RJ, Hussin N, et al. (2010). Do printed information leaflets improve recall of the procedure and risks in adult tonsillectomy? How we do it. Clin Otolaryngol.
6101 Silva JA, Melo LR, Araujo AF, et al. (2010). Resolution of syringomyelia in ten cases of “up-and-down Chiari malformation” after posterior fossa decompression. Arq Neuropsiquiatr.
6102 Simonsen AR, Duncavage JA, Becker SS. (2010). A review of malpractice cases after tonsillectomy and adenoidectomy. Int J Pediatr Otorhinolaryngol.
6103 Sinha D, Guilleminault C. (2010). Sleep disordered breathing in children. Indian J Med Res.
6104 Somani SS, Naik CS, Bangad SV. (2010). Endoscopic adenoidectomy with microdebrider. Indian J Otolaryngol Head Neck Surg.
6105 Song CM, Park MH, Kim YH, et al. (2010). Factors affecting the extrusion rate of ventilation tubes. Clin Exp Otorhinolaryngol.
6106 Songu M, Adibelli ZH, Tuncyurek O, et al. (2010). Age-specific size of the upper airway structures in children during development. Ann Otol Rhinol Laryngol.
6107 Songu M, Altay C, Adibelli ZH, et al. (2010). Endoscopic-assisted versus curettage adenoidectomy: a prospective, randomized, double-blind study with objective outcome measures. Laryngoscope.
6108 Souki BQ, Pimenta GB, Franco LP, et al. (2010). Changes in vertical dentofacial morphology after adeno-/tonsillectomy during deciduous and mixed dentitions mouth breathing children--1 year follow-up study. Int J Pediatr Otorhinolaryngol.
6109 Soysal HG. (2010). Orbital exenteration: a 10-year experience of a general oncology hospital. Orbit.
6110 Spena G, Bernucci C, Garbossa D, et al. (2010). Clinical and radiological outcome of craniocervical osteo-dural decompression for Chiari I-associated syringomyelia. Neurosurg Rev.
6111 Spence D. (2010). Bad medicine: paediatric ear, nose, and throat surgery. BMJ.
6112 Spilsbury K, Miller I, Semmens JB, et al. (2010). Factors associated with developing cholesteatoma: a study of 45,980 children with middle ear disease. Laryngoscope.
6113 Stathas T, Mallis A, Naxakis S, et al. (2010). Taste function evaluation after tonsillectomy: a prospective study of 60 patients. Eur Arch Otorhinolaryngol.
6114 Stein MT, Gottsegen D, Blasco PA, et al. (2010). Chronic hip pain in a boy with mental retardation and cerebral palsy. J Dev Behav Pediatr.
6115 Stelter K, Hiller J, Hempel JM, et al. (2010). Comparison of two different local anaesthetic infiltrations for postoperative pain relief in tonsillectomy: a prospective, randomised, double blind, clinical trial. Eur Arch Otorhinolaryngol.
6116 Stricker PA, Rizzi MD, Schwartz AJ. (2010). Lingual tonsil. Anesthesiology.
6117 Stuck BA, Abrams J, de la Chaux R, et al. (2010). Diagnosis and treatment of snoring in adults--S1 guideline of the German Society of Otorhinolaryngology, Head and Neck Surgery. Sleep Breath.
6118 Sturm-O'Brien AK, Hicks JM, Giannoni CM, et al. (2010). Optimal utilization of histopathologic analysis of tonsil and adenoid specimens in the pediatric population. Int J Pediatr Otorhinolaryngol.
6119 Sturm-O'Brien AK, Hicks MJ, Giannoni CM, et al. (2010). Tonsillectomy in post-transplant lymphoproliferative disease in children. Laryngoscope.
6120 Suchitha S, Sheeladevi CS, Sunila R, et al. (2010). Extra nodal follicular dendritic cell tumor. Indian J Pathol Microbiol.
6121 Suhail Z, Musani MA, Afaq S, et al. (2010). Follicular dendritic cell sarcoma of tonsil. J Coll Physicians Surg Pak.
6122 Suleman M, Clark MP, Goldacre M, et al. (2010). Exploring the variation in paediatric tonsillectomy rates between English regions: a 5-year NHS and independent sector data analysis. Clin Otolaryngol.
6123 Sultesz M, Katona G, Hirschberg A, et al. (2010). Prevalence and risk factors for allergic rhinitis in primary schoolchildren in Budapest. Int J Pediatr Otorhinolaryngol.
6124 Sun J, Wu X, Meng Y, et al. (2010). Bupivacaine versus normal saline for relief of post-adenotonsillectomy pain in children: a meta-analysis. Int J Pediatr Otorhinolaryngol.
6125 Sunitha C, Kumar SA. (2010). Obstructive sleep apnea and its management. Indian J Dent Res.
6126 Supriyatno B, Said M, Hermani B, et al. (2010). Risk factors of obstructive sleep apnea syndrome in obese early adolescents: a prediction model using scoring system. Acta Med Indones.
6127 Sutters KA, Miaskowski C, Holdridge-Zeuner D, et al. (2010). A randomized clinical trial of the efficacy of scheduled dosing of acetaminophen and hydrocodone for the management of postoperative pain in children after tonsillectomy. Clin J Pain.
6128 Syed MI, Amiraraghi N, Williams AT. (2010). Comment on: Indications for tonsillectomy. Ann R Coll Surg Engl.
6129 Szathmari A, Thiesse P, Galand-desme S, et al. (2010). Correlation between pre- or postoperative MRI findings and cerebellar sequelae in patients with medulloblastomas. Pediatr Blood Cancer.
6130 Tas E, Hanci V, Ugur MB, et al. (2010). Does preincisional injection of levobupivacaine with epinephrine have any benefits for children undergoing tonsillectomy? An intraindividual evaluation. Int J Pediatr Otorhinolaryngol.
6131 Tauman R, Derowe A, Ophir O, et al. (2010). Increased risk of snoring and adenotonsillectomy in children referred for tympanostomy tube insertion. Sleep Med.
6132 Tezer H, Sucakli IA, Sayli TR, et al. (2010). Crimean-Congo hemorrhagic fever in children. J Clin Virol.
6133 Tjon Pian Gi R, Bliek V, Borgstein J. (2010). The Sluder method in the Netherlands and the incidence of postoperative haemorrhage in a pediatric hospital. Int J Pediatr Otorhinolaryngol.
6134 Tomino Y. (2010). Immunoglobulin A nephropathy and chronic kidney disease. Nephrology (Carlton).
6135 Tomkinson A, Harrison W, Temple M, et al. (2010). Food and Drug Administration. Surveillance and medical devices. Bmj.
6136 Toros SZ, Kilicoglu G, Noseri H, et al. (2010). Does adenoid hypertrophy really have effect on tympanometry?. Int J Pediatr Otorhinolaryngol.
6137 Toros SZ, Noseri H, Ertugay CK, et al. (2010). Adenotonsillar hypertrophy: Does it correlate with obstructive symptoms in children?. Int J Pediatr Otorhinolaryngol.
6138 Trinidade A, Shakeel M, Majithia A, et al. (2010). Call-fleming syndrome: an extraordinary complication of tonsillectomy. J Coll Physicians Surg Pak.
6139 Tsara V, Amfilochiou A, Papagrigorakis JM, et al. (2010). Guidelines for diagnosing and treating sleep related breathing disorders in adults and children (Part 3: Obstructive sleep apnea in children, diagnosis and treatment). Hippokratia.
6140 Tsuchiya T, Ito S, Yamaguchi Y, et al. (2010). Tonsillectomy and steroid pulse therapy for recurrent IgA nephropathy in renal allograft. Clin Nephrol.
6141 Ueda S, Takahara M, Tohtani T, et al. (2010). Up-regulation of ss1 integrin on tonsillar T cells and its induction by in vitro stimulation with alpha-streptococci in patients with pustulosis Palmaris et Plantaris. J Clin Immunol.
6142 Uijen JH, Schellevis FG, Bindels PJ, et al. (2010). Low hospital admission rates for respiratory diseases in children. BMC Fam Pract.
6143 van den Aardweg MT, Rovers MM, Kraal A, et al. (2010). Current indications for adenoidectomy in a sample of children in the Netherlands. B-ENT.
6144 Vanpouille C, Lisco A, Derudas M, et al. (2010). A new class of dual-targeted antivirals: monophosphorylated acyclovir prodrug derivatives suppress both human immunodeficiency virus type 1 and herpes simplex virus type 2. J Infect Dis.
6145 Vaughan AT, Brackenbury LS, Massari P, et al. (2010). Neisseria lactamica selectively induces mitogenic proliferation of the naive B cell pool via cell surface Ig. J Immunol.
6146 Vayisoglu Y, Gorur K, Ozcan C, et al. (2010). Is speech therapy useful as a complementary treatment for post-tonsillectomy pain?. Int J Pediatr Otorhinolaryngol.
6147 Verma SK, Maheshwari S, Sharma NK, et al. (2010). Role of oral health professional in pediatric obstructive sleep apnea. Natl J Maxillofac Surg.
6148 Vestergaard H, Westergaard T, Wohlfahrt J, et al. (2010). Tonsillitis, tonsillectomy and Hodgkin's lymphoma. Int J Cancer.
6149 Vilarinho S, Guimaraes NM, Ferreira RM, et al. (2010). Helicobacter pylori colonization of the adenotonsillar tissue: fact or fiction?. Int J Pediatr Otorhinolaryngol.
6150 Wagel J, Gruszka J, Szewczyk P, et al. (2010). Herniation to foramen magnum in the course of cerebellitis in a 4-year-old boy, as shown by CT and MRI - case report. Pol J Radiol.
6151 Wan DC, Kumar A, Head CS, et al. (2010). Amelioration of acquired nasopharyngeal stenosis, with bilateral Z-pharyngoplasty. Ann Plast Surg.
6152 Wang JH, Chung YS, Cho YW, et al. (2010). Palatine tonsil size in obese, overweight, and normal-weight children with sleep-disordered breathing. Otolaryngol Head Neck Surg.
6153 Wang R, Ma D, Lin L, et al. (2010). Identification and characterization of an avian beta-defensin orthologue, avian beta-defensin 9, from quails. Appl Microbiol Biotechnol.
6154 Wang Y, Wang JJ, Zhao MQ, et al. (2010). Changes of serum brain-derived neurotrophic factor in children with obstructive sleep apnoea-hypopnoea syndrome following adenotonsillectomy. J Int Med Res.
6155 Warrier R, Chauhan A, Athale U. (2010). Tonsillectomy and adenoidectomy for obstructive sleep apnea in sickle cell anemia. Indian J Pediatr.
6156 Watanabe T, Suzuki M. (2010). Bilateral peritonsillar abscesses: our experience and clinical features. Ann Otol Rhinol Laryngol.
6157 Werner EJ. (2010). Preoperative hemostatic screening for pediatric adenotonsillar surgery: worthwhile effort or waste of resources?. Pediatr Blood Cancer.
6158 Williams MD, Al-Zubidi N, Debnam JM, et al. (2010). Bone invasion by adenoid cystic carcinoma of the lacrimal gland: preoperative imaging assessment and surgical considerations. Ophthal Plast Reconstr Surg.
6159 Williot P. (2010). Editorial comment. J Urol.
6160 Wilson J, Carrie S, Lock C, et al. (2010). The effectiveness of childhood tonsillectomy. Otolaryngology - Head and Neck Surgery.
6161 Wilson-Smith EM. (2010). Systemic analgesics in children. Anaesthesia and Intensive Care Medicine.
6162 Windfuhr JP, Cao Van H, Landis BN. (2010). Recovery from long-lasting post-tonsillectomy dysgeusia. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
6163 Windfuhr JP, Sack F, Sesterhenn AM, et al. (2010). Post-tonsillectomy taste disorders. Eur Arch Otorhinolaryngol.
6164 Windfuhr JP, Sesterhenn AM, Schloendorff G, et al. (2010). Post-tonsillectomy pseudoaneurysm: an underestimated entity?. J Laryngol Otol.
6165 Wong CP, Ng DK, Ma TM, et al. (2010). Improvement in quality of life after adenotonsillectomy in a child with Prader Willi syndrome. Sleep Breath.
6166 Woodson BT. (2010). Non-pressure therapies for obstructive sleep apnea: surgery and oral appliances. Respir Care.
6167 Wootten CT, Shott SR. (2010). Evolving therapies to treat retroglossal and base-of-tongue obstruction in pediatric obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
6168 Xu ZF, Shen KL. (2010). The epidemiology of snoring and obstructive sleep apnea/hypopnea in Mainland China. Biological Rhythm Research.
6169 Yagi A, Sato N, Takahashi A, et al. (2010). Added value of contrast-enhanced CISS imaging in relation to conventional MR images for the evaluation of intracavernous cranial nerve lesions. Neuroradiology.
6170 Yamazaki M, Fujii S, Murata Y, et al. (2010). High expression level of geminin predicts a poor clinical outcome in salivary gland carcinomas. Histopathology.
6171 Yasar H, Ozkul H. (2010). Thermal welding technique versus cold dissection for adult tonsillectomy. B-ENT.
6172 Ye J, Liu H, Zhang GH, et al. (2010). Outcome of adenotonsillectomy for obstructive sleep apnea syndrome in children. Ann Otol Rhinol Laryngol.
6173 Yellon RF. (2010). Is polysomnography required prior to tonsillectomy and adenoidectomy for diagnosis of obstructive sleep apnea versus mild sleep disordered breathing in children?. Laryngoscope.
6174 Yildirim G, Morrison WH, Rosenthal DI, et al. (2010). Outcomes of patients with tonsillar carcinoma treated with post-tonsillectomy radiation therapy. Head Neck.
6175 Ylikontiola L, Siponen M, Salo T, et al. (2010). Sialometaplasia of the soft palate in a 2-year-old girl. J Mich Dent Assoc.
6176 Yong DJ, Majid MNA, Mohd Razif MY. (2010). Patient with occult neck primary turns out to be tonsillar carcinoma in origin. Rawal Medical Journal.
6177 Yuksek M, Ikinciogullari A, Dogu F, et al. (2010). Primary immune deficiency disease awareness among a group of Turkish physicians. Turk J Pediatr.
6178 Zagolski O. (2010). Why do palatine tonsils grow back after partial tonsillectomy in children?. Eur Arch Otorhinolaryngol.
6179 Zagolski O. (2010). Do diet and activity restrictions influence recovery after adenoidectomy and partial tonsillectomy?. Int J Pediatr Otorhinolaryngol.
6180 Zagolski O. (2010). WITHDRAWN: Post-tonsillectomy haemorrhage-Do coagulation tests and coagulopathy history have predictive value?. Acta Otorrinolaringol Esp.
6181 Zautner AE, Krause M, Stropahl G, et al. (2010). Intracellular persisting Staphylococcus aureus is the major pathogen in recurrent tonsillitis. PLoS One.
6182 Zelazowska-Rutkowska B, Wysocka J, Skotnicka B. (2010). Chosen factors of T and B cell apoptosis in hypertrophic adenoid in children with otitis media with effusion. Int J Pediatr Otorhinolaryngol.
6183 Zuckerman NS, Howard WA, Bismuth J, et al. (2010). Ectopic GC in the thymus of myasthenia gravis patients show characteristics of normal GC. Eur J Immunol.
6184 (2011). Commentary on “Letter to the Editor for article titled A Randomized Clinical Trial of the Efficacy of Scheduled Dosing of Acetaminophen and Hydrocodone for the Management of Postoperative Pain in Children After Tonsillectomy”. Clin J Pain.
6185 (2011). Important to identify and treat sleep problems in children with attention-deficit hyperactivity disorder (ADHD). Drugs and Therapy Perspectives.
6186 (2011). Abstracts of the 6th Meeting of the South West ENT Academic Meeting. Otorhinolaryngologist.
6187 Abdel-Aziz M. (2011). Asymptomatic cardiopulmonary changes caused by adenoid hypertrophy. J Craniofac Surg.
6188 Abdel-Aziz M, El-Hoshy H, Rashed M, et al. (2011). Epstein-Barr virus infection as a cause of cervical lymphadenopathy in children. Int J Pediatr Otorhinolaryngol.
6189 Abdel-Aziz M, Ibrahim N, Ahmed A, et al. (2011). Lingual tonsils hypertrophy; a cause of obstructive sleep apnea in children after adenotonsillectomy: operative problems and management. Int J Pediatr Otorhinolaryngol.
6190 Abdel-Ghaffar HS, Abdel-Haleem AK. (2011). Efficacy and safety of intraoperative dexmedetomidine in pediatric posttonsillectomy pain: Peritonsillar versus intravenous administration. Egyptian Journal of Anaesthesia.
6191 Abdel-Monem MH, Magdy EA, Nour YA, et al. (2011). Detection of Helicobacter pylori in adenotonsillar tissue of children with chronic adenotonsillitis using rapid urease test, PCR and blood serology: a prospective study. Int J Pediatr Otorhinolaryngol.
6192 Acar GO, Cansz H, Duman C, et al. (2011). Excessive reactive lymphoid hyperplasia in a child with persistent obstructive sleep apnea despite previous tonsillectomy and adenoidectomy. J Craniofac Surg.
6193 Achar P, Mitra I, Izzat S, et al. (2011). Adult day case tonsillectomy: an audit cycle. J Eval Clin Pract.
6194 Adoga AS, Ma An DN, Nuhu SI. (2011). Is routine histopathology of tonsil specimen necessary?. Afr J Paediatr Surg.
6195 Afsharpaiman S, Sillence DO, Sheikhvatan M, et al. (2011). Respiratory events and obstructive sleep apnea in children with achondroplasia: investigation and treatment outcomes. Sleep Breath.
6196 Ahishakiye D, Najafi N, Velde A, et al. (2011). A randomized controlled trial to evaluate the incidence of emergence agitation in children: A comparison of intravenous versus inhalational anesthesia. European journal of anaesthesiology.
6197 Ahmed KA, Dreher ME, King RF, et al. (2011). Dexamethasone and postoperative bleeding risk after adenotonsillectomy in children. Laryngoscope.
6198 Akagi H, Doi A, Kosaka M, et al. (2011). Indication criteria for tonsillectomy in IgA nephropathy patients. Adv Otorhinolaryngol.
6199 Akhtar N, Sadiq M, Rizvi FUH, et al. (2011). Pakistan cardiac society guidelines for prevention of rheumatic fever and rheumatic heart disease. Pakistan Paediatric Journal.
6200 Akpinar ME, Yigit O, Kocak I, et al. (2011). Does the length of uvula affect the palatal implant outcome in the management of habitual snoring?. Laryngoscope.
6201 Al Maqbali T, Al Khabouri M, Kumar S. (2011). Radiosurgical correlation of obstructive adenoids in children. Eur Arch Otorhinolaryngol.
6202 Al Omari B, Sadacharam M, Sheahan P. (2011). Cervical surgical emphysema following routine tonsillectomy. Rev Laryngol Otol Rhinol (Bord).
6203 Alam MM, Atiq MT, Mamun AA, et al. (2011). Comparison between bipolar diathermy tonsillectomy and cold dissection tonsillectomy. Mymensingh Med J.
6204 Alexander AA, Patel NJ, Southammakosane CA, et al. (2011). Pediatric autoimmune neuropsychiatric disorders associated with streptococcal infections (PANDAS): an indication for tonsillectomy. Int J Pediatr Otorhinolaryngol.
6205 Alexiou VG, Salazar-Salvia MS, Jervis PN, et al. (2011). Modern technology-assisted vs conventional tonsillectomy: a meta-analysis of randomized controlled trials. Arch Otolaryngol Head Neck Surg.
6206 Alherabi AZ. (2011). Impact of pH1N1 influenza A infections on the Otolaryngology, Head and Neck Clinic during Hajj, 2009. Saudi Med J.
6207 Ali NS, Ikram M, Akhtar S, et al. (2011). Harmonic scalpel versus electrocautery tonsillectomy: a comparative study in adult patients. J Pak Med Assoc.
6208 Aliakbari I, Noohi S, Safavi SA, et al. (2011). The role of adenotonsillar tissues as a reservoir for Helicobacter pylori and Helicobacter hepaticus. Gastroenterology and Hepatology from Bed to Bench.
6209 Alkhalil M, Lockey R. (2011). Pediatric obstructive sleep apnea syndrome (OSAS) for the allergist: update on the assessment and management. Ann Allergy Asthma Immunol.
6210 Almeida LA, Anselmo-Lima WT, Valera FC. (2011). OSAS in children: where are we?. Braz J Otorhinolaryngol.
6211 Al-Salam S, Dhaheri SA, Awwad A, et al. (2011). Prevalence of Epstein-Barr virus in tonsils and adenoids of United Arab Emirates nationals. Int J Pediatr Otorhinolaryngol.
6212 Alvarado-Esquivel C, Estrada-Martinez S, Liesenfeld O. (2011). Toxoplasma gondii infection in workers occupationally exposed to unwashed raw fruits and vegetables: a case control seroprevalence study. Parasit Vectors.
6213 Amer HZM, Prasad V, Kahwash SB. (2011). Rosai-Dorfman disease of the tonsil in a 4-year-old boy: Case report and review of the literature. International Journal of Pediatric Otorhinolaryngology Extra.
6214 Amin SM, Amr YM. (2011). Comparison between preemptive gabapentin and paracetamol for pain control after adenotonsillectomy in children. Anesth Essays Res.
6215 Ankichetty S, Wong J, Chung F. (2011). A systematic review of the effects of sedatives and anesthetics in patients with obstructive sleep apnea. Journal of Anaesthesiology Clinical Pharmacology.
6216 Anton-Martin P, Ortiz Movilla R, Guillen Martin S, et al. (2011). PFAPA syndrome in siblings. Is there a genetic background? Eur J Pediatr.
6217 Apuhan T, Yildirim YS, Aksoy F, et al. (2011). The effects of desflurane and sevoflurane on the peri- and postoperative bleeding of adenotonsillectomy patients. Int J Pediatr Otorhinolaryngol.
6218 Apuhan T, Yildirim YS, Ozaslan H. (2011). The developmental relation between adenoid tissue and paranasal sinus volumes in 3-dimensional computed tomography assessment. Otolaryngol Head Neck Surg.
6219 Arens R, Sin S, Nandalike K, et al. (2011). Upper airway structure and body fat composition in obese children with obstructive sleep apnea syndrome. Am J Respir Crit Care Med.
6220 Arnaoutakis D, Collins WO. (2011). Correlation of mucociliary clearance and symptomatology before and after adenoidectomy in children. Int J Pediatr Otorhinolaryngol.
6221 Ashraf MJ, Azarpira N, Khademi B, et al. (2011). Relation between Actinomycosis and Histopathological and Clinical Features of the Palatine Tonsils: An Iranian Experience. Iran Red Crescent Med J.
6222 Attarian H, Viola-Saltzman M, Jay WM. (2011). Ophthalmic and neuro-ophthalmic complications of obstructive sleep apnoea. Neuro-Ophthalmology.
6223 Aurora RN, Zak RS, Karippot A, et al. (2011). Practice parameters for the respiratory indications for polysomnography in children. Sleep.
6224 Aydin E, Tastan E, Aydogan F, et al. (2011). Role of nasopharyngeal reflux in the etiology of otitis media with effusion. J Otolaryngol Head Neck Surg.
6225 Aydin S, Aslan I, Yildiz I, et al. (2011). Vitamin D levels in children with recurrent tonsillitis. Int J Pediatr Otorhinolaryngol.
6226 Azenha MR, Yamaji MA, Avelar RL, et al. (2011). Retropharyngeal and cervicofacial subcutaneous emphysema after maxillofacial trauma. Oral Maxillofac Surg.
6227 Balatsouras DG, Fassolis A, Koukoutsis G, et al. (2011). Primary lymphangioma of the tonsil: A case report. Case Reports in Medicine.
6228 Balci TA, Koc ZP, Turgut B, et al. (2011). A case of intraorbital hemangioma diagnosed with tc 99m labeled erythrocyte scintigraphy and magnetic resonance imaging. Mol Imaging Radionucl Ther.
6229 Bar R, Netzer A, Ostrovsky D, et al. (2011). Abrupt tonsillar hemorrhage from a metastatic hemangiosarcoma of the breast: case report and literature review. Ear Nose Throat J.
6230 Barcelo X, Mirapeix RM, Buges J, et al. (2011). Oropharyngeal examination to predict sleep apnea severity. Arch Otolaryngol Head Neck Surg.
6231 Baroni M, Ballanti F, Polimeni A, et al. (2011). Thin-plate spline analysis of craniofacial morphology in subjects with adenoid or tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
6232 Barr E, Dungworth J, Hunter K, et al. (2011). The prevalence of ear, nose and throat disorders in preschool children with Down's syndrome in Glasgow. Scott Med J.
6233 Barreto I, Costa AF, Martins MT, et al. (2011). Immunohistochemical study of stromal and vascular components of tonsillar polyps: high endothelial venules as participants of the polyp's lymphoid tissue. Virchows Arch.
6234 Basseri RJ, Chong K, Chang C, et al. (2011). History of tonsillectomy is associated with irritable bowel syndrome. J Clin Gastroenterol.
6235 Baugh RF, Archer SM, Mitchell RB, et al. (2011). Clinical practice guideline: tonsillectomy in children. Otolaryngol Head Neck Surg.
6236 Baumert M, Kohler M, Kabir M, et al. (2011). Altered cardio-respiratory response to spontaneous cortical arousals in children with upper airway obstruction. Sleep Med.
6237 Bell D, Roberts D, Karpowicz M, et al. (2011). Clinical significance of Myb protein and downstream target genes in salivary adenoid cystic carcinoma. Cancer Biol Ther.
6238 Bellussi LM, Marchisio P, Materia E, et al. (2011). Clinical guideline on adenotonsillectomy: the Italian experience. Adv Otorhinolaryngol.
6239 Benglis D, Covington D, Bhatia R, et al. (2011). Outcomes in pediatric patients with Chiari malformation Type I followed up without surgery. J Neurosurg Pediatr.
6240 Ben-Yaakov A, Maly B, Abu-Ita R, et al. (2011). Identification and immunolocalization of the innate immune receptor CD14 in hypertrophic adenoids and tonsils. Immunol Invest.
6241 Bhaskar B, Fraser J. (2011). Negative pressure pulmonary edema revisited: Pathophysiology and review of management. Saudi Journal of Anaesthesia.
6242 Bhattacharyya N. (2011). Benchmarks for the durations of ambulatory surgical procedures in otolaryngology. Ann Otol Rhinol Laryngol.
6243 Bittmann S, Kruger C. (2011). Benzocaine-induced methaemoglobinaemia: a case study. Br J Nurs.
6244 Bjorndal K, Krogdahl A, Therkildsen MH, et al. (2011). Salivary gland carcinoma in Denmark 1990-2005: a national study of incidence, site and histology. Results of the Danish Head and Neck Cancer Group (DAHANCA). Oral Oncol.
6245 Bjorndal K, Larsen SR, Godballe C, et al. (2011). Osteopontin expression in salivary gland carcinomas. J Oral Pathol Med.
6246 Bogefors J, Kvarnhammar AM, Latif L, et al. (2011). Retinoic acid-inducible gene 1-like receptors in the upper respiratory tract. Am J Rhinol Allergy.
6247 Bonuck KA, Chervin RD, Cole TJ, et al. (2011). Prevalence and persistence of sleep disordered breathing symptoms in young children: a 6-year population-based cohort study. Sleep.
6248 Boss EF, Smith DF, Ishman SL. (2011). Racial/ethnic and socioeconomic disparities in the diagnosis and treatment of sleep-disordered breathing in children. Int J Pediatr Otorhinolaryngol.
6249 Brandtzaeg P. (2011). Potential of nasopharynx-associated lymphoid tissue for vaccine responses in the airways. Am J Respir Crit Care Med.
6250 Brigati C, Banelli B, Casciano I, et al. (2011). Epigenetic mechanisms regulate DeltaNP73 promoter function in human tonsil B cells. Mol Immunol.
6251 Brill LB, Kanner WA, Fehr A, et al. (2011). Analysis of MYB expression and MYB-NFIB gene fusions in adenoid cystic carcinoma and other salivary neoplasms. Mod Pathol.
6252 Brockmeyer DL. (2011). The complex Chiari: issues and management strategies. Neurol Sci.
6253 Brodsky MA, Machovec KA, Chambers BP, et al. (2011). Platelet-mediated thrombolysis in patients with delta-storage pool deficiency: a thrombelastographic analysis. Blood Coagul Fibrinolysis.
6254 Brouillette RT, Horwood L, Constantin E, et al. (2011). Childhood sleep apnea and neighborhood disadvantage. J Pediatr.
6255 Browaldh N, Friberg D, Svanborg E, et al. (2011). 15-year efficacy of uvulopalatopharyngoplasty based on objective and subjective data. Acta Otolaryngol.
6256 Brown KA. (2011). Outcome, risk, and error and the child with obstructive sleep apnea. Paediatr Anaesth.
6257 Cacchi C, Persechino S, Fidanza L, et al. (2011). A primary cutaneous adenoid-cystic carcinoma in a young woman. Differential diagnosis and clinical implications. Rare Tumors.
6258 Cada D, Levien T, Baker D. (2011). Formulary drug reviews - Acetaminophen intravenous. Hospital Pharmacy.
6259 Cahali MB, Soares CF, Dantas DA, et al. (2011). Tonsil volume, tonsil grade and obstructive sleep apnea: is there any meaningful correlation?. Clinics (Sao Paulo).
6260 Caldwell P, Hensley R, Machaalani R, et al. (2011). How effective is adenoidectomy alone for treatment of obstructive sleep apnoea in a child who presents with adenoid hypertrophy?. J Paediatr Child Health.
6261 Callery P. (2011). Commentary on Buckley A & Savage E (2010) Preoperative information needs of children undergoing tonsillectomy. Journal of Clinical Nursing 19, 2879-2887. J Clin Nurs.
6262 Calo L, Passali GC, Galli J, et al. (2011). Role of biofilms in chronic inflammatory diseases of the upper airways. Adv Otorhinolaryngol.
6263 Cataletto M, Angulo M, Hertz G, et al. (2011). Prader-Willi syndrome: A primer for clinicians. International Journal of Pediatric Endocrinology.
6264 Celebi S, Yelken K, Celik O, et al. (2011). Thermal welding vs. cold knife tonsillectomy: a comparison of voice and speech. Int J Pediatr Otorhinolaryngol.
6265 Celebiler O, Ersoy B, Numanoglu A. (2011). Anterior pillarplasty: a modification in cleft palate repair. J Craniofac Surg.
6266 Chahwakilian P, Huttner B, Schlemmer B, et al. (2011). Impact of the French campaign to reduce inappropriate ambulatory antibiotic use on the prescription and consultation rates for respiratory tract infections. J Antimicrob Chemother.
6267 Chan AQ, Chan MP, Chan EL, et al. (2011). Unusually severe rem sleep apnea hypopnea in a child, strengthens genetic linkage with parents. Sleep and Biological Rhythms.
6268 Charaklias N, Mamais C, Kumar BN. (2011). The art of tonsillectomy: the UK experience for the past 100 years. Otolaryngol Head Neck Surg.
6269 Chen LL, Toyoguchi M, Shimakawa M, et al. (2011). Chronic refractory uveitis in a patient with childhood-onset cyclic neutropenia. Case Rep Ophthalmol.
6270 Chen T, Hedman L, Mattila PS, et al. (2011). Serological evidence of Merkel cell polyomavirus primary infections in childhood. J Clin Virol.
6271 Cheng CC, Ueng SH, Li HY, et al. (2011). Post-tonsillectomy pulmonary complication in a patient with tonsillar myeloid sarcoma. Int J Hematol.
6272 Chern JJ, Gordon AJ, Mortazavi MM, et al. (2011). Pediatric Chiari malformation Type 0: a 12-year institutional experience. J Neurosurg Pediatr.
6273 Chiesa S, Pelagatti MA, Finetti M, et al. (2011). Characterization of tonsil infiltration and gene expression profile of innate sensors in PFAPA patients. Pediatric Rheumatology.
6274 Choi HR, Cho JK, Lee S, et al. (2011). The effect of remifentanil versus N(2)O on postoperative pain and emergence agitation after pediatric tonsillectomy/adenoidectomy. Korean J Anesthesiol.
6275 Chow YH, Chang HW, Sia R, et al. (2011). Tonsillar CD4+FOXP3+ T-regulatory cell dynamics in primary EBV infection. Immunol Res.
6276 Christe A, Waldherr C, Hallett R, et al. (2011). MR imaging of parotid tumors: typical lesion characteristics in MR imaging improve discrimination between benign and malignant disease. AJNR Am J Neuroradiol.
6277 Chua AP, Senthilvel E, Hawley K, et al. (2011). Congenital cervicofacial venous and lymphatic malformations causing severe obstructive sleep apnea-A report of 2 pediatric cases and review of the literature. International Journal of Pediatric Otorhinolaryngology Extra.
6278 Chuang HC, Fang FM, Huang CC, et al. (2011). Clinical and pathological determinants in tonsillar cancer. Head Neck.
6279 Cingi C, Songu M, Ural A, et al. (2011). Effect of chlorhexidine gluconate and benzydamine hydrochloride mouth spray on clinical signs and quality of life of patients with streptococcal tonsillopharyngitis: multicentre, prospective, randomised, double-blinded, placebo-controlled study. J Laryngol Otol.
6280 Civelek S, Sayin I, Caglayan V, et al. (2011). The outcomes of 4 different techniques of tonsillectomy. Otolaryngology - Head and Neck Surgery.
6281 Clayburgh D, Milczuk H, Gorsek S, et al. (2011). Efficacy of tonsillectomy for pediatric patients with Dysphagia and tonsillar hypertrophy. Arch Otolaryngol Head Neck Surg.
6282 Clenney T, Bondy P, Schroeder A, et al. (2011). Postoperative pain after tonsillectomy with plasmaknife versus monopolar cautery. Laryngoscope.
6283 Clenney T, Schroeder A, Bondy P, et al. (2011). Postoperative pain after adult tonsillectomy with PlasmaKnife compared to monopolar electrocautery. Laryngoscope.
6284 Cole KH, Sosnay PR, Yarmus LB, et al. (2011). The novel CFTR mutation A457P in a male with a delayed diagnosis of cystic fibrosis. Case Reports in Medicine.
6285 Colotto M, Maranghi M, Durante C, et al. (2011). PFAPA syndrome in a young adult with a history of tonsillectomy. Intern Med.
6286 Conti PB, Sakano E, Ribeiro MA, et al. (2011). Assessment of the body posture of mouth-breathing children and adolescents. J Pediatr (Rio J).
6287 Courville EL, Lew M, Sadow PM. (2011). Routine evaluation of adult tonsillectomy specimens: toward establishing a new standard of care. Int J Surg Pathol.
6288 Crowder RN, Zhao H, Chatham WW, et al. (2011). B lymphocytes are resistant to death receptor 5-induced apoptosis. Clin Immunol.
6289 Cuvas O, Dikmen B, Yucel F. (2011). Sniffing position combined with mouth opening improves facemask ventilation in children with adenotonsillar hypertrophy. Acta Anaesthesiol Scand.
6290 da Silva JA, dos Santos AA, Melo LR, et al. (2011). Posterior fossa decompression with tonsillectomy in 104 cases of basilar impression, Chiari malformation and/or syringomyelia. Arq Neuropsiquiatr.
6291 Dagtekin A, Kara E, Vayisoglu Y, et al. (2011). The importance of early diagnosis and appropriate treatment in Grisel's syndrome: report of two cases. Turk Neurosurg.
6292 Dahi-Taleghani M, Mousavifard S, Tahmoureszade S, et al. (2011). Rectal acetaminophen versus peritonsillar infiltration of bupivacaine for postoperative analgesia after adenotonsillectomy in children. Eur Arch Otorhinolaryngol.
6293 Dahmani S, Michelet D, Abback PS, et al. (2011). Ketamine for perioperative pain management in children: a meta-analysis of published studies. Paediatr Anaesth.
6294 Davidson HC, Stapleton AL, Casselbrant ML, et al. (2011). Perioperative incidence and management of hyponatremia in vWD patients undergoing adenotonsillectomy. Laryngoscope.
6295 Davoodreza S. (2011). Correlation of tonsillectomy with palatine tonsil size. Acta Med Iran.
6296 Dawar A, Khan AR. (2011). Tonsillectomy without the use of post operative antibiotics. Journal of Medical Sciences.
6297 Dawes PJD, McCassey E. (2011). A double-blind, randomized, placebo controlled trial evaluating the effects of a 5-day course of postoperative prednisolone following pediatric tonsillectomy. Otolaryngology - Head and Neck Surgery.
6298 Deckard NA, Kruper GJ, Bui T, et al. (2011). Comparison of two minimally invasive techniques for treating chronic rhinosinusitis in the pediatric population. Int J Pediatr Otorhinolaryngol.
6299 Delouya G, Igidbashian L, Houle A, et al. (2011). (1)(8)F-FDG-PET imaging in radiotherapy tumor volume delineation in treatment of head and neck cancer. Radiother Oncol.
6300 Dhillon S. (2011). Fibrin sealant (evicel(R) [quixil(R)/crosseal]): a review of its use as supportive treatment for haemostasis in surgery. Drugs.
6301 Diakos EA, Gallos ID, El-Shunnar S, et al. (2011). Dexamethasone reduces pain, vomiting and overall complications following tonsillectomy in adults: a systematic review and meta-analysis of randomised controlled trials. Clin Otolaryngol.
6302 Diaz RR, Picciafuoco S, Paraje MG, et al. (2011). Relevance of biofilms in pediatric tonsillar disease. Eur J Clin Microbiol Infect Dis.
6303 Dierckx E, van Hoorenbeeck K, Valdivia Tamayo J, et al. (2011). Witnessed apnoeas in a 6-yr-old boy: A brain teaser. Breathe.
6304 Donaldson IM. (2011). The Cyrurgia of Albucasis and other works, 1500. J R Coll Physicians Edinb.
6305 Dornier BD, Grothe R, Thompson DM. (2011). Aerodigestive manifestations of eosinophilic esophagitis in Rubinstein-Taybi syndrome. International Journal of Pediatric Otorhinolaryngology Extra.
6306 Doshi HK, Rosow DE, Ward RF, et al. (2011). Age-related tonsillar regrowth in children undergoing powered intracapsular tonsillectomy. Int J Pediatr Otorhinolaryngol.
6307 El Sonbaty MI, Abo el Dahab H, Mostafa A, et al. (2011). Preemptive peritonsillar ketamine infiltration: postoperative analgesic efficacy versus meperidine. Middle East J Anaesthesiol.
6308 Elshammaa N, Chidambaran V, Housny W, et al. (2011). Ketamine as an adjunct to fentanyl improves postoperative analgesia and hastens discharge in children following tonsillectomy - a prospective, double-blinded, randomized study. Paediatr Anaesth.
6309 Elwany S, El-Dine AN, El-Medany A, et al. (2011). Relationship between bacteriology of the adenoid core and middle meatus in children with sinusitis. J Laryngol Otol.
6310 Emaneini M, Khoramrooz SS, Taherikalani M, et al. (2011). Molecular characterization of Staphylococcus aureus isolated from children with adenoid hypertrophy: emergence of new spa types t7685 and t7692. Int J Pediatr Otorhinolaryngol.
6311 Endo LH. (2011). Tonsils diseases, past, present and future and the impact in clinical practice in Brazil. Adv Otorhinolaryngol.
6312 Endo Y, Minato H, Taki R, et al. (2011). Myeloperoxidase-antineutrophil cytoplasmic antibody-negative microscopic polyangiitis with pulmonary haemorrhage and IgA nephropathy. Case Reports in Dermatology.
6313 Erden Aydin I, Akinci SB, Celebi N, et al. (2011). Tumour Lysis Syndrome Developing After Diagnostic Tonsillectomy. Journal of Medical and Surgical Intensive Care Medicine.
6314 Eski E, Dogan I, Yilmaz I. (2011). Seasonal variation of secondary post tonsillectomy hemorrhage rates. B-ENT.
6315 Esteitie R, Emani J, Sharma S, et al. (2011). Effect of fluticasone furoate on interleukin 6 secretion from adenoid tissues in children with obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
6316 Farmer SE, Khatwa MA, Zeitoun HM. (2011). Peritonsillar abscess after tonsillectomy: a review of the literature. Ann R Coll Surg Engl.
6317 Fasunla AJ, Onakoya PA, Ogunkunle OO, et al. (2011). Routine Electrocardiography Request in Adenoidectomy: Is it necessary?. Indian J Otolaryngol Head Neck Surg.
6318 Fedeli U, Alba N, Zambon F, et al. (2011). Hospitalisation for surgical procedures is lower among immigrants than among non-immigrant preschool children: results from a region-wide study in Italy. J Epidemiol Community Health.
6319 Feinstein TM, Lai SY, Lenzner D, et al. (2011). Prognostic factors in patients with high-risk locally advanced salivary gland cancers treated with surgery and postoperative radiotherapy. Head Neck.
6320 Feliciano DV, Lyons JD. (2011). Thyroidectomy is optimal treatment for Graves' disease. J Am Coll Surg.
6321 Ferri E, Armato E. (2011). Argon plasma coagulation versus cold dissection in pediatric tonsillectomy. Am J Otolaryngol.
6322 Filip C, Matzen M, Aagenaes I, et al. (2011). Speech and magnetic resonance imaging results following autologous fat transplantation to the velopharynx in patients with velopharyngeal insufficiency. Cleft Palate Craniofac J.
6323 Flanders L, Tulloh R. (2011). Cardiac problems in Down syndrome. Paediatrics and Child Health.
6324 Frake PC, Domanski M, Howell RJ, et al. (2011). The value of otolaryngologists' services in America: a national survey. Otolaryngol Head Neck Surg.
6325 Friedman BC, Goldman RD. (2011). Anti-inflammatory therapy for obstructive sleep apnea in children. Can Fam Physician.
6326 Friedman M, Maley A, Taylor D, et al. (2011). Treatment of pediatric obstructive sleep apnea beyond tonsillectomy and adenoidectomy. Otolaryngology - Head and Neck Surgery.
6327 Fujii Y. (2011). Current review of ramosetron in the prevention of postoperative nausea and vomiting. Curr Drug Saf.
6328 Furtado SV, Thakar S, Hegde AS. (2011). Correlation of functional outcome and natural history with clinicoradiological factors in surgically managed pediatric Chiari I malformation. Neurosurgery.
6329 Galante D. (2011). The Proseal laryngeal mask airway and the transesophageal Doppler probe: the TED-PLMA technique. Can J Anaesth.
6330 Gammelsrud KW, Sandven P, Hoiby EA, et al. (2011). Colonization by Candida in children with cancer, children with cystic fibrosis, and healthy controls. Clin Microbiol Infect.
6331 Ganapathy S, Brookes J, Bourne R. (2011). Local infiltration analgesia. Anesthesiol Clin.
6332 Gao LW, Xie ZD, Liu YY, et al. (2011). Epidemiologic and clinical characteristics of infectious mononucleosis associated with Epstein-Barr virus infection in children in Beijing, China. World J Pediatr.
6333 Garavello W, Pignataro L, Gaini L, et al. (2011). Tonsillectomy in children with periodic fever with aphthous stomatitis, pharyngitis, and adenitis syndrome. Journal of pediatrics.
6334 Ge MH, Chen C, Xu JJ, et al. (2011). Unfavorable clinical implications for hypermethylation of RUNX3 in patients with salivary gland adenoid cystic carcinoma. Oncol Rep.
6335 George A, Kumar R, Kumar S, et al. (2011). A randomized control trial to verify the efficacy of pre-operative intra venous tranexamic Acid in the control of tonsillectomy bleeding. Indian journal of otolaryngology and head & neck surgery.
6336 Geva A, Brigger MT. (2011). Dexamethasone and tonsillectomy bleeding: a meta-analysis. Otolaryngol Head Neck Surg.
6337 Ghali AM, Mahfouz AK, Al-Bahrani M. (2011). Preanesthetic medication in children: A comparison of intranasal dexmedetomidine versus oral midazolam. Saudi J Anaesth.
6338 Ghosal N, Mais K, Shenjere P, et al. (2011). Phase II study of cisplatin and imatinib in advanced salivary adenoid cystic carcinoma. Br J Oral Maxillofac Surg.
6339 Gillespie NH. (2011). A consideration of the tonsil question. 1918. Minn Med.
6340 Giuca MR, Caputo E, Nastasio S, et al. (2011). Correlation between otitis media and dental malocclusion in children. Eur Arch Paediatr Dent.
6341 Gleinser DM, Kriel HH, Mukerji S. (2011). The relationship between repeat tympanostomy tube insertion and adenoidectomy. Int J Pediatr Otorhinolaryngol.
6342 Gomez AN, Diaz-Novas J, Bidot CJ. (2011). Bilateral ballism following streptococcal infection, associated with psychiatric disorder and purpura. BMJ Case Rep.
6343 Gotoh K, Ito Y, Maruo S, et al. (2011). Replication of Epstein-Barr virus primary infection in human tonsil tissue explants. PLoS One.
6344 Gourin CG, Forastiere AA, Sanguineti G, et al. (2011). Volume-based trends in surgical care of patients with oropharyngeal cancer. Laryngoscope.
6345 Grant RA, Heuer GG, Carrion GM, et al. (2011). Morphometric analysis of posterior fossa after in utero myelomeningocele repair. J Neurosurg Pediatr.
6346 Grindle CR, Curry JM, Cantor JP, et al. (2011). Localized oropharyngeal amyloidosis. Ear Nose Throat J.
6347 Grindle CR, Murray RC, Chennupati SK, et al. (2011). Incidence of revision adenoidectomy in children. Laryngoscope.
6348 Guilleminault C, Monteyrol PJ, Huynh NT, et al. (2011). Adeno-tonsillectomy and rapid maxillary distraction in pre-pubertal children, a pilot study. Sleep Breath.
6349 Guo WB, Sun XL, Liu L, et al. (2011). Disrupted regional homogeneity in treatment-resistant depression: a resting-state fMRI study. Prog Neuropsychopharmacol Biol Psychiatry.
6350 Habib M, Wahid F, Ullah I, et al. (2011). Peritonsillar abscess: is incision drainage superior to abscess tonsillectomy?. Annals of Pakistan Institute of Medical Sciences.
6351 Hadden SM, Burke CN, Skotcher S, et al. (2011). Early postoperative outcomes in children after adenotonsillectomy. J Perianesth Nurs.
6352 Hajr E, Hagr A, Al-Arfaj A, et al. (2011). Suction cautery adenoidectomy (SCA): is the additional cost justified?. Int J Pediatr Otorhinolaryngol.
6353 Hakl M, Lestiansky B, Haklova O. (2011). Etoricoxin in premedication before tonsillectomi. European Journal of Pain Supplements.
6354 Hall A, Lee M. (2011). Training for tonsillectomy: home-made Negus knot pusher. Clin Otolaryngol.
6355 Hansen TS, Jess T, Vind I, et al. (2011). Environmental factors in inflammatory bowel disease: a case-control study based on a Danish inception cohort. J Crohns Colitis.
6356 Hanss J, Nowak C, Decaux A, et al. (2011). Outpatient tonsillectomy in children: a 7-year experience. Eur Ann Otorhinolaryngol Head Neck Dis.
6357 Harabuchi Y. (2011). Clinical manifestations and pathogenesis of tonsillar focal diseases: IgA nephropathy and palmoplantar pustulosis. Adv Otorhinolaryngol.
6358 Hasan M, Kumar A. (2011). Actinomycosis and tonsillar disease. BMJ Case Rep.
6359 Hatemi G, Yazici H. (2011). Behcet's syndrome and micro-organisms. Best Pract Res Clin Rheumatol.
6360 Heffernan CB, Rafferty MA. (2011). Effect of tonsillectomy on the adult voice. J Voice.
6361 Hegarty M, Habre W, Erb T, et al. (2011). Extubation in children with a high risk for postoperative respiratory complications - Awake or anaesthetised?. Anaesthesia and Intensive Care.
6362 Heo KW, Hur DY, Park SK, et al. (2011). Expression of chitinases in hypertrophied adenoids of children. Otolaryngol Head Neck Surg.
6363 Hidaka H, Kuriyama S, Yano H, et al. (2011). Precipitating factors in the pathogenesis of peritonsillar abscess and bacteriological significance of the Streptococcus milleri group. Eur J Clin Microbiol Infect Dis.
6364 Hiki Y, Ito A, Yamamoto Y, et al. (2011). IgA nephropathy and aberrant glycosylation of tonsillar, serum and glomerular IgA1. Adv Otorhinolaryngol.
6365 Hill CA, Litvak A, Canapari C, et al. (2011). A pilot study to identify pre- and peri-operative risk factors for airway complications following adenotonsillectomy for treatment of severe pediatric OSA. Int J Pediatr Otorhinolaryngol.
6366 Hirunwiwatkul P, Kanjanaumporn J. (2011). Vessel sealing system uvulopalatoplasty versus uvulopalatal flap: a randomized, controlled study of efficacy and adverse effects. Eur Arch Otorhinolaryngol.
6367 Horii A, Hirose M, Mochizuki R, et al. (2011). Effects of cooling the pharyngeal mucosa after bipolar scissors tonsillectomy on postoperative pain. Acta Otolaryngol.
6368 Hornibrook J. (2011). More euphemisms for tonsillitis. Otolaryngol Head Neck Surg.
6369 Hotta O. (2011). Tonsillectomy with steroid pulse: a curative therapy for IgA nephropathy. Adv Otorhinolaryngol.
6370 Howard J, Malfroy M, Charlotte L, et al. (2011). Pre-operative transfusion reduces serious adverse events in patients with Sickle Cell Disease (SCD): Results from the Transfusion Alternatives Preoperatively in Sickle Cell Disease (TAPS) randomised controlled multicentre clinical trial. Blood.
6371 Hsieh TH, Chen PY, Huang FL, et al. (2011). Are empiric antibiotics for acute exudative tonsillitis needed in children?. J Microbiol Immunol Infect.
6372 Hurtuk A, Teknos T, Ozer E. (2011). Robotic-assisted lingual tonsillectomy. Laryngoscope.
6373 Huynh NT, Morton PD, Rompre PH, et al. (2011). Associations between sleep-disordered breathing symptoms and facial and dental morphometry, assessed with screening examinations. Am J Orthod Dentofacial Orthop.
6374 Hwang J, Han S, Hwang J, et al. (2011). The McIvor blade improves insertion of the LMA ProSeal in children. Can J Anaesth.
6375 Ifeacho S, Ajayi O, Hannan SA. (2011). Are randomised controlled trials involving adenotonsillectomy well reported?. Int J Pediatr Otorhinolaryngol.
6376 Imbeault M, Ouellet M, Giguere K, et al. (2011). Acquisition of host-derived CD40L by HIV-1 in vivo and its functional consequences in the B-cell compartment. J Virol.
6377 Inoue CN, Matsutani S, Ishidoya M, et al. (2011). Periodontal and ENT therapy in the treatment of pediatric Henoch-Schonlein purpura and IgA nephropathy. Adv Otorhinolaryngol.
6378 Iseri E, Ibiloglu A, Aydil U, et al. (2011). Stuttering after adenotonsillectomy and ventilation tube insertion. J Otolaryngol Head Neck Surg.
6379 Islam MR, Haq MF, Islam MA, et al. (2011). Preoperative use of granisetron plus dexamethasone and granisetron alone in prevention of post operative nausea and vomiting in tonsillectomy. Mymensingh Med J.
6380 Isrctn, Kontinet V. (2011). Topical anaesthesia for postoperative pain in adult patients undergoing tonsillectomy. ISRCTN.
6381 Itagaki T, Abiko C, Aoki Y, et al. (2011). Saffold cardiovirus infection in children associated with respiratory disease and its similarity to coxsackievirus infection. Pediatr Infect Dis J.
6382 Iwatani H, Iio K, Nagasawa Y, et al. (2011). Microarray analysis of tonsils of IgA nephropathy patients. Adv Otorhinolaryngol.
6383 Iwazu Y, Akimoto T, Muto S, et al. (2011). Clinical remission of Henoch-Schonlein purpura nephritis after a monotherapeutic tonsillectomy. Clin Exp Nephrol.
6384 Iynen I, Bozkus F, San I, et al. (2011). The hemostatic efficacy of Ankaferd Blood Stopper in adenoidectomy. Int J Pediatr Otorhinolaryngol.
6385 Jabbari Moghaddam Y, Bavil SG, Abavisani K. (2011). Do pre-adenotonsillectomy echocardiographic findings change postoperatively in children with severe adenotonsillar hypertrophy. J Saudi Heart Assoc.
6386 Jagannathan N, Wong DT. (2011). Successful tracheal intubation through an intubating laryngeal airway in pediatric patients with airway hemorrhage. J Emerg Med.
6387 Jain D, Chauhan JS, Jain S, et al. (2011). Elongated styloid process: an unusual cause of neck pain and difficulty in swallowing. J Orofac Pain.
6388 Jang YY, Lee KH. (2011). Transient asymptomatic white matter lesions following Epstein-Barr virus encephalitis. Korean J Pediatr.
6389 Janszky I, Mukamal KJ, Dalman C, et al. (2011). Childhood appendectomy, tonsillectomy, and risk for premature acute myocardial infarction--a nationwide population-based cohort study. Eur Heart J.
6390 Jarvis SJ, Millar JA, Pittore B, et al. (2011). Cerebral abscess following adenotonsillectomy: a rare complication. Acta Otorhinolaryngol Ital.
6391 Jaryszak EM, Lander L, Patel AK, et al. (2011). Prolonged recovery after out-patient pediatric adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
6392 Jaryszak EM, Shah RK, Vanison CC, et al. (2011). Polysomnographic variables predictive of adverse respiratory events after pediatric adenotonsillectomy. Arch Otolaryngol Head Neck Surg.
6393 Jeong HJ, Shin SY, Oh HA, et al. (2011). IL-32 up-regulation is associated with inflammatory cytokine production in allergic rhinitis. J Pathol.
6394 Jeyakumar A, Fettman N, Armbrecht ES, et al. (2011). A systematic review of adenotonsillectomy as a risk factor for childhood obesity. Otolaryngol Head Neck Surg.
6395 Jeyakumar A, Mitchell R. (2011). Response to: Weight gain after tonsillectomy. Otolaryngol Head Neck Surg.
6396 Jibaly R, Lachance J, Abuhammour W. (2011). Herpes simplex esophagitis: Report of 4 pediatric cases in immunocompetent patients. Journal of Pediatric Infectious Diseases.
6397 Jo YY, Chang YJ, Kim KS, et al. (2011). Anesthetic experience in a pediatric patient with mastocytosis. Korean Journal of Anesthesiology.
6398 Jones BF, Srinivasan V, Gumparthy K, et al. (2011). Leiomyosarcoma of the tonsil. J Laryngol Otol.
6399 Jones VM. (2011). Acetaminophen injection: a review of clinical information. J Pain Palliat Care Pharmacother.
6400 Joseph J, Stephens J, Stott D. (2011). Raised leucocyte levels as a marker for post tonsillectomy haemorrhage - A useful tool?. Otorhinolaryngologist.
6401 Josephson GD, Duckworth L, Hossain J. (2011). Proposed definitive grading system tool for the assessment of adenoid hyperplasia. Laryngoscope.
6402 Jung YG, Kim HY, Min JY, et al. (2011). Role of intranasal topical steroid in pediatric sleep disordered breathing and influence of allergy, sinusitis, and obesity on treatment outcome. Clin Exp Otorhinolaryngol.
6403 Jurecka A, Rozdzynska A, Marucha J, et al. (2011). Natural history of Polish patients with mucopolysaccharidosis type VI. Central European Journal of Medicine.
6404 Kadimella A. (2011). Migration of a GI Foreign Body into Retro Peritoneum Without Peritonitis. Indian J Surg.
6405 Kaditis AG, Chaidas K, Alexopoulos EI, et al. (2011). Effects of adenotonsillectomy on R-R interval and brain natriuretic peptide levels in children with sleep apnea: a preliminary report. Sleep Med.
6406 Kalorin CM, Mouzakes J, Gavin JP, et al. (2011). Tonsillectomy Does Not Improve Bed-wetting: Results of a Prospective Controlled Trial. Journal of wound, ostomy, and continence nursing.
6407 Kanai H, Sawanobori E, Kobayashi A, et al. (2011). Early treatment with methylprednisolone pulse therapy combined with tonsillectomy for heavy proteinuric henoch-schonlein purpura nephritis in children. Nephron Extra.
6408 Kaneko T, Hirama A, Ueda K, et al. (2011). Methylprednisolone pulse therapy combined with mizoribine following tonsillectomy for immunoglobulin A nephropathy: clinical remission rate, steroid sparing effect, and maintenance of renal function. Clin Exp Nephrol.
6409 Karatzanis A, Trompoukis C, Vlastos I, et al. (2011). On the history of modern tonsillectomy: the contribution of Nikolaos Taptas. Eur Arch Otorhinolaryngol.
6410 Kasapoglu F, Kaya FN, Tuzemen G, et al. (2011). Comparison of peritonsillar levobupivacaine and bupivacaine infiltration for post-tonsillectomy pain relief in children: placebo-controlled clinical study. Int J Pediatr Otorhinolaryngol.
6411 Kelishadi R, Nilforoushan N, Okhovat A, et al. (2011). Effects of adenoidectomy on markers of endothelial function and inflammation in normal-weight and overweight prepubescent children with sleep apnea. J Res Med Sci.
6412 Keller F, Psychogios G, Linke R, et al. (2011). Carcinoma of unknown primary in the head and neck: comparison between positron emission tomography (PET) and PET/CT. Head Neck.
6413 Kezirian EJ. (2011). Nonresponders to pharyngeal surgery for obstructive sleep apnea: insights from drug-induced sleep endoscopy. Laryngoscope.
6414 Khademi S, Ghaffarpasand F, Heiran HR, et al. (2011). Intravenous and peritonsillar infiltration of ketamine for postoperative pain after adenotonsillectomy: a randomized placebo-controlled clinical trial. Med Princ Pract.
6415 Khafagy YW, Mokbel KM. (2011). Choanal adenoid in adults with persistent nasal symptoms: endoscopic management to avoid misdiagnosis and unsuccessful surgeries. Eur Arch Otorhinolaryngol.
6416 Khan AM. (2011). Adenotonsillectomy outcomes in treatment of obstructive sleep apnea and children: a multicenter retrospective study. Am J Respir Crit Care Med.
6417 Khan MI, Khan A Muhammad. (2011). Peritonsillar abscess: clinical presentation and efficacy of incision and drainage under local anaesthesia. J Ayub Med Coll Abbottabad.
6418 Khan MKA, Manzoor T, Qayyum A, et al. (2011). Effect of preoperative dexamethasone on postoperative pain, emesis and haemorrhage in tonsillectomy by dissection method. Pakistan armed forces medical journal.
6419 Khedmat H, Taheri S. (2011). Post-transplantation lymphoproliferative disorders localizing in the adenotonsillar region: report from the PTLD.Int survey. Ann Transplant.
6420 Kheirandish-Gozal L, Dayyat EA, Eid NS, et al. (2011). Obstructive sleep apnea in poorly controlled asthmatic children: effect of adenotonsillectomy. Pediatr Pulmonol.
6421 Kim HY, Dhong HJ, Lee JK, et al. (2011). Sleep quality and effects of position on sleep apnea in East Asian children. Auris Nasus Larynx.
6422 Kim JH, Guilleminault C. (2011). The nasomaxillary complex, the mandible, and sleep-disordered breathing. Sleep Breath.
6423 Klug TE, Henriksen JJ, Fuursted K, et al. (2011). Similar recovery rates of Fusobacterium necrophorum from recurrently infected and non-infected tonsils. Dan Med Bull.
6424 Klug TE, Henriksen JJ, Fuursted K, et al. (2011). Significant pathogens in peritonsillar abscesses. Eur J Clin Microbiol Infect Dis.
6425 Knapik M, Saliba I. (2011). Pediatric myringoplasty: a study of factors affecting outcome. Int J Pediatr Otorhinolaryngol.
6426 Kobayashi R, Miyazaki S, Karaki M, et al. (2011). Measurement of nasal resistance by rhinomanometry in 892 Japanese elementary school children. Auris Nasus Larynx.
6427 Kobayashi S. (2011). Tonsil-related skin diseases and possible involvement of T cell co-stimulation in chronic focal infection. Adv Otorhinolaryngol.
6428 Kobayashi S, Ichikawa G. (2011). Reactive arthritis induced by tonsillitis: a type of ‘focal infection’. Adv Otorhinolaryngol.
6429 Koc S, Aksoy N, Bilinc H, et al. (2011). Paraoxonase and arylesterase activity and total oxidative/anti-oxidative status in patients with chronic adenotonsillitis. Int J Pediatr Otorhinolaryngol.
6430 Koc S, Gurbuzler L, Yenisehirli G, et al. (2011). The comparison of bacteremia and amount of bleeding during adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
6431 Kochar A, Tunkel DE. (2011). Hyponatremia after adenotonsillectomy: Not gone and best not forgotten. International Journal of Pediatric Otorhinolaryngology Extra.
6432 Koga T, Rikimaru T, Tokunaga N, et al. (2011). Evaluation of short-term clinical efficacy of 3-day therapy with azithromycin in comparison with 5-day cefcapene-pivoxyl for acute streptococcal tonsillopharyngitis in primary care. J Infect Chemother.
6433 Kolo ES, Ahmed AO, Kazeem MJ, et al. (2011). Plain radiographic evaluation of children with obstructive adenoids. Eur J Radiol.
6434 Komatsu H, Fujimoto S. (2011). Tonsillectomy combined with steroid pulse therapy induces clinical remission of IgA nephropathy. Adv Otorhinolaryngol.
6435 Kontorinis G, Schwab B. (2011). Significance of advanced haemostasis investigation in recurrent, severe post-tonsillectomy bleeding. J Laryngol Otol.
6436 Kordeluk S, Novack L, Puterman M, et al. (2011). Relation between peritonsillar infection and acute tonsillitis: myth or reality?. Otolaryngol Head Neck Surg.
6437 Kotowski M, Niedzielski A, Niedzielska G, et al. (2011). Dendritic cells and lymphocyte subpopulations of the adenoid in the pathogenesis of otitis media with effusion. Int J Pediatr Otorhinolaryngol.
6438 Kovacevic LG, Lakshmanan Y. (2011). Re: tonsillectomy does not improve bedwetting: results of a prospective controlled trial. C. M. Kalorin, J. Mouzakes, J. P. Gavin, T. D. Davis, P. Feustel and B. A. Kogan. J Urol 2010; 184: 2527-2531. J Urol.
6439 Krasny M, Wysocki J, Zadurska M, et al. (2011). Relative nasopharyngeal patency index as possible objective indication for adenoidectomy in children with orthodontic problems. Int J Pediatr Otorhinolaryngol.
6440 Krieger MD, Falkinstein Y, Bowen IE, et al. (2011). Scoliosis and Chiari malformation Type I in children. J Neurosurg Pediatr.
6441 Krishnan P, Rajendran P, Sambandan AP, et al. (2011). Evaluation of coamoxiclav and other antibiotics against S pneumoniae and H influenae from paediatric cases of acute respiratory infections. J Indian Med Assoc.
6442 Kubo K, Sakaki M, Ohashi M, et al. (2011). Expression of aryl hydrocarbon receptor and aryl hydrocarbon receptor nuclear translocators in human adenoid tissue. Auris Nasus Larynx.
6443 Kutluhan A, Salviz M, Yalciner G, et al. (2011). The role of the actinomyces in obstructive tonsillar hypertrophy and recurrent tonsillitis in pediatric population. Int J Pediatr Otorhinolaryngol.
6444 LaFrance DR, Traylor JG, Jin L. (2011). Aspiration pneumonia and esophagotracheal fistula secondary to button battery ingestion. Forensic Sci Med Pathol.
6445 Langille M, El-Hakim H. (2011). Pediatric inferior turbinoplasty with or without adenoidectomy: preliminary report on improvement of quality of life, symptom control, and safety. J Otolaryngol Head Neck Surg.
6446 Larrinaga G, Perez I, Sanz B, et al. (2011). Activity of soluble aminopeptidase A and dipeptidyl peptidase IV and membrane-bound aminopeptidase B and pyroglutamyl peptidase I in adenoid hyperplasia, tonsillar hyperplasia and chronic tonsillitis. Int J Pediatr Otorhinolaryngol.
6447 Larrinaga G, Perez I, Sanz B, et al. (2011). Altered dipeptidyl peptidase IV and prolyl endopeptidase activities in chronic tonsillitis, tonsillar hyperplasia and adenoid hyperplasia. Int J Pediatr Otorhinolaryngol.
6448 Larsson P, Nordlinder A, Bergendahl HT, et al. (2011). Oral bioavailability of clonidine in children. Paediatr Anaesth.
6449 Lee C, Song YK, Lee JH, et al. (2011). The effects of intraoperative adenosine infusion on acute opioid tolerance and opioid induced hyperalgesia induced by remifentanil in adult patients undergoing tonsillectomy. Korean Journal of Pain.
6450 Li J, Huang ZL, Zhang XT, et al. (2011). Sufentanil reduces emergence agitation in children receiving sevoflurane anesthesia for adenotonsillectomy compared with fentanyl. Chin Med J (Engl).
6451 Liadaki K, Petinaki E, Skoulakis C, et al. (2011). Toll-like receptor 4 gene (TLR4), but not TLR2, polymorphisms modify the risk of tonsillar disease due to Streptococcus pyogenes and Haemophilus influenzae. Clin Vaccine Immunol.
6452 Liodden I, Howley M, Grimsgaard AS, et al. (2011). Perioperative acupuncture and postoperative acupressure can prevent postoperative vomiting following paediatric tonsillectomy or adenoidectomy: a pragmatic randomised controlled trial. Acupunct Med.
6453 Liu CM, Cosetti MK, Aziz M, et al. (2011). The otologic microbiome: a study of the bacterial microbiota in a pediatric patient with chronic serous otitis media using 16SrRNA gene-based pyrosequencing. Arch Otolaryngol Head Neck Surg.
6454 Liu H, Peng Y, Liu F, et al. (2011). Expression of IgA class switching gene in tonsillar mononuclear cells in patients with IgA nephropathy. Inflamm Res.
6455 Lloyd S, Yu JB, Wilson LD, et al. (2011). Determinants and patterns of survival in adenoid cystic carcinoma of the head and neck, including an analysis of adjuvant radiation therapy. Am J Clin Oncol.
6456 Lo RH, Chang KP, Chu ST. (2011). Upper airway obstruction caused by bilateral giant tonsilloliths. J Chin Med Assoc.
6457 Lochindarat S, Bunnag T. (2011). Clinical presentations of pandemic 2009 influenza A (H1N1) virus infection in hospitalized Thai children. J Med Assoc Thai.
6458 Love RL, Allison R, Chambers ST. (2011). Peritonsillar infection in Christchurch 2006-2008: epidemiology and microbiology. N Z Med J.
6459 Lowe D, Brown P, Yung M. (2011). Adenoidectomy technique in the United Kingdom and postoperative hemorrhage. Otolaryngol Head Neck Surg.
6460 Luengo Gonzalez R. (2011). Adenotonsillectomy for obstructive sleep apnea in children. Am J Nurs.
6461 Lundeborg I, Ericsson E, Hultcrantz E, et al. (2011). Influence of adenotonsillar hypertrophy on /s/-articulation in children--effects of surgery. Logoped Phoniatr Vocol.
6462 Mackay GA, Knight RSG, Ironside JW. (2011). The molecular epidemiology of variant CJD. International Journal of Molecular Epidemiology and Genetics.
6463 Maeda K, Tsuiki S, Nakata S, et al. (2011). Are children easily predisposed to obstructive sleep apnea?. Sleep and Biological Rhythms.
6464 Malik S, Wadhwani J, Zafar S, et al. (2011). Analgesic efficacy of topical tramadol in the control of postoperative pain in children after tonsillectomy. Anaesthesia, Pain and Intensive Care.
6465 Manjaly JG, Smith HK. (2011). Re: Appraisal of litigation against English Health Trusts in the treatment of adults with ENT pathology. Clin Otolaryngol.
6466 Mannina EM, Pejavar SM, Glastonbury CM, et al. (2011). Diagnosis of Bilateral Tonsil Cancers via Staging PET/CT: Case Report and Review. Int J Otolaryngol.
6467 Mansson A, Bogefors J, Cervin A, et al. (2011). NOD-like receptors in the human upper airways: a potential role in nasal polyposis. Allergy.
6468 Mariano FV, da Silva SD, Chulan TC, et al. (2011). Clinicopathological factors are predictors of distant metastasis from major salivary gland carcinomas. Int J Oral Maxillofac Surg.
6469 Marthas ML, Van Rompay KK, Abbott Z, et al. (2011). Partial efficacy of a VSV-SIV/MVA-SIV vaccine regimen against oral SIV challenge in infant macaques. Vaccine.
6470 Martinez-Rodriguez N, Leco-Berrocal I, Rubio-Alonso L, et al. (2011). Epidemiology and treatment of adenoid cystic carcinoma of the minor salivary glands: a meta-analytic study. Med Oral Patol Oral Cir Bucal.
6471 Marzouk HA, Nathawad R, Hammerschlag MR, et al. (2011). Methicillin-resistant Staphylococcus aureus colonization in otitis-prone children. Arch Otolaryngol Head Neck Surg.
6472 Massimi L, Pravata E, Tamburrini G, et al. (2011). Endoscopic third ventriculostomy for the management of Chiari I and related hydrocephalus: outcome and pathogenetic implications. Neurosurgery.
6473 Mathiesen O, Jørgensen DG, Hilsted KL, et al. (2011). Pregabalin and dexamethasone improves post-operative pain treatment after tonsillectomy. Acta anaesthesiologica Scandinavica.
6474 Mattar SE, Valera FC, Faria G, et al. (2011). Changes in facial morphology after adenotonsillectomy in mouth-breathing children. Int J Paediatr Dent.
6475 Mauer UM, Gottschalk A, Mueller C, et al. (2011). Standard and cardiac-gated phase-contrast magnetic resonance imaging in the clinical course of patients with Chiari malformation Type I. Neurosurg Focus.
6476 McCormick ME, Sheyn A, Haupert M, et al. (2011). Predicting complications after adenotonsillectomy in children 3 years old and younger. Int J Pediatr Otorhinolaryngol.
6477 Mehta AI, Grant GA, Gray L, et al. (2011). Radiographic progression of a Chiari I malformation after minor head trauma: Final increment of obstruction to create pathophysiology. Journal of Surgical Radiology.
6478 Mehta VA, Bettegowda C, Amin A, et al. (2011). Impact of tethered cord release on symptoms of Chiari II malformation in children born with a myelomeningocele. Childs Nerv Syst.
6479 Meighani G, Aghamohammadi A, Javanbakht H, et al. (2011). Oral and dental health status in patients with primary antibody deficiencies. Iran J Allergy Asthma Immunol.
6480 Mello MF, Costa AF, Freitas LL, et al. (2011). Lymphatic vessel density and expressions of lymphangiogenic growth factors in salivary carcinomas. Neoplasma.
6481 Meyer E, fagan JJ. (2011). Tonsillectomy practice in South Africa. S Afr Med J.
6482 Miller ME, Elashoff DA, Abemayor E, et al. (2011). Tonsillar squamous cell carcinoma: are we making a difference?. Otolaryngol Head Neck Surg.
6483 Minetti AM, Forti S, Tassone G, et al. (2011). Efficacy of complex herbal compound of Echinacea angustifolia (Imoviral(R) Junior) in recurrent upper respiratory tract infections during pediatric age: preliminary results. Minerva Pediatr.
6484 Mitka M. (2011). Guideline cites appropriateness criteria for performing tonsillectomy in children. Jama.
6485 Modrzynski M. (2011). Video glasses in endoscopy in children--a preliminary report. Otolaryngol Pol.
6486 Molina FD, Santos FC, Falleiros LR, et al. (2011). Microscopical evaluation of extracellular matrix and its relation to the palatopharyngeal muscle in obstructive sleep apnea. Microsc Res Tech.
6487 Montgomery-Downs HE, Ramadan HH, Clawges HC, et al. (2011). Digital oral photography for pediatric tonsillar hypertrophy grading. Int J Pediatr Otorhinolaryngol.
6488 Moriyama T, Nitta K. (2011). Tonsillectomy and steroid pulse therapy for IgA nephropathy. Tohoku J Exp Med.
6489 Mosges R, Hellmich M, Allekotte S, et al. (2011). Hemorrhage rate after coblation tonsillectomy: a meta-analysis of published trials. Eur Arch Otorhinolaryngol.
6490 Moss JR, Cofer S, Hersey S, et al. (2011). Comparison of clonidine, local anesthetics, and placebo for pain reduction in pediatric tonsillectomy. Arch Otolaryngol Head Neck Surg.
6491 Mottolese C, Szathmari A, Simon E, et al. (2011). Treatment of Chiari type I malformation in children: the experience of Lyon. Neurol Sci.
6492 Mowafi HA, Telmessani L, Ismail SA, et al. (2011). Preoperative lornoxicam for pain prevention after tonsillectomy in adults. J Clin Anesth.
6493 Muhammad Izani S, Irfan M, Suhaimi Y. (2011). A child with epistaxis, reduced hearing and cervical lymphadenopathy: a rare case of nasopharyngeal carcinoma in a child. Malays Fam Physician.
6494 Mutiso MD, MacHaria IM. (2011). Single intraoperative intravenous Co-Amoxiclav versus postoperative full oral course in prevention of postadenotonsillectomy morbidity: A randomised clinical trial Mutiso Musyoka D. BMC Ear, Nose and Throat Disorders.
6495 Muzumdar HV, Sin S, Nikova M, et al. (2011). Changes in heart rate variability after adenotonsillectomy in children with obstructive sleep apnea. Chest.
6496 Myoung J, Ganem D. (2011). Active lytic infection of human primary tonsillar B cells by KSHV and its noncytolytic control by activated CD4+ T cells. J Clin Invest.
6497 Nair S, Sridhar KR, Shah A, et al. (2011). Maxillectomy through mandibulotomy--a retrospective clinical review. J Oral Maxillofac Surg.
6498 Nakaseko H, Uemura O, Nagai T, et al. (2011). High prevalence of sinusitis in children with henoch-schonlein purpura. Int J Pediatr.
6499 Nakayama M. (2011). Seasonal changes of obstructive sleep apnea syndrome (OSAS) in children. Sleep and Biological Rhythms.
6500 Nam JG, Lee TH, Kwon JK, et al. (2011). Effect of fibrin-coated collagen fleece (TachoComb) on pain and bleeding after adenotonsillectomy in children. Acta Otolaryngol.
6501 Nelson ME, Gernon TJ, Taylor JC, et al. (2011). Pathologic evaluation of routine pediatric tonsillectomy specimens: analysis of cost-effectiveness. Otolaryngol Head Neck Surg.
6502 Nishimura Y, Nakata S, Kojima T, et al. (2011). A comparison between pre and postoperative sleep structures in pediatric obstructive sleep apnea patients. Sleep and Biological Rhythms.
6503 Nistico L, Kreft R, Gieseke A, et al. (2011). Adenoid reservoir for pathogenic biofilm bacteria. J Clin Microbiol.
6504 Noda S, Asano Y, Sato S. (2011). Pityriasis lichenoides et varioliformis acuta exacerbated after tonsillectomy. Eur J Dermatol.
6505 Norheim AJ. (2011). Integrating the results of research on acupuncture for nausea at the research site. Acupunct Med.
6506 Ntr. (2011). Conventional tonsillectomy versus outpatient CO2-lasertonsillotomy in adult patients; a randomised controlled trial - ‘sMOKE-protocol’. NTR.
6507 Nurliza I, Norzi G, Azlina A, et al. (2011). Daycare tonsillectomy: a safe outpatient procedure. Hospital Sultanah Bahiyah, Alor Setar Malaysia experience. Med J Malaysia.
6508 O'Brien LM. (2011). The neurocognitive effects of sleep disruption in children and adolescents. Sleep Medicine Clinics.
6509 Ohara S, Kawasaki Y, Matsuura H, et al. (2011). Successful therapy with tonsillectomy for severe ISKDC grade VI Henoch-Schonlein purpura nephritis and persistent nephrotic syndrome. Clin Exp Nephrol.
6510 Okabe T, Takeda S, Hida M, et al. (2011). Study of T serotypes and Emm genotypes of Streptococcus pyogenes in children with pharyngitis and tonsillitis. J Nippon Med Sch.
6511 Okunlola MA, Owonikoko KM, Adeleke AO, et al. (2011). Fertility regulation among women of reproductive age in Ibadan, south-west Nigeria: contraception, abortion or both. Niger Postgrad Med J.
6512 Olaleye O, Moorthy R, Lyne O, et al. (2011). A 20-year retrospective study of tonsil cancer incidence and survival trends in South East England: 1987-2006. Clin Otolaryngol.
6513 Oliveira LR, Soave DF, Oliveira-Costa JP, et al. (2011). Prognostic factors in patients with malignant salivary gland neoplasms in a Brazilian population. Asian Pac J Cancer Prev.
6514 Olutoye OA, Watcha MF, Andropoulos DB. (2011). Pediatric obesity: observed impact in the ambulatory surgery setting. J Natl Med Assoc.
6515 Otuztuzun S, Kilic M, Aydin S. (2011). Evaluation of immunohistochemical expression of antimicrobial peptides in patients with tonsillitis and adenoiditis, Tonsillit ve adenoidit hastalarinda antimikrobiyal peptitlerin ekspresyonlarinin immunohistokimyasal olarak deterlendirilmesi. [Turkish, English]. Turkish Journal of Biochemistry.
6516 Owens D, Fox R, Harrison W, et al. (2011). Re: Improvement in quality of life by adenotonsillectomy in children with adenotonsillar disease. Clin Otolaryngol.
6517 Ozmen OA, Ozmen S. (2011). Topical bupivacaine compared to lidocaine with epinephrine for post-tonsillectomy pain relief in children: a randomized controlled study. Int J Pediatr Otorhinolaryngol.
6518 Ozmen S, Ozmen OA, Kasapoglu F. (2011). Effects of levobupivacaine versus bupivacaine infiltration on postoperative analgesia in pediatric tonsillectomy patients: a randomized, double-blind, placebo-controlled study. Ann Otol Rhinol Laryngol.
6519 Pagella F, Pusateri A, Chu F, et al. (2011). Adenoid assessment in paediatric patients: the role of flexible nasal endoscopy. Int J Immunopathol Pharmacol.
6520 Papacharalampous GX, Vlastarakos PV, Kotsis G, et al. (2011). Bilateral peritonsillar abscesses: A case presentation and review of the current literature with regard to the controversies in diagnosis and treatment. Case Reports in Medicine.
6521 Park CW, Chung JH, Min HJ, et al. (2011). Helicobacter pylori in middle ear of children with otitis media with effusion. Chin Med J (Engl).
6522 Park E, Pransky SM, Malicki DM, et al. (2011). Unilateral lymphangiomatous polyp of the palatine tonsil in a very young child: a clinicopathologic case report. Case Rep Pediatr.
6523 Park JO, Jung CK, Sun DI, et al. (2011). Relationships between metastasis-associated protein (MTA) 1 and lymphatic metastasis in tonsil cancer. Eur Arch Otorhinolaryngol.
6524 Park K. (2011). Otitis media and tonsils--role of adenoidectomy in the treatment of chronic otitis media with effusion. Adv Otorhinolaryngol.
6525 Parker NP, Walner DL. (2011). Trends in the indications for pediatric tonsillectomy or adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
6526 Passali D, De Benedetto M, Lauriello M, et al. (2011). Influence of Waldeyer's ring hypertrophy on snoring and sleep apnea. Adv Otorhinolaryngol.
6527 Peng A, Dodson KM, Thacker LR, et al. (2011). Use of laryngeal mask airway in pediatric adenotonsillectomy. Arch Otolaryngol Head Neck Surg.
6528 Peota C. (2011). A new look at an old standby. Minn Med.
6529 Pereira SR, Bakor SF, Weckx LL. (2011). Adenotonsillectomy in facial growing patients: spontaneous dental effects. Braz J Otorhinolaryngol.
6530 Pestieau SR, Quezado ZM, Johnson YJ, et al. (2011). High-dose dexmedetomidine increases the opioid-free interval and decreases opioid requirement after tonsillectomy in children. Can J Anaesth.
6531 Phoenix A, Valiathan M, Nelson S, et al. (2011). Changes in hyoid bone position following rapid maxillary expansion in adolescents. Angle Orthod.
6532 Piessens P, Indesteege F, Lemkens P. (2011). Alice in Wonderland syndrome and upper airway obstruction in infectious mononucleosis. B-ent.
6533 Pinder DK, Wilson H, Hilton MP. (2011). Dissection versus diathermy for tonsillectomy. Cochrane Database Syst Rev.
6534 Pinder DK WH, Hilton MP. (2011). Dissection versus diathermy for tonsillectomy (Review). Cochrane Database of Systematic Reviews.
6535 Piplani S, Manjari M, Sarin V, et al. (2011). Neurilemmoma masquerading as tonsillitis: A case report. Journal of Clinical and Diagnostic Research.
6536 Pirila-Parkkinen K, Lopponen H, Nieminen P, et al. (2011). Validity of upper airway assessment in children: a clinical, cephalometric, and MRI study. Angle Orthod.
6537 Piumetto E, Sammartano AM, Meinardi G, et al. (2011). Diagnostic and therapeutic iter in paediatric OSAS: personal experience. Acta Otorhinolaryngol Ital.
6538 Popescu GA, Gavriliu LC. (2011). Severe sepsis in a patient with retropharyngeal abscess due to streptococcus acidominimus. Infectious Diseases in Clinical Practice.
6539 Portnof JE, Heggie AA, Kleid S. (2011). Tonsilloliths appearing as multiple opacities on panoramic imaging: case report. Gen Dent.
6540 Post JC. (2011). Genetics of otitis media. Adv Otorhinolaryngol.
6541 Powell SM, Tremlett M, Bosman DA. (2011). Quality of life of children with sleep-disordered breathing treated with adenotonsillectomy. J Laryngol Otol.
6542 Prabhu V, Ingrams D. (2011). First branchial arch fistula: diagnostic dilemma and improvised surgical management. Am J Otolaryngol.
6543 Prasad KC, Prasad SC. (2011). Assessment of Operative Blood Loss and the Factors Affecting it in Tonsillectomy and Adenotonsillectomy. Indian J Otolaryngol Head Neck Surg.
6544 Qteshat BS. (2011). Use of oral clonidine and oral midazolam as preanesthetic medications in the pediatric patient undergoing tonsillectomy. Rawal Medical Journal.
6545 Raeder J. (2011). Ambulatory anesthesia aspects for tonsillectomy and abrasion in children. Curr Opin Anaesthesiol.
6546 Randel A. (2011). AAO-HNS Guidelines for Tonsillectomy in Children and Adolescents. Am Fam Physician.
6547 Randerath WJ, Verbraecken J, Andreas S, et al. (2011). Non-CPAP therapies in obstructive sleep apnoea. Eur Respir J.
6548 Randhawa PS, Cetto R, Chilvers G, et al. (2011). Long-term quality-of-life outcomes in children undergoing adenotonsillectomy for obstructive sleep apnoea: a longitudinal study. Clin Otolaryngol.
6549 Rantala A, Jaakkola JJ, Jaakkola MS. (2011). Respiratory infections precede adult-onset asthma. PLoS One.
6550 Raslan OA, Schellingerhout D, Fuller GN, et al. (2011). Rosai-Dorfman disease in neuroradiology: imaging findings in a series of 10 patients. AJR Am J Roentgenol.
6551 Rastatter JC, Schroeder JW, French A, et al. (2011). Synchronous airway lesions in children younger than age 3 years undergoing adenotonsillectomy. Otolaryngol Head Neck Surg.
6552 Rawlinson E, Walker A, Skone R, et al. (2011). A randomised controlled trial of two analgesic techniques for paediatric tonsillectomy*. Anaesthesia.
6553 Redline S, Amin R, Beebe D, et al. (2011). The Childhood Adenotonsillectomy Trial (CHAT): rationale, design, and challenges of a randomized controlled trial evaluating a standard surgical procedure in a pediatric population. Sleep.
6554 Regmi D, Mathur NN, Bhattarai M. (2011). Rigid endoscopic evaluation of conventional curettage adenoidectomy. J Laryngol Otol.
6555 Reid D, Morton R, Salkeld L, et al. (2011). Vitamin D and tonsil disease--preliminary observations. Int J Pediatr Otorhinolaryngol.
6556 Reid S, Cawthon PM, Craig JC, et al. (2011). Non-immunosuppressive treatment for IgA nephropathy. Cochrane Database Syst Rev.
6557 Rekhi B, Sethi S, Kulkarni SS, et al. (2011). Kaposiform hemangioendothelioma in tonsil of a child associated with cervical lymphangioma: a rare case report. World J Surg Oncol.
6558 Restrepo C, Santamaria A, Pelaez S, et al. (2011). Oropharyngeal airway dimensions after treatment with functional appliances in class II retrognathic children. J Oral Rehabil.
6559 Revell SM, Clark WD. (2011). Late-onset laryngomalacia: a cause of pediatric obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
6560 Revenaugh PC, Chmielewski LJ, Edwards T, et al. (2011). Utility of preoperative cardiac evaluation in pediatric patients undergoing surgery for obstructive sleep apnea. Arch Otolaryngol Head Neck Surg.
6561 Ribeiro JC, Rui C, Natercia S, et al. (2011). Tympanoplasty in children: A review of 91 cases. Auris Nasus Larynx.
6562 Richmon JD, Agrawal N, Pattani KM. (2011). Implementation of a TORS program in an academic medical center. Laryngoscope.
6563 Riha RL. (2011). Just sleep apnoea?. Breathe.
6564 Robb PJ, Ewah BN. (2011). Post-operative nausea and vomiting following paediatric day-case tonsillectomy: audit of the Epsom protocol. J Laryngol Otol.
6565 Robison JG, Otteson TD. (2011). Increased prevalence of obstructive sleep apnea in patients with cleft palate. Arch Otolaryngol Head Neck Surg.
6566 Roby BB, Drehner D, Sidman JD. (2011). Pediatric tracheal and endobronchial tumors: an institutional experience. Arch Otolaryngol Head Neck Surg.
6567 Rodriguez-Hernandez A, Lawton MT. (2011). Anatomical triangles defining surgical routes to posterior inferior cerebellar artery aneurysms. J Neurosurg.
6568 Rohail A, Malik KI, Sheikh TA, et al. (2011). Frequency of secondary hemorrhage after suture technique to control bleeding in the patients undergoing tonsillectomy. Pakistan Journal of Medical and Health Sciences.
6569 Roland PS, Rosenfeld RM, Brooks LJ, et al. (2011). Clinical practice guideline: Polysomnography for sleep-disordered breathing prior to tonsillectomy in children. Otolaryngol Head Neck Surg.
6570 Rosen D. (2011). Management of obstructive sleep apnea associated with Down syndrome and other craniofacial dysmorphologies. Curr Opin Pulm Med.
6571 Rosen D, Lombardo A, Skotko B, et al. (2011). Parental perceptions of sleep disturbances and sleep-disordered breathing in children with Down syndrome. Clin Pediatr (Phila).
6572 Rotenberg B, Tan S. (2011). Endoscopic-assisted radiofrequency lingual tonsillectomy. Laryngoscope.
6573 Ruperto N, Carozzino L, Jamone R, et al. (2011). A randomized, double-blind, placebo-controlled trial of paracetamol and ketoprofren lysine salt for pain control in children with pharyngotonsillitis cared by family pediatricians. Ital J Pediatr.
6574 Sade K, Fishman G, Kivity S, et al. (2011). Expression of Th17 and Treg lymphocyte subsets in hypertrophied adenoids of children and its clinical significance. Immunol Invest.
6575 Sadeghi-Shabestari M, Jabbari Moghaddam Y, Ghaharri H. (2011). Is there any correlation between allergy and adenotonsillar tissue hypertrophy?. Int J Pediatr Otorhinolaryngol.
6576 Saedi B, Sadeghi M, Mojtahed M, et al. (2011). Diagnostic efficacy of different methods in the assessment of adenoid hypertrophy. Am J Otolaryngol.
6577 Safoura S, Mohamad E, Nosrat-Allah E, et al. (2011). Immunohistochemical expression of progesterone receptors in pleomorphic adenoma and adenoid cystic carcinoma. J Cancer Res Ther.
6578 Saldanha G, Potter L, Dyall L, et al. (2011). Detection of copy number changes in DNA from formalin fixed paraffin embedded tissues using paralogue ratio tests. Anal Chem.
6579 Samaniego EA, Linfante I, Dabus G. (2011). Endovascular treatment of a post-tonsillectomy hemorrhage due to a pseudoaneurysm of the ascending palatine artery. International Journal of Pediatric Otorhinolaryngology Extra.
6580 Sanchez Hernandez A, Soliveres J, Hernandez MJ, et al. (2011). Perioperative anxiety management in paediatric anaesthesia. European journal of anaesthesiology.
6581 Sarhan MM, Aldehayat GS. (2011). Preanesthetic medication using oral midazolam in children undergoing tonsillectomy under general anesthesia. Rawal Medical Journal.
6582 Sarny S, Habermann W, Ossimitz G, et al. (2011). Tonsilar haemorrhage and re-admission: a questionnaire based study. Eur Arch Otorhinolaryngol.
6583 Sasaki T, Tsunoda K. (2011). How I do it: chopsticks technique for hemostasis in tonsillectomy. Eur Arch Otorhinolaryngol.
6584 Scarff JR, Iftikhar B, Tatugade A, et al. (2011). Opsoclonus myoclonus. Innovations in Clinical Neuroscience.
6585 Schluter B, De Sousa G, Trowitzsch E, et al. (2011). Diagnostics and management of sleep-related respiratory disturbances in children with skeletal dysplasia caused by FGFR3 mutations (achondroplasia and hypochondroplasia). Georgian Med News.
6586 Schuchmann S, Hauck S, Henning S, et al. (2011). Respiratory alkalosis in children with febrile seizures. Epilepsia.
6587 Schwarz S, Muller M, Ettl T, et al. (2011). Morphological heterogeneity of oral salivary gland carcinomas: a clinicopathologic study of 41 cases with long term follow-up emphasizing the overlapping spectrum of adenoid cystic carcinoma and polymorphous low-grade adenocarcinoma. Int J Clin Exp Pathol.
6588 Setabutr D, Adil EA, Adil TK, et al. (2011). Emerging trends in tonsillectomy. Otolaryngol Head Neck Surg.
6589 Sethi A, Sethi D, Bansal R. (2011). True hamartoma of the tonsil. Indian J Otolaryngol Head Neck Surg.
6590 Sevilla DW, Murty VV, Sun XL, et al. (2011). Cytogenetic abnormalities in reactive lymphoid hyperplasia: byproducts of the germinal centre reaction or indicators of lymphoma?. Hematol Oncol.
6591 Shadmehr MB, Farzanegan R, Graili P, et al. (2011). Primary major airway tumors; management and results. Eur J Cardiothorac Surg.
6592 Shah GH, Panwar SK, Chaturvedi PP, et al. (2011). Isolated primary extranodal lymphoma of the oral cavity: A series of 15 cases and review of literature from a tertiary care cancer centre in India. Indian J Med Paediatr Oncol.
6593 Shah S, Haughton V, del Rio AM. (2011). CSF flow through the upper cervical spinal canal in Chiari I malformation. AJNR Am J Neuroradiol.
6594 Shapiro NL, Tang CG, Bhattacharyya N. (2011). Association between Epstein-Barr virus seroconversion and immunohistochemical changes in tonsils of pediatric solid organ transplant recipients. Laryngoscope.
6595 Sharma K, Kumar D. (2011). Ligation versus bipolar diathermy for hemostasis in tonsillectomy: a comparative study. Indian journal of otolaryngology and head & neck surgery.
6596 Sharma PB, Baroody F, Gozal D, et al. (2011). Obstructive sleep apnea in the formerly preterm infant: an overlooked diagnosis. Front Neurol.
6597 Sheetal D, Devan PP, Manjunath P, et al. (2011). Inflammatory myofibroblastic tumour of tonsil (fourth case in literature). Biomedicine.
6598 Shen Y, Xu Z, Shen K. (2011). Urinary leukotriene E4, obesity, and adenotonsillar hypertrophy in Chinese children with sleep disordered breathing. Sleep.
6599 Shimada N, Hirabayashi Y. (2011). Tonsillar injury caused by the Airtraq optical laryngoscope in children. J Clin Anesth.
6600 Shinder R, Al-Zubidi N, Esmaeli B. (2011). Survey of orbital tumors at a comprehensive cancer center in the United States. Head Neck.
6601 Shott SR. (2011). Evaluation and management of pediatric obstructive sleep apnea beyond tonsillectomy and adenoidectomy. Curr Opin Otolaryngol Head Neck Surg.
6602 Silva P, Varadarajan V, Loughran S. (2011). Tonsillectomy: a routine procedure?. Br J Hosp Med (Lond).
6603 Silvola J, Salonen A, Nieminen J, et al. (2011). Tissue welding tonsillectomy provides an enhanced recovery compared to that after monopolar electrocautery technique in adults: a prospective randomized clinical trial. European archives of oto-rhino-laryngology.
6604 Simsek A, Perek A, Cakcak IE, et al. (2011). Pelvic actinomycosis presenting as a malignant pelvic mass: a case report. J Med Case Rep.
6605 Sink J, Kademani D. (2011). Maxillofacial oncology at the University of Minnesota: treating the epidemic of oral cancer. Northwest Dent.
6606 Sitton M, Arvedson J, Visotcky A, et al. (2011). Fiberoptic Endoscopic Evaluation of Swallowing in children: feeding outcomes related to diagnostic groups and endoscopic findings. Int J Pediatr Otorhinolaryngol.
6607 Skilbeck CJ, Jeannon JP, O'Connell M, et al. (2011). Squamous cell carcinoma of the tonsillar remnant--clinical presentation and oncological outcome. Head Neck Oncol.
6608 Smith JK, Alexander S, Abrahamson E. (2011). Ambulatory intravenous ceftriaxone in paediatric A&E: a useful alternative to hospital admission?. Emerg Med J.
6609 Smith LP, Roy S. (2011). Operating room fires in otolaryngology: risk factors and prevention. Am J Otolaryngol.
6610 Sowmya B, Raghavendra P. (2011). Management of dental trauma to a developing permanent tooth during endotracheal intubation. Journal of Anaesthesiology Clinical Pharmacology.
6611 Spurr KF, Morrison DL, Graven MA, et al. (2011). Characterizing obstructive sleep apnea and its management in paediatric and adolescent patients hospitalized in Canada. Canadian Journal of Respiratory Therapy.
6612 Steiniger B, Trabandt M, Barth PJ. (2011). The follicular dendritic cell network in secondary follicles of human palatine tonsils and spleens. Histochem Cell Biol.
6613 Steward David L, Grisel J, Meinzen-Derr J. (2011). Steroids for improving recovery following tonsillectomy in children. Cochrane Database of Systematic Reviews.
6614 Stewart MG, Liotta DR. (2011). Is partial tonsillectomy equivalent to total tonsillectomy for obstructive symptoms?. Laryngoscope.
6615 Strahle J, Muraszko KM, Buchman SR, et al. (2011). Chiari malformation associated with craniosynostosis. Neurosurg Focus.
6616 Strahle J, Muraszko KM, Kapurch J, et al. (2011). Natural history of Chiari malformation Type I following decision for conservative treatment. J Neurosurg Pediatr.
6617 Strahle J, Muraszko KM, Kapurch J, et al. (2011). Chiari malformation Type I and syrinx in children undergoing magnetic resonance imaging. J Neurosurg Pediatr.
6618 Sun GH, Harmych BM, Dickson JM, et al. (2011). Characteristics of children diagnosed as having coagulopathies following posttonsillectomy bleeding. Arch Otolaryngol Head Neck Surg.
6619 Suratt PM, Diamond R, Barth JT, et al. (2011). Movements during sleep correlate with impaired attention and verbal and memory skills in children with adenotonsillar hypertrophy suspected of having obstructive sleep disordered breathing. Sleep Med.
6620 Sutters KA. (2011). In response. Clinical journal of pain.
6621 Sutters KA, Savedra MC, Miaskowski C. (2011). The pediatric PRO-SELF(c): pain control program: an effective educational program for parents caring for children at home following tonsillectomy. J Spec Pediatr Nurs.
6622 Suzuki Y, Suzuki H, Nakata J, et al. (2011). Pathological role of tonsillar B cells in IgA nephropathy. Clin Dev Immunol.
6623 Sylvester DC, Rafferty A, Bew S, et al. (2011). The use of ice-lollies for pain relief post-paediatric tonsillectomy. A single-blinded, randomised, controlled trial. Clin Otolaryngol.
6624 Taheri R, Seyedhejazi M, Ghojazadeh M, et al. (2011). Comparison of ketamine and fentanyl for postoperative pain relief in children following adenotonsillectomy. Pak J Biol Sci.
6625 Taipale A, Pelkonen T, Taipale M, et al. (2011). Otorhinolaryngological findings and hearing in HIV-positive and HIV-negative children in a developing country. Eur Arch Otorhinolaryngol.
6626 Takahara M. (2011). Clinical outcome of tonsillectomy for palmoplantar pustulosis and etiological relationship between palmoplantar pustulosis and tonsils. Adv Otorhinolaryngol.
6627 Takemoto Y, Saitoh I, Iwasaki T, et al. (2011). Pharyngeal airway in children with prognathism and normal occlusion. Angle Orthod.
6628 Tamashiro E. (2011). Comparative, prospective and randomized study on post-tonsillectomy/adenotonsillectomy pain control in children.
6629 Tang QL, Chen WL, Tan XY, et al. (2011). Expression and significance of Cyr61 in distant metastasis cells of human primary salivary adenoid cystic carcinoma. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
6630 Tanyeri HM, Polat S. (2011). Temperature-controlled radiofrequency tonsil ablation for the treatment of halitosis. Eur Arch Otorhinolaryngol.
6631 Tatlipinar A, Cimen B, Duman D, et al. (2011). Effect of adenotonsillectomy on endothelin-1 and C-reactive protein levels in children with sleep-disordered breathing. Otolaryngol Head Neck Surg.
6632 Taylan I, Ozcan I, Mumcuoglu I, et al. (2011). Comparison of the surface and core bacteria in tonsillar and adenoid tissue with Beta-lactamase production. Indian J Otolaryngol Head Neck Surg.
6633 Ter Haar NM, Frenkel J. (2011). Therapy of autoinflammatory diseases: A review of the literature. Pediatric Rheumatology.
6634 Togawa A, Hotomi M, Tamura S, et al. (2011). Clinical scoring system of acute pharyngotonsillitis. Adv Otorhinolaryngol.
6635 Tokumaru Y, Fujii M, Yane K, et al. (2011). Human papillomavirus in oropharyngeal squamous cell carcinoma-A multicenter prospective study in Japan. Japanese Journal of Head and Neck Cancer.
6636 Tomino Y. (2011). Pathogenetic and therapeutic approaches to IgA nephropathy using a spontaneous animal model, the ddY mouse. Clin Exp Nephrol.
6637 Toros SZ, Toros AB, Kaya KS, et al. (2011). A study to detect Helicobacter pylori in adenotonsillar tissue. Ear Nose Throat J.
6638 Torretta S, Drago L, Marchisio P, et al. (2011). Diagnostic accuracy of nasopharyngeal swabs in detecting biofilm-producing bacteria in chronic adenoiditis: a preliminary study. Otolaryngol Head Neck Surg.
6639 Torretta S, Marchisio P, Esposito S, et al. (2011). Diagnostic accuracy of the nasal obstruction index in detecting adenoid hypertrophy in children without allergy. Int J Pediatr Otorhinolaryngol.
6640 Torretta S, Marchisio P, Esposito S, et al. (2011). Exhaled nitric oxide levels in children with chronic adenotonsillar disease. Int J Immunopathol Pharmacol.
6641 Tripathi A, Jerrell JM, Stallworth JR. (2011). Cost-effectiveness of adenotonsillectomy in reducing obstructive sleep apnea, cerebrovascular ischemia, vaso-occlusive pain, and ACS episodes in pediatric sickle cell disease. Ann Hematol.
6642 Tsai HP, Huang SW, Wu FL, et al. (2011). An echovirus 18-associated outbreak of aseptic meningitis in Taiwan: epidemiology and diagnostic and genetic aspects. J Med Microbiol.
6643 Tschopp K, Zumbrunn T, Knaus C, et al. (2011). Statistical model for postoperative apnea-hypopnea index after multilevel surgery for sleep-disordered breathing. European archives of oto-rhino-laryngology.
6644 Tweedie DJ, Bajaj Y, Ifeacho SN, et al. (2011). Use of a post-operative nasopharyngeal prong airway after adenotonsillectomy in children with obstructive sleep apnoea: how we do it. Clin Otolaryngol.
6645 Udomittipong K, Chierakul N, Ruttanaumpawan P, et al. (2011). Severe obesity is a risk factor for severe obstructive sleep apnea in obese children. J Med Assoc Thai.
6646 Uijen JH, Bindels PJ, Schellevis FG, et al. (2011). ENT problems in Dutch children: trends in incidence rates, antibiotic prescribing and referrals 2002-2008. Scand J Prim Health Care.
6647 Urdaneta AI, Yu JB, Wilson LD. (2011). Population based cancer registry analysis of primary tracheal carcinoma. Am J Clin Oncol.
6648 Uysal HY, Takmaz SA, Yaman F, et al. (2011). The efficacy of intravenous paracetamol versus tramadol for postoperative analgesia after adenotonsillectomy in children. J Clin Anesth.
6649 Vahabi S, Shoja T. (2011). Effect of postoperative topical administration of magnesium sulfate on pain relief in pediatric adenotonsillectomy. European Journal of Pain Supplements.
6650 Vaiman M, Aviram E, Krakovski D, et al. (2011). Electromyographic assessment of dexamethasone in treatment of post-tonsillectomy pain: randomized, placebo-controlled trial. American journal of the medical sciences.
6651 Vaiman M, Krakovski D, Haitov Z. (2011). Oxycodone and dexamethasone for pain management after tonsillectomy: a placebo-controlled EMG assessed clinical trial. Medical science monitor.
6652 Valentini L, Visintini S, Saletti V, et al. (2011). Treatment for Chiari 1 malformation (CIM): analysis of a pediatric surgical series. Neurol Sci.
6653 van den Aardweg MT, Boonacker CW, Rovers MM, et al. (2011). Effectiveness of adenoidectomy in children with recurrent upper respiratory tract infections: open randomised controlled trial. BMJ.
6654 Vassileva V, Varbanova B. (2011). Cutaneous polyarteriitis nodosa with Grave's disease and cholestatic liver disease. Pediatric Rheumatology.
6655 Vavrova M, Slezacek I, Vavra P, et al. (2011). Pseudoaneurysm of the left internal carotid artery following tonsillectomy. Vasa.
6656 Velepic M, Starcevic R, Bonifacic M, et al. (2011). The clinical status of the eardrum: an inclusion criterion for the treatment of chronic secretory otitis media in children. Int J Pediatr Otorhinolaryngol.
6657 Verhulst S, Kaditis A. (2011). Obstructive sleep apnoea in children. Breathe.
6658 Verhulst SL, Kaditis AG. (2011). In reference to Is polysomnography required prior to tonsillectomy and adenoidectomy for the diagnosis of obstructive sleep apnea versus mild sleep-disordered breathing in children?. Laryngoscope.
6659 Verse T, Hormann K. (2011). The surgical treatment of sleep-related upper airway obstruction. Dtsch Arztebl Int.
6660 Vigo G, Martini G, Zoppi S, et al. (2011). Tonsillectomy efficacy is comparable to the standard medical treatment in PFAPA syndrome. Pediatric Rheumatology.
6661 Villa MP, Rizzoli A, Miano S, et al. (2011). Efficacy of rapid maxillary expansion in children with obstructive sleep apnea syndrome: 36 months of follow-up. Sleep Breath.
6662 Virkkula P, Liukkonen K, Suomalainen AK, et al. (2011). Parental smoking, nasal resistance and rhinitis in children. Acta Paediatr.
6663 Vlastos IM, Houlakis M, Kandiloros D, et al. (2011). Adenoidectomy plus tympanostomy tube insertion versus adenoidectomy plus myringotomy in children with obstructive sleep apnoea syndrome. J Laryngol Otol.
6664 Von Ehrlich B, Mathan C, Negele H, et al. (2011). Experience with repeated-long-term additive parentereal magnesium therapy (pMgT) in patients with tinnitus, epilepsia, migraine, diabetes mellitus and cisplatin-nephropathy. Trace Elements and Electrolytes.
6665 Vose JG, Atmodjo D, Weeks BH. (2011). A study of the peak plasmablade tna in adult tonsillectomy compared to traditional electrosurgery. Otolaryngology - Head and Neck Surgery.
6666 Vukoje NJ, Enoz M, Cvetinov M, et al. (2011). Arco-palato-uvular flap: a new surgical technique for the treatment of palatal snoring in tonsillectomized patients. Kulak Burun Bogaz Ihtis Derg.
6667 Wahid FI, Hamza A, Khan Q, et al. (2011). Complications of tonsillectomy experienced at lady reading hospital peshawar. Pakistan Journal of Medical and Health Sciences.
6668 Waleed FE, Samia AF, Samar MF. (2011). Impact of sleep-disordered breathing and its treatment on children with primary nocturnal enuresis. Swiss Med Wkly.
6669 Walker RP. (2011). Surgical treatment for snoring and obstructive sleep apnea. Dis Mon.
6670 Wang SM, Ho TS, Shen CF, et al. (2011). Echovirus 18 meningitis in southern Taiwan. Pediatr Infect Dis J.
6671 Wang Y, Chen J, Wang Y, et al. (2011). A meta-analysis of the clinical remission rate and long-term efficacy of tonsillectomy in patients with IgA nephropathy. Nephrol Dial Transplant.
6672 Wasilewska J, Kaczmarski M, Debkowska K. (2011). Obstructive hypopnea and gastroesophageal reflux as factors associated with residual obstructive sleep apnea syndrome. Int J Pediatr Otorhinolaryngol.
6673 Wasson JD, Prinsley PR. (2011). Tonsillectomy: variation in practice reflecting regional variation in disease presentation. Clin Otolaryngol.
6674 Weaver EM, Woodson BT, Yueh B, et al. (2011). Studying Life Effects & Effectiveness of Palatopharyngoplasty (SLEEP) study: subjective outcomes of isolated uvulopalatopharyngoplasty. Otolaryngol Head Neck Surg.
6675 Wei JL. (2011). Weight gain after tonsillectomy: myth or reality? Interpreting research responsibly. Otolaryngol Head Neck Surg.
6676 Wibawa T, Surono A, Widodo I. (2011). Isolation of viable Helicobacter pylori in the tonsillar tissues of chronic tonsillitis patients. J Infect Dev Ctries.
6677 Williamson I. (2011). Otitis media with effusion in children. BMJ Clin Evid.
6678 Willis MW, Bonkowsky JL, Srivastava R, et al. (2011). Usefulness of airway evaluation in infants initially seen with an apparent life-threatening event. Arch Otolaryngol Head Neck Surg.
6679 Windfuhr JP, Chen YS, Propst EJ, et al. (2011). The effect of dexamethasone on post-tonsillectomy nausea, vomiting and bleeding. Braz J Otorhinolaryngol.
6680 Wood JM, Harris PK, Woods CM, et al. (2011). Quality of life following surgery for sleep disordered breathing: subtotal reduction adenotonsillectomy versus adenotonsillectomy in Australian children. ANZ J Surg.
6681 Wurster VM, Carlucci JG, Feder HM, et al. (2011). Long-term follow-up of children with periodic fever, aphthous stomatitis, pharyngitis, and cervical adenitis syndrome. J Pediatr.
6682 Yagci A, Uysal T, Usumez S, et al. (2011). Effects of modified and conventional facemask therapies with expansion on dynamic measurement of natural head position in Class III patients. Am J Orthod Dentofacial Orthop.
6683 Yaginuma T, Yamamoto H, Mitome J, et al. (2011). Successful treatment of nephrotic syndrome caused by recurrent IgA nephropathy with chronic active antibody-mediated rejection three years after kidney transplantation. Clin Transplant.
6684 Yaman H, Belada A, Yilmaz S. (2011). The effect of ibuprofen on postoperative hemorrhage following tonsillectomy in children. Eur Arch Otorhinolaryngol.
6685 Yaremchuk K, Tacia B, Peterson E, et al. (2011). Change in Epworth Sleepiness Scale after surgical treatment of obstructive sleep apnea. Laryngoscope.
6686 Yasan H, Aynali G, Erdogan O, et al. (2011). Does subjective tonsillar grading reflect the real volume of palatine tonsils?. Int J Pediatr Otorhinolaryngol.
6687 Yasar H, Ozkul H. (2011). Haemostatic effect of Ankaferd Blood Stopper((R)) seen during adenoidectomy. Afr J Tradit Complement Altern Med.
6688 Yavuz H, Caylakli F, Erkan AN, et al. (2011). Modified intraoral approach for removal of an elongated styloid process. J Otolaryngol Head Neck Surg.
6689 Yoshida S, Toyota H, Hara H, et al. (2011). The effect of tonsillectomy or adenotonsillectomy on quality of life in pediatric sleep-disordered breathing patients. Sleep and Biological Rhythms.
6690 Young EB, Goins JL, Constantine CD, et al. (2011). Otologic manifestations in a family with craniometaphyseal dysplasia. International Journal of Pediatric Otorhinolaryngology Extra.
6691 Youshani AS, Thomas L, Sharma RK. (2011). Day case tonsillectomy for the treatment of obstructive sleep apnoea syndrome in children: Alder Hey experience. Int J Pediatr Otorhinolaryngol.
6692 Zeiders JW, Dahya ZJ. (2011). Antral lavage using the Luma transilluminaton wire and vortex irrigator--a safe and effective advance in treating pediatric sinusitis. Int J Pediatr Otorhinolaryngol.
6693 Zhang Q, Leong SC, McNamara PS, et al. (2011). Characterisation of regulatory T cells in nasal associated lymphoid tissue in children: relationships with pneumococcal colonization. PLoS Pathog.
6694 Zhong T, Yuan JQ, Story DA. (2011). Airway management in adults with bleeding airways. Anaesth Intensive Care.
6695 Zhuang PJ, Wang X, Zhang XF, et al. (2011). Postoperative respiratory and analgesic effects of dexmedetomidine or morphine for adenotonsillectomy in children with obstructive sleep apnoea. Anaesthesia.
6696 Zumtobel M, Frei K. (2011). Occurrence of coagulation factor deficiency in post-tonsillectomy hemorrhage. Wien Klin Wochenschr.
6697 (2012). What is in this issue. Clin Otolaryngol.
6698 (2012). Adjuvant adenoidectomy in persistent bilateral otitis media with effusion: hearing and revision surgery outcomes through 2 years in the TARGET randomised trial. Clin Otolaryngol.
6699 (2012). 1st National Research Symposium on Anaesthesia, Pain and Critical Care. Anaesthesia, Pain and Intensive Care.
6700 (2012). Effect of systemic steroids on post-tonsillectomy bleeding and reinterventions: meta-analysis of randomised controlled trials. Clin Otolaryngol.
6701 Abdel-Aziz M. (2012). The effectiveness of tonsillectomy and partial adenoidectomy on obstructive sleep apnea in cleft palate patients. Laryngoscope.
6702 Abdel-Aziz M. (2012). Hypertrophied tonsils impair velopharyngeal function after palatoplasty. Laryngoscope.
6703 Abdel-Aziz M. (2012). Endoscopic nasopharyngeal exploration at the end of conventional curettage adenoidectomy. Eur Arch Otorhinolaryngol.
6704 Abdel-Fattah G. (2012). Palatal eversion: a new technique in treatment of nasopharyngeal stenosis. Int J Pediatr Otorhinolaryngol.
6705 Abdelmawgoud A, Mohy A. (2012). Effect of oral dextromethorphan versus oral ketamine on sevoflurane related emergence agitation in children undergoing adenotonsillectomy. Egyptian Journal of Anaesthesia.
6706 Abdelwahab HH, Omar AM, Abushanab OH. (2012). Does pressure support ventilation improve the postoperative outcome of adeno-tonsillectomy patients? A prospective randomized trial. Egyptian Journal of Anaesthesia.
6707 Abou-Elhamd KE. (2012). Otorhinolaryngological manifestations of sickle cell disease. Int J Pediatr Otorhinolaryngol.
6708 Abulfateh FN, Al-Khalifa S, Janahi W. (2012). Bilateral peritonsillar abscess. Bahrain Medical Bulletin.
6709 Acar HV, Yilmaz A, Demir G, et al. (2012). Capsicum plasters on acupoints decrease the incidence of emergence agitation in pediatric patients. Paediatr Anaesth.
6710 Acevedo JL, Shah RK, Brietzke SE. (2012). Systematic review of complications of tonsillotomy versus tonsillectomy. Otolaryngol Head Neck Surg.
6711 Adams MT, Chen B, Makowski R, et al. (2012). Multimedia approach to preoperative adenotonsillectomy counseling. Otolaryngol Head Neck Surg.
6712 Agaimy A, Kirsche H, Semrau S, et al. (2012). Cytokeratin-positive epithelioid angiosarcoma presenting in the tonsil: a diagnostic challenge. Hum Pathol.
6713 Ahmad R, Anwar K, Ur Rehman H, et al. (2012). Day case tonsillectomy - Is it safe? A comparison of day case tonsillectomy with in-patient tonsillectomy. Pakistan Journal of Medical and Health Sciences.
6714 Aiken AH, Hoots JA, Saindane AM, et al. (2012). Incidence of cerebellar tonsillar ectopia in idiopathic intracranial hypertension: a mimic of the Chiari I malformation. AJNR Am J Neuroradiol.
6715 Akin A, Bayram A, Esmaoglu A, et al. (2012). Dexmedetomidine vs midazolam for premedication of pediatric patients undergoing anesthesia. Paediatr Anaesth.
6716 Akin RC, Holst R, Schousboe LP. (2012). Risk factors for post-tonsillectomy haemorrhage. Acta Otolaryngol.
6717 Al Ahmary MS, Al Mastour AS, Ghnnam WM. (2012). The microbiology of tonsils in khamis civil hospital, saudi arabia. ISRN Otolaryngol.
6718 Alakarppa A, Alho OP. (2012). Patient-recorded outcomes and quality of life in evidence-based medicine databases on most common ear, throat and nose procedures: a systematic review. Clin Otolaryngol.
6719 Albertz N, Nazar G. (2012). Peritonsillar abscess: treatment with immediate tonsillectomy - 10 years of experience. Acta Otolaryngol.
6720 Al-Mamgani A, van Rooij P, Verduijn GM, et al. (2012). Long-term outcomes and quality of life of 186 patients with primary parotid carcinoma treated with surgery and radiotherapy at the Daniel den Hoed Cancer Center. Int J Radiat Oncol Biol Phys.
6721 Alonso-Alvarez ML, Navazo-Eguia AI, Cordero-Guevara JA, et al. (2012). Respiratory polygraphy for follow-up of obstructive sleep apnea in children. Sleep Med.
6722 Al-Qahtani AS. (2012). Post-tonsillectomy hemorrhage. Monopolar microdissection needle versus cold dissection. Saudi Med J.
6723 Altin G, Sanli A, Erdogan BA, et al. (2012). Huge internal carotid artery aneurysm presenting as tonsillar asymmetry. J Craniofac Surg.
6724 Amer I, Falzon A, Choudhury N, et al. (2012). Branchiootic syndrome--a clinical case report and review of the literature. J Pediatr Surg.
6725 Amir I, Belloso A, Broomfield SJ, et al. (2012). Return to theatre in secondary post-tonsillectomy haemorrhage: a comparison of coblation and dissection techniques. Eur Arch Otorhinolaryngol.
6726 Amit S, Purwar N, Agarwal A, et al. (2012). Tonsillar follicular lymphoma in a child. BMJ Case Rep.
6727 Antonello A. (2012). Comparative evaluation of a homeopathic complex medication versus conventional treatment in prevention and treatment of acute respiratory tract infections (ARTIs) in paediatrics. European Journal of Integrative Medicine.
6728 Anton-Pacheco JL, Luna Paredes C, Martinez Gimeno A, et al. (2012). The role of bronchoscopy in the management of patients with severe craniofacial syndromes. J Pediatr Surg.
6729 Arnaud E, Di Rocco F. (2012). Faciocraniosynostosis: monobloc frontofacial osteotomy replacing the two-stage strategy?. Childs Nerv Syst.
6730 Asadian A, Soheilipour S, Taleban R, et al. (2012). A comparative study on the effects of surgery alone and along with radiofrequency in improvement of patients with nocturnal snoring in Isfahan, Iran. Journal of Research in Medical Sciences.
6731 Atmaca S, Belet U, Baris S. (2012). Post-tonsillectomy pseudoaneurysm of the linguofacial trunk: An ENT surgeon's nightmare. International Journal of Pediatric Otorhinolaryngology Extra.
6732 Ayatollahi V, Behdad S, Hatami M, et al. (2012). Comparison of peritonsillar infiltration effects of ketamine and tramadol on post tonsillectomy pain: a double-blinded randomized placebo-controlled clinical trial. Croat Med J.
6733 Aydil U, Kizil Y, Koybasioglu A. (2012). Less known non-infectious and neuromusculoskeletal system-originated anterolateral neck and craniofacial pain disorders. Eur Arch Otorhinolaryngol.
6734 Azevedo de Almeida L, Eckeli AL, Terezinha W, et al. (2012). Central apnea after adenotonsillectomy in childhood: case report. Sleep Breath.
6735 Azodo CC, Chukwumah NM, Ezeja EB. (2012). Dentoalveolar abscess among children attending a dental clinic in Nigeria. Odontostomatol Trop.
6736 Baharudin A, Rohaida I, Khairudin A. (2012). Transoral surgical resection of bilateral styloid processes elongation (Eagle's Syndrome). Acta Informatica Medica.
6737 Baig S, Patil N, Considine N. (2012). An unusual cause of recurrent throat pain - calcified stylohyoid ligament. J Coll Physicians Surg Pak.
6738 Bajaj Y, Atkinson H, Sagoo R, et al. (2012). Paediatric day-case tonsillectomy: a three-year prospective audit spiral in a district hospital. J Laryngol Otol.
6739 Bajaj Y, Kapoor K, Jephson CG, et al. (2012). Intercollegiate exam - viva in paediatric otolaryngology - paediatric emergencies. Otorhinolaryngologist.
6740 Baker JC, Ramadan HH. (2012). The effects of an antistick phospholipid solution on pediatric electrocautery adenoidectomy. Ear Nose Throat J.
6741 Baker KA, Stuart J, Sykes KJ, et al. (2012). Use of computed tomography in the emergency department for the diagnosis of pediatric peritonsillar abscess. Pediatr Emerg Care.
6742 Bakhshaee M, Bameshki AR, Khadivi E, et al. (2012). Bupivacaine Infiltration Effect on Post-Tonsillectomy Pain. Otolaryngology--head and neck surgery.
6743 Balamucki CJ, Amdur RJ, Werning JW, et al. (2012). Adenoid cystic carcinoma of the head and neck. Am J Otolaryngol.
6744 Baldassari CM, Kepchar J, Bryant L, et al. (2012). Changes in central apnea index following pediatric adenotonsillectomy. Otolaryngol Head Neck Surg.
6745 Baloch MA, Akhtar S, Ikram M, et al. (2012). The rationality of prescribing antibiotics after tonsillectomy. J Pak Med Assoc.
6746 Barraclough J, Anari S. (2012). Tonsillectomy for recurrent sore throats in children; where does our knowledge of effectiveness fall short?. Clinical otolaryngology.
6747 Bartoshuk LM, Catalanotto F, Hoffman H, et al. (2012). Taste damage (otitis media, tonsillectomy and head and neck cancer), oral sensations and BMI. Physiol Behav.
6748 Bateman N. (2012). Comment on effect of systemic steroids on post-tonsillectomy bleeding and reinventions: meta-analysis of randomised controlled trials. Clin Otolaryngol.
6749 Bathala S, Eccles R. (2012). RE: The use of ice lollies for pain relief post-paediatric tonsillectomy. Clin Otolaryngol.
6750 Behnoud F. (2012). Evaluation of children with chronic rhinosinusitis after adenotonsillectomy. Iran J Otorhinolaryngol.
6751 Bell D, Bell A, Roberts D, et al. (2012). Developmental transcription factor EN1--a novel biomarker in human salivary gland adenoid cystic carcinoma. Cancer.
6752 Bell S, Howard A, Wilson JA, et al. (2012). Streptococcus pyogenes infection of tonsil explants is associated with a human beta-defensin 1 response from control but not recurrent acute tonsillitis patients. Mol Oral Microbiol.
6753 Ben Salah R, Marzouk S, Kaddour N, et al. (2012). Tonsil amyloidosis revealing a Waldenstrom macroglobulinemia. Eur Arch Otorhinolaryngol.
6754 Bhargava D, Sharma J, Al-Abri R. (2012). Plasma pseudo cholinesterase deficiency leading to seven hour apnoea in a child undergoing adeno-tonsillectomy. Int J Pediatr Otorhinolaryngol.
6755 Bhatia KS, King AD, Vlantis AC, et al. (2012). Nasopharyngeal mucosa and adenoids: appearance at MR imaging. Radiology.
6756 Bhayani MK, Yener M, El-Naggar A, et al. (2012). Prognosis and risk factors for early-stage adenoid cystic carcinoma of the major salivary glands. Cancer.
6757 Blakley B. (2012). Decision analysis using decision trees for a simple clinical decision. J Otolaryngol Head Neck Surg.
6758 Blount A, Riley K, Cure J, et al. (2012). Cerebrospinal fluid volume replacement following large endoscopic anterior cranial base resection. Int Forum Allergy Rhinol.
6759 Bollo RJ, Riva-Cambrin J, Brockmeyer MM, et al. (2012). Complex Chiari malformations in children: an analysis of preoperative risk factors for occipitocervical fusion. J Neurosurg Pediatr.
6760 Boronat-Echeverria NE, Reyes-Garcia E, Sevilla-Delgado Y, et al. (2012). Prognostic factors of successful tympanoplasty in pediatric patients: a cohort study. BMC Pediatr.
6761 Borumandi F, Cascarini L, Mallawaarachchi R, et al. (2012). The chameleon in the neck: Nodular fasciitis mimicking malignant neck mass of unknown primary. International Journal of Surgery Case Reports.
6762 Boss EF. (2012). Tonsillectomy variation in the United States: the evidence is catching up, but are the payers aware of the evidence?. J Pediatr.
6763 Boss EF, Marsteller JA, Simon AE. (2012). Outpatient tonsillectomy in children: demographic and geographic variation in the United States, 2006. J Pediatr.
6764 Brown Z, Whyte S. (2012). Anaesthesia for elective ear, nose and throat surgery in children. Anaesthesia and Intensive Care Medicine.
6765 Brum MR, Miura MS, Castro SF, et al. (2012). Tranexamic acid in adenotonsillectomy in children: a double-blind randomized clinical trial. Int J Pediatr Otorhinolaryngol.
6766 Buckley J. (2012). Case study: a woman who hemorrhages 24 hours post tonsillectomy. Int J Nurs Knowl.
6767 Bukhari MA, Al-Saied AS. (2012). Evaluation of the effect of Bupivacaine (Marcaine) in reducing early post tonsillectomy pain. Saudi Med J.
6768 Buland K, Zahoor MU, Asghar A, et al. (2012). Efficacy of single dose perioperative intravenous steroid (dexamethasone) for postoperative pain relief in tonsillectomy patients. J Coll Physicians Surg Pak.
6769 Calado G, Loureiro G, Machado D, et al. (2012). Streptococcal tonsillitis as a cause of urticaria: tonsillitis and urticaria. Allergol Immunopathol (Madr).
6770 Cantarella G, Viglione S, Forti S, et al. (2012). Comparing postoperative quality of life in children after microdebrider intracapsular tonsillotomy and tonsillectomy. Auris Nasus Larynx.
6771 Cantarini L, Vitale A, Bartolomei B, et al. (2012). Diagnosis of PFAPA syndrome applied to a cohort of 17 adults with unexplained recurrent fevers. Clin Exp Rheumatol.
6772 Carlos Bregni R, Nuyens M, Vassallo J, et al. (2012). Marginal zone lymphoma of mucosa-associated lymphoid tissue with prominent plasma cell differentiation affecting the palatine tonsil: histopathological and immunohistochemical analysis. Oral Surg Oral Med Oral Pathol Oral Radiol.
6773 Caulfield HM, Cunningham A, Naik R. (2012). The use of medical treatment to optimise respiratory function prior to adenotonsillectomy for sleep disordered breathing in the under 3 age group: our experience in one hundred and forty two children. Clin Otolaryngol.
6774 Chan CC, Chan YY, Tanweer F. (2012). Systematic review and meta-analysis of the use of tranexamic acid in tonsillectomy. Clinical otolaryngology.
6775 Chan DK, Jan TA, Koltai PJ. (2012). Effect of obesity and medical comorbidities on outcomes after adjunct surgery for obstructive sleep apnea in cases of adenotonsillectomy failure. Arch Otolaryngol Head Neck Surg.
6776 Chan J, Rashid M, Karagama Y. (2012). An unusual case of a tonsillolith. Case Reports in Medicine.
6777 Chang CY, Thrasher R. (2012). Coblation cryptolysis to treat tonsil stones: a retrospective case series. Ear Nose Throat J.
6778 Chen Y, Chin M, Greenberg S, et al. (2012). Post-tonsillectomy pain in 24 children - utilising short message service (SMS) to assess postoperative outcomes. Clin Otolaryngol.
6779 Cheng J, Elden L. (2012). Management of pediatric second branchial fistulae: is tonsillectomy necessary?. Int J Pediatr Otorhinolaryngol.
6780 Cheng PW, Fang KM, Su HW, et al. (2012). Improved objective outcomes and quality of life after adenotonsillectomy with inferior turbinate reduction in pediatric obstructive sleep apnea with inferior turbinate hypertrophy. Laryngoscope.
6781 Chervin RD, Ruzicka DL, Hoban TF, et al. (2012). Esophageal pressures, polysomnography, and neurobehavioral outcomes of adenotonsillectomy in children. Chest.
6782 Chi HS, Lee KW, Chiang FY, et al. (2012). Head and neck extranodal lymphoma in a single institute: a 17-year retrospective analysis. Kaohsiung J Med Sci.
6783 Chronowski GM, Garden AS, Morrison WH, et al. (2012). Unilateral radiotherapy for the treatment of tonsil cancer. Int J Radiat Oncol Biol Phys.
6784 Chu L, Yao H, Wang B. (2012). Impact of adenotonsillectomy on high-sensitivity C-reactive protein levels in obese children with obstructive sleep apnea. Otolaryngol Head Neck Surg.
6785 Cicek MT, Croo A, Kizilay A. (2012). Posterior plica synechia: rare complication of adenotonsillectomy. J Craniofac Surg.
6786 Cocelli LP, Ugur BK, Durucu C, et al. (2012). Comparison of pre-emptive tonsillar lodge infiltration with ropivacaine versus intravenous tramadol in pediatric tonsillectomies: a randomized placebo-controlled study. Int J Pediatr Otorhinolaryngol.
6787 Cohen JE, Gomori JM, Moscovici S, et al. (2012). Endovascular management of postoperative pseudoaneurysms of the external carotid artery. J Clin Neurosci.
6788 Cohen PR. (2012). Is self-reporting a form fruste of medical experimentation? Personal insights from the ‘family’ literature of a dermatologist and his children. Expert Review of Dermatology.
6789 Coll G, Arnaud E, Selek L, et al. (2012). The growth of the foramen magnum in Crouzon syndrome. Childs Nerv Syst.
6790 Comar M, Cuneo A, Maestri I, et al. (2012). Merkel-cell polyomavirus (MCPyV) is rarely associated to B-chronic lymphocytic leukemia (1 out of 50) samples and occurs late in the natural history of the disease. J Clin Virol.
6791 Combs SE, Kessel KA, Herfarth K, et al. (2012). Treatment of pediatric patients and young adults with particle therapy at the Heidelberg Ion Therapy Center (HIT): establishment of workflow and initial clinical data. Radiat Oncol.
6792 Costa AF, Tasso MG, Mariano FV, et al. (2012). Levels and patterns of expression of hypoxia-inducible factor-1alpha, vascular endothelial growth factor, glucose transporter-1 and CD105 in adenoid cystic carcinomas with high-grade transformation. Histopathology.
6793 Crisalli JA, McConnell K, Vandyke RD, et al. (2012). Baroreflex sensitivity after adenotonsillectomy in children with obstructive sleep apnea during wakefulness and sleep. Sleep.
6794 Dadgarnia MH, Baradaranfar MH, Fallah R, et al. (2012). Effect of adenotonsillectomy on ADHD symptoms of children with adenotonsillar hypertrophy. Acta Med Iran.
6795 Daniel LC, Barakat LP. (2012). A review of sleep concerns in paediatric sickle cell disease. European Oncology and Haematology.
6796 De Amici M, Ciprandi G, Marseglia A, et al. (2012). Adenoid hypetrophy: definition of some risk factors. J Biol Regul Homeost Agents.
6797 Dearking AC, Lahr BD, Kuchena A, et al. (2012). Factors associated with revision adenoidectomy. Otolaryngol Head Neck Surg.
6798 Della Marca G, Scarano E, Leoni C, et al. (2012). Pycnodysostosis with extreme sleep apnea: a possible alternative to tracheotomy. Sleep Breath.
6799 Deng J, Gao X. (2012). A case--control study of craniofacial features of children with obstructed sleep apnea. Sleep Breath.
6800 Di Francesco R, Monteiro R, Paulo ML, et al. (2012). Craniofacial morphology and sleep apnea in children with obstructed upper airways: differences between genders. Sleep Med.
6801 Di Pierro F, Donato G, Fomia F, et al. (2012). Preliminary pediatric clinical evaluation of the oral probiotic Streptococcus salivarius K12 in preventing recurrent pharyngitis and/or tonsillitis caused by Streptococcus pyogenes and recurrent acute otitis media. Int J Gen Med.
6802 Di Rienzo Businco L, Angelone AM, Mattei A, et al. (2012). Paediatric adenoidectomy: endoscopic coblation technique compared to cold curettage. Acta Otorhinolaryngol Ital.
6803 Divi V, Benninger M, Kiupel M, et al. (2012). Coblation of the canine vocal fold: a histologic study. J Voice.
6804 Dong M, Ning ZQ, Xing PY, et al. (2012). Phase I study of chidamide (CS055/HBI-8000), a new histone deacetylase inhibitor, in patients with advanced solid tumors and lymphomas. Cancer Chemother Pharmacol.
6805 Doxtader EE, Katzenstein AL. (2012). The relationship between p16 expression and high-risk human papillomavirus infection in squamous cell carcinomas from sites other than uterine cervix: a study of 137 cases. Hum Pathol.
6806 Drago L, De Vecchi E, Torretta S, et al. (2012). Biofilm formation by bacteria isolated from upper respiratory tract before and after adenotonsillectomy. APMIS.
6807 Durr ML, Meyer AK, Kezirian EJ, et al. (2012). Drug-induced sleep endoscopy in persistent pediatric sleep-disordered breathing after adenotonsillectomy. Arch Otolaryngol Head Neck Surg.
6808 Eftekharian A, Sabeti S, Khajavi M, et al. (2012). Light microscopic histopathology of adenoid tissue in otitis media with effusion: is there any relation?. Int J Pediatr Otorhinolaryngol.
6809 El Sharkawy AA, Elmorsy SM, Eladl HM. (2012). Functional endoscopic sinus surgery in children: predictive factors of outcome. Eur Arch Otorhinolaryngol.
6810 Eldawlatly A, Shafer SL. (2012). Caveat lector. Saudi Journal of Anaesthesia.
6811 Ellington CL, Goodman M, Kono SA, et al. (2012). Adenoid cystic carcinoma of the head and neck: Incidence and survival trends based on 1973-2007 Surveillance, Epidemiology, and End Results data. Cancer.
6812 El-Sawy T, Ali R, Nasser QJ, et al. (2012). Outcomes of dacryocystorhinostomy in patients with head and neck cancer treated with high-dose radiation therapy. Ophthal Plast Reconstr Surg.
6813 Elwany S, Ibrahim AA, Mandour Z, et al. (2012). Effect of passive smoking on the ultrastructure of the nasal mucosa in children. Laryngoscope.
6814 Enciso R, Shigeta Y, Nguyen M, et al. (2012). Comparison of cone-beam computed tomography incidental findings between patients with moderate/severe obstructive sleep apnea and mild obstructive sleep apnea/healthy patients. Oral Surg Oral Med Oral Pathol Oral Radiol.
6815 Engel M, Castrillon-Oberndorfer G, Hoffmann J, et al. (2012). Chiari malformation in nonsyndromal single craniosynostosis--much ado about nothing?. Acta Neurochir (Wien).
6816 Ergil J, Akkaya T, Gozaydin O, et al. (2012). Vasoconstrictive and analgesic efficacy of locally infiltrated levobupivacaine in tonsillectomy patients. Int J Pediatr Otorhinolaryngol.
6817 Ertugrul BM, Erol N, Emek M, et al. (2012). Food-borne tonsillopharyngitis outbreak in a hospital cafeteria. Infection.
6818 Ettinger RE, Oppenheimer AJ, Lau D, et al. (2012). Obstructive sleep apnea after dynamic sphincter pharyngoplasty. J Craniofac Surg.
6819 Ezzeddini R, Darabi M, Ghasemi B, et al. (2012). Circulating phospholipase-A2 activity in obstructive sleep apnea and recurrent tonsillitis. Int J Pediatr Otorhinolaryngol.
6820 Fadzil Abdullah AA, Jamalludin AR, Norrashidah AW, et al. (2012). Prevalence of sleep disordered breathing symptoms among Malay school children in a primary school in Malaysia. Med J Malaysia.
6821 Farmand S, Henneke P, Hufnagel M, et al. (2012). Significant decline in the erythromycin resistance of group A streptococcus isolates at a German paediatric tertiary care centre. Eur J Clin Microbiol Infect Dis.
6822 Farmer JD, Vasdev GM, Martin DP. (2012). Perioperative considerations in patients with Gitelman syndrome: a case series. J Clin Anesth.
6823 Fawzy AH, Hussien A, Hussein A, et al. (2012). Coblation Versus Bipolar Diathermy for Adult Tonsillectomy. Medical journal of Cairo University.
6824 Fazaeli A. (2012). State of the globe: Diagnostic tests to detect Helicobacter pylori tonsillitis. Journal of Global Infectious Diseases.
6825 Feres MF, de Sousa HI, Francisco SM, et al. (2012). Reliability of radiographic parameters in adenoid evaluation. Braz J Otorhinolaryngol.
6826 Feres MF, Hermann JS, Pignatari SS. (2012). Cephalometric evaluation of adenoids: an analysis of current methods and a proposal of a new assessment tool. Am J Orthod Dentofacial Orthop.
6827 Freeman K, Bonuck K. (2012). Snoring, mouth-breathing, and apnea trajectories in a population-based cohort followed from infancy to 81 months: a cluster analysis. Int J Pediatr Otorhinolaryngol.
6828 Friedman M, Samuelson CG, Hamilton C, et al. (2012). Modified adenotonsillectomy to improve cure rates for pediatric obstructive sleep apnea: a randomized controlled trial. Otolaryngol Head Neck Surg.
6829 Friedman M, Wilson M, Kelley K. (2012). Modification of Z-palatoplasty technique and review of five-year experience. Operative Techniques in Otolaryngology - Head and Neck Surgery.
6830 Fung E, Witmans M, Ghosh M, et al. (2012). Upper airway findings in children with Down syndrome on sleep nasopharyngoscopy: case-control study. J Otolaryngol Head Neck Surg.
6831 Gammelsrud KW, Lindstad BL, Gaustad P, et al. (2012). Multilocus sequence typing of serial Candida albicans isolates from children with cancer, children with cystic fibrosis and healthy controls. Med Mycol.
6832 Garcia Callejo FJ, Fernandez NM, Lopez NS, et al. (2012). Inflammatory pseudotumor of the tonsil. Acta Otorrinolaringol Esp.
6833 Garcia-Matte R, Maria Constanza Beltran M, Ximena Fonseca A, et al. (2012). Management of children with inherited mild bleeding disorders undergoing adenotonsillar procedures. Int J Pediatr Otorhinolaryngol.
6834 Gill AI, Schaughency E, Galland BC. (2012). Prevalence and factors associated with snoring in 3-year olds: early links with behavioral adjustment. Sleep Med.
6835 Giordani B, Hodges EK, Guire KE, et al. (2012). Changes in neuropsychological and behavioral functioning in children with and without obstructive sleep apnea following Tonsillectomy. J Int Neuropsychol Soc.
6836 Girard NJ. (2012). Routine goes awry. Aorn j.
6837 Gleich SJ, Olson MD, Sprung J, et al. (2012). Perioperative outcomes of severely obese children undergoing tonsillectomy. Paediatr Anaesth.
6838 Go WH, Kim KT, Kim JY, et al. (2012). The use of laryngeal mask airway in pediatric patient with massive post-tonsillectomy hemorrhage. Korean Journal of Anesthesiology.
6839 Gois EG, Vale MP, Paiva SM, et al. (2012). Incidence of malocclusion between primary and mixed dentitions among Brazilian children. A 5-year longitudinal study. Angle Orthod.
6840 Gokce A, Aslan S, Yalcinkaya FR, et al. (2012). Improvement of monosymptomatic enuresis after adenotonsillectomy in children with obstructive sleep apnea syndrome. Turkish Journal of Medical Sciences.
6841 Goldbart AD, Greenberg-Dotan S, Tal A. (2012). Montelukast for children with obstructive sleep apnea: a double-blind, placebo-controlled study. Pediatrics.
6842 Goldbart AD, Tal A, Givon-Lavi N, et al. (2012). Sleep-disordered breathing is a risk factor for community-acquired alveolar pneumonia in early childhood. Chest.
6843 Goldstein NA, Stefanov DG, Graw-Panzer KD, et al. (2012). Validation of a clinical assessment score for pediatric sleep-disordered breathing. Laryngoscope.
6844 Goodman DC, Challener GJ. (2012). Tonsillectomy: a procedure in search of evidence. J Pediatr.
6845 Gorzelnik A, Jablonska-Jesionowska M, Zawadzka-Glos L, et al. (2012). Perioperative management of children with von willebrand disease and tonsillar hypertrophy in ent department of children hospital in Warsaw Medical University. New Medicine.
6846 Gov-Ari E, Mills JC, Basler KJ. (2012). Predictors of tonsillectomy after previous adenoidectomy for upper airway obstruction. Otolaryngol Head Neck Surg.
6847 Grandi D. (2012). The “Interdisciplinary Orofacial Examination Protocol for Children and Adolescents”: a resource for the interdisciplinary assessment of the stomatognatic system. Int J Orofacial Myology.
6848 Grossman Z, del Torso S, Hadjipanayis A, et al. (2012). Antibiotic prescribing for upper respiratory infections: European primary paediatricians' knowledge, attitudes and practice. Acta Paediatr.
6849 Gupta N, Banik T, Rajwanshi A, et al. (2012). Fine needle aspiration cytology of oral and oropharyngeal lesions with an emphasis on the diagnostic utility and pitfalls. J Cancer Res Ther.
6850 Gurbuzler L, Sogut E, Koc S, et al. (2012). Manganese-superoxide dismutase and glutathione peroxidase 1 polymorphisms in recurrent tonsillitis and tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
6851 Gutierrez C, Nazar GA, Torres JP. (2012). Otolaryngological complications in patients infected with the influenza A (H1N1) virus. Otolaryngol Head Neck Surg.
6852 Haffey T, Pabon S, Hawley K, et al. (2012). Exploring the clinical value and implications of routine pathological examination of septoplasty specimens. Laryngoscope.
6853 Hagebeuk EE, Bijlmer RP, Koelman JH, et al. (2012). Respiratory disturbances in rett syndrome: don't forget to evaluate upper airway obstruction. J Child Neurol.
6854 Hamada M, Iida M. (2012). Home monitoring using portable polygraphy for perioperative assessment of pediatric obstructive sleep apnea syndrome. Tokai J Exp Clin Med.
6855 Hannam JA, Anderson BJ, Holford NH. (2012). Paracetamol and diclofenac additive effects after tonsillectomy.
6856 Harris I, Madan A, Naylor J, et al. (2012). Mortality rates after surgery in New South Wales. ANZ J Surg.
6857 Hashmi MA, Ahmed A, Aslam S, et al. (2012). Post-tonsillectomy pain and vomiting:role of pre-operative steroids. J Coll Physicians Surg Pak.
6858 Hasnain F, Janbaz KH, Qureshi MA. (2012). Analgesic effect of ketamine and morphine after tonsillectomy in children. Pak J Pharm Sci.
6859 Hayward G, Thompson MJ, Perera R, et al. (2012). Corticosteroids as standalone or add-on treatment for sore throat. Cochrane Database Syst Rev.
6860 Heiba MH, Atef A, Mosleh M, et al. (2012). Comparison of peritonsillar infiltration of tramadol and lidocaine for the relief of post-tonsillectomy pain. J Laryngol Otol.
6861 Heidari SM, Mirlohi SZ, Hashemi SJ. (2012). Comparison of the preventive analgesic effect of rectal ketamine and rectal acetaminophen after pediatric tonsillectomy. Int J Prev Med.
6862 Heiser C, Landis BN, Giger R, et al. (2012). Taste disorders after tonsillectomy: a long-term follow-up. Laryngoscope.
6863 Heiss JD, Suffredini G, Bakhtian KD, et al. (2012). Normalization of hindbrain morphology after decompression of Chiari malformation Type I. J Neurosurg.
6864 Hensley R, Baguley K, Cheng A, et al. (2012). Adenoidectomy improves osa related QOL in children. Sleep and Biological Rhythms.
6865 Hermans C, Vander Vorst S, Lambert C. (2012). Successful management of hereditary angioedema during tonsillectomy: a case report. Blood Coagul Fibrinolysis.
6866 Hijjawi SB, Abdullah SE, Abdelhadi K, et al. (2012). Hyalinizing clear cell carcinoma of the tonsil and its treatment. Oral Surg Oral Med Oral Pathol Oral Radiol.
6867 Horne R. (2012). Cardiovascular effects of sleep disordered breathing in children-is it a matter of time?. Sleep and Biological Rhythms.
6868 Hosseini Jahromi SA, Hosseini Valami SM, Hatamian S. (2012). Comparison between effect of lidocaine, morphine and ketamine spray on post-tonsillectomy pain in children. Anesth Pain Med.
6869 Hsiao HJ, Huang YC, Hsia SH, et al. (2012). Clinical features of peritonsillar abscess in children. Pediatr Neonatol.
6870 Hsu PP, Tan AK, Gan EC, et al. (2012). Computer-assisted quantitative upper airway analysis following modified uvulopalatal flap and lateral pharyngoplasty for obstructive sleep apnoea: a prospective case-controlled study. Clin Otolaryngol.
6871 Huang YS, Guilleminault C. (2012). Pediatric obstructive sleep apnea and the critical role of oral-facial growth: evidences. Front Neurol.
6872 Hyun KD. (2012). The Effectiveness of Pregabalin on Tonsillectomy Pain. Otolaryngology--head and neck surgery.
6873 Ieiri N, Hotta O, Sato T, et al. (2012). Significance of the duration of nephropathy for achieving clinical remission in patients with IgA nephropathy treated by tonsillectomy and steroid pulse therapy. Clin Exp Nephrol.
6874 Ifeacho SN, Bajaj Y, Jephson CG, et al. (2012). Surgical site infections in paediatric otolaryngology operative procedures. Int J Pediatr Otorhinolaryngol.
6875 Ikavalko T, Tuomilehto H, Pahkala R, et al. (2012). Craniofacial morphology but not excess body fat is associated with risk of having sleep-disordered breathing--the PANIC Study (a questionnaire-based inquiry in 6-8-year-olds). Eur J Pediatr.
6876 Ikeda FH, Horta PA, Bruscato WL, et al. (2012). Intellectual and school performance evaluation of children submitted to tonsillectomy and adenotonsillectomy before and after surgery. Braz J Otorhinolaryngol.
6877 Ilhan AE, Karaman M, Tekin A. (2012). Symptomatology and etiology of chronic pediatric rhinosinusitis. Kulak Burun Bogaz Ihtis Derg.
6878 Imai H, Miura N. (2012). A treatment dilemma in adult immunoglobulin A nephropathy: what is the appropriate target, preservation of kidney function or induction of clinical remission?. Clin Exp Nephrol.
6879 Immanuel SA, Pamula Y, Kohler M, et al. (2012). Respiratory timing and variability during sleep in children with sleep-disordered breathing. J Appl Physiol (1985).
6880 Inoue CN, Matsutani S, Ishidoya M, et al. (2012). Impact of periodontal treatment in combination with tonsillectomy plus methylprednisolone pulse therapy and angiotensin blockade for pediatric IgA nephropathy. Clin Nephrol.
6881 Iqbal FR, Goh BS, Mazita A. (2012). The role of proton pump inhibitors in adenoid hypertrophy in children. Otolaryngol Head Neck Surg.
6882 Ireland PJ, Johnson S, Donaghey S, et al. (2012). Medical management of children with achondroplasia: evaluation of an Australasian cohort aged 0-5 years. J Paediatr Child Health.
6883 Irfan M, Wong CY, Siti RI. (2012). A rare complication of corneal abrasion in otorhinolaryngology procedure: Lessons learnt. Bangladesh Journal of Medical Science.
6884 Irshad M, Malik M, Furqan A. (2012). Intravenous paracetamol in pediatrics: A global perspective. Anaesthesia, Pain and Intensive Care.
6885 Isaacson G. (2012). Tonsillectomy healing. Ann Otol Rhinol Laryngol.
6886 Isaacson G. (2012). Tonsillectomy care for the pediatrician. Pediatrics.
6887 Isbir AC, Atim A, Duger S, et al. (2012). Comparison of methods used in general anesthesia without muscle relaxants and rocuronium bromide and vecuronium bromide use in cases of pediatric adeno-tonsillectomy. HealthMED.
6888 Ishak GE, Dempsey JC, Shaw DW, et al. (2012). Rhombencephalosynapsis: a hindbrain malformation associated with incomplete separation of midbrain and forebrain, hydrocephalus and a broad spectrum of severity. Brain.
6889 Ishman SL. (2012). Evidence-based practice: pediatric obstructive sleep apnea. Otolaryngol Clin North Am.
6890 Iwatani H, Inoue T, Wada Y, et al. (2012). Quantitative change of IgA hinge O-glycan composition is a novel marker of therapeutic responses of IgA nephropathy. Biochem Biophys Res Commun.
6891 Jablonska-Jesionowska M, Debska M, Zawadzka-Glos L. (2012). Congenital lateral fistulae on the neck in 8-years girl. New Medicine.
6892 Jacobowitz O. (2012). Surgical reconstruction of the upper airway for obstructive sleep apnea. Dent Clin North Am.
6893 Jacobson I. (2012). Choosing the appropriate patients for tonsillectomy. Medicine Today.
6894 Jafari B, Roux F. (2012). Non-positive airway pressure therapy for obstructive sleep apnea. Current Respiratory Care Reports.
6895 Jauhar S, Orchardson R, Banham SW, et al. (2012). The Kushida Index as a screening tool for obstructive sleep apnoea-hypopnoea syndrome. Br Dent J.
6896 Javid MJ, Hajijafari M, Hajipour A, et al. (2012). Evaluation of a low dose ketamine in post tonsillectomy pain relief: a randomized trial comparing intravenous and subcutaneous ketamine in pediatrics. Anesth Pain Med.
6897 Jayasundera S, Mackinnon R. (2012). Dexamathasone and ondansetron in paediatric tonsillectomy. Anaesthesia.
6898 Jeyakumar A, Rahman SI, Armbrecht ES, et al. (2012). The association between sleep-disordered breathing and enuresis in children. Laryngoscope.
6899 Jiang L, Huang S, Li W, et al. (2012). Expression of autophagy and ER stress-related proteins in primary salivary adenoid cystic carcinoma. Pathol Res Pract.
6900 Jiang ZY, Pereira KD, Friedman NR, et al. (2012). Inferior turbinate surgery in children: a survey of practice patterns. Laryngoscope.
6901 Jimenez N, Anderson GD, Shen DD, et al. (2012). Is ethnicity associated with morphine's side effects in children? Morphine pharmacokinetics, analgesic response, and side effects in children having tonsillectomy. Paediatr Anaesth.
6902 Kah TA, Jeng TC, Premsenthil M. (2012). Jerk Seesaw Nystagmus after Posterior Cranial Fossa Decompression with Cerebellar Tonsillectomy for Chiari i Malformation. Neuro-Ophthalmology.
6903 Kane KJ. (2012). Barbara Hepworth and the tonsillectomy. J Laryngol Otol.
6904 Kaneko Y, Kojima M, Nakazato Y, et al. (2012). Epithelioid cell granulomatous response of Waldeyer's ring among Japanese : a clinicopathological and immunohistochemical study of 16 cases. J Clin Exp Hematop.
6905 Kang KT, Lee PL, Weng WC, et al. (2012). Body weight status and obstructive sleep apnea in children. Int J Obes (Lond).
6906 Kapusuz Z, Ozkiris M, Okur A, et al. (2012). The prevalence of adenoid hypertrophy in adults in a rural area of Turkey. Kulak Burun Bogaz Ihtis Derg.
6907 Karaca CT, Toros SZ, Noseri H, et al. (2012). Role of allergy in children with adenotonsillar hypertrophy. J Craniofac Surg.
6908 Karadag S, Ozkiris M, Kubilay U, et al. (2012). The effect of radiofrequency ablation on microbiology of the tonsils. Int J Pediatr Otorhinolaryngol.
6909 Karaman M, Tek A, Tuncel A, et al. (2012). Adult tonsillectomy: relationship between indications and postoperative hemorrhage. Kulak Burun Bogaz Ihtis Derg.
6910 Karimzadeh P. (2012). Psycho-cognitive behavioral problems in sleep disordered children. Neural Regeneration Research.
6911 Karlidag T, Bulut Y, Keles E, et al. (2012). Presence of herpesviruses in adenoid tissues of children with adenoid hypertrophy and chronic adenoiditis. Kulak Burun Bogaz Ihtis Derg.
6912 Karppinen A, Koljonen V, Valanne L, et al. (2012). Asymmetric laterality of Chiari type I malformation in patients with non-syndromic single-suture craniosynostosis. Acta Neurochir (Wien).
6913 Kartal L, Sahin MI, Kulahli I, et al. (2012). Evaluation of the effects of adenotonsillar hypertrophy and adenotonsillectomy on growth in children. Turk Pediatri Arsivi.
6914 Katz ES, Mitchell RB, D'Ambrosio CM. (2012). Obstructive sleep apnea in infants. Am J Respir Crit Care Med.
6915 Kaufmann A, Kraft B, Michalek-Sauberer A, et al. (2012). Novel double and single ryanodine receptor 1 variants in two Austrian malignant hyperthermia families. Anesth Analg.
6916 Kaur J, Swami AC, Kumar A, et al. (2012). Anesthetic management of a child with Hunter's syndrome. J Anaesthesiol Clin Pharmacol.
6917 Kawashima S, Ueda K, Shinohara M, et al. (2012). Relationship between growth of facial morphology and chronologic age in preschool children with obstructive sleep apnea. J Oral Biol Craniofac Res.
6918 Kaya A, Deveci K, Uysal IO, et al. (2012). Tularemia in children: evaluation of clinical, laboratory and therapeutic features of 27 tularemia cases. Turk J Pediatr.
6919 Keilmann A, Nakarat T, Bruce IA, et al. (2012). Hearing loss in patients with mucopolysaccharidosis II: data from HOS - the Hunter Outcome Survey. J Inherit Metab Dis.
6920 Kelly LE, Rieder M, van den Anker J, et al. (2012). More codeine fatalities after tonsillectomy in North American children. Pediatrics.
6921 Kennedy D. (2012). Cognitive performance and behaviour in snoring children. Sleep and Biological Rhythms.
6922 Keren R, Luan X, Localio R, et al. (2012). Prioritization of comparative effectiveness research topics in hospital pediatrics. Arch Pediatr Adolesc Med.
6923 Khalili G, Sajedi P, Shafa A, et al. (2012). A randomized evaluation of intravenous dexamethasone versus oral acetaminophen codeine in pediatric adenotonsillectomy: emergence agitation and analgesia. Middle East J Anaesthesiol.
6924 Khan AA, Aasim MU, Saeed I. (2012). Ultrasonic scalpel tonsillectomy versus cold dissection/electrocautery tonsillectomy: A Pakistani perspective. Pakistan Paediatric Journal.
6925 Khan AR, Khan SA, Khan AA, et al. (2012). Prevalence of infection in tonsillar surgery. Journal of Medical Sciences (Peshawar).
6926 Khan I, Abelardo E, Scott NW, et al. (2012). Coblation tonsillectomy: is it inherently bloody?. Eur Arch Otorhinolaryngol.
6927 Khan I, Ahmad S, Chawala JA. (2012). Comparison of FNA vs surface swab culture in isolating core flora in recurrent tonsillitis. J Ayub Med Coll Abbottabad.
6928 Khan MI, Muhammad, Iqbal K. (2012). Post tonsillectomy pain: Role of single intraoperative dose of dexamethasone. Pakistan Journal of Medical and Health Sciences.
6929 Khan MI, Shah SF, Iqbal K. (2012). Relief of post-tonsillectomy pain by topical application of bupivacaine. Khyber Medical University Journal (KMUJ).
6930 Khetani JD, Madadi P, Sommer DD, et al. (2012). Apnea and oxygen desaturations in children treated with opioids after adenotonsillectomy for obstructive sleep apnea syndrome: a prospective pilot study. Paediatr Drugs.
6931 Khirani S, Leboulanger N, Ramirez A, et al. (2012). Life-threatening obstructive sleep apnea caused by adenoid hypertrophy in an infant with noonan syndrome. Case Rep Pediatr.
6932 Kim JP, Park JJ, Kim NJ, et al. (2012). A case of diffuse alveolar hemorrhage after tonsillectomy -a case report. Korean Journal of Anesthesiology.
6933 Kim MK, Lee JW, Kim MG, et al. (2012). Analysis of prognostic factors for postoperative bleeding after tonsillectomy. Eur Arch Otorhinolaryngol.
6934 Kim SH, Park YS, Kwon KH, et al. (2012). Surgery in patients with congenital factor VII deficiency: A single center experience. Korean J Hematol.
6935 Kirk SF, Kuhle S, Ohinmaa A, et al. (2012). Health care utilization from prevalent medical conditions in normal-weight, overweight, and obese children. J Pediatr.
6936 Klemetti S, Kinnunen I, Suominen T, et al. (2012). The quality of the face-to-face counselling in paediatric ambulatory tonsillectomy: parental point of view. Int J Nurs Pract.
6937 Kljajic Z, Malvic K, Roje Z, et al. (2012). Efficacy and safety of perioperative application of anaesthetics and steriods in tonsillar fossa on intensity of pain in first 24 hours after tonsillectomy in adults. HealthMED.
6938 Klug TE, Henriksen JJ, Rusan M, et al. (2012). Bacteremia during quinsy and elective tonsillectomy: an evaluation of antibiotic prophylaxis recommendations for patients undergoing tonsillectomy. J Cardiovasc Pharmacol Ther.
6939 Knapik M, Saliba I. (2012). Myringoplasty in children with cleft palate and craniofacial anomaly. Int J Pediatr Otorhinolaryngol.
6940 Koc S, Aytekin M, Kalay N, et al. (2012). The effect of adenotonsillectomy on right ventricle function and pulmonary artery pressure in children with adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
6941 Koc S, Uysal IO, Yaman H, et al. (2012). Histopathologic examination of routine tonsil and adenoid specimens: is it a necessary approach?. Kulak Burun Bogaz Ihtis Derg.
6942 Kokki M, Broms S, Eskelinen M, et al. (2012). The analgesic concentration of oxycodone with co-administration of paracetamol -- a dose-finding study in adult patients undergoing laparoscopic cholecystectomy. Basic & clinical pharmacology & toxicology.
6943 Komatsu H, Fujimoto S, Kikuchi M, et al. (2012). Tonsillectomy delays progression of advanced IgA nephropathy to end-stage kidney disease. Ren Fail.
6944 Korndewal MJ, Geurts van Kessel WM, Jak LG, et al. (2012). Influence of obesity on nocturnal oxygen saturation in young children. Eur J Pediatr.
6945 Koshkareva YA, Cohen M, Gaughan JP, et al. (2012). Utility of preoperative hematologic screening for pediatric adenotonsillectomy. Ear Nose Throat J.
6946 Koshy E, Murray J, Bottle A, et al. (2012). Significantly increasing hospital admissions for acute throat infections among children in England: is this related to tonsillectomy rates?. Arch Dis Child.
6947 Kotagal S. (2012). Treatment of dyssomnias and parasomnias in childhood. Curr Treat Options Neurol.
6948 Kotby AA, Habeeb NM, Ezz El Elarab S. (2012). Antistreptolysin O titer in health and disease: levels and significance. Pediatr Rep.
6949 Kristensen RN, Hahn CH. (2012). Facial nerve palsy caused by parotid gland abscess. J Laryngol Otol.
6950 Krol P, Bohm M, Nemcova D, et al. (2012). PFAPA syndrome in the Czech Republic: A single-centre experience. Pediatric Rheumatology.
6951 Kuhle S, Kirk SF, Ohinmaa A, et al. (2012). The association between childhood overweight and obesity and otitis media. Pediatr Obes.
6952 Kujala T, Alho OP, Luotonen J, et al. (2012). Tympanostomy with and without adenoidectomy for the prevention of recurrences of acute otitis media: a randomized controlled trial. Pediatr Infect Dis J.
6953 Kulasegarah J, Harney M, Walsh M, et al. (2012). The quality of information on three common ENT procedures on the Internet. Ir J Med Sci.
6954 Kullar P, Yates PD. (2012). Infections and foreign bodies in ENT. Surgery.
6955 Kuratomi Y, Satoh S, Suzuki K, et al. (2012). Surgery for locally advanced tongue cancer (T3/4)-prevention of parapharyngeal recurrence arising at the inner part of the mandibular angle by removal of the medial pterygoid muscle. Japanese Journal of Head and Neck Cancer.
6956 Kurtipek O, Isik B, Arslan M, et al. (2012). A study to investigate the relationship between difficult intubation and prediction criterion of difficult intubation in patients with obstructive sleep apnea syndrome. Journal of Research in Medical Sciences.
6957 Kyvsgaard N, Mikkelsen T, Korsholm J, et al. (2012). Periodic fever associated with aphthous stomatitis, pharyngitis and cervical adenitis. Dan Med J.
6958 Laeeq K, Francis HW, Varela DA, et al. (2012). The timely completion of objective assessment tools for evaluation of technical skills. Laryngoscope.
6959 Lakos AK, Pangercic A, Gasparic M, et al. (2012). Safety and effectiveness of azithromycin in the treatment of respiratory infections in children. Curr Med Res Opin.
6960 Lamarre ED, Seth R, Lorenz RR, et al. (2012). Intended single-modality management of T1 and T2 tonsillar carcinomas: retrospective comparison of radical tonsillectomy vs radiation from a single institution. Am J Otolaryngol.
6961 Lamyman A, Silva P. (2012). Comment on: Peritonsillar abscess after tonsillectomy. Ann R Coll Surg Engl.
6962 Landau YE, Bar-Yishay O, Greenberg-Dotan S, et al. (2012). Impaired behavioral and neurocognitive function in preschool children with obstructive sleep apnea. Pediatr Pulmonol.
6963 Le LP, Dias-Santagata D, Pawlak AC, et al. (2012). Apocrine-eccrine carcinomas: molecular and immunohistochemical analyses. PLoS One.
6964 Lee DH. (2012). Letter to the editor regarding ‘The effect of adenotonsillectomy on serum insulin like growth factors and the adenoid/nasopharynx ratio in pediatric patients: a blind, prospective clinical study’. Int J Pediatr Otorhinolaryngol.
6965 Lee HS, Lee SH, Kim ES, et al. (2012). Surgical results of arachnoid-preserving posterior fossa decompression for Chiari I malformation with associated syringomyelia. J Clin Neurosci.
6966 Lee JM, Weinstein GS, O'Malley BW, et al. (2012). Transoral robot-assisted lingual tonsillectomy and uvulopalatopharyngoplasty for obstructive sleep apnea. Annals of otology, rhinology, and laryngology.
6967 Lee KS, Lin KL, Chen YC. (2012). Peripheral facial palsy after adenotonsillectomy in children. Int J Pediatr Otorhinolaryngol.
6968 Lee PC, Hwang B, Soong WJ, et al. (2012). The specific characteristics in children with obstructive sleep apnea and cor pulmonale. ScientificWorldJournal.
6969 Lee SH, Chang CH, Park JS, et al. (2012). Stress-induced cardiomyopathy after negative pressure pulmonary edema during emergence from anesthesia -a case report. Korean Journal of Anesthesiology.
6970 Lee SH, Choi JH, Park IH, et al. (2012). Measuring sleep quality after adenotonsillectomy in pediatric sleep apnea. Laryngoscope.
6971 Leikola J, Hukki A, Karppinen A, et al. (2012). The evolution of cerebellar tonsillar herniation after cranial vault remodeling surgery. Childs Nerv Syst.
6972 Lenti S, Burali G, Felici M, et al. (2012). TORS for OSAS in hypertensive patients. Italian Journal of Medicine.
6973 Leonetti JP, Benscoter BJ, Marzo SJ, et al. (2012). Preauricular infratemporal fossa approach for advanced malignant parotid tumors. Laryngoscope.
6974 Leong SC, Wilkie MD, Webb CJ. (2012). Impact of endoscopic stapling of Zenker's diverticulum on patient health status as assessed by the Glasgow Benefit Inventory. Ann Otol Rhinol Laryngol.
6975 Lescanne E, Chiron B, Constant I, et al. (2012). Pediatric tonsillectomy: clinical practice guidelines. Eur Ann Otorhinolaryngol Head Neck Dis.
6976 Leupe P, Hox V, Debruyne F, et al. (2012). Tonsillectomy compared to acute tonsillitis in children: a comparison study of societal costs. B-ENT.
6977 Levi J, Leoniak S, Schmidt R. (2012). Evaluating tonsillectomy as a risk factor for childhood obesity. Arch Otolaryngol Head Neck Surg.
6978 Li HY, Lee LA. (2012). Relocation pharyngoplasty. Operative Techniques in Otolaryngology - Head and Neck Surgery.
6979 Li Q, Zhang XR, Liu XK, et al. (2012). Long-term treatment outcome of minor salivary gland carcinoma of the hard palate. Oral Oncol.
6980 Liao H, Wang L, Zhou B, et al. (2012). A resting-state functional magnetic resonance imaging study on the first-degree relatives of persons with schizophrenia. Brain Imaging Behav.
6981 Licameli G, Lawton M, Kenna M, et al. (2012). Long-term surgical outcomes of adenotonsillectomy for PFAPA syndrome. Arch Otolaryngol Head Neck Surg.
6982 Lim R, Eaton A, Lee NY, et al. (2012). 18F-FDG PET/CT metabolic tumor volume and total lesion glycolysis predict outcome in oropharyngeal squamous cell carcinoma. J Nucl Med.
6983 Lin AC, Koltai PJ. (2012). Sleep endoscopy in the evaluation of pediatric obstructive sleep apnea. Int J Pediatr.
6984 Lin CD, Tsai MH, Lin CW, et al. (2012). Association of adenoid hyperplasia and bacterial biofilm formation in children with adenoiditis in Taiwan. Eur Arch Otorhinolaryngol.
6985 Lin YC, Chen KC, Lin CH, et al. (2012). Clinicopathological features of salivary and non-salivary adenoid cystic carcinomas. Int J Oral Maxillofac Surg.
6986 Little P, Hobbs FD, Mant D, et al. (2012). Incidence and clinical variables associated with streptococcal throat infections: a prospective diagnostic cohort study. Br J Gen Pract.
6987 Liukkonen K, Virkkula P, Haavisto A, et al. (2012). Symptoms at presentation in children with sleep-related disorders. Int J Pediatr Otorhinolaryngol.
6988 Llor C, Hernandez M, Hernandez S, et al. (2012). Validity of a point-of-care based on heterophile antibody detection for the diagnosis of infectious mononucleosis in primary care. Eur J Gen Pract.
6989 Louissaint A, Ferry JA, Soupir CP, et al. (2012). Infectious mononucleosis mimicking lymphoma: distinguishing morphological and immunophenotypic features. Mod Pathol.
6990 Luccoli L, Ellena M, Esposito I, et al. (2012). Noninvasive ventilation in a child with hypothalamic dysfunction, hypoventilation, and autonomic dysregulation (ROHHAD). Minerva Anestesiol.
6991 Luksic I, Virag M, Manojlovic S, et al. (2012). Salivary gland tumours: 25 years of experience from a single institution in Croatia. J Craniomaxillofac Surg.
6992 Luna-Ortiz K, Guemes-Meza A, Villavicencio-Valencia V, et al. (2012). Upper lip malignant neoplasms. A study of 59 cases. Med Oral Patol Oral Cir Bucal.
6993 Lundeborg I, Hultcrantz E, Ericsson E, et al. (2012). Acoustic and perceptual aspects of vocal function in children with adenotonsillar hypertrophy--effects of surgery. J Voice.
6994 Lundkvist K, Sundquist K, Li X, et al. (2012). Familial risk of sleep-disordered breathing. Sleep Med.
6995 Ma AL, Lam YY, Wong SF, et al. (2012). Risk factors for post-operative complications in Chinese children with tonsillectomy and adenoidectomy for obstructive sleep apnea syndrome. Sleep Breath.
6996 Ma J, You C, Chen H, et al. (2012). Cerebellar tonsillectomy with suboccipital decompression and duraplasty by small incision for Chiari I malformation (with syringomyelia): long term follow-up of 76 surgically treated cases. Turk Neurosurg.
6997 Macari AT, Bitar MA, Ghafari JG. (2012). New insights on age-related association between nasopharyngeal airway clearance and facial morphology. Orthod Craniofac Res.
6998 Maeda I, Hayashi T, Sato KK, et al. (2012). Tonsillectomy has beneficial effects on remission and progression of IgA nephropathy independent of steroid therapy. Nephrol Dial Transplant.
6999 Mahakit P, Siriputhorn P, Chalermwattanachai T. (2012). Tonsillectomy with uvulopalatopharyngoplasty and tongue base surgery for treatment of obstructive sleep apnea. J Med Assoc Thai.
7000 Majholm B, Engbaek J, Bartholdy J, et al. (2012). Is day surgery safe? A Danish multicentre study of morbidity after 57,709 day surgery procedures. Acta Anaesthesiol Scand.
7001 Mak CC, Spielmann PM, Hussain SS. (2012). Recurrence of peritonsillar abscess: a 2-year follow-up. Clin Otolaryngol.
7002 Mandavia R, Dhar V, Kapoor K, et al. (2012). Quality of life assessment following adenotonsillectomy for obstructive sleep apnoea in children under three years of age. J Laryngol Otol.
7003 Manickavasagam J, Ali S, Quraishi MS. (2012). General practitioners' versus consultants' perspective on indications for paediatric tonsillectomy: current trends. J Laryngol Otol.
7004 Marc WP, Chattopadhyay M, Gass JK, et al. (2012). Congenital linear sagittal alopecia-a variant of temporal triangular alopecia?. European Journal of Pediatric Dermatology.
7005 Marchisio P, Varricchio A, Baggi E, et al. (2012). Hypertonic saline is more effective than normal saline in seasonal allergic rhinitis in children. Int J Immunopathol Pharmacol.
7006 Marcus CL, Brooks LJ, Draper KA, et al. (2012). Diagnosis and management of childhood obstructive sleep apnea syndrome. Pediatrics.
7007 Marzouk H, Aynehchi B, Thakkar P, et al. (2012). The utility of nasopharyngeal culture in the management of chronic adenoiditis. Int J Pediatr Otorhinolaryngol.
7008 Masoom A, Akhtar S, Humayun HN, et al. (2012). Daycare adeno-tonsillectomy: is it safe in developing countries?. J Pak Med Assoc.
7009 Mathew R, Asimacopoulos E, Walker D, et al. (2012). Analysis of clinical negligence claims following tonsillectomy in England 1995 to 2010. Ann Otol Rhinol Laryngol.
7010 Mathew R, McCombe A. (2012). Rationing based on ‘procedures of limited clinical effectiveness’: what are the risks?. Br J Hosp Med (Lond).
7011 Matt BH, Krol BJ, Ding Y, et al. (2012). Effect of tonsillar fossa closure on postoperative pain and bleeding risk after tonsillectomy. Int J Pediatr Otorhinolaryngol.
7012 Mattar SE, Matsumoto MA, Valera FC, et al. (2012). The effect of adenoidectomy or adenotonsillectomy on occlusal features in mouth-breathing preschoolers. Pediatr Dent.
7013 Mattila PS, Hammaren-Malmi S, Saxen H, et al. (2012). Adenoidectomy in young children and serum IgG antibodies to pneumococcal surface protein A and choline binding protein A. Int J Pediatr Otorhinolaryngol.
7014 Maturo SC, Hartnick CJ. (2012). Pediatric lingual tonsillectomy. Adv Otorhinolaryngol.
7015 Maunsell F, Brown MB, Powe J, et al. (2012). Oral inoculation of young dairy calves with Mycoplasma bovis results in colonization of tonsils, development of otitis media and local immunity. PLoS One.
7016 Mavrogeni S, Bratis K, Kitsiou A, et al. (2012). Streptococcal tonsillitis and acute streptococcal myocarditis: an unusual combination assessed by cardiac magnetic resonance imaging and endomyocardial biopsy. Ann Otol Rhinol Laryngol.
7017 McAllister KA, Clement WA. (2012). Readability and content of postoperative tonsillectomy instructions given to patients in Scotland, a completed audit cycle. Scott Med J.
7018 McIntyre RE, Hardcastle C, Eng RL, et al. (2012). Effect of dexamethasone on postoperative morbidity after dental rehabilitation in children. Can J Anaesth.
7019 McMullen CP, Frank DK, Smith LP. (2012). Backyard hazard: a case series of ingested grill brush bristles and a novel approach to extraction. Am J Otolaryngol.
7020 Mehmood F, Bajwa RA, Butt KA. (2012). Post tonsillectomy complications and role of antibiotics. Pakistan Journal of Medical and Health Sciences.
7021 Mejia-Velazquez CP, Duran-Padilla MA, Gomez-Apo E, et al. (2012). Tumors of the salivary gland in Mexicans. A retrospective study of 360 cases. Med Oral Patol Oral Cir Bucal.
7022 Melake NA, Shaker GH, Salama MA. (2012). Incidence of Helicobacter pylori infection and their clarithromycin-resistant strains in otitis media with effusion regarding phenotypic and genotypic studies. Saudi Pharm J.
7023 Menda SK, Gregory GA, Feiner JR, et al. (2012). The effect of deep and awake tracheal extubation on turnover times and postoperative respiratory complications post adenoid-tonsillectomy. Can J Anaesth.
7024 Meng H, Ohtake H, Ishida A, et al. (2012). IgA production and tonsillar focal infection in IgA nephropathy. J Clin Exp Hematop.
7025 Meng QT, Xia ZY, Luo T, et al. (2012). Dexmedetomidine reduces emergence agitation after tonsillectomy in children by sevoflurane anesthesia: a case-control study. Int J Pediatr Otorhinolaryngol.
7026 Meyer SL, Splaingard M, Repaske DR, et al. (2012). Outcomes of adenotonsillectomy in patients with Prader-Willi syndrome. Arch Otolaryngol Head Neck Surg.
7027 Milczuk HA. (2012). Effects of oropharyngeal surgery on velopharyngeal competence. Curr Opin Otolaryngol Head Neck Surg.
7028 Miller DR. (2012). Retraction note to: Granisetron reduces vomiting after strabismus surgery and tonsillectomy in children. Can J Anaesth 1996; 43: 35-8,DOI 10.1007/BF03015955. Can J Anaesth.
7029 Milobevic DN. (2012). Intensity of hemorrhage following tonsillectomy. Vojnosanit Pregl.
7030 Milosevic DN. (2012). Postadenoidectomy hemorrhage: a two-year prospective study. Vojnosanit Pregl.
7031 Min R, Siyi L, Wenjun Y, et al. (2012). Salivary gland adenoid cystic carcinoma with cervical lymph node metastasis: a preliminary study of 62 cases. Int J Oral Maxillofac Surg.
7032 Mizoe JE, Hasegawa A, Jingu K, et al. (2012). Results of carbon ion radiotherapy for head and neck cancer. Radiother Oncol.
7033 Moeller C, Pawlowski J, Pappas AL, et al. (2012). The safety and efficacy of intravenous ketorolac in patients undergoing primary endoscopic sinus surgery: a randomized, double-blinded clinical trial. International forum of allergy & rhinology.
7034 Moesgaard L, Mirz F. (2012). No clinical advantages of coblation tonsillectomy compared with traditional tonsillectomy. Dan Med J.
7035 Moualed D, Qayyum A, Price T, et al. (2012). Bilateral synchronous tonsillar carcinoma: a case series and review of the literature. Eur Arch Otorhinolaryngol.
7036 Mozet C, Prettin C, Dietze M, et al. (2012). Use of Floseal and effects on wound healing and pain in adults undergoing tonsillectomy: randomised comparison versus electrocautery. European archives of oto-rhino-laryngology.
7037 Muhammad R, Wadood F, Haroon T, et al. (2012). Efficacy of gastric aspiration in reducing post-tonsillectomy vomiting in children. J Ayub Med Coll Abbottabad.
7038 Mullin JE, Cooper BP, Kirkham FJ, et al. (2012). Stability of polysomnography for one year and longer in children with sickle cell disease. J Clin Sleep Med.
7039 Muninnobpamasa T, Khamproh K, Moungthong G. (2012). Prevalence of tonsillectomy and adenoidectomy complication at Phramongkutklao Hospital. J Med Assoc Thai.
7040 Munoz-Fernandez R, Prados A, Leno-Duran E, et al. (2012). Human decidual stromal cells secrete C-X-C motif chemokine 13, express B cell-activating factor and rescue B lymphocytes from apoptosis: distinctive characteristics of follicular dendritic cells. Hum Reprod.
7041 Muntz HR. (2012). Management of sleep apnea in the cleft population. Curr Opin Otolaryngol Head Neck Surg.
7042 Munyaka PM, Tactacan G, Jing M, et al. (2012). Immunomodulation in young laying hens by dietary folic acid and acute immune responses after challenge with Escherichia coli lipopolysaccharide. Poult Sci.
7043 Murphy M, Bradley CP, Byrne S. (2012). Antibiotic prescribing in primary care, adherence to guidelines and unnecessary prescribing--an Irish perspective. BMC Fam Pract.
7044 Murphy TK, Storch EA, Lewin AB, et al. (2012). Clinical factors associated with pediatric autoimmune neuropsychiatric disorders associated with streptococcal infections. J Pediatr.
7045 Murray RC, Chennupati SK. (2012). Chronic streptococcal and non-streptococcal pharyngitis. Infect Disord Drug Targets.
7046 Muzumdar H, Arens R. (2012). Restoration of autonomic dysfunction in children with obstructive sleep apnea after adenotonsillectomy. Sleep.
7047 Nadeem A, Siddiqui K. (2012). Anaesthesia challenges in a patient with hurler syndrome: A case Report. Anaesthesia, Pain and Intensive Care.
7048 Nag D, Biswas PK, Mandal PK, et al. (2012). Tumours of minor salivary glands--a clinicopathologic study. J Indian Med Assoc.
7049 Nagano H, Harada M, Umakoshi M, et al. (2012). Two cases of peritonsillar abscess complicated by von Willebrand disease. Auris Nasus Larynx.
7050 Najafipour R, Farivar T, Pahlevan A, et al. (2012). Agreement rate of rapid urease test, conventional PCR, and scorpion real-time PCR in detecting Helicobacter pylori from tonsillar samples of patients with chronic tonsillitis. Journal of Global Infectious Diseases.
7051 Nakagawa N, Kabara M, Matsuki M, et al. (2012). Retrospective comparison of the efficacy of tonsillectomy with and without steroid-pulse therapy in IgA nephropathy patients. Intern Med.
7052 Naserpour Farivar T, Pahlevan AA, Johari P, et al. (2012). Assessment of Helicobacter pylori prevalence by scorpion real-time PCR in chronic tonsillitis patients. Journal of Global Infectious Diseases.
7053 Nasrin M, Miah MR, Datta PG, et al. (2012). Effect of tonsillectomy on humoral immunity. Bangladesh Med Res Counc Bull.
7054 Neelkant S, Sameena, Sreekantha, et al. (2012). Obstructive sleep apnoea syndrome in morbidly obese children with slipped capital femoral epiphysis (SCFE). International Journal of Pharma and Bio Sciences.
7055 Nelson BP, Wolniak KL, Evens A, et al. (2012). Early posttransplant lymphoproliferative disease: clinicopathologic features and correlation with mTOR signaling pathway activation. Am J Clin Pathol.
7056 Newcomb P, Cyr A. (2012). Conditions associated with childhood asthma in north Texas. ISRN Allergy.
7057 Nikakhlagh S, Rahim F, Boostani H, et al. (2012). The effect of adenotonsillectomy on quality of life in adults and pediatric patients. Indian J Otolaryngol Head Neck Surg.
7058 Nikoghosyan-Bossen G, Hauberg A, Homoe P. (2012). Systematic analysis of ear-nose-throat malpractice complaints may be beneficial for patient safety. Dan Med J.
7059 Nino G, Gutierrez MJ, Ravindra A, et al. (2012). Abdominal adiposity correlates with adenotonsillectomy outcome in obese adolescents with severe obstructive sleep apnea. Pulm Med.
7060 Nishi H, Sugimoto K, Fujita S, et al. (2012). Effect and therapeutic mechanisms of tonsillectomy for childhood IgA nephropathy. Nephrology (Carlton).
7061 Norja P, Hedman L, Kantola K, et al. (2012). Occurrence of human bocaviruses and parvovirus 4 in solid tissues. J Med Virol.
7062 Nosaki T, Uto H, Takami Y, et al. (2012). High serum thioredoxin levels are reduced after tonsillectomy in patients with IgA nephropathy. Intern Med.
7063 Nseir W, Mograbi J, Abu-Rahmeh Z, et al. (2012). The association between vitamin D levels and recurrent group A streptococcal tonsillopharyngitis in adults. Int J Infect Dis.
7064 O'Brien SH. (2012). Common management issues in pediatric patients with mild bleeding disorders. Semin Thromb Hemost.
7065 Oh SY, Kim WS, Kim JS, et al. (2012). Waldeyer's ring marginal zone B cell lymphoma: are the clinical and prognostic features nodal or extranodal? A study by the Consortium for Improving Survival of Lymphoma (CISL). Int J Hematol.
7066 Okonogi H, Kawamura T, Matsuo N, et al. (2012). Successful treatment of adult IgA nephropathy with nephrotic-level proteinuria by combination therapy including long-term coadministration of mizoribine. Case Rep Nephrol Urol.
7067 Okpala NCE, Okpala AMJ, John G, et al. (2012). Effectiveness of consenting in otorhinolaryngology. Central European Journal of Medicine.
7068 Okur E, Tolun FI, Yildirim I, et al. (2012). Malondialdehyde level and adenosine deaminase activity in adenoid tissue of patients with OME and obstructive adenoid hypertrophy. Int J Pediatr Otorhinolaryngol.
7069 Oliveira HF, Sampaio AL, Oliveira CA, et al. (2012). Evaluation of airway obstruction by adenoid tissue: comparison of measures in the sitting and recumbent. Int J Pediatr Otorhinolaryngol.
7070 Olson SH. (2012). Selected medical conditions and risk of pancreatic cancer. Mol Carcinog.
7071 Omland O, Hoffmann L. (2012). Occupational acquisition of methicillin-resistant Staphylococcus aureus in humans--a description of MRSA carrier and infected cases from the Region of North Jutland in Denmark. Ann Agric Environ Med.
7072 Oomen KP, Modi VK, Stewart MG. (2012). Evidence-based practice: pediatric tonsillectomy. Otolaryngol Clin North Am.
7073 Orestes MI, Lander L, Verghese S, et al. (2012). Incidence of laryngospasm and bronchospasm in pediatric adenotonsillectomy. Laryngoscope.
7074 Orji FT, Ezeanolue BC. (2012). Outcome of adenotonsillectomy for sleep and breathing difficulties in nigerian children with obstructive adenotonsillar enlargement. Indian J Otolaryngol Head Neck Surg.
7075 Ostovic KT, Luksic I, Virag M, et al. (2012). The importance of team work of cytologist and surgeon in preoperative diagnosis of intraoral minor salivary gland tumours. Coll Antropol.
7076 Ovesen T, Kamarauskas G, Dahl M, et al. (2012). Pain and bleeding are the main determinants of unscheduled contacts after outpatient tonsillectomy. Dan Med J.
7077 Ozkaya-Parlakay A, Uysal M, Kara A. (2012). Group A streptococcal tonsillopharyngitis burden in a tertiary Turkish hospital. Turk J Pediatr.
7078 Ozkiris M, Kapusuz Z, Saydam L. (2012). Comparison of ropivacaine, bupivacaine and lidocaine in the management of post-tonsillectomy pain. Int J Pediatr Otorhinolaryngol.
7079 Ozturk O, Polat S. (2012). Comparison of transoral power-assisted endoscopic adenoidectomy to curettage adenoidectomy. Adv Ther.
7080 Palomares O, Ruckert B, Jartti T, et al. (2012). Induction and maintenance of allergen-specific FOXP3+ Treg cells in human tonsils as potential first-line organs of oral tolerance. J Allergy Clin Immunol.
7081 Park SJ, Kim IS. (2012). Severe edema of the eyes and lips as rare side effects of eye ointment for protection of eyes under general anesthesia -A case report. Korean J Anesthesiol.
7082 Patel A, Ozsahin M, Mirimanoff RO, et al. (2012). The Rare Cancer Network: achievements from 1993 to 2012. Rare Tumors.
7083 Patel AB, Davidian E, Reebye U. (2012). Complicated airway due to unexpected lingual tonsil hypertrophy. Anesth Prog.
7084 Paulson LM, Macarthur CJ, Beaulieu KB, et al. (2012). Speech outcomes after tonsillectomy in patients with known velopharyngeal insufficiency. Int J Otolaryngol.
7085 Penn E, Yasso SF, Wei JL. (2012). Reducing disposable equipment waste for tonsillectomy and adenotonsillectomy cases. Otolaryngol Head Neck Surg.
7086 Pereira SR, Weckx LL, Ortolani CL, et al. (2012). Study of craniofacial alterations and of the importance of the rapid maxillary expansion after tonsillectomy. Braz J Otorhinolaryngol.
7087 Pervaiz MA, Gau G, Jaffe AS, et al. (2012). A Non-classical Presentation of Tangier Disease with Three ABCA1 Mutations. JIMD Rep.
7088 Piessens P, Hens G, Lemkens N, et al. (2012). Effect of adenotonsillectomy on the use of respiratory medication. Int J Pediatr Otorhinolaryngol.
7089 Ping-Ying Chiang R, Lin CM, Powell N, et al. (2012). Systematic analysis of cephalometry in obstructive sleep apnea in Asian children. Laryngoscope.
7090 Pirila-Parkkinen K, Pirttiniemi P, Paakko E, et al. (2012). Pharyngeal airway in children with sleep-disordered breathing in relation to head posture. Sleep Breath.
7091 Pirzadeh A, Mohammadi MA, Allaf-Akbari S, et al. (2012). The effect of ketamine on posttonsillectomy pain in children: a clinical trial. Iran J Otorhinolaryngol.
7092 Pitak-Arnnop P, Dhanuthai K, Hemprich A, et al. (2012). Histopathological examination of tonsillectomy specimens: Some discussions. Afr J Paediatr Surg.
7093 Plante J, Turgeon AF, Zarychanski R, et al. (2012). Effect of systemic steroids on post-tonsillectomy bleeding and reinterventions: systematic review and meta-analysis of randomised controlled trials. Bmj.
7094 Poachanukoon O, Nanthapisal S, Chaumrattanakul U. (2012). Pediatric acute and chronic rhinosinusitis: comparison of clinical characteristics and outcome of treatment. Asian Pac J Allergy Immunol.
7095 Ponticelli C. (2012). Tonsillectomy and IgA nephritis. Nephrol Dial Transplant.
7096 Powell HR, Mehta N, Daly N, et al. (2012). Improved quality of life in adults undergoing tonsillectomy for recurrent tonsillitis. Is adult tonsillectomy really a low priority treatment? Eur Arch Otorhinolaryngol.
7097 Powell J, Wilson JA. (2012). An evidence-based review of peritonsillar abscess. Clin Otolaryngol.
7098 Powell S, Wilson J. (2012). Paediatric tonsillectomy - What has the literature added in the last 5 years?. Otorhinolaryngologist.
7099 Prasad P, Bhardwaj M. (2012). Primary tuberculosis of tonsils: a case report. Case Rep Med.
7100 Proenca-Modena JL, Pereira Valera FC, Jacob MG, et al. (2012). High rates of detection of respiratory viruses in tonsillar tissues from children with chronic adenotonsillar disease. PLoS One.
7101 Puntoni M, Sbrana F, Bigazzi F, et al. (2012). Tangier disease: epidemiology, pathophysiology, and management. Am J Cardiovasc Drugs.
7102 Puranik V, Roberts R, Griffiths K, et al. (2012). PATCH TRIAL: Is transdermal buprenorphine superior in the management of post tonsillectomy pain in adults-results of a randomised controlled trial. Clinical otolaryngology.
7103 Raees US, Siddiqui SZ, Raza SA, et al. (2012). The efficacy of preincisional peritonsillar infiltration of ketamine for postoperative analgesia in children following tonsillectomy. Anaesthesia, Pain and Intensive Care.
7104 Rafiei MR, Aghadavoudi O, Rezvani M, et al. (2012). Evaluation of preemptive analgesia with dextromethorphan gargling in patients undergoing tonsillectomy. Journal of Research in Medical Sciences.
7105 Ragab SM. (2012). Six years of evidence-based adult dissection tonsillectomy with ultrasonic scalpel, bipolar electrocautery, bipolar radiofrequency or ‘cold steel’ dissection. J Laryngol Otol.
7106 Rakesh S, Anand TS, Payal G, et al. (2012). A Prospective, Randomized, Double-Blind Study of Coblation versus Dissection Tonsillectomy in Adult Patients. Indian journal of otolaryngology and head & neck surgery.
7107 Ramadan HH, Bueller H, Hester ST, et al. (2012). Sinus balloon catheter dilation after adenoidectomy failure for children with chronic rhinosinusitis. Arch Otolaryngol Head Neck Surg.
7108 Raman V, Tobias JD, Bryant J, et al. (2012). Effect of cuffed and uncuffed endotracheal tubes on the oropharyngeal oxygen and volatile anesthetic agent concentration in children. Int J Pediatr Otorhinolaryngol.
7109 Ranieri D, Neubauer AG, Ranieri DM, et al. (2012). The use of disposable laryngeal mask airway for adenotonsillectomies. Rev Bras Anestesiol.
7110 Raynes-Greenow CH, Hadfield RM, Cistulli PA, et al. (2012). Sleep apnea in early childhood associated with preterm birth but not small for gestational age: a population-based record linkage study. Sleep.
7111 Reddy JT, Korath VA, Adamala NR, et al. (2012). Cephalometric evaluation of oropharyngeal airway dimension changes in pre- and postadenoidectomy cases. J Contemp Dent Pract.
7112 Remacle M, Ricci-Maccarini A, Matar N, et al. (2012). Reliability and efficacy of a new CO2 laser hollow fiber: a prospective study of 39 patients. Eur Arch Otorhinolaryngol.
7113 Ren DD, Wang WQ. (2012). Assessment of middle ear effusion and audiological characteristics in young children with adenoid hypertrophy. Chin Med J (Engl).
7114 Rezende RM, Silveira F, Barbosa AP, et al. (2012). Objective reduction in adenoid tissue after mometasone furoate treatment. Int J Pediatr Otorhinolaryngol.
7115 Ridyard E, Varadarajan V. (2012). Improving consenting practise in ENT surgery-measures that lead to effective change. BMC Proceedings.
7116 Ritzel RA, Berwig LC, da Silva AM, et al. (2012). Correlation between nasopharyngoscopy and cephalometry in the diagnosis of hyperplasia of the pharyngeal tonsils. Int Arch Otorhinolaryngol.
7117 Roberts AL, Connolly KL, Kirse DJ, et al. (2012). Detection of group A Streptococcus in tonsils from pediatric patients reveals high rate of asymptomatic streptococcal carriage. BMC Pediatr.
7118 Rodriguez-Hernandez A, Kim H, Pourmohamad T, et al. (2012). Cerebellar arteriovenous malformations: anatomic subtypes, surgical results, and increased predictive accuracy of the supplementary grading system. Neurosurgery.
7119 Roopashri G, Vaishali MR, David MP, et al. (2012). Evaluation of elongated styloid process on digital panoramic radiographs. J Contemp Dent Pract.
7120 Ruiz-Juretschke F, Garcia-Leal R, Garcia-Duque S, et al. (2012). Glossopharyngeal neuralgia in the context of a Chiari type I malformation. J Clin Neurosci.
7121 Rusan M, Klug TE, Henriksen JJ, et al. (2012). The role of viruses in the pathogenesis of peritonsillar abscess. Eur J Clin Microbiol Infect Dis.
7122 Ruthenbeck GS, Tan SB, Carney AS, et al. (2012). A virtual-reality subtotal tonsillectomy simulator. J Laryngol Otol.
7123 Ryu KH, Cho KA, Park HS, et al. (2012). Tonsil-derived mesenchymal stromal cells: evaluation of biologic, immunologic and genetic factors for successful banking. Cytotherapy.
7124 Saccomanno S, Antonini G, D'Alatri L, et al. (2012). Causal relationship between malocclusion and oral muscles dysfunction: a model of approach. Eur J Paediatr Dent.
7125 Sada-Ovalle I, Talayero A, Chavez-Galan L, et al. (2012). Functionality of CD4+ and CD8+ T cells from tonsillar tissue. Clin Exp Immunol.
7126 Sadhasivam S, Chidambaran V, Ngamprasertwong P, et al. (2012). Race and unequal burden of perioperative pain and opioid related adverse effects in children. Pediatrics.
7127 Sadhasivam S, Krekels EH, Chidambaran V, et al. (2012). Morphine clearance in children: does race or genetics matter?. J Opioid Manag.
7128 Sadhasivam S, Myer CM. (2012). Preventing opioid-related deaths in children undergoing surgery. Pain Med.
7129 Said SA, McHembe MD, Chalya PL, et al. (2012). Allergic rhinitis and its associated co-morbidities at Bugando Medical Centre in Northwestern Tanzania; A prospective review of 190 cases. BMC Ear Nose Throat Disord.
7130 Salplahta D, Comanescu MV, Anghelina F, et al. (2012). Non-Hodgkin lymphomas of Waldeyer's ring. Rom J Morphol Embryol.
7131 Salunke P, Sura S, Futane S, et al. (2012). Ventral compression in adult patients with Chiari 1 malformation sans basilar invagination: cause and management. Acta Neurochir (Wien).
7132 Samkova A, Blatny J, Fiamoli V, et al. (2012). Significance and causes of abnormal preoperative coagulation test results in children. Haemophilia.
7133 Santoro C, Hsu F, Dimichele DM. (2012). Haemostasis prophylaxis using single dose desmopressin acetate and extended use epsilon aminocaproic acid for adenotonsillectomy in patients with type 1 von Willebrand disease. Haemophilia.
7134 Sarny S, Habermann W, Ossimitz G, et al. (2012). Significant post-tonsillectomy pain is associated with increased risk of hemorrhage. Ann Otol Rhinol Laryngol.
7135 Sarrell EM, Giveon SM. (2012). Streptococcal pharyngitis: a prospective study of compliance and complications. ISRN Pediatr.
7136 Sato D, Suzuki Y, Kano T, et al. (2012). Tonsillar TLR9 expression and efficacy of tonsillectomy with steroid pulse therapy in IgA nephropathy patients. Nephrol Dial Transplant.
7137 Sato K, Shirakawa T, Sakata H, et al. (2012). Effectiveness of the analysis of craniofacial morphology and pharyngeal airway morphology in the treatment of children with obstructive sleep apnoea syndrome. Dentomaxillofac Radiol.
7138 Sayin I, Cingi C. (2012). Recent medical devices for tonsillectomy. Hippokratia.
7139 Schrock A, Jakob M, Strach K, et al. (2012). Transarterial endovascular treatment in the management of life-threatening intra- and postoperative haemorrhages after otorhinolaryngological surgery. Eur Arch Otorhinolaryngol.
7140 Schwab B, Raynor E. (2012). The role of adenotonsillectomy in graft-versus-host disease. Int J Pediatr Otorhinolaryngol.
7141 Sedaghat AR, Flax-Goldenberg RB, Gayler BW, et al. (2012). A case-control comparison of lingual tonsillar size in children with and without Down syndrome. Laryngoscope.
7142 Senska G, Schroder H, Putter C, et al. (2012). Significantly reducing post-tonsillectomy haemorrhage requiring surgery by suturing the faucial pillars: a retrospective analysis. PLoS One.
7143 Shafique A, Ejaz A, Afridi NM, et al. (2012). Diathermy versus ligation for hemostasis in tonsillectomy - A study on postoperative pain and hemorrhage. Medical Forum Monthly.
7144 Shah I. (2012). Kawasaki's disease: An unusual presentation. J Cardiovasc Dis Res.
7145 Shah RK, Preciado DA. (2012). Re: need for bronchoscopy in adenotonsillectomy. Otolaryngol Head Neck Surg.
7146 Shakeel M, Trinidade A, Al-Adhami A, et al. (2012). Retrospective review of three antiemetic regimens versus no therapy in the prevention of postoperative and vomiting following adenotonsillar surgery. J Otolaryngol Head Neck Surg.
7147 Shakeel M, Trinidade A, Al-Adhami A, et al. (2012). Coblation adenotonsillectomy in children. J Coll Physicians Surg Pak.
7148 Shao C, Tan M, Bishop JA, et al. (2012). Suprabasin is hypomethylated and associated with metastasis in salivary adenoid cystic carcinoma. PLoS One.
7149 Shargorodsky J, Hartnick CJ, Lee GS. (2012). Dexamethasone and postoperative bleeding after tonsillectomy and adenotonsillectomy in children: A meta-analysis of prospective studies. Laryngoscope.
7150 Shen Y, Xu Z, Huang Z, et al. (2012). Increased cysteinyl leukotriene concentration and receptor expression in tonsillar tissues of Chinese children with sleep-disordered breathing. Int Immunopharmacol.
7151 Shete M, Thompson JW, Naidu SI, et al. (2012). Olaryngologic manifestations in children with chronic neutropenia. Int J Pediatr Otorhinolaryngol.
7152 Shields L, Zhou H, Pratt J, et al. (2012). Family-centred care for hospitalised children aged 0-12 years. Cochrane Database Syst Rev.
7153 Shin SY, Ye YM, Eun YG, et al. (2012). Local IgE-mediated hypersensitivity to Alternaria in pediatric adenoid tissue. Int J Pediatr Otorhinolaryngol.
7154 Sia KJ, Tang IP, Kong CK, et al. (2012). Grisel's syndrome: a rare complication of tonsillectomy. J Laryngol Otol.
7155 Sierpina DI, Chaudhary H, Walner DL, et al. (2012). Laryngeal mask airway versus endotracheal tube in pediatric adenotonsillectomy. Laryngoscope.
7156 Silva S, Ouda M, Mathanakumara S, et al. (2012). Tonsillectomy under threat: auditing the indications for performing tonsillectomy. J Laryngol Otol.
7157 Slots J. (2012). Low-cost periodontal therapy. Periodontol 2000.
7158 So HK, Li AM, Au CT, et al. (2012). Night sweats in children: prevalence and associated factors. Arch Dis Child.
7159 Souki MQ, Souki BQ, Franco LP, et al. (2012). Reliability of subjective, linear, ratio and area cephalometric measurements in assessing adenoid hypertrophy among different age groups. Angle Orthod.
7160 Spencer DJ, Jones JE. (2012). Complications of adenotonsillectomy in patients younger than 3 years. Arch Otolaryngol Head Neck Surg.
7161 Spruijt NE, Widdershoven JC, Breugem CC, et al. (2012). Velopharyngeal dysfunction and 22q11.2 deletion syndrome: a longitudinal study of functional outcome and preoperative prognostic factors. Cleft Palate Craniofac J.
7162 Sritippayawan S, Norasetthekul S, Nuchprayoon I, et al. (2012). Obstructive sleep apnea among children with severe beta-thalassemia. Southeast Asian J Trop Med Public Health.
7163 Stalfors J, Ericsson E, Hemlin C, et al. (2012). Tonsil surgery efficiently relieves symptoms: analysis of 54 696 patients in the National Tonsil Surgery Register in Sweden. Acta Otolaryngol.
7164 Stansifer KJ, Szramowski MG, Barazsu L, et al. (2012). Microdebrider tonsillectomy associated with more intraoperative blood loss than electrocautery. Int J Pediatr Otorhinolaryngol.
7165 Stevenson AN, Myer CM, Shuler MD, et al. (2012). Complications and legal outcomes of tonsillectomy malpractice claims. Laryngoscope.
7166 Stewart DW, Ragg PG, Sheppard S, et al. (2012). The severity and duration of postoperative pain and analgesia requirements in children after tonsillectomy, orchidopexy, or inguinal hernia repair. Paediatr Anaesth.
7167 Stiller-Timor L, Goldbart AD, Segal N, et al. (2012). Circulating cytokines in patients undergoing tonsillectomy with fibrin glue. Int J Pediatr Otorhinolaryngol.
7168 Stimpson P, Hewitt R, Barnacle A, et al. (2012). Sodium tetradecyl sulphate sclerotherapy for treating venous malformations of the oral and pharyngeal regions in children. Int J Pediatr Otorhinolaryngol.
7169 Stow NW, Sale PJ, Lee D, et al. (2012). Simultaneous tonsillectomy and nasal surgery in adult obstructive sleep apnea: a pilot study. Otolaryngol Head Neck Surg.
7170 Strauss T, Sin S, Marcus CL, et al. (2012). Upper airway lymphoid tissue size in children with sickle cell disease. Chest.
7171 Sung JY, Ahn HK, Kwon JE, et al. (2012). Reappraisal of KIT mutation in adenoid cystic carcinomas of the salivary gland. J Oral Pathol Med.
7172 Sutters KA, Holdridge-Zeuner D, Waite S, et al. (2012). A descriptive feasibility study to evaluate scheduled oral analgesic dosing at home for the management of postoperative pain in preschool children following tonsillectomy. Pain Med.
7173 Sykes KJ, Le PT, Sale KA, et al. (2012). A 7-year review of the safety of tonsillectomy during short-term medical mission trips. Otolaryngol Head Neck Surg.
7174 Tabain I, Ljubin-Sternak S, Cepin-Bogovic J, et al. (2012). Adenovirus respiratory infections in hospitalized children: clinical findings in relation to species and serotypes. Pediatr Infect Dis J.
7175 Tackett KL, De Bellis H. (2012). Pharmacotherapy options in the treatment of obstructive sleep apnea. Pharmacist.
7176 Tagaya M, Nakata S, Yasuma F, et al. (2012). Children with severe or moderate obstructive sleep apnoea syndrome show a high incidence of persistence after adenotonsillectomy. Acta Otolaryngol.
7177 Tagaya M, Nakata S, Yasuma F, et al. (2012). Relationship between adenoid size and severity of obstructive sleep apnea in preschool children. Int J Pediatr Otorhinolaryngol.
7178 Tagliareni JM, Clarkson EI. (2012). Tonsillitis, peritonsillar and lateral pharyngeal abscesses. Oral Maxillofac Surg Clin North Am.
7179 Tam M, Boyev KP, Wong K, et al. (2012). Surgical management of extracranial meningioma presenting in the parapharyngeal space in a pediatric patient. International Journal of Pediatric Otorhinolaryngology Extra.
7180 Tan L, Tan A, Hsu PP, et al. (2012). Effects of tonsillectomy on sleep study parameters in patients with obstructive sleep apnoea. Sleep and Biological Rhythms.
7181 Taskin U, Binay O, Binay C, et al. (2012). Rapidly developing iatrogenic hyponatremia in a child following tonsillectomy. Ear Nose Throat J.
7182 Tatlipinar A, Atalay S, Esen E, et al. (2012). The effect of adenotonsillectomy on serum insulin like growth factors and the adenoid/nasopharynx ratio in pediatric patients: a blind, prospective clinical study. Int J Pediatr Otorhinolaryngol.
7183 Tatlipinar A, Biteker M, Meric K, et al. (2012). Adenotonsillar hypertrophy: correlation between obstruction types and cardiopulmonary complications. Laryngoscope.
7184 Tepedino K, Collins SW. (2012). Peritonsillar abscess. Consultant.
7185 Thimmasettaiah NB, Chandrappa RG. (2012). A prospective study to compare the effects of pre, intra and post operative steroid (dexamethasone sodium phosphate) on post tonsillectomy morbidity. Journal of Pharmacology and Pharmacotherapeutics.
7186 Thorleifsdottir RH, Sigurdardottir SL, Sigurgeirsson B, et al. (2012). Improvement of psoriasis after tonsillectomy is associated with a decrease in the frequency of circulating T cells that recognize streptococcal determinants and homologous skin determinants. J Immunol.
7187 Thorne MC. (2012). Is routine analysis of pediatric tonsillectomy specimens worth the money?. Ear Nose Throat J.
7188 Toftgaard C. (2012). Day surgery activities 2009 international survey on ambulatory surgery conducted 2011. Ambulatory Surgery.
7189 Tomino Y. (2012). New Insights into the Pathogenesis and Treatment of Patients with Immunoglobulin A Nephropathy. Journal of Experimental and Clinical Medicine.
7190 Trider CL, Blake K. (2012). Obstructive Sleep Apnea in a Patient with CHARGE Syndrome. Case Rep Otolaryngol.
7191 Trider CL, Corsten G, Morrison D, et al. (2012). Understanding obstructive sleep apnea in children with CHARGE syndrome. Int J Pediatr Otorhinolaryngol.
7192 Truong MT, Woo VG, Koltai PJ. (2012). Sleep endoscopy as a diagnostic tool in pediatric obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
7193 Tsaoussoglou M, Lianou L, Maragozidis P, et al. (2012). Cysteinyl leukotriene receptors in tonsillar B- and T-lymphocytes from children with obstructive sleep apnea. Sleep Med.
7194 Tunkel DE. (2012). Polysomnography before tonsillectomy in children: who and when?. Otolaryngol Head Neck Surg.
7195 Ubayasiri K, Kothari R, McClelland L, et al. (2012). Patient attitudes to tonsillectomy. Int J Family Med.
7196 Ulualp SO. (2012). Rate of post-tonsillectomy hemorrhage after elective bipolar microcauterization of nonbleeding vessels. Eur Arch Otorhinolaryngol.
7197 Uppell K. (2012). Drug watch. European Journal of Hospital Pharmacy: Science and Practice.
7198 Uzomefuna V, Glynn F. (2012). Endoscope-assisted tonsillotomy (partial intracapsular tonsillectomy): how we do it. ISRN Otolaryngol.
7199 Vahabi S, Shoja T, Chaibakhsh S, et al. (2012). Effect of postoperative topical administration of magnesium sulfate on pain relief in paediatric adenotonsillectomy: A randomised controlled study. Hong Kong Journal of Paediatrics.
7200 Vaiman M, Krakovski D. (2012). EMG assessment of analgesia in treatment of posttonsillectomy pain: random allocation, preliminary report. Clin J Pain.
7201 Van Heirstraeten L, Leten G, Lammens C, et al. (2012). Increase in fluoroquinolone non-susceptibility among clinical Streptococcus pyogenes in Belgium during 2007-10. J Antimicrob Chemother.
7202 Van Hoorenbeeck K, Franckx H, Debode P, et al. (2012). Weight loss and sleep-disordered breathing in childhood obesity: effects on inflammation and uric acid. Obesity (Silver Spring).
7203 van Tongerloo MA, Bor HH, Lagro-Janssen AL. (2012). Detecting autism spectrum disorders in the general practitioner's practice. J Autism Dev Disord.
7204 Vanpouille C, Lisco A, Introini A, et al. (2012). Exploiting the anti-HIV-1 activity of acyclovir: suppression of primary and drug-resistant HIV isolates and potentiation of the activity by ribavirin. Antimicrob Agents Chemother.
7205 Vazquez-Tello A, Halwani R, Li R, et al. (2012). IL-17A and IL-17F expression in B lymphocytes. Int Arch Allergy Immunol.
7206 Velargo PA, Thompson JW. (2012). Palatoglossal flap: a novel approach to cover herniated fat during tonsillectomy. Ear Nose Throat J.
7207 Vicini C, Montevecchi F, Tenti G, et al. (2012). Transoral robotic surgery: Tongue base reduction and supraglottoplasty for obstructive sleep apnea. Operative Techniques in Otolaryngology - Head and Neck Surgery.
7208 Vieira BB, Sanguino AC, Mattar SE, et al. (2012). Influence of adenotonsillectomy on hard palate dimensions. Int J Pediatr Otorhinolaryngol.
7209 Vigo G, Zulian F. (2012). Periodic fevers with aphthous stomatitis, pharyngitis, and adenitis (PFAPA). Autoimmun Rev.
7210 Villa MP, Miano S, Rizzoli A. (2012). Mandibular advancement devices are an alternative and valid treatment for pediatric obstructive sleep apnea syndrome. Sleep Breath.
7211 Voelker R. (2012). Children's deaths linked with postsurgical codeine. Jama.
7212 Wagner C, Schar D, Tinguely M, et al. (2012). Persistent fever, neck swelling, and small vessel vasculitis following tonsillectomy in a patient with Behcets disease: A case report. Journal of Medical Case Reports.
7213 Walton J, Ebner Y, Stewart MG, et al. (2012). Systematic review of randomized controlled trials comparing intracapsular tonsillectomy with total tonsillectomy in a pediatric population. Arch Otolaryngol Head Neck Surg.
7214 Walton J, Ebner Y, Stewart MG, et al. (2012). Re: “Systematic review of complications of tonsillotomy versus tonsillectomy”. Otolaryngol Head Neck Surg.
7215 Wang B, Tang X, Xu J, et al. (2012). Differential expression of Immunoglobulin A in the adenoids of children with and without exudative otitis media. Int J Pediatr Otorhinolaryngol.
7216 Wang LF, White DR, Andreoli SM, et al. (2012). Cigarette smoke inhibits dynamic ciliary beat frequency in pediatric adenoid explants. Otolaryngol Head Neck Surg.
7217 Wang Z, Li X, Li D, et al. (2012). Clinical features of 167 children with the novel influenza A (H1N1) virus infection in Xi'an, China. Turk J Pediatr.
7218 Warrick JI, Brink DS, Mitchell RB. (2012). Paraganglioma of the palatine tonsil. Ear Nose Throat J.
7219 Watts RG, Cook RP. (2012). Operative management and outcomes in children with congenital bleeding disorders: a retrospective review at a single haemophilia treatment centre. Haemophilia.
7220 White DR. (2012). Is supraglottoplasty underutilized?. Laryngoscope.
7221 Wiksten J, Hytonen M, Pitkaranta A, et al. (2012). Who ends up having tonsillectomy after peritonsillar infection?. Eur Arch Otorhinolaryngol.
7222 Willington AJ, Ramsden JD. (2012). Adenotonsillectomy for the management of obstructive sleep apnea in children with congenital craniosynostosis syndromes. J Craniofac Surg.
7223 Wireklint S, Ericsson E. (2012). Health-related quality of life after tonsillotomy versus tonsillectomy in young adults: 6 years postsurgery follow-up. Eur Arch Otorhinolaryngol.
7224 Wolford LM, Perez D, Stevao E, et al. (2012). Airway space changes after nasopharyngeal adenoidectomy in conjunction with Le Fort I osteotomy. J Oral Maxillofac Surg.
7225 Woo JH, Kim ST, Kang IG, et al. (2012). Comparison of tonsillar biofilms between patients with recurrent tonsillitis and a control group. Acta Otolaryngol.
7226 Woodson BT, Laohasiriwong S. (2012). Lingual tonsillectomy and midline posterior glossectomy for obstructive sleep apnea. Operative Techniques in Otolaryngology - Head and Neck Surgery.
7227 Wu S, Liu G, Chen R, et al. (2012). Role of ultrasound in the assessment of benignity and malignancy of parotid masses. Dentomaxillofac Radiol.
7228 Wu T, Zhu Z, Jiang J, et al. (2012). Syrinx resolution after posterior fossa decompression in patients with scoliosis secondary to Chiari malformation type I. Eur Spine J.
7229 Xenos ES, Orr N, Valentino J. (2012). Internal carotid pseudoaneurysm associated with tortuosity after tonsillectomy: A case report. International Journal of Angiology.
7230 Xie JR, Zhu YM, Zhang LF, et al. (2012). Effect of perioperative administration of parecoxib on post-tonsillectomy pain in adults. African Journal of Pharmacy and Pharmacology.
7231 Yildiz I, Unuvar E, Zeybek U, et al. (2012). The role of vitamin D in children with recurrent tonsillopharyngitis. Ital J Pediatr.
7232 Yousaf M, Inayatullah, Khan F. (2012). Medical versus surgical management of otitis media with effusion in children. J Ayub Med Coll Abbottabad.
7233 Yu GP, Mehta V, Branovan D, et al. (2012). Improved survival among patients with base of tongue and tonsil cancer in the United States. Cancer Causes Control.
7234 Yucel A, Begec Z, Ozgul U, et al. (2012). The effect of magnesium on emergence agitation in children undergoing adenotonsillectomy under sevoflurane general anesthesia: A prospective randomised clinical trial. Health & medicine.
7235 Zagolski O, Kulisiewicz J. (2012). Perioperative antibiotic in adenoidectomy with partial tonsillectomy: a randomized trial. ORL J Otorhinolaryngol Relat Spec.
7236 Zahoor A, Ahmad N, Sereche G, et al. (2012). A novel method for laryngeal mask airway size selection in paediatric patients. Eur J Anaesthesiol.
7237 Zappacosta R, Rosini S, Aiello FB, et al. (2012). Solitary plasmacytoma of the tonsillar site associated with actinomyces infection: the possible role of IL-6. J Biol Regul Homeost Agents.
7238 Zelazowska-Rutkowska B, Wysocka J, Ratomski K, et al. (2012). Increased percentage of T cells with the expression of CD127 and CD132 in hypertrophic adenoid in children with otitis media with effusion. Eur Arch Otorhinolaryngol.
7239 Zhang W, Shi Q, Xu X, et al. (2012). Aberrant CD40-induced NF-kappaB activation in human lupus B lymphocytes. PLoS One.
7240 Zheng H, Xie HK, Li C, et al. (2012). Radical mediastinal nodal removal improves disease-free survival for pulmonary low-grade malignant tumors. Lung Cancer.
7241 Zhou Q, Chang H, Zhang H, et al. (2012). Increased numbers of P63-positive/CD117-positive cells in advanced adenoid cystic carcinoma give a poorer prognosis. Diagn Pathol.
7242 Zicari AM, Magliulo G, Rugiano A, et al. (2012). The role of rhinomanometry after nasal decongestant test in the assessment of adenoid hypertrophy in children. Int J Pediatr Otorhinolaryngol.
7243 (2013). Prevention of wrong-site and wrong-patient surgical errors. Prescrire Int.
7244 (2013). Effect of Self-Care education on controling of pain and side effects of tonsillectomy in children.
7245 (2013). Preoperative oral antiemetics for reducing postoperative vomiting after tonsillectomy in children: granisetron versus perphenazine. Anesth Analg 1999;88:1298-301. Retraction. Anesth Analg.
7246 A P, K-A H, J M, et al. (2013). True cost of post-tonsillectomy bleeds. Clin Otolaryngol.
7247 Abad VC. (2013). Pharmacologic therapy for obstructive sleep apnea. Sleep Medicine Clinics.
7248 Abdelhalim AA, Alarfaj AM. (2013). The effect of ketamine versus fentanyl on the incidence of emergence agitation after sevoflurane anesthesia in pediatric patients undergoing tonsillectomy with or without adenoidectomy. Saudi J Anaesth.
7249 Abdulatif M, Ahmed A, Mukhtar A, et al. (2013). The effect of magnesium sulphate infusion on the incidence and severity of emergence agitation in children undergoing adenotonsillectomy using sevoflurane anaesthesia. Anaesthesia.
7250 Abreu CB, Fuchs SC, Pascoto GR, et al. (2013). Effect of adenotonsillectomy on visual attention tests among children with sleep-disordered breathing: a controlled prospective cohort study. Clin Otolaryngol.
7251 Abu Samra M, El Bendary H, Hayes SM, et al. (2013). Role of topical antibiotic prophylaxis in prevention of bacterial translocation into upper trachea in nasally intubated patients undergoing tonsillectomies. Int J Pediatr Otorhinolaryngol.
7252 Abuhandan M, Bozkus F, Demir N, et al. (2013). The preoperative and postoperative oxidative status of children with chronic adenotonsillar hypertrophy. Clin Ter.
7253 Agarwal J, Tandon MS, Singh D, et al. (2013). Quadriplegia in a child following adenotonsillectomy. Anaesthesia.
7254 Aghamohammadi D, Eidi M, Lotfi A, et al. (2013). Effect of Low Level Laser Application at the End of Surgery to Reduce Pain after Tonsillectomy in Adults. Journal of lasers in medical sciences volume.
7255 Ahlstav Martensson U, Erling Hasselqvist N, Bostrom B. (2013). Differences in pain and nausea in children operated on by Tonsillectomy or Tonsillotomy - a prospective follow-up study. J Adv Nurs.
7256 Ahmadi MS, Amirhassani S, Poorolajal J. (2013). The effect of adenotonsillectomy on pediatric nocturnal enuresis: a prospective cohort study. Iran J Otorhinolaryngol.
7257 Ahmed A, Ishman SL, Laeeq K, et al. (2013). Assessment of improvement of trainee surgical skills in the operating room for tonsillectomy. Laryngoscope.
7258 Al-Ammar AY, Shebib D, Bokhari M, et al. (2013). Grading adenoid utilizing flexible nasopharyngoscopy. Ann Saudi Med.
7259 Alasil SM, Omar R, Ismail S, et al. (2013). Evidence of Bacterial Biofilms among Infected and Hypertrophied Tonsils in Correlation with the Microbiology, Histopathology, and Clinical Symptoms of Tonsillar Diseases. Int J Otolaryngol.
7260 Al-Benna S. (2013). Right hypoglossal nerve paralysis after tracheal intubation for aesthetic breast surgery. Saudi Journal of Anaesthesia.
7261 Albirmawy OA, Saafan ME, Shehata EM, et al. (2013). Topical application of tranexamic acid after adenoidectomy: a double-blind, prospective, randomized, controlled study. Int J Pediatr Otorhinolaryngol.
7262 Algahim MF, Almassi GH. (2013). Current and emerging management options for patients with Morquio A syndrome. Therapeutics and Clinical Risk Management.
7263 Al-Hussaini A, Owens D, Tomkinson A. (2013). Health costs and consequences: have UK national guidelines had any effect on tonsillectomy rates and hospital admissions for tonsillitis?. Eur Arch Otorhinolaryngol.
7264 Ali MA, Abdellatif AA. (2013). Prevention of sevoflurane related emergence agitation in children undergoing adenotonsillectomy: A comparison of dexmedetomidine and propofol. Saudi J Anaesth.
7265 Alkhalaf MA, Guiver M, Cooper RJ. (2013). Prevalence and quantitation of adenovirus DNA from human tonsil and adenoid tissues. J Med Virol.
7266 Al-Langawi JH. (2013). Oral rinses, mouthwashes and sprays for improving recovery following tonsillectomy. Journal of the Bahrain Medical Society.
7267 Alper Z, Uncu Y, Akalin H, et al. (2013). Diagnosis of acute tonsillopharyngitis in primary care: a new approach for low-resource settings. J Chemother.
7268 Alrumaih R, Saleem M, Velagapudi S, et al. (2013). Lateral pharyngeal wall myeloid sarcoma as a relapse of acute biphenotypic leukemia: A case report and review of the literature. Journal of Medical Case Reports.
7269 Ameli F, Brocchetti F, Tosca MA, et al. (2013). Adenoidal hypertrophy and allergic rhinitis: is there an inverse relationship?. Am J Rhinol Allergy.
7270 Amiraraghi N, Calder NJ. (2013). Re: Adult and paediatric tonsillectomy: a two-cycle audit of Scottish Intercollegiate Guidelines Network 117 in a total of one hundred and sixty-nine patients. Clin Otolaryngol.
7271 Andiran N, Celik N, Ark N, et al. (2013). Changes in growth pattern, leptin ghrelin and neuropeptide Y levels after adenotonsillectomy in prepubertal children. J Pediatr Endocrinol Metab.
7272 Andrade-Balieiro FB, Azevedo R, Chiari BM. (2013). Aspects of stomatognathic system before and after adenotonsillectomy. Codas.
7273 Andreoli SM, Schlosser RJ, Wang LF, et al. (2013). Adenoid ciliostimulation in children with chronic otitis media. Otolaryngol Head Neck Surg.
7274 Andreou N, Hadjisymeou S, Panesar J. (2013). Does tonsillectomy improve quality of life in adults? A systematic literature review. J Laryngol Otol.
7275 (2013). Comparison of dexamethasone for intravenous injection and local infiltration on pain and recovery after tonsillectomy and adenoidectomy. ChiCTR.
7276 Arakawa Y, Kita D, Ezuka I, et al. (2013). Regression of cerebellar tonsillar descent and hydrocephalus after endoscopic third ventriculostomy in a patient with a quadrigeminal arachnoid cyst. Surg Neurol Int.
7277 Asimakopoulos P, Ah-See KW. (2013). Variation in tonsillectomy rates between Scottish health boards--implications for emergency admissions?. Clin Otolaryngol.
7278 Asimakopoulos P, Ah-See KW. (2013). Re: Sore throat consultations in general practice prior to tonsillectomy among eight hundred and sixty-three children in England: is this in accordance with the SIGN guidelines?. Clin Otolaryngol.
7279 Aydin G, Apan A, Kose EA, et al. (2013). Pre-versus postoperative tramadol instillation: Both are effective for decreasing pain and/or agitation in pediatric adenotonsillectomy. Turkish Journal of Medical Sciences.
7280 Aydogan F, Aydin E, Tastan E, et al. (2013). Is there a relationship between serum levels of vitamin a, vitamin e, copper and zinc and otitis media with effusion in children?. Indian J Otolaryngol Head Neck Surg.
7281 Ayral M, Baylan MY, Kinis V, et al. (2013). Evaluation of hyperactivity, attention deficit, and impulsivity before and after adenoidectomy/adenotonsillectomy surgery. J Craniofac Surg.
7282 Babaiwa UF, Onyeagwara NC, Akerele JO. (2013). Bacterial tonsillar microbiota and antibiogram in recurrent tonsillitis. Biomedical Research (India).
7283 Baboci L, Boscolo-Rizzo P, Holzinger D, et al. (2013). Evidence of the causal role of human papillomavirus type 58 in an oropharyngeal carcinoma. Virol J.
7284 Bagci AM, Lee SH, Nagornaya N, et al. (2013). Automated posterior cranial fossa volumetry by MRI: applications to Chiari malformation type I. AJNR Am J Neuroradiol.
7285 Bameshki AR, Razban M, Khadivi E, et al. (2013). The effect of local injection of epinephrine and bupivacaine on post-tonsillectomy pain and bleeding. Iranian Journal of Otorhinolaryngology.
7286 Bao C, Yang F, Liu L, et al. (2013). Surgical treatment of chiari I malformation complicated with syringomyelia. Experimental and Therapeutic Medicine.
7287 Baradaranfar MH, Zand V, Dadgarnia MH, et al. (2013). Efficacy of clindamycin in reducing pain following tonsillectomy in adults: a double-blind, randomised trial. J Laryngol Otol.
7288 Bashir F, Ali Z, Naqi SA. (2013). Post-tonsillectomy hemorrhage and pain in dissection and diathermy methods of tonsillectomy. Journal of Medical Sciences (Peshawar).
7289 Bateman N. (2013). Comment on ‘Antibiotics to reduce post-tonsillectomy morbidity’. Clin Otolaryngol.
7290 Batu ED, Kara Eroglu F, Bilginer Y, et al. (2013). PW03-001 PFAPA syndrome in Turkish children. Pediatric Rheumatology.
7291 Batzdorf U, McArthur DL, Bentson JR. (2013). Surgical treatment of Chiari malformation with and without syringomyelia: experience with 177 adult patients. J Neurosurg.
7292 Baugh RF. (2013). IDSA guidelines on group A streptococcal pharyngitis vis-a-vis tonsillectomy recommendations. Clin Infect Dis.
7293 Beigh Z, Ul Islam M, Ahmad S, et al. (2013). Effects of peritonsillar injection of tramadol and adrenaline before tonsillectomy. Iranian Journal of Otorhinolaryngology.
7294 Berini J, Spica Russotto V, Castelnuovo P, et al. (2013). Growth hormone therapy and respiratory disorders: long-term follow-up in PWS children. J Clin Endocrinol Metab.
7295 Bernasconi M, Ueda S, Krukowski P, et al. (2013). Early gene expression changes by Epstein-Barr virus infection of B-cells indicate CDKs and survivin as therapeutic targets for post-transplant lymphoproliferative diseases. Int J Cancer.
7296 Biggs TC, Hayes SM, Bird JH, et al. (2013). Use of the lymphocyte count as a diagnostic screen in adults with suspected Epstein-Barr virus infectious mononucleosis. Laryngoscope.
7297 Bird JH, Biggs TC, Schulz C, et al. (2013). Implementation of an evidence-based acute tonsillitis protocol: our experience in one hundred and twenty-six patients. Clin Otolaryngol.
7298 Bitar MA, Mahfoud L, Nassar J, et al. (2013). Exploring the characteristics of children with obstructive adenoid responding to mometasone fuorate monohydrate: preliminary results. Eur Arch Otorhinolaryngol.
7299 Bitar MA, Saade R. (2013). The role of OM-85 BV (Broncho-Vaxom) in preventing recurrent acute tonsillitis in children. Int J Pediatr Otorhinolaryngol.
7300 Blanchford H, Lowe D. (2013). Cold versus hot tonsillectomy: state of the art and recommendations. ORL J Otorhinolaryngol Relat Spec.
7301 Bogaerts M, Schrooten W, Lemkens N, et al. (2013). Patient reported outcome measures (PROMs) in children with sleep-disordered breathing undergoing adenotonsillectomy. B-ENT.
7302 Bohne S, Siggel R, Sachse S, et al. (2013). Clinical significance and diagnostic usefulness of serologic markers for improvement of outcome of tonsillectomy in adults with chronic tonsillitis. J Negat Results Biomed.
7303 Boonacker CW, van den Aardweg MT, Broos PH, et al. (2013). Immediate adenoidectomy vs initial watchful waiting strategy in children with recurrent upper respiratory tract infections: an economic evaluation. JAMA Otolaryngol Head Neck Surg.
7304 Booth CL, Wang J. (2013). Occult hematologic malignancy in routine tonsillectomy specimens: a single institutional experience and review of the literature. Am J Clin Pathol.
7305 Boroumand P, Zamani MM, Saeedi M, et al. (2013). Post tonsillectomy pain: can honey reduce the analgesic requirements?. Anesth Pain Med.
7306 Bosch FX, Broker TR, Forman D, et al. (2013). Comprehensive control of human papillomavirus infections and related diseases. Vaccine.
7307 Bosio I, Meini A, Cancarini P, et al. (2013). OR6-003-Prospective evaluation of PFAPA patients. Pediatric Rheumatology.
7308 Botica MV, Botica I, Stamenic V, et al. (2013). Antibiotic prescription rate for upper respiratory tract infections and risks for unnecessary prescription in Croatia. Coll Antropol.
7309 Brigger MT, Hultcrantz E, Ericsson E, et al. (2013). Comments to ORL 2013;75:193-202 (DOI: 10.1159/000342329). ORL J Otorhinolaryngol Relat Spec.
7310 Brigger MT, Hultcrantz E, Ericsson E, et al. (2013). Comments to ORL 2013;75:175-181 (DOI: 10.1159/000342319). ORL J Otorhinolaryngol Relat Spec.
7311 Brigger MT, Hultcrantz E, Ericsson E, et al. (2013). Comments to ORL 2013;75:166-173 (DOI: 10.1159/000342317). ORL J Otorhinolaryngol Relat Spec.
7312 Brigger MT, Hultcrantz E, Ericsson E, et al. (2013). Comments to ORL 2013;75:144-151 (DOI: 10.1159/000343706). ORL J Otorhinolaryngol Relat Spec.
7313 Brigger MT, Hultcrantz E, Ericsson E, et al. (2013). Comments to ORL 2013;75:123-132 (DOI: 10.1159/000342314). ORL J Otorhinolaryngol Relat Spec.
7314 Brigger MT, Hultcrantz E, Ericsson E, et al. (2013). Comments to ORL 2013;75:136-141 (DOI: 10.1159/000342315). ORL J Otorhinolaryngol Relat Spec.
7315 Brigger MT, Sarny S. (2013). Comments to ORL 2013;75:184-191 (DOI: 10.1159/000342322). ORL J Otorhinolaryngol Relat Spec.
7316 Broderick L, Carvalho D, Magit A, et al. (2013). PW03-009 genetics of PFAPA syndrome. Pediatric Rheumatology.
7317 Brook I. (2013). Fusobacterial infections in children. Curr Infect Dis Rep.
7318 Brook I. (2013). Penicillin failure in the treatment of streptococcal pharyngo-tonsillitis. Curr Infect Dis Rep.
7319 Brouillette RT. (2013). Adenotonsillectomy in childhood obstructive sleep apnea syndrome improves polysomnographic measures of breathing and sleep, but not attention and executive function. Journal of pediatrics.
7320 Brouillette RT. (2013). Let's CHAT about adenotonsillectomy. N Engl J Med.
7321 Brown KA. (2013). Evaluation of the child with sleep-disordered breathing scheduled for adenotonsillectomy. Sleep Medicine Clinics.
7322 Byrd JK, Duvvuri U. (2013). Current trends in robotic surgery for otolaryngology. Curr Otorhinolaryngol Rep.
7323 Camacho M, Jacobson RL, Schendel SA. (2013). Surgical treatment of obstructive sleep apnea. Sleep Medicine Clinics.
7324 Capone GT, Aidikoff JM, Taylor K, et al. (2013). Adolescents and young adults with Down syndrome presenting to a medical clinic with depression: co-morbid obstructive sleep apnea. Am J Med Genet A.
7325 Cappabianca S, Iaselli F, Negro A, et al. (2013). Magnetic resonance imaging in the evaluation of anatomical risk factors for pediatric obstructive sleep apnoea-hypopnoea: a pilot study. Int J Pediatr Otorhinolaryngol.
7326 Cardesin A, Escamilla Y, Martinez A, et al. (2013). Electrodissection tonsillectomy with laryngeal mask. Acta Otorrinolaringol Esp.
7327 Cattalini M, Bosio I, Meini A, et al. (2013). PReS-FINAL-2230: A prospective evaluation of a cohort of patients with PFAPA syndrome. Pediatric Rheumatology.
7328 Celebi I, Mahmutoglu AS. (2013). Early results of real-time qualitative sonoelastography in the evaluation of parotid gland masses: a study with histopathological correlation. Acta Radiol.
7329 Celebi S, Tepe C, Yelken K, et al. (2013). Efficacy of dexpanthenol for pediatric post-tonsillectomy pain and wound healing. Ann Otol Rhinol Laryngol.
7330 Celebi S, Tepe C, Yelken K, et al. (2013). Efficacy of Dexpanthenol for PÃƒÂ©diatrie Post-tonsillectomy Pain and Wound Healing. Annals of otology, rhinology, and laryngology.
7331 Celebi S, Topak M, Develioglu ON, et al. (2013). Effect of thermal welding tonsillectomy on emergence agitation. J Craniofac Surg.
7332 Celenk F, Durucu C, Baysal E, et al. (2013). Management of upper aerodigestive tract amyloidosis. Ann Otol Rhinol Laryngol.
7333 Cengiz C, Erhan Y, Murat T, et al. (2013). Values of mean platelet volume in patients with chronic tonsillitis and adenoid hypertrophy. Pak J Med Sci.
7334 Cengiz K, Kumral TL, Yildirim G. (2013). Diagnosis of pediatric nasopharynx carcinoma after recurrent adenoidectomy. Case Rep Otolaryngol.
7335 Chan MA, Gigliotti NM, Dotson AL, et al. (2013). Omalizumab may decrease IgE synthesis by targeting membrane IgE+ human B cells. Clin Transl Allergy.
7336 Chang KH, Jun BC, Jeon EJ, et al. (2013). Functional evaluation of paratubal muscles using electromyography in patients with chronic unilateral tubal dysfunction. Eur Arch Otorhinolaryngol.
7337 Chatterjee T, Dewan K, Ganguli P, et al. (2013). A rare case of hemoglobin e hemoglobinopathy with Gaucher's disease. Indian Journal of Hematology and Blood Transfusion.
7338 Cheikhyoussef A, Embashu W. (2013). Ethnobotanical knowledge on indigenous fruits in Ohangwena and Oshikoto regions in Northern Namibia. J Ethnobiol Ethnomed.
7339 Chen XH, Bao YY, Zhou SH, et al. (2013). Palatine tonsillar metastasis of small-cell neuroendocrine carcinoma from the lung detected by FDG-PET/CT after tonsillectomy: A case report. Iranian Journal of Radiology.
7340 Cheng J, Elden L. (2013). Outcomes in children under 12 months of age undergoing adenotonsillectomy for sleep-disordered breathing. Laryngoscope.
7341 Cheng J, Sobol S. (2013). Response to “Further concerns regarding opioids after tonsillectomy in children”. Otolaryngol Head Neck Surg.
7342 Cheng J, Sobol S. (2013). Despite warnings, some graduating otolaryngology residents planning to use codeine for posttonsillectomy pain control. Otolaryngol Head Neck Surg.
7343 Chiesa S, Caorsi R, Penco F, et al. (2013). OR5-001-Characterization of tonsil infiltration in PFAPA. Pediatric Rheumatology.
7344 Chiu PH, Ramar K, Chen KC, et al. (2013). Can pillar suturing promote efficacy of adenotonsillectomy for pediatric OSAS? A prospective randomized controlled trial. Laryngoscope.
7345 Cho W, Park H. (2013). Transoral sonographic diagnosis of tonsilloliths: report of 3 cases. J Ultrasound Med.
7346 Choi IJ, Rhee CS, Lee CH, et al. (2013). Effect of allergic rhinitis on the expression of human beta-defensin 2 in tonsils. Ann Allergy Asthma Immunol.
7347 Choi Y, Kim SB, Yoon DH, et al. (2013). Clinical characteristics and prognostic factors of adenoid cystic carcinoma of the head and neck. Laryngoscope.
7348 Christensen AM, Kirkegaard MG, Randrup TS, et al. (2013). Biochemical tests cannot differentiate between tonsillar and middle ear-derived infections. Dan Med J.
7349 Christianson B, Ulualp SO, Koral K, et al. (2013). Congenital hairy polyp of the palatopharyngeus muscle. Case Rep Otolaryngol.
7350 Chu L, Li Q. (2013). The evaluation of adenotonsillectomy on TNF-alpha and IL-6 levels in obese children with obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
7351 Chuang S, Thambipillay G, Walton J, et al. (2013). Infantile laryngomalacia and obstructive sleep apnea-PSG outcome and management. Sleep and Biological Rhythms.
7352 Chung BK, Tsai K, Allan LL, et al. (2013). Innate immune control of EBV-infected B cells by invariant natural killer T cells. Blood.
7353 Cielo C, Brooks LJ. (2013). Therapies for children with obstructive sleep apnea. Sleep Medicine Clinics.
7354 Clarke ET, Williams NA, Dull PM, et al. (2013). Polysaccharide-protein conjugate vaccination induces antibody production but not sustained B-cell memory in the human nasopharyngeal mucosa. Mucosal Immunol.
7355 Clement WA. (2013). Day-case tonsillectomy for children in Glasgow: the impact of changing indications and deprivation. J Laryngol Otol.
7356 Cohn GM, Morin I, Whiteman DA. (2013). Development of a mnemonic screening tool for identifying subjects with Hunter syndrome. Eur J Pediatr.
7357 Comoglu T. (2013). The influence of administration route in the comparison of dosage forms. Arch Trauma Res.
7358 Cooper L, Ford K, Bajaj Y. (2013). Paediatric adenotonsillectomy as a daycase for obstructive sleep apnoea: how we do it in a tertiary unit. Int J Pediatr Otorhinolaryngol.
7359 Coppo R. (2013). Is a legacy effect possible in IgA nephropathy?. Nephrol Dial Transplant.
7360 Costa EC, Sabino HA, Miura CS, et al. (2013). Atopy and adenotonsillar hypertrophy in mouth breathers from a reference center. Braz J Otorhinolaryngol.
7361 Cravero JP, Fanciullo GJ, McHugo GJ, et al. (2013). The validity of the Computer Face Scale for measuring pediatric pain and mood. Paediatr Anaesth.
7362 Czarnetzki C, Elia N, Tramer MR. (2013). Bleeding risk and dexamethasone use in children undergoing tonsillectomy. Jama.
7363 Czarnetzki C, Tramer M. (2013). How to make tonsillectomy a safer procedure: the anaesthetist's view. ORL J Otorhinolaryngol Relat Spec.
7364 Czudek S. (2013). Robotic surgery - A taste of Hollywood?. Wideochirurgia I Inne Techniki Maloinwazyjne.
7365 Dalgic A, Kandogan T, Ozkok G. (2013). Rosai-dorfman disease presenting as bilateral tonsillary hypertrophy: Case report. Turkiye Klinikleri Journal of Medical Sciences.
7366 Daniel M, Kamani T, El-Shunnar S, et al. (2013). National Institute for Clinical Excellence guidelines on the surgical management of otitis media with effusion: are they being followed and have they changed practice?. Int J Pediatr Otorhinolaryngol.
7367 Darwin L, Chung F. (2013). Patient selection for day surgery. Anaesthesia and Intensive Care Medicine.
7368 de Araujo MT, Bissoli NS, Gouvea SA, et al. (2013). CPAP therapy prevents increase in blood pressure after upper airway surgery for obstructive sleep apnoea. Sleep Breath.
7369 De Carvalho F, Leme AFP, Matsuo AL, et al. (2013). Analysis of protein profile expressed on the membrane surface of plasma cells, stromal cells and mononuclear cells from bone marrow microenvironment of multiple myeloma patients by mass spectrometry. BMC Proceedings.
7370 de Sousa Caixeta JA, Saramago AM, Moreira GA, et al. (2013). Otolaryngologic findings in prepubertal obese children with sleep-disordered breathing. Int J Pediatr Otorhinolaryngol.
7371 DeDea L. (2013). Codeine and acetaminophen recommendations for children. JAAPA.
7372 DelRosso L, Gungor AA, Sankararaman S, et al. (2013). A 5-year-old girl with persistent OSA after tonsillectomy and adenoidectomy. Chest.
7373 Demir UL, Cetinkaya B, Karaca S, et al. (2013). The impacts of adenotonsillar hypertrophy on periodontal health in children: a prospective controlled pilot study. Am J Otolaryngol.
7374 Dhamija R, Wetjen NM, Slocumb NL, et al. (2013). The role of nocturnal polysomnography in assessing children with Chiari type I malformation. Clin Neurol Neurosurg.
7375 Di Pierro F, Adami T, Rapacioli G, et al. (2013). Clinical evaluation of the oral probiotic Streptococcus salivarius K12 in the prevention of recurrent pharyngitis and/or tonsillitis caused by Streptococcus pyogenes in adults. Expert Opin Biol Ther.
7376 Donnellan KA, Pitman KT. (2013). Career development resource for otolaryngology-head and neck surgery. Am J Surg.
7377 dos Reis Santos I, Danaga AR, de Carvalho Aguiar I, et al. (2013). Cardiovascular risk and mortality in end-stage renal disease patients undergoing dialysis: sleep study, pulmonary function, respiratory mechanics, upper airway collapsibility, autonomic nervous activity, depression, anxiety, stress and quality of life: a prospective, double blind, randomized controlled clinical trial. BMC Nephrol.
7378 Dostal M, Pastorkova A, Rychlik S, et al. (2013). Comparison of child morbidity in regions of Ostrava, Czech Republic, with different degrees of pollution: a retrospective cohort study. Environ Health.
7379 Driessen C, Joosten KF, Florisson JM, et al. (2013). Sleep apnoea in syndromic craniosynostosis occurs independent of hindbrain herniation. Childs Nerv Syst.
7380 Duodu J, Lesser TH. (2013). Tonsil tie simulator. J Laryngol Otol.
7381 Durovic B, Gasser O, Gubser P, et al. (2013). Epstein-Barr virus negativity among individuals older than 60 years is associated with HLA-C and HLA-Bw4 variants and tonsillectomy. J Virol.
7382 Duval M, Chung JC, Vaccani JP. (2013). A case-control study of repeated adenoidectomy in children. JAMA Otolaryngol Head Neck Surg.
7383 Dyer SR, Bathula S, Durvasula P, et al. (2013). Intraoperative use of FloSeal with adenotonsillectomy to prevent adverse postoperative outcomes in pediatric patients. Otolaryngol Head Neck Surg.
7384 Dzieciolowska-Baran E, Dabrowski P, Gawlikowska-Sroka A, et al. (2013). Snoring and sleep disorders in children with hypertrophy of lymphoid tissue in the throat. Respir Physiol Neurobiol.
7385 Eftekharian MM. (2013). Risk factors for rheumatoid arthritis: Level of education, tonsillectomy and appendectomy. Marmara Medical Journal.
7386 Eghbal MH, Taregh S, Amin A, et al. (2013). Ketamine improves postoperative pain and emergence agitation following adenotonsillectomy in children. A randomized clinical trial. Middle East J Anaesthesiol.
7387 Eichler C, Sommer JU, Stuck BA, et al. (2013). Does drug-induced sleep endoscopy change the treatment concept of patients with snoring and obstructive sleep apnea?. Sleep Breath.
7388 Elgueta MF, Echevarria GC, De la Fuente N, et al. (2013). Effect of intravenous fluid therapy on postoperative vomiting in children undergoing tonsillectomy. Br J Anaesth.
7389 Elnayal A, Moran CA, Fox PS, et al. (2013). Primary salivary gland-type lung cancer: imaging and clinical predictors of outcome. AJR Am J Roentgenol.
7390 Elstraete AC, Sitbon P. (2013). Median effective dose (ED50) of paracetamol and nefopam for postoperative pain: isobolographic analysis of their antinociceptive interaction. Minerva anestesiologica.
7391 Erol K, Erkan KM, Tolga D, et al. (2013). Epidermoid cyst localized in the palatine tonsil. J Oral Maxillofac Pathol.
7392 Ersozlu T, Yildirim YS. (2013). Early extrusion and infection of ventilation tubes of otitis media with effusion; Alpha-mannosidosis: A report of two siblings. International Journal of Pediatric Otorhinolaryngology Extra.
7393 Ersozlu T, Yildirim YS, Sarica S. (2013). Comparison of pediatric and adult tonsillectomies performed by thermal welding system. Int J Otolaryngol.
7394 Eryaman E, Ozkul A, Ozker BY. (2013). Skin prick test and tonsil size in children: any relation?. Indian J Otolaryngol Head Neck Surg.
7395 Esteller E, Santos P, Segarra F, et al. (2013). Clinical and polysomnographic correlation in sleep-related breathing disorders in children. Acta Otorrinolaringol Esp.
7396 Eyigor H, Osma U, Eyigor M, et al. (2013). Detection of human bocavirus in children with upper respiratory tract infection by polymerase chain reaction. Clin Lab.
7397 Ezzedini R, Darabi M, Ghasemi B, et al. (2013). Tissue fatty acid composition in obstructive sleep apnea and recurrent tonsillitis. Int J Pediatr Otorhinolaryngol.
7398 Farhadi M, Noorbakhsh S, Tabatabaei A. (2013). Searching the H. pylori; serology & PCR in children with adenoid hypertrophy and rhino sinusitis: a cross sectional study, Tehran, Iran. Med J Islam Repub Iran.
7399 Farhadi M, Tabatabaei A, Shekarabi M, et al. (2013). Inflammatory cytokine detection in adenotonsill and peripheral blood mononuclear cells- culture in adenotonsillectomy patients: A comparative study. Tehran University Medical Journal.
7400 Fassnacht W, Hammer F, Gardiner Q, et al. (2013). Delayed endovascular coil extrusion after embolisation for post-tonsillectomy haemorrhage: case report and literature review. J Laryngol Otol.
7401 Fauroux MA, Mas C, Tramini P, et al. (2013). Prevalence of palatine tonsilloliths: a retrospective study on 150 consecutive CT examinations. Dentomaxillofac Radiol.
7402 Fensterseifer GS, Carpes O, Weckx LL, et al. (2013). Mouth breathing in children with learning disorders. Braz J Otorhinolaryngol.
7403 Feres MF, Hermann JS, Sallum AC, et al. (2013). Endoscopic evaluation of adenoids: reproducibility analysis of current methods. Clin Exp Otorhinolaryngol.
7404 Ferguson G, Bell PR, Hall SJ. (2013). Increasingly hard to swallow--18 years of changing tonsillectomy practice in Northern Ireland. Ulster Med J.
7405 Ferriman A. (2013). Tonsillectomy study must not lead to unnecessary increase in surgery, expert says. Bmj.
7406 Fida AR, Sendi KS. (2013). Assessment of postoperative pain scores in thermal welding and conventional tonsillectomy techniques: A randomized control study. Egyptian Journal of Ear, Nose, Throat and Allied Sciences.
7407 Finch P, Stocks RM, Smeltzer MP, et al. (2013). Effects of adenotonsillectomy on polysomnographic parameters in children with sickle cell disease. Pediatr Blood Cancer.
7408 Firdouse M, Garwal A, Almeida CLD, et al. (2013). Takotsubo cardiomyopathy-like phenotype in a boy. Journal of Pediatric Intensive Care.
7409 Fitzgerald NM, Fitzgerald DA. (2013). Managing snoring and obstructive sleep apnoea in childhood. J Paediatr Child Health.
7410 Floege J. (2013). Primary glomerulonephritis: A review of important recent discoveries. Kidney Research and Clinical Practice.
7411 Folman R, Grenier D, Birken C, et al. (2013). Obesity hypoventilation syndrome: A different beast. Paediatrics and Child Health (Canada).
7412 Forsvoll J, Kristoffersen EK, Oymar K. (2013). Incidence, clinical characteristics and outcome in Norwegian children with periodic fever, aphthous stomatitis, pharyngitis and cervical adenitis syndrome; a population-based study. Acta Paediatr.
7413 Fossum GH, Lindbaek M, Gjelstad S, et al. (2013). Are children carrying the burden of broad-spectrum antibiotics in general practice? Prescription pattern for paediatric outpatients with respiratory tract infections in Norway. BMJ Open.
7414 Franzetti M, Adorni F, Parravicini C, et al. (2013). Trends and predictors of non-AIDS-defining cancers in men and women with HIV infection: a single-institution retrospective study before and after the introduction of HAART. J Acquir Immune Defic Syndr.
7415 Friedman NR, Perkins JN, McNair B, et al. (2013). Current practice patterns for sleep-disordered breathing in children. Laryngoscope.
7416 Friedrichsdorf SJ, Nugent AP, Foster LP, et al. (2013). A Comparison of Postoperative Tramadol versus Acetaminophen with Codeine in Children Undergoing Tonsillectomy. Otolaryngology--head and neck surgery.
7417 Fujita K, Hatta K. (2013). Renal biopsy cases in myeloproliferative neoplasms (MPN). CEN Case Reports.
7418 Fukuda T, Chidambaran V, Mizuno T, et al. (2013). OCT1 genetic variants influence the pharmacokinetics of morphine in children. Pharmacogenomics.
7419 Galarza M, Gazzeri R, Alfieri A, et al. (2013). “Triple R” tonsillar technique for the management of adult Chiari I malformation: surgical note. Acta Neurochir (Wien).
7420 Gallagher TQ, Brigger MT, Hartnick CJ. (2013). Bleeding risk and dexamethasone use in children undergoing tonsillectomy--reply. Jama.
7421 Ganesan P, Piha-Paul S, Naing A, et al. (2013). Phase I clinical trial of lenalidomide in combination with temsirolimus in patients with advanced cancer. Invest New Drugs.
7422 Gao M, Hao Y, Huang MX, et al. (2013). Clinicopathological study of distant metastases of salivary adenoid cystic carcinoma. Int J Oral Maxillofac Surg.
7423 Gelardi M, Iannuzzi L, Greco Miani A, et al. (2013). Double-blind placebo-controlled randomized clinical trial on the efficacy of Aerosal in the treatment of sub-obstructive adenotonsillar hypertrophy and related diseases. Int J Pediatr Otorhinolaryngol.
7424 Gelardi M, Passalacqua G, Fiorella ML, et al. (2013). Assessment of biofilm by nasal cytology in different forms of rhinitis and its functional correlations. Eur Ann Allergy Clin Immunol.
7425 Gensheimer MF, Rainey D, Douglas JG, et al. (2013). Neutron radiotherapy for adenoid cystic carcinoma of the lacrimal gland. Ophthal Plast Reconstr Surg.
7426 Gentile D, Bartholow A, Valovirta E, et al. (2013). Current and Future Directions in Pediatric Allergic Rhinitis. Journal of Allergy and Clinical Immunology: In Practice.
7427 Gerbershagen HJ, Aduckathil S, van Wijck AJ, et al. (2013). Pain intensity on the first day after surgery: a prospective cohort study comparing 179 surgical procedures. Anesthesiology.
7428 Gil-Ascencio M, Castillo-Gomez CJ, Palacios-Saucedo Gdel C, et al. (2013). Antibiotic prophylaxis in tonsillectomy and its relationship with postoperative morbidity. Acta Otorrinolaringol Esp.
7429 Giorgianni A, Pellegrino C, De Benedictis A, et al. (2013). Lhermitte-duclos disease: A case report. Neuroradiology Journal.
7430 Goldman JL, Baugh RF, Davies L, et al. (2013). Mortality and major morbidity after tonsillectomy: etiologic factors and strategies for prevention. Laryngoscope.
7431 Gomaa MA, Mohammed HM, Abdalla AA, et al. (2013). Effect of adenoid hypertrophy on the voice and laryngeal mucosa in children. Int J Pediatr Otorhinolaryngol.
7432 Gopalan S, Hamizan A, Yunus MRM, et al. (2013). Bilateral synchronous tonsillar carcinoma with bilateral neck disease. Rawal Medical Journal.
7433 Gordon S, LaTorre A, Witman P. (2013). Persistent pediatric contact leukoderma after exposure to butterfly electrocardiogram back pad: a report of three cases. Pediatr Dermatol.
7434 Gorzelnik A, Zawadzka-Glos L. (2013). Bellocq's tamponade in children who underwent operative treatment on the waldeyer's ring in the children's otolaryngology clinic in warsaw. New Medicine.
7435 Goyal N, Atmakuri M, Goldenberg D. (2013). Anatomy of the oropharynx: The robotic perspective. Operative Techniques in Otolaryngology - Head and Neck Surgery.
7436 Goyal SS, Shah R, Roberson DW, et al. (2013). Variation in post-adenotonsillectomy admission practices in 24 pediatric hospitals. Laryngoscope.
7437 Gozal D, Kheirandish-Gozal L, Bhattacharjee R, et al. (2013). Circulating adropin concentrations in pediatric obstructive sleep apnea: potential relevance to endothelial function. J Pediatr.
7438 Green KK, Mudd P, Prager J. (2013). Death after adenotonsillectomy secondary to massive pulmonary embolism. Int J Pediatr Otorhinolaryngol.
7439 Grover N, Boama V, Chou MR. (2013). Pseudo (platelet-type) von Willebrand disease in pregnancy: a case report. BMC Pregnancy Childbirth.
7440 Gu FM, Chi FL, Dai CF, et al. (2013). Surgical outcomes of 43 cases with adenoid cystic carcinoma of the external auditory canal. Am J Otolaryngol.
7441 Gu MJ, Ha JO. (2013). CD56 positive diffuse large B-cell lymphoma: a case report and literature review. Int J Clin Exp Pathol.
7442 Guclu O, Akcali A, Sahin EM, et al. (2013). Relationship between Helicobacter pylori Adenotonsillar Colonization and Frequency of Adenotonsillitis in Children. Balkan Med J.
7443 Guilleminault C, Huang YS, Monteyrol PJ, et al. (2013). Critical role of myofascial reeducation in pediatric sleep-disordered breathing. Sleep Med.
7444 Guilleminault C, Huang YS, Quo S, et al. (2013). Teenage sleep-disordered breathing: recurrence of syndrome. Sleep Med.
7445 Gupta M, Govil D, Shri I. (2013). Retained foreign bodies: Vigilance is the price of safety. Indian Journal of Anaesthesia.
7446 Gurbuzler L, Eyibilen A, Aladag I. (2013). Tortuosity of the internal carotid artery detected during tonsillectomy: two case reports. Kulak Burun Bogaz Ihtis Derg.
7447 Gysin C. (2013). Indications of pediatric tonsillectomy. ORL J Otorhinolaryngol Relat Spec.
7448 Gysin C, Dulguerov P. (2013). Hemorrhage after tonsillectomy: does the surgical technique really matter?. ORL J Otorhinolaryngol Relat Spec.
7449 Habermann W, Muller W. (2013). Tissue penetration of bipolar electrosurgical currents: Joule overheating beyond the surface layer. Head Neck.
7450 Harper C, Corlett C, Macdonald G, et al. (2013). PW03-032 periodic fevers in children. Pediatric Rheumatology.
7451 Harris SM, Davis JC, Snyder SE, et al. (2013). Evaluation of the biodistribution of 11C-methionine in children and young adults. J Nucl Med.
7452 Hartzell LD, Guillory RM, Munson PD, et al. (2013). Tongue base suspension in children with cerebral palsy and obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
7453 Hasanein R, El-Sayed W. (2013). The effect of nebulized lidocaine hydrochloride on emergence from sevoflurane anesthesia in children undergoing Tonsillectomy. Egyptian Journal of Anaesthesia.
7454 Hasukic B. (2013). OSA-18 survey in evaluation of sleep-disordered breathing in children with adenotonsillar hypertrophy. Med Arch.
7455 Hathorn I, Steele P, Aldridge L, et al. (2013). Adult and paediatric tonsillectomy: a two cycle audit of Scottish Intercollegiate Guidelines Network 117 in a total of one hundred and sixty nine patients. Clin Otolaryngol.
7456 Hauser RA, Carlucci CM. (2013). Sleep Apnea. Parkinson's Disease and Nonmotor Dysfunction.
7457 He L, Peng Y, Liu H, et al. (2013). Activation of the interleukin-4/signal transducer and activator of transcription 6 signaling pathway and homeodomain-interacting protein kinase 2 production by tonsillar mononuclear cells in IgA nephropathy. Am J Nephrol.
7458 He XY, Cao JP, Shi XY, et al. (2013). Dexmedetomidine versus morphine or fentanyl in the management of children after tonsillectomy and adenoidectomy: a meta-analysis of randomized controlled trials. Ann Otol Rhinol Laryngol.
7459 He Y, Scholes MA, Wiet GJ, et al. (2013). Complement activation in pediatric patients with recurrent acute otitis media. Int J Pediatr Otorhinolaryngol.
7460 Heba HA, Elnabil Lobna M, Ahmed EMB, et al. (2013). Effect of adenotonsillectomy on nocturnal enuresis in children with OSA. Egyptian Journal of Chest Diseases and Tuberculosis.
7461 Henke C, Rieger J, Hartmann S, et al. (2013). Paraneoplastic cerebellar degeneration associated with lymphoepithelial carcinoma of the tonsil. BMC Neurol.
7462 Hitre E, Budai B, Takacsi-Nagy Z, et al. (2013). Cetuximab and platinum-based chemoradio- or chemotherapy of patients with epidermal growth factor receptor expressing adenoid cystic carcinoma: a phase II trial. Br J Cancer.
7463 Holliday MA, Tavaluc R, Zhuang T, et al. (2013). Oncologic benefit of tonsillectomy in stage I and II tonsil cancer: a surveillance epidemiology and end results database review. JAMA Otolaryngol Head Neck Surg.
7464 Holstiege J, Garbe E. (2013). Systemic antibiotic use among children and adolescents in Germany: a population-based study. Eur J Pediatr.
7465 Holznagel E, Yutzy B, Schulz-Schaeffer W, et al. (2013). Foodborne transmission of bovine spongiform encephalopathy to nonhuman primates. Emerg Infect Dis.
7466 Honarmand A, Safavi M, Kashefi P, et al. (2013). Comparison of effect of intravenous ketamine, peritonsillar infiltration of tramadol and their combination on pediatric posttonsillectomy pain: A double-blinded randomized placebo-controlled clinical trial. Res Pharm Sci.
7467 Hong SM, Cho JG, Chae SW, et al. (2013). Coblation vs. Electrocautery Tonsillectomy: A Prospective Randomized Study Comparing Clinical Outcomes in Adolescents and Adults. Clin Exp Otorhinolaryngol.
7468 Horwood L, Nguyen LH, Brown K, et al. (2013). African American ethnicity as a risk factor for respiratory complications following adenotonsillectomy. JAMA Otolaryngol Head Neck Surg.
7469 Hotta K, Fukasawa Y, Akimoto M, et al. (2013). Tonsillectomy ameliorates histological damage of recurrent immunoglobulin A nephropathy after kidney transplantation. Nephrology (Carlton).
7470 Hsu WC, Kang KT, Weng WC, et al. (2013). Impacts of body weight after surgery for obstructive sleep apnea in children. Int J Obes (Lond).
7471 Huang H, Peng Y, Long XD, et al. (2013). Tonsillar CD4+CD25+ regulatory T cells from IgA nephropathy patients have decreased immunosuppressive activity in experimental IgA nephropathy rats. Am J Nephrol.
7472 Huang H, Sun W, Liang Y, et al. (2013). Comparative study of bacterial strains and antibiotic susceptibility tests between chronic tonsillitis patients with IgA nephropathy and without nephritis. Ren Fail.
7473 Huang J, Marcus CL, Davenport PW, et al. (2013). Respiratory and auditory cortical processing in children with obstructive sleep apnea syndrome. Am J Respir Crit Care Med.
7474 Huang MW, Zheng L, Liu SM, et al. (2013). 125I brachytherapy alone for recurrent or locally advanced adenoid cystic carcinoma of the oral and maxillofacial region. Strahlenther Onkol.
7475 Hueston WJ, Kaur D. (2013). Section two: otitis media. FP Essent.
7476 Hui JL, Wilson-Smith EM. (2013). Systemic analgesics in children - Update. Anaesthesia and Intensive Care Medicine.
7477 Hultcrantz E, Ericsson E. (2013). Factors influencing the indication for tonsillectomy: a historical overview and current concepts. ORL J Otorhinolaryngol Relat Spec.
7478 Hultcrantz E, Ericsson E, Windfuhr JP, et al. (2013). Comments to ORL 2013;75:155-164 (DOI: 10.1159/000342316). ORL J Otorhinolaryngol Relat Spec.
7479 Hwang SH, Guilleminault C, Park CS, et al. (2013). Usefulness of adenotonsillar size for prediction of severity of obstructive sleep apnea and flow limitation. Otolaryngol Head Neck Surg.
7480 Hyder O, Yaster M, Bateman BT, et al. (2013). Surgical procedures and outcomes among children with sickle cell disease. Anesth Analg.
7481 Ibanez MD, Valero AL, Montoro J, et al. (2013). Analysis of comorbidities and therapeutic approach for allergic rhinitis in a pediatric population in Spain. Pediatr Allergy Immunol.
7482 Ibekwe TS, Obasikene G, Offiong E. (2013). Tonsillectomy: Vasoconstrictive hydrolytic cold dissection method. Afr J Paediatr Surg.
7483 Ingram DG, Matthews CK. (2013). Effect of adenotonsillectomy on c-reactive protein levels in children with obstructive sleep apnea: a meta-analysis. Sleep Med.
7484 Iodice FG, Testa G. (2013). Pain relief in patients undergoing tonsillectomy. Arch Trauma Res.
7485 Isaacson G. (2013). Further concerns regarding opioids after tonsillectomy in children. Otolaryngol Head Neck Surg.
7486 Israel LP, Benharoch D, Gopas J, et al. (2013). A pro-inflammatory role for nuclear factor kappa B in childhood obstructive sleep apnea syndrome. Sleep.
7487 Ivaskevicius V, Marquardt N, Horneff S, et al. (2013). Neoplasm-induced bleeding in inherited fxiii subunit a deficiency-a case report. Transfusion Medicine and Hemotherapy.
7488 Jaafari-Ashkavandi Z, Ashraf MJ, Moshaverinia M. (2013). Salivary gland tumors: a clinicopathologic study of 366 cases in southern Iran. Asian Pac J Cancer Prev.
7489 Jabbari Moghaddam Y, Golzari SE, Saboktakin L, et al. (2013). Does adenotonsillectomy alter IGF-1 and ghrelin serum levels in children with adenotonsillar hypertrophy and failure to thrive? A prospective study. Int J Pediatr Otorhinolaryngol.
7490 Jacques T, Nash R, Kenway B, et al. (2013). Pitfalls of operative management of secondary post-tonsillectomy haemorrhage--a case report. B-ent.
7491 Jaggi P, Kajon AE, Mejias A, et al. (2013). Human adenovirus infection in Kawasaki disease: a confounding bystander?. Clin Infect Dis.
7492 Janda M, Bajorat J, Kudlik C, et al. (2013). Comparison of heart rate variability response in children undergoing elective endotracheal intubation with and without neuromuscular blockade: a randomized controlled trial. Paediatr Anaesth.
7493 Jensen A, Fago-Olsen H, Sorensen CH, et al. (2013). Molecular mapping to species level of the tonsillar crypt microbiota associated with health and recurrent tonsillitis. PLoS One.
7494 Jha AK, Bhardwaj N, Yaddanapudi S, et al. (2013). A randomized study of surgical site infiltration with bupivacaine or ketamine for pain relief in children following cleft palate repair. Paediatr Anaesth.
7495 Jiang JY. (2013). Head trauma in China. Injury.
7496 Jones SF, Barker JA. (2013). Treatment of obstructive sleep apnea. Sleep Medicine Clinics.
7497 Joseph AW, Ogawa T, Bishop JA, et al. (2013). Molecular etiology of second primary tumors in contralateral tonsils of human papillomavirus-associated index tonsillar carcinomas. Oral Oncol.
7498 Joseph S, Prakash M, Mohammed HK, et al. (2013). Benign mass in tonsil- Cavernous hemangioma. Journal of Clinical and Diagnostic Research.
7499 Kallel S, Hadj Taieb H, Makni S, et al. (2013). Lymphoma presenting as a peritonsillar abscess. Eur Ann Otorhinolaryngol Head Neck Dis.
7500 Kalyoussef E, Brooks NO, Quraishi H, et al. (2013). Idiopathic intracranial hypertension in a child with obstructive sleep apnea cured by tonsillectomy/adenoidectomy. J Neuroophthalmol.
7501 Kamarauskas A, Dahl MR, Hlidarsdottir T, et al. (2013). Need for better analgesic treatment after tonsillectomy in ear, nose and throat practices. Dan Med J.
7502 Kanai H, Kobayashi A, Matsushita K, et al. (2013). Methylprednisolone pulse therapy and intravenous cyclophosphamide therapy combined with cocktail therapy in severe pediatric Henoch-Schonlein purpura nephritis patient. CEN Case Reports.
7503 Kaneko T, Shimizu A, Tsuruoka S, et al. (2013). Efficacy of steroid pulse therapy in combination with mizoribine following tonsillectomy for immunoglobulin A nephropathy in renally impaired patients. J Nippon Med Sch.
7504 Kang KT, Chou CH, Weng WC, et al. (2013). Associations between adenotonsillar hypertrophy, age, and obesity in children with obstructive sleep apnea. PLoS One.
7505 Kanmaz A, Muderris T, Bercin S, et al. (2013). Children's quality of life after adenotonsillectomy. B-ENT.
7506 Kansagra S, Vaughn B. (2013). Pediatric sleep apnea Five things you might not know. Neurology: Clinical Practice.
7507 Kara M, Ozturk K, Ozer B. (2013). An evaluation of the effects of adenoidectomy on voice and speech function in children. Kulak Burun Bogaz Ihtis Derg.
7508 Karppelin M, Siljander T, Huhtala H, et al. (2013). Recurrent cellulitis with benzathine penicillin prophylaxis is associated with diabetes and psoriasis. Eur J Clin Microbiol Infect Dis.
7509 Kasapoglu F, Demir UL, Kaya FN, et al. (2013). The effects of levobupivacaine infiltration on post-tonsillectomy pain relief in adults: a single-blinded, randomized, and controlled clinical study. Eur Arch Otorhinolaryngol.
7510 Katsanos KH, Voulgari PV, Goussia A, et al. (2013). Coexistence of Crohn's disease in a patient with systemic lupus erythematosus. Rheumatol Int.
7511 Katyal V, Kennedy D, Martin J, et al. (2013). Paediatric sleep-disordered breathing due to upper airway obstruction in the orthodontic setting: a review. Aust Orthod J.
7512 Keller M, Brigger MT. (2013). The steroid controversy: where are we?. ORL J Otorhinolaryngol Relat Spec.
7513 Khafagy AH, Osman SM. (2013). Preoperative administration of dexamethasone reduces post-tonsillectomy morbidities in adults. Egyptian journal of ear, nose, throat and allied sciences.
7514 Khalifa OSM, Hassanin AAM. (2013). Melatonin, ketamine and their combination in half doses for management of sevoflurane agitation in children undergoing adenotonsillectomy. Egyptian Journal of Anaesthesia.
7515 Khatwa U, Ramgopal S, Mylavarapu A, et al. (2013). MRI findings and sleep apnea in children with Chiari I malformation. Pediatr Neurol.
7516 Khodaghalian B, Tewary KK, Narchi H. (2013). PFAPA with facial swelling- a new association?. Indian J Pediatr.
7517 Khodaverdi M, Jorgensen G, Lange T, et al. (2013). Hearing 25 years after surgical treatment of otitis media with effusion in early childhood. Int J Pediatr Otorhinolaryngol.
7518 Kieran S, Gorman C, Kirby A, et al. (2013). Risk factors for desaturation after tonsillectomy: analysis of 4092 consecutive pediatric cases. Laryngoscope.
7519 Kilic M, Yilmaz C, Otuztuzun S, et al. (2013). Glutathione S-transferase enzyme activity and protein expressions in patients with tonsillitis. Turkish Journal of Biochemistry.
7520 Kim JW, Mun SJ, Lee WH, et al. (2013). Post-tonsillectomy hemorrhage in children: a single surgeon's experience with coblation compared to diathermy. Eur Arch Otorhinolaryngol.
7521 Kim JY, Lee JS, Park HY, et al. (2013). The effect of alfentanil versus ketamine on the intubation condition and hemodynamics with low-dose rocuronium in children. J Anesth.
7522 Kim SY, Lee WH, Rhee CS, et al. (2013). Regrowth of the adenoids after coblation adenoidectomy: cephalometric analysis. Laryngoscope.
7523 Kim YL, Seo DM, Shim KS, et al. (2013). Successful tracheal intubation using fiberoptic bronchoscope via an I-gel supraglottic airway in a pediatric patient with Goldenhar syndrome -A case report. Korean J Anesthesiol.
7524 Kisabay A, Zeybek S, Sari S, et al. (2013). A pre- and postoperative evaluation of multiple joint involvement as the initial finding of cervical syringomyelia and neuropathic arthropathy. Turkish Journal of Rheumatology.
7525 Kitcher ED, Searyoh K, Abaidoo B. (2013). Quality of life outcomes of adenotonsillectomy for obstructive sleep disorders: our experience in a Tertiary Care Centre in Ghana. West Afr J Med.
7526 Kizil Y, Aydil U, Ekinci O, et al. (2013). Salivary gland tumors in Turkey: demographic features and histopathological distribution of 510 patients. Indian J Otolaryngol Head Neck Surg.
7527 Klug TE, Rusan M, Clemmensen KK, et al. (2013). Smoking promotes peritonsillar abscess. Eur Arch Otorhinolaryngol.
7528 Kocum AI, Sener M, Caliskan E, et al. (2013). Intravenous paracetamol and dipyrone for postoperative analgesia after day-case tonsillectomy in children: a prospective, randomized, double blind, placebo controlled study. Braz J Otorhinolaryngol.
7529 Konieczny K, Biggs TC, Caldera S. (2013). Application of the Paediatric Throat Disorders Outcome Test (T-14) for tonsillectomy and adenotonsillectomy. Ann R Coll Surg Engl.
7530 Kontorinis G, Thevasagayam MS, Bateman ND. (2013). Airway obstruction in children with cerebral palsy: need for tracheostomy?. Int J Pediatr Otorhinolaryngol.
7531 Koo TR, Wu HG. (2013). Long-term results of ipsilateral radiotherapy for tonsil cancer. Radiation Oncology Journal.
7532 Kopp VJ. (2013). Counting backward. Anesthesiology.
7533 Korayem MM, Witmans M, MacLean J, et al. (2013). Craniofacial morphology in pediatric patients with persistent obstructive sleep apnea with or without positive airway pressure therapy: a cross-sectional cephalometric comparison with controls. Am J Orthod Dentofacial Orthop.
7534 Korona-Glowniak I, Niedzielski A, Malm A, et al. (2013). Serotypes and antibiotic resistance of Streptococcus pneumoniae from adenoids in preschool children with recurrent upper respiratory tract infections. Pol J Microbiol.
7535 Koshino K, Ushigome H, Sakai K, et al. (2013). Outcome of tonsillectomy for recurrent IgA nephropathy after kidney transplantation. Clin Transplant.
7536 Koshy E, Curcin V, Bottle A, et al. (2013). Response to Asimakopoulos et al. Clin Otolaryngol.
7537 Koshy E, Curcin V, Bottle A, et al. (2013). Sore throat consultations in general practice prior to tonsillectomy among eight hundred and sixty-three children in England: is this in accordance with the SIGN guidelines?. Clin Otolaryngol.
7538 Koskenkorva T, Koivunen P, Koskela M, et al. (2013). Short-term outcomes of tonsillectomy in adult patients with recurrent pharyngitis: a randomized controlled trial. CMAJ.
7539 Koukoutsis G, Balatsouras DG, Ganelis P, et al. (2013). Subcutaneous emphysema and pneumomediastinum after tonsillectomy. Case Rep Otolaryngol.
7540 Kovacevic L, Jurewicz M, Dabaja A, et al. (2013). Enuretic children with obstructive sleep apnea syndrome: should they see otolaryngology first?. J Pediatr Urol.
7541 Kozlova A, Barabanova O, Davydova N, et al. (2013). P03-004 production of proinflammatory cytokines in PFAPA. Pediatric Rheumatology.
7542 Kozlova A, Barabanova O, Kuzmenko N, et al. (2013). P03-005 MEFV heterozygous mutations in PFAPA patients. Pediatric Rheumatology.
7543 Krespi YP, Kizhner V. (2013). Laser tonsil cryptolysis: in-office 500 cases review. Am J Otolaryngol.
7544 Krol P, Bohm M, Sula V, et al. (2013). PFAPA syndrome: clinical characteristics and treatment outcomes in a large single-centre cohort. Clin Exp Rheumatol.
7545 Kuehn BM. (2013). FDA: No codeine after tonsillectomy for children. Jama.
7546 Kumpu M, Swanljung E, Tynkkynen S, et al. (2013). Recovery of probiotic Lactobacillus rhamnosus GG in tonsil tissue after oral administration: randomised, placebo-controlled, double-blind clinical trial. Br J Nutr.
7547 Kuo YY, Chu PY, Chang SY, et al. (2013). Treatment selection for tonsillar squamous cell carcinoma. J Chin Med Assoc.
7548 Kureshi S, Cornaglia MA, Maggs J, et al. (2013). Nasal expiratory positive airway pressure (NEPAP) devices for the treatment of pediatric obstructive sleep apnea syndrome (OSAS): A pilot study. Sleep.
7549 Kurnik K, Bartsch I, Maul-Pavicic A, et al. (2013). Novel mutation in Hermansky-Pudlak syndrome type 2 with mild immunological phenotype. Platelets.
7550 Kuroki H, Ishiwada N, Inoue N, et al. (2013). Comparison of clinical efficacy between 3-day combined clavulanate/amoxicillin preparation treatment and 10-day amoxicillin treatment in children with pharyngolaryngitis or tonsillitis. J Infect Chemother.
7551 Kwak HJ, Min SK, Moon BK, et al. (2013). Intubation time required for tracheal intubation with low-dose rocuronium in children with and without atropine. J Anesth.
7552 Kwon S, Jang K, Hwang S, et al. (2013). Narcolepsy with obstructive sleep apnea in a 4-year-old Korean girl: a case report. J Korean Med Sci.
7553 Lalwani K, Richins S, Aliason I, et al. (2013). The laryngeal mask airway for pediatric adenotonsillectomy: predictors of failure and complications. Int J Pediatr Otorhinolaryngol.
7554 Landelle C, Lesprit P, Legrand P, et al. (2013). Recurrent transmission of group a streptococcus pyogenes (GAS) during surgery by a health care worker (HCW). Antimicrobial Resistance and Infection Control.
7555 Landis BN. (2013). Tonsillectomy: a simple surgical procedure?. ORL J Otorhinolaryngol Relat Spec.
7556 Lane RJ, Davies PT. (2013). Modified Valsalva test differentiates primary from secondary cough headache. J Headache Pain.
7557 Lee JH, Park DC, Oh IW, et al. (2013). C-type lectin receptors mRNA expression in patients with otitis media with effusion. Int J Pediatr Otorhinolaryngol.
7558 Lee TT, Lefebvre CE, Gans NE, et al. (2013). Quantifying respiratory complications post-adenotonsillectomy in patients with normal or inconclusive overnight oximetry. J Otolaryngol Head Neck Surg.
7559 Lee YC, Eun YG, Shin SY, et al. (2013). Prevalence of snoring and high risk of obstructive sleep apnea syndrome in young male soldiers in Korea. J Korean Med Sci.
7560 Lehtivuori T, Palonen R, Mussalo-Rauhamaa H, et al. (2013). Otorhinolaryngological patient injuries in Finland. Laryngoscope.
7561 Lennon P, Amin M, Colreavy MP. (2013). A prospective study of parents' compliance with their child's prescribed analgesia following tonsillectomy. Ear Nose Throat J.
7562 Lennon P, Saunders J, Fenton JE. (2013). A longer stay for the kissing disease: epidemiology of bacterial tonsillitis and infectious mononucleosis over a 20-year period. J Laryngol Otol.
7563 Leonardis R, Duvvuri U, Mehta D. (2013). Transoral robotic surgery in the pediatric patient. Operative Techniques in Otolaryngology - Head and Neck Surgery.
7564 Leonardis RL, Duvvuri U, Mehta D. (2013). Transoral robotic-assisted lingual tonsillectomy in the pediatric population. JAMA Otolaryngol Head Neck Surg.
7565 Leonardis RL, Robison JG, Otteson TD. (2013). Evaluating the management of obstructive sleep apnea in neonates and infants. JAMA Otolaryngol Head Neck Surg.
7566 Letchumanan P, Rajagopalan R, Kamaruddin MY. (2013). Posttonsillectomy pain relief and epithelialization with honey. Turkish Journal of Medical Sciences.
7567 Lewis Sharon R, Nicholson A, Cardwell Mary E, et al. (2013). Nonsteroidal anti-inflammatory drugs and perioperative bleeding in paediatric tonsillectomy. Cochrane Database of Systematic Reviews.
7568 Liang H, Wang Q, Cheng H, et al. (2013). Preemptive peritonsillar infiltration with lidocaine for relief of bipolar adult post-tonsillectomy pain: a randomized, double-blinded clinical study. European archives of oto-rhino-laryngology.
7569 Lim DJ, Kang SH, Kim BH, et al. (2013). Treatment of obstructive sleep apnea syndrome using radiofrequency-assisted uvulopalatoplasty with tonsillectomy. Eur Arch Otorhinolaryngol.
7570 Lin SC, Biggs SN, Davey MJ, et al. (2013). Screening for OSA in children with down syndrome. Sleep and Biological Rhythms.
7571 Little P, Stuart B, Hobbs FD, et al. (2013). Predictors of suppurative complications for acute sore throat in primary care: prospective clinical cohort study. BMJ.
7572 Lunny C, Knopp-Sihota JA, Fraser SN. (2013). Surgery and risk for multiple sclerosis: a systematic review and meta-analysis of case-control studies. BMC Neurol.
7573 Lyford-Pike S, Peng S, Young GD, et al. (2013). Evidence for a role of the PD-1:PD-L1 pathway in immune resistance of HPV-associated head and neck squamous cell carcinoma. Cancer Res.
7574 Macchi A, Castelnuovo P, Terranova P, et al. (2013). Effects of sodium hyaluronate in children with recurrent upper respiratory tract infections: results of a randomised controlled study. Int J Immunopathol Pharmacol.
7575 Macerollo A, Martino D. (2013). Pediatric Autoimmune Neuropsychiatric Disorders Associated with Streptococcal Infections (PANDAS): An Evolving Concept. Tremor Other Hyperkinet Mov (N Y).
7576 MacKay SG, Carney AS, Woods C, et al. (2013). Modified uvulopalatopharyngoplasty and coblation channeling of the tongue for obstructive sleep apnea: a multi-centre Australian trial. J Clin Sleep Med.
7577 MacLean JE. (2013). Montelukast potentially efficacious in children with non-severe obstructive sleep apnoea in the short term. Evidence-Based Medicine.
7578 Magdalena ML, Caragol L, Sole A, et al. (2013). Protocol for post-tonsillectomy pain control in outpatient adults. Acta Otorrinolaringol Esp.
7579 Magnusson A. (2013). Evaluation of surgically assisted rapid maxillary expansion and orthodontic treatment. Effects on dental, skeletal and nasal structures and rhinological findings. Swed Dent J Suppl.
7580 Mahesh Kumar U, Pande P, Savita SS, et al. (2013). An extra-adrenal pheochromocytoma presenting as malignant hypertension- A report of two cases. Journal of Clinical and Diagnostic Research.
7581 Malakasioti G, Alexopoulos EI, Varlami V, et al. (2013). Low morning serum cortisol levels in children with tonsillar hypertrophy and moderate-to-severe OSA. Sleep.
7582 Mandel EM, Swarts JD, Casselbrant ML, et al. (2013). Eustachian tube function as a predictor of the recurrence of middle ear effusion in children. Laryngoscope.
7583 Manuel A, Witmans M, El-Hakim H. (2013). Children with a history of prematurity presenting with snoring and sleep-disordered breathing: a cross-sectional study. Laryngoscope.
7584 Manzato L, Trivelato FP, Alvarenga AY, et al. (2013). Endovascular treatment of a linguofacial trunk pseudoaneurysm after tonsillectomy. Braz J Otorhinolaryngol.
7585 Marchica CL, Pitaro J, Daniel SJ. (2013). Recurrent tube insertion for chronic otitis media with effusion in children over 6 years. Int J Pediatr Otorhinolaryngol.
7586 Marcotullio D, Iannella G, Macri GF, et al. (2013). Renal clear cell carcinoma and tonsil metastasis. Case Rep Otolaryngol.
7587 Mardekian S, Karp JK. (2013). Lymphangioma of the palatine tonsil. Arch Pathol Lab Med.
7588 Martha VF, Moreira Jda S, Martha AS, et al. (2013). Reversal of pulmonary hypertension in children after adenoidectomy or adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
7589 Massard C, Margetts J, Amellal N, et al. (2013). Phase I study of PM00104 (Zalypsis(R)) administered as a 1-hour weekly infusion resting every fourth week in patients with advanced solid tumors. Invest New Drugs.
7590 Mat Lazim N, Abdullah B, Salim R. (2013). The effect of Tualang honey in enhancing post tonsillectomy healing process. An open labelled prospective clinical trial. Int J Pediatr Otorhinolaryngol.
7591 Matich SM. (2013). Just pediatrics: Just say “no” to codeine: The story of kids, ultrarapid metabolizers, and the CYP2D6 system. Journal of Radiology Nursing.
7592 Matsuzaki K, Suzuki Y, Nakata J, et al. (2013). Nationwide survey on current treatments for IgA nephropathy in Japan. Clin Exp Nephrol.
7593 Matuska P, Kara T, Homolka P, et al. (2013). Advances in the management of sleep-disordered breathing in heart failure. Cor et Vasa.
7594 McCormick ME, Sheyn A, Haupert M, et al. (2013). Gastroesophageal reflux as a predictor of complications after adenotonsillectomy in young children. Int J Pediatr Otorhinolaryngol.
7595 McDougall RJ. (2013). Paediatric emergencies. Anaesthesia.
7596 Mehta V, Johnson P, Tassler A, et al. (2013). A new paradigm for the diagnosis and management of unknown primary tumors of the head and neck: a role for transoral robotic surgery. Laryngoscope.
7597 Mendoza PR, Jakobiec FA, Krane JF. (2013). Immunohistochemical features of lacrimal gland epithelial tumors. Am J Ophthalmol.
7598 Mesolella M, Cimmino M, Cantone E, et al. (2013). Management of otolaryngological manifestations in mucopolysaccharidoses: our experience. Acta Otorhinolaryngol Ital.
7599 Michel J, Fakhry N, Santini L, et al. (2013). Sinonasal adenoid cystic carcinomas: clinical outcomes and predictive factors. Int J Oral Maxillofac Surg.
7600 Michel-Lepage A, Ventelou B, Nebout A, et al. (2013). Cross-sectional survey: risk-averse French GPs use more rapid-antigen diagnostic tests in tonsillitis in children. BMJ Open.
7601 Mirzaa GM, Riviere JB, Dobyns WB. (2013). Megalencephaly syndromes and activating mutations in the PI3K-AKT pathway: MPPH and MCAP. Am J Med Genet C Semin Med Genet.
7602 Mizrak A, Karatas E, Saruhan R, et al. (2013). Does dexmedetomidine affect intraoperative blood loss and clotting tests in pediatric adenotonsillectomy patients?. J Surg Res.
7603 Moore A. (2013). Gabapentin and post tonsillectomy pain-the next best thing?. Arch Trauma Res.
7604 Morabia A. (2013). Snippets from the past: the evolution of Wade Hampton Frost's epidemiology as viewed from the American Journal of Hygiene/Epidemiology. Am J Epidemiol.
7605 Motta G, Motta S, Cassano P, et al. (2013). Effects of guidelines on adeno-tonsillar surgery on the clinical behaviour of otorhinolaryngologists in Italy. BMC Ear Nose Throat Disord.
7606 Muderris T, Yazici A, Bercin S, et al. (2013). Consumer acoustic reflectometry: accuracy in diagnosis of otitis media with effusion in children. Int J Pediatr Otorhinolaryngol.
7607 Muhammad R, Ullah A, Anwar K, et al. (2013). Per-operative efficacy of single intravenous bolus dose of Dexamethasone in reducing post tonsillectomy pain in adults. Journal of Medical Sciences (Peshawar).
7608 Muhlebach MS, Shaffer CB, Georges L, et al. (2013). Bronchoscopy and airway management in patients with mucopolysaccharidoses (MPS). Pediatr Pulmonol.
7609 Mulay K, Puthyapurayil FM, Mohammad JA, et al. (2013). Adenoid cystic carcinoma of the lacrimal gland: role of nuclear survivin (BIRC5) as a prognostic marker. Histopathology.
7610 Mun SH, No MY. (2013). Internal leakage of oxygen flush valve. Korean Journal of Anesthesiology.
7611 Muratori E, Meccariello G, Deganello A, et al. (2013). Tonsillectomy and residents: a safe match?. Clin Otolaryngol.
7612 Murphy TK, Lewin AB, Parker-Athill EC, et al. (2013). Tonsillectomies and adenoidectomies do not prevent the onset of pediatric autoimmune neuropsychiatric disorder associated with group A streptococcus. Pediatr Infect Dis J.
7613 Musiatowiwcz M, Koda M, Sulkowski S. (2013). The TIMP-1 expression in germinal centers of hypertrophied adenoids in children. Int J Pediatr Otorhinolaryngol.
7614 Muzzi E, Parentin F, Pelos G, et al. (2013). Bilateral orbital preseptal cellulitis after combined adenotonsillectomy and strabismus surgery--case report and pathogenetic hypothesis. Int J Pediatr Otorhinolaryngol.
7615 Na HS, Song IA, Hwang JW, et al. (2013). Emergence agitation in children undergoing adenotonsillectomy: a comparison of sevoflurane vs. sevoflurane-remifentanil administration. Acta Anaesthesiol Scand.
7616 Nabavizadeh SA, Vossough A, Pollock AN. (2013). Clival osteomyelitis. Pediatr Emerg Care.
7617 Nafiu OO, Shanks A, Abdo S, et al. (2013). Association of high body mass index in children with early post-tonsillectomy pain. Int J Pediatr Otorhinolaryngol.
7618 Nakaya M, Kimura Y, Onuki Y, et al. (2013). Endoscopic-assisted tonsillectomy. Laryngoscope.
7619 Nandalike K, Shifteh K, Sin S, et al. (2013). Adenotonsillectomy in obese children with obstructive sleep apnea syndrome: magnetic resonance imaging findings and considerations. Sleep.
7620 Naresh Bharti J, Ghosh N, Arora P, et al. (2013). Chondroid choriostoma of palatine tonsil- A rare entity. Journal of Clinical and Diagnostic Research.
7621 Naserpour Farivar T, Najafipour R, Johari P. (2013). Prevalence of clarithromycin-resistant Helicobacter pylori in patients with chronic tonsillitis by allele-specific Scorpion real-time polymerase chain reaction assay. Laryngoscope.
7622 Nath A, Emani J, Suskind DL, et al. (2013). Predictors of persistent sleep apnea after surgery in children younger than 3 years. JAMA Otolaryngol Head Neck Surg.
7623 Navaratnarajah J, Thomas M. (2013). Day surgery for children. Anaesthesia and Intensive Care Medicine.
7624 Nebuloni M, Zawada L, Ferri A, et al. (2013). HIV-1 infected lymphoid organs upregulate expression and release of the cleaved form of uPAR that modulates chemotaxis and virus expression. PLoS One.
7625 Niedzielski A, Korona-Glowniak I, Malm A. (2013). High prevalence of Streptococcus pneumoniae in adenoids and nasopharynx in preschool children with recurrent upper respiratory tract infections in Poland--distribution of serotypes and drug resistance patterns. Med Sci Monit.
7626 Nitsch-Osuch A, Wisniewska A, Golebiak I, et al. (2013). Influenza vaccine coverage among children before planned adenotomy or adenotonsillectomy. Family Medicine and Primary Care Review.
7627 Nixon IJ, Palmer FL, Lakin P, et al. (2013). Pathologically determined tumor volume vs pathologic T stage in the prediction of outcome after surgical treatment of oropharyngeal squamous cell carcinoma. JAMA Otolaryngol Head Neck Surg.
7628 Noorbakhsh S, Farhadi M, Tabatabaei A, et al. (2013). Searching Mycoplasma pneumonia by serology & PCR in children with adenoid hypertrophy and rhinosinusitis: A case control study, Tehran, Iran. Iran J Microbiol.
7629 Norrington AC, Flood LM, Meek T, et al. (2013). Does day case pediatric tonsillectomy increase postoperative pain compared to overnight stay pediatric tonsillectomy? A prospective comparative audit. Paediatr Anaesth.
7630 Ochi A, Moriyama T, Takei T, et al. (2013). Comparison between steroid pulse therapy alone and in combination with tonsillectomy for IgA nephropathy. Int Urol Nephrol.
7631 Ochi JW. (2013). Acupuncture instead of codeine for tonsillectomy pain in children. Int J Pediatr Otorhinolaryngol.
7632 Oda K, Takanashi Y, Katori Y, et al. (2013). A ganglion cell cluster along the glossopharyngeal nerve near the human palatine tonsil. Acta Otolaryngol.
7633 Oda M, Kito S, Tanaka T, et al. (2013). Prevalence and imaging characteristics of detectable tonsilloliths on 482 pairs of consecutive CT and panoramic radiographs. BMC Oral Health.
7634 Oh KM, Kim MA, Youn JK, et al. (2013). Three-dimensional evaluation of the relationship between nasopharyngeal airway shape and adenoid size in children. Korean J Orthod.
7635 Ohsawa I, Kusaba G, Ishii M, et al. (2013). Extraglomerular C3 deposition and metabolic impacts in patients with IgA nephropathy. Nephrol Dial Transplant.
7636 Ohtani H. (2013). Granuloma cells in chronic inflammation express CD205 (DEC205) antigen and harbor proliferating T lymphocytes: similarity to antigen-presenting cells. Pathol Int.
7637 Ohya M, Otani H, Minami Y, et al. (2013). Tonsillectomy with steroid pulse therapy has more effect on the relapse rate than steroid pulse monotherapy in IgA nephropathy patients. Clin Nephrol.
7638 Ojha RP, Tota JE, Offutt-Powell TN, et al. (2013). Human papillomavirus-associated subsequent malignancies among long-term survivors of pediatric and young adult cancers. PLoS One.
7639 Okafor UV, Nwosu JN, Onyekwulu FA. (2013). Postoperative vomiting and fever following tonsillectomy in Enugu, Nigeria. Niger J Med.
7640 Olusesi AD, Undie NB, Amodu JE. (2013). Allergy history as a predictor of early onset adenoids/adenotonsillar hypertrophy among Nigerian children. Int J Pediatr Otorhinolaryngol.
7641 Onotai L, Lilly-Tariah O. (2013). Adenoid and tonsil surgeries in children: how relevant is pre-operative blood grouping and cross-matching?. Afr J Paediatr Surg.
7642 Oran B, Ozturk K, Cimen D, et al. (2013). Release of NT-pro brain natriuretic peptide in children before and after adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
7643 Otake H, Suga K, Suzuki H, et al. (2013). Antimicrobial prophylaxis in tonsillectomy: the efficacy of preoperative single-dose oral administration of azithromycin in preventing surgical site infection. Acta oto-laryngologica.
7644 Ovesen T, Kamarauskas A, Hlidarsdottir T, et al. (2013). Good long-term results after tonsillectomy in ear, nose and throat practices. Dan Med J.
7645 Ozbay I, Balikci HH, Alp A, et al. (2013). Candida infection after tonsillectomy in a 12-year-old girl. International Journal of Pediatric Otorhinolaryngology Extra.
7646 Ozkiris M, Kapusuz Z, Saydam L. (2013). The frequency of adenotonsillectomies in relation to socioeconomic status among primary school students in Yozgat province. Turk J Pediatr.
7647 Ozkiris M, Kapusuz Z, Saydam L. (2013). Comparison of three techniques in adult tonsillectomy. Eur Arch Otorhinolaryngol.
7648 Ozkiris M, Karacavus S, Kapusuz Z, et al. (2013). Comparison of two different adenoidectomy techniques with special emphasize on postoperative nasal mucociliary clearance rates: coblation technique vs. cold curettage. Int J Pediatr Otorhinolaryngol.
7649 Ozturk K, Sahin M, Rasit M, et al. (2013). Extramedullary plasmacytoma of head and neck region: Report of six cases with different localizations. Otorhinolaryngology Clinics.
7650 Pagella F, De Amici M, Matti E, et al. (2013). CD64 expression on monocytes in children with adenoid hypertrophy. Asian Pac J Allergy Immunol.
7651 Pajic-Penavic I, Danic D, Mrzljak-Vucinic N, et al. (2013). Postoperative quality of life after two different methods of tonsillectomy. Wien Klin Wochenschr.
7652 Palmieri B, Iannitti T, Fistetto G, et al. (2013). The “Swiss-cheese Doppler-guided laser tonsillectomy”: a new safe cribriform approach to intracapsular tonsillectomy. Lasers Med Sci.
7653 Papaioannou G, Kambas I, Tsaoussoglou M, et al. (2013). Age-dependent changes in the size of adenotonsillar tissue in childhood: implications for sleep-disordered breathing. J Pediatr.
7654 Paquette J, Le May S, Lachance Fiola J, et al. (2013). A randomized clinical trial of a nurse telephone follow-up on paediatric tonsillectomy pain management and complications. J Adv Nurs.
7655 Parikh SR, Sadoughi B, Sin S, et al. (2013). Deep cervical lymph node hypertrophy: a new paradigm in the understanding of pediatric obstructive sleep apnea. Laryngoscope.
7656 Passali D, Passali FM, Cambi J, et al. (2013). Role of adenotonsillectomy in OSAS children and behavioural disturbance. Otolaryngol Pol.
7657 Patel KR, Solomon IH, El-Mofty SK, et al. (2013). Mammaglobin and S-100 immunoreactivity in salivary gland carcinomas other than mammary analogue secretory carcinoma. Hum Pathol.
7658 Patil C, Kharat Patil R, Deshmukh P, et al. (2013). Primary tuberculosis of nasopharynx (adenoid)- a rare presentation. Asian Pac J Trop Med.
7659 Patino M, Sadhasivam S, Mahmoud M. (2013). Obstructive sleep apnoea in children: perioperative considerations. Br J Anaesth.
7660 Pearce EC, Mainthia R, Freeman KL, et al. (2013). The usefulness of a yearly head and neck surgery trip to rural Kenya. Otolaryngol Head Neck Surg.
7661 Pollei TR, Barrs DM, Hinni ML, et al. (2013). Operative time and cost of resident surgical experience: effect of instituting an otolaryngology residency program. Otolaryngol Head Neck Surg.
7662 Ponstein NA, Kim TW, Hsia J, et al. (2013). Continuous lesser palatine nerve block for postoperative analgesia after uvulopalatopharyngoplasty. Clin J Pain.
7663 Powell J, Powell EL, Conroy K, et al. (2013). Throat-related quality of life in peritonsillar abscess sufferers: Application of the adult tonsil outcome inventory. Journal of laryngology and otology.
7664 Prakash S. (2013). Oral gabapentin versus rectal diclofenac for postoperative analgesia. Arch Trauma Res.
7665 Praveen CV, Parthiban S, Terry RM. (2013). High incidence of post-tonsillectomy secondary haemorrhage following coblation tonsillectomy. Indian J Otolaryngol Head Neck Surg.
7666 Premalatha S, Mathankumar R, Mukilan B. (2013). Efficacy of oral clonidine as a premedicant in paediatric adenotonsillectomy in comparison with oral diazepam. Journal of evolution of medical and dental services.
7667 Pribuisiene R, Kuzminiene A, Sarauskas V, et al. (2013). The most important throat-related symptoms suggestive of chronic tonsillitis as the main indication for adult tonsillectomy. Medicina (Kaunas).
7668 Primhak R. (2013). Evaluation and management of upper airway obstruction. Paediatrics and Child Health (United Kingdom).
7669 Pringle MB, Natesh BG, Buchanan EM. (2013). National UK survey on the assessment and surgical management of suspected paediatric obstructive sleep apnoea syndrome. Int J Pediatr Otorhinolaryngol.
7670 Pugalenthi AK, Thomas B, Goh A, et al. (2013). Residual obstructive sleep apnoea (OSA) post adeno-tonsillectomy in a cohort of children referred to a tertiary children's hospital. Sleep and Biological Rhythms.
7671 Quaranta N, Milella C, Iannuzzi L, et al. (2013). A study of the role of different forms of chronic rhinitis in the development of otitis media with effusion in children affected by adenoid hypertrophy. Int J Pediatr Otorhinolaryngol.
7672 Racoosin JA, Roberson DW, Pacanowski MA, et al. (2013). New evidence about an old drug--risk with codeine after adenotonsillectomy. N Engl J Med.
7673 Rahman H, Illing E, Webb C, et al. (2013). Streptococcal toxic shock syndrome secondary to a deep neck space infection presenting with no throat or neck symptoms. BMJ Case Rep.
7674 Rajeshwary A, Rai S, Somayaji G, et al. (2013). Bacteriology of symptomatic adenoids in children. N Am J Med Sci.
7675 Rantala A, Jaakkola JJ, Jaakkola MS. (2013). Respiratory infections in adults with atopic disease and IgE antibodies to common aeroallergens. PLoS One.
7676 Rassekh CH, Weinstein GS, Loevner LA, et al. (2013). Transoral robotic surgery for prestyloid parapharyngeal space masses. Operative Techniques in Otolaryngology - Head and Neck Surgery.
7677 Rebechi G, Pontes TE, Braga EL, et al. (2013). Are histologic studies of adenotonsillectomy really necessary?. Int Arch Otorhinolaryngol.
7678 Reed M. (2013). Adenotonsillectomy for childhood sleep apnea. Pharmacy Times.
7679 Reis LG, Almeida EC, da Silva JC, et al. (2013). Tonsillar hyperplasia and recurrent tonsillitis: clinical-histological correlation. Braz J Otorhinolaryngol.
7680 Riggin L, Ramakrishna J, Sommer DD, et al. (2013). A 2013 updated systematic review & meta-analysis of 36 randomized controlled trials; no apparent effects of non steroidal anti-inflammatory agents on the risk of bleeding after tonsillectomy. Clin Otolaryngol.
7681 Rijken BF, Lequin MH, de Rooi JJ, et al. (2013). Foramen magnum size and involvement of its intraoccipital synchondroses in Crouzon syndrome. Plast Reconstr Surg.
7682 Rinaldi V, Pagani D, Torretta S, et al. (2013). Transoral robotic surgery in the management of head and neck tumours. ecancermedicalscience.
7683 Robb PJ. (2013). More codeine fatalities after tonsillectomy in North American children. Time to revise prescribing practice!. Clin Otolaryngol.
7684 Robison JG, Wilson C, Otteson TD, et al. (2013). Analysis of outcomes in treatment of obstructive sleep apnea in infants. Laryngoscope.
7685 Rodman R, Boehnke M, Venkatesan N, et al. (2013). Discharge after tonsillectomy in pediatric sleep apnea patients. Int J Pediatr Otorhinolaryngol.
7686 Rogers DJ, Ashland JE, Rozeboom MJ, et al. (2013). Modified superior pharyngeal flap for the treatment of velopharyngeal insufficiency in children. Int J Pediatr Otorhinolaryngol.
7687 Roggen I, van Berlaer G, Gordts F, et al. (2013). Centor criteria in children in a paediatric emergency department: for what it is worth. BMJ Open.
7688 Ronaldson PT, Davis TP. (2013). Gabapentin and diclofenac reduce opioid consumption in patients undergoing tonsillectomy: a result of altered CNS drug delivery?. Arch Trauma Res.
7689 Rosas K, Van Siclen CP. (2013). Pancytopenia with predominant thrombocytopenia in a 37-year-old female with Li Fraumeni Syndrome. Laboratory Medicine.
7690 Rospond-Kubiak I, Brazert A, Kociecki J, et al. (2013). Poststreptococcal syndrome mimicking conjunctival lymphoma. BMC Infect Dis.
7691 Rotenberg BW, Wickens B, Parnes J. (2013). Intraoperative ice pack application for uvulopalatoplasty pain reduction: a randomized controlled trial. Laryngoscope.
7692 Rother M, Seidel EJ, Fischer A, et al. (2013). Is the inflammatory reaction an essential part of recovery after muscle injury?. Annals of the Rheumatic Disease.
7693 Rout MR, Mohanty D, Vijaylaxmi Y, et al. (2013). Adenoid Hypertrophy in Adults: A case Series. Indian J Otolaryngol Head Neck Surg.
7694 Rye MS, Wiertsema SP, Scaman ES, et al. (2013). Genetic and functional evidence for a role for SLC11A1 in susceptibility to otitis media in early childhood in a Western Australian population. Infect Genet Evol.
7695 Saafan ME, Ibrahim WS, Tomoum MO. (2013). Role of adenoid biofilm in chronic otitis media with effusion in children. Eur Arch Otorhinolaryngol.
7696 Saito Y, Yoshida M, Ushiku T, et al. (2013). Prognostic value of p16 expression and alcohol consumption in Japanese patients with oropharyngeal squamous cell carcinoma. Cancer.
7697 Salah M, Abdel-Aziz M, Al-Farok A, et al. (2013). Recurrent acute otitis media in infants: analysis of risk factors. Int J Pediatr Otorhinolaryngol.
7698 Saleemi MY, Rashid A, Mujtaba S. (2013). Post-tonsillectomy: Primary and secondary haemorrhage in children. Pakistan Journal of Medical and Health Sciences.
7699 San T, Muluk NB, Cingi C. (2013). 1,25(OH)(2)D(3) and specific IgE levels in children with recurrent tonsillitis, and allergic rhinitis. Int J Pediatr Otorhinolaryngol.
7700 Sanchez Hernandez A, Soliveres J, Hernandez MJ, et al. (2013). How much do our children suffer during anesthesia induction?. European journal of anaesthesiology.
7701 Santos FP, Weber R, Fortes BC, et al. (2013). Short and long term impact of adenotonsillectomy on the immune system. Braz J Otorhinolaryngol.
7702 Sapthavee A, Bhushan B, Penn E, et al. (2013). A comparison of revision adenoidectomy rates based on techniques. Otolaryngol Head Neck Surg.
7703 Sarny S, Ossimitz G, Habermann W, et al. (2013). Preoperative coagulation screening prior to tonsillectomy in adults: current practice and recommendations. Eur Arch Otorhinolaryngol.
7704 Savaris R. (2013). Comparison of Analgesic Effect between Gabapentin and Diclofenac on Post-Operative Pain in Patients Undergoing Tonsillectomy - is the evidence enough?. Arch Trauma Res.
7705 Scalford D, Flynn-Roth R, Howard D, et al. (2013). Pain management of children aged 5 to 10 years after adenotonsillectomy. J Perianesth Nurs.
7706 Schiemann AH, Durholt EM, Pollock N, et al. (2013). Sequence capture and massively parallel sequencing to detect mutations associated with malignant hyperthermia. Br J Anaesth.
7707 Sedky K, Nazir R, Carvalho KS, et al. (2013). Attention deficit hyperactivity disorder and sleep disordered breathing in children. Journal of Pediatric Biochemistry.
7708 Sekole M. (2013). The Use of antibiotics post-tonsillectomy at Dr George Mukhari Hospital (DGMH): Is it of benefit?.
7709 Self EM, Bumpous J, Ziegler C, et al. (2013). Risk factors for hemorrhage after chemoradiation for oropharyngeal squamous cell carcinoma. JAMA Otolaryngol Head Neck Surg.
7710 Semberova J, Rychly B, Hanzelova J, et al. (2013). The immune status in situ of recurrent tonsillitis and idiopathic tonsillar hypertrophy. Bratisl Lek Listy.
7711 Serracino HS, Kleinschmidt-Demasters BK. (2013). Skull invaders: when surgical pathology and neuropathology worlds collide. J Neuropathol Exp Neurol.
7712 Setabutr D, Patel H, Choby G, et al. (2013). Predictive factors for prolonged hospital stay in pediatric tonsillectomy patients. Eur Arch Otorhinolaryngol.
7713 Sezen OS, Kubilay U, Erzin Y, et al. (2013). Does tonsillectomy affect the outcome of drug treatment for the eradication of gastric H pylori infection? A pilot study. Ear Nose Throat J.
7714 Sha S, Zhu Z, Sun X, et al. (2013). Effectiveness of brace treatment of Chiari malformation-associated scoliosis after posterior fossa decompression: a comparison with idiopathic scoliosis. Spine (Phila Pa 1976).
7715 Shahraki AD, Feizi A, Jabalameli M, et al. (2013). The effect of intravenous Dexamethasone on post-cesarean section pain and vital signs: A double-blind randomized clinical trial. Journal of Research in Pharmacy Practice.
7716 Shie DY, Tsou YA, Tai CJ, et al. (2013). Impact of obesity on uvulopalatopharyngoplasty success in patients with severe obstructive sleep apnea: a retrospective single-center study in Taiwan. Acta Otolaryngol.
7717 Siddiqui AS, Raees US, Siddiqui SZ, et al. (2013). Efficacy of pre-incisional peritonsillar infiltration of ketamine for post-tonsillectomy analgesia in children. J Coll Physicians Surg Pak.
7718 Sigurdardottir SL, Thorleifsdottir RH, Valdimarsson H, et al. (2013). The role of the palatine tonsils in the pathogenesis and treatment of psoriasis. Br J Dermatol.
7719 Silva JA, Santos AA, Costa Mdo D, et al. (2013). Suboccipital craniectomy with opening of the fourth ventricle and duraplasty: study of 192 cases of craniovertebral malformations. Arq Neuropsiquiatr.
7720 Simon LM, Matijasec JW, Perry AP, et al. (2013). Pediatric peritonsillar abscess: Quinsy ie versus interval tonsillectomy. Int J Pediatr Otorhinolaryngol.
7721 Sklar MC, Narang I, Ngan BY, et al. (2013). A solitary tonsil can cause severe obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
7722 Sleth JC, Servais R, Saizy C, et al. (2013). Disposable or reusable blade in laryngoscopy: what choice in Languedoc-Roussillon, France?. Br J Anaesth.
7723 Smith DF, Benke JR, Yaster S, et al. (2013). A pilot staging system to predict persistent obstructive sleep apnea in children following adenotonsillectomy. Laryngoscope.
7724 Smith DF, Vikani AR, Benke JR, et al. (2013). Weight gain after adenotonsillectomy is more common in young children. Otolaryngol Head Neck Surg.
7725 Smith ME, Lakhani R, Bhat N. (2013). Consenting for risk in common ENT operations: an evidence-based approach. Eur Arch Otorhinolaryngol.
7726 Soares D, Folbe AJ, Yoo G, et al. (2013). Drug-induced sleep endoscopy vs awake Muller's maneuver in the diagnosis of severe upper airway obstruction. Otolaryngol Head Neck Surg.
7727 Sobhy TS. (2013). Role of intranasal steroid in the prevention of recurrent nasal symptoms after adenoidectomy. Int J Otolaryngol.
7728 Sohn HS, Oh OH, Kwon JW, et al. (2013). Higher systemic antibiotic consumption in a population of South Korea (2008 - 2009). Int J Clin Pharmacol Ther.
7729 Soltani R, Soheilipour S, Hajhashemi V, et al. (2013). Evaluation of the effect of aromatherapy with lavender essential oil on post-tonsillectomy pain in pediatric patients: a randomized controlled trial. Int J Pediatr Otorhinolaryngol.
7730 Soni-Jaiswal A, Parry N, Kumar N. (2013). Paediatric tonsillectomy: Impact assessment using a validated patient reported outcome measure (PROM). Clinical Governance.
7731 Souza JF, Grechi TH, Anselmo-Lima WT, et al. (2013). Mastication and deglutition changes in children with tonsillar hypertrophy. Braz J Otorhinolaryngol.
7732 Sowerby LJ, Hussain Z, Husein M. (2013). The epidemiology, antibiotic resistance and post-discharge course of peritonsillar abscesses in London, Ontario. J Otolaryngol Head Neck Surg.
7733 Soylu E, Soylu N, Yildirim YS, et al. (2013). The prevelance of psichiatric symptoms in preschool children with adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
7734 Soylu E, Soylu N, Yildirim YS, et al. (2013). Psychiatric disorders and symptoms severity in patients with adenotonsillar hypertrophy before and after adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
7735 Spilsbury K, Ha JF, Semmens JB, et al. (2013). Cholesteatoma in cleft lip and palate: a population-based follow-up study of children after ventilation tubes. Laryngoscope.
7736 Standring RT, Guglielmo R, Yaremchuk KL, et al. (2013). Postoperative Tonsillectomy Pain Management: A Prospective Randomized Trial. Otolaryngology--head and neck surgery.
7737 Stanko D, Bergesio R, Davies K, et al. (2013). Postoperative pain, nausea and vomiting following adeno-tonsillectomy - a long-term follow-up. Paediatr Anaesth.
7738 Staudt CB, Gnoinski WM, Peltomaki T. (2013). Upper airway changes in Pierre Robin sequence from childhood to adulthood. Orthod Craniofac Res.
7739 Stojanovic Stipic S, Kardum G, Carev M, et al. (2013). Does total intravenous anesthesia decrease postoperative behavioral changes after adenotonsillectomy in children?. European journal of anaesthesiology.
7740 Stoner MJ, Dulaurier M. (2013). Pediatric ENT emergencies. Emerg Med Clin North Am.
7741 Strojan P, Ferlito A, Medina JE, et al. (2013). Contemporary management of lymph node metastases from an unknown primary to the neck: I. A review of diagnostic approaches. Head Neck.
7742 Strychowsky JE, Nayan S, Farrokhyar F, et al. (2013). YouTube: a good source of information on pediatric tonsillectomy?. Int J Pediatr Otorhinolaryngol.
7743 Stucken EZ, Grunstein E, Haddad J, et al. (2013). Factors contributing to cost in partial versus total tonsillectomy. Laryngoscope.
7744 Subramanyam R, Varughese A, Willging JP, et al. (2013). Future of pediatric tonsillectomy and perioperative outcomes. Int J Pediatr Otorhinolaryngol.
7745 Sudhakara Reddy R, Sai Kiran C, Sai Madhavi N, et al. (2013). Prevalence of elongation and calcification patterns of elongated styloid process in south India. J Clin Exp Dent.
7746 Sugimoto K, Fujita S, Miyazawa T, et al. (2013). Periodic fever, aphthous stomatitis, pharyngitis, and adenitis (PFAPA) syndrome and IgA nephropathy. Pediatr Nephrol.
7747 Suh GD. (2013). Evaluation of open midline glossectomy in the multilevel surgical management of obstructive sleep apnea syndrome. Otolaryngol Head Neck Surg.
7748 Sumitha R, Govar A. (2013). Unique presentation of non-hodgkin's lymphoma. International Journal of Pharma and Bio Sciences.
7749 Sumitha R, Mohamed HK. (2013). Unilateral tonsillar enlargement - a case series. International Journal of Pharma and Bio Sciences.
7750 Sumitha R, Ramya Kumar S, Hariprasad R. (2013). Enzymatic preparations - An alternative anti-inflammatory therapy. International Journal of Pharma and Bio Sciences.
7751 Sun GH, Auger KA, Aliu O, et al. (2013). Variation in inpatient tonsillectomy costs within and between US hospitals attributable to postoperative complications. Med Care.
7752 Sun GH, Auger KA, Aliu O, et al. (2013). Posttonsillectomy hemorrhage in children with von Willebrand disease or hemophilia. JAMA Otolaryngol Head Neck Surg.
7753 Sustersic M, Jeannet E, Cozon-Rein L, et al. (2013). Impact of information leaflets on behavior of patients with gastroenteritis or tonsillitis: a cluster randomized trial in French primary care. J Gen Intern Med.
7754 Szalmas A, Papp Z, Csomor P, et al. (2013). Microbiological profile of adenoid hypertrophy correlates to clinical diagnosis in children. Biomed Res Int.
7755 Szymanska A, Szymanski M, Morshed K, et al. (2013). Extranasopharyngeal angiofibroma: clinical and radiological presentation. Eur Arch Otorhinolaryngol.
7756 Tait AR, Voepel-Lewis T, Christensen R, et al. (2013). The STBUR questionnaire for predicting perioperative respiratory adverse events in children at risk for sleep-disordered breathing. Paediatr Anaesth.
7757 Takechi H, Oda T, Hotta O, et al. (2013). Clinical and immunological implications of increase in CD208+ dendritic cells in tonsils of patients with immunoglobulin A nephropathy. Nephrol Dial Transplant.
7758 Tamay Z, Akcay A, Ergin A, et al. (2013). Effects of dietary habits and risk factors on allergic rhinitis prevalence among Turkish adolescents. Int J Pediatr Otorhinolaryngol.
7759 Tanaka J, Kurosaki T, Shimada A, et al. (2013). Complications of adenotonsillectomy: a case report of meningitis due to dual infection with nontypeable Haemophilus influenzae and Streptococcus pneumoniae, and a prospective study of the rate of postoperative bacteremia. Jpn J Antibiot.
7760 Tang FR, Loke WK. (2013). Sulfur mustard and respiratory diseases: Revisit with special reference to the “Comments on ‘sulfur Mustard and Respiratory Diseases’, Tang and Loke ( 2012 ) and a prepared Integrated Mechanism for Chronic Pulmonary Disease from Exposure to Sulfur Mustard” by Saburi and Ghanei ( 2013 ). Crit Rev Toxicol.
7761 Tang Y, Peng Y, Yang S, et al. (2013). Effect of tonsillar mononuclear cell supernatants in patients with IgA nephropathy on renal tubular epithelial cells. Inflamm Res.
7762 Taspinar M, Cetin N, Gerceker D, et al. (2013). HHV-6 is ubiquitously found using Western blot in tonsils and adenoid tissues of healthy people. New Microbiol.
7763 Tekelioglu UY, Apuhan T, Akkaya A, et al. (2013). Comparison of topical tramadol and ketamine in pain treatment after tonsillectomy. Paediatr Anaesth.
7764 Tepe Karaca C, Celebi S, Oysu C, et al. (2013). Does cooling the tonsillar fossae during thermal welding tonsillectomy have an effect on postoperative pain and healing?. Eur Arch Otorhinolaryngol.
7765 Terada T. (2013). A clinicopathologic study of esophageal 860 benign and malignant lesions in 910 cases of consecutive esophageal biopsies. Int J Clin Exp Pathol.
7766 Thakur JS, Mohindroo NK, Sharma DR, et al. (2013). Tonsillitis with acute myeloid leukemia: a case series for caution. Ear Nose Throat J.
7767 Thomas B, Pugalenthi A, Tan SMQ, et al. (2013). Does optimal positive airway pressure (PAP) for the treatment of obstructive sleep apnoea (OSA) in children, correlate with the body mass index (BMI)?. Sleep and Biological Rhythms.
7768 Thomas K, Boeger D, Buentzel J, et al. (2013). Pediatric adenoidectomy: a population-based regional study on epidemiology and outcome. Int J Pediatr Otorhinolaryngol.
7769 Thong JF, Loke D, Karumathil Sivasankarannair R, et al. (2013). Use of narrow-band imaging in detection of nasopharyngeal carcinoma. J Laryngol Otol.
7770 Thottam PJ, Kovacevic L, Madgy DN, et al. (2013). Sleep architecture parameters that predict postoperative resolution of nocturnal enuresis in children with obstructive sleep apnea. Ann Otol Rhinol Laryngol.
7771 Tinoco G, Kanji R, Moola D. (2013). Schnitzler's syndrome: A case report. Case Reports in Medicine.
7772 Todorovic MM, Zvrko EZ. (2013). Immunoregulatory cytokines and chronic tonsillitis. Bosn J Basic Med Sci.
7773 Toepfner N, Henneke P, Berner R, et al. (2013). Impact of technical training on rapid antigen detection tests (RADT) in group A streptococcal tonsillopharyngitis. Eur J Clin Microbiol Infect Dis.
7774 Tolska HK, Takala A, Pitkaniemi J, et al. (2013). Post-tonsillectomy haemorrhage more common than previously described--an institutional chart review. Acta Otolaryngol.
7775 Tolska K, Takala A, Blomgren K, et al. (2013). Topical anaesthesia with ropivacaine in post-tonsillectomy pain, adult patients. Acta anaesthesiologica Scandinavica. Supplementum.
7776 Topal K, Kara CO, Bozkurt AI, et al. (2013). The risk of overweight and obesity in children after tonsillectomy: a cross-sectional study. Eur Arch Otorhinolaryngol.
7777 Torretta S, Drago L, Marchisio P, et al. (2013). Recurrences in chronic tonsillitis substained by tonsillar biofilm-producing bacteria in children. Relationship with the grade of tonsillar hyperplasy. Int J Pediatr Otorhinolaryngol.
7778 Torretta S, Drago L, Marchisio P, et al. (2013). Topographic distribution of biofilm-producing bacteria in adenoid subsites of children with chronic or recurrent middle ear infections. Ann Otol Rhinol Laryngol.
7779 Torretta S, Marchisio P, Cappadona M, et al. (2013). Nasopharyngeal fiberendoscopy in children: a diagnostic challenge in current clinical practice: how we do it. Int J Pediatr Otorhinolaryngol.
7780 Toubaru S, Yoshikawa K, Ohashi S, et al. (2013). Accuracy of methionine-PET in predicting the efficacy of heavy-particle therapy on primary adenoid cystic carcinomas of the head and neck. Radiat Oncol.
7781 Tremlett MR. (2013). Wither codeine?. Paediatr Anaesth.
7782 Tshifularo M, Govender L, Monama G. (2013). Otolaryngological, head and neck manifestations in HIV-infected patients seen at Steve Biko Academic Hospital in Pretoria, South Africa. S Afr Med J.
7783 Tsou YA, Lin CC, Lai CH, et al. (2013). Does Adenotonsillectomy really reduced clinic visits for pediatric upper respiratory tract infections? A national database study in Taiwan. Int J Pediatr Otorhinolaryngol.
7784 Tunney AM, Boore J. (2013). The effectiveness of a storybook in lessening anxiety in children undergoing tonsillectomy and adenoidectomy in Northern Ireland. Issues Compr Pediatr Nurs.
7785 Turnbull J, Patel A. (2013). The use of the laryngeal mask airway in ENT surgery: Facts and fiction. Trends in Anaesthesia and Critical Care.
7786 Ueda M, Okutani R, Oda Y. (2013). Preemptive analgesia for pain after tonsillectomy using ropivacaine local injection and continuous remifentanil administration: 14AP7-5. European Journal of Anaesthesiology.
7787 Ugur KS, Karabayirli S, Demircioglu RI, et al. (2013). The comparison of preincisional peritonsillar infiltration of ketamine and tramadol for postoperative pain relief on children following adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
7788 Ulualp SO, Koral K, Margraf L, et al. (2013). Management of intratonsillar abscess in children. Pediatr Int.
7789 Ulualp SO, Szmuk P. (2013). Drug-induced sleep endoscopy for upper airway evaluation in children with obstructive sleep apnea. Laryngoscope.
7790 Unal A, Ozlugedik S, Titiz A, et al. (2013). Killian nasal speculum-assisted tonsillectomy under local anesthesia. Turkiye Klinikleri Journal of Medical Sciences.
7791 Ungern-Sternberg BS, Davies K, Hegarty M, et al. (2013). The effect of deep vs. awake extubation on respiratory complications in high-risk children undergoing adenotonsillectomy: A prospective, randomised, controlled trial. European journal of anaesthesiology.
7792 Urquhart DS. (2013). Investigation and management of childhood sleep apnoea. Hippokratia.
7793 Urquhart DS, Starritt N. (2013). Sleep apnoea in children. Paediatrics and Child Health (United Kingdom).
7794 Vaher H, Kasenomm P, Vasar V, et al. (2013). A survey of parentally reported sleep health disorders in Estonian 8-9 year old children. BMC Pediatr.
7795 Valenzuela PM, Araya A, Perez CI, et al. (2013). Profile of inflammatory mediators in tonsils of patients with periodic fever, aphthous stomatitis, pharyngitis, and cervical adenitis (PFAPA) syndrome. Clin Rheumatol.
7796 Van Holsbeke C, Vos W, Van Hoorenbeeck K, et al. (2013). Functional respiratory imaging as a tool to assess upper airway patency in children with obstructive sleep apnea. Sleep Med.
7797 van Weert S, Bloemena E, van der Waal I, et al. (2013). Adenoid cystic carcinoma of the head and neck: a single-center analysis of 105 consecutive cases over a 30-year period. Oral Oncol.
7798 Vandeleur M, Davey MJ, Nixon GM. (2013). Are sleep studies helpful in children with Prader-Willi syndrome prior to commencement of growth hormone therapy?. J Paediatr Child Health.
7799 Vasileiadis I, Sofopoulos M, Arnogiannaki N, et al. (2013). A Merkel-cell carcinoma metastatic to the tonsil: a case report and review of the literature. J Oral Maxillofac Surg.
7800 Velasco Suarez CT, Figueroa Turienzo JM, Len F, et al. (2013). Pulse oximetry recording in children with adenotonsillar hypertrophy: usefulness in the diagnostic of obstructive sleep apnea syndrome. Arch Argent Pediatr.
7801 Venkatesan NN, Rodman RE, Mukerji SS. (2013). Post-tonsillectomy hemorrhage in children with hematological abnormalities. Int J Pediatr Otorhinolaryngol.
7802 Vent J, Haidle B, Wedemeyer I, et al. (2013). p16 expression in carcinoma of unknown primary: diagnostic indicator and prognostic marker. Head Neck.
7803 Vlastarakos PV, Iacovou E. (2013). Spontaneous tonsillar hemorrhage managed with emergency tonsillectomy in a 21-year-old man: A case report. Journal of Medical Case Reports.
7804 von Holstein SL. (2013). Tumours of the lacrimal gland. Epidemiological, clinical and genetic characteristics. Acta Ophthalmol.
7805 Von Scheven-Gete A, Hofer M, Simon G, et al. (2013). PReS-FINAL-2325: Different phenotypes associated with Q703K variant of the NLRP3 gene. Pediatric Rheumatology.
7806 Von Scheven-Gete A, Moix I, Simon G, et al. (2013). P03-002 different phenotypes associated with Q703K variant. Pediatric Rheumatology.
7807 von Ungern-Sternberg BS, Davies K, Hegarty M, et al. (2013). The effect of deep vs. awake extubation on respiratory complications in high-risk children undergoing adenotonsillectomy: a randomised controlled trial. Eur J Anaesthesiol.
7808 Walker P, Whitehead B, Rowley M. (2013). Role of paediatric intensive care following adenotonsillectomy for severe obstructive sleep apnoea: criteria for elective admission. J Laryngol Otol.
7809 Walner DL, Karas A. (2013). Standardization of reporting post-tonsillectomy bleeding. Ann Otol Rhinol Laryngol.
7810 Walter L, Nisbet L, Nixon G, et al. (2013). Long term improvement in sleep disordered breathing severity and sleep parameters following treatment in preschool children. Sleep and Biological Rhythms.
7811 Wandell P, Carlsson AC, Wettermark B, et al. (2013). Most common diseases diagnosed in primary care in Stockholm, Sweden, in 2011. Fam Pract.
7812 Wang AS, Stater BJ, Kacker A. (2013). Intratonsillar abscess: 3 case reports and a review of the literature. Int J Pediatr Otorhinolaryngol.
7813 Wang H, Chen P. (2013). Palatine tonsillar metastasis of rectal adenocarcinoma: a case report and literature review. World J Surg Oncol.
7814 Wang J, Cai CP, He SF, et al. (2013). Characteristics and prognostic factors for head and neck non-Hodgkin's lymphoma in Chinese patients. J Laryngol Otol.
7815 Wang Y, Li J, Ren YY, et al. (2013). The levels of liver enzymes and atypical lymphocytes are higher in youth patients with infectious mononucleosis than in preschool children. Clin Mol Hepatol.
7816 Waqar Rabbani M, Ali I, Zahid Latif H, et al. (2013). Serum Zinc Level in Children Presenting with Febrile Seizures. Pak J Med Sci.
7817 Waters K, Kol-Castro C, Varghese A, et al. (2013). Correlations between polysomnographic and lateral airway radiograph measurements in paediatric obstructive sleep apnoea. J Paediatr Child Health.
7818 Waters KA, Suresh S, Nixon GM. (2013). Sleep disorders in children. Med J Aust.
7819 Weaver JM. (2013). New FDA black box warning for codeine: how will this affect dentists?. Anesth Prog.
7820 Wen SL, Cheng MH, Cheng MF, et al. (2013). Pharmacotherapy response and regional cerebral blood flow characteristics in patients with obsessive-compulsive disorder. Behav Brain Funct.
7821 Whittaker MR. (2013). Opioid use and the risk of respiratory depression and death in the pediatric population. J Pediatr Pharmacol Ther.
7822 Wiksten J, Blomgren K, Roine RP, et al. (2013). Effect of tonsillectomy on health-related quality of life and costs. Acta Otolaryngol.
7823 Wils-Plotz EL, Jenkins MC, Dilger RN. (2013). Modulation of the intestinal environment, innate immune response, and barrier function by dietary threonine and purified fiber during a coccidiosis challenge in broiler chicks. Poult Sci.
7824 Windfuhr JP. (2013). Malpractice claims and unintentional outcome of tonsil surgery and other standard procedures in otorhinolaryngology. GMS Curr Top Otorhinolaryngol Head Neck Surg.
7825 Windfuhr JP. (2013). Serious complications following tonsillectomy: how frequent are they really?. ORL J Otorhinolaryngol Relat Spec.
7826 Windfuhr JP, Werner JA. (2013). Tonsillotomy: it's time to clarify the facts. Eur Arch Otorhinolaryngol.
7827 Withers A, Wilson A. (2013). Demographics of children attending a tertiary level sleep centre. Sleep and Biological Rhythms.
7828 Witmans M, Shafazand S. (2013). Adenotonsillectomy or watchful waiting in the management of childhood obstructive sleep apnea. Journal of clinical sleep medicine.
7829 Woolworth S. (2013). A radical proposition: the brief but exceptional history of the Seattle school clinic, 1914-21. J Hist Med Allied Sci.
7830 Wu G, Peng YM, Liu FY, et al. (2013). The role of memory B cell in tonsil and peripheral blood in the clinical progression of IgA nephropathy. Hum Immunol.
7831 Xia R, Zhou R, Tian Z, et al. (2013). High expression of H3K9me3 is a strong predictor of poor survival in patients with salivary adenoid cystic carcinoma. Arch Pathol Lab Med.
7832 Yamamoto T, Inoue Y, Tomiita M, et al. (2013). Successful treatment of Group A beta-hemolytic Streptococcus infection-associated juvenile cutaneous polyarteritis nodosa with tonsillectomy. Mod Rheumatol.
7833 Yamamoto Y, Hiki Y, Nakai S, et al. (2013). Comparison of effective impact among tonsillectomy alone, tonsillectomy combined with oral steroid and with steroid pulse therapy on long-term outcome of immunoglobulin A nephropathy. Clin Exp Nephrol.
7834 Yang LQ, Li JJ, Chen SQ, et al. (2013). Effect of different depths of anesthesia on perioperative stress response in children undergoing adenoidectomy and tonsillectomy. CNS neuroscience & therapeutics.
7835 Yao WCC, Corbitt CA, Bender ME, et al. (2013). Role of intraoperative ropivacaine in post-tonsillectomy pain control: Randomized control trial using a paired design. Otolaryngology--head and neck surgery.
7836 Yao-Cohen ML, Miller JS, Baganizi M, et al. (2013). Crude tonsillectomy and local concepts of illness in Kisoro, Uganda: community perception of gapfura and its treatment. Glob Public Health.
7837 Yeo JC, Ah-See KW, Mackenzie K. (2013). Variation in practice: an analysis of Scottish Surgical Profiles ENT data. Scott Med J.
7838 Yiengprugsawan V, Hogan A. (2013). Ear infection and its associated risk factors, comorbidity, and health service use in Australian children. Int J Pediatr.
7839 Yilmaz E, Sedky K, Bennett DS. (2013). The relationship between depressive symptoms and obstructive sleep apnea in pediatric populations: a meta-analysis. J Clin Sleep Med.
7840 Yilmaz HB, Celebi S, Sahin-Yilmaz A, et al. (2013). The role of mometasone furoate nasal spray in the treatment of adenoidal hypertrophy in the adolescents: a prospective, randomized, cross-over study. Eur Arch Otorhinolaryngol.
7841 Youngs R, Fisher E. (2013). WHO shows it cares about hearing loss. J Laryngol Otol.
7842 Youssef TF, Ahmed MR. (2013). Laser-assisted myringotomy versus conventional myringotomy with ventilation tube insertion in treatment of otitis media with effusion: Long-term follow-up. Interv Med Appl Sci.
7843 Yu JB, Zhang YC, Yang QP, et al. (2013). Invasion-associated genes identified by gene expression profiling in extranodal natural killer/T-cell lymphoma, nasal type. Leuk Lymphoma.
7844 Yuksel F, Dogan M, Karatas D, et al. (2013). Gastroesophageal reflux disease in children with chronic otitis media with effusion. J Craniofac Surg.
7845 Zagor M, Minarowska A, Knas M, et al. (2013). N-acetyl-beta-hexosaminidase in chronic tonsillitis and tonsillar hypertrophy. Otolaryngol Pol.
7846 Zandieh SO, Padwa BL, Katz ES. (2013). Adenotonsillectomy for obstructive sleep apnea in children with syndromic craniosynostosis. Plast Reconstr Surg.
7847 Zeidan YH, Shultz DB, Murphy JD, et al. (2013). Long-term outcomes of surgery followed by radiation therapy for minor salivary gland carcinomas. Laryngoscope.
7848 Zelenik K, Kukutschova J, Dvorackova J, et al. (2013). Possible role of nano-sized particles in chronic tonsillitis and tonsillar carcinoma: a pilot study. Eur Arch Otorhinolaryngol.
7849 Zeng H, Quinet S, Huang W, et al. (2013). Clinical and MRI features of neurological complications after influenza A (H1N1) infection in critically ill children. Pediatr Radiol.
7850 Zhang CY, Xia RH, Han J, et al. (2013). Adenoid cystic carcinoma of the head and neck: clinicopathologic analysis of 218 cases in a Chinese population. Oral Surg Oral Med Oral Pathol Oral Radiol.
7851 Zhang J, Ye J, Xian J, et al. (2013). Upper airway anatomical changes after velopharyngeal surgery in obstructive sleep apnea patients with small tonsils. Otolaryngol Head Neck Surg.
7852 Zhang L, Mitani Y, Caulin C, et al. (2013). Detailed genome-wide SNP analysis of major salivary carcinomas localizes subtype-specific chromosome sites and oncogenes of potential clinical significance. Am J Pathol.
7853 Zhang L, Prietsch SO, Mendes AP, et al. (2013). Inhaled corticosteroids increase the risk of oropharyngeal colonization by Streptococcus pneumoniae in children with asthma. Respirology.
7854 Zhang X, Sun B, Li S, et al. (2013). Local atopy is more relevant than serum sIgE in reflecting allergy in childhood adenotonsillar hypertrophy. Pediatr Allergy Immunol.
7855 Zhao M, Yu J, Li C. (2013). Lymphoid papillary hyperplasia of the palatine tonsil: a Chinese case report. Int J Clin Exp Pathol.
7856 Zhu F, Liu Z, Hou Y, et al. (2013). Primary salivary gland-type lung cancer: clinicopathological analysis of 88 cases from China. J Thorac Oncol.
7857 Zicari AM, Rugiano A, Ragusa G, et al. (2013). The evaluation of adenoid hypertrophy and obstruction grading based on rhinomanometry after nasal decongestant test in children. Eur Rev Med Pharmacol Sci.
7858 Zong J, Liu Y, Huang Y, et al. (2013). Serum lipids alterations in adenoid hypertrophy or adenotonsillar hypertrophy children with sleep disordered breathing. Int J Pediatr Otorhinolaryngol.
7859 (2014). Codeine use in children after tonsillectomy and/or adenoidectomy. Australian Prescriber.
7860 CADTH Rapid Response Reports. (2014). Montelukast for Sleep Apnea: A Review of the Clinical Effectiveness, Cost Effectiveness, and Guidelines.
7861 Abdulatif M, Ahmed A, Mukhtar A, et al. (2014). A reply. Anaesthesia.
7862 Acar B, Acar M, Ocak E, et al. (2014). Accuracy of Internet guidance on pediatric otolaryngology procedures. Int J Pediatr Otorhinolaryngol.
7863 Acar M, Kankilic ES, Koksal AO, et al. (2014). Method of the diagnosis of adenoid hypertrophy for physicians: adenoid-nasopharynx ratio. J Craniofac Surg.
7864 Adimi P, Bakhshayesh-Karam M, Kiapour N, et al. (2014). Sleep-disordered breathing as presenting manifestation of Chiari type I malformation: a case report. Tanaffos.
7865 Adriaenssens N, Bartholomeeusen S, Ryckebosch P, et al. (2014). Quality of antibiotic prescription during office hours and out-of-hours in Flemish primary care, using European quality indicators. Eur J Gen Pract.
7866 Agarwal R. (2014). Use of oral opioids during, after tonsillectomy re-evaluated. AAP News.
7867 Ahmed AO, Aliyu I, Kolo ES. (2014). Indications for tonsillectomy and adenoidectomy: our experience. Niger J Clin Pract.
7868 Ahn AK, Honeybrook A, Jordan LC, et al. (2014). Stroke after adenotonsillectomy in patients with undiagnosed moyamoya syndrome. JAMA Otolaryngol Head Neck Surg.
7869 Akcay A, Tamay Z, Ergin A, et al. (2014). Prevalence and risk factors of atopic eczema in Turkish adolescents. Pediatr Dermatol.
7870 Akcay A, Tamay Z, Hocaoglu AB, et al. (2014). Risk factors affecting asthma prevalence in adolescents living in Istanbul, Turkey. Allergol Immunopathol (Madr).
7871 Akhtar N, Iqbal M. (2014). Comparison of two different doses of nalbuphine for postoperative tonsillectomy pain in children. Pakistan Journal of Medical and Health Sciences.
7872 Aksoy EA, Serin GM, Polat S, et al. (2014). Comparison of postoperative bleeding between submucosal uvulopalatopharyngoplasty and tonsillectomy. Journal of Research in Medical Sciences.
7873 Al Dhafeeri HO, Kavarodi A, Al Shaikh K, et al. (2014). Recurrent epistaxis caused by an intranasal supernumerary tooth in a young adult. American Journal of Case Reports.
7874 Al-Abri R, Al Okbi MH, Al Bassam W, et al. (2014). Bilateral pulsating pharynx with abnormal internal carotid artery. International Journal of Pediatric Otorhinolaryngology Extra.
7875 Alexopoulos EI, Bizakis J, Gourgoulianis K, et al. (2014). Atopy does not affect the frequency of adenotonsillar hypertrophy and sleep apnoea in children who snore. Acta Paediatr.
7876 Alexopoulos EI, Charitos G, Malakasioti G, et al. (2014). Parental history of adenotonsillectomy is associated with obstructive sleep apnea severity in children with snoring. J Pediatr.
7877 Alexopoulos EI, Malakasioti G, Varlami V, et al. (2014). Nocturnal enuresis is associated with moderate-to-severe obstructive sleep apnea in children with snoring. Pediatr Res.
7878 Alkatan HM, Al-Harkan DH, Al-Mutlaq M, et al. (2014). Epithelial lacrimal gland tumors: A comprehensive clinicopathologic review of 26 lesions with radiologic correlation. Saudi J Ophthalmol.
7879 Allazzam SM, Alaki SM, El Meligy OA. (2014). Molar incisor hypomineralization, prevalence, and etiology. Int J Dent.
7880 Almuhayawi SM, Bakhsh ZA, Almuhayawi MS. (2014). Quality of life assessment using the World Health Organization quality questionnaire pre- and post- otolaryngological surgery among patients in western Saudi Arabia. Saudi Med J.
7881 Alonso-Alvarez ML, Cordero-Guevara JA, Teran-Santos J, et al. (2014). Obstructive sleep apnea in obese community-dwelling children: the NANOS study. Sleep.
7882 Al-Shehri AMS. (2014). Incidence and potential risk factors of post-tonsillectomy hemorrhage. Bahrain Medical Bulletin.
7883 Altermatt FR, Elgueta MF, Auad H, et al. (2014). Use of intravenous lidocaine in the prevention of postoperative vomiting after elective tonsillectomy in children. European journal of anaesthesiology.
7884 Altundag A, Salihoglu M, Cayonu M, et al. (2014). Clinical assessment of olfactory functions in children who underwent adenotonsillectomy during pre- and post-operative period. Int J Pediatr Otorhinolaryngol.
7885 Amit M, Binenbaum Y, Sharma K, et al. (2014). Analysis of failure in patients with adenoid cystic carcinoma of the head and neck. An international collaborative study. Head Neck.
7886 An J, Park S, Sung SH, et al. (2014). Unusual expression of thyroid transcription factor 1 and napsin A in metastatic adenoid cystic carcinoma of extrapulmonary origin in the lung. Am J Clin Pathol.
7887 Anand V, Sarin V, Singh B. (2014). Changing Trends in Adenoidectomy. Indian J Otolaryngol Head Neck Surg.
7888 Andersen IM, Tengesdal G, Lie BA, et al. (2014). Effects of Coffee Consumption, Smoking, and Hormones on Risk for Primary Sclerosing Cholangitis. Clinical gastroenterology and hepatology.
7889 Anderson ME, Buchwald ZS, Ko J, et al. (2014). Patients with pediatric obstructive sleep apnea show altered T-cell populations with a dominant TH17 profile. Otolaryngol Head Neck Surg.
7890 Anna Theresa Weber S, Pierri Carvalho R, Ridley G, et al. (2014). A systematic review and meta-analysis of cohort studies of echocardiographic findings in OSA children after adenotonsilectomy. Int J Pediatr Otorhinolaryngol.
7891 (2014). 33rd Symposium of the German Society for Magnesium-Research. Trace Elements and Electrolytes.
7892 Antos-Bielska M, Lau-Dworak M, Olszewska-Sosinska O, et al. (2014). Utility of antimicrobial susceptibility testing of multiple Haemophilus influenzae isolates from throat swabs of children with adenoid hypertrophy. Diagn Microbiol Infect Dis.
7893 Anu Priyadharshini S, Subhashree AR, Ganapathy H. (2014). Actinomycosis of tonsils - incidental or pathological? - A case report. International Journal of Pharma and Bio Sciences.
7894 Anuntaseree W, Sangsupawanich P, Mo-suwan L, et al. (2014). Prospective cohort study on change in weight status and occurrence of habitual snoring in children. Clin Otolaryngol.
7895 Arakelyan A, Fitzgerald W, Grivel JC, et al. (2014). Histocultures (tissue explants) in human retrovirology. Methods Mol Biol.
7896 Asano T, Kuwabara K, Mishina-Ikegami K, et al. (2014). Hydrocephalus with spontaneous regression in a 14-year-old girl. J Nippon Med Sch.
7897 Askar SM, Abou-Elsaad TS. (2014). A speech nasoendoscopy-based surgeon's decision for correction of velopharyngeal insufficiency following adenotonsillectomy. Eur Arch Otorhinolaryngol.
7898 Askar SM, Quriba AS. (2014). Powered instrumentation for transnasal endoscopic partial adenoidectomy in children with submucosal cleft palate. Int J Pediatr Otorhinolaryngol.
7899 Ata N, Ovet G, Alatas N. (2014). Effectiveness of radiofrequency cryptolysis for the treatment of halitosis due to caseums. Am J Otolaryngol.
7900 Atalay F, Koc EA, Yildiz S. (2014). A rare presentation of langerhans cell histiocytosis tonsil infiltration: review of the literature: atypical presentation of langerhans cell histiocytosis. Indian J Hematol Blood Transfus.
7901 Aydin E, Aydogan F, Tastan E, et al. (2014). Does helicobacter pylori have a role in the etiology of adenoid hypertrophy?. Indian J Otolaryngol Head Neck Surg.
7902 Babakurban ST, Erbek SS, Terzi YK, et al. (2014). Fractalkine receptor polymorphism and chronic tonsillitis. Eur Arch Otorhinolaryngol.
7903 Bagcchi S. (2014). Adenotonsillectomy improves asthma outcomes in children. The Lancet.
7904 Baguley KE, Cheng AT, Castro C, et al. (2014). Is day stay adenotonsillectomy safe in children with mild to moderate obstructive sleep apnoea? A retrospective review of 100 patients. Int J Pediatr Otorhinolaryngol.
7905 Bakkal BH, Ugur MB, Bahadir B. (2014). Bilateral synchronous squamous cell tonsil carcinoma treated with chemoradiotherapy. J Pak Med Assoc.
7906 Balci YI, Gozkeser E, Polat A, et al. (2014). Perioperative management of tonsilloadenoidectomy and circumcision of a patient with Bernard-Soulier syndrome: case report. Blood Coagul Fibrinolysis.
7907 Baldi I, Gulati A, Lorenzoni G, et al. (2014). Public health implications of obstructive sleep apnea burden. Indian J Pediatr.
7908 Bamgbose BO, Ruprecht A, Hellstein J, et al. (2014). The prevalence of tonsilloliths and other soft tissue calcifications in patients attending oral and maxillofacial radiology clinic of the university of iowa. ISRN Dentistry.
7909 Banerjee D, Wang JC, Demke JC. (2014). Novel use of tissue expander for dilation of oropharyngeal stenosis. Int J Pediatr Otorhinolaryngol.
7910 Banuchi V, Cohen JC, Kacker A. (2014). Safety of concurrent nasal and oropharyngeal surgery for obstructive sleep apnea. Ann Otol Rhinol Laryngol.
7911 Barakate M, Havas T. (2014). Surgical management of paediatric chronic rhinosinusitis: review of 10 years' experience. J Laryngol Otol.
7912 Barraclough J. (2014). The role of tonsillectomy for recurrent sore throats in children: a qualitative study. Int J Pediatr Otorhinolaryngol.
7913 Barraclough J, Anari S. (2014). Tonsillectomy for recurrent sore throats in children: indications, outcomes, and efficacy. Otolaryngol Head Neck Surg.
7914 Battaglia P, Turri-Zanoni M, Dallan I, et al. (2014). Endoscopic endonasal transpterygoid transmaxillary approach to the infratemporal and upper parapharyngeal tumors. Otolaryngol Head Neck Surg.
7915 Baugh RF. (2014). Observation following tonsillectomy may be inadequate due to silent death. Otolaryngol Head Neck Surg.
7916 Becker C, Ridder GJ, Pfeiffer J. (2014). The clinical impact of aberrant internal carotid arteries in children. Int J Pediatr Otorhinolaryngol.
7917 Bedwell JR, Pierce M, Levy M, et al. (2014). Ibuprofen with acetaminophen for postoperative pain control following tonsillectomy does not increase emergency department utilization. Otolaryngol Head Neck Surg.
7918 Bell D, Hanna EY, Miele L, et al. (2014). Expression and significance of notch signaling pathway in salivary adenoid cystic carcinoma. Ann Diagn Pathol.
7919 Bellis JR, Pirmohamed M, Nunn AJ, et al. (2014). Dexamethasone and haemorrhage risk in paediatric tonsillectomy: a systematic review and meta-analysis. Br J Anaesth.
7920 Beltran-Beck B, Romero B, Boadella M, et al. (2014). Tonsils of the soft palate do not mediate the response of pigs to oral vaccination with heat-inactivated Mycobacterium bovis. Clin Vaccine Immunol.
7921 Belyea J, Chang Y, Rigby MH, et al. (2014). Post-tonsillectomy complications in children less than three years of age: a case-control study. Int J Pediatr Otorhinolaryngol.
7922 Benini F, Barbi E. (2014). Doing without codeine: why and what are the alternatives?. Ital J Pediatr.
7923 Bent S, Hendren RL, Zandi T, et al. (2014). Internet-based, randomized, controlled trial of omega-3 fatty acids for hyperactivity in autism. Journal of the American Academy of Child and Adolescent Psychiatry.
7924 Berkiten G, Kumral TL, Cakir O, et al. (2014). Effectiveness of azelastine nasal spray in the treatment of adenoidal hyper-trophy in children. Hippokratia.
7925 Berkiten G, Kumral TL, Yildirim G, et al. (2014). Eight years of clinical findings and biopsy results of nasopharyngeal pathologies in 1647 adult patients: a retrospective study. B-ENT.
7926 Berta E, Atallah I, Reyt E, et al. (2014). The role of tonsillectomy in the initial diagnostic work-up of head and neck squamous cell carcinoma of unknown primary. Eur Ann Otorhinolaryngol Head Neck Dis.
7927 Berthet S, Crevier L, Deslandres C. (2014). Abnormal movements associated with oropharyngeal dysfunction in a child with Chiari I malformation. BMC Pediatr.
7928 Bertossi D, Albanese M, Chiarini L, et al. (2014). Eagle syndrome surgical treatment with piezosurgery. J Craniofac Surg.
7929 Bhalerao PM, Khedkar SM, Patil VH, et al. (2014). An adult non-obese male, a case of obstructive sleep apnoea posted for tonsillectomy and septoplasty - Challenges faced. Indian Journal of Anaesthesia.
7930 Bhasin N, Parker RI. (2014). Diagnostic outcome of preoperative coagulation testing in children. Pediatr Hematol Oncol.
7931 Bhattacharjee R, Choi BH, Gozal D, et al. (2014). Association of adenotonsillectomy with asthma outcomes in children: a longitudinal database analysis. PLoS Med.
7932 Bhattacharyya N, Kepnes LJ. (2014). Revisits and postoperative hemorrhage after adult tonsillectomy. Laryngoscope.
7933 Bhushan B, Sheldon S, Wang E, et al. (2014). Clinical indicators that predict the presence of moderate to severe obstructive sleep apnea after adenotonsillectomy in children. Am J Otolaryngol.
7934 Bielicka A, Zielnik-Jurkiewicz B, Podsiadly E, et al. (2014). Chlamydia pneumoniae and typical bacteria occurrence in adenoid in children qualified for adenoidectomy. Int J Pediatr Otorhinolaryngol.
7935 Biesiada J, Chidambaran V, Wagner M, et al. (2014). Genetic risk signatures of opioid-induced respiratory depression following pediatric tonsillectomy. Pharmacogenomics.
7936 Biggs TC, Bird JH, Frampton SJ, et al. (2014). C-reactive protein and coagulation studies in secondary post-tonsillectomy haemorrhage--need for routine testing? Our experience in 93 patients. Clin Otolaryngol.
7937 Biill Primo OV, Lourenco EA, Passos SD. (2014). Detection of respiratory viruses in nasopharyngeal swab and adenoid tissue from children submitted to adenoidectomy: pre- and postoperative analysis. Int Arch Otorhinolaryngol.
7938 Bird JH, Biggs TC, King EV. (2014). Controversies in the management of acute tonsillitis: an evidence-based review. Clin Otolaryngol.
7939 Bizaki A, Kaariainen J, Harju T, et al. (2014). Facial subcutaneous emphysema after tonsillectomy. Head Face Med.
7940 Blackburn L, Ottaway K, Anderson BJ. (2014). The impact of clonidine on sedation after adenotonsillectomy: a prospective audit. Paediatr Anaesth.
7941 Blecher G, Wainbergas N, McGlynn M, et al. (2014). Rapidly evolving narcolepsy-like syndrome coinciding with severe OSA following pharyngoplasty in Prader-Willi syndrome. Respirol Case Rep.
7942 Bolling CF. (2014). 50 years ago in the Journal of Pediatrics: the influence of tonsillectomy on growth and caloric intake. J Pediatr.
7943 Boonacker CW, Rovers MM, Browning GG, et al. (2014). Adenoidectomy with or without grommets for children with otitis media: an individual patient data meta-analysis. Health Technol Assess.
7944 Borodiciene J, Gudaityte J, Gerulyte I, et al. (2014). Randomized controlled study of the acetaminophen effectiveness after adenotonsillectomy or tonsillectomy in children. European journal of anaesthesiology.
7945 Bottcher-Haberzeth S, Biedermann T, Klar AS, et al. (2014). Tissue engineering of skin: human tonsil-derived mesenchymal cells can function as dermal fibroblasts. Pediatr Surg Int.
7946 Boudewyns A, Verhulst S, Maris M, et al. (2014). Drug-induced sedation endoscopy in pediatric obstructive sleep apnea syndrome. Sleep Med.
7947 Boyle KL, Rosenbaum CD. (2014). Oxycodone overdose in the pediatric population: case files of the University of Massachusetts Medical Toxicology Fellowship. J Med Toxicol.
7948 Bozkus F, Sarikaya S, Kocaturk O, et al. (2014). Evaluation of preoperative and postoperative S-100B levels in children with chronic adenotonsillar hypertrophy: preliminary results. Eur Rev Med Pharmacol Sci.
7949 Brown KA, Brouillette RT. (2014). The elephant in the room: lethal apnea at home after adenotonsillectomy. Anesth Analg.
7950 Brown TC. (2014). From kitchen table to operating room. Paediatr Anaesth.
7951 Buddiga V, Gupta VB, Aravind K, et al. (2014). The comparison of oral health problems with other health problems in urban school children of 10-14 years: a group screening. J Int Oral Health.
7952 Bulut F, Meric F, Yorgancilar E, et al. (2014). Effects of N-acetyl-cysteine and acetylsalicylic acid on the tonsil bacterial biofilm tissues by light and electron microscopy. Eur Rev Med Pharmacol Sci.
7953 Buntzel J, Buntzel H, Micke O, et al. (2014). Magnesium and the postoperative pain after tonsillectomy. Trace Elements and Electrolytes.
7954 Buntzel J, Kisters K, Mucke R, et al. (2014). Magnesium in head and neck cancer - Update 2013. Trace Elements and Electrolytes.
7955 Burton MJ, Glasziou PP, Chong LY, et al. (2014). Tonsillectomy or adenotonsillectomy versus non-surgical treatment for chronic/recurrent acute tonsillitis. Cochrane Database Syst Rev.
7956 Burton MJ, Pollard AJ, Ramsden JD, et al. (2014). Tonsillectomy for periodic fever, aphthous stomatitis, pharyngitis and cervical adenitis syndrome (PFAPA). Cochrane Database Syst Rev.
7957 Byrd JK, Smith KJ, de Almeida JR, et al. (2014). Transoral Robotic Surgery and the Unknown Primary: A Cost-Effectiveness Analysis. Otolaryngol Head Neck Surg.
7958 Caixeta AC, Andrade I, Bahia Junqueira Pereira T, et al. (2014). Authors' response. Am J Orthod Dentofacial Orthop.
7959 Calvino O, Llor C, Gomez F, et al. (2014). Association between C-reactive protein rapid test and group A streptococcus infection in acute pharyngitis. J Am Board Fam Med.
7960 Canetta PA, Kiryluk K, Appel GB. (2014). Glomerular diseases: emerging tests and therapies for IgA nephropathy. Clin J Am Soc Nephrol.
7961 Canning DA. (2014). Re: enuretic children with obstructive sleep apnea syndrome: should they see otolaryngology first?. J Urol.
7962 Carron JD. (2014). Avoiding narcotic analgesics in young children. J Miss State Med Assoc.
7963 Carter A, Warner E, Roberton A, et al. (2014). Tonsillectomy discharge information - An improvement in both patient safety and satisfaction. BMJ Qual Improv Rep.
7964 Caterson EJ, Tsai DM, Cauley R, et al. (2014). Transillumination of the occult submucous cleft palate. J Craniofac Surg.
7965 Cayonu M, Altundag A. (2014). An extremely rare complication of adenoidectomy; Massive bleeding 7 days after the operation. International Journal of Pediatric Otorhinolaryngology Extra.
7966 Cetin M, Yilmaz M, Ozen S, et al. (2014). Assessment of pulmonary artery pressure and right ventricular function in children with adenotonsillar hypertrophy using different parameters. Int J Pediatr Otorhinolaryngol.
7967 Chan DK, Liming BJ, Horn DL, et al. (2014). A new scoring system for upper airway pediatric sleep endoscopy. JAMA Otolaryngol Head Neck Surg.
7968 Chang JJ, Buchanan P, Geremakis C, et al. (2014). Cost analysis of tonsillectomy in children using medicaid data. J Pediatr.
7969 Chavez-Delgado ME, Kishi-Sutto CV, Albores de la-Riva XN, et al. (2014). Topic usage of kaolin-impregnated gauze as a hemostatic in tonsillectomy. J Surg Res.
7970 Chellam S, Dalal KS, Toal PV. (2014). Use of filters in anaesthesia: Is it warranted?. Indian Journal of Anaesthesia.
7971 Chen MM, Roman SA, Sosa JA, et al. (2014). Safety of adult tonsillectomy: a population-level analysis of 5968 patients. JAMA Otolaryngol Head Neck Surg.
7972 Chen N, Hou Q, Cui Z, et al. (2014). Effect of otitis media with effusion and its clinical intervention on the development of mastoid in children. Acta Otolaryngol.
7973 Chen WL, Wang WJ, Huang ZQ, et al. (2014). Osteotomy in the vertical ramus outside the mandibular foramen for tumours in the parapharyngeal space. J Craniomaxillofac Surg.
7974 Chen X, Liu H, Peng Y, et al. (2014). Expression and correlation analysis of IL-4, IFN-gamma and FcalphaRI in tonsillar mononuclear cells in patients with IgA nephropathy. Cell Immunol.
7975 Chervin RD, Chung S, O'Brien LM, et al. (2014). Periodic leg movements during sleep in children scheduled for adenotonsillectomy: frequency, persistence, and impact. Sleep Med.
7976 Chervin RD, Garetz SL, Ruzicka DL, et al. (2014). Do respiratory cycle-related EEG changes or arousals from sleep predict neurobehavioral deficits and response to adenotonsillectomy in children?. J Clin Sleep Med.
7977 Chi TH, Tsao YH, Yuan CH. (2014). Influences of patient age on deep neck infection: clinical etiology and treatment outcome. Otolaryngol Head Neck Surg.
7978 Chiaraviglio M, Groote F, Du Maine C, et al. (2014). Does the anaesthetic technique influence the incidence of post-operative respiratory complications in children with recent URTI?. European journal of anaesthesiology.
7979 Cho DY, Sinha SR, Gardner JM, et al. (2014). Effect of intratonsillar injection of steroids on the palatine tonsils of rabbits. Laryngoscope.
7980 Cho HK, Kim KW, Jeong YM, et al. (2014). Efficacy of ketamine in improving pain after tonsillectomy in children: meta-analysis. PLoS One.
7981 Cho KS, Koo SK, Lee JK, et al. (2014). Limited palatal muscle resection with tonsillectomy: a novel palatopharyngoplasty technique for obstructive sleep apnea. Auris Nasus Larynx.
7982 Choi HG, Hah JH, Jung YH, et al. (2014). Influences of demographic changes and medical insurance status on tonsillectomy and adenoidectomy rates in Korea. Eur Arch Otorhinolaryngol.
7983 Chotai S, Medhkour A. (2014). Surgical outcomes after posterior fossa decompression with and without duraplasty in Chiari malformation-I. Clin Neurol Neurosurg.
7984 Chou CH, Kang KT, Weng WC, et al. (2014). Central sleep apnea in obese children with sleep-disordered breathing. Int J Obes (Lond).
7985 Christensen AM, Thomsen MK, Ovesen T, et al. (2014). Are procalcitonin or other infection markers useful in the detection of group A streptococcal acute tonsillitis?. Scand J Infect Dis.
7986 Chung JH, Lee YC, Shin SY, et al. (2014). Risk factors for recurrence of peritonsillar abscess. J Laryngol Otol.
7987 Ciftci Z, Develioglu O, Arbak S, et al. (2014). A new horizon in the treatment of biofilm-associated tonsillitis. Ther Adv Respir Dis.
7988 Cincin A, Sakalli E, Bakirci EM, et al. (2014). Relationship between obstructive sleep apnea-specific symptoms and cardiac function before and after adenotonsillectomy in children with adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
7989 Connell T. (2014). Dental arch dimensional changes. Am J Orthod Dentofacial Orthop.
7990 Conrad DE, Levi JR, Theroux ZA, et al. (2014). Risk factors associated with postoperative tympanostomy tube obstruction. JAMA Otolaryngol Head Neck Surg.
7991 Constant I, Ayari Khalfallah S, Brunaud A, et al. (2014). How to replace codeine after tonsillectomy in children under 12 years of age? Guidelines of the French Oto-Rhino-Laryngology--Head and Neck Surgery Society (SFORL). Eur Ann Otorhinolaryngol Head Neck Dis.
7992 Cook-Sather SD, Li J, Goebel TK, et al. (2014). TAOK3, a novel genome-wide association study locus associated with morphine requirement and postoperative pain in a retrospective pediatric day surgery population. Pain.
7993 Costi D, Cyna AM, Ahmed S, et al. (2014). Effects of sevoflurane versus other general anaesthesia on emergence agitation in children. Cochrane Database Syst Rev.
7994 Cote CJ, Posner KL, Domino KB. (2014). Death or neurologic injury after tonsillectomy in children with a focus on obstructive sleep apnea: houston, we have a problem!. Anesth Analg.
7995 Coupland A, Sewpaul A, Darne A, et al. (2014). Adenoid cystic carcinoma of the submandibular gland, locoregional recurrence, and a solitary liver metastasis more than 30 years since primary diagnosis. Case Rep Surg.
7996 Coussens S, Baumert M, Kohler M, et al. (2014). Movement distribution: a new measure of sleep fragmentation in children with upper airway obstruction. Sleep.
7997 Coyle P, Marzouk SD, Gerolympou M, et al. (2014). Hot tonsillectomy for paediatric obstructive sleep apnoea. BMJ Case Rep.
7998 Crockett DJ, Ahmed SR, Sowder DR, et al. (2014). Velopharyngeal dysfunction in children with Prader-Willi syndrome after adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
7999 Czechowicz JA, Chang KW. (2014). Analysis of Growth Curves in Children After Adenotonsillectomy. JAMA Otolaryngol Head Neck Surg.
8000 Dai ZY, Huang DY, Zhou CY. (2014). Effects of partial tonsillectomy on the immune functions of children with obstructive sleep apnea-hypopnea syndrome at early stage. Genet Mol Res.
8001 Dalgic A, Karakoc O, Aydin U, et al. (2014). Minor salivary gland neoplasms. J Craniofac Surg.
8002 Darlong V, Pandey R, Garg R, et al. (2014). Perioperative management of a patient of Rubinstein-Taybi syndrome with ovarian cyst for laparotomy. J Anaesthesiol Clin Pharmacol.
8003 Dave MH, Gerber A, Bailey M, et al. (2014). Prevalence and characteristics of tracheal cobblestoning in children. Pediatr Pulmonol.
8004 de Azevedo CB, Carenzi LR, de Queiroz DL, et al. (2014). Clinical utility of PPPM and FPS-R to quantify post-tonsillectomy pain in children. Int J Pediatr Otorhinolaryngol.
8005 De Pieri C, Vuch J, Bianco AM, et al. (2014). Genetic profiling of auto-inflammatory disorders in patients with periodic fever: A prospective study. Pediatric Rheumatology.
8006 Deak L, Saxton D, Johnston K, et al. (2014). Comparison of Postoperative Pain in Children with Two Intracapsular Tonsillotomy Techniques and a Standard Tonsillectomy: Microdebrider and radiofrequency tonsillotomies versus standard tonsillectomies. Sultan Qaboos Univ Med J.
8007 del-Rio Camacho G, Martinez Gonzalez M, Sanabria Brossart J, et al. (2014). Post-operative complications following adenotonsillectomy in children with severe sleep apnea-hypopnea syndrome. Do they need to be admitted to an intensive care unit? Acta Otorrinolaringol Esp.
8008 Develioglu ON, Ipek HD, Bahar H, et al. (2014). Bacteriological evaluation of tonsillar microbial flora according to age and tonsillar size in recurrent tonsillitis. Eur Arch Otorhinolaryngol.
8009 Di Capua M, Livia Burzo M, Di Palo M, et al. (2014). Predicting early and delayed bleedings in children who undergo adeno-tonsillectomy surgery. Is it really possible? Haemophilia.
8010 Di Pierro F, Colombo M, Zanvit A, et al. (2014). Use of Streptococcus salivarius K12 in the prevention of streptococcal and viral pharyngotonsillitis in children. Drug Healthc Patient Saf.
8011 Diamond F. (2014). Two tonsillectomy studies reach opposite conclusions. Manag Care.
8012 Donnelly JP, Baddley JW, Wang HE. (2014). Antibiotic utilization for acute respiratory tract infections in U.S. emergency departments. Antimicrob Agents Chemother.
8013 Dorkham MC, Chalkiadis GA, von Ungern Sternberg BS, et al. (2014). Effective postoperative pain management in children after ambulatory surgery, with a focus on tonsillectomy: barriers and possible solutions. Paediatr Anaesth.
8014 Dostal M, Prucha M, Rychlikova E, et al. (2014). Differences between the spectra of respiratory illnesses in children living in urban and rural environments. Cent Eur J Public Health.
8015 Douglas DD, Fasunla AJ, Fayemiwo SA, et al. (2014). Comparative study of aerobic pathogenic bacteria isolates from patients with recurrent tonsillitis. West Afr J Med.
8016 Douglas JA, Senior AJ, Scott A. (2014). The Telford tonsillectomy tie trainer: an AirSim model modification. Ann R Coll Surg Engl.
8017 Duarte VM, Liu YF, Shapiro NL. (2014). Coblation total tonsillectomy and adenoidectomy versus coblation partial intracapsular tonsillectomy and adenoidectomy in children. Laryngoscope.
8018 Edouard S, Michel-Lepage A, Raoult D. (2014). Does it make sense to detect Streptococcus pyogenes during tonsillitis in Europe to prevent acute rheumatic fever?. Clin Microbiol Infect.
8019 Eftekharian MM, Mousavi M, Hormoz MB, et al. (2014). Multiple sclerosis and immunological-related risk factors: results from a case-control study. Hum Antibodies.
8020 Elbistanli MS, Elbistanli S, Kumral TL, et al. (2014). Evaluation of patients with post-tonsillectomy bleeding in a second-degree state hospital our patients with post-tonsillectomy bleeding. Haseki Tip Bulteni.
8021 Elboga U, Kervancioglu S, Sahin E, et al. (2014). Utility of F-18 fluorodeoxyglucose positron emission tomography/computed in carcinoma of unknown primary. Int J Clin Exp Pathol.
8022 Elnashar I, El-Anwar M, Raafat A, et al. (2014). Insulin-like growth factor alpha changes after tonsillectomy for obstructive and nonobstructive causes. The Egyptian Journal of Otolaryngology.
8023 Elnashar I, El-Anwar MW, Basha WM, et al. (2014). Objective assessment of endoscopy assisted adenoidectomy. Int J Pediatr Otorhinolaryngol.
8024 Elsobky S, Ahmad N, Qureshi M, et al. (2014). Paediatric day case tonsillectomy: a safe, feasible and an economical way to treat patients--Yorkhill experience. Scott Med J.
8025 Erdem H, Ozturk-Engin D, Yesilyurt M, et al. (2014). Evaluation of tularaemia courses: a multicentre study from Turkey. Clin Microbiol Infect.
8026 Erdogan BA, Aydin S, Paksoy M, et al. (2014). Efficacy of preincisional levobupivacaine for adult tonsillectomy patients. B-ENT.
8027 Eren Gok S, Kocagul Celikbas A, Baykam N, et al. (2014). Evaluation of tularemia cases focusing on the oculoglandular form. J Infect Dev Ctries.
8028 Erkan AN. (2014). The use of laryngeal mask airway in tonsillectomies. Braz J Anesthesiol.
8029 Farmawy MS, Rashad MM. (2014). Preemptive analgesia by peritonsillar ketamine versus ropivacaine for post-tonsillectomy pain in children. Egyptian Journal of Anaesthesia.
8030 Fayoux P, Wood C. (2014). Non-pharmacological treatment of post-tonsillectomy pain. Eur Ann Otorhinolaryngol Head Neck Dis.
8031 Ferary M, Biet A, Strunski V, et al. (2014). Impact of the mode of hospitalisation on the postoperative complication rate after dissection tonsillectomy in children. Eur Ann Otorhinolaryngol Head Neck Dis.
8032 Ference EH, Schroeder JW, Qureshi H, et al. (2014). Current utilization of balloon dilation versus endoscopic techniques in pediatric sinus surgery. Otolaryngol Head Neck Surg.
8033 Feres MF, Hermann JS, Sallum AC, et al. (2014). Radiographic adenoid evaluation: proposal of an objective parameter. Radiol Bras.
8034 Feres MF, Hermann JS, Sallum AC, et al. (2014). Radiographic adenoid evaluation--suggestion of referral parameters. J Pediatr (Rio J).
8035 Ferguson M, Aydin M, Mickel J. (2014). Halitosis and the tonsils: a review of management. Otolaryngol Head Neck Surg.
8036 Fernandez AM, Cronin J, Greenberg RS, et al. (2014). Pediatric preoperative blood ordering: when is a type and screen or crossmatch really needed?. Paediatr Anaesth.
8037 Fida AR, Sendi KS. (2014). Postoperative pain scores in thermal welding and conventional tonsillectomy techniques: A randomized controlled study. Otolaryngology - Head and Neck Surgery (United States).
8038 Fischer M, Horn IS, Quante M, et al. (2014). Respiratory complications after diode-laser-assisted tonsillotomy. Eur Arch Otorhinolaryngol.
8039 Fleck RJ, Amin RS, Shott SR, et al. (2014). MRI sleep studies: use of positive airway pressure support in patients with severe obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
8040 Folayan MO, Ozeigbe EO, Onyejaeka N, et al. (2014). Non-third molar related pericoronitis in a sub-urban Nigeria population of children. Niger J Clin Pract.
8041 Follmar A, Dentino K, Abramowicz S, et al. (2014). Prevalence of sleep-disordered breathing in patients with Beckwith-Wiedemann syndrome. J Craniofac Surg.
8042 Font-Ribera L, Villanueva CM, Gracia-Lavedan E, et al. (2014). Indoor swimming pool attendance and respiratory and dermal health in schoolchildren--HITEA Catalonia. Respir Med.
8043 Fox R, Varadharajan K, Patel B, et al. (2014). Blood, sweat and tears: androgenic-anabolic steroid misuse and recurrent primary post-tonsillectomy haemorrhage. BMJ Case Rep.
8044 Frati F, Scurati S, Dell'Albani I, et al. (2014). Evaluation of house dust mite allergy in real life: patients' characteristics and satisfaction with treatment. Eur Ann Allergy Clin Immunol.
8045 Fregene T. (2014). Magnesium sulphate and postoperative agitation in children: an analgesic effect?. Anaesthesia.
8046 Ganesan P, Piha-Paul S, Naing A, et al. (2014). Phase I clinical trial of lenalidomide in combination with sorafenib in patients with advanced cancer. Invest New Drugs.
8047 Garca MF, Demir H, Turan M, et al. (2014). Assessment of adenosine deaminase (ADA) activity and oxidative stress in patients with chronic tonsillitis. Eur Arch Otorhinolaryngol.
8048 Gaudreau PA, Gessler E. (2014). Intracapsular tonsillectomy for keratosis pharyngeous: Postoperative recovery and surgical efficacy. Otolaryngology - Head and Neck Surgery (United States).
8049 Gayar OH, Ruterbusch JJ, Elshaikh M, et al. (2014). Oropharyngeal carcinoma in young adults: an alarming national trend. Otolaryngol Head Neck Surg.
8050 Geissler K, Bohne S, Siggel R, et al. (2014). Preoperative serum pattern analysis to predict the outcome of tonsillectomy in adults with chronic tonsillitis. Eur Arch Otorhinolaryngol.
8051 Gentin N, Blackburn C, Teng A. (2014). Can the use of home nocturnal oximetry assist in the prioritisation of polysomnograms?. Sleep and Biological Rhythms.
8052 Georgalas CC, Tolley NS, Narula PA. (2014). Tonsillitis. BMJ Clin Evid.
8053 Gharaei H, Khan TH. (2014). Is regional anesthesia safe in children? Anaesthesia. Pain and Intensive Care.
8054 Giannikas C, Pomeranz HD, Smith LP, et al. (2014). Horner syndrome after tonsillectomy: an anatomic perspective. Pediatr Neurol.
8055 Giesecke C, Frolich D, Reiter K, et al. (2014). Tissue distribution and dependence of responsiveness of human antigen-specific memory B cells. J Immunol.
8056 Gikas A. (2014). Pilonidal sinus disease in young age is associated with diabetes later in life. J Diabetes.
8057 Gimpel C, Heinrich A, Fehrenbach H, et al. (2014). Increased incidence of adenoidectomy and tonsillectomy in children with renal transplantation. Pediatr Nephrol.
8058 Girbal IC, Goncalves C, Nunes T, et al. (2014). Non-invasive ventilation in complex obstructive sleep apnea--a 15-year experience of a pediatric tertiary center. Rev Port Pneumol.
8059 Gohilot A, Pradhan T, Keluskar KM. (2014). Cephalometric evaluation of adenoids, upper airway, maxilla, velum length, need ratio for determining velopharyngeal incompetency in subjects with unilateral cleft lip and palate. J Indian Soc Pedod Prev Dent.
8060 Goldfarb J, Gupta V, Sampson H, et al. (2014). Resource development in otolaryngology-head and neck surgery: an analysis on patient education resource development. J Otolaryngol Head Neck Surg.
8061 Gonuldas B, Yilmaz T, Sivri HS, et al. (2014). Mucopolysaccharidosis: Otolaryngologic findings, obstructive sleep apnea and accumulation of glucosaminoglycans in lymphatic tissue of the upper airway. Int J Pediatr Otorhinolaryngol.
8062 Gonzalez Mangado N, Troncoso Acevedo MF, Gomez Garcia T. (2014). Home ventilation therapy in obstructive sleep apnea-hypopnea syndrome. Arch Bronconeumol.
8063 Gozal D, Kim J, Bhattacharjee R, et al. (2014). Substance P and neurokinin 1 receptors as potential therapeutic targets in children with OSA. Chest.
8064 Gozel MG, Engin A, Altuntas EE, et al. (2014). Evaluation of clinical and laboratory findings of pediatric and adult patients with oropharyngeal tularemia in Turkey: a combination of surgical drainage and antibiotic therapy increases treatment success. Jpn J Infect Dis.
8065 Granell J, Mendez-Benegassi I, Millas T, et al. (2014). Transoral Robotic Surgery: Step-by-Step Radical Tonsillectomy. Case Rep Otolaryngol.
8066 Gu X, Keyoumu Y, Long L, et al. (2014). Detection of bacterial biofilms in different types of chronic otitis media. Eur Arch Otorhinolaryngol.
8067 Gunel C, Ermisler B, Basak HS. (2014). The effect of adenoid hypertrophy on tympanometric findings in children without hearing loss. Kulak Burun Bogaz Ihtis Derg.
8068 Guntinas-Lichius O, Volk GF, Geissler K, et al. (2014). Pain after pediatric otorhinolaryngologic surgery: a prospective multi-center trial. Eur Arch Otorhinolaryngol.
8069 Guntinas-Lichius O, Volk GF, Zaslansky R, et al. (2014). The first postoperative day: prospective evaluation of pain in adult otorhinolaryngologic surgery. Clin J Pain.
8070 Gupta V, Gupta M, Matreja PS, et al. (2014). Efficacy of mometasone nasal spray in children with snoring due to adenoids. Clinical Rhinology.
8071 Guzman Molina C, Rodriguez-Belvis MV, Coroleu Bonet A, et al. (2014). Antibiotics in respiratory tract infections in hospital pediatric emergency departments. Arch Bronconeumol.
8072 Hack H. (2014). An audit of the use of an opiate sparing, multimodal analgesic regime in children with Sleep Disordered Breathing/Obstructive Sleep Apnoea undergoing adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
8073 Haddadi S, Marzban S, Karami MS, et al. (2014). Comparing the duration of the analgesic effects of intravenous and rectal acetaminophen following tonsillectomy in children. Anesth Pain Med.
8074 Hadjisymeou S, Modayil PC, Dean H, et al. (2014). Our experience. Coblation(R) intracapsular tonsillectomy (tonsillotomy) in children: a prospective study of 100 consecutive cases. Clin Otolaryngol.
8075 Hajiioannou J, Tsiouvaka S, Exarchos S, et al. (2014). Histopathologic examination of routine tonsillectomies in times of Greek austerity. Necessity or luxury? A retrospective study of 823 patients. Clin Otolaryngol.
8076 Haksever M, Ozmen S, Akduman D, et al. (2014). Topical bupivacaine compared to bupivacaine infiltration for post-tonsillectomy pain relief in children: a prospective randomized controlled clinical study. European Archives of Oto-rhino-laryngology.
8077 Hamblin JS, Sandulache VC, Alapat PM, et al. (2014). Management of obstructive sleep apnea in the indigent population: a deviation of standard of care?. Otolaryngol Head Neck Surg.
8078 Han I, Kim TK, Yoo JH, et al. (2014). Dislocation of the temporomandibular joint following general anesthesia. Korean Journal of Anesthesiology.
8079 Hannam JA, Anderson BJ, Mahadevan M, et al. (2014). Postoperative analgesia using diclofenac and acetaminophen in children. Paediatr Anaesth.
8080 Hasanzadeh Kiabi F, Soleimani A, Habibi MR, et al. (2014). Can Honey be Used as an Adjunct in Treatment of Post Tonsillectomy Pain?. Anesth Pain Med.
8081 Hasegawa J, Yamada K, Kaga Y, et al. (2014). A case of immunoglobulin A nephropathy treated successfully with tonsillectomy and steroid pulse therapy 20 years after onset. CEN Case Reports.
8082 Hasegawa M, Sasaki H, Takahashi K, et al. (2014). Recurrent IgA nephropathy complicated with Crohn's disease after renal transplantation. CEN Case Reports.
8083 Hashmi AM, Khawaja IS. (2014). Awakening to the dangers of obstructive sleep apnea. Current Psychiatry.
8084 Havenith SH, Remmerswaal EB, Idu MM, et al. (2014). CXCR5+CD4+ follicular helper T cells accumulate in resting human lymph nodes and have superior B cell helper activity. Int Immunol.
8085 He L, Peng Y, Liu H, et al. (2014). Th1/Th2 polarization in tonsillar lymphocyte form patients with IgA nephropathy. Ren Fail.
8086 He Y, Ong KC, Gao Z, et al. (2014). Tonsillar crypt epithelium is an important extra-central nervous system site for viral replication in EV71 encephalomyelitis. Am J Pathol.
8087 Helgadottir HL, Wilson ME. (2014). A randomized controlled trial of the effectiveness of educating parents about distraction to decrease postoperative pain in children at home after tonsillectomy. Pain Manag Nurs.
8088 Helvaci MR, Acipayam C, Aydogan A, et al. (2014). Acute chest syndrome in severity of sickle cell diseases. International Journal of Clinical and Experimental Medicine.
8089 Hembrom R, Roychaudhuri BK, Saha AK, et al. (2014). Evaluation of the validity of high serum antistreptolysin o titre only, as an indication for tonsillectomy. Indian J Otolaryngol Head Neck Surg.
8090 Hester G, Nelson K, Mahant S, et al. (2014). Methodological quality of national guidelines for pediatric inpatient conditions. J Hosp Med.
8091 Hofer M, Pillet P, Cochard MM, et al. (2014). International periodic fever, aphthous stomatitis, pharyngitis, cervical adenitis syndrome cohort: description of distinct phenotypes in 301 patients. Rheumatology (Oxford).
8092 Hoff PT, Glazer TA, Spector ME. (2014). Body mass index predicts success in patients undergoing transoral robotic surgery for obstructive sleep apnea. ORL J Otorhinolaryngol Relat Spec.
8093 Hoffmire CA, Magyar CI, Connolly HV, et al. (2014). High prevalence of sleep disorders and associated comorbidities in a community sample of children with Down syndrome. J Clin Sleep Med.
8094 Hong SD, Kim JH, Kim HY, et al. (2014). Compliance and efficacy of saline irrigation in pediatric chronic rhinosinusitis. Auris Nasus Larynx.
8095 Horiuchi F, Oka Y, Komori K, et al. (2014). Effects of adenotonsillectomy on neurocognitive function in pediatric obstructive sleep apnea syndrome. Case Rep Psychiatry.
8096 Horwood L, Brouillette RT, McGregor CD, et al. (2014). Testing for pediatric obstructive sleep apnea when health care resources are rationed. JAMA Otolaryngol Head Neck Surg.
8097 Hoshino Y, Abe Y, Endo M, et al. (2014). Five cases of tonsillectomy and steroid pulse therapy for recurrent immunoglobulin A nephropathy after kidney transplantation. CEN Case Reports.
8098 Howard D, Davis KF, Phillips E, et al. (2014). Pain management for pediatric tonsillectomy: an integrative review through the perioperative and home experience. J Spec Pediatr Nurs.
8099 Huang H, Sun W, Liang Y, et al. (2014). CD4 (+)CD 25 (+)Treg cells and IgA nephropathy patients with tonsillectomy: a clinical and pathological study. Int Urol Nephrol.
8100 Huang YS, Guilleminault C, Lee LA, et al. (2014). Treatment outcomes of adenotonsillectomy for children with obstructive sleep apnea: a prospective longitudinal study. Sleep.
8101 Hwang SH, Song JN, Jeong YM, et al. (2014). The efficacy of honey for ameliorating pain after tonsillectomy: a meta-analysis. Eur Arch Otorhinolaryngol.
8102 Ikoma R, Sakane S, Niwa K, et al. (2014). Risk factors for post-tonsillectomy hemorrhage. Auris Nasus Larynx.
8103 Immanuel SA, Pamula Y, Kohler M, et al. (2014). Heartbeat evoked potentials during sleep and daytime behavior in children with sleep-disordered breathing. Am J Respir Crit Care Med.
8104 Immanuel SA, Pamula Y, Kohler M, et al. (2014). Respiratory cycle-related electroencephalographic changes during sleep in healthy children and in children with sleep disordered breathing. Sleep.
8105 Ince I, Yoruk O, Ahiskalioglu A, et al. (2014). Does montelukast have an effect on posttonsillectomy pain control in children?. Otolaryngology - Head and Neck Surgery (United States).
8106 Iqbal H, Bhatti AB, Hussain R, et al. (2014). Ten year experience with surgery and radiation in the management of malignant major salivary gland tumors. Asian Pac J Cancer Prev.
8107 Isaacson G. (2014). Pediatric tonsillectomy: an evidence-based approach. Otolaryngol Clin North Am.
8108 Ivey J. (2014). Choosing a design. Pediatr Nurs.
8109 Iwasaki T, Yamasaki Y. (2014). Relation between maxillofacial form and respiratory disorders in children. Sleep and Biological Rhythms.
8110 J SA, Garag SS, Anchan S. (2014). Iatrogenic stenosis of anterior nares: a case report. J Clin Diagn Res.
8111 Jabbari Moghaddam Y, Seyedhejazi M, Naderpour M, et al. (2014). Is fasting duration important in post adenotonsillectomy feeding time?. Anesth Pain Med.
8112 Jagadeeswaran VU, Selvalingam E, Balamuruganvelu S, et al. (2014). A prospective study to determine the bacteriology of palatine tonsil surface and core, along with histopathological examination of tonsil. Research Journal of Pharmaceutical, Biological and Chemical Sciences.
8113 Jahanshahi J, Pazira S, Farahani F, et al. (2014). Effect of topical sucralfate vs clindamycin on posttonsillectomy pain in children aged 6 to 12 years: a triple-blind randomized clinical trial. JAMA Otolaryngol Head Neck Surg.
8114 Jartti T, Palomares O, Waris M, et al. (2014). Distinct regulation of tonsillar immune response in virus infection. Allergy.
8115 Javadi Nia S, Zarabi V, Noorbakhsh S, et al. (2014). Chlamydophila pneumoniae Infection Assessment in Children With Adenoid Hypertrophy Concomitant With Rhino Sinusitis. Jundishapur J Microbiol.
8116 Jenkins BN, Fortier MA. (2014). Developmental and cultural perspectives on children's postoperative pain management at home. Pain Management.
8117 Jeong JH, Guilleminault C, Park CS, et al. (2014). Changes in salivary cortisol levels in pediatric patients with obstructive sleep apnea syndrome after adenotonsillectomy. Sleep Med.
8118 Ji P, Liu J, Zhu H, et al. (2014). Pharmacometrics in pain management.
8119 Jiang LC, Huang SY, Zhang DS, et al. (2014). Expression of beclin 1 in primary salivary adenoid cystic carcinoma and its relation to Bcl-2 and p53 and prognosis. Braz J Med Biol Res.
8120 Jiang N, Muhammad C, Ho Y, et al. (2014). Prevalence of severe obstructive sleep apnea in pediatric adenotonsillectomy patients. Laryngoscope.
8121 Jin L, Zhang T. (2014). Deep neck infections: a retrospective study of 142 patients. B-ENT.
8122 Joaquim AF, Fernandes YB, Mathias RN, et al. (2014). Incidence of basilar invagination in patients with tonsillar herniation? A case control craniometrical study. Arq Neuropsiquiatr.
8123 John LJ, Cherian M, Sreedharan J, et al. (2014). Patterns of antimicrobial therapy in acute tonsillitis: A cross-sectional hospital-based study from UAE. An Acad Bras Cienc.
8124 Jovic TH, Saldanha F, Kuo R, et al. (2014). A true branchial fistula in the context of branchiootic syndrome: challenges of diagnosis and management. J Plast Reconstr Aesthet Surg.
8125 Junior DR. (2014). The use of laryngeal mask airway in tonsillectomies. Reply to Alper Nabi Erkan. Braz J Anesthesiol.
8126 Kajosaari L, Makitie A, Salminen P, et al. (2014). Second branchial cleft fistulae: patient characteristics and surgical outcome. Int J Pediatr Otorhinolaryngol.
8127 Kalampouka E, Moudaki A, Malakasioti G, et al. (2014). Family history of adenotonsillectomy as a risk factor for tonsillar hypertrophy and snoring in childhood. Pediatr Pulmonol.
8128 Kallunki J, Marcusson A, Ericsson E. (2014). Tonsillotomy versus tonsillectomy--a randomized trial regarding dentofacial morphology and post-operative growth in children with tonsillar hypertrophy. Eur J Orthod.
8129 Kamei D, Moriyama T, Takei T, et al. (2014). Comparison between consecutive and intermittent steroid pulse therapy combined with tonsillectomy for clinical remission of IgA nephropathy. Clin Exp Nephrol.
8130 Kaneko Y, Kojima M, Suzuki S, et al. (2014). Atypical interfollicular hyperplasia of tonsils resembling mucosa-associated lymphoid tissue lymphoma: a clinicopathological, immunohistochemical study and epstein-barr virus findings in 12 cases. J Clin Exp Hematop.
8131 Kang KT, Weng WC, Lee CH, et al. (2014). Discrepancy between Objective and Subjective Outcomes after Adenotonsillectomy in Children with Obstructive Sleep Apnea Syndrome. Otolaryngol Head Neck Surg.
8132 Kanotra SP, Davies J. (2014). Management of tonsillar lipoma: is tonsillectomy essential?. Case Rep Otolaryngol.
8133 Karakas A, Coskun O, Artuk C, et al. (2014). Oropharyngeal tularemia cases admitted to a military hospital in Ankara, Turkey. J Infect Dev Ctries.
8134 Karalok ZS, Akdag M, Turhan M, et al. (2014). Leptin and ghrelin levels in children before and after adenoidectomy or adenotonsillectomy. Horm Res Paediatr.
8135 Kasap B, Carman KB, Yis U. (2014). A case of acute post-streptococcal glomerulonephritis that developed posterior reversible encephalopathy syndrome. Turk Pediatri Ars.
8136 Katra R, Kabelka Z, Jurovcik M, et al. (2014). Pilot study: Association between Helicobacter pylori in adenoid hyperplasia and reflux episodes detected by multiple intraluminal impedance in children. Int J Pediatr Otorhinolaryngol.
8137 Katz SL, Vaccani JP, Barrowman N, et al. (2014). Does neck-to-waist ratio predict obstructive sleep apnea in children?. J Clin Sleep Med.
8138 Kawamura T, Yoshimura M, Miyazaki Y, et al. (2014). A multicenter randomized controlled trial of tonsillectomy combined with steroid pulse therapy in patients with immunoglobulin A nephropathy. Nephrology, Dialysis, Transplantation.
8139 Kaymakci M, Aydin M, Yazici S, et al. (2014). Detection of Helicobacter pylori in adenoid tissue by real-time polymerase chain reaction. Kulak Burun Bogaz Ihtis Derg.
8140 Kee K, Naughton MT. (2014). Clinical investigations from the RACP: Investigation of the snoring patient. Medicine Today.
8141 Kelly L, Sommer D, Ramakrishna J, et al. (2014). A randomized trial comparing morphine and ibuprofen for post-tonsillectomy pain management in children with sleep disordered breathing. Basic & clinical pharmacology & toxicology.
8142 Kennedy WP, Mudd PA, Maguire MA, et al. (2014). 22q11.2 Deletion syndrome and obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
8143 Kheirandish-Gozal L, Bhattacharjee R, Bandla HP, et al. (2014). Antiinflammatory therapy outcomes for mild OSA in children. Chest.
8144 Kheirandish-Gozal L, Ghalebandi M, Salehi M, et al. (2014). Neighbourhood air quality and snoring in school-aged children. Eur Respir J.
8145 Kim DK, Rhee CS, Yun PY, et al. (2014). Adenotonsillar hypertrophy as a risk factor of dentofacial abnormality in Korean children. Eur Arch Otorhinolaryngol.
8146 Kinthala S, Kumar Areti Y. (2014). Airway Obstruction and Inability to Ventilate Due to Swollen Uvula following Adenotonsillectomy in a Three-year Old Child. West Indian Med J.
8147 Kirkup J. (2014). John Erichsen's Tonsillectomy Scissors. J Med Biogr.
8148 Kishore S. (2014). A rare case of cavernous hemangioma in the tonsil. Research Journal of Pharmaceutical, Biological and Chemical Sciences.
8149 Kitamura T, Miyazaki S, Kadotani H, et al. (2014). Prevalence of obstructive sleep apnea syndrome in Japanese elementary school children aged 6-8 years. Sleep Breath.
8150 Klug TE. (2014). Incidence and microbiology of peritonsillar abscess: the influence of season, age, and gender. Eur J Clin Microbiol Infect Dis.
8151 Klug TE, Fischer AS, Antonsen C, et al. (2014). Parapharyngeal abscess is frequently associated with concomitant peritonsillar abscess. Eur Arch Otorhinolaryngol.
8152 Klug TE, Henriksen JJ, Rusan M, et al. (2014). Antibody development to Fusobacterium necrophorum in patients with peritonsillar abscess. Eur J Clin Microbiol Infect Dis.
8153 Kmietowicz Z. (2014). Commissioners defend policies on surgery referrals amid accusations of rationing. Bmj.
8154 Kobayashi R, Miyazaki S, Karaki M, et al. (2014). Obstructive sleep apnea in Asian primary school children. Sleep Breath.
8155 Kobayashi R, Miyazaki S, Karaki M, et al. (2014). Evaluation of adenotonsillectomy and tonsillectomy for pediatric obstructive sleep apnea by rhinomanometry and the OSA-18 questionnaire. Acta Otolaryngol.
8156 Kocabas A, Salman N, Ekici F, et al. (2014). Evaluation of cardiac functions and atrial electromechanical delay in children with adenotonsillar hypertrophy. Pediatr Cardiol.
8157 Kodiya AM, Ngamdu YB, Sandabe BM, et al. (2014). Management strategies of peritonsillar abscess in the tropics: a survey of surgeons' preference. Indian J Otolaryngol Head Neck Surg.
8158 Komiya K, Saito M, Sakurai Y, et al. (2014). Effectiveness of setting numerical targets in the surgical training of residents: a trial to achieve an optimal balance. J Med Dent Sci.
8159 Kong Y, Shi L, Hui SC, et al. (2014). Variation in anisotropy and diffusivity along the medulla oblongata and the whole spinal cord in adolescent idiopathic scoliosis: a pilot study using diffusion tensor imaging. AJNR Am J Neuroradiol.
8160 Konka A, Weedon J, Goldstein NA. (2014). Cost-benefit analysis of polysomnography versus Clinical Assessment Score-15 (CAS-15) for treatment of pediatric sleep-disordered breathing. Otolaryngol Head Neck Surg.
8161 Koshy E, Bottle A, Murray J, et al. (2014). Changing indications and socio-demographic determinants of (adeno)tonsillectomy among children in England--are they linked? A retrospective analysis of hospital data. PLoS One.
8162 Koskenkorva T, Koivunen P, Laara E, et al. (2014). Predictive factors for quality of life after tonsillectomy among adults with recurrent pharyngitis: a prospective cohort study. Clin Otolaryngol.
8163 Kotecha BT, Hall AC. (2014). Role of surgery in adult obstructive sleep apnoea. Sleep Med Rev.
8164 Kovacevic L, Wolfe-Christensen C, Lu H, et al. (2014). Why does adenotonsillectomy not correct enuresis in all children with sleep disordered breathing?. J Urol.
8165 Kovacs T, Vas T, Kovesdy CP, et al. (2014). Effect of tonsillectomy and its timing on renal outcomes in Caucasian IgA nephropathy patients. Int Urol Nephrol.
8166 Kraus J, Nartova E, Pavlik E, et al. (2014). Prevalence of Helicobacter pylori in adenotonsillar hypertrophy in children. Acta Otolaryngol.
8167 Krishna V, McLawhorn M, Kosnik-Infinger L, et al. (2014). High long-term symptomatic recurrence rates after Chiari-1 decompression without dural opening: a single center experience. Clin Neurol Neurosurg.
8168 Kubota K, Ohnishi H, Teramoto T, et al. (2014). Clinical and genetic characterization of Japanese sporadic cases of periodic Fever, aphthous stomatitis, pharyngitis and adenitis syndrome from a single medical center in Japan. J Clin Immunol.
8169 Kucuk O, Bicer S, Giray T, et al. (2014). Validity of rapid antigen detection testing in group A beta-hemolytic streptococcal tonsillopharyngitis. Indian J Pediatr.
8170 Kucur C, Kulekci S, Zorlu A, et al. (2014). Mean platelet volume levels in children with adenoid hypertrophy. J Craniofac Surg.
8171 Kujala T, Alho OP, Kristo A, et al. (2014). Quality of life after surgery for recurrent otitis media in a randomized controlled trial. Pediatr Infect Dis J.
8172 Kumar DS, Valenzuela D, Kozak FK, et al. (2014). The reliability of clinical tonsil size grading in children. JAMA Otolaryngol Head Neck Surg.
8173 Kumar HV, Schroeder JW, Gang Z, et al. (2014). Mallampati score and pediatric obstructive sleep apnea. J Clin Sleep Med.
8174 Kuo CY, Parikh SR. (2014). Can lingual tonsillectomy improve persistent pediatric obstructive sleep apnea?. Laryngoscope.
8175 Kupfer RA, Callaghan BC, Hogikyan ND. (2014). Neurogenic vocal fold motion impairment after routine intubation for tonsillectomy in a pediatric patient. J Voice.
8176 Kureshi SA, Gallagher PR, McDonough JM, et al. (2014). Pilot study of nasal expiratory positive airway pressure devices for the treatment of childhood obstructive sleep apnea syndrome. J Clin Sleep Med.
8177 Lachanas VA, Mousailidis GK, Skoulakis CE, et al. (2014). Validation of the Greek OSD-6 quality of life questionnaire in children undergoing polysomnography. Int J Pediatr Otorhinolaryngol.
8178 Lakic D, Tadic I, Odalovic M, et al. (2014). Analysis of antibiotic consumption for treating respiratory tract infections in children and compliance with the national clinical guidelines. Med Pregl.
8179 Lammens F, Lemkens N, Laureyns G, et al. (2014). Epidemiology of ENT emergencies. B-ENT.
8180 Lanchon R, Robin F, Brissaud O, et al. (2014). Factor V and VIII combined deficiency: clinical perioperative management for tonsillectomy in a child. Ann Fr Anesth Reanim.
8181 Larrosa F, Dura MJ, Jeremias J, et al. (2014). The cost associated with interstitial thermotherapy for tonsil reduction vs. standard tonsillectomy. Eur Arch Otorhinolaryngol.
8182 Lau AS, Upile NS, Wilkie MD, et al. (2014). The rising rate of admissions for tonsillitis and neck space abscesses in England, 1991-2011. Ann R Coll Surg Engl.
8183 Lauder G, Emmott A. (2014). Confronting the challenges of effective pain management in children following tonsillectomy. Int J Pediatr Otorhinolaryngol.
8184 Lauren K, Doron S, Jayant R, et al. (2014). Morphine vs. ibuprofen. Journal of Population Therapeutics and Clinical Pharmacology.
8185 Lee CH, Kang KT, Weng WC, et al. (2014). Quality of life after adenotonsillectomy for children with sleep-disordered breathing: a linear mixed model analysis. Int J Pediatr Otorhinolaryngol.
8186 Lee CH, Lee JH, Kim HM. (2014). Flexible integration of laser myringotomy and ventilation tube for bilateral Otitis media with effusion: analysis of laser tympanostomy versus ventilation tube. PLoS One.
8187 Lee CJ, Huang YC, Yang S, et al. (2014). Clinical features of coxsackievirus A4, B3 and B4 infections in children. PLoS One.
8188 Lee DY, Seok J, Kim YJ, et al. (2014). Neck computed tomography in pediatric neck mass as initial evaluation in ED: is it malpractice?. Am J Emerg Med.
8189 Lee HJ, Kim KS, Kim TY, et al. (2014). The use of 3 sugammadex out of 5 reversal of during recovery of rocuronium-induced neuromuscular blockade in a patient with post-tonsillectomy hemorrhage: A case report. Korean Journal of Anesthesiology.
8190 Lee HS, Kim JS, Roh JL, et al. (2014). Clinical values for abnormal (1)(8)F-FDG uptake in the head and neck region of patients with head and neck squamous cell carcinoma. Eur J Radiol.
8191 Lee J, Mansfield D, Hamilton G, et al. (2014). The upper airway sleep apnoea clinic: A new, multidisciplinary model of care between ENT and sleep medicine. Sleep and Biological Rhythms.
8192 Lee JJ, Sun LS, Gu B, et al. (2014). Does obesity prolong anesthesia in children undergoing common ENT surgery?. Paediatr Anaesth.
8193 Lee SJ, Suh CW, Lee SI, et al. (2014). Clinical characteristics, pathological distribution, and prognostic factors in non-Hodgkin lymphoma of Waldeyer's ring: nationwide Korean study. Korean J Intern Med.
8194 Leitzbach SU, Bodlaj R, Maurer JT, et al. (2014). Safety of cold ablation (coblation) in the treatment of tonsillar hypertrophy of the tongue base. Eur Arch Otorhinolaryngol.
8195 Leitzen KP, Brietzke SE, Lindsay RW. (2014). Correlation between nasal anatomy and objective obstructive sleep apnea severity. Otolaryngol Head Neck Surg.
8196 Levin JC, Gagnon L, He X, et al. (2014). Improvement in asthma control and inflammation in children undergoing adenotonsillectomy. Pediatr Res.
8197 Li AM, Au CT, Zhu JY, et al. (2014). Plasma natriuretic peptides in children and adolescents with obstructive sleep apnea and their changes following intervention. Front Pediatr.
8198 Li J, Wang Z, Cao J, et al. (2014). Role of monochromatic light on development of cecal tonsil in young broilers. Anat Rec (Hoboken).
8199 Li Y, Peng A, Yang X, et al. (2014). Clinical manifestation and management of primary malignant tumors of the cervical trachea. Eur Arch Otorhinolaryngol.
8200 Lightbody KA, Kinshuck AJ, Donne AJ. (2014). Pre-operative overnight pulse oximetry to predict high dependency unit intervention in children undergoing adenotonsillectomy for obstructive sleep apnoea. J Laryngol Otol.
8201 Lin HY, Chuang CK, Chen MR, et al. (2014). Natural history and clinical assessment of Taiwanese patients with mucopolysaccharidosis IVA. Orphanet J Rare Dis.
8202 Lin RH, Huang CC, Tsou YA, et al. (2014). Correlation between imaging characteristics and microbiology in patients with deep neck infections: a retrospective review of one hundred sixty-one cases. Surg Infect (Larchmt).
8203 Linkov G, Zwillenberg D, Davis WJ, et al. (2014). Complication of bipolar radiofrequency adenoidectomy: palate fistula. Otolaryngol Head Neck Surg.
8204 Liu Y, Liu H, Tu X, et al. (2014). Study of tonsillectomy for IgA nephropathy patients: short- and longer-term observation. Int Urol Nephrol.
8205 Liu ZW, Meghji S, Jayaraj S. (2014). A randomized controlled trial protocol for gelorevoice throat lozenges as adjunctive analgesic in post-tonsillectomy pain. Otolaryngology - Head and Neck Surgery (United States).
8206 Lu YX, Gu QL, Du J, et al. (2014). Upper airway cough syndrome in children and two inflammatory factors: TRPV1 and TGF-beta2. Int J Pediatr Otorhinolaryngol.
8207 Lukes P, Pavlik E, Potuznikova B, et al. (2014). Detection of Helicobacter pylori in oropharyngeal lymphatic tissue with real-time PCR and assessment of its carcinogenic potential. Eur Arch Otorhinolaryngol.
8208 Luo H, Sin S, McDonough JM, et al. (2014). Computational fluid dynamics endpoints for assessment of adenotonsillectomy outcome in obese children with obstructive sleep apnea syndrome. J Biomech.
8209 Luo HN, Yang QM, Sheng Y, et al. (2014). Role of pepsin and pepsinogen: linking laryngopharyngeal reflux with otitis media with effusion in children. Laryngoscope.
8210 Madej P, Pyrkosz A, Franik G, et al. (2014). Monosomy (interstitial deletion) in chromosome 8 (8p23.1) associated with mayer-rokitansky-kustner-hauser syndrome (MRKH). Ginekologia i Poloznictwo.
8211 Maeda K, Tsuiki S, Nakata S, et al. (2014). Craniofacial contribution to residual obstructive sleep apnea after adenotonsillectomy in children: a preliminary study. J Clin Sleep Med.
8212 Magdalena ML, Caragol L, Sole A, et al. (2014). Comparison of two analgesic protocols for post-tonsillectomy pain control in outpatient adults. Acta Otorrinolaringol Esp.
8213 Magos TA, Syed MI, Montague ML. (2014). Re: More codeine fatalities after tonsillectomy in North American children: time to revise prescribing practice!. Clin Otolaryngol.
8214 Mahgoobifard M, Mirmesdagh Y, Imani F, et al. (2014). The analgesic efficacy of preoperative oral Ibuprofen and acetaminophen in children undergoing adenotonsillectomy: a randomized clinical trial. Anesth Pain Med.
8215 Major MP, Saltaji H, El-Hakim H, et al. (2014). The accuracy of diagnostic tests for adenoid hypertrophy: a systematic review. J Am Dent Assoc.
8216 Major MP, Witmans M, El-Hakim H, et al. (2014). Agreement between cone-beam computed tomography and nasoendoscopy evaluations of adenoid hypertrophy. Am J Orthod Dentofacial Orthop.
8217 Makepeace J, Patel A. (2014). Ear, nose and throat emergencies. Anaesthesia and Intensive Care Medicine.
8218 Malapane E, Solomon EM, Pellow J. (2014). Efficacy of a homeopathic complex on acute viral tonsillitis. J Altern Complement Med.
8219 Mallen-St Clair J, Arshi A, Tajudeen B, et al. (2014). Epidemiology and treatment of lacrimal gland tumors: a population-based cohort analysis. JAMA Otolaryngol Head Neck Surg.
8220 Manara R, Concolino D, Rampazzo A, et al. (2014). Chiari 1 malformation and holocord syringomyelia in hunter syndrome. JIMD Rep.
8221 Marcinow A, Ozer E, Teknos T, et al. (2014). Clinicopathologic predictors of recurrence and overall survival in adenoid cystic carcinoma of the head and neck: a single institutional experience at a tertiary care center. Head Neck.
8222 Marcus CL, Meltzer LJ, Roberts RS, et al. (2014). Long-term effects of caffeine therapy for apnea of prematurity on sleep. Sleep.
8223 Markunas CA, Enterline DS, Dunlap K, et al. (2014). Genetic evaluation and application of posterior cranial fossa traits as endophenotypes for Chiari type I malformation. Ann Hum Genet.
8224 Martin JM, Gillingham MB, Harding CO. (2014). Use of propofol for short duration procedures in children with long chain 3-hydroxyacyl-CoA dehydrogenase (LCHAD) or trifunctional protein (TFP) deficiencies. Molecular genetics and metabolism.
8225 Martin S, Smith AB, Newcomb P, et al. (2014). Effects of therapeutic suggestion under anesthesia on outcomes in children post tonsillectomy. J Perianesth Nurs.
8226 Martins MB, Lima RG, Lima FV, et al. (2014). Demystifying septoplasty in children. Int Arch Otorhinolaryngol.
8227 Marzban S, Haddadi S, Naghipour MR, et al. (2014). The effect of intravenous magnesium sulfate on laryngospasm after elective adenotonsillectomy surgery in children. Anesth Pain Med.
8228 Masieri S, Trabattoni D, Incorvaia C, et al. (2014). A role for Waldeyer's ring in immunological response to allergens. Curr Med Res Opin.
8229 Mathew JL, Narang I. (2014). Sleeping too close together: obesity and obstructive sleep apnea in childhood and adolescence. Paediatr Respir Rev.
8230 Mattos JL, Robison JG, Greenberg J, et al. (2014). Acetaminophen plus ibuprofen versus opioids for treatment of post-tonsillectomy pain in children. Int J Pediatr Otorhinolaryngol.
8231 Mavigner M, Watkins B, Lawson B, et al. (2014). Persistence of virus reservoirs in ART-treated SHIV-infected rhesus macaques after autologous hematopoietic stem cell transplant. PLoS Pathog.
8232 Mawdsley SE. (2014). Polio provocation: solving a mystery with the help of history. Lancet.
8233 Mayor S. (2014). Adenotonsillectomy reduces acute asthma exacerbations in children, study shows. Bmj.
8234 Mbam TT, Adeosun AA, Akinyemi OA, et al. (2014). Comparing Oxygen Saturation of Normal Children with that of Children with Adenotonsillar Hypertrophy. Indian J Otolaryngol Head Neck Surg.
8235 Mehregan FF, Ziaee V, Ahmadinejad Z, et al. (2014). Periodic Fever, Aphthous Stomatitis, Pharyngitis and Cervical Adenitis (PFAPA) Syndrome in Iranian Children First Report of Iranian Periodic Fever and Autoinflammatory Registry (IPFAIR). Iran J Pediatr.
8236 Meier JD, Duval M, Wilkes J, et al. (2014). Surgeon dependent variation in adenotonsillectomy costs in children. Otolaryngol Head Neck Surg.
8237 Michelson AP, Hawley K, Anne S. (2014). Do synchronous airway lesions predict treatment failure after adenotonsillectomy in children less than 3 years of age with obstructive sleep apnea?. Int J Pediatr Otorhinolaryngol.
8238 Migacz E, Kukwa W. (2014). Selected cardiologic aspects of sleep apnea in children - New findings. Experimental and Clinical Cardiology.
8239 Miramontes HP, Fagundes DJ, Jurgielewicz JC, et al. (2014). Prevalence of microorganisms and immunoglobulins in children with tonsillar hypertrophy and adenoiditis. Int Arch Otorhinolaryngol.
8240 Mohamadi J, Panahi J, Havasian MR, et al. (2014). Marshall syndrome in children referred to specialist clinic of Imam Khomeini Hospital of Ilam, Iran, 2012. Der Pharmacia Lettre.
8241 Mohebbi S, Hassannia F, Kelantari F, et al. (2014). Response to the letter to the editor regarding “efficacy of honey in reduction of post tonsillectomy pain, randomized clinical trial” [Int. J. Pediatr. Otorhinolaryngol. (2014), doi:10.1016/j.ijporl.2014.07.023]. International Journal of Pediatric Otorhinolaryngology.
8242 Mohebbi S, Nia FH, Kelantari F, et al. (2014). Efficacy of honey in reduction of post tonsillectomy pain, randomized clinical trial. Int J Pediatr Otorhinolaryngol.
8243 Mohsen N, Susan A, Shahin B, et al. (2014). Sleep related quality of life before and after adenotonsillar surgery in pediatric population. Int J Pediatr Otorhinolaryngol.
8244 Montano-Velazquez BB, Villanueva-Padron LA, Conde-Vazquez E, et al. (2014). The middle ear pressure does not change after adenotonsillectomy in children younger than 10 years old. Rev Invest Clin.
8245 Moore HE, Moore KR. (2014). Magnetic resonance imaging features of complex Chiari malformation variant of Chiari 1 malformation. Pediatr Radiol.
8246 Morales MP, Carvallo AP, Espinosa KA, et al. (2014). A young man with myelosuppression caused by clindamycin: a case report. J Med Case Rep.
8247 Moriyama T, Tanaka K, Iwasaki C, et al. (2014). Prognosis in IgA nephropathy: 30-year analysis of 1,012 patients at a single center in Japan. PLoS One.
8248 Morozumi M, Shimizu H, Matsushima Y, et al. (2014). Evaluation of new immunochromatographic assay kit for adenovirus detection in throat swab: comparison with culture and real-time PCR results. J Infect Chemother.
8249 Mousailidis GK, Lachanas VA, Skoulakis CE, et al. (2014). Cross-cultural adaptation and validation of the Greek OSA-18 questionnaire in children undergoing polysomnography. Int J Pediatr Otorhinolaryngol.
8250 Mueller J, Boeger D, Buentzel J, et al. (2014). Population-based analysis of tonsil surgery and postoperative hemorrhage. Eur Arch Otorhinolaryngol.
8251 Murphy TK, Gerardi DM, Leckman JF. (2014). Pediatric acute-onset neuropsychiatric syndrome. Psychiatr Clin North Am.
8252 Mutlu M, Vuralkan E, Yardim Akaydin S, et al. (2014). Effects of adenoid/tonsillectomy on inflammatory response in snoring children with witnessed apnoea. Clin Otolaryngol.
8253 Nachalon Y, Lowenthal N, Greenberg-Dotan S, et al. (2014). Inflammation and growth in young children with obstructive sleep apnea syndrome before and after adenotonsillectomy. Mediators Inflamm.
8254 Nagasawa Y, Iio K, Fukuda S, et al. (2014). Periodontal disease bacteria specific to tonsil in IgA nephropathy patients predicts the remission by the treatment. PLoS One.
8255 Nagel TH, Hinni ML, Hayden RE, et al. (2014). Transoral laser microsurgery for the unknown primary: role for lingual tonsillectomy. Head Neck.
8256 Nakata J, Suzuki Y, Suzuki H, et al. (2014). Changes in nephritogenic serum galactose-deficient IgA1 in IgA nephropathy following tonsillectomy and steroid therapy. PLoS One.
8257 Nartova E, Kraus J, Pavlik E, et al. (2014). Presence of different genotypes of Helicobacter pylori in patients with chronic tonsillitis and sleep apnoea syndrome. Eur Arch Otorhinolaryngol.
8258 Nation J, Kaufman M, Allen M, et al. (2014). Incidence of gastroesophageal reflux disease and positive maxillary antral cultures in children with symptoms of chronic rhinosinusitis. Int J Pediatr Otorhinolaryngol.
8259 Ng L, Mercer-Jones M. (2014). Day case surgery guidelines. Surgery (United Kingdom).
8260 Nguyen TB, Chin RY, Paramaesvaran S, et al. (2014). Routine tonsillar bed oversew after diathermy tonsillectomy: does it reduce secondary tonsillar haemorrhage?. Eur Arch Otorhinolaryngol.
8261 Nixon GM, Cikor N, Rowe K, et al. (2014). Refining the OSA-18 questionnaire for prediction of OSA in children-can we improve it?. Sleep and Biological Rhythms.
8262 Nokso-Koivisto J, Blomgren K, Roine RP, et al. (2014). Impact of tonsillectomy on health-related quality of life and healthcare costs in children and adolescents. Int J Pediatr Otorhinolaryngol.
8263 Nomura T, Makizumi Y, Yoshida T, et al. (2014). The Relationship between the Efficacy of Tonsillectomy and Renal Pathology in the Patients with IgA Nephropathy. Int J Otolaryngol.
8264 Obeid AA, Al-Qahtani KH, Ashraf M, et al. (2014). Development and testing for an operative competency assessment tool for nasal septoplasty surgery. Am J Rhinol Allergy.
8265 O'Connell BP, Dobbie AM, Oyer SL, et al. (2014). The impact of adenoid size on rate of revision sphincter pharyngoplasty. Laryngoscope.
8266 Onder S, Caypinar B, Sahin-Yilmaz A, et al. (2014). Relation of mean platelet volume with obstructive adenoid hypertrophy in children. Int J Pediatr Otorhinolaryngol.
8267 Ong JJ, Read TR, Vodstrcil LA, et al. (2014). Detection of oral human papillomavirus in HIV-positive men who have sex with men 3 years after baseline: a follow up cross-sectional study. PLoS One.
8268 Oomen KP, Modi VK. (2014). Epiglottopexy with and without lingual tonsillectomy. Laryngoscope.
8269 Orlik K, Griffin GD, Zoumberakis E. (2014). Unilateral neck pain: a case of Eagle syndrome with associated nontraumatic styloid fracture. Am J Emerg Med.
8270 Ormond A, Chao S, Shapiro D, et al. (2014). Peritonsillar abscess with rapid progression to complete airway obstruction in a toddler. Laryngoscope.
8271 Otsuka Y, Takeda A, Horike K, et al. (2014). Early recurrence of active IgA nephropathy after kidney transplantation. Nephrology (Carlton).
8272 Ozbay I, Gencoglu M, Balikci HH, et al. (2014). Histopathological analysis of tonsillectomy specimens: a report from Southeastern Anatolia. Kulak Burun Bogaz Ihtis Derg.
8273 Ozer AB, Demirel I, Gokdemir T, et al. (2014). Anaesthesia management in a child with metabolic myopathy. Eur Rev Med Pharmacol Sci.
8274 Ozkull MH, Bayram O, Balikci HH, et al. (2014). Impedance-controlled radiofrequency vs. cold dissection tonsillectomy. B-ENT.
8275 Oztekin S, Duru S. (2014). Analgesic effects of gabapentin and diclofenac on post-operative pain in patients undergoing tonsillectomy. Arch Trauma Res.
8276 Paganelli A, Ayari Khalfallah S, Brunaud A, et al. (2014). Guidelines (short version) of the French Oto-Rhino-Laryngology--Head and Neck Surgery Society (SFORL) for the management of post-tonsillectomy pain in adults. Eur Ann Otorhinolaryngol Head Neck Dis.
8277 Palanisamy A, Bailey CR. (2014). Codeine in mothers and children: where are we now?. Anaesthesia.
8278 Palmer E, Newcombe RG, Green AC, et al. (2014). Human papillomavirus infection is rare in nonmalignant tonsil tissue in the UK: implications for tonsil cancer precursor lesions. International journal of cancer. Journal international du cancer.
8279 Palmu AA, Jokinen J, Nieminen H, et al. (2014). Effect of pneumococcal Haemophilus influenzae protein D conjugate vaccine (PHiD-CV10) on outpatient antimicrobial purchases: a double-blind, cluster randomised phase 3-4 trial. Lancet Infect Dis.
8280 Palomares O, Martin-Fontecha M, Lauener R, et al. (2014). Regulatory T cells and immune regulation of allergic diseases: roles of IL-10 and TGF-beta. Genes Immun.
8281 Paris JJ, Cummings BM, Moore MP. (2014). “Brain death,” “dead,” and parental denial - the case of Jahi McMath. Camb Q Healthc Ethics.
8282 Park CS, Guilleminault C, Park HJ, et al. (2014). Correlation of salivary alpha amylase level and adenotonsillar hypertrophy with sleep disordered breathing in pediatric subjects. J Clin Sleep Med.
8283 Park CY, Hong JH, Lee JH, et al. (2014). Clinical usefulness of watch-PAT for assessing the surgical results of obstructive sleep apnea syndrome. J Clin Sleep Med.
8284 Park JH, Lim BG, Kim HZ, et al. (2014). Comparison of emergence agitation between sevoflurane/nitrous oxide administration and sevoflurane administration alone in children undergoing adenotonsillectomy with preemptive ketorolac. Korean J Anesthesiol.
8285 Partanen E, Koljonen V, Salonen A, et al. (2014). A patient with intraoral fire during tonsillectomy. J Craniofac Surg.
8286 Patel HH, Straight CE, Lehman EB, et al. (2014). Indications for tonsillectomy: a 10 year retrospective review. Int J Pediatr Otorhinolaryngol.
8287 Patil S, Ghosh S, Vasudeva N. (2014). Morphometric study of the styloid process of temporal bone. J Clin Diagn Res.
8288 Pavone P, Rapisarda V, Serra A, et al. (2014). Pediatric autoimmune neuropsychiatric disorder associated with group a streptococcal infection: the role of surgical treatment. Int J Immunopathol Pharmacol.
8289 Permpalung N, Suksaranjit P, Chongnarungsin D, et al. (2014). Unveiling the hidden eagle: Acute parotitis-induced Eagle syndrome. North American Journal of Medical Sciences.
8290 Petraccone Caixeta AC, Andrade I, Bahia Junqueira Pereira T, et al. (2014). Dental arch dimensional changes after adenotonsillectomy in prepubertal children. Am J Orthod Dentofacial Orthop.
8291 Petrelli D, Di Luca MC, Prenna M, et al. (2014). Characterization of levofloxacin non-susceptible clinical Streptococcus pyogenes isolated in the central part of Italy. Eur J Clin Microbiol Infect Dis.
8292 Pidelaserra Marti G, Isdahl Mohn KG, Cox RJ, et al. (2014). The influence of tonsillectomy on total serum antibody levels. Scand J Immunol.
8293 Plzak J, Macokova P, Zabrodsky M, et al. (2014). Influence of radiofrequency surgery on architecture of the palatine tonsils. Biomed Res Int.
8294 Prandota J, Gryglas A, Fuglewicz A, et al. (2014). Recurrent headaches may be caused by cerebral toxoplasmosis. World J Clin Pediatr.
8295 Proenca-Modena JL, Buzatto GP, Paula FE, et al. (2014). Respiratory viruses are continuously detected in children with chronic tonsillitis throughout the year. Int J Pediatr Otorhinolaryngol.
8296 Proenca-Modena JL, Paula FE, Buzatto GP, et al. (2014). Hypertrophic adenoid is a major infection site of human bocavirus 1. J Clin Microbiol.
8297 Prows CA, Zhang X, Huth MM, et al. (2014). Codeine-related adverse drug reactions in children following tonsillectomy: a prospective study. Laryngoscope.
8298 Pucher B, Szydlowski J, Sroczynski J, et al. (2014). The most common reasons for referral to pediatric ENT outpatient clinic in Poznan. Family Medicine and Primary Care Review.
8299 Rafalska A, Franczuk J, Franczuk P, et al. (2014). Stratifying risk for progression in IgA nephropathy: how to predict the future?. Pol Arch Med Wewn.
8300 Ramadan HH, Makary CA. (2014). Can computed tomography score predict outcome of adenoidectomy for chronic rhinosinusitis in children. Am J Rhinol Allergy.
8301 Raman VT, Jatana KR, Elmaraghy CA, et al. (2014). Guidelines to decrease unanticipated hospital admission following adenotonsillectomy in the pediatric population. Int J Pediatr Otorhinolaryngol.
8302 Ramji M, Biron VL, Jeffery CC, et al. (2014). Validation of pharyngeal findings on sleep nasopharyngoscopy in children with snoring/sleep disordered breathing. J Otolaryngol Head Neck Surg.
8303 Ramsden JD. (2014). Symptoms of obstructive sleep apnoea are treated by adenotonsillectomy, but without change in neurocognitive outcome. Evid Based Med.
8304 Randhawa A, Bondin D, Kumar BN. (2014). A surgical presentation for haemophilia A. BMJ Case Rep.
8305 Rathi SK, Ahmed R. (2014). Pakistan prevalence survey in acute pharyngitis. J Pak Med Assoc.
8306 Ravesloot MJ, Bril H, Braamskamp MJ, et al. (2014). The curious case of the orange coloured tonsils. Int J Pediatr Otorhinolaryngol.
8307 Riechelmann H, Blassnigg EC, Profanter C, et al. (2014). No association between obesity and post-tonsillectomy haemorrhage. J Laryngol Otol.
8308 Ringden O, Brazauskas R, Wang Z, et al. (2014). Second solid cancers after allogeneic hematopoietic cell transplantation using reduced-intensity conditioning. Biol Blood Marrow Transplant.
8309 Ritsuko K, Tetsuya K, Akinori H, et al. (2014). Pathological Sub-Analysis of Randomized Controlled Trial of Tonsillectomy Combined with Steroid Pulse Therapy Vs Steroid Pulse Monotherapy in Iga Nephropathy. Nephrology (Carlton, Vic.).
8310 Rizk SN, Samir EM. (2014). Use of ketofol to control emergence agitation in children undergoing adenotonsillectomy. Egyptian Journal of Anaesthesia.
8311 Robb PJ. (2014). Tranexamic acid - a useful drug in ENT surgery?. J Laryngol Otol.
8312 Robb PJ. (2014). Response to Magos et al. Clin Otolaryngol.
8313 Robb PJ, Thorning G. (2014). Perioperative tranexamic acid in day-case paediatric tonsillectomy. Ann R Coll Surg Engl.
8314 Roje Z, Skrabic V, Stipic SS. (2014). Coblation tonsilloadenoidectomy - Treatment of choice for very small children. Signa Vitae.
8315 Rokkjaer MS, Klug TE. (2014). Malignancy in routine tonsillectomy specimens: a systematic literature review. Eur Arch Otorhinolaryngol.
8316 Ropposch T, Walch C, Avian A, et al. (2014). Effects of the depth of anesthesia on distortion product otoacoustic emissions. Eur Arch Otorhinolaryngol.
8317 Rose C, Svider PF, Sheyn A, et al. (2014). Protecting the most vulnerable: litigation from pediatric otolaryngologic procedures and conditions. Laryngoscope.
8318 Rossi E, Felici AR, Banteyrga L. (2014). Subclinical rheumatic heart disease in an Eritrean high-school population, detected by echocardiography. J Heart Valve Dis.
8319 Rotenberg BW, Theriault J, Gottesman S. (2014). Redefining the timing of surgery for obstructive sleep apnea in anatomically favorable patients. Laryngoscope.
8320 Roy DM, Walsh LA, Chan TA. (2014). Driver mutations of cancer epigenomes. Protein Cell.
8321 Royse CF, Williams Z, Purser S, et al. (2014). Recovery after nasal surgery vs. tonsillectomy: discriminant validation of the Postoperative Quality of Recovery Scale. Acta Anaesthesiol Scand.
8322 Ryan S, Papanikolaou V, Keogh I. (2014). Appraisal of the peri-hospital management and evolving microbiology of peritonsillar abscess disease. B-ENT.
8323 Ryu KH, Kim SY, Kim YR, et al. (2014). Tonsil-derived mesenchymal stem cells alleviate concanavalin A-induced acute liver injury. Exp Cell Res.
8324 Ryu YJ, Wee JH, Lee WH, et al. (2014). Combined extracapsular and intracapsular tonsillectomy: lower pole capsule preservation. Laryngoscope.
8325 Sadhasivam S, Chidambaran V, Olbrecht VA, et al. (2014). Genetics of pain perception, COMT and postoperative pain management in children. Pharmacogenomics.
8326 Sahiner F, Gumral R, Yildizoglu U, et al. (2014). Coexistence of Epstein-Barr virus and Parvovirus B19 in tonsillar tissue samples: quantitative measurement by real-time PCR. Int J Pediatr Otorhinolaryngol.
8327 Sajedi P, Baghery K, Hagibabie E, et al. (2014). Prophylactic Use of Oral Acetaminophen or IV Dexamethasone and Combination of them on Prevention Emergence Agitation in Pediatric after Adenotonsillectomy. Int J Prev Med.
8328 Sakallioglu O, Duzer S, Kapusuz Z. (2014). The efficiacy of anterior and posterior archs suturation at inferior tonsillar pole for posttonsillectomy pain control. Indian J Otolaryngol Head Neck Surg.
8329 Saki N, Samarbaf Zadeh AR, Sheikhpour Jonaky R, et al. (2014). The Prevalence Rate of Helicobacter pylori Infection in, Chronic Otitis Media With Effusion Patients. Jundishapur J Microbiol.
8330 Salazar-Arboleda GE, Moncaleano-Arevalo AM, Rueda-Chartouni AM, et al. (2014). Comparison of the upper airways from cephalometric radiographs of children with and without finger-sucking habit. Eur J Paediatr Dent.
8331 Saleemi MY, Tariq M, Ahmed M. (2014). Comparison of monopolar with bipolar diathermy in patients undergoing tonsillectomy. Pakistan Journal of Medical and Health Sciences.
8332 Salman N, Ozturk G, Akin I, et al. (2014). The effect of adenotonsilectomy on ghrelin, leptin, IGF-1 levels and growth parameters in children with adenotonsillar hypertrophy. J Pediatr Endocrinol Metab.
8333 Salzman R, Starek I, Faisal H, et al. (2014). Pediatric parotideomasseteric pilomatrixoma in children. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub.
8334 Samee MA, Farooq SO, Hameed A, et al. (2014). Surgical audit of patients reported to E.N.T unit 1 Mayo Hospital/King Edward Medical University, Lahore for period of one year 2013-2014. Pakistan Journal of Medical and Health Sciences.
8335 Sanchez A, Soliveres J, Hernandez MJ, et al. (2014). Parental presence during anesthesia induction. Does it improve quality of anesthesia? European journal of anaesthesiology.
8336 Sanli A, Tasdemir O, Eken M, et al. (2014). Prevalence of otitis media with effusion among primary school age-children and etiopathogenic examination. Indian J Otolaryngol Head Neck Surg.
8337 Sato Y, Ishida H, Shimizu T, et al. (2014). Evaluation of tonsillectomy before kidney transplantation in patients with IgA nephropathy. Transpl Immunol.
8338 Sayar H, Sayar C, Adamhasan F, et al. (2014). Lymphangiomatous Polyp of Tonsil: A Case Report. Turk Patoloji Derg.
8339 Scarano E, Della Marca G, De Corso E, et al. (2014). Hyoid myotomy without suspension: a surgical approach to obstructive sleep apnoea syndrome. Acta Otorhinolaryngol Ital.
8340 Schaar V, Uddback I, Nordstrom T, et al. (2014). Group A streptococci are protected from amoxicillin-mediated killing by vesicles containing beta-lactamase derived from Haemophilus influenzae. J Antimicrob Chemother.
8341 Schachtel B, Aspley S, Shephard A, et al. (2014). Utility of the sore throat pain model in a multiple-dose assessment of the acute analgesic flurbiprofen: a randomized controlled study. Trials.
8342 Schilder AG. (2014). Early adenotonsillectomy for obstructive sleep apnoea improved quality of life and symptoms but not attention or executive function. Arch Dis Child Educ Pract Ed.
8343 Schrotzlmair F, Geerke L, Kisser U, et al. (2014). Optical magnification devices in tonsillectomy: a prospective randomised clinical study. European Archives of Oto-rhino-laryngology.
8344 Schulz M, Spors B, Haberl H, et al. (2014). Results of posterior cranial vault remodeling for plagiocephaly and brachycephaly by the meander technique. Childs Nerv Syst.
8345 Sedky K, Bennett DS, Carvalho KS. (2014). Attention deficit hyperactivity disorder and sleep disordered breathing in pediatric populations: a meta-analysis. Sleep Med Rev.
8346 Sedky K, Bennett DS, Pumariega A. (2014). Prader Willi syndrome and obstructive sleep apnea: co-occurrence in the pediatric population. J Clin Sleep Med.
8347 Sekaran A, Muza R. (2014). Positional central sleep apnoea. Sleep and Biological Rhythms.
8348 Seren E, San T, Cingi C, et al. (2014). Effects of body mass index and adenotonsillar size on snoring sound intensity levels at highest power. Int J Pediatr Otorhinolaryngol.
8349 Seshamani M, Vogtmann E, Gatwood J, et al. (2014). Prevalence of complications from adult tonsillectomy and impact on health care expenditures. Otolaryngol Head Neck Surg.
8350 Setabutr D, Adil EA, Chaikhoutdinov I, et al. (2014). Impact of the pediatric tonsillectomy and polysomnography clinical practice guidelines. Int J Pediatr Otorhinolaryngol.
8351 Setabutr D, Perez MR, Truong MT, et al. (2014). Neurofibromatosis of the larynx causing stridor and sleep apnea. Am J Otolaryngol.
8352 Sethi N, Egan P, Ward VM. (2014). Suction diathermy adenoidectomy performed in the district general hospital. J Laryngol Otol.
8353 Setoguchi K, Kawashima Y, Tokumoto T, et al. (2014). Proliferative glomerulonephritis with monoclonal immunoglobulin A light-chain deposits in the renal allograft. Nephrology (Carlton).
8354 Shah UK, Theroux Z, Shah GB, et al. (2014). Resource analysis of tonsillectomy in children. Laryngoscope.
8355 Shahbaz S, Ghauri SM, Shaheen S, et al. (2014). Histomorphological changes in hypertrophied tonsils in children. Pakistan Journal of Medical and Health Sciences.
8356 Shen Z, Li T, Chen D, et al. (2014). The CCL5/CCR5 axis contributes to the perineural invasion of human salivary adenoid cystic carcinoma. Oncol Rep.
8357 Shin JM, Byun JY, Baek BJ, et al. (2014). Effect of cold-water cooling of tonsillar fossa and pharyngeal mucosa on post-tonsillectomy pain. Am J Otolaryngol.
8358 Shin S, Park JS, Shim YM, et al. (2014). Carinal resection and reconstruction in thoracic malignancies. J Surg Oncol.
8359 Shishegar M, Ashraf MJ. (2014). Posttonsillectomy bacteremia and comparison of tonsillar surface and deep culture. Adv Prev Med.
8360 Showmaker J, Gov-Ari E. (2014). A retropharyngeal mass in a young boy. JAMA Otolaryngol Head Neck Surg.
8361 Siddartha K, Faiq A, Rachna K, et al. (2014). Langerhans cell histiocytosis(LCH) of tonsil: An uncommon disease at an unusual site. Indian Journal of Hematology and Blood Transfusion.
8362 Silva D, Colvin L, Hagemann E, et al. (2014). Children diagnosed with attention deficit disorder and their hospitalisations: population data linkage study. Eur Child Adolesc Psychiatry.
8363 Silva-Costa C, Carrico JA, Ramirez M, et al. (2014). Scarlet fever is caused by a limited number of Streptococcus pyogenes lineages and is associated with the exotoxin genes ssa, speA and speC. Pediatr Infect Dis J.
8364 Sim MW, Stanley JJ. (2014). Trends in otolaryngology residency training in the surgical treatment of obstructive sleep apnea. Laryngoscope.
8365 Singh K, Nordstrom T, Morgelin M, et al. (2014). Haemophilus influenzae resides in tonsils and uses immunoglobulin D binding as an evasion strategy. J Infect Dis.
8366 Siupsinskiene N, Zekoniene J, Padervinskis E, et al. (2014). Efficacy of sucralfate for the treatment of post-tonsillectomy symptoms. European Archives of Oto-rhino-laryngology.
8367 Solyom R, Csiszer I, Neagos A. (2014). Tonsillar hypertrophy implications in sleep disorders in adults and children. Rom J Morphol Embryol.
8368 Soni-Jaiswal A, Anderco I, Kumar BN. (2014). Patient-reported outcomes in children suffering with mild to moderate tonsillitis versus those in children with severe tonsillitis. J Laryngol Otol.
8369 Sonsuwan N, Pornlert A, Sawanyawisuth K. (2014). Risk factors for acute pulmonary edema after adenotonsillectomy in children. Auris Nasus Larynx.
8370 Sorensen JA, Pusz MD, Brietzke SE. (2014). YouTube as an information source for pediatric adenotonsillectomy and ear tube surgery. Int J Pediatr Otorhinolaryngol.
8371 Soy FK, Dundar R, Yazici H, et al. (2014). Bipolar cautery tonsillectomy using different energy doses: pain and bleeding. Int J Pediatr Otorhinolaryngol.
8372 Sozeri B, Cam O, Delebe M, et al. (2014). The clinical and genetic features of patients with hyperimmunoglobulin D syndrome (HIDS). Pediatric Rheumatology.
8373 Spangler J, Csakanyi Z, Rogers T, et al. (2014). Parental ease in asking others not to smoke and respiratory symptoms and illness among children. Int J Environ Res Public Health.
8374 Spanos G, Harissis HV, Dounousi E, et al. (2014). A case of encapsulating peritoneal sclerosis presented shortly after renal transplantation. CEN Case Reports.
8375 Sperry S, Knox B, Edwards D, et al. (2014). Cultivating healthy eating, exercise, and relaxation (CHEER): A case study of a family-centered and mindfulness-based cognitive-behavioral intervention for obese adolescents at risk for diabetes and cardiovascular disease. Clinical Case Studies.
8376 Sperry SM, O'Malley BW, Weinstein GS. (2014). The University of Pennsylvania curriculum for training otorhinolaryngology residents in transoral robotic surgery. ORL J Otorhinolaryngol Relat Spec.
8377 Stannard C, Maree G, Tovey S, et al. (2014). Iodine-125 brachytherapy in the management of squamous cell carcinoma of the oral cavity and oropharynx. Brachytherapy.
8378 Steinbichler T, Bender B, Blassnigg E, et al. (2014). Evaluation of a German version of the tonsil and adenoid health status instrument. J Otolaryngol Head Neck Surg.
8379 Stelter K. (2014). Tonsillitis and sore throat in children. GMS Curr Top Otorhinolaryngol Head Neck Surg.
8380 Stepinska M, Olszewska-Sosinska O, Lau-Dworak M, et al. (2014). Identification of intracellular bacteria in adenoid and tonsil tissue specimens: the efficiency of culture versus fluorescent in situ hybridization (FISH). Curr Microbiol.
8381 Stojanovic Stipic S, Carev M, Supe Domic D, et al. (2014). The impact of general anaesthesia for elective adenotonsillectomy in children aged 6-12 years on biomarkers of cerebral injury S100B and NSE. European journal of anaesthesiology.
8382 Stokken J, Gupta A, Krakovitz P, et al. (2014). Rhinosinusitis in children: a comparison of patients requiring surgery for acute complications versus chronic disease. Am J Otolaryngol.
8383 Stowell K, Langton E, Pollock N, et al. (2014). Targeted exon capture and NGS to investigate an undefined myopathy reveal RYR1 variants. BMC Anesthesiology.
8384 Subramanyam R, Chidambaran V, Ding L, et al. (2014). Anesthesia- and opioids-related malpractice claims following tonsillectomy in USA: LexisNexis claims database 1984-2012. Paediatr Anaesth.
8385 Subramanyam R, Varughese A, Kurth CD, et al. (2014). Cost-effectiveness of intravenous acetaminophen for pediatric tonsillectomy. Paediatr Anaesth.
8386 Sujanska A, Durdik P, Rabasco J, et al. (2014). SURGICAL AND NON-SURGICAL THERAPY OF OBSTRUCTIVE SLEEP APNEA SYNDROME IN CHILDREN. Acta Medica (Hradec Kralove).
8387 Sulman CG. (2014). Pediatric sleep surgery. Front Pediatr.
8388 Sutters KA, Isaacson G. (2014). Posttonsillectomy pain in children. Am J Nurs.
8389 Suzuki K, Miura N, Imai H. (2014). Estimated glomerular filtration rate and daily amount of urinary protein predict the clinical remission rate of tonsillectomy plus steroid pulse therapy for IgA nephropathy. Clin Exp Nephrol.
8390 Suzuki Y, Matsuzaki K, Suzuki H, et al. (2014). Serum levels of galactose-deficient immunoglobulin (Ig) A1 and related immune complex are associated with disease activity of IgA nephropathy. Clin Exp Nephrol.
8391 Syed MI, Montague ML. (2014). Re: Response to Magos et al. Clin Otolaryngol.
8392 Tait AR, Voepel-Lewis T, O'Brien LM. (2014). Postsurgical behaviors in children with and without symptoms of sleep-disordered breathing. Perioper Med (Lond).
8393 Tamay Z, Akcay A, Ergin A, et al. (2014). Prevalence of allergic rhinitis and risk factors in 6- to 7-yearold children in Istanbul, Turkey. Turk J Pediatr.
8394 Tan KW, Martin S, Bell G. (2014). Paediatric codeine use after adenotonsillectomy. Anaesthesia.
8395 Tan LT, Tan AK, Hsu PP, et al. (2014). Effects of tonsillectomy on sleep study parameters in adult patients with obstructive sleep apnea--a prospective study. Sleep Breath.
8396 Tan M, Shao C, Bishop JA, et al. (2014). Aquaporin-1 promoter hypermethylation is associated with improved prognosis in salivary gland adenoid cystic carcinoma. Otolaryngol Head Neck Surg.
8397 Tanaka K, Moriyama T, Iwasaki C, et al. (2014). Effect of hematuria on the outcome of IgA nephropathy with mild proteinuria. Clin Exp Nephrol.
8398 Taneja MK, Taneja V. (2014). Drug therapy for otitis media. Indian Journal of Otology.
8399 Tanimoto Y, Fukuyama S, Tanaka N, et al. (2014). Presence of keratin-specific antibody-forming cells in palatine tonsils of patients with pustulosis palmaris et plantaris (PPP) and its correlation with prognosis after tonsillectomy. Acta Otolaryngol.
8400 Tanon-Anoh MJ, Kouassi YM, Yoda M, et al. (2014). Craniofacial modifications in Ivorian melanoderm children with chronic retronasal obstruction. Int J Pediatr Otorhinolaryngol.
8401 Tanzler ED, Amdur RJ, Morris CG, et al. (2014). Challenging the need for random directed biopsies of the nasopharynx, pyriform sinus, and contralateral tonsil in the workup of unknown primary squamous cell carcinoma of the head and neck. Head Neck.
8402 Taylor RJ, Patel MR, Wheless SA, et al. (2014). Endoscopic endonasal approaches to infratemporal fossa tumors: a classification system and case series. Laryngoscope.
8403 Testani E, Scarano E, Leoni C, et al. (2014). Upper airway surgery of obstructive sleep apnea in pycnodysostosis: case report and literature review. Am J Med Genet A.
8404 Tetsuya K, Mitsuhiro Y, Yoichi M, et al. (2014). A multicenter randomized controlled trial of tonsillectomy combined with steroid pulse therapy in patients with iga nephropathy. Nephrology (Carlton, Vic.).
8405 Theilhaber M, Arachchi S, Armstrong DS, et al. (2014). Routine post-operative intensive care is not necessary for children with obstructive sleep apnea at high risk after adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
8406 Thompson LD, Penner C, Ho NJ, et al. (2014). Sinonasal tract and nasopharyngeal adenoid cystic carcinoma: a clinicopathologic and immunophenotypic study of 86 cases. Head Neck Pathol.
8407 Thong G, Davies K, Murphy E, et al. (2014). A prospective cohort study examining the parent reported improvements in health following paediatric adenotonsillectomy. Irish journal of medical science.
8408 Thongyam A, Marcus CL, Lockman JL, et al. (2014). Predictors of perioperative complications in higher risk children after adenotonsillectomy for obstructive sleep apnea: a prospective study. Otolaryngol Head Neck Surg.
8409 Thottam PJ, Bathula SS, Poulik JM, et al. (2014). Complete second branchial cleft anomaly presenting as a fistula and a tonsillar cyst: an interesting congenital anomaly. Ear Nose Throat J.
8410 Tin SS, Wiwanitkit V. (2014). Letter to the Editor regarding ‘honey for reduction of post tonsillectomy pain’. Int J Pediatr Otorhinolaryngol.
8411 Tirelli G, Del Piero GC, Perrino F. (2014). Ultracision Harmonic Scalpel in oral and oropharyngeal cancer resection. J Craniomaxillofac Surg.
8412 Tiwari JP. (2014). Update on the management of IgA nephropathy. Clinical Queries: Nephrology.
8413 Toldo I, Tangari M, Mardari R, et al. (2014). Headache in children with Chiari I malformation. Headache.
8414 Tolisano AM, Bager JM. (2014). Sleep surgery and medical malpractice. Laryngoscope.
8415 Tong Y, Ding XB, Wang X, et al. (2014). Ketamine peritonsillar infiltration during tonsillectomy in pediatric patients: An updated meta-analysis. Int J Pediatr Otorhinolaryngol.
8416 Trafny EA, Olszewska-Sosinska O, Antos-Bielska M, et al. (2014). Carriage of antibiotic-resistant Haemophilus influenzae strains in children undergoing adenotonsillectomy. Int J Med Microbiol.
8417 Truog RD, Miller FG. (2014). Changing the conversation about brain death. Am J Bioeth.
8418 Tsaoussoglou M, Hatzinikolaou S, Baltatzis GE, et al. (2014). Expression of leukotriene biosynthetic enzymes in tonsillar tissue of children with obstructive sleep apnea: a prospective nonrandomized study. JAMA Otolaryngol Head Neck Surg.
8419 Tsimberidou AM, Adamopoulos AM, Ye Y, et al. (2014). Phase I clinical trial of bendamustine and bevacizumab for patients with advanced cancer. J Natl Compr Canc Netw.
8420 Tugrul S, Degirmenci N, Eren SB, et al. (2014). Analgesic effect of magnesium in post-tonsillectomy patients: a prospective randomised clinical trial. European Archives of Oto-rhino-laryngology : Official Journal of the European Federation of Oto-Rhino-Laryngological Societies (EUFOS) : Affiliated with the German Society for Oto-Rhino-Laryngology - Head and Neck Surgery.
8421 Tuzuner A, Demirci S, Akkoc A, et al. (2014). Nasalance scores in pediatric patients after adenoidectomy. Int J Pediatr Otorhinolaryngol.
8422 Ulualp SO. (2014). Modified expansion sphincter pharyngoplasty for treatment of children with obstructive sleep apnea. JAMA Otolaryngol Head Neck Surg.
8423 Urbizu A, Poca MA, Vidal X, et al. (2014). MRI-based morphometric analysis of posterior cranial fossa in the diagnosis of chiari malformation type I. J Neuroimaging.
8424 Uyar M, Kilic SB, Uyar Y, et al. (2014). The place of the helicobacter pylori on the etiopathogenesis of idiopathic recurrent aphthous stomatitis (RAS). Acta Medica Mediterranea.
8425 Uyar M, Tekat A, Koyuncu M, et al. (2014). Validity of acoustic rhinometry in the evaluation of patients with adenoid hypertrophy. J Craniofac Surg.
8426 Valakh V, Miyamoto C, Mazurenka K, et al. (2014). A comparison of outcomes for early oropharyngeal cancers treated with single-modality surgery versus radiotherapy. J Comp Eff Res.
8427 Van Limbergen EJ, Dok R, Laenen A, et al. (2014). HPV-related oropharyngeal cancers in Flanders (Belgium): a multicenter study. B-ENT.
8428 Vanpouille C, Khandazhinskaya A, Karpenko I, et al. (2014). A new antiviral: chimeric 3TC-AZT phosphonate efficiently inhibits HIV-1 in human tissues ex vivo. Antiviral Res.
8429 Varan A, Akyuz C, Atas E, et al. (2014). Salivary gland tumors in children: a retrospective clinical review. Pediatr Hematol Oncol.
8430 Venkatasubramanian R, Fukuda T, Niu J, et al. (2014). ABCC3 and OCT1 genotypes influence pharmacokinetics of morphine in children. Pharmacogenomics.
8431 Vent J, Zimmermann C, Drebber U, et al. (2014). Influence of formalin fixation on tissue dimensions in palatal tonsils. Pathol Res Pract.
8432 Verstegen RH, Driessen GJ, Bartol SJ, et al. (2014). Defective B-cell memory in patients with Down syndrome. J Allergy Clin Immunol.
8433 Vicini C, Montevecchi F, Campanini A, et al. (2014). Clinical outcomes and complications associated with TORS for OSAHS: a benchmark for evaluating an emerging surgical technology in a targeted application for benign disease. ORL J Otorhinolaryngol Relat Spec.
8434 Vidigal TA, Haddad FL, Cabral RF, et al. (2014). New clinical staging for pharyngeal surgery in obstructive sleep apnea patients. Braz J Otorhinolaryngol.
8435 Vieira L, Nissen L, Sela G, et al. (2014). Reducing Postoperative Pain from Tonsillectomy Using Monopolar Electrocautery by Cooling the Oropharynx. International Archives of Otorhinolaryngology.
8436 Vigo G, Martini G, Zoppi S, et al. (2014). Tonsillectomy efficacy in children with PFAPA syndrome is comparable to the standard medical treatment: a long-term observational study. Clin Exp Rheumatol.
8437 Villa MP, Castaldo R, Miano S, et al. (2014). Adenotonsillectomy and orthodontic therapy in pediatric obstructive sleep apnea. Sleep Breath.
8438 Vinuesa D, Parra-Ruiz J, Chueca N, et al. (2014). Protease inhibitor monotherapy is not associated with increased viral replication in lymph nodes. Aids.
8439 von Ungern-Sternberg BS. (2014). Respiratory complications in the pediatric postanesthesia care unit. Anesthesiol Clin.
8440 Vons KM, Bijker JB, Verwijs EW, et al. (2014). Postoperative pain during the first week after adenoidectomy and guillotine adenotonsillectomy in children. Paediatr Anaesth.
8441 Wang L, Cheng H, Li J, et al. (2014). Extranodal follicular dendritic cell sarcoma of the soft palate: a case report. Int J Clin Exp Pathol.
8442 Wang MC, Wang YP, Chu CH, et al. (2014). The protective effect of adenoidectomy on pediatric tympanostomy tube re-insertions: a population-based birth cohort study. PLoS One.
8443 Wang SS, Zhang MZ, Sun Y, et al. (2014). The sedative effects and the attenuation of cardiovascular and arousal responses during anesthesia induction and intubation in pediatric patients: a randomized comparison between two different doses of preoperative intranasal dexmedetomidine. Paediatr Anaesth.
8444 Wang Y, Ichimaru N, Kyo M, et al. (2014). Beneficial effects of tonsillectomy for mesangial immunoglobulin A (IgA) deposition and clinical outcome in five kidney transplant patients with recurrent IgA nephropathy: case report. Transplant Proc.
8445 Wang YP, Wang MC, Lin HC, et al. (2014). The impact of prior tonsillitis and treatment modality on the recurrence of peritonsillar abscess: a nationwide cohort study. PLoS One.
8446 Waters K. (2014). Sleep apnoea in children. Obesity Research and Clinical Practice.
8447 Wentzel JL, Mulligan JK, Soler ZM, et al. (2014). Passive smoke exposure in chronic rhinosinusitis as assessed by hair nicotine. Am J Rhinol Allergy.
8448 Wiggins SA, Freeman JL. (2014). Understanding sleep during adolescence. Pediatr Nurs.
8449 Wood JM, Cho M, Carney AS. (2014). Role of subtotal tonsillectomy ('tonsillotomy') in children with sleep disordered breathing. J Laryngol Otol.
8450 Wootten CT, Chinnadurai S, Goudy SL. (2014). Beyond adenotonsillectomy: outcomes of sleep endoscopy-directed treatments in pediatric obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
8451 Wootton DM, Luo H, Persak SC, et al. (2014). Computational fluid dynamics endpoints to characterize obstructive sleep apnea syndrome in children. J Appl Physiol (1985).
8452 Wu RY, Li YX, Wang WH, et al. (2014). Clinical disparity and favorable prognoses for patients with Waldeyer ring extranodal nasal-type NK/T-cell lymphoma and diffuse large B-cell lymphoma. Am J Clin Oncol.
8453 Wu W, Debbaneh M, Moslehi H, et al. (2014). Tonsillectomy as a treatment for psoriasis: a review. J Dermatolog Treat.
8454 Xiang Z, Yan-Liang Q, Xiao-Yang S, et al. (2014). Effects of promethazine or dexamethasone pretreatment on mivacurium-induced histamine release in children. Paediatr Anaesth.
8455 Yang SI, Geong JH, Kim JY. (2014). Clinical characteristics of primary Epstein Barr virus hepatitis with elevation of alkaline phosphatase and gamma-glutamyltransferase in children. Yonsei Med J.
8456 Yasui T, Morii E, Yamamoto Y, et al. (2014). Human papillomavirus and cystic node metastasis in oropharyngeal cancer and cancer of unknown primary origin. PLoS One.
8457 Yazici H, Soy FK, Kulduk E, et al. (2014). Comparison of nasal mucociliary clearance in adenoid hypertrophy with or without otitis media with effusion. Int J Pediatr Otorhinolaryngol.
8458 Yellon RF, Kenna MA, Cladis FP, et al. (2014). What is the best non-codeine postadenotonsillectomy pain management for children?. Laryngoscope.
8459 Yelnoorkar S, Issing W. (2014). Cervicofacial Surgical Emphysema following Tonsillectomy. Case Rep Otolaryngol.
8460 Yildirim YS, Senturk E, Ozturan O. (2014). Posterior plica perforation: rare complication of adenotonsillectomy. J Craniofac Surg.
8461 Yilmaz MS, Guven M, Akidil O, et al. (2014). Does septoplasty improve the quality of life in children?. Int J Pediatr Otorhinolaryngol.
8462 Yilmaz U, Celegen M, Yilmaz TS, et al. (2014). Childhood headaches and brain magnetic resonance imaging findings. Eur J Paediatr Neurol.
8463 Yoruk O, Alp H, Yuksel S, et al. (2014). DNA damage in children with obstructive adenotonsillar hypertrophy. J Craniofac Surg.
8464 Young D, Collop N. (2014). Advances in the treatment of obstructive sleep apnea. Current Treatment Options in Neurology.
8465 Youngs R, Fisher E. (2014). Bioinformatics, tonsillectomy and visual illusions. J Laryngol Otol.
8466 Zagolski O, Kulisiewicz J. (2014). How do pediatric adenoidectomy and adenotonsillotomy influence maternal psychological status?. Ear Nose Throat J.
8467 Zagolski O, Strek P, Gajda M. (2014). Adult tonsillectomy: anatomical differences affect postoperative transient hypernasality. Folia Phoniatr Logop.
8468 Zaher G, Al-Noury K. (2014). The value of routine preoperative testing in the prediction of operative hemorrhage in adenotonsillectomy. Indian J Otolaryngol Head Neck Surg.
8469 Zainon IH, Salim R, Daud MKM. (2014). Coblation tonsillectomy versus dissection tonsillectomy: A comparison of intraoperative time, intraoperative blood loss and post-operative pain. Medical journal of Malaysia.
8470 Zand L, Fervenza FC. (2014). Does tonsillectomy have a role in the treatment of patients with immunoglobulin A nephropathy?. Nephrol Dial Transplant.
8471 Zhan P, Li G, Liu B, et al. (2014). Bartholin gland carcinoma: A case report. Oncol Lett.
8472 Zhang J, Prizment AE, Dhakal IB, et al. (2014). Cholecystectomy, gallstones, tonsillectomy, and pancreatic cancer risk: a population-based case-control study in Minnesota. Br J Cancer.
8473 Zhang Q, Li D, Wang H. (2014). Long term outcome of tonsillar regrowth after partial tonsillectomy in children with obstructive sleep apnea. Auris Nasus Larynx.
8474 Zhou W, Jiang YM, Wang HJ, et al. (2014). Erythromycin-resistant genes in group A beta-haemolytic Streptococci in Chengdu, Southwestern China. Indian J Med Microbiol.
8475 Zhu J, Fang Y, Chen X, et al. (2014). The impacts of obstructive sleep apnea hypopnea syndrome severity and surgery intervention on psychological and behavioral abnormalities and postoperative recovery in pediatric patients. Med Sci Monit.
8476 Zicari AM, Duse M, Occasi F, et al. (2014). Cephalometric pattern and nasal patency in children with primary snoring: the evidence of a direct correlation. PLoS One.
8477 Zojaji R, Mirzadeh M, Mazloum Farsi Baf M, et al. (2014). The Effect of Adenotonsillectomy on Children's Quality of life. Iran J Otorhinolaryngol.
8478 Aalling M, Klug TE. (2015). Streptococcal toxic shock syndrome complicating a peritonsillar abscess. Infect Dis (Lond).
8479 Abazi B, Shaqiri B, Ajvazi H, et al. (2015). Clinical Impact of Chronic Tonsillitis on Weight and Height Parameters. Med Arch.
8480 Abdel-Aziz M, Khalifa B, Shawky A, et al. (2015). Trans-oral endoscopic partial adenoidectomy does not worsen the speech after cleft palate repair. Braz J Otorhinolaryngol.
8481 Abdullah B, Lazim NM, Salim R. (2015). The effectiveness of Tualang honey in reducing post-tonsillectomy pain. Kulak Burun Bogaz Ihtisas Dergisi : KBB [Journal of Ear, Nose, and Throat].
8482 Abe M, Joh K, Ieiri N, et al. (2015). Prominent hyperplasia of renin-producing juxtaglomerular apparatus after chronic and complete blockade of the renin-angiotensin system in adult IgA nephropathy. CEN Case Reports.
8483 Abulfateh FN, Bedawi F, Janahi W, et al. (2015). Post-tonsillectomy hemorrhage and other complications. Bahrain Medical Bulletin.
8484 Addison AB, Whittaker M, Maddox T, et al. (2015). Tonsillectomy for asymmetrical tonsils, are we over-diagnosing and managing: a review of 157 cases: Our Experience. Clin Otolaryngol.
8485 Agarwal M, Raghuwanshi SK, Asati DP. (2015). Antibiotic Use in Sore Throat: Are We Judicious?. Indian J Otolaryngol Head Neck Surg.
8486 Ahmetasevic D, Ahmetasevic E, Brkic S, et al. (2015). INFLUENCE OF OVERWEIGHT AND OBESITY IN CHILDREN ON ANESTHESIOLOGICAL COMPLICATIONS APPEARANCE DURING ADENOIDECTOMY AND ADENOTONSILLECTOMY. Mater Sociomed.
8487 Akbas A, Tiede C, Lemound J, et al. (2015). Post-transplant lymphoproliferative disorders with naso- and oropharyngeal manifestation. Transpl Int.
8488 Aksu H, Gunel C, Ozgur BG, et al. (2015). Effects of adenoidectomy/adenotonsillectomy on ADHD symptoms and behavioral problems in children. Int J Pediatr Otorhinolaryngol.
8489 Aktas O, Erdur O, Cirik AA, et al. (2015). The role of drug-induced sleep endoscopy in surgical planning for obstructive sleep apnea syndrome. Eur Arch Otorhinolaryngol.
8490 Al Ali A, Richmond S, Popat H, et al. (2015). The influence of snoring, mouth breathing and apnoea on facial morphology in late childhood: a three-dimensional study. BMJ Open.
8491 Alam MM, Ali MI, Habib MA, et al. (2015). Otitis media with effusion in children admitted for adenoidectomy. Mymensingh Med J.
8492 Alkhouri N, Kheirandish-Gozal L, Matloob A, et al. (2015). Evaluation of circulating markers of hepatic apoptosis and inflammation in obese children with and without obstructive sleep apnea. Sleep Med.
8493 Allareddy V, Martinez-Schlurmann N, Rampa S, et al. (2015). Predictors of Complications of Tonsillectomy With or Without Adenoidectomy in Hospitalized Children and Adolescents in the United States, 2001-2010: A Population-Based Study. Clin Pediatr (Phila).
8494 Al-Mayouf S, Alsonbul A. (2015). Monogenic and multifactorial autoinflammatory diseases: Clinical and laboratory characterization in a pediatric Saudi population. Pediatric Rheumatology.
8495 Alonso-Alvarez ML, Teran-Santos J, Navazo-Eguia AI, et al. (2015). Treatment outcomes of obstructive sleep apnoea in obese community-dwelling children: the NANOS study. Eur Respir J.
8496 Altun D, Arslan HH, Umudum H, et al. (2015). Lymphoid papillary hyperplasia of palatine tonsils: A rare pediatric case from Turkey. International Journal of Pediatric Otorhinolaryngology Extra.
8497 Amani S, Abedinzadeh MR. (2015). Effects of Oral Gabapentin, Local Bupivacaine and Intravenous Pethidine on Post Tonsillectomy Pain. Iran J Otorhinolaryngol.
8498 Amani S, Kheiri S, Ahmadi A. (2015). Honey versus diphenhydramine for post-tonsillectomy pain relief in pediatric cases: a randomized clinical trial. J Clin Diagn Res.
8499 Amin R, Sayal P, Sayal A, et al. (2015). The association between sleep-disordered breathing and magnetic resonance imaging findings in a pediatric cohort with Chiari 1 malformation. Can Respir J.
8500 Amiri S, AbdollahiFakhim S, Lotfi A, et al. (2015). Effect of adenotonsillectomy on ADHD symptoms of children with adenotonsillar hypertrophy and sleep disordered breathing. Int J Pediatr Otorhinolaryngol.
8501 Andreu-Ballester JC, Gil-Borras R, Garcia-Ballesteros C, et al. (2015). Epstein-Barr virus is related with 5-aminosalicylic acid, tonsillectomy, and CD19(+) cells in Crohn's disease. World J Gastroenterol.
8502 Anfuso A, Ramadan H, Terrell A, et al. (2015). Sinus and adenoid inflammation in children with chronic rhinosinusitis and asthma. Ann Allergy Asthma Immunol.
8503 Anwar K, Ahmad R, Khan M. (2015). Control of bleeding by silk ligation and diathermy coagulation during tonsillectomy: A comparison of efficacy of the two techniques in the first 24 hours after surgery. Pakistan Journal of Medical Sciences.
8504 Arachchi S, Armstrong DS, Davey MJ, et al. (2015). Clinical outcomes in a high nursing ratio ward setting for children with obstructive sleep apnoea at high risk after adenotonsillectomy. Sleep and Biological Rhythms.
8505 Armstrong AW, Florek AG. (2015). Response to: “Is tonsillectomy a therapeutic option for plaque-type psoriasis?”. J Am Acad Dermatol.
8506 Arn P, Bruce IA, Wraith JE, et al. (2015). Airway-related symptoms and surgeries in patients with mucopolysaccharidosis I. Ann Otol Rhinol Laryngol.
8507 Arnautovic A, Splavski B, Boop FA, et al. (2015). Pediatric and adult Chiari malformation Type I surgical series 1965-2013: a review of demographics, operative treatment, and outcomes. J Neurosurg Pediatr.
8508 Arora R, Saraiya S, Niu X, et al. (2015). Post tonsillectomy hemorrhage: who needs intervention?. Int J Pediatr Otorhinolaryngol.
8509 Arslan F, Babakurban ST, Erbek SS, et al. (2015). Chronic tonsillitis is not associated with beta defensin 1 gene polymorphisms in Turkish population. Int J Pediatr Otorhinolaryngol.
8510 Arunkumar KV, Garg N, Kumar V. (2015). Oversized submandibular gland sialolith: a report of two cases. J Maxillofac Oral Surg.
8511 Atkinson H, Wallis S, Coatesworth AP. (2015). Otitis media with effusion. Postgrad Med.
8512 Aveline C, Le Hetet H, Le Roux A, et al. (2015). A survey of the administration of prednisolone versus ibuprofen analgesic protocols after ambulatory tonsillectomy. Anaesth Crit Care Pain Med.
8513 Awad OG, Hamid KA. (2015). Endoscopic Type 1 Tympanoplasty in Pediatric Patients Using Tragal Cartilage. JAMA Otolaryngol Head Neck Surg.
8514 Badran H, Salah M, Fawzy M, et al. (2015). Detection of Bacterial Biofilms in Chronic Pharyngitis Resistant to Medical Treatment. Ann Otol Rhinol Laryngol.
8515 Baglam T, Binnetoglu A, Yumusakhuylu AC, et al. (2015). Predictive value of the neutrophil-to-lymphocyte ratio in patients with deep neck space infection secondary to acute bacterial tonsillitis. Int J Pediatr Otorhinolaryngol.
8516 Baijal RG, Bidani SA, Minard CG, et al. (2015). Perioperative respiratory complications following awake and deep extubation in children undergoing adenotonsillectomy. Paediatr Anaesth.
8517 Bailey L, Sun J, Courtney M, et al. (2015). Improving postoperative tonsillectomy pain management in children--a double blinded randomised control trial of a patient analgesia information sheet. Int J Pediatr Otorhinolaryngol.
8518 Bailey L, Sun J, Courtney M, et al. (2015). Improving postoperative tonsillectomy pain management in children - A double blinded randomised control trial of a patient analgesia information sheet. International journal of pediatric otorhinolaryngology.
8519 Bakhsh ZA, Al-Khatib TA, Al-Muhayawi SM, et al. (2015). Evaluating the therapeutic efficacy, tolerability, and safety of an aqueous extract of Costus speciosus rhizome in acute pharyngitis and acute tonsillitis. A pilot study. Saudi Med J.
8520 Bakshi SS. (2015). Letter to the Editor. Int J Pediatr Otorhinolaryngol.
8521 Balakrishnan K, Goico B, Arjmand EM. (2015). Applying cost accounting to operating room staffing in otolaryngology: time-driven activity-based costing and outpatient adenotonsillectomy. Otolaryngol Head Neck Surg.
8522 Bameshki SA, Salari MR, Bakhshaee M, et al. (2015). Effect of Ketamine on Post-Tonsillectomy Sedation and Pain Relief. Iran J Otorhinolaryngol.
8523 Bandarkar AN, Adeyiga AO, Fordham MT, et al. (2015). Tonsil ultrasound: technical approach and spectrum of pediatric peritonsillar infections. Pediatr Radiol.
8524 Bang P, Polak M, Woelfle J, et al. (2015). Effectiveness and Safety of rhIGF-1 Therapy in Children: The European Increlex(R) Growth Forum Database Experience. Horm Res Paediatr.
8525 Bao CS, Liu L, Wang B, et al. (2015). Craniocervical decompression with duraplasty and cerebellar tonsillectomy as treatment for Chiari malformation-I complicated with syringomyelia. Genet Mol Res.
8526 Baradaranfar MH, Edalatkhah M, Dadgarnia MH, et al. (2015). The effect of uvulopalatopharyngoplasty with tonsillectomy in patients with obstructive sleep apnea. Indian J Otolaryngol Head Neck Surg.
8527 Barberi S, Ciprandi G, Verduci E, et al. (2015). Effect of high-dose sublingual immunotherapy on respiratory infections in children allergic to house dust mite. Asia Pac Allergy.
8528 Bartlett A, Bola S, Williams R. (2015). Acute tonsillitis and its complications: an overview. J R Nav Med Serv.
8529 Bassell JL, Phan H, Leu R, et al. (2015). Sleep profiles in children with Down syndrome. Am J Med Genet A.
8530 Bast F, Uecker K, Chadha P, et al. (2015). Is there a need for a histological examination of the adenoid tissue after adenoidectomy?. Int J Pediatr Otorhinolaryngol.
8531 Bathala S, Eccles R. (2015). Assessment of upper airway obstruction by measuring peak oral and nasal inspiratory flow. J Laryngol Otol.
8532 Baugh RF. (2015). Ibuprofen with acetaminophen for tonsillectomy pain. Otolaryngol Head Neck Surg.
8533 Baumert M, Pamula Y, Kohler M, et al. (2015). Effect of respiration on heartbeat-evoked potentials during sleep in children with sleep-disordered breathing. Sleep Med.
8534 Bayram A, Dogan M, Cihan C, et al. (2015). The Efficacy of Levobupivacaine Hydrochloride-Dexamethasone Infiltration for Post-Tonsillectomy Pain in Adults. J Craniofac Surg.
8535 Becque T, White IR, Haggard M. (2015). A causal model for longitudinal randomised trials with time-dependent non-compliance. Stat Med.
8536 Bedajit RK, Priyokumar O, Abhilash R, et al. (2015). Eagle syndrome with multiple cranial nerve involvement. JMS - Journal of Medical Society.
8537 Beeton A. (2015). The FLK for tonsillectomy. South African Family Practice.
8538 Belard S, Toepfner N, Arnold B, et al. (2015). beta-Hemolytic streptococcal throat carriage and tonsillopharyngitis: a cross-sectional prevalence study in Gabon, Central Africa. Infection.
8539 Bender B, Blassnigg EC, Bechthold J, et al. (2015). Microdebrider-assisted intracapsular Tonsillectomy in adults with chronic or recurrent tonsillitis. Laryngoscope.
8540 Bentur PM, Veeresh AR. (2015). Evaluation of efficacy of topical bupivacaine for post-tonsillectomy pain relief. Indian Journal of Public Health Research and Development.
8541 Benumof JL. (2015). The elephant in the room is bigger than you think: finding obstructive sleep apnea patients dead in bed postoperatively. Anesth Analg.
8542 Benzon HA, Shah RD, Hansen J, et al. (2015). The Effect of Systemic Magnesium on Postsurgical Pain in Children Undergoing Tonsillectomies: A Double-Blinded, Randomized, Placebo-Controlled Trial. Anesth Analg.
8543 Bergallo M, Gambarino S, Loiacono E, et al. (2015). Evaluation of IFN-gamma polymorphism+874 T/A in patients with recurrent tonsillitis by PCR real time mismatch amplification mutation assay (MAMA real time PCR). Cytokine.
8544 Berger N, Ampanozi G, Schweitzer W, et al. (2015). Racking the brain: detection of cerebral edema on postmortem computed tomography compared with forensic autopsy. Eur J Radiol.
8545 Betancourt AR, Lopez C, Zerpa V, et al. (2015). Does surgical technique influence post-tonsillectomy haemorrhage? Our experience. Acta Otorrinolaringol Esp.
8546 Bhattacharyya N. (2015). Rapid communication: The risk of additional post-tonsillectomy bleeding after the first bleeding episode. Laryngoscope.
8547 Bhattacharyya N. (2015). Healthcare disparities in revisits for complications after adult tonsillectomy. Am J Otolaryngol.
8548 Biezen R, Pollack AJ, Harrison C, et al. (2015). Respiratory tract infections among children younger than 5 years: current management in Australian general practice. Med J Aust.
8549 Bilal JA. (2015). Prevalence and Clinical Characteristics of Primary Epstein-Barr Virus Infection Among Children Presented with Cervical Lymphadenopathy. J Clin Diagn Res.
8550 Bitar MA, Dowli A, Mourad M. (2015). The effect of tonsillectomy on the immune system: A systematic review and meta-analysis. Int J Pediatr Otorhinolaryngol.
8551 Bjork H, Bieber L, Hedin K, et al. (2015). Tonsillar colonisation of Fusobacterium necrophorum in patients subjected to tonsillectomy. BMC Infect Dis.
8552 Blair AB, Booth R, Baugh R. (2015). A unifying theory of tonsillitis, intratonsillar abscess and peritonsillar abscess. Am J Otolaryngol.
8553 Bola S, Bartlett A, Williams R. (2015). Perioperative dexamethasone administration in tonsillectomy patients: A three-cycle audit showing improvement using printed theatre lists. BMJ Qual Improv Rep.
8554 Bond AE, Jane JA, Liu KC, et al. (2015). Changes in cerebrospinal fluid flow assessed using intraoperative MRI during posterior fossa decompression for Chiari malformation. J Neurosurg.
8555 Borhan WM, Dababo MA, Thompson LD, et al. (2015). Acute necrotizing herpetic tonsillitis: a report of two cases. Head Neck Pathol.
8556 Boss EF, Benke JR, Tunkel DE, et al. (2015). Public insurance and timing of polysomnography and surgical care for children with sleep-disordered breathing. JAMA Otolaryngol Head Neck Surg.
8557 Bovo R, Barillari MR, Martini A. (2015). Hospital discharge survey on 4,199 peritonsillar abscesses in the Veneto region: what is the risk of recurrence and complications without tonsillectomy?. Eur Arch Otorhinolaryngol.
8558 Bowles PF, Moore A, Dezoysa N, et al. (2015). A service evaluation of HDU related adenotonsillectomy cancellations in one hundred and sixty-nine children at a University Teaching Hospital. Clin Otolaryngol.
8559 Bozic B, Bajcetic M. (2015). Use of antibiotics in paediatric primary care settings in Serbia. Arch Dis Child.
8560 Brierley D, Green D, Speight PM. (2015). Cribriform adenocarcinoma of the minor salivary glands arising in the epiglottis-a previously undocumented occurrence. Oral Surg Oral Med Oral Pathol Oral Radiol.
8561 Brierley D, Green D, Speight PM. (2015). Cribriform adenocarcinoma of the minor salivary glands arising in the epiglottis--a previously undocumented occurrence. Oral Surg Oral Med Oral Pathol Oral Radiol.
8562 Brietzke SE, Pusz MD. (2015). An anatomically based analysis of objectively measured pediatric snoring: a pilot study. Otolaryngol Head Neck Surg.
8563 Brockmann PE. (2015). Cardiovascular Consequences in Children with Obstructive Sleep Apnea: Is It Possible to Predict Them?. Sleep.
8564 Broderick L, Carvalho D, Magit A, et al. (2015). Long-term outcomes of tonsillectomy in children with periodic fever, aphthous stomatitis, pharyngitis, adenitis (PFAPA) syndrome. Pediatric Rheumatology.
8565 Broderick L, Carvalho D, Magit A, et al. (2015). Immune dysregulation in periodic fever, aphthous atomatitis, pharyngitis, adenitis (PFAPA) syndrome. Pediatric Rheumatology.
8566 Brodsky JR, Cunningham MJ. (2015). Letter to the Editor regarding “Tonsillectomy versus Tonsillotomy: A Study of Parental Preference”. Int J Pediatr Otorhinolaryngol.
8567 Brooks LJ, Olsen MN, Bacevice AM, et al. (2015). Relationship between sleep, sleep apnea, and neuropsychological function in children with Down syndrome. Sleep Breath.
8568 Browaldh N, Bring J, Friberg D. (2015). SKUP RCT; continuous study: Changes in sleepiness and quality of life after modified UPPP. Laryngoscope.
8569 Bueno Dde A, Grechi TH, Trawitzki LV, et al. (2015). Muscular and functional changes following adenotonsillectomy in children. Int J Pediatr Otorhinolaryngol.
8570 Cadd B, Rogers M, Patel H, et al. (2015). (Ton)silly seasons? Do atmospheric conditions actually affect post-tonsillectomy secondary haemorrhage rates?. J Laryngol Otol.
8571 Cakar Turhan KS, Salviz EA, Beton S, et al. (2015). Peritonsillar infiltration with levobupivacaine for posttonsillectomy pain relief: does concentration have any effect? A double-blind randomized controlled clinical study. Eur Rev Med Pharmacol Sci.
8572 Calandrelli R, D'Apolito G, Marco P, et al. (2015). Costello syndrome: Analysis of the posterior cranial fossa in children with posterior fossa crowding. Neuroradiol J.
8573 Camacho M, Certal V, Abdullatif J, et al. (2015). Myofunctional Therapy to Treat Obstructive Sleep Apnea: A Systematic Review and Meta-analysis. Sleep.
8574 Cantone E, Cavaliere M, Castagna G, et al. (2015). Operative Management of OSAS in a Complex Case of Proteus Syndrome. Case Rep Otolaryngol.
8575 Cantore S, Ballini A, Farronato D, et al. (2015). Evaluation of an oral appliance in patients with mild to moderate obstructive sleep apnea syndrome intolerant to continuous positive airway pressure use: Preliminary results. Int J Immunopathol Pharmacol.
8576 Casas L, Espinosa A, Borras-Santos A, et al. (2015). Domestic use of bleach and infections in children: a multicentre cross-sectional study. Occup Environ Med.
8577 Cattalini M, Soliani M, Rigante D, et al. (2015). Basic Characteristics of Adults with Periodic Fever, Aphthous Stomatitis, Pharyngitis, and Adenopathy Syndrome in Comparison with the Typical Pediatric Expression of Disease. Mediators Inflamm.
8578 Certal V, Silva H, Carvalho C, et al. (2015). Model for prediction of pediatric OSA: Proposal for a clinical decision rule. Laryngoscope.
8579 Chan CC, Au CT, Lam HS, et al. (2015). Intranasal corticosteroids for mild childhood obstructive sleep apnea--a randomized, placebo-controlled study. Sleep Med.
8580 Chan KC, Au CT, Chook P, et al. (2015). Endothelial function in children with OSA and the effects of adenotonsillectomy. Chest.
8581 Chang LY, Lai CC, Chen CJ, et al. (2015). Recent trends in prescribing antibiotics for acute tonsillitis in pediatric ambulatory care in Taiwan, 2000-2009: A nationwide population-based study. J Microbiol Immunol Infect.
8582 Channir HI, Rubek N, Nielsen HU, et al. (2015). Transoral robotic surgery for the management of head and neck squamous cell carcinoma of unknown primary. Acta Otolaryngol.
8583 Chaturvedi AK. (2015). Tonsillectomy and Risk of Oropharyngeal Cancer: Implications for Research and Prevention. Cancer Prev Res (Phila).
8584 Chawla J, Waters KA. (2015). Snoring in children. J Paediatr Child Health.
8585 Chen HX, Lai CH, Hsu HY, et al. (2015). The bacterial interactions in the nasopharynx of children receiving adenoidectomy. Biomedicine (Taipei).
8586 Chen X, Zhang L, Wang J, et al. (2015). Complete response after chemotherapy and radiotherapy of a tonsillar histiocytic sarcoma with regional lymph node involvement: A case report and review of the literature. International Journal of Clinical and Experimental Medicine.
8587 Cheong JP, Chong AW, Mun KS. (2015). Bilateral intratonsillar abscesses: A first case report in an adult patient. Journal of Emergency Medicine, Trauma and Acute Care.
8588 Cherko M, Goswami T, Ghufoor K. (2015). A prospective observational study of 50 paediatric suction diathermy adenoidectomy cases to determine the potential safety of a two hour discharge time. Clin Otolaryngol.
8589 Chiesa S, Caorsi R, Ingrosso I, et al. (2015). Recruitment of abundant NK cells to the PFAPA tonsils support the crucial role of innate immunity in pathogenesis of PFAPA syndrome. Pediatric Rheumatology.
8590 Chisholm K, Bhatt A, Freemman S, et al. (2015). In search of human proteins and infectious triggers involved in periodic fever, aphthous stomatitis, pharyngitis and adenitis syndrome. Pediatric Rheumatology.
8591 Cho JH, Suh JD, Kim YW, et al. (2015). Reduction in oxidative stress biomarkers after adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
8592 Choi J, Kim H, Jeon YS, et al. (2015). Anaphylaxis following atropine administration during general anesthesia-a case report. Korean Journal of Anesthesiology.
8593 Choi JH, Oh JI, Kim TM, et al. (2015). Long-term Subjective and Objective Outcomes of Adenotonsillectomy in Korean Children With Obstructive Sleep Apnea Syndrome. Clin Exp Otorhinolaryngol.
8594 Choi JH, Yoon HC, Kim TM, et al. (2015). The immediate effect of adenotonsillectomy on Eustachian tube function in children. Int J Pediatr Otorhinolaryngol.
8595 Choi JS, Lee BJ, Park HY, et al. (2015). Effects of donor age, long-term passage culture, and cryopreservation on tonsil-derived mesenchymal stem cells. Cell Physiol Biochem.
8596 Chow W, Rotenberg BW. (2015). Discontinuing routine histopathological analysis after adult tonsillectomy for benign indication. Laryngoscope.
8597 Chuang CM, Chan IC, Lee YS, et al. (2015). Role of Pediatricians in the Ambulatory Care of Children in Taiwan, 1999-2011. Pediatr Neonatol.
8598 Cinici E, Tatar A. (2015). Thickness alterations of retinal nerve fiber layer in children with sleep-disordered breathing due to adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
8599 Ciorba C, Gonzalez M, Cabello M, et al. (2015). Central apneas in childhood's obstructive sleep apnea syndrome. Somnologie.
8600 Cohen JE, Gomori JM, Itshayek E. (2015). Endovascular Treatment of Tonsillar Artery Pseudoaneurysm Causing Recurrent Hemorrhages after Tonsillectomy. Isr Med Assoc J.
8601 Colavita L, Miraglia Del, Giudice M, Stroscio G, et al. (2015). ALLERGIC RHINITIS AND ADENOID HYPERTROPHY IN CHILDREN: IS ADENOIDECTOMY ALWAYS REALLY USEFUL?. J Biol Regul Homeost Agents.
8602 Coll G, Arnaud E, Collet C, et al. (2015). Skull base morphology in fibroblast growth factor receptor type 2-related faciocraniosynostosis: a descriptive analysis. Neurosurgery.
8603 Com G, Carroll JL, Tang X, et al. (2015). Characteristics and surgical and clinical outcomes of severely obese children with obstructive sleep apnea. J Clin Sleep Med.
8604 Cook DA, Moses PA, Mackie JT. (2015). Clinical effects of the use of a bipolar vessel sealing device for soft palate resection and tonsillectomy in dogs, with histological assessment of resected tonsillar tissue. Aust Vet J.
8605 Coppo R. (2015). The intestine-renal connection in IgA nephropathy. Nephrol Dial Transplant.
8606 Cote CJ. (2015). Anesthesiological considerations for children with obstructive sleep apnea. Curr Opin Anaesthesiol.
8607 Cote V, Ruiz AG, Perkins J, et al. (2015). Characteristics of children under 2 years of age undergoing tonsillectomy for upper airway obstruction. Int J Pediatr Otorhinolaryngol.
8608 Coussens S, Chatburn A, Cava M, et al. (2015). EEG spectral changes associated with spontaneous arousals in nrem sleep in children with upper airway obstruction before and after adenotonsillectomy. Sleep and Biological Rhythms.
8609 Creighton FX, Bhattacharyya N. (2015). Does septoplasty performed at the same time as oropharyngeal surgery increase complication rates?. Laryngoscope.
8610 Cunningham LC, Chio EG. (2015). Comparison of outcomes and cost in patients undergoing tonsillectomy with electrocautery and thermal welding. American Journal of Otolaryngology - Head and Neck Medicine and Surgery.
8611 Curtis JL, Harvey DB, Willie S, et al. (2015). Causes and costs for ED visits after pediatric adenotonsillectomy. Otolaryngol Head Neck Surg.
8612 Daar G, Sari K, Gencer ZK, et al. (2015). The relation between childhood obesity and adenotonsillar hypertrophy. Eur Arch Otorhinolaryngol.
8613 Dale OT, Aleksic T, Shah KA, et al. (2015). IGF-1R expression is associated with HPV-negative status and adverse survival in head and neck squamous cell cancer. Carcinogenesis.
8614 Dalesio NM, McMichael DH, Benke JR, et al. (2015). Are nocturnal hypoxemia and hypercapnia associated with desaturation immediately after adenotonsillectomy?. Paediatr Anaesth.
8615 Danino JF, Taylor T, Metcalfe CW, et al. (2015). Readmission rates and financial penalties after ear, nose and throat surgery: how can we improve?. Br J Hosp Med (Lond).
8616 Das B, Ahmed SM, Raza N. (2015). Nasotracheal intubation with MacGrath videolaryngoscope using Schroeder directional stylet: Case series. Journal of Anaesthesiology Clinical Pharmacology.
8617 Dawe N, Erskine S, Moor JW. (2015). The application and value of the ‘T-14 tool’ as a patient-reported outcome measure for paediatric tonsillectomy: a report on 45 cases. Clin Otolaryngol.
8618 De Luca Canto G, Pacheco-Pereira C, Aydinoz S, et al. (2015). Adenotonsillectomy Complications: A Meta-analysis. Pediatrics.
8619 De Pieri C, Vuch J, De Martino E, et al. (2015). Genetic profiling of autoinflammatory disorders in patients with periodic fever: A prospective study. Pediatric Rheumatology.
8620 de Sousa Caixeta JA, Saramago AM, de Cacia Pradella-Hallinan ML, et al. (2015). Waist-to-height ratio distinguish obstructive sleep apnea from primary snoring in obese children. Sleep Breath.
8621 Dekker AR, Verheij TJ, van der Velden AW. (2015). Inappropriate antibiotic prescription for respiratory tract indications: most prominent in adult patients. Fam Pract.
8622 Demesh D, Virbalas JM, Bent JP. (2015). The role of tonsillectomy in the treatment of pediatric autoimmune neuropsychiatric disorders associated with streptococcal infections (PANDAS). JAMA Otolaryngol Head Neck Surg.
8623 Demirbilek N, Evren C, Altun U. (2015). Postadenoidectomy hemorrhage: How we do it?. International Journal of Clinical and Experimental Medicine.
8624 Deng M, Hui SC, Yu FW, et al. (2015). MRI-based morphological evidence of spinal cord tethering predicts curve progression in adolescent idiopathic scoliosis. Spine J.
8625 Deng X, Yang C, Gan J, et al. (2015). Long-Term Outcomes After Small-Bone-Window Posterior Fossa Decompression and Duraplasty in Adults with Chiari Malformation Type I. World Neurosurg.
8626 Derkay CS, Baydoun HA, Stone L. (2015). Intraoperative Use of QuikClot During Adenotonsillectomy: A Prospective Pediatric Trial. Ann Otol Rhinol Laryngol.
8627 Dhaeze T, Peelen E, Hombrouck A, et al. (2015). Circulating Follicular Regulatory T Cells Are Defective in Multiple Sclerosis. J Immunol.
8628 Di Carlo G, Polimeni A, Melsen B, et al. (2015). The relationship between upper airways and craniofacial morphology studied in 3D. A CBCT study. Orthod Craniofac Res.
8629 Di Pierro F, Di Pasquale D, Di Cicco M. (2015). Oral use of Streptococcus salivarius K12 in children with secretory otitis media: preliminary results of a pilot, uncontrolled study. Int J Gen Med.
8630 Diep B, Wang A, Kun S, et al. (2015). Diaphragm Pacing without Tracheostomy in Congenital Central Hypoventilation Syndrome Patients. Respiration.
8631 Diouf JS, Ngom PI, Fadiga MS, et al. (2015). Influence of tonsil size on sagittal cephalometric measurements. Int Orthod.
8632 Diouf JS, Ngom PI, Sonko O, et al. (2015). Influence of tonsillar grade on the dental arch measurements. Am J Orthod Dentofacial Orthop.
8633 Doganer YC, Rohrer JE, Aydogan U, et al. (2015). Tonsillectomy, adenoidectomy and adenotonsillectomy rates in school-aged children: Relative contributions of socio-demographic and clinical features. Int J Pediatr Otorhinolaryngol.
8634 Donnelly O, Youngstein T, Pepper R, et al. (2015). Adult PFAPA-a single centre experience. Pediatric Rheumatology.
8635 Dratva J, Caviezel S, Schaffner E, et al. (2015). Infectious diseases are associated with carotid intima media thickness in adolescence. Atherosclerosis.
8636 D'Souza JN, Schmidt RJ, Xie L, et al. (2015). Postoperative nonsteroidal anti-inflammatory drugs and risk of bleeding in pediatric intracapsular tonsillectomy. Int J Pediatr Otorhinolaryngol.
8637 D'Souza JN, Schmidt RJ, Xie L, et al. (2015). Response to Letter to the Editor regarding “Postoperative nonsteroidal anti-inflammatory drugs and risk of bleeding in pediatric intracapsular tonsillectomy”. Int J Pediatr Otorhinolaryngol.
8638 Dualibi AP, Martins AM, Moreira GA, et al. (2015). The impact of laronidase treatment in otolaryngological manifestations of patients with mucopolysaccharidosis. Braz J Otorhinolaryngol.
8639 Duarte VM, McGrath CL, Shapiro NL, et al. (2015). Healthcare costs of acute and chronic tonsillar conditions in the pediatric population in the United States. Int J Pediatr Otorhinolaryngol.
8640 Dutta M, Roy S, Ghatak S. (2015). Naso-oropharyngeal choristoma (hairy polyps): an overview and current update on presentation, management, origin and related controversies. Eur Arch Otorhinolaryngol.
8641 Dvorackova J, Bielnikova H, Kukutschova J, et al. (2015). Detection of nano- and micro-sized particles in routine biopsy material - pilot study. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub.
8642 Dybkaer K, Bogsted M, Falgreen S, et al. (2015). Diffuse large B-cell lymphoma classification system that associates normal B-cell subset phenotypes with prognosis. J Clin Oncol.
8643 El-Anwar MW, Mostafa K, Abd-Elsamad A. (2015). Levobupivacaine alone versus levobupivacaine plus magnesium infiltration for post-tonsillectomy analgesia. International Journal of Pharmacology.
8644 Elbassiouny AM. (2015). Soft palatal webbing flap palatopharyngoplasty for both soft palatal and oropharyngeal lateral wall collapse in the treatment of snoring and obstructive sleep apnea: a new innovative technique without tonsillectomy. Sleep Breath.
8645 Elicora SS, Ozturk M, Sevinc R, et al. (2015). Risk factors for otitis media effusion in children who have adenoid hypertrophia. Int J Pediatr Otorhinolaryngol.
8646 Emaneini M, Khoramrooz SS, Shahsavan S, et al. (2015). Prevalence of Panton-Valentine leucocidin and phenotypic and genotypic characterization of biofilm formation among Staphylococcus aureus strains isolated from children with adenoid hypertrophy. Microb Pathog.
8647 Eneh A, Parsa K, Wright KW, et al. (2015). Pediatric adenoid cystic carcinoma of the lacrimal gland treated with intra-arterial cytoreductive chemotherapy. J AAPOS.
8648 Erdim I, Akcay T, Yilmazer R, et al. (2015). Is Metabolic Syndrome Associated With Obstructive Sleep Apnea in Obese Adolescents?. J Clin Sleep Med.
8649 Erdogan F, Kulak K, Ozturk O, et al. (2015). Surgery vs medical treatment in the management of PFAPA syndrome: a comparative trial. Paediatr Int Child Health.
8650 Ericsson E, Brattwall M, Lundeberg S. (2015). Swedish guidelines for the treatment of pain in tonsil surgery in pediatric patients up to 18 years. Int J Pediatr Otorhinolaryngol.
8651 Escarra F, Vidaurreta SM. (2015). Assessment of quality of life before and after an adenotonsillectomy among children with hypertrophic tonsils and/or adenoids. Arch Argent Pediatr.
8652 Esteller E, Mulas D, Haspert R, et al. (2015). Drug-induced sleep-endoscopy in children's sleep related breathing disorders. Acta Otorrinolaringol Esp.
8653 Evcimik MF, Dogru M, Cirik AA, et al. (2015). Adenoid hypertrophy in children with allergic disease and influential factors. Int J Pediatr Otorhinolaryngol.
8654 Fakhry C, Andersen KK, Christensen J, et al. (2015). The Impact of Tonsillectomy upon the Risk of Oropharyngeal Carcinoma Diagnosis and Prognosis in the Danish Cancer Registry. Cancer Prev Res (Phila).
8655 Faria Junior NS, Oliveira LV, Perez EA, et al. (2015). Observational study of sleep, respiratory mechanics and quality of life in patients with non-cystic fibrosis bronchiectasis: a protocol study. BMJ Open.
8656 Feng HW, Jiang T, Zhang HP, et al. (2015). Comparisons of thyroid hormone, intelligence, attention, and quality of life in children with obstructive sleep apnea hypopnea syndrome before and after endoscopic adenoidectomy. Biomed Res Int.
8657 Feng HW, Tian YD, Zhang HP, et al. (2015). Bone Age and Serum Osteocalcin Levels in Children With Obstructive Sleep Apnea Hypopnea Syndrome Before and After Adenotonsillectomy. Am J Ther.
8658 Feng X, Li G, Qu Z, et al. (2015). Comparative analysis of upper airway volume with lateral cephalograms and cone-beam computed tomography. Am J Orthod Dentofacial Orthop.
8659 Fischer L, Ludin SM, Puente de la Vega K, et al. (2015). Neuralgia of the glossopharyngeal nerve in a patient with posttonsillectomy scarring: recovery after local infiltration of procaine-case report and pathophysiologic discussion. Case Rep Neurol Med.
8660 Fitzgerald C, Oosthuizen JC, Colreavy M. (2015). Paediatric tonsillotomy--an Irish perspective on potential evolving indications. Ir Med J.
8661 Foppoli M, Ferreri AJ. (2015). Gamma-delta t-cell lymphomas. Eur J Haematol.
8662 Formanek M, Kominek P, Matousek P, et al. (2015). Comparison of Three Methods Used in the Diagnosis of Extraesophageal Reflux in Children with Chronic Otitis Media with Effusion. Gastroenterol Res Pract.
8663 Forsvoll J, Janssen EAM, Moller I, et al. (2015). Reduced Number of CD8+ Cells in Tonsillar Germinal Centres in Children with the Periodic Fever, Aphthous Stomatitis, Pharyngitis and Cervical Adenitis Syndrome. Scandinavian Journal of Immunology.
8664 Franceschi S, Combes JD, Dalstein V, et al. (2015). Deep brush-based cytology in tonsils resected for benign diseases. Int J Cancer.
8665 Franco LP, Souki BQ, Cheib PL, et al. (2015). Are distinct etiologies of upper airway obstruction in mouth-breathing children associated with different cephalometric patterns?. Int J Pediatr Otorhinolaryngol.
8666 Friberg D, Lundkvist K, Li X, et al. (2015). Parental poverty and occupation as risk factors for pediatric sleep-disordered breathing. Sleep Med.
8667 Friedman M, Hwang MS. (2015). Evaluation of the patient with obstructive sleep apnea: Friedman tongue position and staging. Operative Techniques in Otolaryngology - Head and Neck Surgery.
8668 Friedman M, Hwang MS. (2015). Z-palatopharyngoplasty. Operative Techniques in Otolaryngology - Head and Neck Surgery.
8669 Friedman NR, Prager JD, Ruiz AG, et al. (2015). A Pediatric Grading Scale for Lingual Tonsil Hypertrophy. Otolaryngol Head Neck Surg.
8670 Friedrichsdorf SJ, Postier AC, Foster LP, et al. (2015). Tramadol versus codeine/acetaminophen after pediatric tonsillectomy: A prospective, double-blinded, randomized controlled trial. J Opioid Manag.
8671 Galluzzi F, Pignataro L, Gaini RM, et al. (2015). Drug induced sleep endoscopy in the decision-making process of children with obstructive sleep apnea. Sleep Med.
8672 Gan RW, Kamani T, Wilkinson S, et al. (2015). Day-case adenotonsillectomy for sleep apnoea in children?. Int J Pediatr Otorhinolaryngol.
8673 Garcia Callejo FJ, Rincon Piedrahita I, Monzo Gandia R, et al. (2015). Factors related to post-tonsillectomy pain in adults. Acta Otorrinolaringol Esp.
8674 Garcia-Romo GS, Gonzalez-Ibarra M, Donis-Hernandez FR, et al. (2015). Immunization with heat-inactivated Staphylococcus aureus induced an antibody response mediated by IgG1 and IgG2 in patients with recurrent tonsillitis. Microbiol Immunol.
8675 Garcia-Vera C, de Dios Javierre B, Castan Larraz B, et al. (2015). Scarlet fever: A not so typical exanthematous pharyngotonsillitis (based on 171 cases). Enferm Infecc Microbiol Clin.
8676 Garg R, Rusciolelli C, Gerber ME. (2015). An adolescent girl with Crohn's disease, fever, and sore throat. Pediatr Ann.
8677 Gay JC, Agrawal R, Auger KA, et al. (2015). Rates and impact of potentially preventable readmissions at children's hospitals. J Pediatr.
8678 Geelan-Hansen K, Anne S. (2015). Otolaryngologic manifestations of Noonan syndrome. Ear Nose Throat J.
8679 Germain C, Guillaudeux T, Galsgaard ED, et al. (2015). Lectin-like transcript 1 is a marker of germinal center-derived B-cell non-Hodgkin's lymphomas dampening natural killer cell functions. OncoImmunology.
8680 Giannasi LC, Santos IR, Alfaya TA, et al. (2015). Effect of a rapid maxillary expansion on snoring and sleep in children: a pilot study. Cranio.
8681 Gilbey P, Bretler S, Avraham Y, et al. (2015). Acupuncture for posttonsillectomy pain in children: a randomized, controlled study. Paediatr Anaesth.
8682 Gilbey P, Livshits L, Sharabi-Nov A, et al. (2015). Probiotics in addition to antibiotics for the treatment of acute tonsillitis: a randomized, placebo-controlled study. Eur J Clin Microbiol Infect Dis.
8683 Gileles-Hillel A, Philby MF, Lapping-Carr G. (2015). Insights into Selected Aspects of Pediatric Sleep Medicine. Am J Respir Crit Care Med.
8684 Giordano L, Toma S, Palonta F, et al. (2015). Obstructive sleep apnea in Prader-Willi syndrome: risks and advantages of adenotonsillectomy. Pediatr Med Chir.
8685 Gisselsson-Solen M. (2015). Acute otitis media in children-current treatment and prevention. Curr Infect Dis Rep.
8686 Glenn C, Cheema AA, Safavi-Abbasi S, et al. (2015). Spinal cord detethering in children with tethered cord syndrome and Chiari type 1 malformations. J Clin Neurosci.
8687 Go H, Jang JY, Kim PJ, et al. (2015). MicroRNA-21 plays an oncogenic role by targeting FOXO1 and activating the PI3K/AKT pathway in diffuse large B-cell lymphoma. Oncotarget.
8688 Godai K. (2015). Carbon monoxide has antinociceptive effects in rodent models of pain. Paediatr Anaesth.
8689 Goel A. (2015). Can foramen magnum decompression surgery become historical?. Journal of Craniovertebral Junction and Spine.
8690 Golbin D, Musgrave B, Succar E, et al. (2015). Clinical analysis of drug-induced sleep endoscopy for the OSA patient. Laryngoscope.
8691 Goldbart AD. (2015). Sleep medicine. Curr Opin Pediatr.
8692 Gopalakaje S, Pandit C, Seton C, et al. (2015). Spectrum of sleep disordered breathing in joubert syndrome. Sleep and Biological Rhythms.
8693 Gorodzinsky AY, Hong P, Chorney JM. (2015). Parental knowledge in pediatric otolaryngology surgical consultations: A qualitative content analysis. Int J Pediatr Otorhinolaryngol.
8694 Gratacap M, Couloigner V, Boulouis G, et al. (2015). Embolization in the management of recurrent secondary post-tonsillectomy haemorrhage in children. Eur Radiol.
8695 Grounds R, Al-Hussaini A, Owens D. (2015). Predicting operative duration and implications for list planning: a retrospective analysis of data from 85 adults and 72 children undergoing tonsillectomy. Clin Otolaryngol.
8696 Grounds R, Al-Hussaini A, Owens D. (2015). Predicting operative duration and implications for list planning: a retrospective analysis of data from 85 adults and 72 children undergoing tonsillectomy: Our Experience. Clin Otolaryngol.
8697 Gu M, Yang Y, Ho AC, et al. (2015). Craniofacial characteristics related to daytime sleepiness screened by the paediatric daytime sleepiness scale. Open Dent J.
8698 Gunel C, Kirdar S, Omurlu IK, et al. (2015). Detection of the Epstein-Barr virus, Human Bocavirus and novel KI and KU polyomaviruses in adenotonsillar tissues. Int J Pediatr Otorhinolaryngol.
8699 Gurbuz MS, Karaaslan N, Caliskan T, et al. (2015). Comparison of the Surgical Results for Foramen Magnum Decompression with and without Duraplasty in Chiari Malformation Type 1. Turk Neurosurg.
8700 Gut G, Tauman R, Greenfeld M, et al. (2015). Nasal nitric oxide in sleep-disordered breathing in children. Sleep Breath.
8701 Gwanmesia I, Jeelani O, Hayward R, et al. (2015). Frontofacial advancement by distraction osteogenesis: a long-term review. Plast Reconstr Surg.
8702 Hadi BA, Sbeitan SM. (2015). Clinical pharmacy intervention post tonsillectomy: a randomized control trial. Int J Clin Pharm.
8703 Hadi SM, Saleh AJ, Tang YZ, et al. (2015). The effect of KETODEX on the incidence and severity of emergence agitation in children undergoing adenotonsillectomy using sevoflurane based-anesthesia. Int J Pediatr Otorhinolaryngol.
8704 Haighton C, Wilson J. (2015). Tonsillectomy or adenotonsillectomy reduces the number of sore throats in children; however, insufficient information is available on the effectiveness in adults. Evid Based Med.
8705 Hajji F, Beraud G, Genay A, et al. (2015). Extensive Inflammatory Gingival Tumor in a Young Nonsmoking Woman: Back to Basics. J Craniofac Surg.
8706 Hamada M, Iida M, Nota J, et al. (2015). Safety and efficacy of adenotonsillectomy for obstructive sleep apnea in infants, toddlers and preschool children. Auris Nasus Larynx.
8707 Hanci D, Altun H. (2015). Effectiveness of hyaluronic acid in post-tonsillectomy pain relief and wound healing: a prospective, double-blind, controlled clinical study. International Journal of Pediatric Otorhinolaryngology.
8708 Harada A, Miya F, Utsunomiya H, et al. (2015). Sudden death in a case of megalencephaly capillary malformation associated with a de novo mutation in AKT3. Childs Nerv Syst.
8709 Hardman J, Muzaffar J, Nankivell P, et al. (2015). Tympanoplasty for Chronic Tympanic Membrane Perforation in Children: Systematic Review and Meta-analysis. Otol Neurotol.
8710 Harley E. (2015). Ibuprofen and acetaminophen for posttonsillectomy pain. Otolaryngol Head Neck Surg.
8711 Harper P, Rawling L, Brown Z. (2015). Update on ENT anaesthesia. Anaesthesia and Intensive Care Medicine.
8712 Harreld JH, Mohammed N, Goldsberry G, et al. (2015). Postoperative intraspinal subdural collections after pediatric posterior fossa tumor resection: incidence, imaging, and clinical features. AJNR Am J Neuroradiol.
8713 Harvey R. (2015). Editorial. J Laryngol Otol.
8714 Hauber JA, Davis PJ, Bendel LP, et al. (2015). Dexmedetomidine as a Rapid Bolus for Treatment and Prophylactic Prevention of Emergence Agitation in Anesthetized Children. Anesth Analg.
8715 Haytoglu S, Arikan OK, Muluk NB, et al. (2015). Relief of pain at rest and during swallowing after modified cautery-assisted uvulopalatopharyngoplasty: bupivacaine versus lidocaine. J Craniofac Surg.
8716 Heidemann CH, Lauridsen HH, Kjeldsen AD, et al. (2015). Quality-of-Life Differences among Diagnostic Subgroups of Children Receiving Ventilating Tubes for Otitis Media. Otolaryngol Head Neck Surg.
8717 Helvaci MR, Gokce C, Davran R, et al. (2015). Tonsilectomy in sickle cell diseases. International Journal of Clinical and Experimental Medicine.
8718 Henatsch D, Wesseling F, Kross KW, et al. (2015). Honey and Beehive Products in Otorhinolaryngology: a narrative review. Clin Otolaryngol.
8719 Hendry J, Chin A, Swan I, et al. (2015). The Glasgow Benefit Inventory: A systematic review of the use and value of an otorhinolaryngological generic Patient Recorded Outcome Measure [PROM]. Clin Otolaryngol.
8720 Herman JH. (2015). Attention deficit/hyperactivity disorder and sleep in children. Sleep Medicine Clinics.
8721 Hirano K, Amano H, Kawamura T, et al. (2015). Tonsillectomy reduces recurrence of IgA nephropathy in mesangial hypercellularity type categorized by the Oxford classification. Clin Exp Nephrol.
8722 Hobson A, Wiffen PJ, Conlon JA. (2015). As required versus fixed schedule analgesic administration for postoperative pain in children. Cochrane Database Syst Rev.
8723 Hodgins N, Hoo C, McGee P, et al. (2015). A survey of assessment and management of velopharyngeal incompetence (VPI) in the UK and Ireland. J Plast Reconstr Aesthet Surg.
8724 Hoff PT, D'Agostino MA, Thaler ER. (2015). Transoral robotic surgery in benign diseases including obstructive sleep apnea: Safety and feasibility. Laryngoscope.
8725 Holznagel E, Yutzy B, Kruip C, et al. (2015). Foodborne-Transmitted Prions From the Brain of Cows With Bovine Spongiform Encephalopathy Ascend in Afferent Neurons to the Simian Central Nervous System and Spread to Tonsils and Spleen at a Late Stage of the Incubation Period. J Infect Dis.
8726 Honarmand A, Safavi M, Naghibi K, et al. (2015). Preemptive peritonsillar infiltration with bupivacaine in combination with tramadol improves pediatric post-tonsillectomy pain better than using bupivacaine or tramadol alone: A randomized, placebo-controlled, double blind clinical trial. Adv Biomed Res.
8727 Hone R, Barnes S, Kirkland P. (2015). Inflammatory pseudotumor. Otorhinolaryngologist.
8728 Hooper JE, Hebert JF, Schilling A, et al. (2015). Hybrid Capture 2 is as effective as PCR testing for high-risk human papillomavirus in head and neck cancers. Appl Immunohistochem Mol Morphol.
8729 Hopkins C, Almeyda R, Alreefy H, et al. (2015). Multicentre prospective clinical application of the T14 paediatric outcome tool. J Laryngol Otol.
8730 Hoshino J, Fujii T, Usui J, et al. (2015). Renal outcome after tonsillectomy plus corticosteroid pulse therapy in patients with immunoglobulin A nephropathy: results of a multicenter cohort study. Clin Exp Nephrol.
8731 Hosseinzadeh N, Samadi S, Jafari Javid M, et al. (2015). Impending Complete Airway Obstruction from a Reinforced Orotracheal Tube: a Case Report. Acta Med Iran.
8732 Hu S, Patel NA, Shinhar S. (2015). Follow-up audiometry after bilateral myringotomy and tympanostomy tube insertion. Int J Pediatr Otorhinolaryngol.
8733 Huang YS, Hwang FM, Lin CH, et al. (2015). Clinical Manifestations of Pediatric Obstructive Sleep Apnea Syndrome: Clinical Utility of the Chinese-version Obstructive Sleep Apnea Questionaire-18. Psychiatry Clin Neurosci.
8734 Hurley M, Vyas H. (2015). Respiratory problems in children with neurodisability. Paediatrics and Child Health (United Kingdom).
8735 Hwang MS, Forman SN, Kanter JA, et al. (2015). Tonsillar Helicobacter pylori colonization in chronic tonsillitis: systematic review and meta-analysis. JAMA Otolaryngol Head Neck Surg.
8736 Hwang MS, Kaye KE, Waxman JA, et al. (2015). What is the best management of asymptomatic unilateral tonsillar enlargement?. Laryngoscope.
8737 Hwang MS, Salapatas AM, Yalamanchali S, et al. (2015). Factors associated with hypertrophy of the lingual tonsils. Otolaryngol Head Neck Surg.
8738 Ieiri N, Osamu H. (2015). Importance of the duration of nephropathy prior to tonsillectomy and steroid pulse therapy in IgA nephropathy patients. Clin Exp Nephrol.
8739 Immanuel SA, Kohler M, Martin J, et al. (2015). Increased thoracoabdominal asynchrony during breathing periods free of discretely scored obstructive events in children with upper airway obstruction. Sleep Breath.
8740 Ince I, Yoruk O, Ahiskalioglu A, et al. (2015). Does Montelukast Have an Effect on Post-tonsillectomy Pain Control in Children?. A Randomized Trial Study Otolaryngol Head Neck Surg.
8741 Ingram DG, Friedman NR. (2015). Toward Adenotonsillectomy in Children: A Review for the General Pediatrician. JAMA Pediatr.
8742 Ingram DG, Ruiz A, Friedman NR. (2015). Friedman tongue position: age distribution and relationship to sleep-disordered breathing. Int J Pediatr Otorhinolaryngol.
8743 Iqbal Z, Qureshi AE, Nadeem M. (2015). Tonsillectomy by spray coagulation mode of diathermy: A study on peroperative bleeding and operative time. Pakistan Journal of Medical and Health Sciences.
8744 Isaac A, Major M, Witmans M, et al. (2015). Correlations Between Acoustic Rhinometry, Subjective Symptoms, and Endoscopic Findings in Symptomatic Children With Nasal Obstruction. JAMA Otolaryngol Head Neck Surg.
8745 Isaacson G. (2015). Surgical treatment of pediatric rhinosinusitis. Minerva Pediatr.
8746 Isaiah A, Pereira KD. (2015). Outcomes after adenotonsillectomy using a fixed anesthesia protocol in children with obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
8747 Ishman SL, Tawfik KO, Smith DF, et al. (2015). Screening for Pediatric Obstructive Sleep Apnea before Ambulatory Surgery. J Clin Sleep Med.
8748 Ivaskevicius V, Goldmann G, Biswas A, et al. (2015). Neoplasm-induced bleeding in inherited, heterozygous FXIII-A deficiency. Hamostaseologie.
8749 Iwatani H, Nagasawa Y, Yamamoto R, et al. (2015). CD16+CD56+ cells are a potential culprit for hematuria in IgA nephropathy. Clin Exp Nephrol.
8750 Jamieson K, Nixon G, Davey M. (2015). Understanding respiratory compromise on the first post-operative night after paediatric adenotonsillectomy-the contribution of downloadable oximetry recordings. Sleep and Biological Rhythms.
8751 Jawhar N, Chami I, Saliba Z, et al. (2015). FALSE AND TRUE ACUTE RHEUMATIC FEVER: A Lebanese Experience. J Med Liban.
8752 Jegalian AG, Bodo J, Hsi ED. (2015). NOTCH1 intracellular domain immunohistochemistry as a diagnostic tool to distinguish T-lymphoblastic lymphoma from thymoma. Am J Surg Pathol.
8753 Jensen A, Hansen TM, Bank S, et al. (2015). Fusobacterium necrophorum tonsillitis: an important cause of tonsillitis in adolescents and young adults. Clin Microbiol Infect.
8754 Jiang XL, Zhang GL, Yang T, et al. (2015). Association of Pneumococcal Carriage and Expression of Foxp3+ Regulatory T Cells and Th17 Cells in the Adenoids of Children. Respiration.
8755 John-Olabode S, Awodele I, Oni O. (2015). Adolescents with sickle cell anaemia: Experience in a private tertiary hospital serving a tertiary institution. Niger Med J.
8756 Johr M, Berger TM. (2015). Anaesthesia for the paediatric outpatient. Curr Opin Anaesthesiol.
8757 Jonas C, Ging J, Teng A. (2015). Clinical audit study of home-based initiation of CPAP in children. Sleep and Biological Rhythms.
8758 Jovic M, Avramovic V, Vlahovic P, et al. (2015). Ultrastructure of the human palatine tonsil and its functional significance. Rom J Morphol Embryol.
8759 Judge PD, Lydiatt C, Jones DT. (2015). Extracorporeal membrane oxygenation after tonsillectomy. Otolaryngol Head Neck Surg.
8760 Kadhim C, Maiolini F, Cerrito L, et al. (2015). PFAPA syndrome as an hereditary autoinflamatory disorder. Pediatric Rheumatology.
8761 Kaditis A, Kheirandish-Gozal L, Gozal D, Pediatric OSAS. (2015). Oximetry can provide answers when polysomnography is not available. Sleep Med Rev.
8762 Kamath PM, Shenoy VS, Nirupama M, et al. (2015). Tuberculosis of waldeyer's ring with an atypical presentation as chronic adeno-tonsilitis. Journal of Clinical and Diagnostic Research.
8763 Kaneko T, Arai M, Ikeda M, et al. (2015). Comparison of immunosuppressive therapies for IgA nephropathy after tonsillectomy: three-course versus one-course steroid pulse combined with mizoribine. Int Urol Nephrol.
8764 Kaneko T, Mii A, Fukui M, et al. (2015). IgA nephropathy and psoriatic arthritis that improved with steroid pulse therapy and mizoribine in combination with treatment for chronic tonsillitis and epipharyngitis. Intern Med.
8765 Kang KT, Weng WC, Lee CH, et al. (2015). Detection of pediatric obstructive sleep apnea syndrome: history or anatomical findings?. Sleep Med.
8766 Kanona H, Sharma S, Chaidas K, et al. (2015). Pulse oximetry in paediatric obstructive sleep apnoea: is it used appropriately?. J Laryngol Otol.
8767 Karimnejad K, Costa DJ. (2015). Otolaryngologic surgery in children with trisomy 18 and 13. Int J Pediatr Otorhinolaryngol.
8768 Katafuchi R, Kawamura T, Joh K, et al. (2015). Pathological sub-analysis of a multicenter randomized controlled trial of tonsillectomy combined with steroid pulse therapy versus steroid pulse monotherapy in patients with immunoglobulin A nephropathy. Clin Exp Nephrol.
8769 Keamy DG, Chhabra KR, Hartnick CJ. (2015). Predictors of complications following adenotonsillectomy in children with severe obstructive sleep apnea. Int J Pediatr Otorhinolaryngol.
8770 Keilmann A, Lassig AK, Pollak-Hainz A, et al. (2015). Adenoids of patients with mucopolysaccharidoses demonstrate typical alterations. Int J Pediatr Otorhinolaryngol.
8771 Kelly EA, Linn D, Keppel KL, et al. (2015). Otolaryngologic surgeries are frequent in children with eosinophilic esophagitis. Ann Otol Rhinol Laryngol.
8772 Kennedy BC, Kelly KM, Phan MQ, et al. (2015). Outcomes after suboccipital decompression without dural opening in children with Chiari malformation Type I. J Neurosurg Pediatr.
8773 Khami M, Tan S, Glicksman JT, et al. (2015). Incidence and Risk Factors of Velopharyngeal Insufficiency Postadenotonsillectomy. Otolaryngol Head Neck Surg.
8774 Khan SG, Binmahfoodh M, Alali M, et al. (2015). Cerebellar swelling due to familial hemophagocytic lymphohistiocytosis: An unusual presentation. Eur J Paediatr Neurol.
8775 Kharytaniuk N, Ali R, Sharafa A, et al. (2015). Day-case tonsillectomy: practical solution or practical impossibility. Ir Med J.
8776 Khatib Y, Gite V, Patel R, et al. (2015). Lymphangiomatous polyp of palatine tonsil in a child presenting with dysphagia and dysarthria. Journal of Clinical and Diagnostic Research.
8777 Kheirandish-Gozal L, Gileles-Hillel A, Alonso-Alvarez ML, et al. (2015). Effects of adenotonsillectomy on plasma inflammatory biomarkers in obese children with obstructive sleep apnea: A community-based study. Int J Obes (Lond).
8778 Kille TL, Lewoczko K. (2015). Lingual tonsillectomy with the PlasmaBlade. Operative Techniques in Otolaryngology - Head and Neck Surgery.
8779 Kim DK, Han DH. (2015). Impact of allergic rhinitis on quality of life after adenotonsillectomy for pediatric sleep-disordered breathing. Int Forum Allergy Rhinol.
8780 Kim DK, Lee JW, Na YS, et al. (2015). Clinical factor for successful nonsurgical treatment of pediatric peritonsillar abscess. Laryngoscope.
8781 Kim HS, Byon HJ, Kim JE, et al. (2015). Appropriate dose of dexmedetomidine for the prevention of emergence agitation after desflurane anesthesia for tonsillectomy or adenoidectomy in children: up and down sequential allocation. BMC Anesthesiol.
8782 Kim JW, Kim HJ, Lee WH, et al. (2015). Comparative Study for Efficacy and Safety of Adenoidectomy according to the Surgical Method: A Prospective Multicenter Study. PLoS One.
8783 Kim SY, Kim YR, Park WJ, et al. (2015). Characterisation of insulin-producing cells differentiated from tonsil derived mesenchymal stem cells. Differentiation.
8784 Kim YW, Kang MJ, Lee HJ, et al. (2015). The efficacy of TachoComb on reducing postoperative complications after tonsillectomy in children. Int J Pediatr Otorhinolaryngol.
8785 Kjaerulff AM, Thomsen MK, Ovesen T, et al. (2015). Clinical and biochemical characteristics of patients with Fusobacterium necrophorum-positive acute tonsillitis. Eur Arch Otorhinolaryngol.
8786 Kleinsorge GHD, Sousa AMD, Botelho LF, et al. (2015). Endovascular treatment of delayed bleeding after tonsillectomy. Jornal Vascular Brasileiro.
8787 Kline-Tilford AM. (2015). Impact of Obesity during Pediatric Acute and Critical Illness. Journal of Pediatric Intensive Care.
8788 Ko AR, Kim SJ, Jung MK, et al. (2015). Hypotonic hyponatremia by primary polydipsia caused brain death in a 10-year-old boy. Ann Pediatr Endocrinol Metab.
8789 Ko Y, Kariyawasam V, Karnib M, et al. (2015). Inflammatory Bowel Disease Environmental Risk Factors: A Population-Based Case-Control Study of Middle Eastern Migration to Australia. Clin Gastroenterol Hepatol.
8790 Koltai PJ. (2015). Gizmo is a mean word!. Otolaryngol Head Neck Surg.
8791 Komatsu H, Sato Y, Miyamoto T, et al. (2015). Significance of tonsillectomy combined with steroid pulse therapy for IgA nephropathy with mild proteinuria. Clin Exp Nephrol.
8792 Konieczny KM, Biggs TC, Pringle MB. (2015). A two-year follow-up observational study of the T-14 paediatric throat disorders outcome measure in tonsillectomy and adenotonsillectomy. Ann R Coll Surg Engl.
8793 Kontos A, Kennedy D, Martin J, et al. (2015). Delayed brachial artery dilation response and increased resting blood flow velocity in young children with mild upper airway obstruction. Sleep and Biological Rhythms.
8794 Kontos A, van den Heuvel C, Pamula Y, et al. (2015). Delayed brachial artery dilation response and increased resting blood flow velocity in young children with mild sleep-disordered breathing. Sleep Med.
8795 Koren D, Gozal D, Bhattacharjee R, et al. (2015). Impact of Adenotonsillectomy On Insulin Resistance And Lipoprotein Profile In Nonobese And Obese Children. Chest.
8796 Korona-Glowniak I, Niedzielski A, Kosikowska U, et al. (2015). Nasopharyngeal vs. adenoid cultures in children undergoing adenoidectomy: prevalence of bacterial pathogens, their interactions and risk factors. Epidemiol Infect.
8797 Kortus-Gotze B, Hoyer J. (2015). Anti-IL1s-monoclonal antibody in two adult patients with PFAPA Syndrome-a single centre experience. Pediatric Rheumatology.
8798 Kosikowska U, Korona-Glowniak I, Niedzielski A, et al. (2015). Nasopharyngeal and Adenoid Colonization by Haemophilus influenzae and Haemophilus parainfluenzae in Children Undergoing Adenoidectomy and the Ability of Bacterial Isolates to Biofilm Production. Medicine (Baltimore).
8799 Kourelis K, Haronis V, Konandreas I, et al. (2015). Atypical post-adenoidectomy Grisel's syndrome in Crouzon child with kyphotic skull base. Auris Nasus Larynx.
8800 Kourlaba G, Kourkouni E, Spyridis N, et al. (2015). Antibiotic prescribing and expenditures in outpatient paediatrics in Greece, 2010-13. J Antimicrob Chemother.
8801 Kovacevic L, Lu H, Wolfe-Christensen C, et al. (2015). Adenotonsillectomy Normalizes Hormones and Urinary Electrolytes in Children With Nocturnal Enuresis and Sleep-Disordered Breathing. Urology.
8802 Kovacevic L, Wolfe-Christensen C, Lu H, et al. (2015). Adenotonsillectomy improves quality of life in children with sleep-disordered breathing regardless of nocturnal enuresis outcome. J Pediatr Urol.
8803 Kowalczyk DM, Hardy ET, Lewis AF. (2015). Airway evaluation in obstructive sleep apnea. Operative Techniques in Otolaryngology - Head and Neck Surgery.
8804 Koyuncu O, Turhanoglu S, Tuzcu K, et al. (2015). Effect of carboxyhemoglobin on postoperative complications and pain in pediatric tonsillectomy patients. Paediatr Anaesth.
8805 Kronbichler A, Kerschbaum J, Mayer G. (2015). The Influence and Role of Microbial Factors in Autoimmune Kidney Diseases: A Systematic Review. J Immunol Res.
8806 Kubinska M, Tykalowski B, Koncicki A, et al. (2015). Biochemical and immunological responses of young turkeys to vaccination against Ornithobacterium rhinotraheale and different levels of dietary methionine. Pol J Vet Sci.
8807 Kuchar E, Miskiewicz K, Szenborn L, et al. (2015). Respiratory tract infections in children in primary healthcare in Poland. Adv Exp Med Biol.
8808 Kucur C, Ozbay I, Oghan F, et al. (2015). A Rare Complication of Radiofrequency Tonsil Ablation: Horner Syndrome. Case Rep Otolaryngol.
8809 Kukwa W, Kukwa A, Galazka A, et al. (2015). Long-term parental satisfaction with adenotonsillectomy: a population study. Sleep Breath.
8810 Kukwa W, Kukwa A, Galazka A, et al. (2015). Long-term parental satisfaction with adenotonsillectomy-a population study. Somnologie.
8811 Kulkarni MP, Momin YA, Deshmukh BD, et al. (2015). Extranodal follicular dendritic cell sarcoma involving tonsil. Malays J Pathol.
8812 Kundi NA, Mehmood T, Abid O. (2015). Application of mouth gag and temporomandibular joint pain and trismus in tonsillectomy. J Coll Physicians Surg Pak.
8813 Kuo YL, Kang KT, Chiu SN, et al. (2015). Blood pressure after surgery among obese and nonobese children with obstructive sleep apnea. Otolaryngol Head Neck Surg.
8814 Ladner TR, Dewan MC, Day MA, et al. (2015). Posterior odontoid process angulation in pediatric Chiari I malformation: an MRI morphometric external validation study. J Neurosurg Pediatr.
8815 Lago DM, Koning JL, Naheedy J, et al. (2015). Carotid artery pseudoaneurysm: A rare complication following tonsillectomy. Int J Pediatr Otorhinolaryngol.
8816 Lai CC, Friedman M, Lin HC, et al. (2015). Clinical predictors of effective continuous positive airway pressure in patients with obstructive sleep apnea/hypopnea syndrome. Laryngoscope.
8817 Lakhani R, Loh Y, Zhang TT, et al. (2015). A prospective study of blood splatter in ENT. Eur Arch Otorhinolaryngol.
8818 Lamprell L, Ahluwalia S. (2015). Who has been hiding in your tonsillectomy tray? Eponymous instruments in tonsillectomy surgery. J Laryngol Otol.
8819 Lantto U, Koivunen P, Tapiainen T, et al. (2015). Microbes of the tonsils in PFAPA (Periodic Fever, Aphtous stomatitis, Pharyngitis and Adenitis) syndrome - a possible trigger of febrile episodes. Apmis.
8820 Larrier DR, Huang ZJ, Zhang W, et al. (2015). Is routine pre-operative cardiac evaluation necessary in obese children undergoing adenotonsillectomy for OSA?. Am J Otolaryngol.
8821 Lazarow FB, Ahuja GS, Chin Loy A, et al. (2015). Intraoperative long range optical coherence tomography as a novel method of imaging the pediatric upper airway before and after adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
8822 Lazea C, Manasia R, Lazer C. (2015). Marshall syndrome - A challenge in medical practice. Paediatria Croatica.
8823 Leao SC, Leal IO, do Nascimento Rocha HM, et al. (2015). Evaluation of cytokines produced by beta-hemolytic streptococcus in acute pharyngotonsillitis. Braz J Otorhinolaryngol.
8824 Lee CH, Hsu WC, Chang WH, et al. (2015). Polysomnographic Findings after Adenotonsillectomy for Obstructive Sleep Apnea in Obese and Non-Obese Children: A Systemic review and Meta-Analysis. Clin Otolaryngol.
8825 Lee CH, Kang KT, Weng WC, et al. (2015). Quality of life after adenotonsillectomy in children with obstructive sleep apnea: short-term and long-term results. Int J Pediatr Otorhinolaryngol.
8826 Lee J, Chang DY, Kim SW, et al. (2015). Age-related differences in human palatine tonsillar B cell subsets and immunoglobulin isotypes. Clin Exp Med.
8827 Lee LA, Li HY, Lin YS, et al. (2015). Severity of childhood obstructive sleep apnea and hypertension improved after adenotonsillectomy. Otolaryngol Head Neck Surg.
8828 Lee RK, Griffith JF, Leung JH, et al. (2015). Effect of upright position on tonsillar level in adolescent idiopathic scoliosis. Eur Radiol.
8829 Lee SY, Guilleminault C, Chiu HY, et al. (2015). Mouth breathing, “nasal disuse,” and pediatric sleep-disordered breathing. Sleep Breath.
8830 Leute PJF, Hammad A, Hoffmann I, et al. (2015). Set screw fracture with cage dislocation after two-level transforaminal lumbar interbody fusion (TLIF): A case report. Journal of Medical Case Reports.
8831 Lewis TL, Johnson RF, Choi J, et al. (2015). Weight gain after adenotonsillectomy: a case control study. Otolaryngol Head Neck Surg.
8832 Li HY, Lee LA, Yu JF, et al. (2015). Changes of snoring sound after relocation pharyngoplasty for obstructive sleep apnoea: the surgery reduces mean intensity in snoring which correlates well with apnoea-hypopnoea index. Clin Otolaryngol.
8833 Li S, Wu D, Shi H. (2015). Reoperation on patients with obstructive sleep apnea-hypopnea syndrome after failed uvulopalatopharyngoplasty. Eur Arch Otorhinolaryngol.
8834 Li X, Xia Q, Li W. (2015). Comparison of the effects of dezocine, fentanyl, and placebo on emergence agitation after sevoflurane anesthesia in children. Int J Clin Pharmacol Ther.
8835 Liang C, Ruiz AG, Jensen EL, et al. (2015). Indications, clinical course, and postoperative outcomes of urgent adenotonsillectomy in children. JAMA Otolaryngol Head Neck Surg.
8836 Liederbach E, Lewis CM, Yao K, et al. (2015). A Contemporary Analysis of Surgical Trends in the Treatment of Squamous Cell Carcinoma of the Oropharynx from 1998 to 2012: A Report from the National Cancer Database. Ann Surg Oncol.
8837 Lim J, McKean MC, Hearne BJ. (2015). WITHDRAWN: Adenotonsillectomy for obstructive sleep apnoea in children. Cochrane Database Syst Rev.
8838 Lin SY, Baugher KM, Brown DJ, et al. (2015). Effects of nasal saline lavage on pediatric sinusitis symptoms and disease-specific quality of life: a case series of 10 patients. Ear Nose Throat J.
8839 Lin YC, Lu PL, Lin KH, et al. (2015). Molecular Epidemiology and Phylogenetic Analysis of Human Adenovirus Caused an Outbreak in Taiwan during 2011. PLoS One.
8840 Linz C, Collmann H, Meyer-Marcotty P, et al. (2015). Occipital plagiocephaly: unilateral lambdoid synostosis versus positional plagiocephaly. Arch Dis Child.
8841 Liodden I, Sandvik L, Valeberg BT, et al. (2015). Acupuncture versus usual care for postoperative nausea and vomiting in children after tonsillectomy/adenoidectomy: a pragmatic, multicentre, double-blinded, randomised trial. Acupunct Med.
8842 Liu C, Ulualp SO. (2015). Outcomes of an Alternating Ibuprofen and Acetaminophen Regimen for Pain Relief After Tonsillectomy in Children. Ann Otol Rhinol Laryngol.
8843 Liu J, Ai H, Xiong Y, et al. (2015). Prevalence and correlation of infectious agents in hospitalized children with acute respiratory tract infections in Central China. PLoS One.
8844 Liu LL, Wang LN, Jiang Y, et al. (2015). Tonsillectomy for IgA nephropathy: a meta-analysis. Am J Kidney Dis.
8845 Liu W, Chen X. (2015). Adenoid cystic carcinoma of the larynx: a report of six cases with review of the literature. Acta Otolaryngol.
8846 Liu X, Zheng Y, Tian P, et al. (2015). The impact of tonsillectomy with or without adenoidectomy on voice: acoustic and aerodynamic assessments. J Voice.
8847 Loffredo L, Zicari AM, Occasi F, et al. (2015). Endothelial dysfunction and oxidative stress in children with sleep disordered breathing: role of NADPH oxidase. Atherosclerosis.
8848 Lopez-Jimenez E, Barrios R, Llodra Calvo JC, et al. (2015). Association of oral breathing with dental malocclusions and general health in children. Minerva Pediatr.
8849 Lu ZJ, Li J, Zhou SH, et al. (2015). Follicular dendritic cell sarcoma of the right tonsil: A case report and literature review. Oncol Lett.
8850 Mahant S, Hall M, Ishman SL, et al. (2015). Association of National Guidelines With Tonsillectomy Perioperative Care and Outcomes. Pediatrics.
8851 Maheswaran S, Rupa V, Ebenezer J, et al. (2015). Relative etiological importance of adenoid hypertrophy versus sinusitis in children with persistent rhinorrhoea. Indian J Otolaryngol Head Neck Surg.
8852 Malbora B, Malbora N, Avci Z, et al. (2015). A case of transient cortical blindness associated with hypercapnia as a result of extremely enlarged adenoid tissue. Ear Nose Throat J.
8853 Malo S, Bjerrum L, Feja C, et al. (2015). Compliance with recommendations on outpatient antibiotic prescribing for respiratory tract infections: the case of Spain. Basic Clin Pharmacol Toxicol.
8854 Mandapathil M, Greene B, Wilhelm T. (2015). Transoral surgery using a novel single-port flexible endoscope system. Eur Arch Otorhinolaryngol.
8855 Manickam PV, Shott SR, Boss EF, et al. (2015). Systematic review of site of obstruction identification and non-CPAP treatment options for children with persistent pediatric obstructive sleep apnea. Laryngoscope.
8856 Manikyamba D, Satyavani A, Deepa P. (2015). Diphtheritic polyneuropathy in the wake of resurgence of diphtheria. J Pediatr Neurosci.
8857 Maricic L, Vceva A, Vcev A, et al. (2015). The Role of Tonsillectomy in the Prevention of Helicobacter Pylori Infection. Coll Antropol.
8858 Martin CS. (2015). Acupuncture for the prevention and treatment of pediatric perioperative conditions. Medical Acupuncture.
8859 Martines F, Salvago P, Costanzo R, et al. (2015). Extramedullary plasmacytoma of the tonsil: A new management. Acta Medica Mediterranea.
8860 Martins R, Oliveira J, Ferreira R. (2015). Rhinitis: A risk factor for persistence of sleep disordered breathing in paediatric patients after adenotonsillectomy?. Somnologie.
8861 Martins RO, Castello-Branco N, Barros JL, et al. (2015). Risk factors for respiratory complications after adenotonsillectomy in children with obstructive sleep apnea. J Bras Pneumol.
8862 Matilla Alvarez A, Garcia Serrano E, Gonzalez de la Huebra Labrador T, et al. (2015). Ischemic stroke in childhood. A complication of tonsillectomy. Rev Esp Anestesiol Reanim.
8863 Mattia C, Coluzzi F. (2015). A look inside the association codeine-paracetamol: clinical pharmacology supports analgesic efficacy. Eur Rev Med Pharmacol Sci.
8864 Mazur E, Czerwinska E, Grochowalska A, et al. (2015). Concurrent peritonsillar abscess and poststreptococcal reactive arthritis complicating acute streptococcal tonsillitis in a young healthy adult: a case report. BMC Infect Dis.
8865 Mazur E, Czerwinska E, Korona-Glowniak I, et al. (2015). Epidemiology, clinical history and microbiology of peritonsillar abscess. Eur J Clin Microbiol Infect Dis.
8866 McDonald MW, Linton OR, Calley CS. (2015). Dose-volume relationships associated with temporal lobe radiation necrosis after skull base proton beam therapy. Int J Radiat Oncol Biol Phys.
8867 Meehan WP, Jordaan M, Prabhu SP, et al. (2015). Risk of athletes with Chiari malformations suffering catastrophic injuries during sports participation is low. Clin J Sport Med.
8868 Megna M, Napolitano M, Balato A, et al. (2015). Psoriasis in children: A review. Current Pediatric Reviews.
8869 Meier BA, Holst R, Schousboe LP. (2015). Patient-perceived benefit of sialendoscopy as measured by the Glasgow Benefit Inventory. Laryngoscope.
8870 Meier JD, Zhang Y, Greene TH, et al. (2015). Variation in pediatric outpatient adenotonsillectomy costs in a multihospital network. Laryngoscope.
8871 Milder EA, Rizzi MD, Morales KH, et al. (2015). Impact of a new practice guideline on antibiotic use with pediatric tonsillectomy. JAMA Otolaryngol Head Neck Surg.
8872 Min HJ, Chung HJ, Seong SY, et al. (2015). Differential characteristics of pediatric sinusitis who underwent endoscopic sinus surgery: children vs. adolescents. Clin Otolaryngol.
8873 Misiukiewicz K, Posner M. (2015). Role of Prophylactic Bilateral Tonsillectomy as a Cancer Preventive Strategy. Cancer Prev Res (Phila).
8874 Mistik S, Gokahmetoglu S, Balci E, et al. (2015). Sore throat in primary care project: a clinical score to diagnose viral sore throat. Fam Pract.
8875 Mitchell RB, Garetz S, Moore RH, et al. (2015). The use of clinical parameters to predict obstructive sleep apnea syndrome severity in children: the Childhood Adenotonsillectomy (CHAT) study randomized clinical trial. JAMA Otolaryngol Head Neck Surg.
8876 Miyamoto T, Nishino T, Nakata T, et al. (2015). Impact of tonsillectomy combined with steroid pulse therapy on immunoglobulin A nephropathy depending on histological classification: a multicenter study. Clin Exp Nephrol.
8877 Moraleda-Cibrian M, Edwards SP, Kasten SJ, et al. (2015). Obstructive sleep apnea pretreatment and posttreatment in symptomatic children with congenital craniofacial malformations. J Clin Sleep Med.
8878 More PG, Durve SR. (2015). Acute pulmonary oedema: A post-operative complication due to neostigmine and post obstructive pulmonary oedema in a case of tonsillectomy. Journal of Clinical and Diagnostic Research.
8879 Moro ET, Goulart AP. (2015). “Loss of breath” as a cause of postoperative hypoxia and bradycardia in children submitted to tonsillectomy. Braz J Anesthesiol.
8880 Mu H, Liu J, Gong K, et al. (2015). Quantitative tissue velocity imaging evaluation of ventricular function in obstructive sleep apnoea-hypopnoea syndrome in children. Clin Exp Pharmacol Physiol.
8881 Muderris T, Sevil E, Bercin S, et al. (2015). Oropharyngeal stenosis after transoral robotic lingual tonsillectomy. J Craniofac Surg.
8882 Muderris T, Sevil E, Bercin S, et al. (2015). Transoral robotic lingual tonsillectomy in adults: preliminary results. Acta Otolaryngol.
8883 Mushwani M, Naeem M, Sheikh S, et al. (2015). Surgical audit of patients operated in ENT Mayo Hospital Lahore over a period of one year. Pakistan Journal of Medical and Health Sciences.
8884 Nagayama Y, Nishiwaki H, Hasegawa T, et al. (2015). Impact of the new risk stratification in the 2011 Japanese Society of Nephrology clinical guidelines for IgA nephropathy on incidence of early clinical remission with tonsillectomy plus steroid pulse therapy. Clin Exp Nephrol.
8885 Najm J, Rath M, Pauli S, et al. (2015). FVII deficiency in children. Medizinische Genetik.
8886 Naraghi M, Adil S, Bastaninejad S, et al. (2015). Evaluation of pediatric voice handicap index and pediatric voice related quality of life before and after adenotonsillectomy in pediatric population. Int J Pediatr Otorhinolaryngol.
8887 Narahari A, Panjwani S, Bains A, et al. (2015). Consider a mandibular positioning device to alleviate sleep-disordered breathing. Current Psychiatry.
8888 Narenthiran G, Parks C, Pettorini B. (2015). Management of Chiari I malformation in children: effectiveness of intra-operative ultrasound for tailoring foramen magnum decompression. Childs Nerv Syst.
8889 Nash R, Possamai V, Manjaly J, et al. (2015). The Management of Obstructive Sleep Apnea in Syndromic Craniosynostosis. J Craniofac Surg.
8890 Nejat M, Werno A. (2015). Importance of blood cultures to aid the diagnosis of Lemierre's syndrome. N Z Med J.
8891 Neveus T. (2015). Commentary to 'Adenotonsillectomy improves quality of life in children with nocturnal enuresis and sleep-disordered breathing'. J Pediatr Urol.
8892 Ngiam J, Cistulli PA. (2015). Dental Treatment for Paediatric Obstructive Sleep Apnea. Paediatr Respir Rev.
8893 Nguyen T, Haberland CA, Hernandez-Boussard T. (2015). Pediatric Patient and Hospital Characteristics Associated With Treatment of Peritonsillar Abscess and Peritonsillar Cellulitis. Clin Pediatr (Phila).
8894 Nguyen TV, Loudon ME. (2015). Upper airway obstruction and resultant growth factors influencing malocclusions. Int J Orthod Milwaukee.
8895 Ni K, Zhao L, Wu J, et al. (2015). Th17/Treg balance in children with obstructive sleep apnea syndrome and the relationship with allergic rhinitis. Int J Pediatr Otorhinolaryngol.
8896 Niemi P, Numminen J, Rautiainen M, et al. (2015). The effect of adenoidectomy on occlusal development and nasal cavity volume in children with recurrent middle ear infection. Int J Pediatr Otorhinolaryngol.
8897 Nishimura Y, Saito Y, Kondo N, et al. (2015). Ictal central apnea and bradycardia in temporal lobe epilepsy complicated by obstructive sleep apnea syndrome. Epilepsy and Behavior Case Reports.
8898 Nishiwaki H, Hasegawa T, Nagayama Y, et al. (2015). Absence of mesangial C1q deposition is associated with resolution of proteinuria and hematuria after tonsillectomy plus steroid pulse therapy for immunoglobulin a nephropathy. Nephron.
8899 Nixon GM, Davey M. (2015). Sleep apnoea in the child. Aust Fam Physician.
8900 Norouzi A, Jafari A, Vishteh HR, et al. (2015). COMPARISON OF THE EFFECTS OF ORAL VS. PERITONSILLAR INFILTRATION OF KETAMINE IN PAIN REDUCTION AFTER TONSILLECTOMY: A RANDOMIZED CLINICAL TRIAL. Middle East J Anaesthesiol.
8901 Nourizadeh N, Ghazvini K, Gharavi V, et al. (2015). Evaluation of nasopharyngeal microbial flora and antibiogram and its relation to otitis media with effusion. Eur Arch Otorhinolaryngol.
8902 O'Brien K, Bellis TW, Kelson M, et al. (2015). Clinical predictors of antibiotic prescribing for acutely ill children in primary care: an observational study. Br J Gen Pract.
8903 Ochi JW. (2015). Korean hand therapy for tonsillectomy pain in children. Int J Pediatr Otorhinolaryngol.
8904 Ochung'o OP, Mugwe P, Masinde P, et al. (2015). Prevalence of H. Pylori in Tonsillar Tissue of Patients with Chronic Recurrent Tonsillitis Using Rapid Urease Test in a Tertiary Referral Hospital in Sub Saharan Africa. Indian J Otolaryngol Head Neck Surg.
8905 Okumura Y, Hidaka H, Noguchi N, et al. (2015). Intraoral drainage under surgical microscopy with tonsillectomy for parapharyngeal abscesses. J Laryngol Otol.
8906 Okumura Y, Hidaka H, Seiji K, et al. (2015). Unique migration of a dental needle into the parapharyngeal space: successful removal by an intraoral approach and simulation for tracking visibility in X-ray fluoroscopy. Ann Otol Rhinol Laryngol.
8907 Olagunju AT, Asoegwu CN, Campbell EA, et al. (2015). Impact of emotional distress on caregivers burden among Nigerian children with Obstructive Adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
8908 Oliveira VX, Teng AY. (2015). The Clinical Usefulness of Sleep Studies in Children. Paediatr Respir Rev.
8909 Onal M, Yilmaz T, Bilgic E, et al. (2015). Possible role of apoptosis in pathogenesis of adenoid hypertrophy and chronic adenoiditis: Prospective case-control study. Auris Nasus Larynx.
8910 Onal M, Yilmaz T, Bilgic E, et al. (2015). Apoptosis in chronic tonsillitis and tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
8911 Onouchi T, Mizutani Y, Shiogama K, et al. (2015). Application of an enzyme-labeled antigen method for visualizing plasma cells producing antibodies against Strep A, a carbohydrate antigen of Streptococcus pyogenes, in recurrent tonsillitis. Microbiol Immunol.
8912 Oremule B, Johnson M, Sanderson L, et al. (2015). Oral morphine for pain management in paediatric patients after tonsillectomy and adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
8913 Orliaguet G, Hamza J, Couloigner V, et al. (2015). A case of respiratory depression in a child with ultrarapid CYP2D6 metabolism after tramadol. Pediatrics.
8914 Oshima Y, Moriyama T, Itabashi M, et al. (2015). Characteristics of IgA nephropathy in advanced-age patients. Int Urol Nephrol.
8915 Osiatuma VI, Otuyemi OD, Kolawole KA, et al. (2015). Occlusal characteristics of children with hypertrophied adenoids in Nigeria. Int Orthod.
8916 Ostvoll E, Sunnergren O, Ericsson E, et al. (2015). Mortality after tonsil surgery, a population study, covering eight years and 82,527 operations in Sweden. Eur Arch Otorhinolaryngol.
8917 Oudeman E, Tewarie RN, Jobsis G, et al. (2015). Complications corner: Anterior thoracic disc surgery with dural tear/CSF fistula and low-pressure pleural drain led to severe intracranial hypotension. Surgical Neurology International.
8918 Overdijk LE, van Kesteren PJ, de Haan P, et al. (2015). Carboxyhaemoglobin formation and ECG changes during hysteroscopic surgery, transurethral prostatectomy and tonsillectomy using bipolar diathermy. Anaesthesia.
8919 Ozbay I, Ozturk A, Kucur C, et al. (2015). Effects of Obstructive Sleep Apnea in Children as a Result of Adenoid and/or Adenotonsillar Hypertrophy on Maternal Psychologic Status. J Craniofac Surg.
8920 Ozgun E, Tuncel D, Tan A, et al. (2015). Is helicobacter pylori a possible etiopathogenic factor in chronic tonsillitis?. Journal of Clinical and Analytical Medicine.
8921 Pacheco MC, Fiorott BS, Finck NS, et al. (2015). Craniofacial changes and symptoms of sleep-disordered breathing in healthy children. Dental Press J Orthod.
8922 Padilla-Zuniga EA, Nuricumbo-Vazquez A, Castro-Ibarra S. (2015). Post-tonsillectomy lingual artery pseudoaneurysm. Revista Mexicana de Angiologia.
8923 Panapasa JA, Cox RJ, Mohn KG, et al. (2015). The expression of B & T cell activation markers in children's tonsils following live attenuated influenza vaccine. Hum Vaccin Immunother.
8924 Park JH, Lim BG, Kim H, et al. (2015). Comparison of Surgical Pleth Index-guided Analgesia with Conventional Analgesia Practices in Children: A Randomized Controlled Trial. Anesthesiology.
8925 Park M, Kim YH, Ryu JH, et al. (2015). Immune suppressive effects of tonsil-derived mesenchymal stem cells on mouse bone-marrow-derived dendritic cells. Stem Cells Int.
8926 Park M, Kim YH, Woo SY, et al. (2015). Tonsil-derived mesenchymal stem cells ameliorate CCl4-induced liver fibrosis in mice via autophagy activation. Sci Rep.
8927 Park SS, Kim DH, Nam IC, et al. (2015). The effectiveness of pregabalin for post-tonsillectomy pain control: A randomized controlled trial. PloS one.
8928 Park YH, Chung EJ, Lee JH, et al. (2015). Determination of the 95% effective dose of remifentanil for the prevention of coughing during extubation in children undergoing tonsillectomy (with or without adenoidectomy). Paediatr Anaesth.
8929 Park YS, Kim HS, Jin YM, et al. (2015). Differentiated tonsil-derived mesenchymal stem cells embedded in Matrigel restore parathyroid cell functions in rats with parathyroidectomy. Biomaterials.
8930 Pavelec V, Froymovich O, Seyyedi M. (2015). Tongue base procedures for obstructive sleep apnea-How I do it. Operative Techniques in Otolaryngology - Head and Neck Surgery.
8931 Pavlidis E, Copioli C, Spagnoli C, et al. (2015). A painful stiff neck following an ear, nose, and throat surgical procedure: case report. Neuropediatrics.
8932 Payne NR, Flood A. (2015). Preventing pediatric readmissions: which ones and how?. J Pediatr.
8933 Pearson F, Mann KD, Rees A, et al. (2015). The effect of childhood infection on hearing function at age 61 to 63 years in the newcastle thousand families study. Ear Hear.
8934 Pessanha LB, de Melo AM, Braga FS, et al. (2015). Acute post-tonsillectomy negative pressure pulmonary edema. Radiol Bras.
8935 Peters F, van Wyk J, van Rooyen M. (2015). Intern to independent doctor: Basic surgical skills required for South African practice and interns' reports on their competence. South African Family Practice.
8936 Petra D, Petra K, Michaela K, et al. (2015). Polyclonal, newly derived T cells with low expression of inhibitory molecule PD-1 in tonsils define the phenotype of lymphocytes in children with Periodic Fever, Aphtous Stomatitis, Pharyngitis and Adenitis (PFAPA) syndrome. Mol Immunol.
8937 Picard A, Cardinne C, Denoux Y, et al. (2015). Extranodal lymphoma of the head and neck: a 67-case series. Eur Ann Otorhinolaryngol Head Neck Dis.
8938 Pilavakis Y, Biggs TC, Burgess A, et al. (2015). Improving post-operative pain control in paediatric tonsillectomy through use of a specialist information leaflet; our experience in 43 patients. Clin Otolaryngol.
8939 Pilavakis Y, Biggs TC, Burgess A, et al. (2015). Improving postoperative pain control in paediatric tonsillectomy through use of a specialist information leaflet: Our experience in 43 patients. Clin Otolaryngol.
8940 Pipolo C, Turati F, Cressoni P, et al. (2015). Prevalence of sinonasal disease in children with Juvenile idiopathic arthritis. Laryngoscope.
8941 Pirkl I, Filipovic B, Goranovic T, et al. (2015). Large tonsillolith associated with the accessory duct of the ipsilateral submandibular gland: support for saliva stasis hypothesis. Dentomaxillofac Radiol.
8942 Plum AW, Mortelliti AJ. (2015). Acute chest syndrome following adenotonsillectomy in a pediatric patient with Hemoglobin SC disease. Int J Pediatr Otorhinolaryngol.
8943 Plum AW, Mortelliti AJ, Walsh RE. (2015). Microbial Flora and Antibiotic Resistance in Peritonsillar Abscesses in Upstate New York. Ann Otol Rhinol Laryngol.
8944 Pomeraniec IJ, Ksendzovsky A, Yu PL, et al. (2015). Surgical History of Sleep Apnea in Pediatric Patients with Chiari Type 1 Malformation. Neurosurg Clin N Am.
8945 Pribuisiene R, Sarauskas V, Kuzminiene A, et al. (2015). Correlation between throat-related symptoms and histological examination in adults with chronic tonsillitis. Medicina (Kaunas).
8946 Propst EJ. (2015). Lingual tonsillectomy and midline posterior glossectomy in children with obstructive sleep apnea. Operative Techniques in Otolaryngology - Head and Neck Surgery.
8947 Prottengeier J, Munster T, Pohmer S, et al. (2015). Anaesthesia and orphan disease: fragile X syndrome (Martin-Bell syndrome). Eur J Anaesthesiol.
8948 Puram SV, Kozin ED, Sethi R, et al. (2015). Impact of resident surgeons on procedure length based on common pediatric otolaryngology cases. Laryngoscope.
8949 Pusztaszeri M, Wang H, Cibas ES, et al. (2015). Fine-needle aspiration biopsy of secondary neoplasms of the thyroid gland: a multi-institutional study of 62 cases. Cancer Cytopathol.
8950 Qu XP, Huang ZX, Sun Y, et al. (2015). Expression of Innate Immunity Genes in Epithelial Cells of Hypertrophic Adenoids with and without Pediatric Chronic Rhinosinusitis: A Preliminary Report. Chin Med J (Engl).
8951 Qualls H, Rimell F. (2015). Surgical management of sleep-disordered breathing in children. Operative Techniques in Otolaryngology - Head and Neck Surgery.
8952 Quon JL, Grant RA, DiLuna ML. (2015). Multimodal evaluation of CSF dynamics following extradural decompression for Chiari malformation Type I. J Neurosurg Spine.
8953 Qureshi H, Ference E, Novis S, et al. (2015). Trends in the management of pediatric peritonsillar abscess infections in the U.S., 2000-2009. Int J Pediatr Otorhinolaryngol.
8954 Qureshi HA, Ference EH, Tan BK, et al. (2015). National trends in retropharyngeal abscess among adult inpatients with peritonsillar abscess. Otolaryngol Head Neck Surg.
8955 Rachakonda TD, Dhillon JS, Florek AG, et al. (2015). Effect of tonsillectomy on psoriasis: a systematic review. J Am Acad Dermatol.
8956 Radmanesh A, Greenberg JK, Chatterjee A, et al. (2015). Tonsillar pulsatility before and after surgical decompression for children with Chiari malformation type 1: an application for true fast imaging with steady state precession. Neuroradiology.
8957 Rahmanian R, Wan Fook Cheung V, Chadha NK. (2015). Non-fatal extensive cerebral venous thrombosis as a complication of adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
8958 Rahmati R, Dogan S, Pyke O, et al. (2015). Squamous cell carcinoma of the tonsil managed by conventional surgery and postoperative radiation. Head Neck.
8959 Ramirez L, Cros J, Marin B, et al. (2015). Analgesic interaction between ondansetron and acetaminophen after tonsillectomy in children: the Paratron randomized, controlled trial. Eur J Pain.
8960 Rao KI, Hesselink J, Trauner DA. (2015). Chiari I Malformation in Nephropathic Cystinosis. J Pediatr.
8961 Rassekh CH, Kazahaya K, Livolsi VA, et al. (2015). Transoral robotic surgery-assisted excision of a congenital cervical salivary duct fistula presenting as a branchial cleft fistula. Head Neck.
8962 Raudenska M, Sztalmachova M, Gumulec J, et al. (2015). Prognostic significance of the tumour-adjacent tissue in head and neck cancers. Tumour Biol.
8963 Refaat M, Ashour ZA, Farres MN, et al. (2015). Effect of tonsillectomy on the efficacy of house dust mite sublingual immunotherapy. Allergol Immunopathol (Madr).
8964 Rezende RM, Amato FS, Barbosa AP, et al. (2015). Does atopy influence the effectiveness of treatment of adenoid hypertrophy with mometasone furoate?. Am J Rhinol Allergy.
8965 Rico-Ferreira P, Palazon-Bru A, Calvo-Perez M, et al. (2015). Nonadherence to guidelines for prescribing antibiotic therapy to patients with tonsillitis or pharyngotonsillitis: a cross-sectional study. Curr Med Res Opin.
8966 Rifat UN, Hamadalla NY, Chiad Safi KC, et al. (2015). Urothelial bladder tumour in childhood: A report of two cases and a review. Arab Journal of Urology.
8967 Rodney JD, Ahmed Z, Gupta D, et al. (2015). STRAIGHT TO VIDEO: TONSILLAR INJURY DURING ELECTIVE GLIDESCOPE(o)-ASSISTED PEDIATRIC INTUBATION. Middle East J Anaesthesiol.
8968 Rogers MA, Frauenfelder C, Woods C, et al. (2015). Bleeding following coblation tonsillectomy: a 10-year, single-surgeon audit and modified grading system. J Laryngol Otol.
8969 Rokkjaer MS, Klug TE. (2015). Tonsillar malignancy in adult patients with peritonsillar abscess: retrospective study of 275 patients and review of the literature. Eur Arch Otorhinolaryngol.
8970 Roplekar R, Van M, Hussain S. (2015). Does the Quality of Life (QOL) impact of tonsillitis correlate with SIGN guideline compliance? An assessment of range and normality. Clin Otolaryngol.
8971 Rosain J, Froissart A, Estrangin E, et al. (2015). Severe acute pharyngotonsillitis due to herpes simplex virus type 2 in a young woman. J Clin Virol.
8972 Rozycki S, Gessler EM. (2015). Posttonsillectomy weight loss in adults. Otolaryngol Head Neck Surg.
8973 Rubie I, Haighton C, O'Hara J, et al. (2015). The NAtional randomised controlled Trial of Tonsillectomy IN Adults (NATTINA): a clinical and cost-effectiveness study: study protocol for a randomised control trial. Trials.
8974 Ruohoalho J, Makitie AA, Atula T, et al. (2015). Developing a Registry for Complications in Otorhinolaryngologic Surgery: Tonsil Surgery as a Pilot Cohort. Otolaryngol Head Neck Surg.
8975 Rusan M, Klug TE, Henriksen JJ, et al. (2015). Prevalence of tonsillar human papillomavirus infections in Denmark. Eur Arch Otorhinolaryngol.
8976 Sadhasivam S, Chidambaran V, Olbrecht VA, et al. (2015). Opioid-related adverse effects in children undergoing surgery: unequal burden on younger girls with higher doses of opioids. Pain Med.
8977 Sadhasivam S, Chidambaran V, Zhang X, et al. (2015). Opioid-induced respiratory depression: ABCB1 transporter pharmacogenetics. Pharmacogenomics J.
8978 Sadhasivam S, Zhang X, Chidambaran V, et al. (2015). Novel associations between FAAH genetic variants and postoperative central opioid-related adverse effects. Pharmacogenomics J.
8979 Saini AT, Schorn VJ, Lin FY. (2015). Tonsillectomy on rivaroxaban. Am J Otolaryngol.
8980 Saki N, Nikakhlagh S, Karampur LS, et al. (2015). Analysis of timing of post-adenotonsillectomy bleeding in Imam Khomeini and Apadana Hospitals (Khuzestan, Iran). Biomedical and Pharmacology Journal.
8981 Salviz M, Bayram O, Bayram AA, et al. (2015). Prognostic factors in type I tympanoplasty. Auris Nasus Larynx.
8982 Sayyahfar S, Fahimzad A, Naddaf A, et al. (2015). Antibiotic Susceptibility Evaluation of Group A Streptococcus Isolated from Children with Pharyngitis: A Study from Iran. Infect Chemother.
8983 Schapowal A, Klein P, Johnston SL. (2015). Echinacea reduces the risk of recurrent respiratory tract infections and complications: a meta-analysis of randomized controlled trials. Adv Ther.
8984 Schmit JM, Turner DJ, Hromas RA, et al. (2015). Two novel RUNX1 mutations in a patient with congenital thrombocytopenia that evolved into a high grade myelodysplastic syndrome. Leukemia Research Reports.
8985 Schwab RJ, Kim C, Bagchi S, et al. (2015). Understanding the anatomic basis for obstructive sleep apnea syndrome in adolescents. Am J Respir Crit Care Med.
8986 Schymik FA, Lavoie Smith EM, Voepel-Lewis T. (2015). Parental Analgesic Knowledge and Decision Making for Children With and Without Obstructive Sleep Apnea After Tonsillectomy and Adenoidectomy. Pain Manag Nurs.
8987 Sediva A. (2015). Periodic fevers associated with celiac disease and marked increase of NK cells. Pediatric Rheumatology.
8988 Sedrak M, Muthukumar A, Elghetany MT, et al. (2015). Steroid-responsive atypical marginal zone hyperplasia of the lip in a child. Am J Dermatopathol.
8989 Senchak AJ, McKinlay AJ, Acevedo J, et al. (2015). The effect of tonsillectomy alone in adult obstructive sleep apnea. Otolaryngol Head Neck Surg.
8990 Senel E, Satilmis O, Acar B. (2015). Dermatologic manifestations of tularemia: a study of 151 cases in the mid-Anatolian region of Turkey. Int J Dermatol.
8991 Sener M, Kocum A, Caliskan E, et al. (2015). Administration of paracetamol versus dipyrone by intravenous patient-controlled analgesia for postoperative pain relief in children after tonsillectomy. Braz J Anesthesiol.
8992 Senska G, Atay H, Putter C, et al. (2015). Long-Term Results From Tonsillectomy in Adults. Dtsch Arztebl Int.
8993 Seymour NC. (2015). How effective are common ENT operations?. J Laryngol Otol.
8994 Shah S, Garritano FG. (2015). Pediatric oral anatomy. Operative Techniques in Otolaryngology - Head and Neck Surgery.
8995 Shahbaz S, Shaheen S, Moeen Ud D, et al. (2015). Follicles in hypertrophied tonsils. Pakistan Journal of Medical and Health Sciences.
8996 Sharifkashani S, Dabirmoghaddam P, Kheirkhah M, et al. (2015). A new clinical scoring system for adenoid hypertrophy in children. Iran J Otorhinolaryngol.
8997 Sharma MK, Singh T, Pandey AK, et al. (2015). Epidemiological Trends of GI Cancers in Patients Visiting a Tertiary Care Hospital in Chandigarh, North India. Asian Pac J Cancer Prev.
8998 Shastri D, Tandon P, Nagar A, et al. (2015). Cephalometric norms for the upper airway in a healthy North Indian population. Contemp Clin Dent.
8999 Shaul C, Koslowsky B, Rodriguez M, et al. (2015). Is Needle Aspiration for Peritonsillar Abscess Still as Good as We Think? A Long-term Follow-up. Ann Otol Rhinol Laryngol.
9000 Shen L, Zheng B, Lin Z, et al. (2015). Tailoring therapy to improve the treatment of children with obstructive sleep apnea according to grade of adenotonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
9001 Shimamoto M, Ohsawa I, Suzuki H, et al. (2015). Impact of Body Mass Index on Progression of IgA Nephropathy Among Japanese Patients. J Clin Lab Anal.
9002 Shin SM, Shin JY, Kim MH, et al. (2015). Prevalence of antibiotic use for pediatric acute upper respiratory tract infections in Korea. J Korean Med Sci.
9003 Shiraishi W, Hayashi S, Iwanaga Y, et al. (2015). A case of synovitis, acne, pustulosis, hyperostosis, and osteitis (SAPHO) syndrome presenting with hypertrophic pachymeningitis. J Neurol Sci.
9004 Shokouhi F, Meymaneh Jahromi A, Majidi MR, et al. (2015). Montelukast in Adenoid Hypertrophy: Its Effect on Size and Symptoms. Iran J Otorhinolaryngol.
9005 Simoes JF, Ribeiro J, Ferreira BR, et al. (2015). The role of tonsillectomy in psoriasis treatment. BMJ Case Rep.
9006 Simsek G, Karacayli C, Ozel A, et al. (2015). Blood parameters as indicators of upper airway obstruction in children with adenoid or adenotonsillar hypertrophy. J Craniofac Surg.
9007 Singla D, Chaudhary G, Dureja J, et al. (2015). Comparison of dexmedetomidine versus midazolam for intranasal premedication in children posted for elective surgery: A double-blind, randomised study. Southern African Journal of Anaesthesia and Analgesia.
9008 Slaats MA, Van Hoorenbeeck K, Van Eyck A, et al. (2015). Upper airway imaging in pediatric obstructive sleep apnea syndrome. Sleep Med Rev.
9009 Smith B, Strahle J, Garton H, et al. (2015). 198 The Association Between Chiari Malformation Type-1 and Tethered Spinal Cord in Children. Neurosurgery.
9010 Soderman AC, Odhagen E, Ericsson E, et al. (2015). Post-tonsillectomy haemorrhage rates are related to technique for dissection and for haemostasis. An analysis of 15734 patients in the National Tonsil Surgery Register in Sweden. Clin Otolaryngol.
9011 Soleymanifard F, Khademolhoseyni SM, Nouri JM. (2015). Nursing process in post tonsillectomy pain diagnosis: a systematic review. Glob J Health Sci.
9012 Soliman R, Alshehri A. (2015). Effect of dexmedetomidine on emergence agitation in children undergoing adenotonsillectomy under sevoflurane anesthesia: A randomized controlled study. Egyptian Journal of Anaesthesia.
9013 Soliman R, Alshehri A. (2015). Assessment of the effect of tranexamic acid on perioperative bleeding in pediatric patients undergoing tonsillectomy. Egyptian Journal of Anaesthesia.
9014 Somaini M, Sahillioglu E, Marzorati C, et al. (2015). Emergence delirium, pain or both? A challenge for clinicians. Paediatr Anaesth.
9015 Soyalic H, Somuk BT, Dogru S, et al. (2015). Evaluation of mean platelet volume and its ratio over platelet count in children with obstructive sleep apnea syndrome. Kulak Burun Bogaz Ihtis Derg.
9016 Soylu E, Kersin B, Karaaslan P, et al. (2015). Effect of anesthesia without a neuromuscular blocking agent on intraoperative bleeding in adenotonsillectomy patients. Int J Pediatr Otorhinolaryngol.
9017 Spennato P, Nicosia G, Rapana A, et al. (2015). Grisel Syndrome Following Adenoidectomy: Surgical Management in a Case with Delayed Diagnosis. World Neurosurg.
9018 Spilsbury JC, Storfer-Isser A, Rosen CL, et al. (2015). Remission and incidence of obstructive sleep apnea from middle childhood to late adolescence. Sleep.
9019 Spina A, Boari N, Gagliardi F, et al. (2015). Sudden onset of Chiari malformation type 1 in a young child after trauma. Childs Nerv Syst.
9020 Sporns PB, Zimmer S, Hanning U, et al. (2015). Acute tonsillar cerebellar herniation in a patient with traumatic dural tear and VAC therapy after complex trauma. Spine J.
9021 Sproat R, Radford P, Hunt A. (2015). Hemostatic glues in tonsillectomy: A systematic review. Laryngoscope.
9022 Stanko KM, Lee YM, Rios J, et al. (2015). Improvement of syrinx resolution after tonsillar cautery in pediatric patients with Chiari Type I malformation. J Neurosurg Pediatr.
9023 Stasio SD, Yang C, Brietzke SE, et al. (2015). Tonsillectomy versus tonsillotomy: a study of parental preference. Int J Pediatr Otorhinolaryngol.
9024 Stasio SD, Yang C, Brietzke SE, et al. (2015). Response to Letter to the Editor for “Tonsillectomy versus Tonsillotomy: A study of parental preference”. Int J Pediatr Otorhinolaryngol.
9025 Stewart MW. (2015). Postoperative pain control after tonsillectomy. J Perianesth Nurs.
9026 Stipic SS, Carev M, Kardum G, et al. (2015). Are postoperative behavioural changes after adenotonsillectomy in children influenced by the type of anaesthesia?: A randomised clinical study. Eur J Anaesthesiol.
9027 Stipic SS, Carev M, Kardum G, et al. (2015). Are postoperative behavioural changes after adenotonsillectomy in children influenced by the type of anaesthesia?. European journal of anaesthesiology.
9028 Stipic SS, Carev M, Kardum G, et al. (2015). Are postoperative behavioural changes after adenotonsillectomy in children influenced by the type of anaesthesia?: A prospective, randomised clinical study. European Journal of Anaesthesiology.
9029 Strahle J, Muraszko KM, Garton HJ, et al. (2015). Syrinx location and size according to etiology: identification of Chiari-associated syrinx. J Neurosurg Pediatr.
9030 Straight CE, Patel HH, Lehman EB, et al. (2015). Prevalence of smoke exposure amongst children who undergo tonsillectomy for recurrent tonsillitis. Int J Pediatr Otorhinolaryngol.
9031 Sun GH. (2015). From tonsils to scopes: 80 years of variation in the practice of otolaryngology. Otolaryngol Head Neck Surg.
9032 Sun J, Wu X, Zhao X, et al. (2015). Pre-emptive peritonsillar infiltration of magnesium sulphate and ropivacaine vs. ropivacaine or magnesium alone for relief of post-adenotonsillectomy pain in children. Int J Pediatr Otorhinolaryngol.
9033 Sun LM, Chen HJ, Li TC, et al. (2015). A nationwide population-based cohort study on tonsillectomy and subsequent cancer incidence. Laryngoscope.
9034 Sun W, Han X, Wu S, et al. (2015). Tonsillectomy and the risk of inflammatory bowel disease: A systematic review and meta-analysis. J Gastroenterol Hepatol.
9035 Suri JC, Sen MK, Venkatachalam VP, et al. (2015). Outcome of adenotonsillectomy for children with sleep apnea. Sleep Med.
9036 Suzuki K, Kurono Y, Ikeda K, et al. (2015). Nationwide surveillance of 6 otorhinolaryngological infectious diseases and antimicrobial susceptibility pattern in the isolated pathogens in Japan. J Infect Chemother.
9037 Swanljung E, Tapiovaara L, Lehtoranta L, et al. (2015). Lactobacillus rhamnosus GG in adenoid tissue: Double-blind, placebo-controlled, randomized clinical trial. Acta Otolaryngol.
9038 Syed MI, Magos TA, Singh J, et al. (2015). A new analgesia regimen after (adeno) tonsillectomy in children: a pilot study. Clin Otolaryngol.
9039 Tada M, Masumoto S, Hinoshita F. (2015). Clinical remission of IgA nephropathy in an HIV-positive patient after combined treatment with tonsillectomy and steroid pulse therapy. CEN Case Reports.
9040 Tagliacarne SC, Valsecchi C, Castellazzi AM, et al. (2015). Impact of passive smoke and/or atopy on adenoid immunoglobulin production in children. Immunol Lett.
9041 Tahara S, Hara H, Yamashita H. (2015). Evaluation of body growth in prepubertal Japanese children with obstructive sleep apnea after adenotonsillectomy over a long postoperative period. Int J Pediatr Otorhinolaryngol.
9042 Tan QT, Chuwa EW, Chew SH, et al. (2015). Low-grade adenosquamous carcinoma of the breast: A diagnostic and clinical challenge. Int J Surg.
9043 Tang A, Benke JR, Cohen AP, et al. (2015). Influence of Tonsillar Size on OSA Improvement in Children Undergoing Adenotonsillectomy. Otolaryngol Head Neck Surg.
9044 Tapia IE, McDonough JM, Huang J, et al. (2015). Respiratory cortical processing to inspiratory resistances during wakefulness in children with the obstructive sleep apnea syndrome. J Appl Physiol (1985).
9045 Thorleifsdottir RH, Eysteinsdottir JH, Olafsson JH, et al. (2015). Throat infections can cause substantial aggravation of chronic plaque psoriasis. Journal of investigative dermatology.
9046 Thottam PJ, Choi S, Simons JP, et al. (2015). Effect of Adenotonsillectomy on Central and Obstructive Sleep Apnea in Children with Down Syndrome. Otolaryngol Head Neck Surg.
9047 Thottam PJ, Christenson JR, Cohen DS, et al. (2015). The utility of common surgical instruments for pediatric adenotonsillectomy. Laryngoscope.
9048 Thottam PJ, Govil N, Duvvuri U, et al. (2015). Transoral robotic surgery for sleep apnea in children: Is it effective?. Int J Pediatr Otorhinolaryngol.
9049 Thottam PJ, Trivedi S, Siegel B, et al. (2015). Comparative outcomes of severe obstructive sleep apnea in pediatric patients with Trisomy 21. Int J Pediatr Otorhinolaryngol.
9050 Toliyat M, Zangoee M, Ahrari S, et al. (2015). Comparison of the Effect of Thiopental Sodium with Midazolam-ketamine on Post-tonsillectomy Agitation in Children. Acta Med Iran.
9051 Tompkins JJ, Vaughn CA, Shaikh FA, et al. (2015). Palatopharyngoplasty with bilateral buccal mucosal graft repair to alleviate oropharyngeal stenosis. Int J Pediatr Otorhinolaryngol.
9052 Topp SK, Rosenfeldt V, Vestergaard H, et al. (2015). Clinical characteristics and laboratory findings in Danish children hospitalized with primary Epstein-Barr virus infection. Infect Dis (Lond).
9053 Toppinen M, Norja P, Aaltonen LM, et al. (2015). A new quantitative PCR for human parvovirus B19 genotypes. J Virol Methods.
9054 Torretta S, Marchisio P, Drago L, et al. (2015). The presence of biofilm-producing bacteria on tonsils is associated with increased exhaled nitric oxide levels: preliminary data in children who experience recurrent exacerbations of chronic tonsillitis. J Laryngol Otol.
9055 Tran DD, Littlefield PD. (2015). Late presentation of subcutaneous emphysema and pneumomediastinum following elective tonsillectomy. Am J Otolaryngol.
9056 Trinidade A, Philpott CM. (2015). Bilateral glossopharyngeal nerve palsy following tonsillectomy: a very rare and difficult complication of a common procedure. J Laryngol Otol.
9057 Troupis T, Michalinos A, Kakisis J, et al. (2015). Bilateral lingual-facial trunk: anatomic and clinical implications. Folia Morphol (Warsz).
9058 Tsao GJ, Messner AH, Seybold J, et al. (2015). Intraoperative acupuncture for posttonsillectomy pain: A randomized, double-blind, placebo-controlled trial. Laryngoscope.
9059 Tsou YA, Lin CD, Hsu HY, et al. (2015). Association of beta-Lactam-Sensitive Haemophilus influenzae Type B with Adenoid Biofilm Formation in Patients with Adenoidectomy Surgery. Surg Infect (Larchmt).
9060 Tsoucalas G, Laios K, Sgantzos M, et al. (2015). Paul of Aegina (c. 7th Century AD): Introducing in the Surgical Operating Theatre of the Era an Innovative Tonsillectomy With a Forceps Under the Sunlight. Surg Innov.
9061 Tsui BC, Horne S, Tsui J, et al. (2015). Generation of tidal volume via gentle chest pressure in children over one year old. Resuscitation.
9062 Tuchtan L, Torrents J, Lebreton-Chakour C, et al. (2015). Liability under post-tonsillectomy lethal bleeding of the tonsillar artery: a report of two cases. Int J Pediatr Otorhinolaryngol.
9063 Tucker Woodson B, Kocdor P, Seyyedi M, et al. (2015). Transpalatal advancement pharyngoplasty and expansion sphincterplasty for obstructive sleep apnea. Operative Techniques in Otolaryngology - Head and Neck Surgery.
9064 Tugrul S, Dogan R, Kocyigit A, et al. (2015). DNA damage and oxidative status in PFAPA syndrome. Auris Nasus Larynx.
9065 Tusaliu M, Mogoanta CA, Dobrea CM, et al. (2015). Clinical and histological aspects with therapeutic implications in head and neck lymphomas. Rom J Morphol Embryol.
9066 Ucar M, Tokgoz N, Koc AM, et al. (2015). Assessment of 3D T2-weighted high-sampling-efficiency technique (SPACE) for detection of cerebellar tonsillar motion: new useful sign for Chiari I malformation. Clin Imaging.
9067 Unlu I, Unlu EN, Kesici GG, et al. (2015). Evaluation of middle ear pressure in the early period after adenoidectomy in children with adenoid hypertrophy without otitis media with effusion. Am J Otolaryngol.
9068 Van M, Khan I, Hussain SS. (2015). Short-term weight gain after adenotonsillectomy in children with obstructive sleep apnoea: systematic review. J Laryngol Otol.
9069 Vanoni F, Federici S, Ozen S, et al. (2015). How experts on Autoinflammatory diseases classify Periodic Fever, Aphthous stomatitis, Pharyngitis and Cervical Adenitis (PFAPA): Preliminary results of the Eurofever Delphi survey. Pediatric Rheumatology.
9070 Varshney R, Pitaro J, Alghonaim Y, et al. (2015). Hemorrhagic Hairy Polyp Causing Velopharyngeal Dysfunction in a Newborn. Cleft Palate Craniofac J.
9071 Vcev A, Pezerovic D, Jovanovic Z, et al. (2015). A retrospective, case-control study on traditional environmental risk factors in inflammatory bowel disease in Vukovar-Srijem County, north-eastern Croatia, 2010. Wien Klin Wochenschr.
9072 Venekamp RP, Hearne BJ, Chandrasekharan D, et al. (2015). Tonsillectomy or adenotonsillectomy versus non-surgical management for obstructive sleep-disordered breathing in children. Cochrane Database Syst Rev.
9073 Vergano L, Loiacono E, Albera R, et al. (2015). Can tonsillectomy modify the innate and adaptive immunity pathways involved in IgA nephropathy?. J Nephrol.
9074 Verse T, Wenzel S, Brus J. (2015). Multi-level surgery for obstructive sleep apnea. Lingual tonsillectomy vs. hyoid suspension in combination with radiofrequency of the tongue base. Sleep Breath.
9075 Veskitkul J, Vichyanond P, Pacharn P, et al. (2015). Clinical characteristics of recurrent acute rhinosinusitis in children. Asian Pac J Allergy Immunol.
9076 Vicini C, Eesa M, Hendawy E, et al. (2015). Powered intracapsular tonsillotomy vs. conventional extracapsular tonsillectomy for pediatric OSA: A retrospective study about efficacy, complications and quality of life. Int J Pediatr Otorhinolaryngol.
9077 Vigue MG, Tuaillon E, Makinson A, et al. (2015). Lymphoma-Like Syndrome: 4 Case Reports About Atypical Presentation of Primary Cytomegalovirus Infection in Immunocompetent Children. Medicine (Baltimore).
9078 Villa MP, Brasili L, Ferretti A, et al. (2015). Oropharyngeal exercises to reduce symptoms of OSA after AT. Sleep Breath.
9079 Volgger V, Sharma GK, Jing JC, et al. (2015). Long-range Fourier domain optical coherence tomography of the pediatric subglottis. Int J Pediatr Otorhinolaryngol.
9080 Vorsprach M, Kalinski T, Vorwerk U. (2015). Follicular dendritic cell sarcoma of the tonsil. Pathol Res Pract.
9081 Walijee H, Al-Hussaini A, Harris A, et al. (2015). What Are the Trends in Tonsillectomy Techniques in Wales? A Prospective Observational Study of 19,195 Tonsillectomies over a 10-Year Period. Int J Otolaryngol.
9082 Walker SM. (2015). Pain after surgery in children: clinical recommendations. Curr Opin Anaesthesiol.
9083 Walls A, Cubangbang M, Wang H, et al. (2015). Pediatric Autoimmune Neuropsychiatric Disorder Associated with Streptococcus Immunology: A Pilot Study. Otolaryngol Head Neck Surg.
9084 Walter LM, Biggs SN, Nisbet LC, et al. (2015). Long-Term Improvements in Sleep and Respiratory Parameters in Preschool Children Following Treatment of Sleep Disordered Breathing. J Clin Sleep Med.
9085 Wang CP, Chang YH, Chang YT. (2015). Fetal Rhabdomyoma of the Right Tonsil with Polyp-Like Appearance. Case Rep Otolaryngol.
9086 Wang F, Song Y, Zhang X, et al. (2015). Sinus Balloon Catheter Dilation in Pediatric Chronic Rhinosinusitis Resistant to Medical Therapy. JAMA Otolaryngol Head Neck Surg.
9087 Wang H, Fu Y, Feng Y, et al. (2015). Tonsillectomy versus tonsillotomy for sleep-disordered breathing in children: a meta analysis. PLoS One.
9088 Wang J, Mack TM, Hamilton AS, et al. (2015). Common immune-related exposures/conditions and risk of non-Hodgkin lymphoma: a case-control study of disease-discordant twin pairs. Am J Epidemiol.
9089 Wang Y, Liu X, Chen Y. (2015). Adult systemic Epstein-Barr virus-positive T-cell lymphoproliferative disease: A case report. Experimental and Therapeutic Medicine.
9090 Wang YP, Wang MC, Lin HC, et al. (2015). Tonsillectomy and the risk for deep neck infection-a nationwide cohort study. PLoS One.
9091 Wannemuehler TJ, Elghouche AN, Kokoska MS, et al. (2015). Impact of Lean on surgical instrument reduction: Less is more. Laryngoscope.
9092 Warad D, Hussain FT, Rao AN, et al. (2015). Haemorrhagic complications with adenotonsillectomy in children and young adults with bleeding disorders. Haemophilia.
9093 Warman M, Granot E, Halperin D. (2015). Improvement in allergic and nonallergic rhinitis: A secondary benefit of adenoidectomy in children. Ear Nose Throat J.
9094 Warrier K, Cliffe L, McDermott L, et al. (2015). MEFV mutations-therapeutic guides or red herrings?. Pediatric Rheumatology.
9095 Wei L, Wang M, Hua N, et al. (2015). Regrowth of the adenoids after adenoidectomy down to the pharyngobasilar fascial surface. J Laryngol Otol.
9096 Weigel C, Geissler K, Markwart R, et al. (2015). Isolation of viable and functional T-cells from human palatine tonsils. J Immunol Methods.
9097 Whitson WJ, Lane JR, Bauer DF, et al. (2015). A prospective natural history study of nonoperatively managed Chiari I malformation: does follow-up MRI surveillance alter surgical decision making?. J Neurosurg Pediatr.
9098 Wijakkanalan P, Saesaew P, Wongsawatdiwat M, et al. (2015). Whether Post-Tonsillectomy Medication Should be Liquid Based or Can be Solid? A Randomised, Single-Blinded, Controlled Trial. J Med Assoc Thai.
9099 Williams G, Bell G, Buys J, et al. (2015). The prevalence of pain at home and its consequences in children following two types of short stay surgery: a multicenter observational cohort study. Paediatr Anaesth.
9100 Wilson PF, Wannemuehler TJ, Matt BH. (2015). Invasive group A Streptococcus resulting in sepsis and abdominal wall abscess after adenotonsillectomy. Laryngoscope.
9101 Windfuhr JP, Savva K, Dahm JD, et al. (2015). Tonsillotomy: facts and fiction. Eur Arch Otorhinolaryngol.
9102 Windfuhr JP, Verspohl BC, Chen YS, et al. (2015). Post-tonsillectomy hemorrhage--some facts will never change. Eur Arch Otorhinolaryngol.
9103 Windfuhr JP, Zurawski A. (2015). Peritonsillar abscess: remember to always think twice. Eur Arch Otorhinolaryngol.
9104 Winston KR, Stence NV, Boylan AJ, et al. (2015). Upward Translation of Cerebellar Tonsils following Surgical Expansion of Supratentorial Cranial Vault: A Unified Biomechanical Explanation of Chiari Type I. Pediatr Neurosurg.
9105 Wlasiuk P, Niedzielski A, Skorka K, et al. (2015). Accumulation of CD5CD19 B lymphocytes expressing PD-1 and PD-1L in hypertrophied pharyngeal tonsils. Clin Exp Med.
9106 Womack J, Jimenez M. (2015). Common questions about infectious mononucleosis. Am Fam Physician.
9107 Worrall DM, Brant JA, Chai RL, et al. (2015). Cribriform adenocarcinoma of the tongue and minor salivary gland: transoral robotic surgical resection. ORL J Otorhinolaryngol Relat Spec.
9108 Xia Y, Cutrona A, Barreiro TJ. (2015). A man with intractable convulsion. Infectious Diseases in Clinical Practice.
9109 Xie D, Qiu Y, Sha S, et al. (2015). Syrinx resolution is correlated with the upward shifting of cerebellar tonsil following posterior fossa decompression in pediatric patients with Chiari malformation type I. Eur Spine J.
9110 Yamamoto T. (2015). Is tonsillectomy a therapeutic option for plaque-type psoriasis?. J Am Acad Dermatol.
9111 Yaman H, Memis M, Ilhan E. (2015). Comparison of Transoral/Transnasal Endoscopic-Guided Adenoidectomy with Endoscopic Nasopharyngeal Inspection at the End of Curettage Adenoidectomy. Indian J Otolaryngol Head Neck Surg.
9112 Yan M, Wang Z, Niu N, et al. (2015). Relationship between chronic tonsillitis and Henoch-Schonlein purpura. Int J Clin Exp Med.
9113 Ye J, Liu H, Li P, et al. (2015). CD4T-lymphocyte subsets in nonobese children with obstructive sleep apnea syndrome. Pediatr Res.
9114 Ye J, Liu H, Li P, et al. (2015). CD4(+)T-lymphocyte subsets in nonobese children with obstructive sleep apnea syndrome. Pediatr Res.
9115 Yegin Y, Celik M, Olgun B, et al. (2015). Is ventilation tube insertion necessary in children with otitis media with effusion?. Otolaryngol Pol.
9116 Yeh WC, Tang Y, Yeh LR, et al. (2015). Six-year course of POEMS Syndrome: A case report. Chinese Journal of Radiology (Taiwan).
9117 Yenigun A. (2015). The efficacy of tonsillectomy in chronic tonsillitis patients as demonstrated by the neutrophil-to-lymphocyte ratio. J Laryngol Otol.
9118 Yenigun A, Et T, Aytac S, et al. (2015). Comparison of different administration of ketamine and intravenous tramadol hydrochloride for postoperative pain relief and sedation after pediatric tonsillectomy. J Craniofac Surg.
9119 Yeshuroon-Koffler K, Shemer-Avni Y, Keren-Naus A, et al. (2015). Detection of common respiratory viruses in tonsillar tissue of children with obstructive sleep apnea. Pediatr Pulmonol.
9120 Yildizoglu U, Polat B, Gumral R, et al. (2015). Effect of antibiotic use on bacterial flora of tonsil core in patients with recurrent tonsillitis. Eur Arch Otorhinolaryngol.
9121 Yusuf E, Halewyck S, Wybo I, et al. (2015). Fusobacterium necrophorum and other Fusobacterium spp. isolated from head and neck infections: A 10-year epidemiology study in an academic hospital. Anaerobe.
9122 Zhang CX, Liang L, Zhang B, et al. (2015). Imaging Anatomy of Waldeyer's Ring and PET/CT and MRI Findings of Oropharyngeal Non-Hodgkin's Lymphoma. Asian Pac J Cancer Prev.
9123 Zhang S, Long C. (2015). Pediatric Pharyngeal IgD-positive Monoclonal Plasmacytoid and Plasma Cell Neoplasm. J Pediatr Hematol Oncol.
9124 Zhang X, Zheng Y, Xie J, et al. (2015). Long-term Tumor-free Survival With Untreated Primary Diffuse Large B-cell Lymphoma of the Tonsil: A Report of 9 Cases. Am J Surg Pathol.
9125 Zhang XM, Shi J, Meng GZ, et al. (2015). The effect of obstructive sleep apnea syndrome on growth and development in nonobese children: a parallel study of twins. J Pediatr.
9126 Zhou TC, Hsia JC. (2015). The uvulopalatal flap. Operative Techniques in Otolaryngology - Head and Neck Surgery.
9127 Zhu J, Fang Y, Wang HF, et al. (2015). Insulin-like growth factor-1 and insulin-like growth factor-binding protein-3 concentrations in children with obstructive sleep apnea-hypopnea syndrome. Respir Care.
9128 Zwart S. (2015). Less sore throat after (adeno)tonsillectomy. Huisarts en Wetenschap.
9129 Acar OC, Uner A, Garca MF, et al. (2016). The Effect of Tonsillectomy and Adenoidectomy on Right Ventricle Function and Pulmonary Artery Pressure by Using Doppler Echocardiography in Children. Clin Exp Otorhinolaryngol.
9130 Adekwu A, Adoga AS, Gav TA. (2016). Our experience with pre-operative haemostatic assessment of paediatric patients undergoing adenotonsillectomy at Federal Medical Centre, Makurdi. Afr J Paediatr Surg.
9131 Aesif SW, Kuipers I, DePalma L. (2016). The relevance of tissue thiol histochemistry to diagnostic hematopathology. Biotech Histochem.
9132 Ahmad M, Sommerfreund D. (2016). A new analgesic paradigm for pediatric tonsillectomy: Are we dragging our heels?. Can J Anaesth.
9133 Ahmadi MS, Poorolajal J, Masoomi FS, et al. (2016). Effect of adenotonsillectomy on attention deficit-hyperactivity disorder in children with adenotonsillar hypertrophy: A prospective cohort study. Int J Pediatr Otorhinolaryngol.
9134 Akhtar N, Ansar F, Baig M, et al. (2016). Airway fires during surgery: Management and prevention. Journal of Anaesthesiology Clinical Pharmacology.
9135 Akural EI, Alahuhta S, Ohtonen P, et al. (2016). Peritonsillar morphine infiltration to prevent early postoperative pain after tonsillectomy: A randomised controlled trial. Eur J Anaesthesiol.
9136 Ali NS, Sartori-Valinotti JC, Bruce AJ. (2016). Periodic fever, aphthous stomatitis, pharyngitis, and adenitis (PFAPA) syndrome. Clin Dermatol.
9137 Aljfout Q, Alississ A, Rashdan H, et al. (2016). Antibiotics for Post-Tonsillectomy Morbidity: Comparative Analysis of a Single Institutional Experience. J Clin Med Res.
9138 Amani S, Yarmohammadi P. (2016). Study of Effect of Household Parental Smoking on Development of Acute Otitis Media in Children Under 12 Years. Glob J Health Sci.
9139 Amoils M, Chang KW, Saynina O, et al. (2016). Postoperative Complications in Pediatric Tonsillectomy and Adenoidectomy in Ambulatory vs Inpatient Settings. JAMA Otolaryngol Head Neck Surg.
9140 Andrzejowski P, Carroll W. (2016). Codeine in paediatrics: pharmacology, prescribing and controversies. Arch Dis Child Educ Pract Ed.
9141 Arachchi S, Armstrong DS, Roberts N, et al. (2016). Clinical outcomes in a high nursing ratio ward setting for children with obstructive sleep apnea at high risk after adenotonsillectomy. Int J Pediatr Otorhinolaryngol.
9142 Arun Raj GR, Shailaja U, Debnath P, et al. (2016). Exploratory studies on the therapeutic effects of Kumarabharana Rasa in the management of chronic tonsillitis among children at a tertiary care hospital of Karnataka. J Tradit Complement Med.
9143 Ashman A, Harris R. (2016). Outpatient management of patients with acute tonsillitis and peritonsillar abscess in ninety adult patients. Clin Otolaryngol.
9144 Assadian F, Sandstrom K, Bondeson K, et al. (2016). Distribution and Molecular Characterization of Human Adenovirus and Epstein-Barr Virus Infections in Tonsillar Lymphocytes Isolated from Patients Diagnosed with Tonsillar Diseases. PLoS One.
9145 Atan D, Apaydin E, Ozcan KM, et al. (2016). Does Tonsillectomy Affect Voice in Early or Late Postoperative Periods in Adults?. J Voice.
9146 Ayatollahi V, Dehghanpoor-Farashah S, Behdad S, et al. (2016). Effect of intravenous vitamin C on post-operative pain in uvulopalatopharyngoplasty with tonsillectomy. Clin Otolaryngol.
9147 Babademez MA, Gul F, Muz E, et al. (2016). Impact of partial and total tonsillectomy on adenoid regrowth. Laryngoscope.
9148 Barrett G, Williams R, Elias-Jones W, et al. (2016). A multicentre 2-cycle retrospective audit of post-operative haemorrhages from 2169 tonsillectomies. Clin Otolaryngol.
9149 Barzilai O, Roth J, Korn A, et al. (2016). The value of multimodality intraoperative neurophysiological monitoring in treating pediatric Chiari malformation type I. Acta Neurochir (Wien).
9150 Bechtel-Grosch U, Beguelin C, Berezowska S, et al. (2016). Fulminant hepatic and multiple organ failure following acute viral tonsillitis: a case report. J Med Case Rep.
9151 Bellon M, Le Bot A, Michelet D, et al. (2016). Efficacy of Intraoperative Dexmedetomidine Compared with Placebo for Postoperative Pain Management: A Meta-Analysis of Published Studies. Pain Ther.
9152 Bergallo M, Loiacono E, Gambarino S, et al. (2016). Standard and immunoproteasomes expression in paediatric tonsillectomy patients. Minerva Pediatr.
9153 Bhattacharjee R, Kheirandish-Gozal L, Kaditis AG, et al. (2016). C-reactive Protein as a Potential Biomarker of Residual Obstructive Sleep Apnea Following Adenotonsillectomy in Children. Sleep.
9154 Bitar MA, Nassar J, Dana R. (2016). Is the effect of topical intranasal steroids on obstructive adenoids transient or long-lasting? Case series and systematic review of literature. J Laryngol Otol.
9155 Borovich A, Sivan Y, Greenfeld M, et al. (2016). The history of primary snoring in children: the effect of adenotonsillectomy. Sleep Med.
9156 Bostwick B, Fang P, Patel A, et al. (2016). Phenotypic and molecular characterization of focal dermal hypoplasia in 18 individuals. Am J Med Genet C Semin Med Genet.
9157 Bramhagen AC, Eriksson M, Ericsson E, et al. (2016). Self-reported post-operative recovery in children: development of an instrument. J Eval Clin Pract.
9158 Brant JA, Bur AM, Chai R, et al. (2016). Reoperation following Adult Tonsillectomy: Review of the American College of Surgeons National Surgical Quality Improvement Program. Otolaryngol Head Neck Surg.
9159 Browaldh N, Bring J, Friberg D. (2016). SKUP(3) RCT; continuous study: Changes in sleepiness and quality of life after modified UPPP. Laryngoscope.
9160 Brown R, Fortier MA, Zolghadr S, et al. (2016). Postoperative Pain Management in Children of Hispanic Origin: A Descriptive Cohort Study. Anesth Analg.
9161 Burton MJ, Goldstein NA, Rosenfeld RM. (2016). Cochrane Corner: Extracts from The Cochrane Library: Tonsillectomy or Adenotonsillectomy versus Non-Surgical Management for Obstructive Sleep-Disordered Breathing in Children. Otolaryngol Head Neck Surg.
9162 Camacho M, Li D, Kawai M, et al. (2016). Tonsillectomy for adult obstructive sleep apnea: A systematic review and meta-analysis. Laryngoscope.
9163 Can U, Sayar E, Serdar MA. (2016). Macro-aspartate aminotransferase (AST): A case report. Turkish Journal of Biochemistry.
9164 Capaccio P, Torretta S, Marciante GA, et al. (2016). Endoscopic Adenoidectomy in Children With Otitis Media With Effusion and Mild Hearing Loss. Clin Exp Otorhinolaryngol.
9165 Carr MM, Derr JB, Karikari K. (2016). Decisional Conflict and Regret in Parents Whose Children Undergo Tonsillectomy. Otolaryngol Head Neck Surg.
9166 Castano JE, Freiser ME, Ramadan HH. (2016). Complications Following Inpatient Extracapsular Tonsillectomy in Children 36 Months and Younger. JAMA Otolaryngol Head Neck Surg.
9167 Chaturvedi AK, Song H, Rosenberg PS, et al. (2016). Tonsillectomy and incidence of oropharyngeal cancers. Cancer Epidemiol Biomarkers Prev.
9168 Chau WW, Chu WC, Lam TP, et al. (2016). Anatomical Origin of Abnormal Somatosensory-Evoked Potential (SEP) in Adolescent Idiopathic Scoliosis With Different Curve Severity and Correlation With Cerebellar Tonsillar Level Determined by MRI. Spine (Phila Pa 1976).
9169 Chelo D, Nguefack F, Menanga AP, et al. (2016). Spectrum of heart diseases in children: an echocardiographic study of 1,666 subjects in a pediatric hospital, Yaounde, Cameroon. Cardiovasc Diagn Ther.
9170 Chen X, Li JR. (2016). Glucocorticoid receptor expression in the tonsils of children with obstructive sleep apnea hypopnea syndrome. Genet Mol Res.
9171 Chidambaran V, Venkatasubramanian R, Zhang X, et al. (2016). ABCC3 genetic variants are associated with postoperative morphine-induced respiratory depression and morphine pharmacokinetics in children. Pharmacogenomics J.
9172 Cho HJ, Park DY, Min HJ, et al. (2016). Endoscope-guided coblator tongue base resection using an endoscope-holding system for obstructive sleep apnea. Head Neck.
9173 Cho HK, Park IJ, Jeong YM, et al. (2016). Can perioperative acupuncture reduce the pain and vomiting experienced after tonsillectomy? A meta-analysis. Laryngoscope.
9174 Choi YJ, Lee JH, Kim HO, et al. (2016). Histogram Analysis of Apparent Diffusion Coefficients for Occult Tonsil Cancer in Patients with Cervical Nodal Metastasis from an Unknown Primary Site at Presentation. Radiology.
9175 Chung S, Hodges EK, Ruzicka DL, et al. (2016). Improved behavior after adenotonsillectomy in children with higher and lower IQ. Int J Pediatr Otorhinolaryngol.
9176 Cielo CM, Gungor A. (2016). Treatment Options for Pediatric Obstructive Sleep Apnea. Curr Probl Pediatr Adolesc Health Care.
9177 Cohen N, Sommer DD. (2016). Post-tonsillectomy pain control: consensus or controversy?. Pain Manag.
9178 Cooper L. (2016). Post-tonsillectomy management: A framework. Aust Fam Physician.
9179 Coordes A, Soudry J, Hofmann VM, et al. (2016). Gender-specific risk factors in post-tonsillectomy hemorrhage. Eur Arch Otorhinolaryngol.
9180 Couto EV, Ballin CR, Sampaio CP, et al. (2016). Experimental study on the effects of bismuth subgallate on the inflammatory process and angiogenesis of the oral mucosa. Braz J Otorhinolaryngol.
9181 Das AJ, Valdez TA, Vargas JA, et al. (2016). Volume estimation of tonsil phantoms using an oral camera with 3D imaging. Biomedical Optics Express.
9182 Dayal R, Agarwal D. (2016). Fever in Children and Fever of Unknown Origin. Indian J Pediatr.
9183 Derin S, Erdogan S, Sahan M, et al. (2016). Neutrophil-Lymphocyte Ratio in Patients with Adenoidectomy. J Clin Diagn Res.
9184 Di Francesco RC, Alvarez J. (2016). Allergic rhinitis affects the duration of rapid eye movement sleep in children with sleep-disordered breathing without sleep apnea. Int Forum Allergy Rhinol.
9185 Di Francesco RC, Kreibich MS. (2016). Is the difference in the volume of the pharyngeal space, as measured by acoustic pharyngometry, before and after tonsillectomy proportional to the volume of the excised tonsils?. Clinics (Sao Paulo).
9186 Dimatos SC, Neves LR, Beltrame JM, et al. (2016). Impact of adenotonsillectomy on vocal emission in children. Braz J Otorhinolaryngol.
9187 Dou G, Zhang Y, Zong C, et al. (2016). Application of surgical navigation in styloidectomy for treating Eagle's syndrome. Ther Clin Risk Manag.
9188 Dudley KA, Patel SR. (2016). Disparities and genetic risk factors in obstructive sleep apnea. Sleep Med.
9189 Estcourt LJ, Fortin PM, Trivella M, et al. (2016). Preoperative blood transfusions for sickle cell disease. Cochrane Database Syst Rev.
9190 Esteller E, Villatoro JC, Pedemonte G, et al. (2016). Surgical treatment for childhood obstructive sleep apnoea: Cold-knife tonsillar dissection versus bipolar radiofrequency thermal ablation. Acta Otorrinolaringol Esp.
9191 Farnebo L, Laurell G, Makitie A. (2016). A Nordic survey on the management of head and neck CUP. Acta Otolaryngol.
9192 Feehally J, Coppo R, Troyanov S, et al. (2016). Tonsillectomy in a European Cohort of 1,147 Patients with IgA Nephropathy. Nephron.
9193 Feinberg M, Babington P, Sood S, et al. (2016). Isolated unilateral trismus as a presentation of Chiari malformation: case report. J Neurosurg Pediatr.
9194 Feriozzi S, Polci R. (2016). The role of tonsillectomy in IgA nephropathy. J Nephrol.
9195 Flores-Gallegos L, Hidalgo-Bravo A, Casas-Avila L, et al. (2016). Clinical and molecular analysis in a series of Mexican patients with clinical diagnosis of Fibrodysplasia Ossificans Progressiva (FOP). International Journal of Clinical and Experimental Medicine.
9196 Fu TS, Foreman A, Goldstein DP, et al. (2016). The role of transoral robotic surgery, transoral laser microsurgery, and lingual tonsillectomy in the identification of head and neck squamous cell carcinoma of unknown primary origin: a systematic review. J Otolaryngol Head Neck Surg.
9197 Gammal RS, Crews KR, Haidar CE, et al. (2016). Pharmacogenetics for Safe Codeine Use in Sickle Cell Disease. Pediatrics.
9198 Garetz SL. (2016). Limited data suggest that otherwise healthy school-aged children with obstructive sleep disordered breathing have some benefit from adenotonsillectomy compared with non-surgical treatment. Evid Based Med.
9199 Garg A, Singh Y, Singh P, et al. (2016). Carotid artery dissection following adenoidectomy. Int J Pediatr Otorhinolaryngol.
9200 Giordano M, Di Rocco C. (2016). Iatrogenic intradiploic cerebrospinal fluid collection. Childs Nerv Syst.
9201 Gregori G, Righi O, Risso P, et al. (2016). Reduction of group A beta-hemolytic streptococcus pharyngo-tonsillar infections associated with use of the oral probiotic Streptococcus salivarius K12: a retrospective observational study. Ther Clin Risk Manag.
9202 Guilleminault C, Abad VC, Chiu HY, et al. (2016). Missing teeth and pediatric obstructive sleep apnea. Sleep Breath.
9203 Gulec E, Biricik E, Turktan M, et al. (2016). The Effect of Intravenous Dexamethasone on Sugammadex Reversal Time in Children Undergoing Adenotonsillectomy. Anesth Analg.
9204 Gungor G, Sutas Bozkurt P, Yener HM, et al. (2016). Comparison of anesthetic agents on otoacoustic emissions in children: propofol vs ketamine. Paediatr Anaesth.
9205 Guntinas-Lichius O, Geissler K, Komann M, et al. (2016). Inter-Hospital Variability of Postoperative Pain after Tonsillectomy: Prospective Registry-Based Multicentre Cohort Study. PLoS One.
9206 Haddad N, Morris T, Dhillon R, et al. (2016). Unusual neurological presentation of Fusobacterium necrophorum disease. BMJ Case Rep.
9207 Hakim M, Krishna SG, Syed A, et al. (2016). Oropharyngeal oxygen and volatile anesthetic agent concentration during the use of laryngeal mask airway in children. Paediatr Anaesth.
9208 Hamid Z, Arul P, Madatang A, et al. (2016). Hamartomatous polyp of the palatine tonsil: A case report. International Medical Journal.
9209 Hart JA, Glickman-Simon R. (2016). Phytomedicines for Helicobacter pylori, Garlic for Hypertension, Intraoperative Acupuncture for Tonsillectomy, Omega-3 Fatty Acids for Cognitive Decline, Qigong for COPD. Explore (NY).
9210 Hendry J, Chin A, Swan IR, et al. (2016). The Glasgow Benefit Inventory: a systematic review of the use and value of an otorhinolaryngological generic patient-recorded outcome measure. Clin Otolaryngol.
9211 Hill CA, Beach M, Smith MC, et al. (2016). Incidence of and Factors Associated With Hypogeusia in Healthy Children. JAMA Otolaryngol Head Neck Surg.
9212 Hill CA, Thimmappa V, Smith MC, et al. (2016). Incidence of Visualization of the Glossopharyngeal Nerve after Pediatric Tonsillectomy. Otolaryngol Head Neck Surg.
9213 Hirshoren N, Olayos E, Callahan J, et al. (2016). PET/CT findings within the contralateral tonsil following unilateral tonsillectomy. Laryngoscope.
9214 Ho AW, Moul DE, Krishna J. (2016). Neck Circumference-Height Ratio as a Predictor of Sleep Related Breathing Disorder in Children and Adults. J Clin Sleep Med.
9215 Holmlund T, Franklin KA, Levring Jaghagen E, et al. (2016). Tonsillectomy in adults with obstructive sleep apnea. Laryngoscope.
9216 Hwang SH, Park IJ, Cho YJ, et al. (2016). The efficacy of gabapentin/pregabalin in improving pain after tonsillectomy: A meta-analysis. Laryngoscope.
9217 Imanguli M, Ulualp SO. (2016). Risk factors for residual obstructive sleep apnea after adenotonsillectomy in children. Laryngoscope.
9218 Ishman SL, Tang A, Cohen AP, et al. (2016). Decision Making for Children with Obstructive Sleep Apnea without Tonsillar Hypertrophy. Otolaryngol Head Neck Surg.
9219 Izadi P, Delavar P, Yarmohammadi ME, et al. (2016). Effect of supplemental oxygen 80 % on post-tonsillectomy nausea and vomiting: a randomized controlled trial. Eur Arch Otorhinolaryngol.
9220 Jain A, Shelley S, Muthukrishnan I, et al. (2016). Diagnostic importance of contrast enhanced <sup>18</sup> F-fluorodeoxyglucose positron emission computed tomography in patients with tumor induced osteomalacia: Our experience. Indian Journal of Nuclear Medicine.
9221 Jeon YJ, Song JJ, Ahn JC, et al. (2016). Immediate and Sustained Improvement in Behavior and Life Quality by Adenotonsillectomy in Children With Sleep-Disordered Breathing. Clin Exp Otorhinolaryngol.
9222 Ji J, Sundquist J, Sundquist K. (2016). Tonsillectomy associated with an increased risk of autoimmune diseases: A national cohort study. J Autoimmun.
9223 Kang KT, Weng WC, Lee CH, et al. (2016). Clinical risk assessment model for pediatric obstructive sleep apnea. Laryngoscope.
9224 Kara M, Erdogan H, Altinisik HB, et al. (2016). Does topical use of autologous serum help to reduce post-tonsillectomy morbidity? A prospective, controlled preliminary study. J Laryngol Otol.
9225 Karunanayake CP, Albritton W, Rennie DC, et al. (2016). Ear Infection and Its Associated Risk Factors in First Nations and Rural School-Aged Canadian Children. Int J Pediatr.
9226 Kawabata M, Umakoshi M, Makise T, et al. (2016). Clinical classification of peritonsillar abscess based on CT and indications for immediate abscess tonsillectomy. Auris Nasus Larynx.
9227 Kawasaki Y, Maeda R, Kanno S, et al. (2016). Long-term follow-up outcome of pediatric IgA nephropathy treated with tonsillectomy plus methylprednisolone pulse therapy. Pediatr Int.
9228 Kennedy BC, Kelly KM, Anderson RC, et al. (2016). Isolated thoracic syrinx in children with Chiari I malformation. Childs Nerv Syst.
9229 Kheirandish-Gozal L, Philby MF, Alonso-Alvarez ML, et al. (2016). Biomarkers of Alzheimer Disease in Children with Obstructive Sleep Apnea: Effect of Adenotonsillectomy. Sleep.
9230 Kiaer EK, Bock T, Tingsgaard PK. (2016). Tonsillotomy in children with sleep-disordered breathing is safe and results in high parent satisfaction. Dan Med J.
9231 Kim JH, Jeong HS, Kim KM, et al. (2016). Extra-Esophageal Pepsin from Stomach Refluxate Promoted Tonsil Hypertrophy. PLoS One.
9232 Kimiaei Asadi H, Nikooseresht M, Noori L, et al. (2016). The Effect of Administration of Ketamine and Paracetamol Versus Paracetamol Singly on Postoperative Pain, Nausea and Vomiting After Pediatric Adenotonsillectomy. Anesth Pain Med.
9233 Kitamura T, Miyazaki S, Kobayashi R, et al. (2016). Obstructive sleep apnea in preschool-aged Japanese children - efficiency of screening using lateral neck radiography. Acta Otolaryngol.
9234 Kono M, Hasegawa J, Ogawa T, et al. (2016). Immunoglobulin A Nephropathy in a Living Kidney Donor Diagnosed and Treated After Transplantation: A Case Report. Transplant Proc.
9235 Koycu A, Aydin E, Tulgar Kinik S. (2016). Changes in body composition and growth pattern after adenotonsillectomy in prepubertal children. Int J Pediatr Otorhinolaryngol.
9236 Kunnamo A, Korppi M, Helminen M. (2016). Tonsillitis in children: unnecessary laboratory studies and antibiotic use. World J Pediatr.
9237 Lam DJ, Weaver EM, Macarthur CJ, et al. (2016). Assessment of pediatric obstructive sleep apnea using a drug-induced sleep endoscopy rating scale. Laryngoscope.
9238 Lee BJ, Kang DW, Park HY, et al. (2016). Isolation and Localization of Mesenchymal Stem Cells in Human Palatine Tonsil by W5C5 (SUSD2). Cell Physiol Biochem.
9239 Lee MG, Kim HJ, Lee KH, et al. (2016). The Influence of Genotype Polymorphism on Morphine Analgesic Effect for Postoperative Pain in Children. Korean J Pain.
9240 Lepelletier D, Pinaud V, Le Conte P, et al. (2016). Peritonsillar abscess (PTA): clinical characteristics, microbiology, drug exposures and outcomes of a large multicenter cohort survey of 412 patients hospitalized in 13 French university hospitals. Eur J Clin Microbiol Infect Dis.
9241 Li X, Zhou M, Xia Q, et al. (2016). Parecoxib sodium reduces the need for opioids after tonsillectomy in children: a double-blind placebo-controlled randomized clinical trial. Can J Anaesth.
9242 Lourijsen ES, Wong Chung JE, Koopman JP, et al. (2016). Post-operative morbidity and 1-year outcomes in CO2-laser tonsillotomy versus dissection tonsillectomy. Acta Otolaryngol.
9243 Luk LJ, Mosen D, MacArthur CJ, et al. (2016). Implementation of a Pediatric Posttonsillectomy Pain Protocol in a Large Group Practice. Otolaryngol Head Neck Surg.
9244 Machado-Junior AJ, Zancanella E, Crespo AN. (2016). Rapid maxillary expansion and obstructive sleep apnea: A review and meta-analysis. Med Oral Patol Oral Cir Bucal.
9245 Magnussen MD, Gaini S, Gislason H, et al. (2016). Antibacterial resistance in Streptococcus pyogenes (GAS) from healthy carriers and tonsillitis patients and association with antibacterial sale in the Faroe Islands. Apmis.
9246 Martin-Mateos MA, Piquer Gibert M. (2016). Primary immunodeficiencies and B-cell lymphomas. Boletin Medico del Hospital Infantil de Mexico.
9247 McGinley BM, Kirkness JP, Schneider H, et al. (2016). Utilizing inspiratory airflows during standard polysomnography to assess pharyngeal function in children during sleep. Pediatr Pulmonol.
9248 Miller SC, Nguyen SA, Ong AA, et al. (2016). Transoral robotic base of tongue reduction for obstructive sleep apnea: A systematic review and meta-analysis. Laryngoscope.
9249 Min CB, Kain ZN, Stevenson RS, et al. (2016). A randomized trial examining preoperative sedative medication and postoperative sleep in children. J Clin Anesth.
9250 Miranda SP, Kimmell KT, Silberstein HJ. (2016). Acute Presentation of Chiari I Malformation with Hemiparesis in a Pediatric Patient. World Neurosurg.
9251 Mitchell RM, Parikh SR. (2016). Hemostasis in Tonsillectomy. Otolaryngol Clin North Am.
9252 Miyasato Y, Miyoshi T, Fujimoto D, et al. (2016). Successful treatment of rapidly progressive Immunoglobulin A nephropathy with human immunodeficiency virus infection by steroid pulse therapy and tonsillectomy. Nephrology (Carlton).
9253 Moeen SM. (2016). Could acupuncture be an adequate alternative to dexamethasone in pediatric tonsillectomy?. Paediatr Anaesth.
9254 Mostovych N, Holmes L, Ruszkay N, et al. (2016). Effectiveness of Powered Intracapsular Tonsillectomy in Children With Severe Obstructive Sleep Apnea. JAMA Otolaryngol Head Neck Surg.
9255 Muderris T, Gul F, Yalciner G, et al. (2016). Oral Flurbiprofen Spray for Posttonsillectomy Pain. Otolaryngol Head Neck Surg.
9256 Munonyara M, Kamani T. (2016). Nurse-led 'one stop' clinic for elective tonsillectomy referrals: Patient satisfaction of the service. Otorhinolaryngologist.
9257 Murray R, Logvinenko T, Roberson D. (2016). Frequency and cause of readmissions following pediatric otolaryngologic surgery. Laryngoscope.
9258 Mylavarapu G, Subramaniam D, Jonnagiri R, et al. (2016). Computational Modeling of Airway Obstruction in Sleep Apnea in Down Syndrome: A Feasibility Study. Otolaryngol Head Neck Surg.
9259 Nanke Y, Kobasigawa T, Yoda K, et al. (2016). Tonsillectomy to Effectively Treat a Patient with Behcet's Disease. Intern Med.
9260 Nardone HC, McKee-Cole KM, Friedman NR. (2016). Current Pediatric Tertiary Care Admission Practices Following Adenotonsillectomy. JAMA Otolaryngol Head Neck Surg.
9261 Newton L, Sulman C. (2016). A Pilot Program: Using Text Messaging to Improve Timely Communication to Tonsillectomy Patients. ORL Head Neck Nurs.
9262 Niewiadomski O, Studd C, Wilson J, et al. (2016). Influence of food and lifestyle on the risk of developing Inflammatory Bowel Disease. Intern Med J.
9263 O'Connell Ferster AP, Tanner AM, Karikari K, et al. (2016). Factors related to persisting perforations after ventilation tube insertion. Int J Pediatr Otorhinolaryngol.
9264 Ohashi T, Hiraiwa T, Yamamoto T. (2016). Low prevalence of anti-cyclic citrullinated peptide antibodies in Japanese patients with pustulotic arthro-osteitis. Indian Journal of Dermatology.
9265 Olsen GH, Krishna SG, Jatana KR, et al. (2016). Changes in intracuff pressure of cuffed endotracheal tubes while positioning for adenotonsillectomy in children. Paediatr Anaesth.
9266 Olszewska-Sosinska O, Zielnik-Jurkiewicz B, Stepinska M, et al. (2016). Persistence of non-typeable Haemophilus Influenzae in the pharynx of children with adenotonsillar hypertrophy after treatment with azithromycin. Pathog Dis.
9267 Omana-Cepeda C, Martinez-Valverde A, Del Mar Sabater-Recolons M, et al. (2016). A literature review and case report of hand, foot and mouth disease in an immunocompetent adult. BMC Res Notes.
9268 Pang Y, Gong J, Huang J, et al. (2016). Coblation tonsillectomy under surgical microscopy: A retrospective study. J Int Med Res.
9269 Papandreou A, Hedrera-Fernandez A, Kaliakatsos M, et al. (2016). An unusual presentation of paediatric Listeria meningitis with selective spinal grey matter involvement and acute demyelinating polyneuropathy. Eur J Paediatr Neurol.
9270 Park S, Choi Y, Jung N, et al. (2016). Myogenic differentiation potential of human tonsil-derived mesenchymal stem cells and their potential for use to promote skeletal muscle regeneration. Int J Mol Med.
9271 Park S, Lee JM, Sim CS, et al. (2016). Impact of adenotonsillectomy on nocturnal enuresis in children with sleep-disordered breathing: A prospective study. Laryngoscope.
9272 Patel A, Foden N, Rachmanidou A. (2016). Is weekend surgery a risk factor for post-tonsillectomy haemorrhage?. J Laryngol Otol.
9273 Paulucci BP, Pereira J, Picciarelli P, et al. (2016). Expression of CysLTR1 and 2 in Maturating Lymphocytes of Hyperplasic Tonsils Compared to Peripheral Cells in Children. Inflammation.
9274 Pearson CR. (2016). Worrying tonsillectomy. J R Soc Med.
9275 Pfaff JA, Hsu K, Chennupati SK. (2016). The Use of Ibuprofen in Posttonsillectomy Analgesia and Its Effect on Posttonsillectomy Hemorrhage Rate. Otolaryngol Head Neck Surg.
9276 Pianosi K, Gorodzinsky AY, Chorney JM, et al. (2016). Informed Consent in Pediatric Otolaryngology: What Risks and Benefits Do Parents Recall?. Otolaryngol Head Neck Surg.
9277 Pinheiro-Neto CD, Galati LT. (2016). Nasoseptal flap for reconstruction after robotic radical tonsillectomy. Head Neck.
9278 Pohl S, Roedler FS, Oechtering GU. (2016). How does multilevel upper airway surgery influence the lives of dogs with severe brachycephaly? Results of a structured pre- and postoperative owner questionnaire. Vet J.
9279 Pomeraniec IJ, Ksendzovsky A, Awad AJ, et al. (2016). Natural and surgical history of Chiari malformation Type I in the pediatric population. J Neurosurg Pediatr.
9280 Pontin IP, Sanchez DC, Di Francesco R. (2016). Asymptomatic Group A Streptococcus carriage in children with recurrent tonsillitis and tonsillar hypertrophy. Int J Pediatr Otorhinolaryngol.
9281 Powell T, Sharma N, McKie KT. (2016). Postobstructive Pulmonary Edema following Tonsillectomy/Adenoidectomy in a 2-Year-Old with Poland-Moebius Syndrome. Case Rep Otolaryngol.
9282 Principi N, Marchisio P, Esposito S. (2016). Otitis media with effusion: benefits and harms of strategies in use for treatment and prevention. Expert Rev Anti Infect Ther.
9283 Propst EJ, Amin R, Talwar N, et al. (2016). Midline posterior glossectomy and lingual tonsillectomy in obese and nonobese children with down syndrome: Biomarkers for success. Laryngoscope.
9284 Rajesh MC. (2016). Prion body contamination: Is it not relevant in indian context?. Indian Journal of Anaesthesia.
9285 Rasband-Lindquist A, Shnayder Y, O'Neil M. (2016). Synchronous bilateral tonsillar squamous cell carcinoma related to human papillomavirus: Two case reports and a brief review of the literature. Ear Nose Throat J.
9286 Rice JC. (2016). Garnett Passe and the tonsillectomy gag. J Laryngol Otol.
9287 Rigante D, Vitale A, Natale MF, et al. (2016). A comprehensive comparison between pediatric and adult patients with periodic fever, aphthous stomatitis, pharyngitis, and cervical adenopathy (PFAPA) syndrome. Clin Rheumatol.
9288 Risoud M, Mortuaire G, Chevalier D, et al. (2016). Atypical Lemierre syndrome. Eur Ann Otorhinolaryngol Head Neck Dis.
9289 Rohlfing ML, Wistermayer PR, Bungo TM, et al. (2016). Investigation of Postoperative Oral Fluid Intake as a Predictor of Postoperative Emergency Department Visits After Pediatric Tonsillectomy. JAMA Otolaryngol Head Neck Surg.
9290 Rosenfeld RM, Shin JJ, Schwartz SR, et al. (2016). Clinical Practice Guideline: Otitis Media with Effusion Executive Summary (Update). Otolaryngol Head Neck Surg.
9291 Rosenfeld RM, Shin JJ, Schwartz SR, et al. (2016). Clinical Practice Guideline: Otitis Media with Effusion (Update). Otolaryngol Head Neck Surg.
9292 Roy S, Bigcas JL, Vandelaar L. (2016). Hemostasis in Pediatric Surgery. Otolaryngol Clin North Am.
9293 Ruan X, Salinas OJ, Kaye AD. (2016). Peritonsillar morphine infiltration to prevent early postoperative pain after tonsillectomy. Eur J Anaesthesiol.
9294 Sagiroglu A, Acer N, Okuducu H, et al. (2016). Palatine tonsil volume estimation using different methods after tonsillectomy. Anat Sci Int.
9295 Sakai N, Kawasaki Y, Waragai T, et al. (2016). Successful therapy with tonsillectomy plus pulse therapy for the relapse of pediatric IgA nephropathy treated with multi-drugs combination therapy. Fukushima J Med Sci.
9296 Salatino S, Gray A. (2016). Integrative management of pediatric tonsillopharyngitis: An international survey. Complement Ther Clin Pract.
9297 Samareh Fekri M, Arabi Mianroodi A, Shakeri H, et al. (2016). Effects of Tonsil size on Pulmonary Function test Results after Tonsillectomy in Children. Iran J Otorhinolaryngol.
9298 Sattar MA, Sultana T. (2016). Comparison of Common Tonsillectomy Methods. Mymensingh Med J.
9299 Sawada A, Kawanishi K, Horita S, et al. (2016). Proliferative glomerulonephritis with monoclonal immunoglobulin G deposits complicated by immunoglobulin A nephropathy in the renal allograft. Nephrology (Carlton).
9300 Scott B, Johnson RF, Mitchell Md RB. (2016). Obstructive Sleep Apnea: Differences between Normal-Weight, Overweight, Obese, and Morbidly Obese Children. Otolaryngol Head Neck Surg.
9301 Segal D, Heary RF, Sabharwal S, et al. (2016). Severe holocord syrinx in a child with megalencephaly-capillary malformation syndrome. J Neurosurg Pediatr.
9302 Selvadurai S, Al-Saleh S, Amin R, et al. (2016). Utility of brain MRI in children with sleep-disordered breathing. Laryngoscope.
9303 Sharma A, Albergotti WG, Duvvuri U. (2016). Applications of Evolving Robotic Technology for Head and Neck Surgery. Ann Otol Rhinol Laryngol.
9304 Sharma S, Yao A, Mahalingam S, et al. (2016). Compliance of ENT emergency surgery with the Royal College of Surgeons standards. Ann R Coll Surg Engl.
9305 Shaul C, Attal PD, Schwarz Y, et al. (2016). Bipolar tonsillotomy: A novel and effective tonsillotomy technique. Int J Pediatr Otorhinolaryngol.
9306 Shay S, Shapiro NL, Bhattacharyya N. (2016). Patterns of Hospital Use and Regionalization of Inpatient Pediatric Adenotonsillectomy. JAMA Otolaryngol Head Neck Surg.
9307 Shin HC, Kim JS, Lee SK, et al. (2016). The effect of acupuncture on postoperative nausea and vomiting after pediatric tonsillectomy: A meta-analysis and systematic review. Laryngoscope.
9308 Sidjabat HE, Grahn Hakansson E, Cervin A. (2016). Draft Genome Sequence of the Oral Commensal Streptococcus oralis 89a with Interference Activity against Respiratory Pathogens. Genome Announc.
9309 Simsek A, Bayraktar C, Dogan S, et al. (2016). Retinal Nerve Fiber Layer Thickness Alteration in Apneic Children. Optom Vis Sci.
9310 Slouka D, Polenik P, Hes O, et al. (2016). Can we improve clinical results of tonsillectomy using lasers?. Journal of Applied Biomedicine.
9311 Sobel RH, Blanco R, Ha PK, et al. (2016). Implementation of a comprehensive competency-based transoral robotic surgery training curriculum with ex vivo dissection models. Head Neck.
9312 Somaini M, Engelhardt T, Fumagalli R, et al. (2016). Emergence delirium or pain after anaesthesia-how to distinguish between the two in young children: a retrospective analysis of observational studies. Br J Anaesth.
9313 Sommer UJ, Heiser C, Gahleitner C, et al. (2016). Tonsillectomy with Uvulopalatopharyngoplasty in Obstructive Sleep Apnea. Dtsch Arztebl Int.
9314 Somuk BT, Bozkurt H, Goktas G, et al. (2016). Impact of adenotonsillectomy on ADHD and nocturnal enuresis in children with chronic adenotonsillar hypertrophy. Am J Otolaryngol.
9315 Somuk BT, Sapmaz E, Soyalic H, et al. (2016). Evaluation of iron and zinc levels in recurrent tonsillitis and tonsillar hypertrophy. Am J Otolaryngol.
9316 Son EL, Underbrink MP, Qiu S, et al. (2016). The surgical plane for lingual tonsillectomy: an anatomic study. J Otolaryngol Head Neck Surg.
9317 Song SA, Tolisano AM, Cable BB, et al. (2016). Neurocognitive outcomes after pediatric adenotonsillectomy for obstructive sleep apnea: A systematic review and meta-analysis. Int J Pediatr Otorhinolaryngol.
9318 Soylu E, Soylu N, Polat C, et al. (2016). Developmental delays in preschool children with adenotonsillar hypertrophy. Kulak Burun Bogaz Ihtis Derg.
9319 Spector ME, Glazer TA, Hoff PT. (2016). Addressing the Retrolingual Space in Obstructive Sleep Apnea: Outcomes Stratified by Friedman Stage in Patients Undergoing Transoral Robotic Surgery. ORL J Otorhinolaryngol Relat Spec.
9320 Spektor Z, Saint-Victor S, Kay DJ, et al. (2016). Risk factors for pediatric post-tonsillectomy hemorrhage. Int J Pediatr Otorhinolaryngol.
9321 Splendiani A, Felli V, Di Sibio A, et al. (2016). Magnetic resonance imaging and magnetic resonance spectroscopy in a young male patient with anti-N-methyl-D-aspartate receptor encephalitis and uncommon cerebellar involvement: A case report with review of the literature. Neuroradiol J.
9322 Spruijt B, Rijken BF, den Ottelander BK, et al. (2016). First Vault Expansion in Apert and Crouzon-Pfeiffer Syndromes: Front or Back?. Plast Reconstr Surg.
9323 Storck K, Kreiser K, Hauber J, et al. (2016). Management and prevention of acute bleedings in the head and neck area with interventional radiology. Head Face Med.
9324 Stork NC, Smoot MK. (2016). Pregame Sore Throat, Postgame Intensive Care Unit. Clin J Sport Med.
9325 Stuck BA, Maurer JT. (2016). Recent developments in the diagnosis and treatment of obstructive sleep apnea : English version. Hno.
9326 Tan HL, Kheirandish-Gozal L, Gozal D. (2016). Obstructive sleep apnea in children: update on the recognition, treatment and management of persistent disease. Expert Rev Respir Med.
9327 Tang A, Gropler M, Duggins AL, et al. (2016). Gaps in evidence: Management of pediatric obstructive sleep apnea without tonsillar hypertrophy. Laryngoscope.
9328 Tapia IE, Marcus CL, McDonough JM, et al. (2016). Airway Resistance in Children with Obstructive Sleep Apnea Syndrome. Sleep.
9329 Tejesvi MV, Uhari M, Tapiainen T, et al. (2016). Tonsillar microbiota in children with PFAPA (periodic fever, aphthous stomatitis, pharyngitis, and adenitis) syndrome. Eur J Clin Microbiol Infect Dis.
9330 Terreri MT, Bernardo WM, Len CA, et al. (2016). Guidelines for the management and treatment of periodic fever syndromes: periodic fever, aphthous stomatitis, pharyngitis and adenitis syndrome. Rev Bras Reumatol.
9331 Thabit MN, Elnady HM, Shahat B, et al. (2016). Cognitive event related potentials in patients with adenoid hypertrophy; a case control pilot study. J Clin Neurophysiol.
9332 Thorleifsdottir RH, Eysteinsdottir JH, Olafsson JH, et al. (2016). Throat Infections are Associated with Exacerbation in a Substantial Proportion of Patients with Chronic Plaque Psoriasis. Acta Derm Venereol.
9333 Tien DA, Woodson EA, Anne S. (2016). Safety of Monopolar Electrocautery in Patients With Cochlear Implants. Ann Otol Rhinol Laryngol.
9334 Tong Y, Udupa JK, Odhner D, et al. (2016). Minimally interactive segmentation of 4D dynamic upper airway MR images via fuzzy connectedness. Med Phys.
9335 Tsubomatsu C, Shintani T, Abe A, et al. (2016). Diagnosis and Treatment of Obstructive Sleep Apnea Syndrome in Children. Adv Otorhinolaryngol.
9336 Tubbs RS, Demerdash A, Oskouian RJ, et al. (2016). Evolution of cerebellar tonsillar ischemia to cerebellar tonsillar cysts in the Chiari I malformation: radiological, surgical, and histological evidence. Childs Nerv Syst.
9337 Tubbs RS, Kirkpatrick CM, Rizk E, et al. (2016). Do the cerebellar tonsils move during flexion and extension of the neck in patients with Chiari I malformation? A radiological study with clinical implications. Childs Nerv Syst.
9338 Turkoglu Babakurban S, Aydin E. (2016). Adenoidectomy: current approaches and review of the literature. Kulak Burun Bogaz Ihtis Derg.
9339 Urbizu A, Ferre A, Poca MA, et al. (2016). Cephalometric oropharynx and oral cavity analysis in Chiari malformation Type I: a retrospective case-control study. J Neurosurg.
9340 Vaikjarv R, Kasenomm P, Jaanimae L, et al. (2016). Microbiology of peritonsillar abscess in the South Estonian population. Microb Ecol Health Dis.
9341 Varghese AM, Naina P, Cheng AT, et al. (2016). ACE grading-A proposed endoscopic grading system for adenoids and its clinical correlation. Int J Pediatr Otorhinolaryngol.
9342 Veeravigrom M, Desudchit T. (2016). Prevalence of Sleep Disorders in Thai Children. Indian J Pediatr.
9343 Viciani E, Montagnani F, Tavarini S, et al. (2016). Paediatric obstructive sleep apnoea syndrome (OSAS) is associated with tonsil colonisation by Streptococcus pyogenes. Sci Rep.
9344 Villa MP, Sujanska A, Vitelli O, et al. (2016). Use of the sleep clinical record in the follow-up of children with obstructive sleep apnea (OSA) after treatment. Sleep Breath.
9345 Walls A, Dermody S, Kumaran R, et al. (2016). Characterization of B-Cells in tonsils of patients diagnosed with pediatric autoimmune neuropsychiatric disorder associated streptococcus. Int J Pediatr Otorhinolaryngol.
9346 Wang C, Kundaria S, Fernandez-Miranda J, et al. (2016). A description of the anatomy of the glossopharyngeal nerve as encountered in transoral surgery. Laryngoscope.
9347 Watanabe H, Goto S, Kondo D, et al. (2016). Comparison of methods of steroid administration combined with tonsillectomy for IgA nephropathy patients. Clin Exp Nephrol.
9348 Whitla L, Lennon P. (2016). Non-surgical management of obstructive sleep apnoea: a review. Paediatr Int Child Health.
9349 Windfuhr JP, Toepfner N, Steffen G, et al. (2016). Clinical practice guideline: tonsillitis II. Surgical management. Eur Arch Otorhinolaryngol.
9350 Windfuhr JP, Toepfner N, Steffen G, et al. (2016). Clinical practice guideline: tonsillitis I. Diagnostics and nonsurgical management. Eur Arch Otorhinolaryngol.
9351 Windfuhr JP, Werner JA. (2016). Tonsillectomy 30 years after Paradise: implosion of arguments. Eur Arch Otorhinolaryngol.
9352 Xie C, De S, Selby A. (2016). Management of the Airway in Apert Syndrome. J Craniofac Surg.
9353 Xiong HF, Wang B, Zhao ZH, et al. (2016). Tonsillectomy and inflammatory bowel disease: a meta-analysis. Colorectal Dis.
9354 Yamakawa T, Yamamoto I, Komatsuzaki Y, et al. (2016). Successful Treatment of Recurrent Henoch-Schonlein Purpura Nephritis in a renal allograft with Tonsillectomy and Steroid Pulse Therapy: A Case Report. Nephrology (Carlton).
9355 Yamakawa T, Yamamoto I, Komatsuzaki Y, et al. (2016). Successful treatment of recurrent Henoch-Schonlein purpura nephritis in a renal allograft with tonsillectomy and steroid pulse therapy. Nephrology (Carlton).
9356 Yang D, He L, Peng X, et al. (2016). The efficacy of tonsillectomy on clinical remission and relapse in patients with IgA nephropathy: a randomized controlled trial. Ren Fail.
9357 Yang JY, Lee H, Zhang Y, et al. (2016). The Effects of Tonsillectomy Education Using Smartphone Text Message for Mothers and Children Undergoing Tonsillectomy: A Randomized Controlled Trial. Telemed J E Health.
9358 Yang L, Shan Y, Wang S, et al. (2016). Endoscopic assisted adenoidectomy versus conventional curettage adenoidectomy: a meta-analysis of randomized controlled trials. Springerplus.
9359 Yenigun A, Dogan R, Ozturan O, et al. (2016). RGB Measurements From Endoscopic Photography as a New and Objective Diagnostic Method for Chronic Tonsillitis. Clin Ther.
9360 Yildirim YS, Senturk E, Eren SB, et al. (2016). Efficacy of nasal corticosteroid in preventing regrowth after adenoidectomy. Auris Nasus Larynx.
9361 Yumusakhuylu AC, Binnetoglu A, Demir B, et al. (2016). Is it safe to perform adenotonsillectomy in children with Down syndrome?. Eur Arch Otorhinolaryngol.
9362 Zaghi S, Holty JE, Certal V, et al. (2016). Maxillomandibular Advancement for Treatment of Obstructive Sleep Apnea: A Meta-analysis. JAMA Otolaryngol Head Neck Surg.
9363 Zagolski O, Gajda M, Strek P, et al. (2016). Adult tonsillectomy: postoperative pain depends on indications. Braz J Otorhinolaryngol.
9364 Zevallos JP, Mazul AL, Rodriguez N, et al. (2016). Previous tonsillectomy modifies odds of tonsil and base of tongue cancer. Br J Cancer.
9365 Zhong A, Xiong X, Shi M, et al. (2016). Roles of interleukin (IL)-6 gene polymorphisms, serum IL-6 levels, and treatment in obstructive sleep apnea: a meta-analysis. Sleep Breath.
9366 Zupin L, Polesello V, Grasso DL, et al. (2016). DEFB1 polymorphisms and susceptibility to recurrent tonsillitis in Italian children. Int J Pediatr Otorhinolaryngol.
9367 Kristensen S, Tveteras K. (1984). Post-tonsillectomy haemorrhage. A retrospective study of 1150 operations. Clin Otolaryngol Allied Sci.