# Appendix C Information for Screening, Risk of Bias Assessment, and Strength of the Evidence

Tonsillectomy Abstract Review Form

Tonsillectomy Full Text Review Form

Harms Risk of Bias Assessment Form

Risk of Bias Assessment for Observational Studies

Risk of Bias for RCTs Form

## Strength of the Evidence Domains

Table C-1 Domains used to assess strength of evidence^*^

Domain | Explanation
Study Limitations | Degree to which included studies for a given outcome have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through study design and study conduct.
Consistency | Degree to which included studies find either the same direction or similar magnitude of effect. Assessed through two main elements:; - Direction of effect: Effect sizes have the same sign (that is, are on the same side of no effect or a minimally important difference).; - Magnitude of effect: The range of effect sizes is similar.
Directness | Extent to which evidence links interventions directly to a health outcome of specific importance for the review, and for comparative studies, whether the comparisons are based on head-to-head studies. Evidence may be indirect in several situations such as:; - Outcome being graded is considered intermediate in a review that is focused on clinical health outcomes (such as morbidity, mortality).; - Data do not come from head-to-head comparisons but rather from two or more bodies of evidence to compare.; - Data are available only for proxy respondents instead of directly from patients for situations in which patients are capable of self-reporting and self-report is more reliable.
Precision | Degree of certainty surrounding an effect estimate with respect to a given outcome, based on the sufficiency of sample size and number of events. A body of evidence will generally be imprecise if the optimal information size (OIS) is not met. OIS refers to the minimum number of patients (and events when assessing dichotomous outcomes) needed for an evidence base to be considered adequately powered.
Reporting bias | Degree of selective publishing or reporting of research findings based on the favorability of direction or magnitude of effect.

* Excerpted from Berkman, et al. (2014). Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol.