# Appendix B Search Strategies

Table B-1 Preliminary PubMed search strategy (July 2015)

Search terms | | Search results
1 | tonsillectomy [mh] OR adenotonsillectomy OR tonsillotomy OR adenoidectomy | 10158
2 | therapeutics[mh] OR therapy[sh] OR “treatment outcome”[mh] OR therapy[tiab] OR therapies[tiab] OR therapeutic[tiab] OR therapeutics[tiab] OR outcome[tiab] OR outcomes[tiab] OR treatment[tiab] OR treatments[tiab] OR treatment^*^ OR treat^*^ OR intervention OR interven^*^ OR surgical procedures, operative[mh] OR surgery[tiab] OR surgeries[tiab] OR surgical[tiab] OR manage[tiab] OR management[tiab] OR evaluate[tiab] OR evaluation[tiab] OR sleep[tiab] OR Anti-Inflammatory Agents [mh] OR Multi-Ingredient Cold, Flu, and Allergy Medications [mh] OR Respiratory System Agents [mh] OR Anti-Bacterial Agents [mh] OR antibiotic [tiab] OR Anti-Allergic Agents [mh] | 11304977
3 | palatine tonsil[mh] OR tonsil^*^[tiab] OR adenoids [mh] OR adenoid [tiab] | 32464
4 | Sleep Apnea Syndromes [mh] OR Pharyngitis [mh] OR Craniofacial Abnormalities [mh] OR tonsillitis [tiab] OR “sleep apnea” [tiab] OR “throat infection” [tiab] OR “sleep disordered breathing” [tiab] OR “down syndrome” [tiab] | 103125
5 | #3 AND (#1 OR #2) | 20464
6 | ((#4 AND #3) AND (#1 OR #2)) | 6026
7 | #5 OR #6 OR #1 | 23407
8 | #7 AND (child^*^ OR adoles^*^ OR pediatr^*^ OR young OR youth OR infant) | 12142
9 | #8 AND eng [la] | 8854
10 | #9 NOT newspaper article[pt] OR letter[pt] OR comment[pt] OR case reports[pt] OR news[pt] OR editorial[pt] OR historical article[pt] OR legal cases[pt] OR congresses[pt] OR review [pt] | 6676
11 | #10 AND 1980:2016[dp] | 5897

Key: [la] language; [mh] medical subject heading; [pt] publication type.

Table B-2 EMBASE search (August 2015)

Search terms | | Search results
1 | tonsillectomy/ or palatine tonsillectomy/ or tonsillectomy.mp. | 11409
2 | adenotonsillectomy.mp. or adenotonsillectomy/ | 2843
3 | 1 or 2 | 13036
4 | Limit 3 to English, 1980-current, non-medline journals | 613

Table B-3 Cochrane Trials Register

Search terms | | Search results
1 | Tonsillectomy or adenotonsillectomy | 1860
2 | 1980-2015 | 1789