# Appendix A Analytic Frameworks

Figure A-1 Analytic framework for Key Question 1

Abbreviations: CPAP = Continuous Positive Airway Pressure; KQ = Key Question; OSDB = Obstructive Sleep-Disordered Breathing

* Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

† Includes tonsillectomy, adenotonsillectomy, or partial tonsillectomy performed using any method or approach (e.g., coblation, cold dissection, laser)

Figure A-1 depicts Key Question 1 within the context of the patient, intervention, comparator, and outcomes (PICOS) parameters described in the document. Children between the ages of 3 and 18 years with obstructive sleep-disordered breathing (OSDB) may undergo tonsillectomy (which includes tonsillectomy, adenotonsillectomy, or partial tonsillectomy) or other treatment (medical treatments, CPAP). Outcomes resulting from treatment may include changes in sleep measures; cognitive or behavioral changes; changes in health outcomes; changes in health care utilization; and persistence of OSDB. Harms may occur at any point after the intervention is received and may include emergency room visits for bleeding, pain, dehydration, and nausea and vomiting.

Figure A-2 Analytic framework for Key Question 1a

Abbreviations: CPAP = Continuous Positive Airway Pressure; KQ = Key Question; OSDB = Obstructive Sleep-Disordered Breathing

* Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

† Includes tonsillectomy, adenotonsillectomy, partial tonsillectomy performed using any method or approach (e.g., coblation, cold dissection, laser)

Figure A-2 depicts Key Question 1a within the context of the patient, intervention, comparator, and outcomes (PICOS) parameters described in the document. Children between the ages of 3 and 18 years with neuromuscular or craniofacial abnormalities and with obstructive sleep-disordered breathing (OSDB) may undergo tonsillectomy (which includes tonsillectomy, adenotonsillectomy, or partial tonsillectomy) or other treatment (medical treatments, CPAP,). Outcomes resulting from treatment may include changes in sleep measures; cognitive or behavioral changes; changes in health outcomes; changes in health care utilization; and persistence of OSDB. Harms may occur at any point after the intervention is received and may include emergency room visits for bleeding, pain, dehydration, and nausea and vomiting.

Figure A-3 Analytic framework for Key Question 1b

Abbreviations: CPAP = Continuous Positive Airway Pressure; KQ = Key Question; OSDB = Obstructive Sleep-Disordered Breathing

* Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

† Includes tonsillectomy, adenotonsillectomy, partial tonsillectomy performed using any method or approach (e.g., coblation, cold dissection, laser)

Figure A-3 depicts Key Question 1b within the context of the patient, intervention, comparator, and outcomes (PICOS) parameters described in the document. Children under age 3 years with obstructive sleep-disordered breathing (OSDB) may undergo tonsillectomy (which includes tonsillectomy, adenotonsillectomy, or partial tonsillectomy) or other treatment (medical treatments, CPAP). Outcomes resulting from treatment may include changes in sleep measures; cognitive or behavioral changes; changes in health outcomes; changes in health care utilization; and persistence of OSDB. Harms may occur at any point after the intervention is received and may include emergency room visits for bleeding, pain, dehydration, and nausea and vomiting.

Figure A-4 Analytic framework for Key Question 1c

Abbreviations: CPAP = Continuous Positive Airway Pressure; KQ = Key Question; OSDB = Obstructive Sleep-Disordered Breathing

* Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

† Includes tonsillectomy, adenotonsillectomy, partial tonsillectomy performed using any method or approach (e.g., coblation, cold dissection, laser)

Figure A-4 depicts Key Question 1c within the context of the patient, intervention, comparator, and outcomes (PICOS) parameters described in the document. Children between the ages of 3 and 18 years with Down Syndrome and with obstructive sleep-disordered breathing (OSDB) may undergo tonsillectomy (which includes tonsillectomy, adenotonsillectomy, or partial tonsillectomy) or other treatment (medical treatments, CPAP). Outcomes resulting from treatment may include changes in sleep measures; cognitive or behavioral changes; changes in health outcomes; changes in health care utilization; and persistence of OSDB. Harms may occur at any point after the intervention is received and may include emergency room visits for bleeding, pain, dehydration, and nausea and vomiting.

Figure A-5 Analytic framework for Key Question 1d

Abbreviations: CPAP = Continuous Positive Airway Pressure; KQ = Key Question; OSDB = Obstructive Sleep-Disordered Breathing

* Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

† Includes tonsillectomy, adenotonsillectomy, partial tonsillectomy performed using any method or approach (e.g., coblation, cold dissection, laser)

Figure A-5 depicts Key Question 1d within the context of the patient, intervention, comparator, and outcomes (PICOS) parameters described in the document. Children between the ages of 3 and 18 years with obesity or overweight and with obstructive sleep-disordered breathing (OSDB) may undergo tonsillectomy (which includes tonsillectomy, adenotonsillectomy, or partial tonsillectomy) or other treatment (medical treatments, CPAP,weight loss). Outcomes resulting from treatment may include changes in sleep measures; cognitive or behavioral changes; changes in health outcomes; changes in health care utilization; and recurrence of OSDB. Harms may occur at any point after the intervention is received and may include emergency room visits for bleeding, pain, dehydration, and nausea and vomiting.

Figure A-6 Analytic framework for Key Question 2

Abbreviations: KQ = Key Question; QoL = Quality of Life

† Includes tonsillectomy, adenotonsillectomy, partial tonsillectomy performed using any method or approach (e.g., coblation, cold dissection, laser)

Figure A-6 depicts Key Question 2 within the context of the patient, intervention, comparator, and outcomes (PICOS) parameters described in the document. Children between the ages of 3 and 18 years with recurrent throat infections may undergo tonsillectomy (which includes tonsillectomy, adenotonsillectomy, or partial tonsillectomy) or other treatment (medical treatments, watchful waiting). Outcomes resulting from treatment may include changes in the number and severity of throat infections annually; changes in health care utilization; and quality of life including missed school or work. Harms may occur at any point after the intervention is received and may include emergency room visits for bleeding, pain, dehydration, and nausea and vomiting.

Figure A-7 Analytic framework for Key Question 3

Abbreviations: KQ = Key Question; OSDB = Obstructive Sleep-Disordered Breathing

* Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

† Includes tonsillectomy or adenotonsillectomy.

Figure A-7 depicts Key Question 3 within the context of the patient, intervention, comparator, and outcomes (PICOS) parameters described in the document. Children between the ages of 3 and 18 years with recurrent throat infections or obstructive sleep-disordered breathing (OSDB) may undergo total tonsillectomy or partial tonsillectomy. Outcomes resulting from treatment may include changes in sleep measures; cognitive or behavioral changes; health outcomes including growth velocity; tonsillar regrowth after partial tonsillectomy; changes in health care utilization; persistence of OSDB; time to return to usual activities; and quality of life including missed school or work. Harms may occur at any point after the intervention is received and may include bleeding, pain, dehydration, and nausea and vomiting.

Figure A-8 Analytic framework for Key Question 4

Abbreviations: KQ = Key Question; OSDB = Obstructive Sleep-Disordered Breathing

* Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

† Includes tonsillectomy or adenotonsillectomy.

Figure A-8 depicts Key Question 4 within the context of the patient, intervention, comparator, and outcomes (PICOS) parameters described in the document. Children between the ages of 3 and 18 years with recurrent throat infections or obstructive sleep-disordered breathing (OSDB) may undergo tonsillectomy (which includes tonsillectomy, adenotonsillectomy, or partial tonsillectomy) using different surgical techniques (e.g., cautery, cold dissection). Outcomes resulting from treatment may include changes in sleep measures; cognitive or behavioral changes; changes in health care utilization; health outcomes including growth velocity; time to return to usual activities; persistence of OSDB; and quality of life including missed school or work. Harms may occur at any point after the intervention is received and may include emergency room visits for bleeding, pain, dehydration, and nausea and vomiting.

Figure A-9 Analytic framework for Key Question 5

Abbreviations: KQ = Key Question; OSDB = Obstructive Sleep-Disordered Breathing

* Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

† Includes tonsillectomy, adenotonsillectomy, partial tonsillectomy performed using any method or approach (e.g., coblation, cold dissection, laser).

Figure A-9 depicts Key Question 5 within the context of the patient, intervention, comparator, and outcomes (PICOS) parameters described in the document. Children between the ages of 3 and 18 years with recurrent throat infections or obstructive sleep-disordered breathing (OSDB) may undergo tonsillectomy (which includes tonsillectomy, adenotonsillectomy, or partial tonsillectomy) with or without adjunctive perioperative medications intended to improve outcomes. Outcomes resulting from treatment may include changes in pain management; time to return to usual activities; and changes in health care utilization. Harms may occur at any point after the intervention is received and may include emergency room visits for bleeding, pain, dehydration, and nausea and vomiting.

Figure A-10 Analytic framework for Key Question 6

Abbreviations: KQ = Key Question; OSDB = Obstructive Sleep-Disordered Breathing

* Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

†* Includes tonsillectomy, adenotonsillectomy, partial tonsillectomy performed using any method or approach (e.g., coblation, cold dissection, laser).

Figure A-10 depicts Key Question 6 within the context of the patient, intervention, comparator, and outcomes (PICOS) parameters described in the document. Children between the ages of 3 and 18 years with recurrent throat infections or obstructive sleep-disordered breathing (OSDB) may undergo tonsillectomy (which includes tonsillectomy, adenotonsillectomy, or partial tonsillectomy) and receive varied postoperative medications for pain (e.g. NSAIDs, ketorolac). Outcomes resulting from treatment may include pain management; time to return to usual activities; and health care utilization. Harms may occur at any point after the intervention is received and may include emergency room visits for bleeding, pain, dehydration, and nausea and vomiting.

Table A-1 Population, intervention, comparator, outcome characteristics^*^

KQ | Population | Intervention^†^ | Comparators | Outcomes
1 | Children (3-18 years of age) with OSDB^**^ | Tonsillectomy | - Continuous positive airway pressure (CPAP); - Pharmacologic treatment including anti-inflammatory medications, decongestants, allergy medication, antihistamines, nasal steroids, leukotriene inhibitors | Sleep outcomes; - Apnea Hypopnea Index (AHI); - Sleep quality measures (Obstructive Sleep Apnea-18 [OSA-18], Clinical Assessment Score-15 [CAS-15]); - Pediatric Sleep Questionnaire (PSQ); - Modified Epworth Sleepiness Scale; - Desaturation nadir; - OSDB persistence; Cognitive or behavioral outcomes; - Validated measures of attention, irritability, and memory; Health outcomes; - Growth velocity (height, BMI for age); - Cardiopulmonary issues; - Self or caregiver-reported enuresis; - Health care utilization (number of clinician visits); Harms; - Re-admission or ER visit or ICU admission for postoperative pain, dehydration, bleeding, or nausea and vomiting; - Reoperation for primary or secondary bleeding; - Velopharyngeal insufficiency; - 30-day mortality; - Harms of comparator agents reported in studies with comparison groups
1a | Children (3-18 years of age) with OSDB and neuromuscular or craniofacial abnormalities | Tonsillectomy | See comparators above (KQ1) | See outcomes above (KQ1)
1b | Children under age 3 with OSDB | Tonsillectomy | See comparators above (KQ1) | See outcomes above (KQ1) Length of stay
1c | Children (3-18 years of age) with OSDB and Down syndrome | Tonsillectomy | See comparators above (KQ1) | See outcomes above (KQ1) Length of stay
1d | Children (3-18 years of age) with OSDB who are overweight or obese | Tonsillectomy | - CPAP; - Weight loss; - Pharmacologic treatment including anti-inflammatory medications, decongestants, allergy medication, antihistamines, nasal steroids, leukotriene inhibitors | See outcomes above (KQ1)
2 | Children (3-18 years) with recurrent throat infections | Tonsillectomy | - Antibiotics; - Nonantibiotic pharmacologic treatments (e.g., anti-inflammatory agents, decongestants, antihistamines, leukotriene inhibitors, nasal or systemic steroids) | Throat infections; - Number of throat infections/year; - Severity of throat infections; - Number of streptococcal infections/year; Quality of life; - Validated quality of life measures; - Missed school or work for child or caregiver; Other outcomes; - Health care utilization (number of clinician visits, number of courses of antibiotics); Harms; - ER visit or hospital or ICU admission for postoperative pain, bleeding, dehydration, or nausea and vomiting; - Reoperation for primary or secondary bleeding; - Velopharyngeal insufficiency; - 30-day mortality; - Harms of comparator agents reported in studies with comparison groups
3 | Children (3-18 years) undergoing tonsillectomy | Total tonsillectomy | - Partial tonsillectomy | See sleep, cognitive or behavioral, and health outcomes (KQ1) and quality of life outcomes (KQ2) Throat infections; - Number of throat infections/year; - Severity of throat infections; - Number of streptococcal infections/year; Other outcomes; - Symptomatic tonsillar regrowth; - Time to return to usual activity (diet, school); Harms See KQ1 Reoperation for complete tonsillectomy
4 | Children (3-18 years) undergoing tonsillectomy | Tonsillectomy | - Other technique for tonsillectomy | See sleep, cognitive or behavioral, and health outcomes (KQ1) and quality of life outcomes (KQ2) Throat infections; - Number of throat infections/year; - Severity of throat infections; - Number of streptococcal infections/year; Other outcomes; - Time to return to usual activity (diet, school); Harms See KQ1
5 | Children (3-18 years) undergoing tonsillectomy | Tonsillectomy plus adjunctive perioperative (i.e., preoperative, intraoperative, or immediate postoperative [post-anesthesia care] periods) pharmacologic agents | - Tonsillectomy without adjunctive perioperative pharmacologic agents (i.e., pharmacologic agents given to attempt to reduce postoperative morbidity including pain or nausea and vomiting ) | - Pain management (need for or # of rescue medications); - Time to return to usual activities (diet, school); - Health care utilization (number of clinician visits, number of courses of antibiotics); Harms; - Harms of agent; - Re-admission to hospital or ICU or ER visit for postoperative pain, bleeding, dehydration, or nausea and vomiting; - Reoperation for primary or secondary bleeding; - 30-day mortality
6 | Children (3-18 years) undergoing tonsillectomy and receiving pharmacologic agents for pain postoperatively (i.e., up to 10 days after discharge from post-anesthesia care) | Tonsillectomy plus postoperative pharmacologic agents for pain (e.g., NSAID, ketorolac) | - Tonsillectomy with other postoperative pharmacologic agents for pain | See outcomes and harms for KQ5

* Studies of any length or follow-up and in any setting, except for KQ6, which includes pharmacologic agents for pain given up to 10 days post-surgery.

** Includes breathing difficulties during sleep as operationalized in each study, including obstructive sleep apnea and upper airway resistance syndrome

† Tonsillectomy includes tonsillectomy, adenotonsillectomy, partial tonsillectomy

Abbreviations: AHI = Apnea Hypopnea Index; BMI = Body Mass Index; CAS-15 = Clinical Assessment Score-15; CPAP = Continuous Positive Airway Pressure; ER = Emergency Room; KQ = Key Question; NSAID = Non-steroidal Anti-Inflammatory Drug; OSA-18 = Obstructive Sleep Apnea-18; OSDB = Obstructive Sleep-Disordered Breathing