# Acronyms and Abbreviations

AAO-HNSF: American Academy Of Otolaryngology - Head & Neck Surgery Foundation
AHI: Apnea Hypopnea Index
AHRQ: Agency For Healthcare Research And Quality
BCI: Bayesian Credible Intervals
BMI: Body Mass Index
BRIEF: Behavior Rating Inventory Of Executive Function
CAS-15: Clinical Assessment Score-15
CBC: Child Behavior Checklist
CGI: Connors Global Index
CHAT: Childhood Adenotonsillectomy Trial
CI: Confidence Interval
CPAP: Continuous Positive Airway Pressure
ER: Emergency Room
ESS-C: Epworth Sleepiness Scale - Child
G: Group
GAS: Group A Strep
CGBI: Glasgow Children's Benefit Inventory
GEC: Global Executive Composite
ICU: Intensive Care Unit
IQ: Intelligence Quotient
IQR: Interquartile Range
IV: Intravenous
kg: Kilograms
KQ: Key Question
M-ESS: Modified Epworth Sleepiness Scale
mg: Milligrams
N: Number
NA: Not Applicable
NEPSY: Developmental Neuropsychological Assessment
NR: Not Reported
NS: Not Significant
NSAID: Nonsteroidal Anti-Inflammatory Drug
OSDB: Obstructive-Sleep Disordered Breathing
OSA: Obstructive Sleep Apnea
OSA-18: Obstructive Sleep Apnea-18
PACU: Post-Anesthesia Care Unit
PFAPA: Periodic Fever, Aphthous Stomatitis, Pharyngitis, Cervical Adenitis
PICOTS: Population, Intervention, Comparator, Outcomes, Timing, And Setting
PedsQL: Pediatric Quality Of Life Inventory
POD: Post-op Day
PONV: Postoperative Nausea and Vomiting
PSG: Polysomnography
PSQ: Pediatric Sleep Questionnaire
PSQ-SRBD: Pediatric Sleep Questionnaire Sleep-Related Breathing Disorder
PTH: Post-Tonsillectomy Hemorrhage
QoL: Quality of Life
RCT: Randomized Controlled Trial
ROB: Risk of Bias
RR: Risk Ratio
SD: Standard Deviation
SOE: Strength Of Evidence
TEP: Technical Expert Panel
UARS: Upper Airway Resistance Syndrome
WASI: Wechsler Abbreviated Scale Of Intelligence