# Results

## Results of Literature Search

Results of the literature search and selection process are summarized in the literature flow diagram (Figure 2). Database searches resulted in 4,412 potentially relevant citations. After dual review of abstracts and titles, 698 articles were selected for full-text review. After dual review of full-text articles, 32 studies were included. Data extraction and risk of bias assessment tables for included studies by Key Question are available in Appendixes H through L.

Figure 2 Literature flow diagram

HaPI=Health and Psychosocial Instruments; ; n=sample size

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews

† Other sources include reference list, experts, etc.

‡ Two studies were used for Key Question 1 and Key Question 4

This figure is a literature flow diagram depicting the search and selection of articles for the review. The figure shows that 4,412 abstracts of potentially relevant articles were identified through MEDLINE, CINAHL, HAPI, PyschINFO, Cochrane, and other sources. After excluding 3,714 non-relevant abstracts and background articles, 698 articles were reviewed at the full-text level. Of these, 665 articles were excluded for the following reasons: wrong population (48), wrong intervention (382), wrong outcomes (69), wrong study design (12), wrong publication type (33), wrong comparison (7), wrong setting (34), not English language (5), review not meeting inclusion criteria (11), studies outside of search dates (2), indirect studies for Key Question 1 that do not address a subgroup of interest (63). Therefore, 32 publications were included in the review, as follows: 18 head-to-head studies and 6 indirect studies for Key Question 1; no studies for Key Question 2; no studies for Key Question 3; 9 studies for Key Question 4. A footnote indicates that one study was included for both Key Question 1 and Key Question 4.

## Key Question 1 In patients with known or suspected trauma, what is the predictive utility of the total Glasgow Coma Scale (tGCS) compared with the motor component of the GCS (mGCS) score for predicting in-hospital mortality, morbidity, Injury Severity Score (ISS) of 16 or greater, head Abbreviated Injury Scale (AIS) score greater than 2 (AIS-2005) or greater than 3 (AIS-1998), presence of intracranial hemorrhage, and utilization indicators of severe injury (e.g., receipt of intracranial monitoring within 48 hours of admission, receipt of a neurosurgical intervention within 12 hours of admission, or early intubation [in the field or immediately upon presentation to the emergency department (ED)])?

### Key Points

- In-hospital mortality
  ○ For the tGCS versus the mGCS, the pooled area under the receiver operating characteristic curve (AUROC) was 0.877 (95% confidence interval [CI] 0.847 to 0.906) versus 0.855 (95% CI 0.822 to 0.888), with a pooled mean difference of 0.015 (95% CI 0.009 to 0.022; I^2^=85%), based on 12 studies (strength of evidence [SOE]: Moderate).
  ○ For the tGCS (cutoff of ≤13) versus the mGCS (cutoff of ≤5), differences in sensitivity ranged from 0 percent to 3 percent; difference in specificity ranged from 0 percent to 5 percent in favor of the mGCS, though the CIs overlapped in most studies (SOE: Low).
  ○ For the tGCS versus the Simplified Motor Score (SMS), the pooled AUROC was 0.884 (95% CI 0.852 to 0.916) versus 0.840 (95% CI 0.802 to 0.878), for a mean difference of 0.030 (95% CI 0.024 to 0.036, I^2^=0%), based on five studies (SOE: Moderate).
  ○ One study found the out-of-hospital tGCS (cutoff of ≤13) associated with slightly higher sensitivity versus the SMS (cutoff of ≤1) (75%, 95% CI 73 to 76 vs. 72%, 95% CI 70 to 74) and slightly lower specificity (88%, 95% CI 87 to 88 vs. 89%, 95% CI 89 to 87) (SOE: Low).
  ○ For the mGCS versus the SMS, the mean difference in the pooled AUROC was 0.014 (95% CI 0.006 to 0.021, I^2^=0%), based on four studies (SOE: Moderate).
- Neurosurgical intervention
  ○ For the tGCS versus the mGCS, the pooled AUROC was 0.786 (95% CI 0.729 to 0.842) versus 0.754 (95% CI 0.688 to 0.819), with a mean difference of 0.032 (95% CI 0.020 to 0.043; I^2^=72%), based on seven studies (SOE: Moderate).
  ○ Two studies found inconsistent results for sensitivity (51%, 95% CI 50 to 52 vs. 46%, 95% CI 45 to 48 and 63%, 95% CI 38 to 84 vs. 68%, 95% CI 43 to 87) and no clear differences in specificity (86%, 95% CI 86 to 86 vs. 88%, 95% CI 88 to 88 and 82%, 95% CI 80 to 84 vs. 83%, 95% CI 81 to 85) between out-of-hospital tGCS (cutoff of ≤13) versus the mGCS (cutoff of ≤5) in accuracy for identifying people undergoing craniotomy (SOE: Insufficient for sensitivity, low for specificity).
  ○ For the tGCS versus the SMS, the pooled AUROC was 0.809 (95% CI 0.766 to 0.853) versus 0.769 (95% CI 0.711 to 0.827), with a mean difference of 0.032 (95% CI 0.025 to 0.039, I^2^=0%), based on five studies (SOE: Moderate).
  ○ One study found the out-of-hospital tGCS (cutoff of ≤13) associated with higher sensitivity than the SMS (cutoff of ≤1) for identifying patients who underwent neurosurgical intervention (60%, 95% CI 56 to 63 vs. 53%, 95% CI 49 to 56) and slightly lower specificity (85%, 95% CI 84 to 85 vs. 86%, 95% CI 86 to 87) (SOE: Low).
  ○ For the mGCS versus the SMS, the mean difference in the pooled AUROC was 0.002 (95% CI -0.005 to 0.010, I^2^=0%), based on four studies (SOE: Moderate).
- Severe brain injury
  ○ For the tGCS versus the mGCS, the pooled AUROC was 0.791 (95% CI 0.734 to 0.827) versus 0.720 (95% CI 0.666 to 0.774), with a mean difference of 0.050 (95% CI 0.034 to 0.065; I^2^=57%), based on five studies (SOE: Moderate).
  ○ One study found no difference between out-of-hospital tGCS (cutoff of ≤13) versus the mGCS (cutoff of ≤5) in sensitivity (62%, 95% CI 55% to 68% vs. 61%, 95% CI 54% to 67%) or specificity (85%, 95% CI 83 to 88 vs. 89%, 95% CI 88 to 91) for identifying people with severe head injury (defined as head AIS score of ≥4) (SOE: Low).
  ○ For the tGCS versus the SMS, the pooled AUROC was 0.763 (95% CI 0.710 to 0.815) versus 0.713 (95% CI 0.654 to 0.771), with a mean difference of 0.048 (95% CI 0.038 to 0.059, I^2^=72%), based on five studies (SOE: Moderate).
  ○ One study found out-of-hospital tGCS (cutoff of ≤13) associated with slightly higher sensitivity than the SMS (cutoff of ≤1) for severe brain injury based on presence of head computed tomography (CT) imaging findings (45%, 95% CI 44 to 46 vs. 41%, 95% CI 40 to 42) and similar specificity (89%, 95% CI 89 to 90 vs. 90%, 95% CI 90 to 91) (SOE: Low).
  ○ For the mGCS versus the SMS, there was no difference in the AUROC (mean difference 0.000, 95% CI -0.008 to 0.007, I^2^=0%), based on four studies (SOE: Moderate).
- Emergency intubation
  ○ For the tGCS versus the mGCS, the pooled AUROC was 0.865 (95% CI 0.830 to 0.901) versus 0.822 (95% CI 0.775 to 0.870), with a mean difference of 0.034 (95% CI 0.020 to 0.048; I^2^=88%), based on six studies (SOE: Moderate).
  ○ One study found very small differences between out-of-hospital tGCS (cutoff of ≤13) versus the mGCS (cutoff of ≤5) in accuracy for identifying people who underwent emergency intubation (sensitivity 84%, 95% CI 83 to 84 vs. 81%, 95% CI 81 to 82; and specificity 90%, 95% CI 90 to 90 vs. 92.0%, 95% CI 92 to 92) (SOE: Low).
  ○ For the tGCS versus the SMS, the pooled AUROC was 0.843 (95% CI 0.823 to 0.864) versus 0.783 (95% CI 0.747 to 0.819), with a mean difference of 0.040 (95% CI 0.030 to 0.050, I^2^=55%), based on five studies (SOE: Moderate).
  ○ One study found the out-of-hospital tGCS (cutoff of ≤13) associated with slightly higher sensitivity than the SMS (cutoff of ≤1) for identifying people who underwent emergency intubation (76%, 95% CI 74 to 77 vs. 73%, 95% CI 71 to 74) and slightly lower specificity (89%, 95% CI 89 to 89 vs. 91%, 95% CI 90 to 91) (SOE: Low).
  ○ For the mGCS versus the SMS, there was no difference in the AUROC (mean difference 0.000, 95% CI -0.007 to 0.007, I^2^=0%), based on four studies (SOE: Moderate).
- Trauma center need
  ○ Two studies found small differences between the tGCS versus the mGCS in the AUROC (0.617 vs. 0.609 and 0.641 vs. 0.603), sensitivity (30% vs. 27% and 28% vs. 25%), and specificity (93% vs. 95% and 94% vs. 95%) for trauma center care need (defined as ISS score of >15, intensive care unit [ICU] admission >24 hours, need for urgent surgery, or death in the ED) (SOE: Low).
- Severe injury
  ○ Two studies found the tGCS was better able to discriminate those with major injury (defined as an ISS score of >15) from those without major injury (AUROC 0.72, 95% CI 0.71 to 0.72 vs. 0.68, 95% CI 0.68 to 0.69 and 0.65, 95% CI 0.65 to 0.65 vs. 0.61, 95% CI 0.60 to 0.61) (SOE: Low).
  ○ One study found the out-of-hospital tGCS (cutoff of ≤13) associated with slightly higher sensitivity and slightly lower specificity than the mGCS (cutoff of ≤5) for identifying people with major injury (defined as an ISS score of >15) from those without major injury (sensitivity 31%, 95% CI 31 to 32 vs. 28%, 95% CI 28 to 28 and specificity 91%, 95% CI 91 to 91 vs. 93%, 95% CI 93 to 93). (SOE: Low).

### Detailed Synthesis

Eighteen studies directly compared the predictive utility of the tGCS versus the mGCS (12 studies) and/or the SMS (6 studies, Table 1, Appendix H).^17-20,36,48,51-62^ All studies were retrospective analyses in which the mGCS or SMS scores were taken from the tGCS (i.e., the tGCS and mGCS or SMS were not assessed independently). Sample sizes ranged from 96 to 811,143. Fifteen studies were conducted in the United States, two studies in Europe, and one in Canada. Four studies restricted enrollment to children;^51,55,60,62^ the other studies enrolled adults or mixed populations of adults and children. Four studies utilized data collected in or after 2006. GCS scores were obtained during out-of-hospital assessment in 11 studies,^17-19,36,48,52-56,61^ in the ED in 5 studies,^20,51,58-60^ and in mixed (ED or out-hospital) settings in 2 studies.^57,62^ The assessment setting was mixed or unclear in four studies. Four studies focused on patients with TBI^51,56,57,62^ and the remainder evaluated mixed trauma populations. Among studies that enrolled mixed trauma patients, the proportion of trauma patients with TBI ranged from 5 to 18 percent in studies that reported this information; none of these studies reported results in subgroup of patients with TBI. No study reported the proportion of intoxicated patients. In two studies, the proportion of patients who underwent out-of-hospital intubation was 0.3 percent^52^ and 3.5 percent,^19^ it was unclear when the GCS was assessed in intubated patients. Thirteen studies were rated moderate risk of bias and five studies were rated low risk of bias. Eight studies did not report attrition and seven studies reported missing data in more than 20 percent of patients. Most studies on predictive utility focused on measures of discrimination or diagnostic accuracy; adjustment for confounders is generally not performed for either of these measures.

Table 1 Characteristics of head-to-head studies

Author, Year | Settings Years of Study | Assessment Timing Measures and/or Scores Compared | N | Population Characteristics
Acker et al., 2014^51^ | USA, Colorado Urban 2 Level 1 pediatric trauma centers 2002 to 2011 | ED A: tGCS B: mGCS | 2,231 | Age (mean, years): 6.9 (SD 5.8) Male: 65% Race: NR TBI: 100% ISS (median): 17 (IQR: 10-26)
Al-Salamah et al., 2004^52^ | Canada, Ontario Trauma registry 72% urban, 28% suburban or rural 1994 to 2002 | Out-of-hospital A: tGCS score ≤13 B: mGCS score ≤5 | 795 | Age (mean, years): 44 (SD 21) Male: 70% Race: NR TBI: NR ISS: NR
Beskind et al., 2014^17^ | USA, Southern Arizona Urban, University Health Network Level 1 trauma center 2008 to 2010 | Out-of-hospital A: tGCS B: mGCS | 9,816 | Age (median, years): 32 (IQR: 20-51) Male: 65.5% Race: NR TBI: NR ISS ≥16: 11.7%
Brown et al., 2014^53^ | USA Trauma registry^*^ 2007 to 2008 | Out-of-hospital A: tGCS score ≤13 B: mGCS score ≤5 | 811,143 | Age (median): 39 (IQR: 23-57) Male: 66% Race: NR TBI: NR ISS (median): 9 (IQR: 4-13)
Caterino and Raubenolt, 2012^54^ | USA, Ohio Urban, hospitals Trauma and nontrauma centers 2002 to 2007 | Out-of-hospital A: tGCS ≤13 B: SMS ≤1 | 52,412 | Age (mean, years): 53 Male: 55.9% White: 79.9% Black: 13.5% Hispanic: 1.5% Other race: 1.7% Race not documented: 3.4% TBI: 15.2% ISS (median): 9 ISS >15: 26.6%
Cicero and Cross, 2013^55^ | USA Trauma registry^*^ 2007 to 2009 | Out-of-hospital A: tGCS B: mGCS | 104,035 | Age (mean, years): 12.6 (SD 5.5) Male: 67% Nonwhite race: 38% TBI: NR ISS (mean): 9.9 (SD 10.3) Major injury (ISS >15): 15%
Corrigan et al., 2014^56^ | USA Trauma registry^*^ 2007 to 2010 | Out-of-hospital A: tGCS B: mGCS | 77,470 | NR
Davis et al., 2006^57^ | USA, California (San Diego) Urban, other data NR Date NR | Out-of-hospital and ED A: tGCS B: mGCS | 12,882 | NR
Eken et al., 2009^58^ | Turkey Tertiary care ED of hospital Level IV trauma center 2006 | ED A: tGCS B: mGCS | 185 | Age (median, years): 59 (range: 18-97) Male: 64% Race: NR TBI: NR ISS: NR
Gill et al., 2005^20^ | USA, California (Loma Linda) Urban, University Level 1 trauma center and children's hospital 1990 to 2002 | ED A: tGCS B: mGCS C: SMS | 8,412 | Age (median, years): 24 (IQR: 15-38) Male: 71.5% Race: NR TBI: 17.1% ISS: NR
Gill et al., 2006^36^ | USA, California (Loma Linda) Urban, University Level 1 trauma center and children's hospital 1990 to 2002 | Out-of-hospital A: tGCS B: mGCS C: SMS | 7,233 | Age (median, years): 24 (IQR: 16-38) Male: 70% Race: NR TBI: 17% ISS: NR
Haukoos et al., 2007^59^ | USA, Colorado Urban, Denver Health Medical Center Level 1 trauma center 1995 to 2004 | ED A: tGCS B: mGCS C: SMS | 21,170 | Age (median, years): 32 (IQR: 21-45) Male: 71% Race: NR TBI: 14% ISS score (median): 9 (IQR: 2-14)
Healey et al., 2003^18^ | USA Trauma registry^*^ 1994 to 2001 | Out-of-hospital A: tGCS B: mGCS | 202,255 | NR
Holmes et al., 2005^60^ | USA, California (Davis) Level 1 trauma center 1998 to 2001 | ED A: tGCS B: mGCS | 2,043 | Ages ≤2 years: 16% Ages >2 years: 84% Male: NR Race: NR TBI: 5% ISS: NR
Kupas et al., 2016^61^ | USA, Pennsylvania Level I, II, III, or IV trauma centers 1999 to 2013 | Out-of-hospital A: tGCS score ≤13 B: mGCS score ≤5 | 370,392 | Age (median, years): 50 Male: 62% White: 79% Black: 14% Asian: 0.9% TBI: NR (88% blunt trauma) ISS >15: 29%
Ross et al., 1998^19^ | USA, New Jersey Level 1 trauma center 1994 to 1996 | Out-of-hospital A: tGCS score ≤13 B: mGCS score ≤5 | 1,410 | Age (mean, years): 37.1 (range: 13-95) Male: 69% Race: NR TBI: NR ISS (mean): 14.4 ISS (median): 13
Thompson et al., 2011^48^ | USA, Colorado Urban, Denver Health Medical Center Level 1 trauma center 1999 to 2008 | Out-of-hospital A: tGCS ≤13 B: mGCS score ≤5 B: SMS ≤1 | 19,408 | Age (median, years): 33 (IQR: 22-48) Male: 71% Race: NR TBI: 18% ISS (median): 9 (IQR: 4-17)
Van de Voorde et al., 2008^62^ | Belgium Pediatric trauma registry (PENTA) 2005 | Out-of-hospital and ED A: tGCS score ≤13 B: mGCS score ≤5 | 96 | Age (mean, years): 8.2 (SD 5.3) Male: 59% Race: NR TBI: NR ISS (median): 16

ED=emergency department; IQR=interquartile range; ISS=Injury Severity Score; mGCS=motor Glasgow Coma Scale; n=number; NR=not reported; NTDB=National Trauma Data Bank; PENTA=pediatric trauma registry; SD=standard deviation; SMS=Simplified Motor Scale; TBI=traumatic brain injury; tGCS=total Glasgow Coma Scale; USA=United States of America

* Patients from the NTDB data set

Four studies were based on analyses of the NTDB database,^18,53,55,56^ but evaluated different populations or outcomes. Sample sizes ranged from 77,470 to 811,143. One of the NTDB studies focused on children,^55^ one focused on adults,^56^ and two evaluated mixed populations.^18,53^ There were also two studies^20,36^ that used data from a trauma center in in Loma Linda, California and three studies^48,51,59^ that used data from the Denver area trauma system in which there could be some overlap in the populations assessed. In sensitivity analyses, we excluded two studies^20,59^ from these trauma systems that focused on GCS scores obtained in the ED, since other studies^36,48^ from these trauma systems evaluated out-of-hospital GCS scores around the same time period.

The most commonly evaluated outcome was in-hospital mortality. Other outcomes reported in at least five studies were severe brain injury, receipt of neurosurgical intervention, and intubation (Table 2). The proportion of patients who experienced in-hospital mortality ranged from 3 percent to 18 percent;^17,19,20,36,48,51-55,58,59,61,62^ the proportion with severe brain injury (defined in one study^60^ as CT imaging findings of skull fracture, contusion, or hemorrhage, or acute intervention for TBI [neurosurgical procedure, hospitalization >2 days, antiepileptic medications for >7 days]; the others defined severe brain injury based on CT imaging alone^20,36,48,54,59^) ranged from 5 percent to 39 percent; the proportion who underwent a neurosurgical intervention (defined as craniotomy in two studies^51,61^ and as a composite outcome including various neurosurgical procedures, ventriculostomy, and/or intracerebral pressure monitoring in the others^17,20,36,48,54,59^) ranged from 1.5 percent to 10 percent; and the proportion who were intubated (out-of-hospital, ED, or both) ranged from 4 percent to 26 percent.^17,20,36,48,52,54,59,61^

Table 2 Proportion of patients experiencing outcomes in head-to-head studies on predictive utility

Study, Year | In-Hospital Mortality | Neurosurgical Intervention | Severe Brain Injury | Severe Injury | Intubation
Acker et al., 2014^51^ | 8.4% | 10.4%^*^ | -- | -- | --
Al-Salamah et al., 2004^52^ | 18% | -- | -- | -- | 16%^†^
Beskind et al., 2014^17^ | 2.9% | 3.8% | -- | -- | 4.1%^‡^
Brown et al., 2014^§^, ^53^ | 4.3% | -- | -- | 39%^‖^ | --
Caterino, and Raubenolt, 2012^54^ | 5.8% | 1.5% | 15%^¶^ | -- | 7.6%^‡^
Cicero, and Cross, 2013^§^, ^55^ | 3.8% | -- | -- | 21%^**^ | --
Corrigan et al., 2014^§^, ^56^ | -- | -- | -- | -- | --
Davis et al., 2006^57^ | -- | -- | -- | -- | --
Eken et al., 2009^58^ | 14% | -- | -- | -- | --
Gill et al., 2005^20^ | 11% | 9.3% | 17%^¶^ | -- | 26%^†^
Gill et al., 2006^36^ | 10% | 8.8% | 17%^¶^ | -- | 26%^†^
Haukoos et al., 2007^59^ | 5.5% | 6.6% | 14%^¶^ | -- | 18%^‡^
Healey et al., 2003^§^, ^18^ | 6% | -- | -- | -- | --
Holmes et al., 2005^60^ | -- | -- | 6.3%^††^ | -- | --
Kupas et al., 2016^61^ | 5.7% | 2.0%^*^ | -- | 29%^**^ | 7.1%^‡^
Ross et al., 1998^19^ | 6.6% | -- | -- | -- | 3.5%^‡‡^
Thompson et al., 2011^48^ | 5.8% | 7.8% | 18%^¶^ | -- | 18%^‡^
Van de Voorde et al., 2008^62^ | 11% | -- | -- | -- | --

* Craniotomy only

† Intubation in emergency department

‡ Intubation in out-of-hospital setting or emergency department

§ Studies from National Trauma Data Bank database

‖ Injury Severity Score >15, intensive care unit admission ≥24 hours, need for urgent surgery (emergency department disposition to the operating room), or death in the emergency department

¶ Skull fracture with underlying brain injury, intracranial hemorrhage, cerebral contusion, or nonspecific intracranial injury

** Injury Severity Score >15

†† Traumatic brain injury on computed tomography scan (intracranial hemorrhage, hematoma, contusion, or cerebral edema) or in need of acute intervention (neurosurgical procedure, antiepileptic medication for >7 days, neurologic deficit persisting until discharge, or ≥2 nights of hospitalization for treatment for blunt head injury)

‡‡ Intubation in out-of-hospital setting

#### In-Hospital Mortality

##### Total Glasgow Coma Scale Versus Motor Glasgow Coma Scale

The tGCS was slightly better than the mGCS at discriminating individuals who experienced in-hospital mortality from those who survived to hospital discharge (Table 3). Based on 12 studies, the pooled AUROC for the tGCS was 0.877 (95% CI 0.847 to 0.906) and for the mGCS was 0.855 (95% CI 0.822 to 0.888), with a pooled mean difference of 0.015 (95% CI 0.009 to 0.022; I^2^=85%; Figure 3).^17,18,20,36,48,51,52,55,57-59,61^ Results were unchanged when the analysis was performed using the profile likelihood method. Stratification of studies according to whether they focused on children (2 studies, mean difference in AUROC 0.006, 95% CI 0.002 to 0.011, I^2^=0%)^51,55^ or evaluated adults or mixed populations (10 studies, mean difference in AUROC 0.019, 95% CI 0.012 to 0.025, I^2^=75%)^17,18,20,36,48,52,57-59,61^ eliminated statistical heterogeneity, though the pooled mean difference for each subgroup was very similar (Table 4). Results were also similar in subgroup analyses stratified according to use of out-of-hospital (7 studies, mean difference in AUROC 0.016, 95% CI 0.007 to 0.024, I^2^=91%)^17,18,36,48,55,57,61^ or ED GCS scores (3 studies, mean difference in AUROC 0.020, 95% CI 0.006 to 0.034, I^2^=23%)^20,58,59^ or years in which data were collected (all data in 2006 or later vs. some or all before 2006), or when analyses were restricted to low risk of bias studies,^17,18,20,36,59^ studies of patients with TBI,^17,51,57^ or studies conducted in the United States (Table 4). Two of the three largest studies (n=202,255 and 101,504; one non-NTDB study had 370,392 patients,^61^ compared with 185 to 21,170 in the other studies) were based on the NTDB database.^18,55^ Estimates from the NTDB studies were very similar (differences in the AUROC 0.02, 95% CI 0.02 to 0.02^18^ and 0.01, 95% CI 0.00 to 0.01^55^) and excluding the NTDB studies had little effect on estimates (Table 4). When multiple studies were available from a trauma center, restricting the analysis to the most recent study from each trauma center that used out-of-hospital GCS scores (excluding 3 studies^20,51,59^) also had little effect on estimates.^20,48^

Table 3 Summary of discrimination (AUROC) of head-to-head studies

Author, Year Country | Assessment Timing Measures and/or Scores Compared | N | Age | In-Hospital Mortality (95% CI) | Neurosurgical Intervention (95% CI) | Severe Brain Injury (95% CI) | Intubation (95% CI)
Acker et al., 2014^51^ USA | ED A: tGCS B: mGCS | 2,231 | ≤18 years Mean: 6.9 years | A: 0.949 (0.938 to 0.961) B. 0.941 (0.926 to 0.957) p=0.06 | A: 0.642 (0.603 to 0.681) B: 0.638 (0.601 to 0.675) p=0.64^*^ A: 0.808 (0.784 to 0.832) B: 0.774 (0.748 to 0.800) p<0.001^†^ | NR | NR
Al-Salamah et al., 2004^52^ Canada | Out-of-hospital A: tGCS score ≤13 B: mGCS score ≤5 | 795 | ≥16 years Mean: 44 years | A: 0.82 B: 0.81 p=NR | NR | NR | NR
Beskind et al., 2014^17^ USA | Out-of-hospital A: tGCS B: mGCS | 9,816 | Mean: 32 years | A: 0.899 (0.874 to 0.923) B: 0.888 (0.864 to 0.913) Mean difference=0.010 (0.002 to 0.018) | A: 0.571 (0.533 to 0.609) B: 0.570 (0.531 to 0.608) Mean difference=0.002 (-0.013 to 0.016) | NR | A: 0.966 (0.955 to 0.976) B: 0.948 (0.933 to 0.963) Mean difference=0.018 (0.011 to 0.024)
Caterino and Raubenolt, 2012^54^ USA | Out-of-hospital A: tGCS ≤13 B: SMS ≤1 | 52,412 | ≥16 years Mean: 53 years | A: 0.85 (0.84 to 0.86) B: 0.82 (0.81 to 0.83) | A; 0.75 (0.73 to 0.77) B: 0.70 (0.68 to 0.72) | A: 0.72 (0.71 to 0.72) B: 0.66 (0.65 to 0.66) | A: 0.86 (0.85 to 0.87) B: 0.83 (0.82 to 0.83)
Cicero and Cross, 2013^‡^, ^55^ USA | Out-of-hospital A: tGCS B: mGCS | 104,035 | <19 years Mean: 12.6 years | A: 0.946 (0.941 to 0.951) B: 0.940 (0.935 to 0.945) | NR | NR | NR
Corrigan et al., 2014^‡^, ^56^ USA | Out-of-hospital A: tGCS B: mGCS | 77,470 | ≥18 years | A: 0.886 (NR) B: 0.878 (NR) | NR | NR | NR
Davis et al., 2006^57^ USA | Out-of-hospital and ED A: tGCS B: mGCS | 12,882 | NR | A: 0.84 (NR) B: 0.83 (NR) | A: 0.80 (NR) B: 0.78 (NR) | NR | NR
Eken et al., 2009^58^ Turkey | ED A: tGCS B: mGCS | 185 | >17 years | A: 0.735 (0.655 to 0.797) B: 0.662 (0.589 to 0.730) | NR | NR | NR
Gill et al., 2005^20^ USA | ED A: tGCS B: mGCS C: SMS | 8,412 | Median of 24 years | A: 0.906 (NR) B: 0.894 (NR) C: 0.878 (NR) | A: 0.874 (NR) B: 0.848 (NR) C: 0.851 (NR) | A: 0.826 (NR) B: 0.789 (NR) C: 0.791 (NR) | A: 0.865 (NR) B: 0.826 (NR) C: 0.826 (NR)
Gill et al., 2006^36^ USA | Out-of-hospital A: tGCS B: mGCS C: SMS | 7,233 | Median of 24 years | A: 0.89 (0.88 to 0.90) B: 0.88 (0.87 to 0.89) C: 0.86 (0.86 to 0.89) | A: 0.86 (0.85 to 0.88) B: 0.84 (0.82 to 0.85) C: 0.83 (0.81 to 0.84) | A: 0.83 (0.82 to 0.84) B: 0.79 (0.78 to 0.81) C: 0.79 (0.77 to 0.80) | A: 0.83 (0.81 to 0.84) B: 0.79 (0.78 to 0.80) C: 0.79 (0.77 to 0.80)
Haukoos et al., 2007^‡^, ^59^ USA | ED A: tGCS B: mGCS C: SMS | 21,170 | Median of 32 years | A: 0.92 (0.91 to 0.93) B: 0.90 (0.89 to 0.91) C: 0.89 (0.88 to 0.90) | A: 0.83 (0.82 to 0.84) B: 0.80 (0.79 to 0.81) C: 0.80 (0.79 to 0.81) | A: 0.76 (0.75 to 0.77) B: 0.71 (0.70 to 0.72) C: 0.71 (0.70 to 0.72) | A: 0.86 (0.85 to 0.87) B: 0.81 (0.80 to 0.82) C: 0.81 (0.80 to 0.82)
Healey et al., 2003^18^ USA | Out-of-hospital A: tGCS B: mGCS | 202,255 | NR | A: 0.891 (0.888 to 0.894) B: 0.873 (0.870 to 0.875) p=0.000 | NR | NR | NR
Holmes et al., 2005^60^ USA | ED A: tGCS B: mGCS | 2,043 | ≤2 years | NR | NR | Ages ≤2 years: A: 0.72 (0.56 to 0.87) B: 0.60 (0.48 to 0.72) Ages >2 years: A: 0.82 (0.76 to 0.87) B: 0.71 (0.65 to 0.77) AUROC (95% CI) for TBI in need of acute intervention Ages ≤2 years: A: 0.97 (0.94 to 1.0) B: 0.76 (0.59 to 0.93) Ages >2 years: A: 0.87 (0.83 to 0.92) B: 0.76 (0.71 to 0.81) | NR
Kupas et al., 2016^61^ USA | Out-of-hospital A: tGCS B: mGCS | 370,392 | ≥18 years | A: 0.831 (0.828 to 0.834) B: 0.803 (0.800 to 0.806) Difference=0.028 (0.026 to 0.030) | A: 0.724 (0.718 to 0.730) B: 0.676 (0.670 to 0.682) Difference=0.048 (0.044 to 0.052)^*^ | NR | A: 0.904 (0.902 to 0.907) B: 0.884 (0.882 to 0.887) Difference=0.020 (0.019 to 0.021)
Thompson et al., 2011^48^ USA | Out-of-hospital A: tGCS ≤13 B: mGCS score ≤5 B: SMS ≤1 | 19,408 | All Median: 33 years | A: 0.82 (0.74 to 0.90) B: 0.76 (0.70 to 0.83) C: 0.74 (0.70 to 0.77) | A: 0.70 (0.64 to 0.77) B: 0.66 (0.61 to 0.71) C: 0.66 (0.64 to 0.69) | A: 0.66 (0.60 to 0.71) B: 0.61 (0.57 to 0.65) C: 0.61 (0.58 to 0.64) | A: 0.70 (0.63 to 0.77) B: 0.65 (0.60 to 0.70) C: 0.65 (0.62 to 0.67)

AUROC=area under the receiver operating characteristic curve; CI=confidence interval; ED=emergency department; mGCS=motor Glasgow Coma Scale; n=number; NR=not reported; SMS=Simplified Motor Scale; TBI=traumatic brain injury; tGCS=total Glasgow Coma Scale; vs.=versus

* Craniotomy only

† Intracranial pressure monitoring only

‡ Studies from NTDB database

Figure 3 Pooled AUROC of in-hospital mortality for the total Glasgow Coma Scale versus the motor component only

AUROC=area under the receiver operating characteristic curve; CI=confidence interval; mGCS=motor Glasgow Coma Scale; n=number; NR=not reported; tGCS=total Glasgow Coma Scale

* Patients from the National Trauma Data Bank data set

Figure 3 is a meta-analysis forest plot comparing how well tGCS and mGCS discriminate persons who experienced in-hospital mortality from persons who survived to hospital discharge. This figure is described further in the section “Mortality” as follows: “Based on 12 studies, the pooled AUROC for the tGCS was 0.877 (95% CI 0.847 to 0.906)and for the mGCS was 0.855 (95% CI 0.822 to 0.888), with a pooled mean difference of 0.015 (95% CI 0.009 to 0.022; I2=85%. Results were unchanged when the analysis was performed using the profile likelihood method. Stratification of studies according to whether they focused on children (2 studies, mean difference in AUROC 0.006, 95% CI 0.002 to 0.011, I2=0%) or evaluated adults or mixed populations (10 studies, mean difference in AUROC 0.019, 95% CI 0.012 to 0.025, I2=75%) eliminated statistical heterogeneity, though the pooled mean difference for each subgroup was very similar.”

Table 4 Pooled AUROC results of head-to-head studies

Outcome and Analysis | tGCS Vs. mGCS, Difference in AUROC (95% CI) | Number of Studies | I^2^ | tGCS Vs. SMS, Difference in AUROC (95% CI) | Number of Studies | I^2^
In-hospital mortality, overall | 0.015 (0.009 to 0.022) | 12 | 85% | 0.030 (0.024 to 0.036) | 5 | 0%
Adults or mixed | 0.019 (0.012 to 0.025) | 10 | 75% | 0.030 (0.024 to 0.036) | 5 | 0%
Children | 0.006 (0.002 to 0.011) | 2 | 0% | -- | -- | --
Excluding NTDB studies | 0.017 (0.008 to 0.025) | 10 | 68% | 0.030 (0.024 to 0.036) | 5 | 0%
Excluding studies with potential overlap^*^ | 0.016 (0.008 to 0.024) | 9 | 88% | 0.031 (0.023 to 0.039) | 3 | 0%
Out-of-hospital GCS | 0.016 (0.007 to 0.024) | 7 | 91% | 0.031 (0.023 to 0.039) | 3 | 0%
ED GCS | 0.020 (0.006 to 0.034) | 3 | 23% | 0.030 (0.020 to 0.039) | 2 | 0%
U.S. setting | 0.015 (0.008 to 0.022) | 10 | 87% | 0.030 (0.024 to 0.036) | 5 | 0%
TBI patients | 0.009 (-0.002 to 0.020) | 3 | 0% | -- | -- | --
Low risk of bias studies | 0.017 (0.015 to 0.020) | 5 | 0% | 0.030 (0.022 to 0.037) | 3 | 0%
Enrollment before 2006 | 0.018 (0.011 to 0.024) | 10 | 77% | 0.030 (0.024 to 0.036) | 5 | 0%
Enrollment 2006 or later | 0.006 (0.001 to 0.011) | 2 | 0% | -- | -- | --
Neurosurgical intervention, overall | 0.032 (0.020 to 0.043) | 7 | 72% | 0.032 (0.025 to 0.039) | 5 | 0%
Adults or mixed | 0.031 (0.018 to 0.044) | 6 | 76% | 0.032 (0.025 to 0.039) | 5 | 0%
Children | 0.034 (0.009 to 0.059) | 1 | -- | -- | -- | --
Excluding studies with potential overlap^*^ | 0.032 (0.011 to 0.053) | 4 | 79% | 0.038 (0.024 to 0.052) | 3 | 19%
Out-of-hospital GCS | 0.032 (0.011 to 0.053) | 4 | 79% | 0.038 (0.024 to 0.052) | 3 | 19%
ED GCS | 0.029 (0.020 to 0.039) | 2 | 0% | 0.029 (0.020 to 0.038) | 2 | 0%
U.S. setting | 0.032 (0.020 to 0.044) | 7 | 72% | 0.032 (0.025 to 0.039) | 5 | 0%
TBI patients | 0.017 (-0.022 to 0.056) | 2 | 66% | -- | -- | --
Low risk of bias studies | 0.026 (0.019 to 0.034) | 4 | 0% | 0.029 (0.021 to 0.037) | 3 | 0%
Enrollment before 2006 | 0.033 (0.021 to 0.045) | 6 | 74% | 0.032 (0.025 to 0.039) | 5 | 0%
Enrollment 2006 or later | 0.019 (-0.009 to 0.047) | 1 | -- | -- | -- | --
Severe brain injury, overall | 0.050 (0.034 to 0.065) | 5 | 57% | 0.048 (0.038 to 0.059) | 5 | 72%
Adults or mixed | 0.046 (0.038 to 0.054) | 4 | 0% | 0.048 (0.038 to 0.059) | 5 | 72%
Children | 0.121 (0.068 to 0.174) | 1 | -- | -- | -- | --
Excluding NTDB studies | 0.050 (0.034 to 0.065) | 5 | 57% | 0.048 (0.038 to 0.059) | 5 | 72%
Excluding studies with potential overlap^*^ | 0.065 (0.020 to 0.111) | 3 | 76% | 0.051 (0.034 to 0.068) | 3 | 74%
Out-of-hospital GCS | 0.041 (0.028 to 0.053) | 2 | 0% | 0.051 (0.034 to 0.068) | 3 | 74%
ED GCS | 0.060 (0.028 to 0.093) | 3 | 73% | 0.044 (0.030 to 0.059) | 2 | 51%
U.S. setting | 0.050 (0.034 to 0.065) | 5 | 57% | 0.048 (0.038 to 0.059) | 5 | 72%
TBI patients | -- | -- | -- | -- | -- | --
Low risk of bias studies | 0.046 (0.038 to 0.053) | 3 | 0% | 0.044 (0.035 to 0.053) | 3 | 25%
Enrollment before 2006 | 0.050 (0.034 to 0.065) | 5 | 57% | 0.048 (0.038 to 0.059) | 5 | 72%
Enrollment 2006 or later | -- | -- | -- | -- | -- | --
Emergency intubation, overall | 0.034 (0.020 to 0.048) | 6 | 88% | 0.040 (0.030 to 0.050) | 5 | 55%
Adults or mixed | 0.034 (0.020 to 0.048) | 6 | 88% | 0.040 (0.030 to 0.050) | 5 | 55%
Children | -- | -- | -- | -- | -- | --
Excluding studies with potential overlap^*^ | 0.026 (0.015 to 0.037) | 4 | 68% | 0.033 (0.025 to 0.040) | 3 | 0%
Out-of-hospital GCS | 0.026 (0.015 to 0.037) | 4 | 68% | 0.033 (0.025 to 0.040) | 3 | 0%
ED GCS | 0.048 (0.039 to 0.057) | 2 | 0% | 0.048 (0.039 to 0.057) | 2 | 0%
U.S. setting | 0.034 (0.020 to 0.048) | 6 | 88% | 0.040 (0.030 to 0.050) | 5 | 55%
TBI patients | 0.011 (-0.010 to 0.032) | 1 | -- | -- | -- | --
Low risk of bias studies | 0.037 (0.022 to 0.052) | 4 | 79% | 0.046 (0.038 to 0.054) | 3 | 0%
Enrollment before 2006 | 0.038 (0.020 to 0.055) | 5 | 91% | 0.040 (0.030 to 0.050) | 5 | 55%
Enrollment 2006 or later | 0.018 (0.005 to 0.031) | 1 | -- | -- | -- | --

AUROC=area under the receiver operating characteristic curve; CI=confidence interval; ED=emergency department; GCS=Glasgow Coma Scale; mGCS=motor Glasgow Coma Scale; NTDB=National Trauma Data Bank; SMS=Simplified Motor Score; TBI=traumatic brain injury; tGCS=total Glasgow Coma Scale

* When multiple studies published from the same trauma center, analysis restricted to the most recent study using prehospital GCS scores (excluded Gill 2005,^20^ Haukoos 2007,^59^ Acker 2014^51^)

Data on the diagnostic accuracy of the tGCS versus the mGCS were limited (Table 5). In five studies, sensitivity ranged widely from 30 percent to 100 percent for the tGCS (cutoff of ≤13) and from 27 percent to 100 percent for the mGCS (cutoff of ≤5); however, differences in sensitivity were small, ranging from 0 percent to 3 percent (Table 5).^19,52,53,61,62^ Specificity ranged from 68 percent to 93 percent for the tGCS and from 73 percent to 95 percent for the mGCS; difference in specificity ranged from 0 percent to 5 percent in favor of the mGCS, though the CIs overlapped in most studies. Two of the studies were conducted in mixed populations of adults and children and one of the studies focused on children (sensitivity 100%, specificity 74%).^62^ The latter study found that the specificity of the tGCS decreased at higher cutoffs (74% for a cutoff of ≤13, 71% for ≤14 and 56% for ≤15) with little change in sensitivity;^62^ the other studies did not report specificity at tGCS cutoffs other than 13 or less. One study found that calibration of the tGCS and mGCS was similarly poor based on the Hosmer-Lemeshow test (p<0.01 for both scales).^52^

Table 5 Summary of diagnostic accuracy outcomes for head-to-head studies

Author, Year Country | Assessment Timing Measures and/or Scores Compared | N | Age | In-Hospital Mortality | Neurosurgical Intervention | Severe Brain Injury | Intubation
Al-Salamah et al., 2004^52^ Canada | Out-of-hospital A: tGCS score ≤13 B: mGCS score ≤5 | 795 | ≥16 years Mean: 44 years | Sensitivity (95% CI)^*^: 80.28% (72.78 to 86.48) vs. 80.28% (72.78 to 86.48) Specificity (95% CI)^*^: 67.99% (64.26 to 71.56) vs. 73.05% (69.47 to 76.42) PPV (95% CI)^*^: 35.29% (30.08 to 40.78) vs. 39.31% (33.65 to 45.19) NPV (95% CI)^*^: 94.07% (91.54 to 96.02) vs. 94.46% (92.09 to 96.28) | NR | NR | NR
Brown et al., 2014^†^, ^53^ USA | Out-of-hospital A: tGCS score ≤13 B: mGCS score ≤5 | 811,143 | ≥3 years Median: 39 years | Sensitivity: 30.3% vs. 26.7% Specificity: 93.1% vs. 95.1% | NR | NR | NR
Caterino and Raubenolt, 2012^54^ USA | Out-of-hospital A: tGCS ≤13 B: SMS ≤1 | 52,412 | ≥16 years Mean: 53 years | Sensitivity (95% CI)^*^: 75.03% (73.45 to 76.56) vs. 72.20% (70.57 to 73.79) Specificity (95% CI)^*^: 87.63% (87.34 to 87.92) vs. 89.42% (89.14 to 89.69) PPV (95% CI)^*^: 27.20% (26.25 to 28.17) vs. 29.59% (28.55 to 30.64) NPV (95% CI)^*^: 98.28% (98.15 to 98.40) vs. 98.12% (97.99 to 98.25) | Sensitivity (95% CI)^*^: 60.05% (56.53 to 63.50) vs. 52.93% (49.37 to 56.46) Specificity (95% CI)^*^: 84.70% (84.39 to 85.01) vs. 86.40% (86.10 to 86.69) PPV (95% CI)^*^: 5.64% (5.15 to 6.15) vs. 5.59% (5.08 to 6.14) NPV (95% CI)^*^: 99.29% (99.20 to 99.36) vs. 99.18% (99.09 to 99.26) | Sensitivity (95% CI)^*^: 45.40% (44.30 to 46.50) vs. 40.81% (39.72 to 41.89) Specificity (95% CI)^*^: 89.30% (89.01 to 89.59) vs. 90.50% (90.22 to 90.77) PPV (95% CI)^*^: 43.20% (42.13 to 44.27) vs. 43.50% (42.38 to 44.64) NPV (95% CI)^*^: 90.12% (89.84 to 90.40) vs. 89.51% (89.22 to 89.79) | Any emergency intubation Sensitivity (95% CI)^*^: 75.50% (74.13 to 76.83) vs. 72.71% (71.30 to 74.09) Specificity (95% CI)^*^: 88.90% (88.62 to 89.18) vs. 90.60% (90.34 to 90.86) PPV (95% CI)^*^: 35.87% (34.84 to 36.91) vs. 38.88% (37.77 to 40.00) NPV (95% CI)^*^: 97.78% (97.64 to 97.92) vs. 97.58% (97.44 to 97.72) ED intubation Sensitivity (95% CI)^*^: 76.89% (75.43 to 78.31) vs. 74.09% (72.57 to 75.57) Specificity (95% CI)^*^: 88.20% (87.91 to 88.48) vs. 89.83% (89.56 to 90.09) PPV (95% CI)^*^: 30.82% (29.83 to 31.82) vs. 33.22% (32.15 to 34.30) NPV (95% CI)^*^: 98.24% (98.11 to 98.36) vs. 98.07% (97.94 to 98.19)
Kupas et al., 2016^61^ USA | Out-of-hospital A: tGCS score ≤13 B: mGCS score ≤5 | 370,392 | >18 years Mean: NR | Sensitivity (95% CI): 69.8% (69.2 to 70.4) vs. 67.3% (66.7 to 67.9) Specificity (95% CI): 88.1% (88.0 to 88.2) vs. 90.1% (90.0 to 90.2) | Sensitivity (95% CI): 51.4% (50.2 to 52.5) vs. 46.5% (45.4 to 47.7) Specificity (95% CI): 85.9% (85.8 to 86.0) vs. 87.8% (87.7 to 87.9) | NR | Sensitivity (95% CI): 83.7% (83.3 to 84.2) vs. 81.3% (80.9 to 81.8) Specificity (95% CI): 90.0% (89.9 to 90.1) vs. 92.0% (91.9 to 92.1)
Ross et al., 1998^19^ USA | Out-of-hospital A: tGCS score ≤13 B: mGCS score ≤5 | 1,410 | ≥13 years Mean: 37 years | Sensitivity (95% CI)^*^: 71.28% (61.02 to 80.14) vs. 72.34% (62.15 to 81.07) Specificity (95% CI)^*^: 84.95% (82.91 to 86.84) vs. 86.02% (84.03 to 87.85) PPV (95% CI)^*^: 25.28% (20.16 to 30.96) vs. 26.98% (21.61 to 32.91) NPV (95% CI)^*^: 97.64% (96.59 to 98.44) vs. 97.75% (96.73 to 98.53) | Sensitivity (95% CI)^*^: 63.16% (38.36 to 83.71) vs. 68.42% (43.45 to 87.42) Specificity (95% CI)^*^: 81.81% (79.68 to 83.81) vs. 82.82% (80.73 to 84.77) PPV (95% CI)^*^: 4.53% (2.36 to 7.78) vs. 5.16% (2.78 to 8.66) NPV (95% CI)^*^: 99.39% (98.74 to 99.75) vs. 99.48% (98.88 to 99.81) | Sensitivity: 61.72% (54.76 to 68.34) vs. 60.77% (53.79 to 67.43) Specificity: 85.47% (83.05 to 87.67) vs. 89.59% (87.73 to 91.26) PLR: 4.25 (3.52 to 5.13) vs. 5.84 (4.79 to 7.12) NLR: 0.45 (0.38 to 0.53) vs. 0.44 (0.37 to 0.52) PPV: 48.68% (42.52 to 54.87) vs. 50.40% (44.05 to 56.73) NPV: 90.91% (88.81 to 92.73) vs. 92.92% (91.29 to 94.33) | NR
Van de Voorde et al., 2008^62^ Belgium | Out-of-hospital and ED A: tGCS score ≤13 B: mGCS score ≤5 | 96 | ≤18 years Mean: 8 years | Sensitivity (95% CI): 100% (69.15 to 100) vs. 100% (69.15 to 100) Specificity (95% CI): 74.39% (63.56 to 83.40) vs. 74.36% (63.21 to 83.58) | NR | NR | NR

CI=confidence interval; ED=emergency department; mGCS=motor Glasgow Coma Scale; n=number; NPV=negative predictive value; NR=not reported; PPV=positive predictive values; SMS=Simplified Motor Scale; tGCS=total Glasgow Coma Scale; vs.=versus

* Calculated

† Study from NTDB database

##### Total Glasgow Coma Scale Versus Simplified Motor Scale

The tGCS was slightly better than the SMS at discriminating patients who experienced in-hospital mortality from patients who survived to hospital discharge. Based on five studies, the pooled AUROC for the tGCS was 0.884 (95% CI 0.852 to 0.916) and for the SMS was 0.840 (95% CI 0.802 to 0.878), with a mean difference of 0.030 (95% CI 0.024 to 0.036, I^2^=0%; Figure 4).^20,36,48,54,59^ All of the studies were conducted in the United States and none focused on children or patients with TBI. There were no differences in estimates between studies that utilized out-of-hospital GCS scores or ED GCS scores (Table 4). Results were also unchanged when analyses were restricted to low risk of bias studies, or when studies from the same center with potential overlap^20,59^ were excluded. No study was based on the NTDB database.

One study found the out-of-hospital tGCS (cutoff of ≤13) associated with slightly higher sensitivity versus the SMS (cutoff of ≤1) (75% vs. 72%) and slightly lower specificity (88% vs. 89%; Table 5).^54^

Figure 4 Pooled AUROC of in-hospital mortality for the total Glasgow Coma Scale versus the Simplified Motor Scale

AUROC=area under the receiver operating characteristic curve; CI=confidence interval; n=number; NR=not reported; SMS=Simplified Motor Scale; tGCS=total Glasgow Coma Scale

Figure 4 is a meta-analysis forest plot comparing how well tGCS and SMS discriminate persons who experienced in-hospital mortality from persons who survived to hospital discharge. This figure is described further in the section “Mortality” as follows: “Based on five studies, the pooled AUROC for the tGCS was 0.884 (95% CI 0.852 to 0.916) and for the SMS was 0.840 (95% CI 0.802 to 0.878), with a mean difference of 0.030 (95% CI 0.024 to 0.036, I2=0%).”

##### Motor Glasgow Coma Scale Versus Simplified Motor Scale

The mGCS was slightly better than the SMS at discriminating patients who experienced in-hospital mortality from patients who survived to hospital discharge (4 studies, mean difference in AUROC 0.014, 95% CI 0.006 to 0.021, I^2^=0%).^20,36,48,59^ There was no statistical heterogeneity and findings were unchanged in sensitivity and subgroup analyses.

#### Neurosurgical Intervention

##### Total Glasgow Coma Scale Versus Motor Glasgow Coma Scale

The tGCS was slightly better than the mGCS at discriminating patients who went on to receive a neurosurgical intervention from those who did not. Based on seven studies, the pooled AUROC for the tGCS was 0.786 (95% CI 0.729 to 0.842) and for the mGCS was 0.754 (95% CI 0.688 to 0.819) for a mean difference of 0.032 (95% CI 0.020 to 0.043; I^2^=72%; Figure 5).^17,20,36,48,51,59,61^ Results were similar when the analysis was performed using the profile likelihood method. Results were similar in one study^51^ that restricted enrollment to children (mean difference in AUROC 0.034, 95% CI 0.009 to 0.059) and the other six studies, which evaluated mixed populations of adults and children (mean difference in AUROC 0.031, 95% CI 0.018 to 0.044, I^2^=76%). Two studies that reported results for craniotomy only^51,61^ reported results similar to studies that evaluated craniotomy plus other neurosurgical interventions. Results were also similar when studies were stratified according to whether they used out-of-hospital or ED GCS scores, or when analyses were restricted to studies conducted in the United States, studies that focused on TBI patients, or low risk of bias studies (Table 4). No study was based on the NTDB database.

Figure 5 Pooled AUROC of neurological intervention for the total Glasgow Coma Scale versus the motor component only

AUROC=area under the receiver operating characteristic curve; CI=confidence interval; mGCS=motor Glasgow Coma Scale; n=number; NA=not applicable; NR=not reported; tGCS=total Glasgow Coma Scale

* Intracranial pressure monitoring only

Figure 5 is a meta-analysis forest plot comparing how well tGCS and mGCS discriminate persons who underwent a neurosurgical intervention from persons who did not undergo a neurosurgical intervention. This figure is described further in the section “Mortality” as follows: “Based on seven studies, the pooled AUROC for the tGCS was 0.786 (95% CI 0.729 to 0.842) and for the mGCS was .754 (95% CI 0.688 to 0.819) for a mean difference of 0.032 (95% CI 0.020 to 0.043; I2=72%). Results were similar when the analysis was performed using the profile likelihood method. Results were similar in one study that restricted enrollment to children (mean difference in AUROC 0.034, 95% CI 0.009 to 0.059) and the other six studies, which evaluated mixed populations of adults and children (mean difference in AUROC 0.031, 95% CI 0.018 to 0.044, I2=76%).

Two studies found inconsistent results for sensitivity (51%, 95% CI 50 to 52 vs. 46%, 95% CI 45 to 48 and 63%, 95% CI 38 to 84 vs. 68%, 95% CI 43 to 87) and no clear differences in specificity (86%, 95% CI, 86 to 86 vs. 88%, 95% CI 88 to 88 and 82%, 95% CI 80 to 84 vs. 83%, 95% CI 81 to 85) between out-of-hospital tGCS (cutoff of ≤13) versus the mGCS (cutoff of ≤5) in accuracy for identifying patients undergoing craniotomy (Table 5).^19,61^

##### Total Glasgow Coma Scale Versus Simplified Motor Scale

The tGCS was slightly better than the SMS at discriminating patients who underwent a neurosurgical intervention from patients who did not undergo a neurosurgical intervention; results were very similar to the comparison of the tGCS with the mGCS. Based on five studies, the pooled AUROC for the tGCS was 0.809 (95% CI 0.766 to 0.853) and for the mGCS was 0.769 (95% CI 0.711 to 0.827), with a mean difference of 0.032 (95% CI 0.025 to 0.039, I^2^=0%; Figure 6).^20,36,48,54,59^ All of the studies were conducted in the United States and none focused on children or patients with TBI. There were no differences in estimates between studies that utilized out-of-hospital GCS scores or ED GCS scores (Table 4). Results were also unchanged when analyses were restricted to low risk of bias studies, or when studies with potential overlap^20,59^ were excluded. No study utilized data from the NTDB.

Figure 6 Pooled AUROC of neurological intervention for the total Glasgow Coma Scale versus the Simplified Motor Scale

AUROC=area under the receiver operating characteristic curve; CI=confidence interval; n=number; NR=not reported; SMS=Simplified Motor Scale; tGCS=total Glasgow Coma Scale

Figure 6 is a meta-analysis forest plot comparing how well tGCS and SMS discriminate persons who underwent a neurosurgical intervention from persons who did not undergo a neurosurgical intervention. This figure is described further in the section “Mortality” as follows: “Based on five studies, the pooled AUROC for the tGCS was 0.809 (95% CI 0.766 to 0.853) and for the mGCS was 0.769 (95% CI 0.711 to 0.827), with a mean difference of 0.032 (95% CI 0.025 to 0.039, I2=0%).”

One study found the out-of-hospital tGCS (cutoff of ≤13) associated with higher sensitivity than the SMS (cutoff of ≤1) for identifying patients who underwent neurosurgical intervention (60%, 95% CI 56 to 63 vs. 53%, 95% CI 49 to 56) and slightly lower specificity (85%, 95% CI 84 to 85 vs. 86%, 95% CI 86 to 87; Table 5).^54^

##### Motor Glasgow Coma Scale Versus Simplified Motor Scale

There was no difference between the mGCS and the SMS in ability to discriminate patients who would undergo a neurosurgical intervention from those who would not undergo a neurosurgical intervention (4 studies, mean difference in AUROC 0.002, 95% CI -0.005 to 0.010, I^2^=0%).^20,36,48,59^ There was no statistical heterogeneity and findings were unchanged in sensitivity and stratified analyses.

#### Severe Brain Injury

##### Total Glasgow Coma Scale Versus Motor Glasgow Coma Scale

The tGCS was slightly better than the mGCS at discriminating patients found to have a severe brain injury from those without severe brain injury. Based on five studies, the pooled AUROC for the tGCS was 0.791 (95% CI 0.734 to 0.827) and for the mGCS was 0.720 (95% CI 0.666 to 0.774), with a mean difference of 0.050 (95% CI 0.034 to 0.065; I^2^=57%; Figure 7).^20,36,48,55,59,60^ Results were similar when the analysis was performed using the profile likelihood method. The mean difference in AUROC was slightly higher in one study of children (0.121, 95% CI 0.068 to 0.174)^55,60^ than in four studies of mixed populations of adults and children (0.046, 95% CI 0.038 to 0.054, I^2^=0%),^20,36,48,59^ but there was no statistically significant interaction with age group (p=0.07). Differences in how severe brain injury was defined could explain some of the differences in estimates. The study in children used a composite outcome of head CT imaging findings or need for intervention.^60^ All of the studies of mixed populations of adults and children defined severe brain injury on the basis of CT imaging findings.

Figure 7 Pooled AUROC of severe brain injury for the total Glasgow Coma Scale versus the motor component only

AUROC=area under the receiver operating characteristic curve; CI=confidence interval; mGCS=motor Glasgow Coma Scale; n=number; NR=not reported; tGCS=total Glasgow Coma Scale

Figure 7 is a meta-analysis forest plot comparing how well tGCS and mGCS discriminate persons found to have severe brain injury from persons without severe brain injury. This figure is described further in the section “Mortality” as follows: “Based on five studies, the pooled AUROC for the tGCS was 0.791 (95% CI 0.734 to 0.827) and for the mGCS was 0.720 (95% CI 0.666 to 0.774), with a mean difference of 0.050 (95% CI 0.034 to 0.065; I2=57%). Results were similar when the analysis was performed using the profile likelihood method. The mean difference in AUROC was slightly higher in the one study of children (0.121, 95% CI 0.068 to 0.174) than in four studies of mixed populations of adults and children (0.046, 95% CI 0.038 to 0.054, I2=0%), but there was no statistically significant interaction with age group (p=0.07).”

Results were similar when studies were stratified according to whether they used out-of-hospital or ED GCS scores, or when analyses were restricted to studies conducted in the United States, studies that focused on TBI patients, or low risk of bias studies (Table 4). There were also no differences when we excluded studies with potential overlap.^20,59^ No study was based on data from the NTDB.

One study found no difference between out-of-hospital tGCS (cutoff of ≤13) versus the mGCS (cutoff of ≤5) in sensitivity (62%, 95% CI 55 to 68 vs. 61%, 95% CI 54 to 67) or specificity (85%, 95% CI 83 to 88 vs. 89%, 95% CI 88 to 91) for identifying patients with severe head injury (defined as head AIS score of ≥4)^19^ (Table 5).

##### Total Glasgow Coma Scale Versus Simplified Motor Scale

The tGCS was slightly better than the SMS at discriminating patients found to have severe brain injury from those without a severe brain injury; results were very similar to the comparison of tGCS versus mGCS. Based on five studies, the pooled AUROC for the tGCS was 0.763 (95% CI 0.710 to 0.815) and for the mGCS was 0.713 (95% CI 0.654 to 0.771), with a mean difference of 0.048 (95% CI 0.038 to 0.059, I^2^=72%; Figure 8).^20,36,48,54,59^ Although statistical heterogeneity was present, the estimates from individual studies were similar (mean difference in AUROC ranged from 0.035 to 0.060), and all studies favored the tGCS. All of the studies defined severe brain injury similarly, based on head CT imaging findings. All of the studies were conducted in the United States and none focused on children or patients with TBI. There were no differences in estimates between studies that utilized out-of-hospital GCS scores or ED GCS scores (Table 4). Results were also unchanged when analyses were restricted to low risk of bias studies, or when studies with potential overlap^20,59^ were excluded. No study utilized the NTDB database. Results were unchanged using the profile likelihood method.

Figure 8 Pooled AUROC of severe brain injury for the total Glasgow Coma Scale versus the Simplified Motor Scale

AUROC=area under the receiver operating characteristic curve; CI=confidence interval; n=number; NR=not reported; SMS=Simplified Motor Scale; tGCS=total Glasgow Coma Scale

Figure 8 is a meta-analysis forest plot comparing how well tGCS and SMS discriminate persons found to have severe brain injury from persons without severe brain injury. This figure is described further in the section “Mortality” as follows: “Based on five studies, the pooled AUROC for the tGCS was 0.763 (95% CI 0.710 to 0.815) and for the mGCS was 0.713 (95% CI 0.654 to 0.771), with a mean difference of 0.048 (95% CI 0.038 to 0.059, I2=72%).”

One study found out-of-hospital tGCS (cutoff of ≤13) associated with slightly higher sensitivity than the SMS (cutoff of ≤1) for severe brain injury (45%, 95% CI 44 to 46 vs. 41%, 95% CI 40 to 42), based on presence of head CT imaging findings, and similar specificity (89%, 95% CI 89 to 90 vs. 90%, 95% CI 90 to 91; Table 5).^54^

##### Motor Glasgow Coma Scale Versus Simplified Motor Scale

There was no difference between the mGCS versus the SMS in ability to discriminate patients who would undergo a neurosurgical intervention from those who would not undergo a neurosurgical intervention (4 studies, mean difference in AUROC 0.000, 95% CI -0.008 to 0.007, I^2^=0%).^20,36,48,59^ There was no statistical heterogeneity and findings were unchanged in sensitivity and stratified analyses.

#### Emergency Intubation

##### Total Glasgow Coma Scale Versus Motor Glasgow Coma Scale

The tGCS was slightly better than the mGCS at discriminating patients who underwent emergency intubation from those who did not undergo intubation. Based on six studies, the pooled AUROC for the tGCS was 0.865 (95% CI 0.830 to 0.901) and for the mGCS was 0.822 (95% CI 0.775 to 0.870), with a mean difference of 0.034 (95% CI 0.020 to 0.048; I^2^=88%; Figure 9).^17,20,36,48,59,61^ Although statistical heterogeneity was present, estimates were similar across studies (mean difference in AUROC ranged from 0.018 to 0.050) and all studies favored the tGCS. There was no clear difference in estimates between two studies that focused on out-of-hospital intubation (mean difference in AUROC 0.039 and 0.040)^20,36^ and four studies that evaluated any emergency intubation (ED or out-of-hospital) (mean difference in AUROC 0.018 to 0.050).^17,48,59,61^ All of the studies evaluated mixed populations of adults and children and were conducted in the United States. There were no differences when studies were stratified according to use of out-of-hospital or ED GCS scores, when analyses were restricted to low risk of bias studies, or when we excluded studies with potential overlap in populations. One study reported subgroup findings for trauma patients with TBI;^17^ as in the analysis of patients with any trauma, results favored the tGCS (mean difference in AUROC 0.011, 95% CI -0.010 to 0.032). No study was based on data from the NTDB.

Figure 9 Pooled AUROC of intubation for the total Glasgow Coma Scale versus the motor component only

AUROC=area under the receiver operating characteristic curve; CI=confidence interval; mGCS=motor Glasgow Coma Scale; n=number; NR=not reported; tGCS=total Glasgow Coma Scale

Figure 9 is a meta-analysis forest plot comparing how well tGCS and mGCS discriminate persons who underwent intubation from persons who did not undergo intubation. This figure is described further in the section “Mortality” as follows: “Based on six studies, the pooled AUROC for the tGCS was 0.865 (95% CI 0.830 to 0.901 and for the mGCS was 0.822 (95% CI 0.775 to 0.870), with a mean difference of 0.034 (95% CI 0.020 to 0.048; I2=88%). Although statistical heterogeneity was present, estimates were similar across studies (mean difference in AUROC ranged from 0.018 to 0.050) and all studies favored the tGCS.”

##### Total Glasgow Coma Scale Versus Simplified Motor Scale

The tGCS was slightly better than the SMS at discriminating patients who underwent emergency intubation from patients who did not undergo intubation; results were very similar to the comparison of tGCS versus mGCS. Based on five studies, the pooled AUROC for the tGCS was 0.843 (95% CI 0.823 to 0.864) and for the SMS was 0.783 (95% CI 0.747 to 0.819), with a mean difference of 0.040 (95% CI 0.030 to 0.050, I^2^=55%, Figure 10).^20,36,48,54,59^ Although statistical heterogeneity was present, the estimates from individual studies were similar (mean difference in AUROC ranged from 0.030 to 0.050), and all studies favored the tGCS. All of the studies defined severe brain injury similarly, based on head CT imaging findings. All of the studies were conducted in the United States and none focused on children or patients with TBI. There were no differences in estimates between studies that utilized out-of-hospital GCS scores or ED GCS scores (Table 4). Results were also unchanged when analyses were restricted to low risk of bias studies, or when studies with potential overlap^20,59^ were excluded. No study utilized data from the NTDB. Results were unchanged using the profile likelihood method.

Figure 10 Pooled AUROC of intubation for the total Glasgow Coma Scale versus the Simplified Motor Scale

AUROC=area under the receiver operating characteristic curve; CI=confidence interval; n=number; NR=not reported; SMS=Simplified Motor Scale; tGCS=total Glasgow Coma Scale

Figure 10 is a meta-analysis forest plot comparing how well tGCS and SMS discriminate persons who underwent intubation from persons who did not undergo intubation. This figure is described further in the section “Mortality” as follows: “Based on five studies, the pooled AUROC for the tGCS was 0.843 (95% CI 0.823 to 0.864) and for the SMS was 0.783 (95% CI 0.747 to 0.819), with a mean difference of 0.040 (95% CI 0.030 to 0.050, I2=55%).”

One study found the out-of-hospital tGCS (cutoff of ≤13) associated with slightly higher sensitivity than the SMS (cutoff of ≤1) for identifying patients who underwent emergency intubation (76%, 95% CI 74 to 77 vs. 73%, 95% CI 71 to 74) and slightly lower specificity (89%, 95% CI 89 to 89 vs. 91%, 95% CI 90 to 91; Table 5).^54^

##### Motor Glasgow Coma Scale Versus Simplified Motor Scale

There was no clear difference between the mGCS versus the SMS in ability to discriminate between patients who undergo emergency intubation from those who do not undergo emergency intubation (4 studies, mean difference in AUROC 0.000, 95% CI -0.007 to 0.007, I^2^=0%).^20,36,48,59^ There was no statistical heterogeneity and findings were unchanged in sensitivity and stratified analyses.

#### Trauma Center Need

Two studies (n=811,143 and n=393,877) evaluated the predictive utility of the tGCS versus the mGCS for identifying patients in need of trauma center care (defined as ISS score of >5, ICU admission >24 hours, need for urgent surgery, or death in the ED).^53,61^ Differences in the AUROC (0.617 vs. 0.609 [CIs not reported] and 0.641, 95% CI 0.639 to 0.642 vs. 0.603, 95% CI 0.602 to 0.604), sensitivity (30% vs. 27% [CIs not reported] and 28%, 95% CI 28 to 28 vs. 25%, 95% CI 25 to 25), and specificity (93% vs. 95% [CIs not reported] and 94%, 95% CI 94 to 94 vs. 95%, 95% CI 95 to 95) were small. The adjusted risk estimates were also similar (odds ratio [OR] 3.03, 95% CI 2.95 to 3.13 for tGCS score of ≤13 vs. >13 and OR 3.37, 95% CI 3.27 to 3.48 for mGCS score of ≤5 vs. >5).

#### Other Outcomes

Two studies found the tGCS was better able to discriminate those with major injury (defined as an ISS score of >15) from those without major injury (AUROC 0.720, 95% CI 0.715 to 0.724 vs 0.681, 95% CI 0.677 to 0.686^55^ and 0.648, 95% CI 0.646 to 0.650 vs. 0.606, 95% CI 0.605 to 0.608^61^). One study found the out-of-hospital tGCS (cutoff of ≤13) associated with slightly higher sensitivity than the mGCS (cutoff of ≤5) for identifying people with major injury (defined as an ISS score of >15) from those without major injury (sensitivity 31%, 95% CI 31 to 32 vs. 28%, 95% CI 28 to 28 and slightly lower specificity 91%, 95% CI 91 to 91 vs. 93%, 95% CI 93 to 93).^61^ Two studies found that the tGCS was better able to discriminate those admitted to the ICU from those not admitted to the ICU (AUROC 0.772, 95% CI 0.754 to 0.790 vs. 0.721, 95% CI 0.705 to 0.738, p<0.001^51^ and 0.625, 95% CI 0.623 to 0.626 vs. 0.583, 95% CI 0.581 to 0.584, difference 0.042, 95% CI 0.041 to 0.043^61^). One study (n=2,231) of children with TBI found that the tGCS was better able to discriminate those with a length of stay 5 days or longer from those with a stay of more than 5 days (0.683, 95% CI 0.660 to 0.706 vs. 0.644, 95% CI 0.622 to 0.666, p<0.001), those discharged to rehabilitation from those not discharged to rehabilitation (0.804, 95% CI 0.782 to 0.826 vs. 0.766, 95% CI 0.740 to 0.792, p<0.001), and those dependent on a caregiver from those not dependent on a caregiver following discharge (0.757, 95% CI 0.732 to 0.783 vs. 0.747, 95% CI 0.722 to 0.772, p=0.06).^51^

## Key Question 1a How does predictive utility vary according to patient age or other patient characteristics (e.g., TBI vs. unspecified or other trauma, systolic blood pressure, level of intoxication, type of trauma, intubation or receipt of medications in the field), the training and background of the person administering the instrument, and the timing/setting of assessment (i.e., in the field vs. upon presentation to the ED or urban vs. rural location)?

### Key Points

- Age: Differences in the AUROC between the tGCS versus the mGCS were similar in studies that enrolled children and those that enrolled mixed populations of adults and children (SOE: Low).
- Type of trauma: Differences in the AUROC between the tGCS versus the mGCS were similar in studies that evaluated patients with TBI and those that enrolled mixed trauma patients (SOE: Low).
- Out-of-hospital vs. ED assessment: One study of adults found no differences between out-of-hospital and ED GCS scores on discrimination for in-hospital mortality or neurosurgical intervention but another study of adults or children found out-of-hospital GCS scores associated with higher discrimination for in-hospital mortality than ED scores (AUROC 0.754 vs. 0.635, p-value not reported). Differences in the AUROC between the tGCS versus the mGCS were similar in studies that evaluated out-of-hospital GCS scores and those that used ED scores (SOE: Insufficient).
- No study evaluated how intoxication status, blood pressure, intubation status, receipt of field intubation, or level/training of field assessors impacts comparative predictive utility of the tGCS versus the mGCS or SMS.

### Detailed Synthesis

#### Age

No study that evaluated mixed populations of adults and children performed analyses stratified according to age group. Among the head-to-head studies on predictive utility, two studies on in-hospital mortality, one study on neurosurgical interventions, and two studies on severe brain injuries focused on children. For all of these outcomes, differences between the tGCS versus the mGCS in the AUROC slightly favored the tGCS and estimates were similar in studies that evaluated children and studies that evaluated adults or mixed populations (Table 4). For in-hospital mortality, the mean difference in AUROC was 0.006 (95% CI 0.002 to 0.011, I^2^=0%) in 2 studies of children^51,55^ and 0.019 (95% CI 0.012 to 0.025, I^2^=75%) in 10 studies of adults or mixed populations.^17,18,20,36,48,52,57-59,61^ For neurosurgical intervention, results were similar in one study^51^ of children (mean difference in AUROC 0.034, 95% CI 0.009 to 0.059) and six studies of adults or mixed populations of adults and children (mean difference in AUROC 0.031, 95% CI 0.018 to 0.043, I^2^=72%).^17,20,36,48,59,61^ For severe brain injury, the mean difference in AUROC was higher in one study of children (0.121, 95% CI 0.068 to 0.174)^60^ than in four studies of adults or mixed populations of adults and children (0.046, 95% CI 0.038 to 0.054, I^2^=0%),^20,36,48,59^ but there was no statistically significant interaction with age (p=0.07). The study in children used a broader definition for severe brain injury (based on head CT imaging findings or need for intervention)^60^ than the studies conducted in adults or mixed populations, which focused on CT imaging findings. One study of children up to 18 years of age found no clear differences in AUROC estimates for mGCS between the subgroup of children 0 to 3 years of age and the entire cohort for survival to hospital discharge (0.936, 95% CI 0.911 to 0.962 vs. 0.941, 95% CI 0.926 to 0.957), craniotomy (0.659, 95% CI 0.597 to 0.721 vs. 0.638, 95% CI 0.601 to 0.675), or ICU admission (0.723, 95% CI 0.696 to 0.750 vs. 0.721, 95% CI 0.705 to 0.738), or length of stay greater than 4 days (0.589, 95% CI 0.555 to 0.623 vs. 0.644, 95% CI 0.622 to 0.666). The mGCS was associated with slighter better discrimination for being dependent on a caregiver in those 0 to 3 years (0.787, 95% CI 0.752 to 0.821 vs. 0.747, 95% CI 0.722 to 0.772).^51^

Two studies of children with TBI found a tGCS score of 12 or 13 or less associated with sensitivity of 80 percent and 100 percent for in-hospital mortality; specificity was 74 percent^63^ and 86 percent (Appendix I).^64^ In three studies of adults or mixed populations of adults and children, sensitivity of the tGCS (cutoff of ≤13) ranged from 71 percent to 80 percent and specificity from 68 percent to 88 percent (Table 5).^19,52,54^

One study evaluated the diagnostic accuracy of tGCS in older (≥70 years) versus younger (<70 years) adults (Appendix I).^65^ Based on a tGCS cutoff of 13 or less, it found that sensitivity of the tGCS was lower in adults 70 years or older and worse by more than 20 percent versus those younger for in-hospital mortality (51% vs. 86%), severe TBI (28% vs. 53%), neurosurgical intervention (43% vs. 66%), and emergency intubation (58% vs. 78%). Specificity was greater than 90 percent on these outcomes in adults 70 years or older and 5 percent to 10 percent higher than adults younger than 70 years. At a cutoff of 14 or less, sensitivity improved in patients 70 years or older by about 10 percent on all outcomes and specificity decreased by 5 percent to 10 percent, but the differences compared with patients younger than 70 years of age remained similar. In older adults, decreases in the tGCS to 14 from 15 (adjusted OR [AOR] 1.40, 95% CI 1.07 to 1.83) and from 13 to 14 (AOR 2.34, 95% CI 1.57 to 3.52) were associated with greater risk of in-hospital mortality than in adults younger than 70 years of age (AOR 1.22, 95% CI 0.88 to 1.71 and 1.45, 95% CI 0.91 to 2.30).

#### Type of Trauma

No study that evaluated mixed populations of trauma patients performed analyses stratified according to the type of trauma. Among the head-to-head studies on predictive utility, differences in the AUROC between the tGCS and the mGCS were similar among studies that focused on patients with TBI versus those that evaluated patients with mixed trauma (Table 4). For in-hospital mortality, the difference in the AUROC was 0.009 (95% CI -0.002 to 0.020) in 3 studies of TBI patients^17,51,57^ and 0.017 (95% CI 0.009 to 0.024) in 10 studies of mixed trauma patients.^17,18,20,36,48,52,55,58,59,61^ For neurosurgical intervention, the difference in the AUROC was 0.017 (95% CI -0.022 to 0.056) in two studies of TBI patients^17,51^ and 0.031 (95% CI 0.018 to 0.044) in six studies of mixed trauma patients.^17,20,36,48,59,61^ For emergency intubation, the difference in the AUROC was 0.011 (95% CI -0.010 to 0.032) in one study of TBI patients^17^ and 0.034 (95% CI 0.020 to 0.048) in six studies of mixed trauma patients.^17,20,36,48,59,61^

No head-to-head study evaluated the predictive utility of the tGCS versus the SMS specifically in patients with TBI, or evaluated effects of type of TBI or presence of other injuries on predictive utility. One study of patients with multiple injuries (based on head and skeletal injury AIS scores ≥3) found the tGCS (cutoff of ≤12) associated with sensitivity of 87 percent (95% CI 78 to 94) and specificity of 71 percent (95% CI 68 to 74, Appendix I).^66^ One study of TBI patients found the tGCS associated with an AUROC for in-hospital mortality of 0.85 (95% CI 0.80 to 0.90) among all patients and 0.82 (95% CI 0.77 to 0.86) among the subgroup of patients with a GCS score less than 15 (Appendix I).^67^

#### Field Versus Emergency Department Assessment

Among the head-to-head studies on predictive utility, differences between the tGCS versus the mGCS or the tGCS versus the SMS were similar among studies that used out-of-hospital GCC scores versus ED GCS score (Table 4). For in-hospital mortality, the difference in AUROC for studies that used out-of-hospital GCS scores was 0.016 (95% CI 0.007 to 0.024, I^2^=91%)^17,18,36,48,55,57,61^ and for studies that used ED GCS scores the difference was 0.020 (95% CI 0.006 to 0.034, I^2^=23%).^20,58,59^ Findings were similar for other outcomes and for comparisons of tGCS versus SMS. Of the studies that were pooled, two that used out-of-hospital GCS scores^36,48^ and two that used ED scores^20,59^ were conducted in the same trauma center/system. Differences in the AUROC between the tGCS versus the mGCS or SMS were very similar when results based on out-of-hospital versus ED GCS scores were compared from each system. For example, for in-hospital mortality, a study from the Loma Linda trauma center found out-of-hospital tGCS associated with an AUROC for in-hospital mortality of 0.89 for the tGCS versus 0.88 for the mGCS and 0.86 for the SMS.^36^ Using ED scores, the AUROCs were 0.906, 0.894, and 0.878, respectively.^20^ A study from the Denver trauma system found AUROCs for in-hospital mortality of 0.90, 0.88, and 0.87 for the tGCS, mGCS, and SMS (missing GCS data excluded from analysis).^48^ AUROCs were similar in a study from the Denver trauma system that used ED GCS scores (0.92, 0.90, and 0.89, respectively).^59^ The degree to which the patient populations in studies conducted in the same trauma system overlapped in the studies was unclear. Sample sizes were not the same in the out-of-hospital and ED studies from the same trauma center/system, indicating that some patients with out-of-hospital GCS scores did not have ED scores, or vice versa. In addition, in the Denver studies, data collection dates were not identical for the out-of-hospital (1999 to 2008)^48^ and ED (1995 to 2004)^59^ studies.

Three studies directly compared discrimination for out-of-hospital versus ED GCS scores obtained from the same patients (Appendixes H and I). One study of adults found no differences between out-of-hospital versus ED tGCS for in-hospital mortality (AUROC 0.84 vs. 0.84) or for neurosurgical intervention (0.80 vs. 0.83).^57^ One study (adults or children) found field mGCS scores associated with better discrimination for in-hospital mortality than ED mGCS scores (0.754 vs. 0.635, p-value not reported).^68^ One other study of children found no difference between out-of-hospital versus ED tGCS scores (cutoff of <13) in sensitivity (80% vs. 80%) or specificity (74% vs. 76%) for in-hospital mortality.^63^

#### Other Factors

No study evaluated how intoxication status, blood pressure, intubation status, receipt of field intubation, or level/training of field assessors impacts comparative predictive utility of the tGCS versus the mGCS or SMS.

## Key Question 2 In patients with known or suspected trauma, what are the comparative effects of the tGCS compared with the mGCS on over- and under-triage (e.g., proportion of patients in whom initial emergency medical services transport is to a higher or lower than appropriate level of care, or proportion transferred to a higher or lower level of care)?

### Key Points

- No study compared effects on the tGCS versus the mGCS or SMS on rates of over- or under-triage.

### Detailed Synthesis

No study compared effects of the tGCS versus the mGCS or SMS on rates of over- or under-triage. The head-to-head studies in Key Question 1 of tGCS versus the mGCS or SMS were not designed to assess effects on over- or under-triage, because all patients underwent a single triage decision based on the tGCS, and do not reflect differences in actual triage decisions. In additions, such studies do not account for other factors that impact triage decisions. ^4^

Nonetheless, measures of diagnostic accuracy may provide some indirect information about the potential degree of over-triage (1-specificity, or the false-positive rate) and under-triage (1-sensitivity, or the false-negative rate). However, data on diagnostic accuracy were very limited. For in-hospital mortality, three studies found that differences in sensitivity between the tGCS and mGCS ranged from 0 percent to 1 percent and differences in specificity ranged from 0 percent to 5 percent (Table 5). For other outcomes, data on sensitivity and specificity differences were limited to a single study.

One study on predictive utility included in Key Question 1 attempted to estimate the net effect on over- and under-triage.^53^ It found that replacing the tGCS (cutoff of ≤13) with the mGCS (cutoff of ≤5) in the 2011 Centers for Disease Control and Prevention (CDC) guideline for field triage would result in a net decrease in over- or under-triage of 0.4 percent (prevent over-triage in 1.7% and under-triage in 0.2%, while causing over-triage in 0.4% and under-triage in 1.1%), based on accuracy for identification of patients with trauma center need (ISS of >15, ICU admission ≥24 hours, need for urgent surgery, or death in the ED). In addition, it found that benefits of the mGCS on rates of over- or under-triage may be higher, as 0.5 percent of patients who would have been under-triaged by mGCS would have received the appropriate triage decision based on other elements of the NTTP. Another study included in Key Question 1 found that based on diagnostic accuracy, rates of misclassification for in-hospital survival were very similar for the tGCS versus the mGCS (4.9% vs. 5.1%).^18^

## Key Question 2a How do effects on over- and under-triage vary according to patient age or other patient characteristics (e.g., TBI vs. unspecified or other trauma, systolic blood pressure, level of intoxication, type of trauma, intubation or receipt of medication in the field), the training and background of the person administering the instrument, and the timing/setting of assessment (i.e., in the field vs. upon presentation to the ED or urban vs. rural location)?

### Key Points

- No evidence.

## Key Question 3 In patients with known or suspected trauma, what is the comparative effectiveness of the tGCS compared with the mGCS on clinical outcomes (e.g., in-hospital mortality, morbidity, quality of life)?

### Key Points

- No study compared effects on the tGCS versus the mGCS or SMS on clinical outcomes.

## Key Question 3a How do effects on clinical outcomes vary according to patient age or other patient characteristics (e.g., TBI vs. unspecified or other trauma, systolic blood pressure, level of intoxication, type of trauma, intubation or receipt of medication in the field), the training and background of the person administering the instrument, and the timing/setting of assessment (i.e., in the field vs. upon presentation to the ED or urban vs. rural location)?

### Key Points

- No evidence.

## Key Question 4 In patients with known or suspected trauma, what is the comparative reliability (e.g., interrater and intrarater kappa) and ease of use (e.g., time to complete, amount of missing data, user reported satisfaction) of the tGCS compared with the mGCS score?

### Key Points

- The interrater reliability of tGCS and mGCS appears to be high, but evidence was insufficient to determine if there were differences between scales (SOE: Insufficient).
- Three studies found the tGCS associated with a lower proportion of correct scores than the mGCS (differences in proportion of correct scores ranged from 6% to 27%), though the difference was statistically significant in only one study (SOE: Low).
- Three studies found that training or use of a scoring aid increased the proportion of correct scores on both the tGCS and mGCS (increase in proportion of correct scores ranged from 32% to 70%) (SOE: Low).

### Detailed Synthesis

#### Interrater Reliability

Interrater or inter-observer reliability refers to the extent to which different people using a scale arrive at the same rating for the same patient. Two studies evaluated the interrater reliability of the GCS in TBI patients presenting to the ED (Table 6, Appendix J).^60,69^

Table 6 Reliability and ease of use findings for studies comparing the total Glasgow Coma Scale versus the motor component only

| Author, Year Study Design Risk of Bias Country | Objective | N Type of Raters | Results Overall | Results by Patient Characteristics | Results by Provider Characteristics
Interrater Reliability | Holmes et al., 2005^60^ Cross-sectional High USA | Compare the pediatric GCS in children ≤2 years to the standard GCS in children >2 years. | N=102 patients Emergency Physicians | Weighted kappa (95% CI) across raters tGCS: 0.77 (0.38 to 1.00) for ≤2 year olds and 0.91 (0.75 to 1.00) for >2 year olds mGCS: 0.91 (0.75 to 1.00) for ages combined | Weighted kappa (95% CI) across raters tGCS: 0.77 (0.38 to 1.00) for ≤2 year olds 0.91 (0.75 to 1.00) for >2 year olds mGCS: not reported by age groups | None reported
Ease of Use/Correct Scoring | Bledsoe et al., 2015^70^ Cross-sectional Low USA | Evaluate tGCS and its components in standardized video vignettes. | N= 217 providers; 10 patient scenarios Advanced EMTs CCPs EMTs Nurses Paramedics Physicians Residents | Correct scores (95% CI), tGCS vs. mGCS Across all vignettes and participants: 33.1% (30.2 to 36.0) vs. 59.8% (58.1 to 61.5) | Correct scores tGCS Accuracy was lowest for scenarios with tGCS scores of 9 to 13 (<20%; data taken from figure) mGCS Accuracy not reported by score or severity | Correct scores (95% CI) tGCS vs. mGCS by provider type Highest/best residents: 51% (44.5 to 57.5) vs. 78% (71.5 to 84.5) Lowest/worst nurses tGCS: 29% (10.3 to 47.7) EMTs mGCS: 51% (43.7 to 58.3)
Ease of Use/Correct Scoring | Feldman et al., 2015^71^ RCT Low USA | Assess ability of EMS personal to correctly score the tGCS and its components and to determine if scoring improves with the use of a scoring aid. | N=178 Providers EMTs Paramedics | Correct scores, tGCS vs. mGCS All scenarios: 41.0% vs. 50.6% | Correct, tGCS vs. mGCS Mild TBI scenarios: 54.2% vs. 74.6% Moderate TBI scenarios: 28.8% vs. 35.6% Severe TBI scenarios: 40.0% vs. 41.7% | None reported
Ease of Use/Correct Scoring | Heim et al., 2009^72^ Cross-sectional High Switzerland | Assess knowledge of GCS and scoring of a clinical scenario. | N=103 providers; 1 patient scenario Air rescue physicians | Incorrect (correct) scores tGCS: 36.9% (63.1%) mGCS: 27.2% (72.8%) | None reported | Incorrect (correct) scores by experience Registrars (trainees): 47.5% (52.5%) p=0.095 Fellow: 33.3% (66.7%) p=0.671 Consultant: 0% (100%) p<0.05 Private practice: 36.8% (63.2%) p=1.00 Specialty was not associated with statistically significant differences in errors (anesthesia, internal medicine, general practice, other)
Field vs. ED Agreement | Kerby et al., 2007^73^ Cross-sectional High USA | Linkage of EMS and trauma registry data to determine if differences may cause inappropriate enrollment in out-of-hospital trials. | N=3,052 patients EMTs all levels ED personnel not specified | Weighed kappa (95% CI) tGCS vs. mGCS: 0.53 (0.48 to 0.58) vs. 0.48 (0.43 to 0.53) | Weighted kappa (95% CI) by transport time tGCS vs. mGCS <20 minutes: 0.56 (0.50 to 0.61) vs. 0.52 (0.46 to 0.57) ≥20 minutes: 0.42 (0.32 to 0.52) vs. 0.35 (0.25 to 0.46) | None reported

CCP=critical care paramedic; CI=confidence interval; ED=emergency department; EMS=emergency medical services; EMT=emergency medical technician; GCS=Glasgow Coma Scale; KQ=Key Question; mGCS=motor Glasgow Coma Scale; n=number; RCT=randomized controlled trial; TBI=traumatic brain injury; tGCS=total Glasgow Coma Scale; vs=versus

One high risk of bias study (n=102 patients; number of raters unclear) conducted in the United States compared the interrater reliability of a pediatric version of the tGCS in preverbal children 2 years old and younger and the standard version in children older than two.^60^ Two faculty emergency physicians assessed the same patients upon presentation to the ED. The agreement on tGCS was higher for older children using the standard tGCS (weighted kappa 0.91, 95% CI 0.75 to 1.00) than for younger children using the pediatric tGCS (weighted kappa 0.77, 95% CI 0.38 to 1.00), but estimates were imprecise, particularly for younger children, and CIs overlapped. The interrater reliability of the mGCS for all children in the sample (not reported by age group) was high (weighted kappa 0.91, 95% CI 0.75 to 1.00).

A moderate risk of bias study conducted in Japan assessed interrater reliability of the tGCS in 66 patients with suspected TBI.^69^ The tGCS was assessed by two members of the medical team (number of assessors=33) upon arrival at the ED. The weighted kappa for the TBI patients was 0.74 (95% CI 0.71 to 0.76). The weighted kappa for all trauma patients was not reported.

Methodological shortcomings in the studies include lack of information on how patients were selected or use of a convenience sample, unclear blinding of assessors to other assessors' ratings, and unclear timing of GCS assessment.

#### Ease of Use

Five studies (reported in 4 articles) evaluated the ability of medical personal to correctly score the tGCS and the mGCS,^70-72,74^ based on simulated patients presented in video^70,74^ or written^71,72^ scenarios in which correct scores were determined by experts (Appendix J). In three studies, the assessors were emergency medical technicians (EMTs) and paramedics or paramedic students,^71,74^ in one study the assessors were air rescue physicians,^72^ and the fifth study evaluated assessors with various types and levels (e.g., EMT, nurse, physician, and resident) of training.^70^ Four studies were conducted in the United States^70,71,74^ and one in Switzerland.^72^ Sample sizes ranged from 46 to 217 providers/raters. In four studies, the scenarios represented a spectrum of injury severity from mild to severe; the fifth study^72^ used a single scenario in which the correct tGCS score was 6. Three studies^70-72^ evaluated the proportion of correct scores with the tGCS and the mGCS and the other two^74^ only evaluated the tGCS.

The studies differed in how they were designed. One study was a randomized controlled trial (RCT) (rated low risk of bias) that compared tGCS and mGCS scores with versus without the use of a scoring aid.^71^ One article reported two studies (both rated moderate risk of bias): the first was a before-after study on the effects of video training on tGCS scoring, and the second was also a before-after study on the effects of video training on tGCS scoring, but in which participants were also randomized to use of a GCS scoring aid.^74^ The other two studies (one rated low risk of bias^70^ and the other high risk of bias^72^) used a cross-sectional design. The RCT and one cross-sectional study were rated low risk of bias.^70,71^ Methodological shortcomings in the high and moderate risk of bias studies included use of the same patient scenarios on repeat testing and unclear methods for determining correct answers;^74^ the high risk of bias study only evaluated one scenario and allowed assessors 10 minutes to rate a written scenario.^72^

Three studies consistently found that the proportion of correct scores was lower with the tGCS than with the mGCS.^70-72^ One cross-sectional study found that the overall proportion of correct scores by assessors from different types and levels of training was 33.1 percent (95% CI 30.2 to 36.0) with the tGCS and 59.8 percent (95% CI 58.1 to 61.5) with the mGCS.^70^ In two other studies, the proportion of correct scores was lower with the tGCS than with the mGCS, but differences were not statistically significant. A cross-sectional study found that the proportion of correct scores by air rescue physicians was 63.1 percent (53.8% to 72.4%) for the tGCS and 72.8 percent (95% CI 64.2% to 81.4%) for the mGCS.^72^ An RCT found that the proportion of correct scores by EMTs or paramedics was lower using the tGCS than using the mGCS in assessors randomized to a scoring aid (56.7%, 95% CI 46.5 to 66.9 vs. 70.0%, 95% CI 60.5 to 79.5) as well as those randomized to no aid (25.0%, 95% CI 16.0 to 34.0 vs. 30.7%, 95% CI 21.1 to 40.3), though differences were not statistically significant.^71^ In this study, the overall rate of correct tGCS scores was 41 percent, and 69 percent of scores were within 1 point of the correct score. No other study reported the degree to which incorrect scores differed from correct scores (e.g., the proportion of scores that were incorrect by 1 point vs. those that differed by ≥2 points), or the proportion of scores that crossed GCS triage thresholds (e.g., patient scenario in which the correct tGCS score is 14 or 15 is scored as ≤13).

Three studies (reported in 2 articles) evaluated the effect of training and scoring aids on performance of the tGCS and the mGCS.^71,74^ In one study, 75 attendees at an Emergency Medical Services meeting evaluated four video scenarios depicting a spectrum of injury severity before and after watching a 13-minute training video.^74^ Across the patient scenarios, the proportion of correct scores on the tGCS increased from 15 percent before the video to 64 percent after the video (p<0.001); a similar pattern was observed for each individual patient scenario. In a second study reported in the same article, 46 students in a paramedic class watched the same video, and in addition were randomized to use or not use a tGCS reference card with the scoring for each GCS component. The proportion of correct tGCS scores improved both among those randomized to the reference card aid (50% pre-video and 100% post-video, p=0.001) as well as those randomized to no reference card aid (7.7% pre-video and 76.9% post-video, p<0.0001). In the third study, EMTs and paramedics (n=178) scored one out of nine possible written scenarios (depicting TBI and a spectrum of injury severity) after randomization to a scoring aid or no scoring aid.^71^ The proportion of correct scores was higher with the aid versus without the aid for both the tGCS (56.7% vs. 25.0%, difference 31.9%, 95% CI 18.3 to 45.6) and the mGCS (70.0% vs. 30.7%, difference 39.7%, 95% CI 26.2 to 53.1).

No study compared the ease of use of the tGCS or the mGCS in terms of the amount of time needed to complete assessments of trauma patients or satisfaction of assessors.

## Key Question 4a How do comparative reliability and ease of use vary according to patient age or other patient characteristics (e.g., TBI vs. unspecified or other trauma, systolic blood pressure, level of intoxication, type of trauma, intubation or receipt of medication in the field), the training and background of the person administering the instrument, and the timing/setting of assessment (i.e., in the field vs. upon presentation to the ED or urban vs. rural location)?

### Key Points

- Evidence was insufficient to assess effects of patient or assessor characteristics on comparative interrater reliability of the tGCS versus the mGCS (SOE: Insufficient).
- No study evaluated how comparative interrater reliability or ease of use of the tGCS versus the mGCS vary according to assessment setting (SOE: Insufficient).
- The proportion of correct GCS scores was generally lowest for assessment of patient scenarios with moderate injury severity in three studies, including one study that evaluated the tGCS and the mGCS (SOE: Low).
- Evidence was insufficient to determine effects of level of training or professional background on the proportion of correct scores on the tGCS versus the mGCS (SOE: Insufficient).
- One study found agreement between out-of-hospital and ED scores was similar for the tGCS and the mGCS (SOE: Low).

### Detailed Synthesis

#### Ease of Use

##### Patient Characteristics

Evidence regarding how patient or assessor characteristics impact ease of use of GCS scales was limited. Three studies that assessed the proportion of correct scores on the tGCS or mGCS varied according to TBI severity in the patient scenario assessed.^70,71,74^ In one study (75 assessors) the proportion of correct scores were 64.0 percent to 76.0 percent before viewing a training video and 89.3 percent to 98.6 percent using two patient scenarios of tGCS scores of 15.^74^ For the scenarios with a tGCS of 5, the proportion correct increased from 45.3 percent pre-video to 94.7 percent post-video, and in the scenario with a tGCS of 8, the proportion correct increased from 36.0 percent to 74.7 percent. In another study (178 assessors), the percent correct for both the tGCS and mGCS was highest without a scoring aid in the three mild TBI scenarios (proportion correct 44.8% for the tGCS and 58.6% for the mGCS) and lower in the three severe TBI scenarios (20% and 13.3%, respectively) and the three moderate TBI scenarios (10.3% and 20.7%, respectively).^71^ With a scoring aid, the proportion of correct scores at all severity levels improved but still remained highest for mild TBI (63.3% for tGCS and 90.0% for mGCS) and lower in the moderate (46.7% and 50.0%, respectively) and severe scenarios (60.0% and 70.0%, respectively). The third study (217 assessors) found that the proportion of correct scores was lowest for scenarios in which the tGCS scores were 9 to 13 (<20%) and highest for scenarios in which the tGCS score was 3 (>90% correct).^70^

##### Rater Characteristics

Evidence on how assessor characteristics such as type or level of training impacts the proportion of correct GCS scores was limited. One study (46 assessors) found that prior to watching a training video, neither level of training nor participation in a training course was associated with correct scoring.^74^ After watching the video, participants who had taken a trauma care course in the last 5 years were more likely to score the scenarios correctly (p=0.001). Another study evaluated the proportion of correct scores according to training background (advanced EMTs, EMTs, critical care paramedics, paramedics, nurses, resident physicians, and staff physicians).^70^ The proportion of correct scores was highest for residents with both the tGCS (51%, 95% CI 44.5 to 57.5) and the mGCS (78%, 95% CI 71.5 to 84.5) than the other assessor categories. The proportion of correct scores on the tGCS was lowest for nurses (29%, 95% CI 10.3 to 47.7) and the proportion of correct mGCS scores was lowest for EMTs (51%, 95% CI 43.7 to 58.3). A third study found that the highest rate of errors in scoring on the tGCS was in registrars (physicians who had not yet obtained the rank of consultant) at 47.5 percent, compared with 33.3 percent in fellows and 36.8 percent of physicians in private practice.^72^ Consultants had no errors, but the sample size was small (n=8). There were no clear differences in the rate of errors between different specialties (e.g., anesthesia, internal medicine, general practice, or others).

#### Field Versus Emergency Department Agreement

No study evaluated how interrater reliability or ease of use vary according to assessment setting. Four studies evaluated agreement between out-of-hospital and ED GCS scores.^63,73,75,76^ One high risk of bias study (n=3,052) found that agreement between out-of-hospital and ED scores for adults with blunt or penetrating trauma were similar for the tGCS (weighted kappa 0.53, 95% CI 0.48 to 0.58) and the mGCS (weighted kappa 0.48, 95% CI 0.43 to 0.53).^73^ Agreement between out-of-hospital and ED scores was somewhat higher among patients with shorter versus those with longer transport time (weighted kappa for tGCS 0.56 vs. 0.42, respectively; weighted kappa for mGCS 0.52 vs. 0.35, respectively).

The three other studies focused on the tGCS without a comparison with the mGCS and generally found high levels of agreement between out-of-hospital and ED scores.^63,75,76^ One high risk of bias study (n=7,823) found no statistically significant differences between out-of-hospital and ED tGCS scores for adult trauma patients, with 82 percent of tGCS scores falling in the same category (mild 14-15, moderate 9-13, or severe 3-8), 3 percent higher GCS (less severe in ED) compared with out-of-hospital, and 15 percent lower GCS (more severe in ED).^75^ A moderate risk of bias study (n=1,181) found good agreement between out-of-hospital and ED tGCS scores for trauma patients 15 years old or older, based on an intraclass correlation coefficient of 0.74 (95% CI, 0.37 to 1.12).^76^ In this study, 96.3 percent of out-of-hospital-ED pairs were within a predetermined range of acceptability of 3 points. Another moderate risk of bias study (n=185) found good agreement between out-of-hospital and ED tGCS scores in children, with a weighted kappa of 0.74 (95% CI 0.63 to 0.85).^63^ Although ED scores tended to be higher than out-of-hospital scores, differences were small (0.44 points on average, with no difference in median scores).