# References

1 Centers for Disease Control and Prevention. 10 Leading Causes of Death by Age Group, United States - 2014.
2 Centers for Disease Control and Prevention. 10 Leading Causes of Injury Deaths by Age Group Highlighting Unintentional Injury Deaths, United States - 2014.
3 Centers for Disease Control and Prevention. National Hospital Ambulatory Medical Care Survey: 2011 Emergency Department Summary Tables.
4 Sasser SM, Hunt RC, Faul M, et al. (2012). Guidelines for field triage of injured patients: recommendations of the national expert panel on field triage, 2011. MMWR Recomm Rep.
5 Faul M, Xu L, Wald MM, et al. (2010). Traumatic Brain Injury in the United States: Emergency Department Visits, Hospitalizations and Deaths 2002–2006.
6 Centers for Disease Control and Prevention. Injury Prevention & Control: Traumatic Brain Injury. Rates of TBI-related Emergency Department Visits, Hospitalizations, and Deaths – United States, 2001–2010.
7 (2014). Committee on Trauma, American College of Surgeons, Rotondo MF, et al., editors. Resources for Optimal Care of the Injured Patient.
8 Baxt WG, Moody P. (1987). The impact of advanced prehospital emergency care on the mortality of severely brain-injured patients. J Trauma.
9 MacKenzie EJ, Rivara FP, Jurkovich GJ, et al. (2006). A national evaluation of the effect of trauma-center care on mortality. N Engl J Med.
10 Cook CH, Muscarella P, Praba AC, et al. (2001). Reducing overtriage without compromising outcomes in trauma patients. Arch Surg.
11 Teasdale G, Jennett B. (1974). Assessment of coma and impaired consciousness. A practical scale. Lancet.
12 Teasdale G, Maas A, Lecky F, et al. (2014). The Glasgow Coma Scale at 40 years: standing the test of time. Lancet Neurol.
13 Marshall LF. (1991). Evoked potentials: a decade later. Crit Care Med.
14 Bradshaw D. (2008). Report to the Surgeon General: Traumatic Brain Injury Task Force.
15 Singh B, Murad MH, Prokop LJ, et al. (2013). Meta-analysis of Glasgow Coma Scale and Simplified Motor Score in predicting traumatic brain injury outcomes. Brain Inj.
16 Brown KM, Hirshon JM, Alcorta R, et al. (2014). The implementation and evaluation of an evidence-based statewide prehospital pain management protocol developed using the national prehospital evidence-based guideline model process for emergency medical services. Prehosp Emerg Care.
17 Beskind DL, Stolz U, Gross A, et al. (2014). A comparison of the prehospital motor component of the Glasgow Coma Scale (mGCS) to the prehospital total GCS (tGCS) as a prehospital risk adjustment measure for trauma patients. Prehosp Emerg Care.
18 Healey C, Osler TM, Rogers FB, et al. (2003). Improving the Glasgow Coma Scale score: motor score alone is a better predictor. J Trauma.
19 Ross SE, Leipold C, Terregino C, et al. (1998). Efficacy of the motor component of the Glasgow Coma Scale in trauma triage. J Trauma.
20 Gill M, Windemuth R, Steele R, et al. (2005). A comparison of the Glasgow Coma Scale score to simplified alternative scores for the prediction of traumatic brain injury outcomes. Ann Emerg Med.
21 Cook NR. (2008). Statistical evaluation of prognostic versus diagnostic models: beyond the ROC curve. Clin Chem.
22 Menegazzi JJ, Davis EA, Sucov AN, et al. (1993). Reliability of the Glasgow Coma Scale when used by emergency physicians and paramedics. J Trauma.
23 Gill MR, Reiley DG, Green SM. (2004). Interrater reliability of Glasgow Coma Scale scores in the emergency department. Ann Emerg Med.
24 (2013). National Emergency Medical Services Workforce Data Definitions.
25 Badjatia N, Carney N, Crocco TJ, et al. (2008). Guidelines for prehospital management of traumatic brain injury 2nd edition. Prehosp Emerg Care.
26 Lerner EB, Willenbring BD, Pirrallo RG, et al. (2014). A consensus-based criterion standard for trauma center need. J Trauma Acute Care Surg.
27 Newgard CD, Hsia RY, Mann NC, et al. (2013). The trade-offs in field trauma triage: a multiregion assessment of accuracy metrics and volume shifts associated with different triage strategies. J Trauma Acute Care Surg.
28 Haas B, Stukel TA, Gomez D, et al. (2012). The mortality benefit of direct trauma center transport in a regional trauma system: A population-based analysis. J Trauma Acute Care Surg.
29 Haas B, Gomez D, Zagorski B, et al. (2010). Survival of the fittest: the hidden cost of undertriage of major trauma. J Am Coll Surg.
30 Newgard CD, Staudenmayer K, Hsia RY, et al. (2013). The cost of overtriage: more than one-third of low-risk injured patients were taken to major trauma centers. Health Aff (Millwood).
31 Newgard CD, Yang Z, Nishijima D, et al. (2016). Cost-Effectiveness of Field Trauma Triage among Injured Adults Served by Emergency Medical Services. J Am Coll Surg.
32 Zocchi MS, Hsia RY, Carr BG, et al. (2016). Comparison of mortality and costs at trauma and nontrauma centers for minor and moderately severe injuries in California. Ann Emerg Med.
33 (2014). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
34 Graham E, Chou R, Newgard C, et al. (2016). Field triage guideline revision: Glasgow Coma Scale systematic review. PROSPERO.
35 Bazzoli GJ, Madura KJ, Cooper GF, et al. (1995). Progress in the development of trauma systems in the United States. Results of a national survey. JAMA.
36 Gill M, Steele R, Windemuth R, et al. (2006). A comparison of five simplified scales to the out-of-hospital Glasgow Coma Scale for the prediction of traumatic brain injury outcomes. Acad Emerg Med.
37 Baker SP, O'Neill B, Haddon W, et al. (1974). The injury severity score: a method for describing patients with multiple injuries and evaluating emergency care. J Trauma.
38 Baxt WG, Jones G, Fortlage D. (1990). The trauma triage rule: a new, resource-based approach to the prehospital identification of major trauma victims. Ann Emerg Med.
39 Hayden JA, van der Windt DA, Cartwright JL, et al. (2013). Assessing bias in studies of prognostic factors. Ann Intern Med.
40 Whiting PF, Rutjes AW, Westwood ME, et al. (2011). QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med.
41 Atkins D, Chang SM, Gartlehner G, et al. (2011). Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol.
42 Zweig MH, Campbell G. (1993). Receiver-operating characteristic (ROC) plots: a fundamental evaluation tool in clinical medicine. Clin Chem.
43 Bewick V, Cheek L, Ball J. (2004). Statistics review 13: receiver operating characteristic curves. Crit Care.
44 Landis JR, Koch GG. (1977). The measurement of observer agreement for categorical data. Biometrics.
45 Takwoingi Y, Leeflang MM, Deeks JJ. (2013). Empirical evidence of the importance of comparative studies of diagnostic test accuracy. Ann Intern Med.
46 Cornell JE, Mulrow CD, Localio R, et al. (2014). Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med.
47 Beskind DL, Keim SM, Spaite DW, et al. (2011). Risk adjustment measures and outcome measures for prehospital trauma research: recommendations from the Emergency Medical Services Outcomes Project (EMSOP). Acad Emerg Med.
48 Thompson DO, Hurtado TR, Liao MM, et al. (2011). Validation of the Simplified Motor Score in the out-of-hospital setting for the prediction of outcomes after traumatic brain injury. Ann Emerg Med.
49 Nance M, Rotondo M, Fildes J. (2013). National Trauma Data Bank 2013: Annual Report American College of Surgeons.
50 (2012). AHRQ Methods for Effective Health Care. Chang SM, Matchar DB, Smetana GW, Umscheid CA, et al., editors. Methods Guide for Medical Test Reviews.
51 Acker SN, Ross JT, Partrick DA, et al. (2014). Glasgow motor scale alone is equivalent to Glasgow Coma Scale at identifying children at risk for serious traumatic brain injury. J Trauma Acute Care Surg.
52 Al-Salamah MA, McDowell I, Stiell IG, et al. (2004). Initial emergency department trauma scores from the OPALS study: the case for the motor score in blunt trauma. Acad Emerg Med.
53 Brown JB, Forsythe RM, Stassen NA, et al. (2014). Evidence-based improvement of the National Trauma Triage Protocol: the Glasgow Coma Scale versus Glasgow Coma Scale motor subscale. J Trauma Acute Care Surg.
54 Caterino JM, Raubenolt A. (2012). The prehospital Simplified Motor Score is as accurate as the prehospital Glasgow Coma Scale: analysis of a statewide trauma registry. Emerg Med J.
55 Cicero MX, Cross KP. (2013). Predictive value of initial Glasgow Coma Scale score in pediatric trauma patients. Pediatr Emerg Care.
56 Corrigan JD, Kreider S, Cuthbert J, et al. (2014). Components of traumatic brain injury severity indices. J Neurotrauma.
57 Davis DP, Serrano JA, Vilke GM, et al. (2006). The predictive value of field versus arrival Glasgow Coma Scale score and TRISS calculations in moderate-to-severe traumatic brain injury. J Trauma.
58 Eken C, Kartal M, Bacanli A, et al. (2009). Comparison of the Full Outline of UnResponsiveness score coma scale and the Glasgow Coma Scale in an emergency setting population. Eur J Emerg Med.
59 Haukoos JS, Gill MR, Rabon RE, et al. (2007). Validation of the Simplified Motor Score for the prediction of brain injury outcomes after trauma. Ann Emerg Med.
60 Holmes JF, Palchak MJ, MacFarlane T, et al. (2005). Performance of the pediatric Glasgow Coma Scale in children with blunt head trauma. Acad Emerg Med.
61 Kupas DF, Melnychuk EM, Young AJ. (2016). Glasgow Coma Scale Motor Component ("patient does not follow commands") performs similarly to Total Glasgow Coma Scale in predicting severe injury in trauma patients. Ann Emerg Med.
62 Van de Voorde P, Sabbe M, Rizopoulos D, et al. (2008). Assessing the level of consciousness in children: a plea for the Glasgow coma motor subscore. Resuscitation.
63 Nesiama JA, Pirallo RG, Lerner EB, et al. (2012). Does a prehospital Glasgow Coma Scale score predict pediatric outcomes?. Pediatr Emerg Care.
64 Johnson DL, Krishnamurthy S. (1996). Send severely head-injured children to a pediatric trauma center. Pediatr Neurosurg.
65 Caterino JM, Raubenolt A, Cudnik MT. (2011). Modification of Glasgow Coma Scale criteria for injured elders. Emerg Med J.
66 Leijdesdorff HA, van Dijck JT, Krijnen P, et al. (2014). Injury pattern, hospital triage, and mortality of 1250 patients with severe traumatic brain injury caused by road traffic accidents. J Neurotrauma.
67 Reisner A, Chen X, Kumar K, et al. (2014). Prehospital heart rate and blood pressure increase the positive predictive value of the Glasgow Coma Scale for high-mortality traumatic brain injury. J Neurotrauma.
68 Majdan M, Steyerberg EW, Nieboer D, et al. (2015). Glasgow Coma Scale motor score and pupillary reaction to predict six-month mortality in patients with traumatic brain injury: comparison of field and admission assessment. J Neurotrauma.
69 Takahashi C, Okudera H, Origasa H, et al. (2011). A simple and useful coma scale for patients with neurologic emergencies: the emergency coma scale. Am J Emerg Med.
70 Bledsoe BE, Casey MJ, Feldman J, et al. (2015). Glasgow Coma Scale scoring is often inaccurate. Prehospital Disaster Med.
71 Feldman A, Hart KW, Lindsell CJ, et al. (2015). Randomized controlled trial of a scoring aid to improve Glasgow Coma Scale scoring by emergency medical services providers. Ann Emergency Med.
72 Heim C, Schoettker P, Gilliard N, et al. (2009). Knowledge of Glasgow Coma Scale by air-rescue physicians. Scand J Trauma Resusc Emerg Med.
73 Kerby JD, MacLennan PA, Burton JN, et al. (2007). Agreement between prehospital and emergency department Glasgow Coma Scores. J Trauma.
74 Lane PL, Baez AA, Brabson T, et al. (2002). Effectiveness of a Glasgow Coma Scale instructional video for EMS providers. Prehospital Disaster Med.
75 Arbabi S, Jurkovich GJ, Wahl WL, et al. (2004). A comparison of prehospital and hospital data in trauma patients. J Trauma.
76 Dinh MM, Oliver M, Bein K, et al. (2013). Level of agreement between prehospital and emergency department vital signs in trauma patients. Emerg Med Australas.
77 Rundhaug NP, Moen KG, Skandsen T, et al. (2015). Moderate and severe traumatic brain injury: effect of blood alcohol concentration on Glasgow Coma Scale score and relation to computed tomography findings. J Neurosurg.
78 Lange RT, Iverson GL, Brubacher JR, et al. (2010). Effect of blood alcohol level on Glasgow Coma Scale scores following traumatic brain injury. Brain Injury.
79 Stuke L, Diaz-Arrastia R, Gentilello LM, et al. (2007). Effect of alcohol on Glasgow Coma Scale in head-injured patients. Ann Surg.
80 American College of Surgeons. (2015). National Trauma Data Bank 2015: Annual Report.
81 Newgard CD, Zive D, Holmes JF, et al. (2011). A multisite assessment of the American College of Surgeons Committee on Trauma field triage decision scheme for identifying seriously injured children and adults. J Am Coll Surg.
82 Gill M, Martens K, Lynch EL, et al. (2007). Interrater reliability of 3 simplified neurologic scales applied to adults presenting to the emergency department with altered levels of consciousness. Ann Emerg Med.
83 Kirkham FJ, Newton CR, Whitehouse W. (2008). Paediatric coma scales. Dev Med Child Neurol.
84 Yokobori S, Bullock MR. (2013). Pathbiology of primary traumatic brain injury (Chapter 11). Zasler ND, Katz DI, RD Z, editors. Brain Injury Medicine: Principles and Practice.