# Methods

The methods for this Comparative Effectiveness Review (CER) follow the guidance in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^33^

## Scope Development

The initial Key Questions were provided by the National Highway Traffic Safety Administration (NHTSA). The Key Questions were further developed and the final protocol developed with additional input from NHTSA and a Technical Expert Panel (TEP) convened for this report. The TEP consisted of eight experts in adult and pediatric field triage, emergency medical services (EMS), trauma surgery, general surgery, critical care, and emergency medicine. TEP members disclosed financial and other conflicts of interest prior to participation. The AHRQ Task Order Officer and the investigators reviewed the disclosures and determined that the TEP members had no conflicts of interest that precluded participation.

The final protocol was posted on the AHRQ Web site on February 28, 2016 at: http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=2187. The protocol was also registered in the PROSPERO international database of prospectively registered systematic reviews (registration number CRD42016035944).^34^

## Literature Search Strategy

A research librarian conducted searches in the Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, CINAHL^®^, PsycINFO^®^, HaPI (Health and Psychosocial Instruments), and Ovid MEDLINE^®^ (January, 1995 to June, 2016), limiting to English-language abstracts. Search strategies are provided in Appendix A. We restricted search start dates to January, 1995 to improve applicability to current U.S. trauma care; only five states had fully implemented trauma systems in the early 1990s.^35^ In addition, the first studies to compare the predictive utility of the motor component of the Glasgow Coma Scale (mGCS) with the total score of the Glasgow Coma Scale (tGCS) were published in 1998 and 2003.^18,19^

We also hand-searched the reference lists of relevant studies and searched for unpublished studies in ClinicalTrials.gov.

## Study Selection

We developed criteria for inclusion and exclusion of studies based on the Key Questions and the populations, interventions, comparators, outcomes, timing, types of studies, and setting (PICOTS) approach, in accordance with the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^33^ Inclusion and exclusion criteria are summarized below and described in more detail in Appendix B. Abstracts were reviewed by two investigators, and all citations deemed potentially appropriate for inclusion by at least one of the reviewers were retrieved for full-text review. Two investigators then independently reviewed all full-text articles for final inclusion. Investigators did not review, assess, or screen papers that they authored. Inclusion was restricted to English-language articles. Discrepancies were resolved by discussion and consensus, with a third investigator if necessary.

A list of the included studies appears in Appendix C; a list of excluded studies and primary reasons for exclusion can be found in Appendix D.

### Population and Conditions of Interest

For all Key Questions we included studies of children and adults with known or suspected trauma. Although the population of interest was patients with blunt trauma, we included studies of general trauma patients. We excluded studies of individuals without trauma, studies that focused on nonblunt trauma patients, or studies of patients with and without trauma in which the proportion without trauma was more than 10 percent and results were not reported separately for patients with trauma.

### Interventions, Comparisons, and Study Designs

We focused on studies of the total Glasgow Coma Scale (tGCS), the motor component of the Glasgow Coma Scale (mGCS), and the Simplified Motor Score (SMS). For studies evaluating measures of diagnostic accuracy (sensitivity, specificity, predictive values), we focused on studies that used standard cutoff scores of 13 or less on the tGCS, 5 or less on the mGCS, or 1 or 0 on the SMS to indicate people who require high-level trauma care,^4,36^ but also included studies that used alternative cutoffs or modifications of the tGCS and mGCS. We excluded studies that evaluated the utility of mGCS or tGCS in combination with other predictors in a multi-item risk assessment or triage instrument.

For all Key Questions, we included cohort studies and randomized controlled trials (RCTs) that directly compared the tGCS with the mGCS or SMS. For Key Question 4 (reliability and ease of use), we also included cross-sectional studies and studies that assessed one of these scales. For Key Question 1a (predictive utility) we included studies that assessed one of these scales if they addressed one of the subpopulations specified in the Key Questions (e.g., children, intoxicated, intubated, traumatic brain injury [TBI] patients) not addressed well in the head-to-head studies. We restricted Key Questions 2 and 3 to head-to-head studies because given the large number of other factors that impact these outcomes, it is not possible to isolate the effects of risk assessment scales on over- or under-triage or clinical outcomes from single-arm studies..

### Outcomes

For Key Question 1, we included measures of predictive utility for in-hospital mortality, morbidity, markers of severe injury (e.g., Abbreviated Injury Scale [AIS] score of ≥4 or Injury Severity Score [ISS] of ≥16^37^), or utilization indicators of severe injury^38^ (e.g., receipt of intracranial monitoring within 48 hours of admission, receipt of a neurosurgical intervention within 12 hours of admission, or receipt of early intubation [in the field or immediately upon arrival to the emergency department (ED)]), as measured by diagnostic accuracy, adjusted risk estimates, measures of discrimination (e.g., the c-index), measures of calibration (e.g., the Hosmer-Lemeshow test), or risk reclassification rates.^26^

For Key Question 2, we included studies that reported the proportion of patients who were over- or under-triaged (e.g., the proportion of patients transported to a higher or lower than appropriate level of care according to a standardized definition for trauma center need^26^ or the proportion transferred to a higher or lower level of care).

For Key Question 3, we included studies that reported clinical outcomes, including mortality (prior to hospital arrival, in the ED, or after hospital admission), measures of morbidity, including cognitive impairment and medical complications related to trauma, and quality of life, including functional capacity at discharge or followup.

For Key Question 4, we included outcomes that assessed reliability (e.g., interrater and intrarater kappa) or ease of use (e.g., time to complete, measures of missing data, user-reported satisfaction).

### Timing and Setting

For all Key Questions we included prospective and retrospective studies in which the tGCS, mGCS, or SMS were administered soon after injury (conducted in the field/out-of-hospital setting by Emergency Medical Services personnel) or immediately upon arrival to the ED, or that were based on trauma registry data collected in the field or in the ED. We excluded studies in which the Glasgow Coma Scale (GCS) was administered after more than 4 hours in the ED or hospital or when it was administered after hospital admission. We also excluded studies conducted in the developing world, which may be less applicable to U.S. trauma care settings.

## Data Abstraction and Data Management

A single investigator abstracted information on study design, year, geographic location, patient characteristics (i.e., demographics, type and mechanism of trauma, type of injury, tGCS scores, severity of injury, intoxication status, systolic blood pressure, intubation or receipt of medication in the field), the proportion of patients who experienced outcomes, which triage instrument was used, timing of triage assessment, cutoff scores used (for studies that evaluated sensitivity and specificity), the training and experience of the person administering the GCS, assessment setting (in the field or upon ED presentation), and results relevant to each Key Question. All data abstractions were reviewed by a second investigator for accuracy and discrepancies were resolved through discussion and consensus.

## Assessment of Methodological Risk of Bias of Individual Studies

We assessed risk of bias of included studies using predefined criteria. Our methods for assessing risk of bias are based on the recommendations in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^33^ For Key Question 1 (predictive utility), we applied the Quality in Prognostic Studies (QUIPS) tool for prognostic studies.^39^ The QUIPS tool includes domains on study participation, study attrition, prognostic factor measurement, outcomes measurement, study confounding, and statistical analysis and reporting. For Key Question 4 (reliability and ease of use), we assessed risk of bias using criteria adapted from the Quality Assessment of Diagnostic Accuracy Studies (QUADAS).^40^ This includes criteria about patient selection, whether raters were blinded to other ratings, how the scores from different assessments were compared and the situation and timing of measurement. Two investigators independently assessed risk of bias for each study. Differences were resolved by discussion; we used a third rater to resolve discrepancies if needed (Appendix E). No study met inclusion criteria for Key Questions 2 or 3.

Studies rated “low” risk of bias have the least risk of bias, and their results are generally considered more valid than studies with the same study design but more flaws. For example, low risk of bias studies on predictive utility select all or a random subset of patients who meet predefined criteria, report low attrition, perform the risk assessment scale in all patients, measure outcomes accurately, and in all patients, assess and measure important confounders, use appropriate statistical methods, and avoid selective reporting of results.

Studies rated “moderate” risk of bias are susceptible to some bias, though not enough to necessarily invalidate the results. These studies may not meet all the criteria for “low” risk of bias rating, but do not have flaws likely to cause major bias. The study may also be missing information, making it difficult to assess limitations and potential problems. The moderate risk of bias category is broad, and studies with this rating vary in their strengths and weaknesses. The results of some moderate risk of bias studies are likely to be valid, while others may be only possibly valid.

Studies rated “high” risk of bias have significant flaws that may invalidate the results. They may have a serious or “fatal” flaw or set of flaws in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting. The results of these studies are at least as likely to reflect flaws in the study design as the true difference between the compared interventions. We did not exclude studies rated high risk of bias a priori, but performed sensitivity analyses in which such studies were excluded.

## Assessing Research Applicability

Applicability is defined as the extent to which the effects observed in published studies are likely to reflect the expected results when a specific intervention is applied to the population of interest under “real-world” conditions.^33^ It is an indicator of the extent to which research included in a review might be useful for informing clinical decisions in specific situations. Because applicability depends on the perspective of the user of the review, we did not assign a rating for applicability (such as “high” or “low”). Rather, factors important for understanding the applicability of studies were recorded, such as population characteristics (age, type of trauma, intoxication status), setting (United States vs. other country, out-of-hospital vs. ED assessment), and type and level of training of people administering the GCS were recorded and assessed in subgroup and sensitivity analyses.^41^ We also recorded the funding source for studies. Most studies on predictive utility reported the area under the receiver operating characteristic curve (AUROC), a measure of discrimination.^42,43^ The AUROC value represents the probability that a patient who experiences an outcome will have a higher score on the triage scale than a person who does not experience the outcome. We did not identify published recommendations on how to interpret the magnitude of differences in the AUROC value. Therefore, we defined a small difference in the AUROC a priori as a difference of less than 0.05, moderate as a difference of 0.05 to 0.10, and large as a difference of greater than 0.10. For measuring interrater or intrarater reliability, we defined a meaningful difference in kappa values as 0.20 or greater.^44^

## Data Synthesis and Rating the Body of Evidence

We performed random effects meta-analysis to calculate pooled differences on the AUROC from head-to-head studies^45^ of the tGCS versus the mGCS or SMS using the DerSimonian-Laird random effects model with Stata/IC 13.1 (StataCorp LP, College Station, TX). We measured statistical heterogeneity using the I^2^ statistic. The DerSimonian-Laird estimator can result in confidence intervals (CIs) for the pooled estimate that are too narrow, particularly when statistical heterogeneity is present.^46^ We also performed analyses using the Profile Likelihood method. The AUROC value represents the probability that a patient who experiences an outcome will have a higher score on the triage scale than a person who does not experience the outcome. We defined a small difference in the AUROC a priori as a difference of less than 0.05, moderate as a difference of 0.05 to 0.10, and large as a difference of greater than 0.10. Therefore, we repeated analyses using an alternative random effects model, the profile likelihood method, which may provide more accurate confidence limits. Most studies reported estimated AUROCs with associated 95 percent CIs. When a study only reported the point estimate of AUROC without providing a 95 percent CI or a standard error, we imputed the standard error using the average standard error from other studies in the same meta-analysis. In all studies, the mGCS or SMS scores were derived from the tGCS and applied to the same patient population (i.e., the risk assessment scales were not applied independently). To account for this nonindependence, we assumed a correlation of 0.5 when comparing the tGCS with the mGCS, or SMS in the primary analysis. Two studies^47,48^ reported data that allowed us to calculate the correlations between the AUROC for the tGCS and the mGCS or SMS, which ranged from 0.5 to 0.9 depending on the outcome and comparison. Therefore, 0.5 is a conservative assumption for the correlation. A high correlation is expected given mGCS or SMS scores are a subset of tGCS applied on the same population. Sensitivity analyses were conducted assuming correlations of 0.3 and 0.8; results were similar and not separately reported.

Primary analyses were stratified by the age group evaluated in the study (children vs. adults or mixed populations). We performed additional sensitivity and subgroup analyses based on timing of GCS assessment (field vs. ED), study dates (all data collected in 2006 or later or some or all data collected prior to 2006), country (United States vs. other), and risk of bias rating. For the primary analysis, we included studies conducted using the National Trauma Data Bank (NTDB). In 2012, 805 hospitals submitted data to the NTDB.^49^ Because populations evaluated in single trauma centers or systems could be included (in part or in full) in the NTDB, we performed a sensitivity analysis in which NTDB studies were excluded. For the primary analysis, we included multiple studies from the same trauma center or system unless there was clearly complete overlap in the populations assessed. In sensitivity analyses, we restricted analyses to studies from each trauma center that utilized field GCS scores; if multiple studies utilized field GCS scores we utilized the study that evaluated more recent data.

## Grading the Body of Evidence for Each Key Question

For all comparisons and outcomes we assessed the strength of evidence (Appendix F) using the approach described in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews^33^ and Methods Guide for Medical Test Reviews,^50^ based on the overall risk of bias (graded low, moderate, or high); the consistency of results across studies (graded consistent, inconsistent, or unable to determine when only one study was available); the directness of the evidence linking the intervention and health outcomes (graded direct or indirect); the precision of the estimate of effect, based on the number and size of studies and CIs for the estimates (graded precise or imprecise); and reporting bias (suspected or undetected). Assessments of reporting bias were based on whether studies defined and reported primary outcomes and whether we identified relevant unpublished studies.

Based on our assessments on the domains described above, we graded the strength of evidence for each Key Question using the four key categories recommended in the Methods Guide for Comparative Effectiveness and Effectiveness Reviews.^33^ Randomized controlled trials and cohort studies on predictive utility started as “high” strength of evidence and were graded down based on the presence of deficiencies in the domains. Because observational studies on predictive utility started as high, we did not consider factors for upgrading such as dose-response relationship, magnitude of effects, or impact of plausible confounders. A high grade indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect. A “moderate” grade indicates moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate. A “low” grade indicates low confidence that the evidence reflects the true effect and further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. An “insufficient” grade indicates evidence either is unavailable or is too limited to permit any conclusion, due to the availability of only high risk of bias studies, extreme inconsistency, or extreme imprecision.

See Appendix G for the strength of evidence table.

## External Review

Peer reviewers with expertise in trauma and triage provided written comments on the draft report. The AHRQ Task Order Officer and an Evidence-based Practice Center Associate Editor also provided comments and editorial review. The draft report was posted on the AHRQ Web site for 4 weeks for public comment from June 29, 2016 to July 26, 2016. A disposition of comments report with authors' responses to the peer and public review comments will be posted after publication of the final CER on the public Web site.