# Introduction

## Background

### Nature and Burden of Trauma

Unintentional injuries are the leading cause of death among people in the United States ages 1 to 44, and the third leading cause among people ages 45 to 64.^1^ Among all age groups, motor vehicle crashes are the first or second leading cause of unintentional injury death.^2^ In 2011, there were approximately 40,000,000 emergency department (ED) visits for injuries; of these approximately 2.5 million were due to trauma complications and unspecified injuries.^3^ Approximately 18 percent of patients seen in the ED for an injury were transported by emergency medical services (EMS) personnel.^4^ Traumatic brain injury (TBI) is an important subset of trauma. Among an estimated 1.7 million annual cases of TBI, there are 52,000 deaths and 275,000 hospitalizations.^5^ TBI is a contributing factor to about one-third of injury-related deaths in the United States. From 2001 to 2010, the rate of TBI-related ED visits increased from 421 to 716 per 100,000,^6^ though the rate of deaths declined from 18.5 to 17.1 per 100,000 people.

### Field Triage of Patients With Trauma

Field triage by EMS is a critical aspect of trauma systems, as it helps to identify potentially seriously injured patients and inform transport decisions.^7-9^ Appropriate decisions regarding transport are crucial because management of severely injured patients in a Level I or a Level II trauma center has been shown to be associated with improved clinical outcomes.^9^ On the other hand, unnecessarily triaging patients to high-level trauma care may represent an inefficient use of staff and resources.^10^

EMS personnel must rapidly triage individuals who have undergone trauma in challenging environments. Therefore, EMS personnel must have assessment tools that are easy to use, reliable, and accurate. A key component of field triage for patients with suspected serious injury is level of consciousness assessment.^4^ The Glasgow Coma Scale (GCS)^11,12^ is an instrument widely used for assessment of consciousness at the site of injury, in EDs, and in hospitals, as well as to monitor progress or deterioration during treatment.^13^ The GCS consists of three items (components): eye (scored 1 to 4), verbal (scored 1 to 5), and motor (scored 1 to 6). Scores on each of these components are added to obtain the total Glasgow Coma Scale (tGCS) score, ranging from 3 to 15. Lower scores on the tGCS indicate lower levels of consciousness, generally correlating with more severe injury associated with poorer prognosis and requiring more intensive care. For patients with TBI, scores of 3 to 8 are generally considered to denote severe head injury, 9 to 12 moderate, and 13 to 15 mild.^14^ The 2011 field triage guidelines from the Centers for Disease Control and Prevention (CDC) National Expert Panel recommend transporting patients with tGCS scores of 13 or less to facilities providing the highest level of trauma care.^4^

In some circumstances (e.g., trauma victims who are intoxicated, intubated, or whose other injuries influence response) it may not be possible to accurately assess the verbal and eye components of the tGCS. In these cases, assessments may be primarily based on the motor component of the Glasgow Coma Scale (mGCS) alone.^11,15-17^ In addition, the mGCS has been proposed for assessment of trauma patients even when the tGCS can be obtained, since only one item is assessed, potentially increasing ease of use in the field.^18^ mGCS scores of 5 or less are considered an indication of patients with severe injury.^18,19^ The Simplified Motor Score (SMS) has been proposed as a streamlined alternative to the mGCS; it is assessed on a three-point scale (scored 0 to 2, with a score of 0 corresponding to 1 to 4 on the mGCS, 1 corresponding to 5 on the mGCS, and 2 corresponding to 6 on the mGCS).^20^

Decisions regarding the use of the tGCS versus more simplified versions of the tGCS should be based on their relative performance. The ultimate goal of selecting one risk prediction instrument over another is to improve clinical outcomes (e.g., mortality). However, information on clinical outcomes is often lacking and decisions about their use must often be based on how they perform on intermediate outcomes. Intermediate outcomes include measures of over- or under-triage (i.e., the degree to which patients are unnecessarily transported to a Level I or II trauma center [over-triage] or not transported to a Level I or II trauma center when needed [under-triage]) or predictive utility, as assessed using measures of discrimination (ability of an instrument to distinguish people with the disease from those without), calibration (how well predicted risk correlates with actual risk), standard measures of diagnostic accuracy (e.g., sensitivity, specificity, and predictive values), or adjusted risk estimates (e.g., odds ratio, relative risk, hazards ratio).^21^ Other factors that could inform selection of field triage risk assessment instruments include intra- and interrater reliability and ease of use (e.g., time to administer the instrument and amount of missing data).^12,22,23^

A number of factors could impact the performance of field assessment instruments. These include variability in patient populations (e.g., type of trauma, demographic characteristics, presence and severity of intoxication, and medical comorbidities), level of training and certification of administering personnel (e.g., emergency medical responder, emergency medical technician [EMT], advanced EMT, paramedic, physician, or nurse^24^), receipt of field interventions (e.g., medications, intubation), setting (e.g., country, urban vs. rural), or timing of assessment relative to injury occurrence. Evidence about field triage instruments frequently relies on extrapolation from studies conducted in EDs, as this environment is more controlled and easier to study.^25^ However, the performance of the tGCS and mGCS may be different when administered soon after injury by EMS personnel in the field as opposed to later by ED personnel, after destination decisions have already been made and patients have been stabilized with initial interventions.

During the development of field triage guidelines and algorithms by the CDC National Expert Panel in 2011,^4^ use of the mGCS was considered a way to potentially simplify field triage. However, the mGCS was not adopted due in part to lack of evidence about the comparative accuracy and reliability of the mGCS relative to the tGCS. More evidence is now available on the mGCS.

## Rationale for Review

The purpose of this report is to systematically review the currently available evidence on the comparative predictive utility, reliability, and ease of use of the tGCS and mGCS in field assessment of trauma (with or without TBI), as well as comparative effects on clinical outcomes and early critical resource use. This review provides a synthesis of currently available evidence and gaps in evidence that may be helpful to inform clinical practice and guideline development for field triage of trauma by EMS personnel. The review is the first step of a larger Federal effort to systematically examine the evidence base about out-of-hospital triage decisionmaking and transport of trauma patients, and inform future updates to the Field Triage Guidelines.^4^

### Scope of Review and Key Questions

The report addresses the following Key Questions:

Key Question 1. In patients with known or suspected trauma, what is the predictive utility of the tGCS compared with the mGCS for predicting in-hospital mortality, morbidity, Injury Severity Score of 16 or greater, head Abbreviated Injury Scale (AIS) score greater than 2 (AIS-2005) or greater than 3 (AIS-1998), presence of intracranial hemorrhage, and utilization indicators of severe injury (e.g., receipt of intracranial monitoring within 48 hours of admission, receipt of a neurosurgical intervention within 12 hours of admission, or early intubation [in the field or immediately upon presentation to the ED])?

Key Question 1a How does predictive utility vary according to patient age or other patient characteristics (e.g., TBI vs. unspecified or other trauma, systolic blood pressure, level of intoxication, type of trauma, intubation or receipt of medications in the field), the training and background of the person administering the instrument, and the timing/setting of assessment (i.e., in the field vs. upon presentation to the ED or urban vs. rural location)?

Key Question 2. In patients with known or suspected trauma, what are the comparative effects of the tGCS compared with the mGCS on over- and under-triage (e.g., proportion of patients in whom initial EMS transport is to a higher or lower than appropriate level of care, or proportion transferred to a lower or higher level of care)?

Key Question 2a How do effects on over- and under-triage vary according to patient age or other patient characteristics (e.g., TBI vs. unspecified or other trauma, systolic blood pressure, level of intoxication, type of trauma, intubation or receipt of medication in the field), the training and background of the person administering the instrument, and the timing/setting of assessment (i.e., in the field vs. upon presentation to the ED or urban vs. rural location)?

Key Question 3. In patients with known or suspected trauma, what is the comparative effectiveness of the tGCS compared with the mGCS on clinical outcomes (e.g., in-hospital mortality, morbidity, quality of life)?

Key Question 3a How do effects on clinical outcomes vary according to patient age or other patient characteristics (e.g., TBI vs. unspecified or other trauma, systolic blood pressure, level of intoxication, type of trauma, intubation or receipt of medication in the field), the training and background of the person administering the instrument, and the timing/setting of assessment (i.e., in the field vs. upon presentation to the ED or urban vs. rural location)?

Key Question 4. In patients with known or suspected trauma, what is the comparative reliability (e.g., interrater and intrarater kappa) and ease of use (e.g., time to complete, amount of missing data, user reported satisfaction) of the tGCS compared with the mGCS score?

Key Question 4a How do comparative reliability and ease of use vary according to patient age or other patient characteristics (e.g., TBI vs. unspecified or other trauma, systolic blood pressure, level of intoxication, type of trauma, intubation or receipt of medication in the field), the training and background of the person administering the instrument, and the timing/setting of assessment (i.e., in the field vs. upon presentation to the ED or urban vs. rural location)?

The research questions used to guide this review were initially developed by the National Highway Traffic Safety Administration and revised with input from a Technical Expert Panel. The Key Questions focus on predictive utility, over- and under-triage, clinical outcomes of the tGCS versus the mGCS or SMS, as well as reliability and ease of use.

Key Question 1 addresses the predictive utility of the tGCS compared with the mGCS for predicting clinical outcomes (in-hospital mortality, morbidity). In addition, Key Question 1 addresses the predictive utility of the tGCS versus the mGCS on markers of injury severity, as indicated by the injury severity score and utilization markers for severe injury (receipt of neurosurgical interventions such as early surgery or intracranial pressure monitoring) and as a marker of need for tertiary trauma care. Key Question 1 does not assess the utility of the tGCS compared with the mGCS for predicting the likelihood that a patient receives tertiary trauma care, since the GCS is one of the factors used to determine who is transported to tertiary trauma care. Therefore, receipt of tertiary trauma care does not represent a marker of injury severity independent from the GCS score.

Key Question 2 addresses the impact of the tGCS compared with the mGCS on clinical decisionmaking based on rates of over- and under-triage, an intermediate outcome, as determined by the proportion of patients transported to a higher or lower than appropriate level of care based on a standardized definition for trauma center need.^26^ We also considered rates of transfer to higher or lower levels of care as a potential marker of over- or under-triage. Measuring over- and under-triage is a challenge because factors other than findings on field triage assessment scales, including other patient characteristics (e.g., mechanism of injury, hemodynamic instability, respiratory distress, comorbidities), geographic proximity, and availability of resources, also impact triage decisions.^10^ Interpretation of transfer rates is particularly challenging since minimally injured over-triaged patients may be discharged directly home rather than transferred to lower-level care. In addition, some over-triage may be acceptable in order to prevent under-triage,^7,27^ which may be more likely to result in adverse clinical outcomes,^28,29^ while over-triage may primarily represent inefficient use of resources and increased costs^30,31^ without necessarily adversely impacting clinical outcomes.^32^ Therefore, results for Key Question 2 must be interpreted with caution.

Key Question 3 addresses the impact of the tGCS compared with the mCGS on clinical outcomes. Key Question 4 addresses the reliability and ease of use of the tGCS compared with the mGCS. For each Key Question, a subquestion addresses potential modifiers of treatment effect, including patient age or other patient characteristics, the training and background of the person administering the instrument, and the timing/setting of assessment. The analytic framework (Figure 1) used to guide this review is shown below.

The analytic framework shows the target populations, interventions, and health outcomes examined, with numbers corresponding to the Key Questions.

Figure 1 Analytic framework

EMS=emergency medical services; KQ=Key Question; mGCS=motor Glasgow Coma Scale; tGCS=total Glasgow Coma Scale; vs.=versus

* Based on tGCS score of ≤13 or mGCS score of ≤5

The figure is an analytic framework that depicts the pathway patients with known or suspected blunt trauma, assessed by emergency medical services (EMS) personnel, take in reaching intermediate outcomes and final health outcomes related to screening with the total Glasgow Coma Scale (tGCS) versus the motor (mGCS) score only. The figure shows that patients with known or suspected blunt trauma, assessed by EMS personnel and screened with tGCS or mGCS will be divided into moderate or severe injury (based on tGCS score of 13 or less and mGCS score of 5 or less) or mild injury. The figure then shows the link between these patients and intermediate outcomes, such as over-or under-triage and utilization indicators of severe injury. The figure shows an overarching question about screening with tGCS versus mGCS to final health outcomes, such as mortality, morbidity, and quality of life. The figure also shows a link between screening with the tGCS vs. mGCS and reliability and ease of use of these measures.