# Peer Reviewers

Prior to publication of the final evidence report, the EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Blair Bigham, M.D., M.Sc., ACP
  Paramedic and EMS Researcher
  Physician and Scientist
  McMaster University
  Hamilton, ON, Canada
- David Cone, M.D.
  Professor of Emergency Medicine
  Chief, Section of EMS
  Director, EMS Fellowship
  Yale University School of Medicine
  New Haven, CT
- Mark Gestring, M.D., FACS
  Medical Director, Kessler Trauma Center
  Associate Professor of Surgery, Emergency Medicine and Pediatrics
  University of Rochester School of Medicine
  Rochester, NY
- Ritu Sahni, M.D.
  Physician, Emergency Medicine
  Providence Hospital
  Portland, OR