# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Eileen Metzger Bulger, M.D., FACS^*^
  Professor
  Department of Surgery
  University of Washington
  Chief of Trauma, Harborview Medical Care
  Seattle, WA
- Steven M. Green, M.D., FACEP^*^
  Professor
  Emergency Medicine and Pediatrics
  Loma Linda University Medical Center and Children's Hospital
  Loma Linda, CA
- Julie C. Leonard, M.D., M.P.H.^*^
  Associate Professor
  Department of Pediatrics
  Division of Emergency Medicine
  The Ohio State University College of Medicine
  Columbus, OH
- E. Brooke Lerner, Ph.D.^*^
  Professor With Tenure
  Departments of Emergency Medicine and Pediatrics
  Medical College of Wisconsin
  Milwaukee, WI
- N. Clay Mann, Ph.D., M.S.^*^
  Professor
  Department of Pediatrics
  University of Utah School of Medicine
  Salt Lake City, UT
- P. Daniel Patterson, Ph.D., M.P.H., M.S., N.R.P.^*^
  Adjunct Assistant Professor
  Department of Emergency Medicine
  University of Pittsburgh
  Pittsburgh, PA
- Scott M. Sasser, M.D.^*^
  Professor
  Department of Emergency Medicine
  University of South Carolina School of Medicine
  Columbia, SC
- David W. Wright, M.D., FACEP
  Associate Professor With Tenure
  Department of Emergency Medicine
  Emory University
  Atlanta, GA

* Provided input on Draft Report