# Acknowledgments

The authors acknowledge Andrew Hamilton, M.L.S., M.S., for conducting literature searches, and Leah Williams, B.S., for providing editorial assistance. Both are located at the Oregon Health & Science University.