# Discussion

## Key Findings and Strength of Evidence

The Key Findings of this review, with overall strength of evidence ratings, are summarized in Appendix G. Details about ratings for individual strength of evidence domains are shown in Appendix F.

Based on head-to-head studies, we found that the total Glasgow Coma Scale (tGCS) is associated with slightly better predictive utility than the motor component of the Glasgow Coma Scale (mGCS), based on the area under the receiver operating characteristic curve (AUROC), a measure of discrimination. The tGCS is better able than the mGCS to discriminate patients with trauma who undergo neurosurgical intervention, have severe brain injury (traumatic brain injury [TBI]), or undergo emergency intubation from patients who do not experience these outcomes. Evidence on discrimination for identifying patients with severe injury (based on the Injury Severity Score [ISS] or criteria for trauma center need) was limited, but reported similar findings.^53,55^ Although the differences in discrimination are statistically significant, their clinical significance is uncertain. The difference in the AUROC on each of these outcomes ranged from 0.03 to 0.05, or “small” based on our prespecified thresholds for interpreting differences in the AUROC. The tGCS was also better than the mGCS at discriminating trauma patients who died during hospitalization from those who survived hospitalization, but the difference in the AUROC was even smaller (0.01) than for nonmortality outcomes. Findings for the tGCS versus the Simplified Motor Scale (SMS) were similar to findings for the tGCS versus the mGCS for nonmortality outcomes, though the SMS performed slightly worse than the mGCS for in-hospital mortality. This means that for every 100 trauma patients, the tGCS is able to correctly discriminate 1 to 3 more cases of in-hospital mortality from cases without in-hospital mortality than the mGCS or the SMS. Across scales, discrimination was generally higher for in-hospital mortality (0.84 to 0.89) than for nonmortality outcomes (0.71 to 0.85). Although studies varied in how they defined neurosurgical interventions, severe brain injury, and emergency intubation, findings were generally similar across definitions for these outcomes. One study^60^ in children found a greater difference in the AUROC (0.121, 95% confidence interval [CI] 0.068 to 0.174) compared with four studies conducted in mixed populations of adults and children (0.046, 95% CI 0.038 to 0.054), using a broader definition for severe brain injury that included interventions in addition to computed tomography (CT) imaging findings. However, the test for an interaction effect was not statistically significant (p=0.07).

Findings for discrimination were generally robust in sensitivity and subgroup analyses based on factors such as the age group analyzed (children vs. mixed populations of children and adults), study year (data collected in 2006 or later or included data collected before 2006), assessment setting (out-of-hospital vs. emergency department [ED]), or risk of bias ratings. However, sensitivity and subgroup analyses were limited by small numbers of studies, particularly for nonmortality outcomes. In addition, no study that evaluated mixed populations of adults and children reported results stratified by age group and no study that evaluated mixed populations of trauma patients reported results stratified by type of trauma. Therefore, findings on effects of age on predictive utility are based on cross-study comparisons. For age and type of trauma, few studies specifically evaluated children or patients with TBI, though those available reported findings similar to studies that evaluated mixed populations of adults and children or mixed trauma populations. None of the head-to-head studies specifically evaluated older patients or reported findings in this subgroup, though one study found lower accuracy of the tGCS using the standard cutoff score of 13 or less in adults older than 70 years of age versus those younger.^65^ Another study found that among patients younger than 18 years of age, differences between the tGCS versus the mGCS on discrimination for in-hospital mortality and other outcomes were similar for children 0 to 3 years of age, in whom the verbal component is difficult to assess, and the whole cohort.^51^ There were also no clear differences when studies were stratified according to out-of-hospital versus ED assessment of the Glasgow Coma Scale (GCS). In addition, studies that evaluated out-of-hospital versus ED scores in the same trauma center reported similar discriminative performance. There was insufficient evidence to determine how intubation status, intoxication status, receipt of field interventions, timing of GCS assessment, or level of training of people administering the GCS impacted predictive utility. No study evaluated how different GCS assessments performed in intoxicated patients or after intubation, or how performance varied according to receipt of out-of-hospital interventions. In the case of intoxication or intubation, the tGCS is often limited to the motor component due to the inability to accurately assess the verbal and eye domains. Studies on the effects of alcohol intoxication have shown somewhat mixed results, with some finding little effect on tGCS scores and others reporting lower tGCS scores in certain subgroups.^77-79^ No study evaluated effects of the type or level of training of GCS assessors on predictive utility.

Several studies on discrimination for in-hospital mortality utilized data from the National Trauma Data Bank (NTDB). Over 700 centers across the United States contribute to the NTDB.^80^ This could result in double counting of patients analyzed in studies based on single centers and overweighting of such patients, if that center contributes data to the NTDB and depending on whether the NTDB and single-center studies utilized data from the same time frame. There was insufficient information on the NTDB Web site to determine the extent to which trauma centers reported in single-center studies contributed to NTDB. However, excluding NTDB studies had little impact on our findings regarding in-hospital mortality, and estimates from the NTDB studies were very similar to the estimates from the studies conducted at single trauma centers. In cases where there were multiple studies from the same center (e.g., Loma Linda^20,36^ and Denver^48,51,59^) and potential overlap in patient populations, restricting the analysis to the most recent study based on out-of-hospital GCS data also had little impact on findings.

Few studies reported the comparative diagnostic accuracy (sensitivity, specificity) of the tGCS versus the mGCS, but findings were generally consistent with analyses based on the AUROC. Based on standard cutoffs for the tGCS (≤13), mGCS (≤5), and SMS (≤1), differences in sensitivity and specificity were small. The consistency of findings between measures of discrimination and diagnostic accuracy may be expected, given that discrimination is calculated from sensitivity and specificity over the range of test values. There was insufficient evidence to compare the performance of triage instruments based on other measures of predictive utility, such as calibration or adjusted risk estimates.

No study evaluated how using the tGCS versus the mGCS or SMS impacts the likelihood of over- or under-triage. Head-to-head studies of the tGCS versus the mGCS or SMS were not designed to assess effects on over- or under-triage because the mGCS and SMS were taken from the tGCS, with each patient only undergoing a single triage decision. Studies that evaluate the tGCS, mGCS, or SMS alone are not helpful for assessing effects on over- or under-triage because they cannot isolate the effects of the GCS assessment from the many other factors that impact triage decisions.^4,81^ Measures of diagnostic accuracy may provide some indirect indication of the potential degree of over- and under-triage, with 1-sensitivity indicating the proportion of patients who experience the outcome who would be missed (under-triage) and 1-specificity indicating the proportion of patients without the diagnosis (over-triage). However, this is an oversimplification that assumes that GCS assessments are the primary or sole driver of triage decisions, even though such decisions are known to be multifactorial and depend on other patient factors (e.g., presence of hypotension, type of injury) and other variables (e.g., proximity to a trauma center). Nonetheless, as noted above, limited evidence suggests no marked differences in predictive utility between the tGCS, mGCS, and SMS, including two studies that attempted to assess overall impact on over- or under-triage based on diagnostic accuracy estimates.^18,53^

No study evaluated how using the tGCS versus the mGCS or SMS impacts the likelihood of clinical outcomes such as in-hospital mortality, morbidity, or quality of life. As for over- or under-triage, understanding comparative effects on clinical outcomes requires head-to-head studies in which trauma patients who are assessed using different GCS scales are followed over time, in order to assess effects of the GCS scales versus other factors that impact clinical outcomes.

Evidence on interrater reliability and ease of use was limited. For assessment of patients with trauma, there was insufficient evidence to determine comparative interrater reliability of the tGCS, mGCS, and SMS, as there was only one head-to-head study with methodological limitations and imprecise estimates.^60^ Other studies found the mGCS associated with higher interrater reliability than the tGCS, but were excluded either because they did not report results separately for trauma patients^20,36^ or because they focused on interrater reliability of the GCS among hospitalized patients. Studies that addressed ease of use were limited to those that evaluated whether the measures were scored correctly when applied to video or written patient scenarios, compared with a reference standard (usually expert assessment). Three studies found that the percentage of correct scores was higher for the mGCS than the tGCS,^70-72^ though the difference was statistically significant in only one study.^70^ Limited evidence suggests that errors are more frequent when assessing patient scenarios, indicating moderate injury severity (tGCS scores of 9-13).^70,71,74^ For both scales, use of a scoring aid or training appears to improve the proportion of correct scores. No study evaluated other measures of ease of use, such as time to complete the assessment or assessor satisfaction.

One study found that agreement between field and ED scores was similar for the tGCS and mGCS.^73^ Although differences between field and ED scores were noted for both scales, the study also found that blood pressure readings changed. Therefore, some differences between field and ED scores may accurately reflect changing status of the patient due to receipt of out-of-hospital interventions and evolving clinical status, rather than true lack of agreement.

## Findings in Relationship to What Is Already Known

A prior Centers for Disease Control and Prevention (CDC) guideline found limited evidence on the predictive utility of the tGCS versus the mGCS.^4^ Our review included a number of studies that were published after the CDC guideline and provides more robust findings, particularly since some studies evaluated very large samples, enabling precise estimates. Our findings on predictive utility are consistent with a prior systematic review comparing the tGCS versus the SMS that also found that discrimination was similar for these scales.^15^ Like the CDC guideline, we found insufficient evidence to determine effects on over- or under-triage, or on clinical outcomes. Our finding that the interrater reliability of the tGCS and the mGCS are similar was based on very limited evidence in trauma patients; studies that included nontrauma patients have found the tGCS to be associated with lower interrater reliability.^23,82^

## Applicability

Our findings on predictive utility of different GCS scales appear to have broad applicability to field triage in the United States, as they are primarily based on large studies conducted in U.S. trauma settings in mixed populations of adults and children with various types of trauma. We also restricted study inclusion to studies published in 1995 or later, with most studies utilizing data collected through the last 5 to 10 years, suggesting high applicability to use in the context of current trauma systems.

Nonetheless, we identified a number of factors that can impact applicability. Despite the broad applicability of the evidence, its applicability to specific patient populations (e.g., specific type of trauma, age, presence and severity of intoxication, presence of medical comorbidities, and presence of other injuries) is less certain. For example, a modified version of the tGCS is utilized in young children^83^ and the GCS was originally developed for assessment of TBI,^11,12^ not trauma injuries or conditions associated with impaired consciousness in general. Limited evidence from across-study comparisons suggests similar results in children versus mixed populations of adults plus children and in patients with TBI versus mixed trauma populations. Within the subgroup of patients with TBI, the nature and prognosis of a TBI sustained from an impact injury (blunt force which may or may not involve fracture or intracranial lesion) may be different from that of a TBI sustained from an acceleration/deceleration injury^84^ (diffuse injury resulting from contrecoup forces), and TBI often occurs in conjunction with other injuries. However, no study evaluated how the type of TBI injury or co-occurring injuries impacts performance of GCS scales. No study evaluated how predictive utility varied according to the level or training of field personnel (e.g., emergency medical responder, emergency medical technician [EMT], advanced EMT, paramedic, physician, or nurse^24^). In fact, no study that used out-of-hospital scores reported the training of the people administering the GCS. Another factor that could impact applicability is that the performance of the tGCS and mGCS may be different when administered soon after injury (in the field) as opposed to later (after field stabilization and destination decisions have been made or patients have arrived in the ED). A number of studies on predictive utility were conducted in ED settings, which are more controlled and easier to study than field settings,^25^ but may be of limited applicability to field settings. However, we found that predictive utility was similar in studies that utilized out-of-hospital versus ED GCS scores. We also found no clear differences in estimates of predictive utility when we restricted analyses to studies conducted in U.S. settings or to more recent (2006 or later) studies, which may be more applicable to current U.S. practice.

The differences between the tGCS and the mGCS or SMS in mean AUROC ranged from 0.01 to 0.05. This indicates that the ability of the scales to distinguish patients who experience an outcome from those who do not based on a higher score is 1 percent to 5 percent higher with the tGCS than with the more abbreviated scales. These differences were statistically significant, in part due to the large sample sizes evaluated in the studies. Although we classified such differences as “small,” based on a priori thresholds, such thresholds are by nature somewhat arbitrary. The importance of “small” differences in discrimination depend in part on the seriousness of the outcome evaluated, the degree to which triage and other treatment decisions are based on the field triage scale, and the degree to which such actions impact clinical outcomes.

Studies on ease of use focused on the proportion of correct scores using video or written scenarios, as opposed to assessment of actual patients/situations. While some studies limited the time allowed for the assessment and utilized scenarios indicating a spectrum of injury intensity, the applicability of such studies to actual field conditions is uncertain. In addition, there was insufficient evidence to determine the effects of incorrect scoring on triage decisions (e.g., whether the incorrect score would result in a change from being above the threshold for transport to a high-level trauma center to below, or vice versa).

## Implications for Clinical and Policy Decisionmaking

Our review has implications for clinical and policy decisionmaking. Because we found no evidence on effects on clinical outcomes or risk of over- or under-triage, decisions regarding the selection of field assessment scales for trauma must rely on comparative predictive utility. Therefore, decisions regarding implementation of simplified GCS scales for field triage must consider the potential trade-offs between predictive utility and ease of use. Although the tGCS appears to have slightly greater discrimination than the mGCS or SMS for in-hospital mortality, severe brain injury, and markers of severe injury such as receipt of neurosurgical interventions or emergency intubation, differences were relatively small and of uncertain clinical significance. It is also possible that some of the differences in predictive utility could be reduced because field triage personnel also use other factors to inform triage decisions. Limited evidence suggests that the mGCS may be easier to score correctly than the tGCS, which may offset its slightly lower predictive utility.^17,71,72^

Similar results for the mGCS and the SMS might be expected because the SMS utilizes the same information as the mGCS, with the only difference being that for the SMS, patients with low scores on the mGCS (0 to 4) are collapsed into a single category. Therefore, any differences in predictive utility between the SMS and mGCS are likely to be primarily related to ease of use and reliability. Therefore, studies in which the mGCS and SMS scores are derived from the same assessment are inadequate for evaluating comparative performance; rather, studies that independently apply the SMS and mGCS are needed.

Evidence on how factors related to patients, assessors, and settings impacts predictive utility is limited. However, even if such differences exist, there may be advantages to having a single scale that can be applied across trauma scenarios, instead of requiring field assessors to select from among different scales for particular situations, even if the predictive utility of the single scale is slightly lower in certain situations.

Although evidence on comparative interrater reliability was very limited, scales with poor interrater reliability would also be expected to be associated with low predictive utility, which depends in part on the reliability of assessments. As differences in predictive utility were small, differences in interrater reliability are unlikely to be a major factor driving clinical and policy decisions regarding selection of field assessment scales. For all field assessment scales, training and use of scoring aids is likely to improve reliability and accuracy of scoring.

## Limitations of the Review Process

Our review process had some limitations. Because of anticipated heterogeneity due to differences in patient populations, outcomes, assessment settings, and other factors, we used the random effects DerSimonian-Laird model to pool data. Statistical heterogeneity was moderate or high in some analyses. The DerSimonian-Laird estimator can result in confidence intervals that are too narrow when statistical heterogeneity is present.^46^ Therefore, we also performed analyses using an alternative random effects model, the profile likelihood method, to evaluate whether findings were sensitive to the statistical model used. Results were similar using the profile likelihood method. Even when statistical heterogeneity was high, estimates for differences in AUROC across studies were generally quite similar, with statistical heterogeneity largely related to the presence of large sample sizes and very precise estimates. For example, for the analysis of tGCS versus mGCS for in-hospital mortality, the I^2^ value was 85 percent, but differences in the AUROC ranged from 0.01 to 0.07 and all favored the tGCS (pooled estimate 0.016, 95% CI 0.009 to 0.022).

Another limitation is that we had to impute CIs for some studies included in the pooled analyses. However, findings were similar when we used alternative imputation methods. Also, no head-to-head study performed the tGCS and mGCS or SMS separately. Rather, the mGCS and SMS were retrospectively determined for each patient from the tGCS. Therefore, the tGCS and mGCS or SMS were not performed independently, and it is uncertain how findings on the other GCS components may have impacted scoring on the motor component. Because data to estimate the correlation between tGCS and mGCS scores were limited, we assumed moderate correlation. Findings were similar in sensitivity analyses that utilized alternative correlation assumptions.

Most studies on predictive accuracy focused on differences in discrimination based on the AUROC, with only a few studies reporting sensitivity and specificity of the tGCS, mGCS, or SMS using standard thresholds. Analyses based on the AUROC tend to favor measures based on scales with more input points, which “smooth” the curve and could explain some of the superior discrimination observed with the tGCS (3 to 15 scale) over more abbreviated scales. Studies that reported sensitivity and specificity based on standard cutoffs reported small differences between the tGCS and the mGCS.

No study compared effects of the tGCS versus the mGCS or the SMS on risk of over- or under-triage, as measured by differences in the rate of inappropriate transport decisions as defined using standardized criteria for need for high level trauma center care. In addition, no study evaluated rates of transfer to a higher or lower level of care, which may be a marker for over- or under-triage. Should such studies have been available, their interpretation would have been a challenge because factors other than the severity of trauma, such as the clinical course, geographic proximity, and availability of resources, may impact transfer decisions. In addition, minimally injured over-triaged patients may be discharged directly home rather than transferred to lower level care.

Most studies on predictive utility had methodological limitations, including failure to report attrition, missing data, and unclear methods for measuring outcomes. However, restricting analyses to low risk of bias studies had little impact on findings. In addition, studies that reported low missing GCS data reported results similar to those with high or unclear missing data. Many of the studies on reliability and ease of use of the tGCS and mGCS scales had major flaws, as reflected by insufficient and low strength of evidence ratings.

We restricted analyses to English-language studies, which could result in language bias. However, we identified no foreign-language study that appeared to meet inclusion criteria, and our focus was on studies conducted in U.S. trauma settings, which are unlikely to be published in languages other than English. We were limited in our ability to assess publication bias, given the relatively small number of studies. Although we searched for relevant studies on ClinicalTrials.gov, this database focuses on clinical trials. We did not identify any ongoing studies on predictive utility of the GCS, which are unlikely to be registered in this database, or relevant clinical trials.

A number of studies were based on the large NTDB, which incorporates data from over 700 trauma centers across the United States, with very large sample samples. We could not reliably determine the degree to which studies that analyzed data from single centers analyzed populations with overlap with the NTDB studies. We performed sensitivity analyses in which NTDB studies were excluded, which had little impact on findings. Similarly, in situations where there was more than one study from a single trauma center with potential overlap, we found that results were similar when we focused on the most recent study from each center that used out-of-hospital GCS scores.

## Gaps in the Evidence Base

The most important gap in the evidence base was the lack of evidence on effects of using different GCS scales on risk of over- or under-triage or on clinical outcomes. Although there were a fair number of head-to-head studies for predictive utility, including studies with large samples, the studies mostly evaluated mixed populations of adults and children with various types of trauma. Evidence to determine how predictive utility differs in subgroups defined by patient characteristics such as type of trauma (including presence and type of TBI), degree of intoxication, intubation status, and receipt of cointerventions was limited. There was also insufficient evidence to determine how the type or level of training of field personnel impacts predictive utility. A number of analyses and subgroup analyses were based on small numbers of studies, and should be interpreted with caution. We also identified little evidence on measures of predictive utility other than discrimination (e.g., diagnostic accuracy, calibration, adjusted risk estimates, and risk reclassification rates).

The literature on interrater reliability and ease of use was very limited. There was only one head-to-head study of interrater reliability in trauma patients, and it had methodological limitations and imprecise estimates.^60^ Studies on ease of use focused on scoring of written or video patient scenarios and did not address factors such as the time needed to complete the assessment or assessor satisfaction.

## Future Research Needs

We identified several important future research needs. Head-to-head observational or randomized studies that assess one set of patients with the tGCS and another set with the SMS or mGCS are needed to understand effects on clinical outcomes as well as risk of over- or under-triage. Alternatively, studies that utilize the tGCS and simplified scales in the same patients could assess potential effects on over- or under-triage when the field assessment scales are incorporated into field assessment guidelines. However, such studies would represent less direct evidence, since they would not be based on actual differences in triage decisions. For over- and under-triage, studies should utilize standardized, validated measures to determine the appropriateness of transport and triage decisions. For predictive utility, prospective studies that independently assess patients using the tGCS and the mGCS or SMS would be useful for confirming the findings of the currently available retrospective studies, in which the mGCS or SMS were not independently assessed. Studies are needed to better understand the predictive utility in important subpopulations, including children, older patients, patients with specific types of trauma, and patients who have received field interventions prior to assessment. For patients who are intoxicated or intubated, studies that measure how frequently the tGCS reverts to the mGCS due to the inability to assess the other GCS components would be helpful. Studies that evaluate how the predictive utility of the tGCS compares with the mGCS or SMS according to the level or type of training of assessing personnel in the field are also needed. Studies that assess measures of predictive utility other than discrimination (e.g., calibration, adjusted risk estimates, diagnostic accuracy, risk reclassification) would be useful for providing more complete information on predictive utility. Finally, head-to-head studies on interrater reliability and ease of use (including time to use, assessor comfort or satisfaction, and impacts of educational efforts) when the scales are administered to trauma patients in field settings are needed to better understand how these factors may impact decisions regarding selection of field assessment scales.

## Conclusions

The tGCS is associated with slightly greater discrimination than the mGCS or SMS for in-hospital mortality, receipt of neurosurgical interventions, severe brain injury, overall injury severity, and emergency intubation, with differences in the AUROC ranging from 0.01 to 0.05. The clinical significance of small differences in discrimination is likely to be small, and could be offset by factors such as convenience and ease of use. Research is needed to understand how use of the tGCS versus the mGCS or SMS impacts clinical outcomes and risk of over- or under-triage.