# Appendix L Quality Assessments of Studies of Reliability and Ease of Use

Table L-1 Quality assessments of reliability and ease of use studies

Author, year | Assessment Type | Patient Selection | Index Tests | Reference Standard | Flow and Timing | Risk of Bias
Arbabi, et al., 2004 | Field vs. ED agreement | High | Unclear | Moderate | Unclear | High
Blesdsoe, et al., 2015 | Ease of use | Low | Not applicable | Moderate | Low | Low
Dinh, et al., 2013 | Field vs. ED agreement | Low | Unclear | Moderate | Low | Moderate
Feldman, et al., 2015 | Ease of use | Low | Not applicable | Moderate | Low | Low
Heim, et al., 2009 | Ease of use | High | Not applicable | Unclear | Moderate | High
Holmes, et al., 2005 | Interrater reliability | High | Unclear | Moderate | Unclear | High
Kerby, et al., 2007 | Field vs. ED agreement | High | High | Moderate | Unclear | High
Lane, et al., 2002 | Ease of use | High | Not applicable | Unclear | Low | Moderate
Nesiama, et al., 2012 | Field vs. ED agreement | Moderate | High | Low | Moderate | Moderate
Takahashi, et al., 2011 | Interrater reliability | High | Moderate | Moderate | Low | Moderate

Please see Appendix C. Included Studies for full study references.

ED= emergency department; vs.= versus