# Appendix K Quality Assessment of Studies of Predictive Utility

Table K-1 Quality assessments of predictive utility studies

Author, Year | Study Participation | Study Attrition | Prognostic Factor Measurement | Outcome Measurement | Study Confounding | Statistical Analysis and Reporting | Risk of Bias
Acker, et al., 2014 | Low | Unclear, attrition not reported. | Low, 110/2,341 excluded due to GCS missing data. | Unclear, details on methods for measuring outcomes not reported. | Not applicable, study reports discrimination only. | Not applicable, study reports discrimination only. | Moderate
Al-Salamah, et al., 2004 | Low | Low, 20/815 excluded due to missing data from trauma registry. | Low, 20/815 excluded due to missing data from trauma registry. | Unclear, details on methods for measuring outcomes not reported. | Not applicable, study reports diagnostic accuracy and discrimination only. | Not applicable, study reports diagnostic accuracy and discrimination only. | Moderate
Beskind, et al. , 2014 | Low | Low | Moderate, approximately 25% missing GCS data, multiple imputation performed. | Low | Not applicable, study reports discrimination only. | Not applicable, study reports discrimination only. | Low
Brown, et al., 2014 | Low | Unclear, attrition not reported. | Moderate, approximately 40% missing GCS data, multiple imputation performed. | Low (NTDB) | Low | Low | Moderate
Caterino and Raubenolt, 2012 | Low | Unclear, attrition not reported. | High, approximately 25% missing GCS data, excluded from analysis. | Low | Not applicable, study reports diagnostic accuracy and discrimination only. | Not applicable, study reports diagnostic accuracy and discrimination only. | Moderate
Caterino, Raubenolt, and Cudnik, 2011 | Unclear | Unclear | Unclear | Low | Low | Low | Moderate
Cicero and Cross, 2013 | Low | Low, between 2% and 4% missing data for outcomes. | High, approximately 51% excluded due to missing GCS data. | Low (NTDB) | Not applicable, study reports discrimination only. | Not applicable, study reports discrimination only. | Moderate
Corrigan, et al., 2014 | Low | Unclear, approximately 50% missing data (either GCS or outcomes). | Unclear, approximately 50% missing data (either GCS or outcomes). | Low (NTDB) | Not applicable, study reports discrimination only. | Not applicable, study reports discrimination only. | Moderate
Davis, et al., 2006 | Low | Moderate, 30% missing outcome data. | Unclear. Missing GCS data not reported. | Unclear, details on methods for measuring outcomes not reported. | Not applicable, study report discrimination only. | Not applicable, study reports discrimination only. | Moderate
Eken, et al., 2009 | Low | Low, <2% missing data for outcomes. | Unclear, missing GCS data not reported. | Unclear, details on methods for measuring outcomes not reported. | Not applicable, study reports discrimination only. | Not applicable, study reports discrimination only. | Moderate
Gill, et al., 2005 | Low | Low, <1% missing data for outcomes. | Low, 216/8,648 excluded due to missing data. | Low | Not applicable, study reports discrimination only. | Not applicable, study reports discrimination only. | Low
Gill, et al., 2006 | Low | Low, <1% missing data for outcomes. | Low, 1415/8,648 excluded due to missing GCS data. | Low | Not applicable, study reports discrimination only. | Not applicable, study reports discrimination only. | Low
Haukoos, et al., 2007 | Low | Low | Low, 583/21,753 excluded due to missing GCS data. | Low | Not applicable, study reports discrimination only. | Not applicable, study reports discrimination only. | Low
Healey, et al., 2003 | Low | Unclear, attrition not reported. | Low, 1,926 missing GCS scores for 204,181 patients, excluded from analysis. | Low (NTDB) | Not applicable, study reports discrimination only. | Not applicable, study reports discrimination only. | Low
Holmes, et al., 2005 | Low | Unclear, attrition not reported. | Unclear, missing GCS data not reported. | Low | Not applicable, study reports discrimination only. | Not applicable, study reports discrimination only. | Moderate
Johnson and Krishnamurthy, 1996 | Low | Unclear, attrition not reported. | Unclear, missing GCS data not reported. | Low | Not applicable, study reports diagnostic accuracy only. | Not applicable, study reports diagnostic accuracy only. | Moderate
Kupas, et al., 2016 | Low | Moderate, 33% missing ICU admission, other outcomes <3% missing data | Unclear, missing GCS data not reported. | Low | Not applicable, study reports diagnostic accuracy and discrimination only. | Not applicable, study reports diagnostic accuracy and discrimination only. | Moderate
Leijdesdorff, et al., 2014 | Moderate | Low | Moderate | Low | Low | Moderate | Moderate
Majdan, et al., 2015 | Low | Unclear | Unclear | Unclear, not reported if data was validated. | Low | Low | Moderate
Nesiama, et al., 2012 | Unclear | Low | Moderate | Low | Unclear | Moderate | Moderate
Reisner, et al., 2014 | Unclear | Unclear | Unclear | Unclear | Low | Low | Moderate
Ross, et al., 1998 | Low | Unclear, attrition not reported. | High, 56% missing GCS data, excluded from analysis. | Unclear, details on methods for measuring outcomes not reported. | Not applicable, study reports diagnostic accuracy only. | Not applicable, study reports diagnostic accuracy only. | Moderate
Thompson, et al. , 2011 | Low | Low, <1% missing data for outcomes. | Unclear, missing GCS data not reported. | Low | Not applicable, study reports diagnostic accuracy and discrimination only. | Not applicable, study reports diagnostic accuracy and discrimination only. | Moderate
Van de Voorde, et al., 2008 | Low | Unclear, attrition not reported. | Unclear, missing GCS data not reported. | Unclear, details on methods for measuring outcomes not reported. | Not applicable, study reports diagnostic accuracy only. | Not applicable, stud reports diagnostic accuracy only. | Moderate

Please see Appendix C. Included Studies for full study references.

GCS= Glasgow Coma Scale; NTDB= National trauma Data Bank