# Appendix J Studies of Reliability and Ease of Use

Table J-1 Characteristics of reliability and ease of use studies