# Appendix I Indirect Studies for Predictive Utility

Table I-1 Characteristics of indirect predictive utility studies