# Appendix H Head-to-Head Studies for Predictive Utility

Table H-1 Characteristics of head-to-head studies