# Appendix G Strength of Evidence Table

Table G-1 Strength of evidence