# Appendix E Risk of Bias Criteria

## Risk Prediction Studies^1^

### Criteria

- The study sample adequately represents the population of interest
- The study data available (i.e., participants not lost to followup) adequately represent the study sample
- The prognostic factor is measured in a similar way for all participants
- The outcome of interest is measured in a similar way for all participants
- Important potential confounding factors are appropriately accounted for
- The observed effect of the prognostic factor on the outcome is very likely to be distorted by another factor related to prognostic factor and outcome

### Definitions of risk of bias based on above criteria

Low: | The least risk of bias, and results are generally considered more valid than studies with the same study design but more flaws. Low risk of bias studies include clear descriptions of the population, setting, interventions, and comparison groups clear reporting of missing data; apply appropriate means to prevent; and appropriately measure outcomes.
Moderate: | Susceptible to some bias, though not enough to necessarily invalidate the results. These studies may not meet all the criteria for “low” risk of bias rating, but do not have flaws likely to cause major bias. The study may also be missing information, making it difficult to assess limitations and potential problems.
High: | Have significant flaws that may invalidate the results. They may have a serious or “fatal” flaw or set of flaws in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting. The results of these studies will be least as likely to reflect flaws in the study design as the true difference between the compared interventions.

## Reliability and Ease of Use Studies^2^

### Criteria

#### Patient Selection

For assessments of interrater reliability and field versus emergency department (ED) agreement

- Are raters rating the same patient?
- Are raters rating all patients in a set time frame or a random selection of patients?
- Are no or only small numbers of patients dropped as two ratings were not possible?

For assessments of ease of use

- Is a rationale given for the sample size/number of dual ratings?
- Is scoring/assessment done on more than one patient and a range of patient situations?

#### Index Test(s)

For assessments of interrater reliability and field versus ED agreement

- Are raters blinded to the other rater?

Not applicable for assessments of ease of use

#### Reference Standard

For assessments of interrater reliability and field versus ED agreement

- Is the approach to scoring agreement explained and appropriate (e.g. Kappa, % agreement, exact match or in same category)?

For assessments of ease of use

- Is how the correct answer was determined clearly described?
- Was the correct answer verified with more than one expert?

#### Flow and Timing

For assessments of interrater reliability

- Are ratings of the patient being made within a reasonable amount of time or time within which it could be expected that score did not change (at the same time or within minutes)?

For assessments of field versus ED agreement

- Is ED rating immediately upon arrival?

For assessments of ease of use

- Is it clear if the field rating is before or after resuscitation?
- Was the scoring done in a way to simulate field or ED (e.g., limited amount of time, video preferable to written etc.)?

### Definition of risk of bias based on above criteria

Low: | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles missing data in a reasonable manner; includes a large number (>100), broad-spectrum of patients with and without disease; study attempts to enroll a random or consecutive sample of patients who meet inclusion criteria screening cutoffs pre-stated.
Moderate: | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients (i.e. applicable to most screening settings).
High: | Has important limitation such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size of very narrow selected spectrum of patients.

## References

1 Hayden JA, van der Windt DA, Cartwright JL, et al. (2013). Assessing bias in studies of prognostic factors. Ann Intern Med.
2 Whiting PF, Rutjes AW, Westwood ME, et al. (2011). QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med.