# Appendix D List of Excluded Studies

Table D-1 Exclusion code key

Codes | Reason
2 | Background or discussion paper only, no data for evidence
3 | Wrong population (nonhuman population, patients without known or suspected trauma, transferred patients)
4 | Wrong intervention (measure other than the GCS, composite variables [GCS + something], guidelines/triage criteria)
5 | Wrong outcome (costs, prevalence rates, doesn't report outcome of interest)
6 | Wrong study design (case reports, case series, cross-sectional studies [KQ 1-3, only], and modeling studies)
7 | Wrong publication type (opinion, editorial, letter, guideline document not used for background)
8 | Wrong comparison (other measures, non head-to-head comparison studies for main KQs, direct vs. transferred patients)
9 | Wrong setting (in hospital or ICU not ED, not immediately upon arrival in ED [>4 hours], studies conducted in the developing world, unable to determine where/when GCS administered)
10 | Not English language but may be relevant
11 | Review not meeting our requirements (i.e. wrong study designs included, no risk of bias assessment, only one library searched, nonsystematic review, more updated review available)
12 | Studies outside of search dates (published before January 1995)
13 | Indirect studies (tGCS, mGCS, or SMS only) for KQ 1 that do not address one of the subgroups of interest (e.g., pediatrics, elderly, intoxicated individuals, intubated patients, TBI vs. other trauma patients, etc.)

ED=emergency department; GCS=Glasgow Coma Scale; ICU=intensive care unit; KQ=key question; mGCS=motor only compotent of GCS; SMS=Simplified Motor Score; TBI=traumatic brain injury; tGCS=total score of GCS; vs.=versus

Abdel-Aty M, Keller J. (2005). Exploring the overall and specific crash severity levels at signalized intersections. Accid Anal Prev.
Abu-Kishk I, Vaiman M, Rosenfeld-Yehoshua N, et al. (2010). Riding a bicycle: do we need more than a helmet?. Pediatr Int.
Ackerman R, Waldron RL. (2006). Difficulty breathing: agreement of paramedic and emergency physician diagnoses. Prehosp Emerg Care.
Acosta CD, Delgado MK, Gisondi MA, et al. (2010). Characteristics of pediatric trauma transfers to a level I trauma center: implications for developing a regionalized pediatric trauma system in California. Acad Emerg Med.
Adams SD, Cotton BA, Wade CE, et al. (2013). Do not resuscitate status, not age, affects outcomes after injury: An evaluation of 15,227 consecutive trauma patients. J Trauma Acute Care Surg.
Ahmed N, Bialowas C, Kuo YH, et al. (2009). Impact of preinjury anticoagulation in patients with traumatic brain injury. South Med J.
Ahun E, Koksal O, Sigirli D, et al. (2014). Value of the Glasgow Coma Scale, age, and arterial blood pressure score for predicting the mortality of major trauma patients presenting to the emergency department. Ulus Travma Acil Cerrahi Derg: TJTES.
Alderson P, Roberts I. (2009). Corticosteroids for acute traumatic brain injury. Cochrane Database Syst Rev.
Alkhoury F, Courtney J. (2011). Outcomes after severe head injury: a National Trauma Data Bank-based comparison of level I and level II trauma centers. Am Surg.
Allen CJ, Hannay W, Murray C, et al. (2015). Causes of death differ between elderly and adult falls. J Trauma Acute Care Surg.
Allen S, Zhu S, Sauter C, et al. (2006). A comprehensive statewide analysis of seatbelt non-use with injury and hospital admissions: new data, old problem. Acad Emerg Med.
Anders JF, Adelgais K, Hoyle JD, et al. (2014). Comparison of Outcomes for Children With Cervical Spine Injury Based on Destination Hospital From Scene of Injury Comparación de los Resultados en Niños con Lesión de Columna Cervical según el Hospital de Destino desde el. Acad Emerg Med.
Andriessen TM, Horn J, Franschman G, et al. (2011). Epidemiology, severity classification, and outcome of moderate and severe traumatic brain injury: a prospective multicenter study. J Neurotrauma.
Arbabi S, Jurkovich GJ, Wahl WL, et al. (2005). Effect of patient load on trauma outcomes in a level I trauma center. J Trauma.
Arbogast KB, Ghati Y, Menon RA, et al. (2005). Field investigation of child restraints in side impact crashes. Traffic Inj Prev.
Arslan ED, Solakoglu AG, Komut E, et al. (2014). Assessment of maxillofacial trauma in emergency department. World J Emerg Surg.
Arthur M, Newgard CD, Mullins RJ, et al. (2009). A population-based survival assessment of categorizing level III and IV rural hospitals as trauma centers. J Rural Health.
Asikainen I, Kaste M, Sarna S. (1996). Patients with traumatic brain injury referred to a rehabilitation and re-employment programme: social and professional outcome for 508 Finnish patients 5 or more years after injury. Brain Inj.
Asikainen I, Nybo T, Muller K, et al. (1999). Speed performance and long-term functional and vocational outcome in a group of young patients with moderate or severe traumatic brain injury. Eur J Neurol.
Atabaki SM. (2006). Prehospital evaluation and management of traumatic brain injury in children. Clin Pediatr Emerg Med.
Atabaki SM. (2007). Pediatric head injury. Pediatrics in Review.
Atanasijevic TC, Popovic VM, Nikolic SD. (2009). Characteristics of chest injury in falls from heights. Leg Med (Tokyo).
Athanasiou T, Krasopoulos G, Nambiar P, et al. (2004). Emergency thoracotomy in the pre-hospital setting: a procedure requiring clarification. Eur J Cardiothorac Surg.
Atkin C, Freedman I, Rosenfeld JV, et al. (2005). The evolution of an integrated state trauma system in Victoria, Australia. Injury.
Aubuchon M, Hemmes B, Poeze M, et al. (2013). Prehospital care in patients with severe traumatic brain injury: does the level of prehospital care influence mortality?. Eur J Trauma Emerg Surg.
Babu MA, Nahed BV, Demoya MA, et al. (2011). Is trauma transfer influenced by factors other than medical need? An examination of insurance status and transfer in patients with mild head injury. Neurosurgery.
Baethmann A, Chapuis D, Wirth A. (1999). System analysis of patient management during the pre- and early clinical phase in severe head injury. Acta Neurochir Suppl.
Baethmann A, Lehr D, Wirth A. (1998). Prospective analysis of patient management in severe head injury. Acta Neurochir Suppl.
Baethmann A, Wirth A, Schlesinger-Raab A. (2002). Prospective system analysis of the pre- and early hospital care in severe head injury in Bavaria at a population-based level. Eur Surg Res.
Baez AA, Giraldez EM, De Pena JM. (2007). Precision and reliability of the Glasgow Coma Scale score among a cohort of Latin American prehospital emergency care providers. Prehospital Disaster Med.
Baker M. (2008). Reviewing the application of the Glasgow Coma Scale: does it have interrater reliability?. BJNN.
Balestreri M, Czosnyka M, Chatfield DA, et al. (2004). Predictive value of Glasgow Coma Scale after brain trauma: change in trend over the past ten years. J Neurol Neurosurg Psychiatry.
Ball CG, Dente CJ, Kirkpatrick AW, et al. (2010). Occult pneumothoraces in patients with penetrating trauma: does mechanism matter?. Can J Surg.
Ball CG, Rozycki GS, Feliciano DV. (2009). Upper extremity amputations after motor vehicle rollovers. J Trauma.
Balogh Z, King KL, Mackay P, et al. (2007). The epidemiology of pelvic ring fractures: a population-based study. J Trauma.
Banerjee S, Barry MJ, Paterson JM. (2009). Paediatric pelvic fractures: 10 years experience in a trauma centre. Injury.
Bankole S, Asuncion A, Ross S, et al. (2011). First responder performance in pediatric trauma: a comparison with an adult cohort. Pediatr Crit Care Med.
Bansal V, Conroy C, Lee J, et al. (2009). Is bigger better? The effect of obesity on pelvic fractures after side impact motor vehicle crashes. J Trauma.
Baratloo A, Shokravi M, Safari S, et al. (2016). Predictive value of Glasgow Coma Score and Full Outline of UnResponsiveness score on the outcome of multiple trauma patients. Arch Iran Med.
Barker MD, Whyte J, Pretz CR, et al. (2014). Application and clinical utility of the Glasgow Coma Scale over time: a study employing the NIDRR traumatic brain injury model systems database. J Head Trauma Rehabil.
Barnett AS, Wang NE, Sahni R, et al. (2013). Variation in prehospital use and uptake of the national field triage decision scheme. Prehosp Emerg Care.
Barraco RD, Chiu WC, Bard MR, et al. (2010). Practice management guidelines for the appropriate triage of the victim of trauma. Eastern Association for the Surgery of Trauma.
Barraco RD, Chiu WC, Clancy TV, et al. (2010). Practice management guidelines for the diagnosis and management of injury in the pregnant patient: the EAST Practice Management Guidelines Work Group. J Trauma.
Bastos R, Calhoon JH, Baisden CE. (2008). Flail chest and pulmonary contusion. Semin Thorac Cardiovasc Surg.
Batchinsky AI, Cancio LC, Salinas J, et al. (2007). Prehospital loss of R-to-R interval complexity is associated with mortality in trauma patients. J Trauma.
Batchinsky AI, Salinas J, Kuusela T, et al. (2009). Rapid prediction of trauma patient survival by analysis of heart rate complexity: impact of reducing data set size. Shock.
Batchinsky AI, Skinner JE, Necsoiu C, et al. (2010). New measures of heart-rate complexity: effect of chest trauma and hemorrhage. J Trauma.
Bazarian JJ, Eirich MA, Salhanick SD. (2003). The relationship between pre-hospital and emergency department Glasgow Coma Scale scores. Brain Injury.
Beca J, Cox PN, Taylor MJ, et al. (1995). Somatosensory evoked potentials for prediction of outcome in acute severe brain injury. J Pediatr.
Beekley AC, Sebesta JA, Blackbourne LH, et al. (2008). Prehospital tourniquet use in Operation Iraqi Freedom: effect on hemorrhage control and outcomes. J Trauma.
Behera C, Rautji R, Dogra TD. (2010). Fatal accidental fall from height in infants and children: a study from South Delhi. Med Sci Law.
Beilman GJ, Blondet JJ, Nelson TR, et al. (2009). Early hypothermia in severely injured trauma patients is a significant risk factor for multiple organ dysfunction syndrome but not mortality. Ann Surg.
Benner JP, Brauning G, Green M, et al. (2006). Disagreement between transport team and ED staff regarding the prehospital assessment of air medically evacuated scene patients. Air Med J.
Bennett TD, Kaufman R, Schiff M, et al. (2006). Crash analysis of lower extremity injuries in children restrained in forward-facing car seats during front and rear impacts. J Trauma.
Benzer A, Traweger C, Ofner D, et al. (1995). Statistical modelling in analysis of outcome after trauma Glasgow-coma-scale and Innsbruck-coma-scale. Anasthesiol Intensivmed Notfallmed Schmerzther.
Berbiglia L, Lopez PP, Bair L, et al. (2013). Patterns of early mortality after trauma in a neighborhood urban trauma center: can we improve outcomes?. Am Surg.
Bernier RA, Hillary FG. (2016). Trends in alcohol use during moderate and severe traumatic brain injury: 18 years of neurotrauma in Pennsylvania. Brain Inj.
Bernstein ML, Chung KC. (2007). Early management of the mangled upper extremity. Injury.
Berry C, Ley EJ, Margulies DR, et al. (2014). Prospective evaluation of posttraumatic vasospasm: determining its clinical significance after traumatic brain injury. Am Surg.
Bertrand S, Cuny S, Petit P, et al. (2008). Traumatic rupture of thoracic aorta in real-world motor vehicle crashes. Traffic Inj Prev.
Bidez MW, Cochran JE, King D, et al. (2007). Occupant dynamics in rollover crashes: influence of roof deformation and seat belt performance on probable spinal column injury. Ann Biomed Eng.
Biros MH, Heegaard W. (2001). Prehospital and resuscitative care of the head-injured patient. Curr Opin Crit Care.
Blakey CM, Biant LC, Birch R. (2009). Ischaemia and the pink, pulseless hand complicating supracondylar fractures of the humerus in childhood: long-term follow-up. J Bone Joint Surg Br.
Boatright DH, Byyny RL, Hopkins E, et al. (2013). Validation of rules to predict emergent surgical intervention in pediatric trauma patients. J Am Coll Surg.
Bochicchio GV, Lumpkins K, O'Connor J, et al. (2008). Blast injury in a civilian trauma setting is associated with a delay in diagnosis of traumatic brain injury. Am Surg.
Bolland K, Sooriyarachchi MR, Whitehead J. (1998). Sample size review in a head injury trial with ordered categorical responses. Stat Medicine.
Borman JB, Aharonson-Daniel L, Savitsky B, et al. (2006). Unilateral flail chest is seldom a lethal injury. Emerg Med J.
Bouillon B, Lefering R, Vorweg M, et al. (1997). Trauma score systems: cologne validation study. J Trauma.
Boyle MJ, Smith EC, Archer F. (2008). A review of patients who suddenly deteriorate in the presence of paramedics. BMC Emerg Med.
Boyle MJ, Smith EC, Archer F. (2008). Is mechanism of injury alone a useful predictor of major trauma?. Injury.
Boyle MJ, Smith EC, Archer FL. (2008). Trauma incidents attended by emergency medical services in Victoria, Australia. Prehosp Disaster Med.
Braakman R, Avezaat CJ, Maas AI, et al. (1977). Inter observer agreement in the assessment of the motor response of the Glasgow ‘coma’ scale. Clin Neurol Neurosurg.
Brain Trauma Foundation, The American Association of Neurological Surgeons. (2000). The Joint Section on Neurotrauma and Critical Care. Glasgow Coma Scale score. J Neurotrauma.
Branas CC, MacKenzie EJ, Williams JC, et al. (2005). Access to trauma centers in the United States. JAMA.
Brattström O, Granath F, Rossi P, et al. (2010). Early predictors of morbidity and mortality in trauma patients treated in the intensive care unit. Acta Anaesthesiol Scand.
Brewer ES, Reznikov B, Liberman RF, et al. (2011). Incidence and predictors of intracranial hemorrhage after minor head trauma in patients taking anticoagulant and antiplatelet medication. J Trauma.
Brown CV, Sowery L, Curry E, et al. (2012). Recombinant factor VIIa to correct coagulopathy in patients with traumatic brain injury presenting to outlying facilities before transfer to the regional trauma center. Am Surg.
Brown HL. (2009). Trauma in pregnancy. Obstet Gynecol.
Brown JB, Forsythe RM, Stassen NA, et al. (2012). The National Trauma Triage Protocol: can this tool predict which patients with trauma will benefit from helicopter transport?. J Trauma Acute Care Surg.
Brown JB, Stassen NA, Bankey PE, et al. (2010). Helicopters and the civilian trauma system: national utilization patterns demonstrate improved outcomes after traumatic injury. J Trauma.
Brown JB, Stassen NA, Bankey PE, et al. (2011). Mechanism of injury and special consideration criteria still matter: an evaluation of the National Trauma Triage Protocol. J Trauma.
Brown JB, Stassen NA, Cheng JD, et al. (2010). Trauma center designation correlates with functional independence after severe but not moderate traumatic brain injury. J Trauma.
Brown KV, Murray CK, Clasper JC. (2010). Infectious complications of combat-related mangled extremity injuries in the British military. J Trauma.
Brown KV, Ramasamy A, McLeod J, et al. (2009). Predicting the need for early amputation in ballistic mangled extremity injuries. J Trauma.
Brown LH, Hubble MW, Cone DC, et al. (2009). Paramedic determinations of medical necessity: a meta-analysis. Prehosp Emerg Care.
Bruijns SR, Guly HR, Bouamra O, et al. (2013). The value of the difference between ED and prehospital vital signs in predicting outcome in trauma. Emerg Med J.
Bruno MA, Ledoux D, Lambermont B, et al. (2011). Comparison of the Full Outline of UnResponsiveness and Glasgow Liege Scale/Glasgow Coma Scale in an intensive care unit population. Neurocritical care.
Bruns B, Gentilello L, Elliott A, et al. (2008). Prehospital hypotension redefined. J Trauma.
Bulger EM, Kaufman R, Mock C. (2008). Childhood crash injury patterns associated with restraint misuse: implications for field triage. Prehosp Disaster Med.
Bulger EM, May S, Brasel KJ, et al. (2010). Out-of-hospital hypertonic resuscitation following severe traumatic brain injury: a randomized controlled trial. JAMA.
Bulger EM, Nathens AB, Rivara FP, et al. (2002). Management of severe head injury: institutional variations in care and effect on outcome. Crit Care Med.
Bunn TL, Slavova S, Bernard AC. (2014). Work-related injuries in a state trauma registry: relationship between industry and drug screening. J Trauma Acute Care Surg.
Burd RS, Jang TS, Nair SS. (2007). Evaluation of the relationship between mechanism of injury and outcome in pediatric trauma. J Trauma.
Bush BA, Novack TA, Malec JF, et al. (2003). Validation of a model for evaluating outcome after traumatic brain injury. Arch Phys Med Rehabil.
Caille S, Deguise E, Feyz M, et al. (2000). Early prediction of neuropsychological deficits and global outcome during the acute phase of treatment following traumatic brain injury. Brain Cogn.
Callaway DW, Wolfe R. (2007). Geriatric trauma. Emerg Med Clin North Am.
Camilloni L, Farchi S, Giorgi Rossi P, et al. (2008). Mortality in elderly injured patients: the role of comorbidities. Int J Inj Contr Saf Promot.
Cancio LC, Batchinsky AI, Salinas J, et al. (2008). Heart-rate complexity for prediction of prehospital lifesaving interventions in trauma patients. J Trauma.
Cannada LK, Cooper C. (2005). The mangled extremity: limb salvage versus amputation. Curr Surg.
Cannon CM, Braxton CC, Kling-Smith M, et al. (2009). Utility of the shock index in predicting mortality in traumatically injured patients. J Trauma.
Carrick MM, Morrison CA, Alexis DJ, et al. (2009). Thoracoabdominal shotgun wounds: an evaluation of factors associated with the need for surgical intervention. Am J Surg.
Cassidy LD, Potoka DA, Adelson PD, et al. (2003). Development of a novel method to predict disability after head trauma in children. J Pediatr Surg.
Caterino JM, Valasek T, Werman HA. (2010). Identification of an age cutoff for increased mortality in patients with elderly trauma. Am J Emerg Med.
Caulfield EV. (2008). Prehospital ventilation of traumatic brain injured adult patients and early post injury neurological outcomes.
Celso B, Tepas J, Langland-Orban B, et al. (2006). A systematic review and meta-analysis comparing outcome of severely injured patients treated in trauma centers following the establishment of trauma systems. J Trauma.
Challen K, Walter D. (2010). Physiological scoring: an aid to emergency medical services transport decisions?. Prehosp Disaster Med.
Champion HR, Lombardo LV, Shair EK. (2009). The importance of vehicle rollover as a field triage criterion. J Trauma.
Chandler CL, Cummins B. (1995). Initial assessment and management of the severely head-injured patient. Br J Hosp Med.
Chandler WL. (2010). Procoagulant activity in trauma patients. Am J Clin Pathol.
Chang DC, Bass RR, Cornwell EE, et al. (2008). Undertriage of elderly trauma patients to state-designated trauma centers. Arch Surg.
Chang L-Y, Wang H-W. (2006). Analysis of traffic injury severity: an application of non-parametric classification tree techniques. Accid Anal Prev.
Cheddie S, Muckart DJ, Hardcastle TC, et al. (2011). Direct admission versus inter-hospital transfer to a level I trauma unit improves survival: an audit of the new Inkosi Albert Luthuli Central Hospital trauma unit. S Afr Med J.
Chen L, McKenna TM, Reisner AT, et al. (2008). Decision tool for the early diagnosis of trauma patient hypovolemia. J Biomed Inform.
Chen L, Piao Y, Zeng F, et al. (2001). Moderate hypothermia therapy for patients with severe head injury. Chin J Traumatol.
Chen L, Reisner AT, Gribok A, et al. (2009). Can we improve the clinical utility of respiratory rate as a monitored vital sign?. Shock.
Chen L, Reisner AT, Gribok A, et al. (2009). Exploration of prehospital vital sign trends for the prediction of trauma outcomes. Prehosp Emerg Care.
Chen L, Reisner AT, McKenna TM, et al. (2007). Diagnosis of hemorrhage in a prehospital trauma population using linear and nonlinear multiparameter analysis of vital signs. Conf Proc IEEE Eng Med Biol Soc.
Cherry RA, King TS, Carney DE, et al. (2007). Trauma team activation and the impact on mortality. J Trauma.
Cheung DS, Kharasch M. (1999). Evaluation of the patient with closed head trauma: an evidence based approach. Emerg Med Clin North Am.
Chi JH, Knudson MM, Vassar MJ, et al. (2006). Prehospital hypoxia affects outcome in patients with traumatic brain injury: a prospective multicenter study. J Trauma.
Chisholm KM, Harruff RC. (2010). Elderly deaths due to ground-level falls. Am J Forensic Med Pathol.
Chiu WC, Haan JM, Cushing BM, et al. (2001). Ligamentous injuries of the cervical spine in unreliable blunt trauma patients: incidence, evaluation, and outcome. J Trauma.
Christensen TL, Brandes SB. (2008). Urologic injuries sustained after free falls from hunting tree stands. South Med J.
Ciesla DJ, Pracht E, Tepas 3rd JJ, et al. (2015). Measuring trauma system performance: right patient, right place-mission accomplished?. J Trauma Acute Care Surg.
Ciesla DJ, Pracht EE, Cha JY, et al. (2012). Geographic distribution of severely injured patients: implications for trauma system development. J Trauma Acute Care Surg.
Cipolle MD, Geffe K, Getchell J, et al. (2014). Long-term outcome in elderly patients after operation for traumatic intracranial hemorrhage. Del Med J.
Cirera E, Plasencia A, Ferrando J, et al. (2001). Factors associated with severity and hospital admission of motor-vehicle injury cases in a Southern European urban area. Eur J Epidemiol.
Claridge JA, Golob JF, Leukhardt WH, et al. (2010). Trauma team activation can be tailored by prehospital criteria. Am Surg.
Claridge JA, Schulman AM, Sawyer RG, et al. (2001). The “July phenomenon” and the care of the severely injured patient: fact or fiction?. Surgery.
Clark DE, Hannan EL, Wu C. (2010). Predicting risk-adjusted mortality for trauma patients: logistic versus multilevel logistic models. J Am Coll Surg.
Clark DE, Qian J, Winchell RJ, et al. (2012). Hazard regression models of early mortality in trauma centers. J Am Coll Surg.
Clark DE, Ryan LM. (2002). Concurrent prediction of hospital mortality and length of stay from risk factors on admission. Health Serv Res.
Clesham K, Mason S, Gray J, et al. (2008). Can emergency medical service staff predict the disposition of patients they are transporting?. Emerg Med J.
Codner P, Obaid A, Porral D, et al. (2005). Is field hypotension a reliable indicator of significant injury in trauma patients who are normotensive on arrival to the emergency department?. Am Surg.
Cohn SM, Nathens AB, Moore FA, et al. (2007). Tissue oxygen saturation predicts the development of organ dysfunction during traumatic shock resuscitation. J Trauma.
Cole E. (2015). How regional trauma systems improve outcomes. Emerg Nurse.
Cone DC, Domeier R. (2005). Examining the applicability of guidelines promulgated in 2003 by the American College of Surgeons' Committee on Trauma. J Trauma.
Conroy C, Hoyt DB, Eastman AB, et al. (2006). Rollover crashes: predicting serious injury based on occupant, vehicle, and crash characteristics. Accid Anal Prev.
Conroy C, Tominaga GT, Erwin S, et al. (2008). The influence of vehicle damage on injury severity of drivers in head-on motor vehicle crashes. Accid Anal Prev.
Cook A, Weddle J, Baker S, et al. (2014). A comparison of the injury severity score and the trauma mortality prediction model. J Trauma Acute Care Surg.
Cook WL, Tomlinson G, Donaldson M, et al. (2006). Falls and fall-related injuries in older dialysis patients. Clin J Am Soc Nephrol.
Cooke WH, Salinas J, Convertino VA, et al. (2006). Heart rate variability and its association with mortality in prehospital trauma patients. J Trauma.
Cooke WH, Salinas J, McManus JG, et al. (2006). Heart period variability in trauma patients may predict mortality and allow remote triage. Aviat Space Environ Med.
Corner EJ, Wood H, Englebretsen C, et al. (2013). The Chelsea Critical Care Physical Assessment tool (CPAx): validation of an innovative new tool to measure physical morbidity in the general adult critical care population; an observational proof-of-concept pilot study. Physiotherapy.
Cox S, Currell A, Harriss L, et al. (2012). Evaluation of the Victorian state adult pre-hospital trauma triage criteria. Injury.
Criss EA. (2007). Research review. JEMS.
Criss EA. (2008). Research review. JEMS.
Criss EA. (2010). Research review. JEMS.
Cross KP, Cicero MX. (2013). Head-to-head comparison of disaster triage methods in pediatric, adult, and geriatric patients. Ann Emerg Med.
Crossman J, Bankes M, Bhan A, et al. (1998). The Glasgow Coma Score: reliable evidence?. Injury.
Cryer C, Davie G. (2011). Alcohol, ethnicity and service use in trauma patients: challenges of presenting and interpreting effect modification. Injury.
Cudnik MT, Newgard CD, Daya M, et al. (2010). The impact of rapid sequence intubation on trauma patient mortality in attempted prehospital intubation. J Emerg Med.
Cudnik MT, Newgard CD, Sayre MR, et al. (2009). Level I versus level II trauma centers: an outcomes-based assessment. J Trauma.
Cudnik MT, Sayre MR, Hiestand B, et al. (2010). Are all trauma centers created equally? A statewide analysis. Acad Emerg Med.
Cudnik MT, Werman HA, White LJ, et al. (2012). Prehospital factors associated with mortality in injured air medical patients. Prehosp Emerg Care.
Culley JM, Svendsen E, Craig J, et al. (2014). A validation study of 5 triage systems using data from the 2005 Graniteville, South Carolina, chlorine spill. J Emerg Nurs.
Da Silva Nunes M, Hora EC, Fakhouri R, et al. (2013). Trauma in adolescents and adults: severity assessment by anatomical score. J Nurs UFPE.
Danne P, Brazenor G, Cade R, et al. (1998). The major trauma management study: an analysis of the efficacy of current trauma care. Aust N Z J Surg.
Davidson GH, Rivara FP, Mack CD, et al. (2014). Validation of prehospital trauma triage criteria for motor vehicle collisions. J Trauma Acute Care Surg.
Davis DP, Fakhry SM, Wang HE, et al. (2007). Paramedic rapid sequence intubation for severe traumatic brain injury: perspectives from an expert panel. Prehosp Emerg Care.
Davis DP, Kene M, Vilke GM, et al. (2007). Head-injured patients who “talk and die”: the San Diego perspective. J Trauma.
Davis DP, Peay J, Serrano JA, et al. (2005). The impact of aeromedical response to patients with moderate to severe traumatic brain injury. Ann Emerg Med.
Davis DP, Vadeboncoeur TF, Ochs M, et al. (2005). The association between field Glasgow Coma Scale score and outcome in patients undergoing paramedic rapid sequence intubation. J Emerg Med.
Davis RL, Hughes M, Gubler KD, et al. (1995). The use of cranial CT scans in the triage of pediatric patients with mild head injury. Pediatrics.
de Jongh MA, Meeuwis JD, van Baar ME, et al. (2008). Evaluation of trauma care by comparing mortality risks and admission policy in a Dutch trauma region. Injury.
de Jongh MA, van Stel HF, Schrijvers AJ, et al. (2012). The effect of helicopter emergency medical services on trauma patient mortality in the Netherlands. Injury.
Delgado MK, Yokell MA, Staudenmayer KL, et al. (2014). Factors associated with the disposition of severely injured patients initially seen at non–trauma center emergency departments: disparities by insurance status. JAMA Surgery.
Dellinger AM, Stevens JA. (2006). The injury problem among older adults: mortality, morbidity and costs. J Safety Res.
Demetriades D, Kuncir E, Brown CV, et al. (2006). Early prediction of mortality in isolated head injury patients: a new predictive model. J Trauma.
Demetriades D, Kuncir E, Murray J, et al. (2004). Mortality prediction of head Abbreviated Injury Score and Glasgow Coma Scale: analysis of 7,764 head injuries. J Am Coll Surg.
Demetriades D, Martin M, Salim A, et al. (2006). Relationship between American College of Surgeons trauma center designation and mortality in patients with severe trauma (injury severity score > 15). J Am Coll Surg.
Demirhan R, Onan B, Oz K, et al. (2009). Comprehensive analysis of 4205 patients with chest trauma: a 10-year experience. Interact Cardiovasc Thorac Surg.
Dent DL, Croce MA, Menke PG, et al. (1995). Prognostic factors after acute subdural hematoma. J Trauma.
Di Bartolomeo S, Sanson G, Nardi G, et al. (2001). Effects of 2 patterns of prehospital care on the outcome of patients with severe head injury. Arch Surg.
Diamond IR, Parkin PC, Wales PW, et al. (2009). Preventable pediatric trauma deaths in Ontario: a comparative population-based study. J Trauma.
Dinh MM, Bein KJ, Byrne CM, et al. (2014). Deriving a prediction rule for short stay admission in trauma patients admitted at a major trauma centre in Australia. Emerg Med J.
Diringer MN, Edwards DF. (1997). Does modification of the Innsbruck and the Glasgow Coma Scales improve their ability to predict functional outcome?. Arch Neurol.
DiRusso SM, Sullivan T, Holly C, et al. (2000). An artificial neural network as a model for prediction of survival in trauma patients: validation for a regional trauma area. J Trauma.
Do HQ, Hesselfeldt R, Steinmetz J, et al. (2014). Is paediatric trauma severity overestimated at triage? An observational follow-up study. Acta Anaesthesiologica Scandinavica.
Do HQ, Steinmetz J, Rasmussen LS. (2012). In-hospital mortality pattern of severely injured children. Injury.
Dorlac WC, DeBakey ME, Holcomb JB, et al. (2005). Mortality from isolated civilian penetrating extremity injury. J Trauma.
Drayna PC, Browne LR, Guse CE, et al. (2015). Prehospital pediatric care: opportunities for training, treatment, and research. Prehosp Emerg Care.
DuBose JJ, Browder T, Inaba K, et al. (2008). Effect of trauma center designation on outcome in patients with severe traumatic brain injury. Arch Surg.
Ducharme-Crevier L, Wainwright M. (2015). Acute management of children with traumatic brain injury. Clin Pediatr Emerg Med.
Ducrocq SC, Meyer PG, Orliaguet GA, et al. (2006). Epidemiology and early predictive factors of mortality and outcome in children with traumatic severe brain injury: experience of a French pediatric trauma center. Pediatr Crit Care Med.
Duma SM, Moorcroft DM, Gabler HC, et al. (2006). Analysis of pregnant occupant crash exposure and the potential effectiveness of four-point seatbelts in far side crashes. Annu Proc Assoc Adv Automot Med.
Dunham CM, Barraco RD, Clark DE, et al. (2003). Guidelines for emergency tracheal intubation immediately after traumatic injury. J Trauma.
Dutton RP. (2010). Making medics smarter. Critical Care Medicine.
Eastman AL, Arnoldo BA, Hunt JL, et al. (2010). Pre-burn center management of the burned airway: do we know enough?. J Burn Care Res.
Eastridge BJ, Butler F, Wade CE, et al. (2010). Field triage score (FTS) in battlefield casualties: validation of a novel triage technique in a combat environment. Am J Surg.
Eckstein M. (2003). The value of prehospital Glasgow Coma Scale (GCS) to predict the need for patient hospitalization. J Trauma.
Edelman DA, White MT, Tyburski JG, et al. (2007). Post-traumatic hypotension: should systolic blood pressure of 90-109 mmHg be included?. Shock.
Ehrlich PF, Brown JK, Sochor MR, et al. (2006). Factors influencing pediatric injury severity score and Glasgow Coma Scale in pediatric automobile crashes: results from the Crash Injury Research Engineering Network. J Pediatr Surg.
El Kady D. (2007). Perinatal outcomes of traumatic injuries during pregnancy. Clin Obstet Gynecol.
Elliott M. (1996). Interrater reliability of the Glasgow Coma Scale. J Neurosci Nurs.
Emircan S, Ozguc H, Akkose Aydin S, et al. (2011). Factors affecting mortality in patients with thorax trauma. Ulus Travma Acil Cerrahi Derg.
Englander J, Bushnik T, Duong TT, et al. (2003). Analyzing risk factors for late posttraumatic seizures: a prospective, multicenter investigation. Arch Phys Med Rehabil.
Engum SA, Mitchell MK, Scherer LR, et al. (2000). Prehospital triage in the injured pediatric patient. J Pediatr Surg.
Esposito TJ, Reed RL, Gamelli RL, et al. (2005). Neurosurgical coverage: essential, desired, or irrelevant for good patient care and trauma center status. Ann Surg.
Evans SL, Nance ML, Arbogast KB, et al. (2009). Passenger compartment intrusion as a predictor of significant injury for children in motor vehicle crashes. J Trauma.
Fabbri A, Servadei F, Marchesini G, et al. (2008). Early predictors of unfavourable outcome in subjects with moderate head injury in the emergency department. J Neurol Neurosurg Psychiatry.
Falcone RA, Haas L, King E, et al. (2012). A multicenter prospective analysis of pediatric trauma activation criteria routinely used in addition to the six criteria of the American College of Surgeons. J Trauma Acute Care Surg.
Falcone RE, Herron H, Dean B, et al. (1996). Emergency scene endotracheal intubation before and after the introduction of a rapid sequence induction protocol. Air Med J.
Falcone RE, Herron H, Werman H, et al. (1998). Air medical transport of the injured patient: scene versus referring hospital. Air Med J.
Fang JF, Shih LY, Lin BC, et al. (2008). Pelvic fractures due to falls from a height in people with mental disorders. Injury.
Fang R, Markandaya M, DuBose JJ, et al. (2015). Early in-theater management of combat-related traumatic brain injury: a prospective, observational study to identify opportunities for performance improvement. J Trauma Acute Care Surg.
Farmer KA, McGrath SP, Blike GT. (2007). An experimental architecture for observation of triage related decision making. Conf Proc IEEE Eng Med Biol Soc.
Fayssoux RS, Tally W, Sanfilippo JA, et al. (2008). Spinal injuries after falls from hunting tree stands. Spine J.
Ferris JD, Smith I, Robertson CE. (2008). Emergency department at the cutting edge. Eur J Emerg Med.
Fiissel D, Pattison G, Howard A. (2005). Severity of playground fractures: play equipment versus standing height falls. Inj Prev.
(2014). Findings question the applicability of widely used trauma triage scores to assess older patients. Orthopedics Today.
Finkelstein EA, Chen H, Prabhu M, et al. (2007). The relationship between obesity and injuries among U.S. adults. Am J Health Promot.
Fischer J, Mathieson C. (2001). The history of the Glasgow Coma Scale: implications for practice. Crit Care Nurs Q.
Fischer PE, Colavita PD, Fleming GP, et al. (2014). Delays in transfer of elderly less-injured trauma patients can have deadly consequences. Am Surg.
Fitzharris M, Yu J, Hammond N, et al. (2011). Injury in China: a systematic review of injury surveillance studies conducted in Chinese hospital emergency departments. BMC Emerg Med.
Franschman G, Andriessen TMJC, Boer C, et al. (2013). Physician-based emergency medical service deployment characteristics in severe traumatic brain injury: A Dutch multicenter study. Injury.
Franschman G, Greuters S, Loer SA, et al. (2010). Prehospital treatment guidelines in severe traumatic brain injury: what really happens outside the hospital?. Resuscitation.
Franschman G, Peerdeman SM, Andriessen TM, et al. (2011). Effect of secondary prehospital risk factors on outcome in severe traumatic brain injury in the context of fast access to trauma care. J Trauma.
Frohlich M, Lefering R, Probst C, et al. (2014). Epidemiology and risk factors of multiple-organ failure after multiple trauma: an analysis of 31,154 patients from the traumaregister DGU. J Trauma Acute Care Surg.
Fuglistaler-Montali I, Attenberger C, Fuglistaler P, et al. (2009). In search of benchmarking for mortality following multiple trauma: a Swiss trauma center experience. World J Surg.
Gabbe BJ, Cameron PA, Finch CF. (2003). The status of the Glasgow Coma Scale. Emerg Med (Fremantle).
Gabbe BJ, Cameron PA, Wolfe R, et al. (2005). Prehospital prediction of intensive care unit stay and mortality in blunt trauma patients. J Trauma.
Galvagno SM, Sikorski R, Hirshon JM, et al. (2015). Helicopter emergency medical services for adults with major trauma. Cochrane Database Syst Rev.
Galvagno SM, Haut ER, Zafar S, et al. (2012). Association between helicopter vs ground emergency medical services and survival for adults with major trauma. JAMA.
Gangavati AS, Kiely DK, Kulchycki LK, et al. (2009). Prevalence and characteristics of traumatic intracranial hemorrhage in elderly fallers presenting to the emergency department without focal findings. J Am Geriatr Soc.
Garner AA, Mann KP, Fearnside M, et al. (2015). The Head Injury Retrieval Trial (HIRT): A singlecentre randomised controlled trial of physician prehospital management of severe blunt head injury compared with management by paramedics only. Emerge Med J.
Garthe E, Mango NK, Prenney B. (2002). Statewide air medical transports for Massachusetts. Air Med J.
Garwe T, Cowan LD, Neas BR, et al. (2011). Directness of transport of major trauma patients to a level I trauma center: a propensity-adjusted survival analysis of the impact on short-term mortality. J Trauma.
Garwe T, Cowan LD, Neas BR, et al. (2011). A propensity score analysis of prehospital factors and directness of transport of major trauma patients to a level I trauma center. J Trauma.
Gebhart ME, Pence R. (2007). START triage: does it work?. Disaster Management & Response: DMR.
Geeraedts LM, Kaasjager HA, van Vugt AB, et al. (2009). Exsanguination in trauma: a review of diagnostics and treatment options. Injury.
George RL, McGwin G, Metzger J, et al. (2003). The association between gender and mortality among trauma patients as modified by age. J Trauma.
Giannoudis PV, Grotz MR, Tzioupis C, et al. (2007). Prevalence of pelvic fractures, associated injuries, and mortality: the United Kingdom perspective. J Trauma.
Gill M, Martens K, Lynch EL, et al. (2007). Interrater reliability of 3 simplified neurologic scales applied to adults presenting to the emergency department with altered levels of consciousness. Ann Emerg Med.
Gill MR, Reiley DG, Green SM. (2004). Interrater reliability of Glasgow Coma Scale scores in the emergency department. Ann Emerg Med.
Glassberg E, Lipsky AM, Lending G, et al. (2013). Blood glucose levels as an adjunct for prehospital field triage. Am J Emerg Med.
Gleich SJ, Bennett TD, Bratton SL, et al. (2011). Pediatric trauma transport performance measures in a mountain state: adherence and outcomes. J Trauma.
Gloeckner DC, Moore TL, Steffey D, et al. (2006). Implications of vehicle roll direction on occupant ejection and injury risk. Annu Proc Assoc Adv Automot Med.
Goettler CE, Fugo JR, Bard MR, et al. (2006). Predicting the need for early tracheostomy: a multifactorial analysis of 992 intubated trauma patients. J Trauma.
Goldschlager T, Rosenfeld JV, Winter CD. (2007). ‘Talk and die’ patients presenting to a major trauma centre over a 10 year period: a critical review. J Clin Neurosci.
Gordon E, von Holst H, Rudehill A. (1995). Outcome of head injury in 2298 patients treated in a single clinic during a 21-year period. J Neurosurg Anesthesiol.
Gorelick MH, Atabaki SM, Hoyle J, et al. (2008). Interobserver agreement in assessment of clinical variables in children with blunt head trauma. Acad Emerg Med.
Gottschalk SB, Wood D, DeVries S, et al. (2006). The Cape Triage Score: a new triage system South Africa. Proposal from the Cape Triage Group. Emerg Med J.
Grba-Bujevic M, Bosan-Kilibarda I, Strikic N. (2012). The use of hypertonic-hyperoncotic solution for hypovolemic shock in trauma patients in prehospital setting. Neurol Croat.
Grote S, Bocker W, Mutschler W, et al. (2011). Diagnostic value of the Glasgow Coma Scale for traumatic brain injury in 18,002 patients with severe multiple injuries. J Neurotrauma.
(2007). Guidelines for the operation of burn centers. J Burn Care Res.
Guo QF, Xu ZH. (2005). Rescue and treatment of severely injured lower extremities. Chin J Traumatol.
Gurkin SA, Parikshak M, Kralovich KA, et al. (2002). Indicators for tracheostomy in patients with traumatic brain injury. Am Surg.
Guyette FX, Gomez H, Suffoletto B, et al. (2012). Prehospital dynamic tissue oxygen saturation response predicts in-hospital lifesaving interventions in trauma patients. J Trauma Acute Care Surg.
Guzel A, Ceylan A, Tatli M, et al. (2009). Ulus Travma Acil Cerrahi Derg.
Haas B, Gomez D, Zagorski B, et al. (2010). Survival of the fittest: the hidden cost of undertriage of major trauma. J Am Coll Surg.
Haider AH, Chang DC, Haut ER, et al. (2009). Mechanism of injury predicts patient mortality and impairment after blunt trauma. J Surg Res.
Haines CJ, Lutes RE, Blaser M, et al. (2006). Paramedic initiated non-transport of pediatric patients. Prehosp Emerg Care.
Hall JR, Reyes HM, Meller JL, et al. (1996). The outcome for children with blunt trauma is best at a pediatric trauma center. J Pediatr Surg.
Hammell CL, Henning JD. (2009). Prehospital management of severe traumatic brain injury. BMJ.
Hampton DA, Fabricant LJ, Differding J, et al. (2013). Prehospital intravenous fluid is associated with increased survival in trauma patients. J Trauma Acute Care Surg.
Hannay RS, Wyrzykowski AD, Ball CG, et al. (2014). Retrospective review of injury severity, interventions and outcomes among helicopter and nonhelicopter transport patients at a level 1 urban trauma centre. Can J Surg.
Hannon M, Hadjizacharia P, Chan L, et al. (2009). Prognostic significance of lower extremity long bone fractures after automobile versus pedestrian injuries. J Trauma.
Hansoti B, Beattie T. (2005). Can the height of fall predict long bone fracture in children under 24 months?. Eur J Emerg Med.
Harrington DT, Connolly M, Biffl WL, et al. (2005). Transfer times to definitive care facilities are too long: a consequence of an immature trauma system. Ann Surg.
Harris JE, Draper HL, Rhodes AI, et al. (2000). High yield criteria for emergency cranial computed tomography in adult patients with no history of head injury. J Accid Emerg Med.
Härtl R, Gerber LM, Iacono L, et al. (2006). Direct transport within an organized state trauma system reduces mortality in patients with severe traumatic brain injury. J Trauma.
Hasler RM, Kehl C, Exadaktylos AK, et al. (2012). Accuracy of prehospital diagnosis and triage of a Swiss helicopter emergency medical service. J Trauma Acute Care Surg.
Haug E, Miner J, Dannehy M, et al. (2004). Bispectral electroencephalographic analysis of head-injured patients in the emergency department. Acad Emerg Med.
Hauschild O, Strohm PC, Culemann U, et al. (2008). Mortality in patients with pelvic fractures: results from the German pelvic injury register. J Trauma.
Hayes JR, Bechtel NM, Beck RA, et al. (2007). Assessment of Ohio's adult and pediatric legislatively mandated prehospital trauma triage criteria. J Trauma Nurs.
Heard K, Bebarta VS. (2004). Reliability of the Glasgow Coma Scale for the emergency department evaluation of poisoned patients. Hum Exp Toxicol.
Heffernan DS, Thakkar RK, Monaghan SF, et al. (2010). Normal presenting vital signs are unreliable in geriatric blunt trauma victims. J Trauma.
Heis HA, Bani-Hani KE, Elheis MA. (2008). Overview of extremity arterial trauma in Jordan. Int Angiol.
Helling TS. (2007). Trauma care at rural level III trauma centers in a state trauma system. J Trauma.
Helling TS, Watkins M, Evans LL, et al. (1999). Low falls: an underappreciated mechanism of injury. J Trauma.
Henry MC, Hollander JE, Alicandro JM, et al. (1996). Incremental benefit of individual American College of Surgeons trauma triage criteria. Acad Emerg Med.
Heron R, Davie A, Gillies R, et al. (2001). Interrater reliability of the Glasgow Coma Scale scoring among nurses in sub-specialties of critical care. Aust Crit Care.
Hill AD, Fowler RA, Nathens AB. (2011). Impact of interhospital transfer on outcomes for trauma patients: a systematic review. J Trauma.
Hill DA, Delaney LM, Roncal S. (1997). A chi-square automatic interaction detection (CHAID) analysis of factors determining trauma outcomes. J Trauma.
Hitosugi M, Motozawa Y, Kido M, et al. (2006). Traffic injuries of the pregnant women and fetal or neonatal outcomes. Forensic Sci Int.
Holcomb JB, Niles SE, Miller CC, et al. (2005). Prehospital physiologic data and lifesaving interventions in trauma patients. Mil Med.
Holcomb JB, Salinas J, McManus JM, et al. (2005). Manual vital signs reliably predict need for life-saving interventions in trauma patients. J Trauma.
Holdgate A, Ching N, Angonese L. (2006). Variability in agreement between physicians and nurses when measuring the Glasgow Coma Scale in the emergency department limits its clinical usefulness. Emerg Med Australas.
Hollander JE, Go S, Lowery DW, et al. (2003). Interrater reliability of criteria used in assessing blunt head injury patients for intracranial injuries. Acad Emerg Med.
Holmes JF, Wisner DH, McGahan JP, et al. (2009). Clinical prediction rules for identifying adults at very low risk for intra-abdominal injuries after blunt trauma. Ann Emerg Med.
Holmes M, Garver M, Albrecht L, et al. (2014). Comparison of two comorbidity scoring systems for older adults with traumatic injuries. J Am Coll Surg.
Hoogervorst EM, van Beeck EF, Goslings JC, et al. (2013). Developing process guidelines for trauma care in the Netherlands for severely injured patients: results from a Delphi study. BMC Health Serv Res.
Howard JL, Cipolle MD, Horvat SA, et al. (2009). Preinjury warfarin worsens outcome in elderly patients who fall from standing. J Trauma.
Hranjec T, Sawyer RG, Young JS, et al. (2012). Mortality factors in geriatric blunt trauma patients: creation of a highly predictive statistical model for mortality using 50,765 consecutive elderly trauma admissions from the National Sample Project. Am Surg.
Hsiao KH, Dinh MM, McNamara KP, et al. (2013). Whole-body computed tomography in the initial assessment of trauma patients: is there optimal criteria for patient selection?. Emerg Med Australas.
Hsiao KY, Chen IC, Yang CJ, et al. (2012). Is direct transport to a trauma centre best for patients with severe traumatic brain injury? A study in South-Central Taiwan. Emerg Med J.
Hsiao KY, Hsiao CT, Weng HH, et al. (2008). Factors predicting mortality in victims of blunt trauma brain injury in emergency department settings. Emerg Med J.
Hu PF, Mackenzie C, Dutton R, et al. (2008). Statewide real-time in-flight trauma patient vital signs collection system. AMIA Annu Symp Proc.
Huber-Wagner S, Stegmaier J, Mathonia P, et al. (2010). The sequential trauma score - a new instrument for the sequential mortality prediction in major trauma. Eur J Med Res.
Hutter M, Woltmann A, Hierholzer C, et al. (2011). Association between a single-pass whole-body computed tomography policy and survival after blunt major trauma: a retrospective cohort study. Scand J Trauma Resus Emerg Med.
Ibanez J, Arikan F, Pedraza S, et al. (2004). Reliability of clinical guidelines in the detection of patients at risk following mild head injury: results of a prospective study. J Neurosurg.
Ikossi DG, Lazar AA, Morabito D, et al. (2005). Profile of mothers at risk: an analysis of injury and pregnancy loss in 1,195 trauma patients. J Am Coll Surg.
Ivarsson BJ, Henary B, Crandall JR, et al. (2005). Significance of adult pedestrian torso injury. Annu Proc Assoc Adv Automot Med.
Ivascu FA, Howells GA, Junn FS, et al. (2008). Predictors of mortality in trauma patients with intracranial hemorrhage on preinjury aspirin or clopidogrel. J Trauma.
Janus TJ, Vaughan-Sarrazin MS, Baker LJ, et al. (2012). Predictors of pneumonia in trauma patients with pulmonary contusion. J Trauma Nurs.
Johnson K, Fischer T, Chapman S, et al. (2005). Accidental head injuries in children under 5 years of age. Clin Radiol.
Johnson NJ, Carr BG, Salhi R, et al. (2013). Characteristics and outcomes of injured patients presenting by private vehicle in a state trauma system. Am J Emerg Med.
Jones JM, Skaga NO, Sovik S, et al. (2014). Norwegian survival prediction model in trauma: modelling effects of anatomic injury, acute physiology, age, and co-morbidity. Acta Anaesthesiol Scand.
Jones K, Sharp C, Mangram AJ, et al. (2006). The effects of preinjury clopidogrel use on older trauma patients with head injuries. Am J Surg.
Joosse P, de Jong WJ, Reitsma JB, et al. (2014). External validation of the emergency trauma score for early prediction of mortality in trauma patients. Crit Care Med.
Joosse P, Saltzherr TP, van Lieshout WA, et al. (2012). Impact of secondary transfer on patients with severe traumatic brain injury. J Trauma Acute Care Surg.
Juarez VJ, Lyons M. (1995). Interrater reliability of the Glasgow Coma Scale. J Neurosci Nurs.
Juhra C, Vordemvenne T, Hartensuer R, et al. (2009). Telematics in acute trauma care. Stud Health Technol Inform.
Kaiser M, Ahearn P, Nguyen XM, et al. (2009). Early predictors of the need for emergent surgery to control hemorrhage in hypotensive trauma patients. Am Surg.
Kam CW, Kitchell AK, Yau HH, et al. (1998). Outcome of major trauma patients in a Hong Kong general hospital. Eur J Emerg Med.
Kann SH, Hougaard K, Christensen EF. (2007). Evaluation of pre-hospital trauma triage criteria: a prospective study at a Danish level I trauma centre. Acta Anaesthesiol Scand.
Kapapa T, Konig K, Pfister U, et al. (2010). Head trauma in children, part 1: admission, diagnostics, and findings. J Child Neurol.
Kaur B, Geary M, Palmer J, et al. (2014). Neurological outcome and early intracranial hypertension after paediatric traumatic brain injury. Dev Med Child Neurol.
Kejriwal R, Civil I. (2009). Time to definitive care for patients with moderate and severe traumatic brain injury--does a trauma system matter?. N Z Med J.
Kelly ML, Roach MJ, Banerjee A, et al. (2015). Functional and long-term outcomes in severe traumatic brain injury following regionalization of a trauma system. J Trauma Acute Care Surg.
Kevric J, Jelinek GA, Knott J, et al. (2011). Validation of the Full Outline of UnResponsiveness (FOUR) scale for conscious state in the emergency department: comparison against the Glasgow Coma Scale. Emerg Med J.
Kilaru S, Garb J, Emhoff T, et al. (1996). Long-term functional status and mortality of elderly patients with severe closed head injuries. J Trauma.
Kilic YA, Konan A, Yorganci K, et al. (2010). A novel fuzzy-logic inference system for predicting trauma-related mortality: emphasis on the impact of response to resuscitation. Eur J Trauma Emerg Surg.
Kim D, Kobayashi L, Chang D, et al. (2014). Development of a preliminary risk index to identify trauma patients at risk for an unplanned intubation. J Trauma Acute Care Surg.
Kimura A, Nakahara S, Chadbunchachai W. (2012). The development of simple survival prediction models for blunt trauma victims treated at Asian emergency centers. Scand J Trauma Resusc Emerg Med.
King DR, Ogilvie MP, Pereira BM, et al. (2009). Heart rate variability as a triage tool in patients with trauma during prehospital helicopter transport. J Trauma.
Kirves H, Handolin L, Niemela M, et al. (2010). Paramedics' and pre-hospital physicians' assessments of anatomic injury in trauma patients: a cohort study. Scand J Trauma Resusc Emerg Med.
Kissoon N, Tepas JJ, Peterson RJ, et al. (1996). The evaluation of pediatric trauma care using audit filters. Pediatr Emerg Care.
Klein MB, Kramer CB, Nelson J, et al. (2009). Geographic access to burn center hospitals. JAMA.
Klein MB, Nathens AB, Emerson D, et al. (2007). An analysis of the long-distance transport of burn patients to a regional burn center. J Burn Care Res.
Klemenc-Ketis Z, Bacovnik-Jansa U, Ogorevc M, et al. (2011). Outcome predictors of Glasgow outcome scale score in patients with severe traumatic brain injury. Ulus Travma ve Acil Cerrahi Derg.
Kleppel JB, Lincoln AE, Winston FK. (2002). Assessing head-injury survivors of motor vehicle crashes at discharge from trauma care. Am J Phys Med Rehabil.
Klin B, Rosenfeld-Yehoshua N, Abu-Kishk I, et al. (2009). Bicycle-related injuries in children: disturbing profile of a growing problem. Injury.
Kohli A, Banerjee KK. (2006). Pattern of injuries in fatal falls from buildings. Med Sci Law.
Koksal O, Ozdemir F, Bulut M, et al. (2009). Comparison of trauma scoring systems for predicting mortality in firearm injuries. Ulus Travma Acil Cerrahi Derg.
Kondo Y, Abe T, Kohshi K, et al. (2011). Revised trauma scoring system to predict in-hospital mortality in the emergency department: Glasgow Coma Scale, age, and systolic blood pressure score. Crit Care.
Kononen DW, Flannagan CA, Wang SC. (2011). Identification and validation of a logistic regression model for predicting serious injuries associated with motor vehicle crashes. Accid Anal Prev.
Koval KJ, Tingey CW, Spratt KF. (2006). Are patients being transferred to level-I trauma centers for reasons other than medical necessity?. J Bone Joint Surg Am.
Kuhne CA, Homann M, Ose C, et al. (2003). Unfallchirurg.
Kulvatunyou N, Friese RS, Joseph B, et al. (2012). Incidence and pattern of cervical spine injury in blunt assault: it is not how they are hit, but how they fall. J Trauma Acute Care Surg.
Kuo WY, Lin HJ, Foo NP, et al. (2011). Will computed tomography (CT) miss something? The characteristics and pitfalls of torso CT in evaluating patients with blunt solid organ trauma. Ulus Travma Acil Cerrahi Derg.
Kuppermann N, Holmes JF, Dayan PS, et al. (2009). Identification of children at very low risk of clinically-important brain injuries after head trauma: a prospective cohort study. Lancet.
Kuppermann N, Holmes JF, Dayan PS, et al. (2014). Identification of children at very low risk of clinically-important brain injuries after head trauma: a prospective cohort study. Lancet.
Lahausse JA, Fildes BN, Page Y, et al. (2008). The potential for automatic crash notification systems to reduce road fatalities. Ann Adv Automot Med.
Lakstein D, Blumenfeld A, Sokolov T, et al. (2003). Tourniquets for hemorrhage control on the battlefield: a 4-year accumulated experience. J Trauma.
Lalezarzadeh F, Wisniewski P, Huynh K, et al. (2009). Evaluation of prehospital and emergency department systolic blood pressure as a predictor of in-hospital mortality. Am Surg.
Lange RT, Iverson GL, Brubacher JR, et al. (2010). Effect of blood alcohol level on Glasgow Coma Scale scores following traumatic brain injury. Brain Inj.
Lansink KW, Leenen LP. (2007). Do designated trauma systems improve outcome?. Curr Opin Crit Care.
Lapostolle F, Gere C, Borron SW, et al. (2005). Prognostic factors in victims of falls from height. Crit Care Med.
Larson JT, Dietrich AM, Abdessalam SF, et al. (2004). Effective use of the air ambulance for pediatric trauma. J Trauma.
Lavelle JM, Shaw KN. (1998). Evaluation of head injury in a pediatric emergency department: pretrauma and posttrauma system. Arch Pediatr Adolesc Med.
Lavoie A, Emond M, Moore L, et al. (2010). Evaluation of the prehospital index, presence of high-velocity impact and judgment of emergency medical technicians as criteria for trauma triage. CJEM.
Leach SR, Swor RA, Jackson RE, et al. (2008). Do outcome measures for trauma triage agree?. Prehosp Emerg Care.
Lecky F, Russell W, Fuller G, et al. (2016). The head injury transportation straight to neurosurgery (HITS-NS) randomised trial: a feasibility study. Health Technol Assess.
Lee A, Garner A, Fearnside M, et al. (2003). Level of prehospital care and risk of mortality in patients with and without severe blunt head injury. Injury.
Lee C, Porter K. (2007). The prehospital management of pelvic fractures. Emerg Med J.
Lee YT, Feng XY, Lin YC, et al. (2014). Pediatric trauma team activation: are we making the right call?. Eur J Pediatr Surg.
Lehr D, Baethmann A, Reulen HJ, et al. (1997). Management of patients with severe head injury in the preclinical phase: a prospective analysis. J Trauma.
Leong LB, Sukarom S, Vasu A, et al. (2013). Identifying predictors of an abnormal computed tomographic scan among patients with a head injury and a Glasgow Coma Scale of 15. Eur J Emerg Med.
Lerner EB, Shah MN, Swor RA, et al. (2011). Comparison of the 1999 and 2006 trauma triage guidelines: where do patients go?. Prehosp Emerg Care.
Lesko MM, Jenks T, O'Brien SJ, et al. (2013). Comparing model performance for survival prediction using total Glasgow Coma Scale and its components in traumatic brain injury. J Neurotrauma.
Levine SD, Colwell CB, Pons PT, et al. (2006). How well do paramedics predict admission to the hospital? A prospective study. J Emerg Med.
Liberman M, Mulder D, Sampalis J. (2000). Advanced or basic life support for trauma: meta-analysis and critical review of the literature. J Trauma.
Liberman M, Mulder DS, Jurkovich GJ, et al. (2005). The association between trauma system and trauma center components and outcome in a mature regionalized trauma system. Surgery.
Lichenstein R, Glass TF, Quayle KS, et al. (2012). Presentations and outcomes of children with intraventricular hemorrhages after blunt head trauma. Arch Pediatr Adolesc Med.
Lichtveld RA, Panhuizen IF, Snit RBJ, et al. (2007). Predictors of death in trauma patients who are alive on arrival at hospital. Eur J Trauma Emerg Surg.
Lieberman JD, Pasquale MD, Garcia R, et al. (2003). Use of admission Glasgow Coma Score, pupil size, and pupil reactivity to determine outcome for trauma patients. J Trauma.
Lin G, Becker A, Lynn M. (2011). Changes in vital signs of trauma victims from prehospital to hospital settings. JPP.
Lin G, Becker A, Lynn M. (2012). Do pre-hospital trauma alert criteria predict the severity of injury and a need for an emergent surgical intervention?. Injury.
Lin YR, Wu HP, Chen WL, et al. (2013). Predictors of survival and neurologic outcomes in children with traumatic out-of-hospital cardiac arrest during the early postresuscitative period. J Trauma Acute Care Surg.
Lipsky AM, Gausche-Hill M, Henneman PL, et al. (2006). Prehospital hypotension is a predictor of the need for an emergent, therapeutic operation in trauma patients with normal systolic blood pressure in the emergency department. J Trauma.
Lipsky AM, Klein Y, Givon A, et al. (2014). Accuracy of initial critical care triage decisions in blast versus non-blast trauma. Disaster Med Public Health Prep.
Liu CC, Wang CY, Shih HC, et al. (2009). Prognostic factors for mortality following falls from height. Injury.
Liu NT, Holcomb JB, Wade CE, et al. (2014). Utility of vital signs, heart rate variability and complexity, and machine learning for identifying the need for lifesaving interventions in trauma patients. Shock.
Liu NT, Holcomb JB, Wade CE, et al. (2015). Improving the prediction of mortality and the need for life-saving interventions in trauma patients using standard vital signs with heart-rate variability and complexity. Shock.
London JA, Rosengart MR, Jurkovich GJ, et al. (2006). Prospective payments in a regional trauma center: the case for recognition of the transfer patient in diagnostic related groups. J Trauma.
Louahem DM, Nebunescu A, Canavese F, et al. (2006). Neurovascular complications and severe displacement in supracondylar humerus fractures in children: defensive or offensive strategy?. J Pediatr Orthop B.
Lu HY, Li TC, Tu YK, et al. (2015). Predicting long-term outcome after traumatic brain injury using repeated measurements of Glasgow Coma Scale and data mining methods. J Med Syst.
Lubin JS, Delbridge TR, Cole JS, et al. (2005). EMS and emergency department physician triage: injury severity in trauma patients transported by helicopter. Prehosp Emerg Care.
Lunsjo K, Tadros A, Hauggaard A, et al. (2007). Associated injuries and not fracture instability predict mortality in pelvic fractures: a prospective study of 100 patients. J Trauma.
Lustenberger T, Inaba K, Talving P, et al. (2010). Bicyclists injured by automobiles: relationship of age to injury type and severity-a national trauma databank analysis. J Trauma.
Macken L, Manovel A. (2005). Trauma bypass in south-eastern Sydney: an 8-year review. Emerg Med Australas.
Mackenzie CF, Hu P, Sen A, et al. (2008). Automatic pre-hospital vital signs waveform and trend data capture fills quality management, triage and outcome prediction gaps. AMIA Annu Symp Proc.
MacKenzie EJ, Rivara FP, Jurkovich GJ, et al. (2006). A national evaluation of the effect of trauma-center care on mortality. N Engl J Med.
Mackersie RC. (2010). Pitfalls in the evaluation and resuscitation of the trauma patient. Emerg Med Clin North Am.
MacLeod JB, Cohn SM, Johnson EW, et al. (2007). Trauma deaths in the first hour: are they all unsalvageable injuries?. Am J Surg.
Majdan M, Lingsma HF, Nieboer D, et al. (2014). Performance of IMPACT, CRASH and Nijmegen models in predicting six month outcome of patients with severe or moderate TBI: an external validation study. Scand J Trauma Resusc Emerg Med.
Majidi S, Siddiq F, Qureshi AI. (2013). Prehospital neurologic deterioration is independent predictor of outcome in traumatic brain injury: analysis from National Trauma Data Bank. Am J Emerg Med.
Mamelak AN, Pitts LH, Damron S. (1996). Predicting survival from head trauma 24 hours after injury: a practical method with therapeutic implications. J Trauma.
Manthey DE, Nicks BA. (2008). Penetrating trauma to the extremity. J Emerg Med.
Marcin JP, Pollack MM. (2002). Triage scoring systems, severity of illness measures, and mortality prediction models in pediatric trauma. Crit Care Med.
Markovchick VJ, Moore EE. (2007). Optimal trauma outcome: trauma system design and the trauma team. Emerg Med Clin North Am.
Marmarou A, Lu J, Butcher I, et al. (2007). Prognostic value of the Glasgow Coma Scale and pupil reactivity in traumatic brain injury assessed pre-hospital and on enrollment: an IMPACT analysis. J Neurotrauma.
Martin JT, Alkhoury F, O'Connor JA, et al. (2010). ‘Normal’ vital signs belie occult hypoperfusion in geriatric trauma patients. Am Surg.
Martin M, Izenberg S, Cole F, et al. (2012). A decade of experience with a selective policy for direct to operating room trauma resuscitations. Am J Surg.
Matsuyama T, Okuchi K, Seki T, et al. (2004). Prognostic factors in hanging injuries. Am J Emerg Med.
Matthes G, Stengel D, Bauwens K, et al. (2006). Predictive factors of liver injury in blunt multiple trauma. Langenbecks Arch Surg.
Mauritz W, Leitgeb J, Wilbacher I, et al. (2009). Outcome of brain trauma patients who have a Glasgow Coma Scale score of 3 and bilateral fixed and dilated pupils in the field. Eur J Emerg Med.
Mayer L, Meuli M, Lips U, et al. (2006). The silent epidemic of falls from buildings: analysis of risk factors. Pediatr Surg Int.
McCowan CL, Swanson ER, Thomas F, et al. (2008). Outcomes of pediatric trauma patients transported from rural and urban scenes. Air Med J.
McCowan CL, Swanson ER, Thomas F, et al. (2006). Scene transport of pediatric patients injured at winter resorts. PrehospEmerg Care.
McCoy CE, Menchine M, Sampson S, et al. (2013). Emergency medical services out-of-hospital scene and transport times and their association with mortality in trauma patients presenting to an urban level I trauma center. Ann Emerg Med.
McDermott FT, Rosenfeld JV, Laidlaw JD, et al. (2004). Evaluation of management of road trauma survivors with brain injury and neurologic disability in Victoria. J Trauma.
McGuffie AC, Graham CA, Beard D, et al. (2005). Scottish urban versus rural trauma outcome study. J Trauma.
McGwin G, MacLennan PA, Fife JB, et al. (2004). Preexisting conditions and mortality in older trauma patients. J Trauma.
McMahon CG, Kenny R, Bennett K, et al. (2011). Effect of acute traumatic brain injury on baroreflex function. Shock.
McManus J, Yershov AL, Ludwig D, et al. (2005). Radial pulse character relationships to systolic blood pressure and trauma outcomes. Prehosp Emerg Care.
Meisler R, Thomsen AB, Abildstrom H, et al. (2010). Triage and mortality in 2875 consecutive trauma patients. Acta Anaesthesiol Scand.
Meizoso JP, Valle EJ, Allen CJ, et al. (2015). Decreased mortality after prehospital interventions in severely injured trauma patients. J Trauma Acute Care Surg.
Menakuru SR, Behera A, Jindal R, et al. (2005). Extremity vascular trauma in civilian population: a seven-year review from North India. Injury.
Meredith W, Rutledge R, Fakhry SM, et al. (1998). The conundrum of the Glasgow Coma Scale in intubated patients: a linear regression prediction of the Glasgow verbal score from the Glasgow eye and motor scores. J Trauma.
Meredith W, Rutledge R, Hansen AR, et al. (1995). Field triage of trauma patients based upon the ability to follow commands: a study in 29,573 injured patients. J Trauma.
Metz TD, Abbott JT. (2006). Uterine trauma in pregnancy after motor vehicle crashes with airbag deployment: a 30-case series. J Trauma.
Michetti CP, Hanna R, Crandall JR, et al. (2007). Contemporary analysis of thoracic aortic injury: importance of screening based on crach characteristics. J Trauma.
Mitra B, Cameron P, Butt W. (2007). Population-based study of paediatric head injury. J Paediatr Child Health.
Moore L, Lavoie A, LeSage N, et al. (2006). Statistical validation of the revised trauma score. J Trauma.
Morris DS, Rohrbach J, Sundaram LMT, et al. (2014). Early hospital readmission in the trauma population: are the risk factors different?. Injury.
Motozawa Y, Hitosugi M, Abe T, et al. (2010). Effects of seat belts worn by pregnant drivers during low-impact collisions. Am J Obstet Gynecol.
Mountain D, Sistenich V, Jacobs IG. (2010). Characteristics, management and outcomes of adults with major trauma taking pre-injury warfarin in a Western Australian population from 2000 to 2005: a population-based cohort study. Med J Aust.
Mubang RN, Stoltzfus JC, Cohen MS, et al. (2015). Comorbidity-polypharmacy score as predictor of outcomes in older trauma patients: a retrospective validation study. World J Surg.
Mukherjee K, Rimer M, McConnell MD, et al. (2010). Physiologically focused triage criteria improve utilization of pediatric surgeon-directed trauma teams and reduce costs. J Pediatr Surg.
Mulholland SA, Cameron PA, Gabbe BJ, et al. (2008). Prehospital prediction of the severity of blunt anatomic injury. J Trauma.
Mulholland SA, Gabbe BJ, Cameron P. (2005). Is paramedic judgement useful in prehospital trauma triage?. Injury.
Mutschler M, Nienaber U, Munzberg M, et al. (2014). Assessment of hypovolaemic shock at scene: is the PHTLS classification of hypovolaemic shock really valid?. Emerg Med J.
Nabaweesi R, Arnold MA, Chang DC, et al. (2008). Prehospital predictors of risk for pelvic fractures in pediatric trauma patients. Pediatr Surg Int.
Nabaweesi R, Morlock L, Lule C, et al. (2014). Do prehospital criteria optimally assign injured children to the appropriate level of trauma team activation and emergency department disposition at a level I pediatric trauma center?. Pediatr Surg Int.
Nakahara S, Matsuoka T, Ueno M, et al. (2011). Triage protocol modifications to reduce undertriage. J Trauma.
Nakahara S, Matsuoka T, Ueno M, et al. (2010). Predictive factors for undertriage among severe blunt trauma patients: what enables them to slip through an established trauma triage protocol?. J Trauma.
Nakamura Y, Daya M, Bulger EM, et al. (2012). Evaluating age in the field triage of injured persons. Ann Emerg Med.
Namiki J, Yamazaki M, Funabiki T, et al. (2011). Inaccuracy and misjudged factors of Glasgow Coma Scale scores when assessed by inexperienced physicians. Clin Neurol Neurosurg.
Narayan RK, Michel ME, Ansell B, et al. (2002). Clinical trials in head injury. J Neurotrauma.
Narci A, Solak O, Turhan-Haktanir N, et al. (2009). The prognostic importance of trauma scoring systems in pediatric patients. Pediatr Surg Int.
Nathens AB, Maier RV, Brundage SI, et al. (2003). The effect of interfacility transfer on outcome in an urban trauma system. J Trauma.
Newgard C, Mullins R, Hedges J, et al. (2007). Establishing the need for trauma center care: anatomic injury or resource utilization?...2007 Society for Academic Emergency Medicine annual meeting. Acad Emerg Med.
Newgard C, Zive D, Rea T, et al. (2010). 85: A multi-site assessment and validation of the ACSCOT trauma triage criteria for identifying seriously injured children and adults. Ann Emerg Med.
Newgard CD, Holmes JF, Haukoos JS, et al. (2016). Improving early identification of the high-risk elderly trauma patient by emergency medical services. Injury.
Newgard CD, Cudnik M, Warden CR, et al. (2007). The predictive value and appropriate ranges of prehospital physiological parameters for high-risk injured children. Pediatr Emerg Care.
Newgard CD, Hedges JR, Adams A, et al. (2007). Secondary triage: early identification of high-risk trauma patients presenting to non-tertiary hospitals. Prehosp Emerg Care.
Newgard CD, Hedges JR, Diggs B, et al. (2008). Establishing the need for trauma center care: anatomic injury or resource use?. Prehosp Emerg Care.
Newgard CD, Hedges JR, Stone JV, et al. (2005). Derivation of a clinical decision rule to guide the interhospital transfer of patients with blunt traumatic brain injury. Emerg Med J.
Newgard CD, Hsia RY, Mann NC, et al. (2013). The trade-offs in field trauma triage: a multiregion assessment of accuracy metrics and volume shifts associated with different triage strategies. J Trauma Acute Care Surg.
Newgard CD, Hui SH, Griffin A, et al. (2005). Prospective validation of an out-of-hospital decision rule to identify seriously injured children involved in motor vehicle crashes. Acad Emerg Med.
Newgard CD, Lewis RJ, Jolly BT. (2002). Use of out-of-hospital variables to predict severity of injury in pediatric patients involved in motor vehicle crashes. Ann Emerg Med.
Newgard CD, Lewis RJ, Kraus JF, et al. (2005). Seat position and the risk of serious thoracoabdominal injury in lateral motor vehicle crashes. Accid Anal Prev.
Newgard CD, Mann NC, Hsia RY, et al. (2013). Patient choice in the selection of hospitals by 9-1-1 emergency medical services providers in trauma systems. Acad Emerg Med.
Newgard CD, McConnell KJ, Hedges JR. (2006). Variability of trauma transfer practices among non-tertiary care hospital emergency departments. Acad Emerg Med.
Newgard CD, Meier EN, Bulger EM, et al. (2015). Revisiting the “golden hour”: an evaluation of out-of-hospital time in shock and traumatic brain injury. Ann Emerg Med.
Newgard CD, Nelson MJ, Kampp M, et al. (2011). Out-of-hospital decision making and factors influencing the regional distribution of injured patients in a trauma system. J Trauma.
Newgard CD, Richardson D, Holmes JF, et al. (2014). Physiologic field triage criteria for identifying seriously injured older adults. Prehosp Emerg Care.
Newgard CD, Rudser K, Atkins DL, et al. (2009). The availability and use of out-of-hospital physiologic information to identify high-risk injured children in a multisite, population-based cohort. Prehosp Emerg Care.
Newgard CD, Rudser K, Hedges JR, et al. (2010). A critical assessment of the out-of-hospital trauma triage guidelines for physiologic abnormality. J Trauma.
Newgard CD, Schmicker RH, Hedges JR, et al. (2010). Emergency medical services intervals and survival in trauma: assessment of the ‘golden hour’ in a North American prospective cohort. Ann Emerg Med.
Newgard CD, Zive D, Holmes JF, et al. (2011). A multisite assessment of the American College of Surgeons Committee on Trauma field triage decision scheme for identifying seriously injured children and adults. J Am Coll Surg.
Newland C, Belcher T, Bostrom O, et al. (2008). Occupant-to-occupant interaction and impact injury risk in side impact crashes. Stapp Car Crash J.
Newton EJ, Love J. (2007). Acute complications of extremity trauma. Emerg Med Clin North Am.
Nicholl J, Hughes S, Dixon S, et al. (1998). The costs and benefits of paramedic skills in pre-hospital trauma care. Health Technol Assess.
Nichols SD, McCarthy MC, Ekeh AP, et al. (2009). Outcome of cervical near-hanging injuries. J Trauma.
Nirula R, Maier R, Moore E, et al. (2010). Scoop and run to the trauma center or stay and play at the local hospital: hospital transfer's effect on mortality. J Trauma.
Nirula R, Talmor D, Brasel K. (2005). Predicting significant torso trauma. J Trauma.
Nishijima DK, Dager WE, Schrot RJ, et al. (2010). The efficacy of factor VIIa in emergency department patients with warfarin use and traumatic intracranial hemorrhage. Acad Emerg Med.
Nishijima DK, Shahlaie K, Echeverri A, et al. (2012). A clinical decision rule to predict adult patients with traumatic intracranial haemorrhage who do not require intensive care unit admission. Injury.
Nore AK, Ommundsen OE, Steine S. (2001). Tidsskr Nor Laegeforen.
Norwood SH, McAuley CE, Berne JD, et al. (2002). A prehospital Glasgow Coma Scale score < or = 14 accurately predicts the need for full trauma team activation and patient hospitalization after motor vehicle collisions. J Trauma.
Novack TA, Bush BA, Meythaler JM, et al. (2001). Outcome after traumatic brain injury: pathway analysis of contributions from premorbid, injury severity, and recovery variables. Arch Phys Med Rehabil.
Ocak G, Sturms LM, Hoogeveen JM, et al. (2009). Prehospital identification of major trauma patients. Langenbecks Arch Surg.
O'Connor JV, Kufera JA, Kerns TJ, et al. (2009). Crash and occupant predictors of pulmonary contusion. J Trauma.
Odetola FO, Davis MM, Cohn LM, et al. (2009). Interhospital transfer of critically ill and injured children: an evaluation of transfer patterns, resource utilization, and clinical outcomes. J Hosp Med.
Oh EJ, Kim YM, Jegal DW, et al. (2007). Diagnostic value of elecsys S100 as a marker of acute brain injury in the emergency department. J Clin Lab Anal.
O'Reilly GM, Jolley DJ, Cameron PA, et al. (2010). Missing in action: a case study of the application of methods for dealing with missing data to trauma system benchmarking. Acad Emerg Med.
Osifo OD, Iribhogbe P, Idiodi-Thomas H. (2010). Falls from heights: epidemiology and pattern of injury at the accident and emergency centre of the university of Benin Teaching Hospital. Injury.
Osterwalder JJ. (2002). Could a regional trauma system in eastern Switzerland decrease the mortality of blunt polytrauma patients? A prospective cohort study. J Trauma.
Ott MM, Eriksson E, Vanderkolk W, et al. (2010). Antiplatelet and anticoagulation therapies do not increase mortality in the absence of traumatic brain injury. J Trauma.
Otte D, Haasper C, Eis V, et al. (2008). Characteristics of pole impacts to side of passenger cars in European traffic accidents and assessment of injury mechanisms--analysis of German and UK in-depth data. Stapp Car Crash J.
Owings JT, Wisner DH, Battistella FD, et al. (1998). Isolated transient loss of consciousness is an indicator of significant injury. Arch Surg.
Ozyurekoglu T, Napolitano M, Kleinert JM. (2007). Hay baler injuries to the upper extremity. J Trauma.
Paladino L, Subramanian RA, Nabors S, et al. (2010). Triage hyperglycemia as a prognostic indicator of major trauma. J Trauma.
Patel MS, Malinoski DJ, Nguyen XM, et al. (2011). The impact of select chronic diseases on outcomes after trauma: a study from the National Trauma Data Bank. J Am Coll Surg.
Paulson EH, Gerberich SG, Alexander BH, et al. (2006). Fall-related injuries among agricultural household members: regional rural injury study II (RRIS-II). J Occup Environ Med.
Pearson WS, Ovalle F, Faul M, et al. (2012). A review of traumatic brain injury trauma center visits meeting physiologic criteria from the American College of Surgeons Committee on Trauma/Centers for Disease Control and Prevention field triage guidelines. Prehosp Emerg Care.
Petsas A, Waldmann C. (2010). Where should patients with severe traumatic brain injury be managed?: Patients can be safely managed in a nonspecialist center. J Neurosurg Anesthesiol.
Phillips S, Rond PC, Kelly SM, et al. (1996). The failure of triage criteria to identify geriatric patients with trauma: results from the Florida Trauma Triage Study. J Trauma.
Pickering A, Carter J, Hanning I, et al. (2008). Emergency department measurement of urinary S100B in children following head injury: can extracranial injury confound findings?. Emerg Med J.
Pickering A, Cooper K, Harnan S, et al. (2015). Impact of prehospital transfer strategies in major trauma and head injury: systematic review, meta-analysis, and recommendations for study design. J Trauma Acute Care Surg.
Pickering A, Grundy K, Clarke A, et al. (2012). A cohort study of outcomes following head injury among children and young adults in full-time education. Emerg Med J.
Pieske O, Rauscher S, Baur P, et al. (2010). Automatische unfallmelder: erste erfahrungen aus der anwendung (Leitthema). Unfallchirurg.
Pintar FA, Maiman DJ, Yoganandan N. (2007). Injury patterns in side pole crashes. Annu Proc Assoc Adv Automot Med.
Pollak AN, Jones AL, Castillo RC, et al. (2010). The relationship between time to surgical debridement and incidence of infection after open high-energy lower extremity trauma. J Bone Joint Surg Am.
Poltavski D, Muus K. (2005). Factors associated with incidence of “inappropriate” ambulance transport in rural areas in cases of moderate to severe head injury in children. J Rural Health.
Poon WS, Zhu XL, Ng SC, et al. (2005). Predicting one year clinical outcome in traumatic brain injury (TBI) at the beginning of rehabilitation. Acta Neurochir Suppl.
Potoka DA, Schall LC, Ford HR. (2001). Development of a novel age-specific pediatric trauma score. J Pediatr Surg.
Potoka DA, Schall LC, Gardner MJ, et al. (2000). Impact of pediatric trauma centers on mortality in a statewide system. J Trauma.
Pracht EE, Langland-Orban B, Flint L. (2011). Survival advantage for elderly trauma patients treated in a designated trauma center. J Trauma.
Pracht EE, Tepas JJ, Celso BG, et al. (2007). Survival advantage associated with treatment of injury at designated trauma centers: a bivariate probit model with instrumental variables. Med Care Res Rev.
Pracht EE, Tepas JJ, Langland-Orban B, et al. (2008). Do pediatric patients with trauma in Florida have reduced mortality rates when treated in designated trauma centers?. J Pediatr Surg.
Prasad K. (1996). The Glasgow Coma Scale: a critical appraisal of its clinimetric properties. J Clin Epidemiol.
Price TG, Hooker EA, Neubauer J. (2005). Prehospital provider prediction of emergency department disposition: implications for selective diversion. Prehosp Emerg Care.
Prichayudh S, Verananvattna A, Sriussadaporn S, et al. (2009). Management of upper extremity vascular injury: outcome related to the Mangled Extremity Severity Score. World J Surg.
Purtill MA, Benedict K, Hernandez-Boussard T, et al. (2008). Validation of a prehospital trauma triage tool: a 10-year perspective. J Trauma.
Quayle KS, Powell EC, Mahajan P, et al. (2014). Epidemiology of blunt head trauma in children in U.S. emergency departments. N Engl J Med.
Rahbar MH, Fox EE, del Junco DJ, et al. (2012). Coordination and management of multicenter clinical studies in trauma: Experience from the PRospective Observational Multicenter Major Trauma Transfusion (PROMMTT) Study. Resuscitation.
Rainer TH, Houlihan KP, Robertson CE, et al. (1997). An evaluation of paramedic activities in prehospital trauma care. Injury.
Randazzo C, Stolz U, Hodges NL, et al. (2009). Pediatric tree house-related injuries treated in emergency departments in the United States: 1990-2006. Acad Emerg Med.
Raum MR, Nijsten MW, Vogelzang M, et al. (2009). Emergency trauma score: an instrument for early estimation of trauma severity. Crit Care Med.
Rehn M, Eken T, Kruger AJ, et al. (2009). Precision of field triage in patients brought to a trauma centre after introducing trauma team activation guidelines. Scand J Trauma Resusc Emerg Med.
Reisner AT, Chen L, McKenna TM, et al. (2008). Automatically-computed prehospital severity scores are equivalent to scores based on medic documentation. J Trauma.
Reith FC, Brennan PM, Maas AI, et al. (2016). Lack of standardization in the use of the Glasgow Coma Scale: results of international surveys. J Neurotrauma.
Reith FC, Van den Brande R, Synnot A, et al. (2016). The reliability of the Glasgow Coma Scale: a systematic review. Intensive Care Med.
Remick KN, Schwab CW, Smith BP, et al. (2014). Defining the optimal time to the operating room may salvage early trauma deaths. J Trauma Acute Care Surgery.
Rhee P, Kuncir EJ, Johnson L, et al. (2006). Cervical spine injury is highly dependent on the mechanism of injury following blunt and penetrating assault. J Trauma.
Richmond TS, Kauder D, Strumpf N, et al. (2002). Characteristics and outcomes of serious traumatic injury in older adults. J Am Geriatr Soc.
Rickards CA, Ryan KL, Ludwig DA, et al. (2010). Is heart period variability associated with the administration of lifesaving interventions in individual prehospital trauma patients with normal standard vital signs?. Crit Care Med.
Ringburg AN, de Ronde G, Thomas SH, et al. (2009). Validity of helicopter emergency medical services dispatch criteria for traumatic injuries: a systematic review. Prehosp Emerg Care.
Ringburg AN, Frissen IN, Spanjersberg WR, et al. (2005). Physician-staffed HEMS dispatch in the Netherlands: adequate deployment or minimal utilization?. Air Med J.
Rivara FP, Koepsell TD, Wang J, et al. (2008). Outcomes of trauma patients after transfer to a level I trauma center. J Trauma.
Robertson BD. (2010). Differences in service delivery and patient outcome between rural and urban areas: the case of traumatic brain injury at a level I pediatric trauma center in North Texas. Dissertation Abstracts International Section A: Humanities and Social Sciences.
Rogers FB, Osler T, Krasne M, et al. (2012). Has TRISS become an anachronism? A comparison of mortality between the National Trauma Data Bank and Major Trauma Outcome Study databases. JTrauma Acute Care Surg.
Rogers FB, Osler T, Lee JC, et al. (2011). In a Mature Trauma System, There Is No Difference in Outcome (Survival) Between Level I and Level II Trauma Centers. J Trauma.
Rogers FB, Osler TM, Shackford SR, et al. (1999). Study of the outcome of patients transferred to a level I hospital after stabilization at an outlying hospital in a rural setting. J Trauma.
Ronning P, Gunstad PO, Skaga N-O, et al. (2015). The impact of blood ethanol concentration on the classification of head injury severity in traumatic brain injury. Brain Injury.
Ross DW, Caputo LM, Salottolo KM, et al. (2016). Lights and siren transport and the need for hospital intervention in trauma patients. Prehosp Emerg Care.
Ross DW, Rewers A, Homan MB, et al. (2012). Factors associated with the interfacility transfer of the pediatric trauma patient: implications for prehospital triage. Pediatr Emerg Care.
(2005). Routine early corticosteroid infusion increases death rate after serious head injury. Evidence-Based Healthcare and Public Health.
Rouxel JP, Tazarourte K, Le Moigno S, et al. (2004). Anns Fr Anesth Reanim.
Rovlias A, Kotsou S. (2004). Classification and regression tree for prediction of outcome after severe head injury using simple clinical and laboratory variables. J Neurotrauma.
Rowley G, Fielding K. (1991). Reliability and accuracy of the Glasgow Coma Scale with experienced and inexperienced users. Lancet.
Ruffolo DC. (2009). Trauma care and managing the injured pregnant patient. J Obstet Gynecol Neonatal Nurs.
Rush RM, Beekley AC, Puttler EG, et al. (2009). The mangled extremity. Curr Probl Surg.
Rush RM, Kjorstad R, Starnes BW, et al. (2007). Application of the mangled extremity severity score in a combat setting. Mil Med.
Rusnak M, Janciak I, Majdan M, et al. (2007). Severe traumatic brain injury in Austria I: introduction to the study. Wien Klin Wochenschr.
Ryb GE, Dischinger PC. (2011). Scene mobility status as a predictor of injury severity and mortality due to vehicular crashes. J Trauma.
Ryb GE, Dischinger PC. (2011). Disparities in trauma center access of older injured motor vehicular crash occupants. J Trauma.
Ryb GE, Dischinger PC, Braver ER, et al. (2009). Expected differences and unexpected commonalities in mortality, injury severity, and injury patterns between near versus far occupants of side impact crashes. J Trauma.
Sadaka F, Patel D, Lakshmanan R. (2012). The FOUR score predicts outcome in patients after traumatic brain injury. Neurocritical care.
Sagraves SG, Newell MA, Bard MR, et al. (2009). Tissue oxygenation monitoring in the field: a new EMS vital sign. J Trauma.
Sagraves SG, Phade SV, Spain T, et al. (2007). A collaborative systems approach to rural burn care. J Burn Care Res.
Salvucci JA. (2011). Literature review: helicopter transport and mortality. EMS World.
Salvucci JA. (2012). Literature review: undertriage by age. EMS World.
Sampalis JS, Denis R, Frechette P, et al. (1997). Direct transport to tertiary trauma centers versus transfer from lower level facilities: impact on mortality and morbidity among patients with major trauma. J Trauma.
Sampalis JS, Nathanson R, Vaillancourt J, et al. (2009). Assessment of mortality in older trauma patients sustaining injuries from falls or motor vehicle collisions treated in regional level I trauma centers. Ann Surg.
Saniova B, Drobny M, Drobna E, et al. (2012). Acute consciousness disorders in intensive care medicine - value of its grading for prognostic conclusion. Neuroendocrinol Lett.
Sartorius D, Le Manach Y, David JS, et al. (2010). Mechanism, Glasgow Coma Scale, age, and arterial pressure (MGAP): a new simple prehospital triage score to predict mortality in trauma patients. Crit Care Med.
Savitsky E, Rodenberg H. (1995). Prediction of the intensity of patient care in prehospital helicopter transport: use of the revised trauma score. Aviat Space Environ Med.
Savolainen P, Mannering F. (2007). Probabilistic models of motorcyclists' injury severities in single- and multi-vehicle crashes. Accid Anal Prev.
Sawauchi S, Murakami S, Ogawa T, et al. (2007). No Shinkei Geka.
Scarborough K, Slone DS, Uribe P, et al. (2008). Reduced mortality at a community hospital trauma center: the impact of changing trauma level designation from II to I. Arch Surg.
Scheetz LJ. (2005). Relationship of age, injury severity, injury type, comorbid conditions, level of care, and survival among older motor vehicle trauma patients. Res Nurs Health.
Scheetz LJ. (2010). Prehospital factors associated with severe injury in older adults. Injury.
Scheetz LJ. (2011). Trends in the accuracy of older person trauma triage from 2004 to 2008. Prehosp Emerg Care.
Scheyerer MJ, Dutschler J, Billeter A, et al. (2014). Effect of elevated serum alcohol level on the outcome of severely injured patients. Emerg Med J.
Schiff JS, Moore B, Louie J. (2005). Pediatric trauma--unique considerations in evaluating and treating children. Minn Med.
Schiff MA, Holt VL. (2005). Pregnancy outcomes following hospitalization for motor vehicle crashes in Washington State from 1989 to 2001. Am J Epidemiol.
Schiff MA, Mack CD, Kaufman RP, et al. (2010). The effect of air bags on pregnancy outcomes in Washington State: 2002-2005. Obstet Gynecol.
Schiff MA, Tencer AF, Mack CD. (2008). Risk factors for pelvic fractures in lateral impact motor vehicle crashes. Accid Anal Prev.
Schmidt MJ, Handel D, Lindsell CJ, et al. (2006). Evaluating an emergency medical services-initiated nontransport system. Prehosp Emerg Care.
Schulman CI, Wilbur V, Leibowitz B, et al. (2007). The scenescore for improved pre-hospital triage of motor-vehicle crash victims. Annu Proc Assoc Adv Automot Med.
Seel RT, Kreutzer JS. (2003). Depression assessment after traumatic brain injury: an empirically based classification method. Arch Phys Med Rehabil.
Seid M, Azazh A, Enquselassie F, et al. (2015). Injury characteristics and outcome of road traffic accident among victims at adult emergency department of Tikur Anbessa Specialized Hospital, Addis Ababa, Ethiopia: a prospective hospital based study. BMC Emerg Med.
Sethi D, Aljunid S, Saperi SB, et al. (2002). Comparison of the effectiveness of major trauma services provided by tertiary and secondary hospitals in Malaysia. J Trauma.
Shackford SR. (2011). Prehospital fluid resuscitation of known or suspected traumatic brain injury. J Trauma.
Shackford SR, Bourguignon PR, Wald SL, et al. (1998). Hypertonic saline resuscitation of patients with head injury: a prospective, randomized clinical trial. J Trauma.
Shafi S, Ahn C, Parks J, et al. (2010). Quality of care within a trauma center is not altered by injury type. J Trauma.
Shafi S, Friese R, Gentilello LM. (2008). Moving beyond personnel and process: a case for incorporating outcome measures in the trauma center designation process. Arch Surg.
Shah MI. (2010). Prehospital management of pediatric trauma. Clin Pediatr Emerg Med.
Shah S, Muncer SJ. (2003). A comparison of rehabilitation outcome measures for traumatic brain injury. OTJR.
Shahin H, Gopinath SP, Robertson CS. (2010). Influence of alcohol on early Glasgow Coma Scale in head-injured patients. J Trauma.
Shapiro MJ, McCormack JE, Jen J. (2008). Let the surgeon sleep: trauma team activation for severe hypotension. J Trauma.
Sharma OP, Oswanski MF, Rabbi J, et al. (2008). Pelvic fracture risk assessment on admission. Am Surg.
Shavit I, Grant VJ, Kramsky A, et al. (2009). A comparison of two mechanisms of severe paediatric injury in Northern Israel. Injury.
Shaw GJ, Jauch EC, Zemlan FP. (2002). Serum cleaved tau protein levels and clinical outcome in adult patients with closed head injury. Ann Emerg Med.
Shawhan RR, McVay DP, Casey L, et al. (2015). A simplified trauma triage system safely reduces overtriage and improves provider satisfaction: a prospective study. Am J Surg.
Shifflette VK, Lorenzo M, Mangram AJ, et al. (2010). Should age be a factor to change from a level II to a level I trauma activation?. J Trauma.
Shiozaki T, Sugimoto H, Taneda M, et al. (1998). Selection of severely head injured patients for mild hypothermia therapy. J Neurosurg.
Shoqirat N. (2006). Nursing students' understanding of the Glasgow Coma Scale. Nurs Stand.
Shores EA, Lammel A, Hullick C, et al. (2008). The diagnostic accuracy of the Revised Westmead PTA scale as an adjunct to the Glasgow Coma Scale in the early identification of cognitive impairment in patients with mild traumatic brain injury. J Neurol Neurosurg Psychiatry.
Sihler KC, Hemmila MR. (2009). Injuries in nonurban areas are associated with increased disability at hospital discharge. J Trauma.
Sikic M, Mikocka-Walus AA, Gabbe BJ, et al. (2009). Bicycling injuries and mortality in Victoria, 2001-2006. Med J Aust.
Silka PA, Geiderman JM, Kim JY. (2001). Diversion of ALS ambulances: characteristics, causes, and effects in a large urban system. Prehosp Emerg Care.
Simmons E, Hedges JR, Irwin L, et al. (1995). Paramedic injury severity perception can aid trauma triage. Ann Emerg Med.
Simons R, Brasher P, Taulu T, et al. (2010). A population-based analysis of injury-related deaths and access to trauma care in rural-remote Northwest British Columbia. J Trauma.
Sloan EP, Koenigsberg M, Clark JM, et al. (2012). The use of the revised trauma score as an entry criterion in traumatic hemorrhagic shock studies: data from the DCLHb clinical trials. Prehospital Disaster Med.
Smith HL, Sidwell RA. (2013). Trauma patients over-triaged to helicopter transport in an established Midwestern state trauma system. J Rural Health.
Smith J, Caldwell E, Sugrue M. (2005). Difference in trauma team activation criteria between hospitals within the same region. Emerg Med Australas.
Snoek A, Dekker M, Lagrand T, et al. (2013). A clinical decision model identifies patients at risk for delayed diagnosed injuries after high-energy trauma. Eur J Emerg Med.
Sokol KK, Black GE, Azarow KS, et al. (2015). Prehospital interventions in severely injured pediatric patients: rethinking the ABCs. J Trauma Acute Care Surg.
Sola JE, Cheung MC, Yang R, et al. (2009). Pediatric FAST and elevated liver transaminases: an effective screening tool in blunt abdominal trauma. J Surg Res.
Spain DA, Bellino M, Kopelman A, et al. (2007). Requests for 692 transfers to an academic level I trauma center: implications of the Emergency Medical Treatment and Active Labor Act. J Trauma.
Spaniolas K, Cheng JD, Gestring ML, et al. (2010). Ground level falls are associated with significant mortality in elderly patients. J Trauma.
Sperry JL, Gentilello LM, Minei JP, et al. (2006). Waiting for the patient to “sober up”: effect of alcohol intoxication on Glasgow Coma Scale score of brain injured patients. J Trauma.
Spiguel L, Glynn L, Liu D, et al. (2006). Pediatric pelvic fractures: a marker for injury severity. Am Surg.
Sporer KA, Solares M, Durant EJ, et al. (2013). Accuracy of the initial diagnosis among patients with an acutely altered mental status. Emerg Med J.
Staff T, Eken T, Wik L, et al. (2014). Physiologic, demographic and mechanistic factors predicting New Injury Severity Score (NISS) in motor vehicle accident victims. Injury.
Stanic-Canji D, Popovic N, Draskovic B, et al. (2007). Srpski Arhiv Za Celokupno Lekarstvo.
Staudenmayer KL, Hsia RY, Mann NC, et al. (2013). Triage of elderly trauma patients: a population-based perspective. J Am Coll Surg.
Stead LG, Wijdicks EF, Bhagra A, et al. (2009). Validation of a new coma scale, the FOUR score, in the emergency department. Neurocrit Care.
Stein SC, Spettell C. (1995). The head injury severity scale (HISS): a practical classification of closed-head injury. Brain Inj.
Stewart KE, Cowan LD, Thompson DM, et al. (2011). Association of direct helicopter versus ground transport and in-hospital mortality in trauma patients: a propensity score analysis. Acad Emerg Med.
Strnad M, Lesjak VB, Vujanović V, et al. (2015). Predictors of mortality and prehospital monitoring limitations in blunt trauma patients. Biomed Res Int.
Stuke LE, Duchesne JC, Greiffenstein P, et al. (2013). Not all mechanisms are created equal: a single-center experience with the national guidelines for field triage of injured patients. J Trauma Acute Care Surg.
Sturms LM, Hoogeveen JM, Le Cessie S, et al. (2006). Prehospital triage and survival of major trauma patients in a Dutch regional trauma system: relevance of trauma registry. Langenbecks Arch Surg.
Subbe CP, Slater A, Menon D, et al. (2006). Validation of physiological scoring systems in the accident and emergency department. Emerg Med J.
Sugerman DE, Xu L, Pearson WS, et al. (2012). Patients with severe traumatic brain injury transferred to a level I or II trauma center: United States, 2007 to 2009. J Trauma Acute Care Surg.
Sugimoto K, Aruga T, Hirata M, et al. (1999). Geriatric trauma patients at a suburban level-I trauma center in Japan. Prehosp Disaster Med.
Sukumaran S, Henry JM, Beard D, et al. (2005). Prehospital trauma management: a national study of paramedic activities. Emerg Med J.
Sullivent EE, Faul M, Wald MM. (2011). Reduced mortality in injured adults transported by helicopter emergency medical services. Prehosp Emerg Care.
Talbert S. (2009). Changing physiological status predicts severe injury and need for specialized trauma center resources. J Trauma Nurs.
Talmor D, Legedza AT, Nirula R. (2010). Injury thresholds after motor vehicle crash--important factors for patient triage and vehicle design. Accid Anal Prev.
Talmor D, Thompson KM, Legedza AT, et al. (2006). Predicting severe head injury after light motor vehicle crashes: implications for automatic crash notification systems. Accid Anal Prev.
Talving P, Teixeira PG, Barmparas G, et al. (2010). Motorcycle-related injuries: effect of age on type and severity of injuries and mortality. J Trauma.
Tang A, Hashmi A, Pandit V, et al. (2014). A critical analysis of secondary overtriage to a level I trauma center. J Trauma Acute Care Surg.
Tauber M, Koller H, Moroder P, et al. (2009). Secondary intracranial hemorrhage after mild head injury in patients with low-dose acetylsalicylate acid prophylaxis. J Trauma.
Taussky P, Widmer HR, Takala J, et al. (2008). Outcome after acute traumatic subdural and epidural haematoma in Switzerland: a single-centre experience. Swiss Med Wkly.
Tazarourte K, Atchabahian A, Tourtier JP, et al. (2011). Pre-hospital transcranial Doppler in severe traumatic brain injury: a pilot study. Acta Anaesthesiol Scand.
Templeton J, Oakley PA, MacKenzie G, et al. (2000). A comparison of patient characteristics and survival in two trauma centres located in different countries. Injury.
Tencer AF, Kaufman R, Mack C, et al. (2005). Factors affecting pelvic and thoracic forces in near-side impact crashes: a study of US-NCAP, NASS, and CIREN data. Accid Anal Prev.
Testerman GM. (2009). 300 all-terrain vehicle crashes: an East Tennessee trauma center's experience. Tenn Med.
Tham KY, Seow E, Lau G. (2004). Pattern of injuries in helmeted motorcyclists in Singapore. Emerg Med J.
Thomson DP, Thomas SH. (2003). Guidelines for air medical dispatch. Prehosp Emerg Care.
Tien HC, Jung V, Rizoli SB, et al. (2008). An evaluation of tactical combat casualty care interventions in a combat environment. J Am Coll Surg.
Tiesman H, Young T, Torner JC, et al. (2007). Effects of a rural trauma system on traumatic brain injuries. J Neurotrauma.
Timberlake GA. (1997). Blunt pancreatic trauma: experience at a rural referral center. Am Surg.
Timmons SD, Bee T, Webb S, et al. (2011). Using the abbreviated injury severity and Glasgow Coma Scale scores to predict 2-week mortality after traumatic brain injury. J Trauma.
Ting JY. (2012). Impact of interhospital transfer on outcomes for patients with trauma. J Trauma Acute Care Surg.
Tinkoff GH, O'Connor RE. (2002). Validation of new trauma triage rules for trauma attending response to the emergency department. J Trauma.
Tohira H, Jacobs I, Matsuoka T, et al. (2011). Impact of the version of the abbreviated injury scale on injury severity characterization and quality assessment of trauma care. J Trauma.
Tohme S, Delhumeau C, Zuercher M, et al. (2014). Prehospital risk factors of mortality and impaired consciousness after severe traumatic brain injury: an epidemiological study. Scand J Trauma, Resusc Emerg Med.
Tornetta P, Mostafavi H, Riina J, et al. (1999). Morbidity and mortality in elderly trauma patients. J Trauma.
Tourtier JP, Le Moullec D, Jault P, et al. (2010). Shock index and undertriage. J Trauma.
Tourtier JP, Lenoel A, Trueba F, et al. (2010). Triage of elderly trauma patients. J Trauma.
Tsai SH, Chen WL, Yang CM, et al. (2006). Emergency air medical services for patients with head injury. Surg Neurol.
Tuma M, El-Menyar A, Abdelrahman H, et al. (2014). Prehospital intubation in patients with isolated severe traumatic brain injury: a 4-year observational study. Crit Care Res Pract.
Twijnstra MJ, Moons KG, Simmermacher RK, et al. (2010). Regional trauma system reduces mortality and changes admission rates: a before and after study. Ann Surg.
Udekwu P, Kromhout-Schiro S, Vaslef S, et al. (2004). Glasgow Coma Scale score, mortality, and functional outcome in head-injured patients. J Trauma.
Uleberg O, Vinjevoll OP, Eriksson U, et al. (2007). Overtriage in trauma - what are the causes?. Acta Anaesthesiol Scand.
Vaca FE, Anderson CL, Herrera H, et al. (2009). Crash injury prediction and vehicle damage reporting by paramedics. West J Emerg Med.
Van Camp LA, Delooz HH. (1998). Current trauma scoring systems and their applications. Eur J Emerg Med.
Van Haren RM, Thorson CM, Valle EJ, et al. (2014). Novel prehospital monitor with injury acuity alarm to identify trauma patients who require lifesaving intervention. J Trauma Acute Care Surg.
van Laarhoven JJEM, Lansink KWW, van Heijl M, et al. (2014). Accuracy of the field triage protocol in selecting severely injured patients after high energy trauma. Injury.
Vandromme MJ, Griffin RL, Kerby JD, et al. (2011). Identifying risk for massive transfusion in the relatively normotensive patient: utility of the prehospital shock index. J Trauma.
Vandromme MJ, Griffin RL, Weinberg JA, et al. (2010). Lactate is a better predictor than systolic blood pressure for determining blood requirement and mortality: could prehospital measures improve trauma triage?. J Am Coll Surg.
Viano D, von Holst H, Gordon E. (1997). Serious brain injury from traffic-related causes: priorities for primary prevention. Accid Anal Prev.
Viano DC, Parenteau CS. (2010). Ejection and severe injury risks by crash type and belt use with a focus on rear impacts. Traffic Inj Prev.
Viano DC, Parenteau CS. (2010). Severe injury to near- and far-seated occupants in side impacts by crash severity and belt use. Traffic Inj Prev.
Viano DC, Parenteau CS, Edwards ML. (2007). Rollover injury: effects of near- and far-seating position, belt use, and number of quarter rolls. Traffic Inj Prev.
Vish NL, Powell EC, Wiltsek D, et al. (2005). Pediatric window falls: not just a problem for children in high rises. Inj Prev.
Vivien B, Yeguiayan JM, Le Manach Y, et al. (2012). The motor component does not convey all the mortality prediction capacity of the Glasgow Coma Scale in trauma patients. Am J Emerg Med.
Vos PE, van Voskuilen AC, Beems T, et al. (2001). Evaluation of the Traumatic Coma Data Bank computed tomography classification for severe head injury. J Neurotrauma.
Walker N, Russell RJ, Hodgetts TJ. (2010). British military experience of pre-hospital paediatric trauma in Afghanistan. J R Army Med Corps.
Waterhouse C. (2008). An audit of nurses' conduct and recording of observations using the Glasgow Coma Scale. BJNN.
Weber JM, Jablonski RA, Penrod J. (2010). Missed opportunities: under-detection of trauma in elderly adults involved in motor vehicle crashes. J Emerg Nurs.
Weninger P, Hertz H. (2007). Factors influencing the injury pattern and injury severity after high speed motor vehicle accident--a retrospective study. Resuscitation.
White L, Cudnik M, Werman H. (2011). Can prehospital triage criteria predict clinical outcomes for trauma patients transported by air...2011 Air Medical Transport Conference abstracts scientific assembly, Monday, October 17, 2011. Air Medical Journal.
Wiese MF. (2003). British hospitals and different versions of the Glasgow Coma Scale: telephone survey. BMJ.
Wijdicks EF. (2006). Clinical scales for comatose patients: the Glasgow Coma Scale in historical context and the new FOUR Score. Rev Neurol Dis.
Williams TM, Sadjadi J, Harken AH, et al. (2008). The necessity to assess anticoagulation status in elderly injured patients. J Trauma.
Wolf L. (2006). Triage and early recognition of significant head injury in the geriatric trauma patient. J Emerg Nurs.
Wong DK, Lurie F, Wong LL. (2008). The effects of clopidogrel on elderly traumatic brain injured patients. J Trauma.
Wright DW, Kellermann AL, Hertzberg VS, et al. (2007). ProTECT: a randomized clinical trial of progesterone for acute traumatic brain injury. Ann Emerg Med.
Wright DW, Yeatts SD, Silbergleit R, et al. (2014). Very early administration of progesterone for acute traumatic brain injury. N Engl J Med.
Wu J, Sheng L, Wang S, et al. (2012). Analysis of clinical risk factors associated with the prognosis of severe multiple-trauma patients with acute lung injury. J Emerg Med (0736-4679).
Wuerz R, Taylor J, Smith JS. (1996). Accuracy of trauma triage in patients transported by helicopter. Air Med J.
Yanar H, Demetriades D, Hadjizacharia P, et al. (2007). Pedestrians injured by automobiles: risk factors for cervical spine injuries. J Am Coll Surg.
Yang DB, Yu WH, Dong XQ, et al. (2014). Plasma copeptin level predicts acute traumatic coagulopathy and progressive hemorrhagic injury after traumatic brain injury. Peptides.
Yildiz M, Bozdemir MN, Kilicaslan I, et al. (2012). Elderly trauma: the two years experience of a university-affiliated emergency department. Eur Rev Med Pharmacol Sci.
Yoganandan N, Pintar FA, Zhang J, et al. (2007). Lateral impact injuries with side airbag deployments--a descriptive study. Accid Anal Prev.
Young JS, Bassam D, Cephas GA, et al. (1998). Interhospital versus direct scene transfer of major trauma patients in a rural trauma system. Am Surg.
Yuen MSY, Mann SKF, Chow DHK. (2016). A simplified emergency trauma score for predicting mortality in emergency setting. Nurs Crit Care.
Zafonte RD, Hammond FM, Mann NR, et al. (1996). Relationship between Glasgow Coma Scale and functional outcome. Am J Phys Med Rehabil.
Zalstein S, Danne P, Taylor D, et al. (2010). The victorian major trauma transfer study. Injury.
Zautcke JL, Coker SB, Morris RW, et al. (2002). Geriatric trauma in the state of Illinois: substance use and injury patterns. Am J Emerg Med.
Zechnich AD, Hedges JR, Spackman K, et al. (1995). Applying the trauma triage rule to blunt trauma patients. Acad Emerg Med.
Zhang G, Cao L, Hu J, et al. (2008). A field data analysis of risk factors affecting the injury risks in vehicle-to-pedestrian crashes. Ann Adv Automot Med.