# Appendix C List of Included Studies

Acker SN, Ross JT, Partrick DA, et al. (2014). Glasgow motor scale alone is equivalent to Glasgow Coma Scale at identifying children at risk for serious traumatic brain injury. J Trauma Acute Care Surg.
Al-Salamah MA, McDowell I, Stiell IG, et al. (2004). Initial emergency department trauma scores from the OPALS study: the case for the motor score in blunt trauma. Acad Emerg Med.
Arbabi S, Jurkovich GJ, Wahl WL, et al. (2004). A comparison of prehospital and hospital data in trauma patients. J Trauma.
Beskind DL, Stolz U, Gross A, et al. (2014). A comparison of the prehospital motor component of the Glasgow coma scale (mGCS) to the prehospital total GCS (tGCS) as a prehospital risk adjustment measure for trauma patients. Prehosp Emerg Care.
Bledsoe BE, Casey MJ, Feldman J, et al. (2015). Glasgow Coma Scale Scoring is Often Inaccurate. Prehospital Disaster Med.
Brown JB, Forsythe RM, Stassen NA, et al. (2014). Evidence-based improvement of the National Trauma Triage Protocol: The Glasgow Coma Scale versus Glasgow Coma Scale motor subscale. J Trauma Acute Care Surg.
Caterino JM, Raubenolt A. (2012). The prehospital simplified motor score is as accurate as the prehospital Glasgow coma scale: analysis of a statewide trauma registry. Emerg Med J.
Caterino JM, Raubenolt A, Cudnik MT. (2011). Modification of Glasgow Coma Scale criteria for injured elders. Acad Emerg Med.
Cicero MX, Cross KP. (2013). Predictive value of initial Glasgow coma scale score in pediatric trauma patients. Pediatr Emerg Care.
Corrigan JD, Kreider S, Cuthbert J, et al. (2014). Components of traumatic brain injury severity indices. J Neurotrauma.
Davis DP, Serrano JA, Vilke GM, et al. (2006). The predictive value of field versus arrival Glasgow Coma Scale score and TRISS calculations in moderate-to-severe traumatic brain injury. J Trauma.
Dinh MM, Oliver M, Bein K, et al. (2013). Level of agreement between prehospital and emergency department vital signs in trauma patients. Emerg Med Australas.
Eken C, Kartal M, Bacanli A, et al. (2009). Comparison of the Full Outline of Unresponsiveness Score Coma Scale and the Glasgow Coma Scale in an emergency setting population. Eur J Emerg Med.
Feldman A, Hart KW, Lindsell CJ, et al. (2015). Randomized controlled trial of a scoring aid to improve glasgow coma scale scoring by emergency medical services providers. Ann Emerg Med.
Gill M, Steele R, Windemuth R, et al. (2006). A comparison of five simplified scales to the out-of-hospital Glasgow Coma Scale for the prediction of traumatic brain injury outcomes. Acad Emerg Med.
Gill M, Windemuth R, Steele R, et al. (2005). A comparison of the Glasgow Coma Scale score to simplified alternative scores for the prediction of traumatic brain injury outcomes. Ann Emerg Med.
Haukoos JS, Gill MR, Rabon RE, et al. (2007). Validation of the Simplified Motor Score for the prediction of brain injury outcomes after trauma. Ann Emerg Med.
Healey C, Osler TM, Rogers FB, et al. (2003). Improving the Glasgow Coma Scale score: motor score alone is a better predictor. J Trauma.
Heim C, Schoettker P, Gilliard N, et al. (2009). Knowledge of Glasgow coma scale by air-rescue physicians. Scand J Trauma Resusc Emerg Med.
Holmes JF, Palchak MJ, MacFarlane T, et al. (2005). Performance of the pediatric glasgow coma scale in children with blunt head trauma. Acad Emerg Med.
Johnson DL, Krishnamurthy S. (1996). Send severely head-injured children to a pediatric trauma center. Pediatr Neurosurg.
Kerby JD, MacLennan PA, Burton JN, et al. (2007). Agreement between prehospital and emergency department glasgow coma scores. J Trauma.
Kupas DF, Melnychuk EM, Young AJ. (2016). Glasgow Coma Scale Motor Component (“patient does not follow commands”) performs similarly to Total Glasgow Coma Scale in predicting severe injury in trauma patients. Ann Emerg Med.
Lane PL, Baez AA, Brabson T, et al. (2002). Effectiveness of a Glasgow Coma Scale instructional video for EMS providers. Prehospital Disaster Med.
Leijdesdorff HA, van Dijck JT, Krijnen P, et al. (2014). Injury pattern, hospital triage, and mortality of 1250 patients with severe traumatic brain injury caused by road traffic accidents. J Neurotrauma.
Majdan M, Steyerberg EW, Nieboer D, et al. (2015). Glasgow coma scale motor score and pupillary reaction to predict six-month mortality in patients with traumatic brain injury: comparison of field and admission assessment. J Neurotrauma.
Nesiama JA, Pirallo RG, Lerner EB, et al. (2012). Does a prehospital Glasgow Coma Scale score predict pediatric outcomes?. Pediatr Emerg Care.
Reisner A, Chen X, Kumar K, et al. (2014). Prehospital heart rate and blood pressure increase the positive predictive value of the Glasgow Coma Scale for high-mortality traumatic brain injury. J Neurotrauma.
Ross SE, Leipold C, Terregino C, et al. (1998). Efficacy of the motor component of the Glasgow Coma Scale in trauma triage. J Trauma.
Takahashi C, Okudera H, Origasa H, et al. (2011). A simple and useful coma scale for patients with neurologic emergencies: the Emergency Coma Scale. Am J Emerg Med.
Thompson DO, Hurtado TR, Liao MM, et al. (2011). Validation of the Simplified Motor Score in the out-of-hospital setting for the prediction of outcomes after traumatic brain injury. Ann Emerg Med.
Van de Voorde P, Sabbe M, Rizopoulos D, et al. (2008). Assessing the level of consciousness in children: a plea for the Glasgow Coma Motor subscore. Resuscitation.