# Appendix B Inclusion and Exclusion Criteria

Table B-1 Inclusion and exclusion criteria

| Include | Exclude
Population | Patients with known or suspected trauma. | Nonhuman population, patients without known or suspected trauma, patients transferred from another hospital.
Intervention | GCS motor score (mGCS): Focus on studies of the mGCS using a cutoff score of ≤5 to indicate patients who require high level trauma care, but will include studies that use alternative cutoffs or modifications of mGCS. GCS total score (tGCS): Focus on studies that use a cutoff tGCS score of ≤13 to indicate patients who require high level trauma care, but will include studies that use alternative cutoffs or modifications of tGCS. Potential modifiers: age or other patient characteristics (such as TBI vs. unspecified or other trauma, systolic blood pressure, level of intoxication, type of trauma, or intubation or receipt of medication in the field), the training and background of the person administering the instrument, and the timing/setting of assessment (i.e., in the field vs. upon presentation to the emergency department or urban vs. rural location). | Studies that evaluate the utility of mGCS or tGCS in combination with other predictors, including guidelines and triage criteria.
Comparisons | Main KQs: Head-to-head comparisons of mGCS vs. tGCS Sub KQs: No comparison required | Other measures, comparison of transferred and direct transport patients, or no comparison for main KQs
Outcomes | KQ1: Predictive utility for mortality, morbidity, ISS ≥16, or utilization indicators of severe injury (e.g., receipt of intracranial monitoring within 48 hours of admission, receipt of surgery within 12 hours of admission, or receipt of early intubation [in the field or immediately upon arrival to the ED]), as measured by diagnostic accuracy, adjusted risk estimates, measures of discrimination (e.g., the c-index), measures of calibration (e.g., the Hosmer-Lemeshow test), and risk reclassification rates. KQ2: Over- or under-triage, proportion of patients who are transferred to a higher or lower level of care. KQ3: Clinical outcomes, mortality (prior to hospital arrival, in the emergency department, or after hospital admission); morbidity, including cognitive impairment, and medical complications related to the brain injury; quality of life, including functional capacity at discharge or followup. KQ4: Reliability (e.g., inter-rater and intra-rater kappa); ease of use (e.g., time to complete, measures of missing data, user reported satisfaction). | Costs, prevalence rates.
Timing | Administered soon after injury (in the field) or immediately upon arrival in the emergency department. | After admission to the ICU, after >24 hours in the hospital.
Setting | Out-of-hospital setting (in the field) or immediately upon arrival at the hospital emergency department. | Studies conducted in the ICU or in the developing world.
Study Design | Randomized trials, cohort, and case-control studies. | Case reports, case series, cross-sectional studies, and modeling studies.
Language | English-language abstracts (includes English-language abstracts of non English-language papers) and papers. | Non English-language papers.

ED= emergency department; GCS= Glasgow Coma Scale; ICU= intensive care unit; ISS= injury severity score; KQ= key question; mGCS= motor scale of GCS; TBI= traumatic brain injury; tGCS= total GCS; vs.= versus